# Methods

## Overview

This evidence report on breastfeeding and health outcomes in infants and mothers is based on a systematic review of the literature. To identify the specific issues central to this report, the Tufts-New England Medical Center (Tufts-NEMC) Evidence-based Practice Center (EPC) held teleconferences with a panel of technical experts (TEP) and various stakeholders. A comprehensive search of the medical literature was conducted to identify studies addressing the key questions. Evidence tables of study characteristics and results were compiled, and the methodological quality of the studies was appraised. Study results were summarized with qualitative reviews of the evidence, summary tables, and quantitative summary data, when appropriate.

A number of individuals and groups supported the Tufts-NEMC EPC in preparing this report. The TEP served as our science partner. Technical experts and representatives from the Agency for Healthcare Research and Quality (AHRQ), DHHS Office on Women's Health, The National Institute of Child Health and Human Development (NICHD), Centers for Disease Control and Prevention (CDC), American Academy of Pediatrics (AAP), American College of Obstetrics and Gynecology (ACOG), Association of Women's Health, Obstetrics and Neonatal Nurses (AWHONN), and La Leche League worked with the EPC staff to refine key questions, identify important issues, and define parameters for literature review in this report.

In the early phase of exploring the literature available for this report, it was soon discovered that there was a large number of primary studies and systematic reviews/meta-analyses on the various outcomes of interest. As it was not feasible to review all the primary studies addressing the outcomes of interest, therefore, in consultation with the Office on Women's Health and the TEP, we developed an approach that capitalized on the existing systematic reviews/meta-analyses. For outcomes of interest that had previously been reviewed systematically, we assessed the quality of those reviews and summarized their findings. For selected infant (necrotizing enterocolitis, cognitive development, acute otitis media, asthma, type 1 and 2 diabetes, SIDS) and maternal (weight changes, type 2 diabetes, breast cancer) outcomes, in addition to reporting on the existing systematic reviews, we also updated them by summarizing the relevant primary studies that were published after those reviews. For outcomes of interest (osteoporosis, ovarian cancer, postpartum depression, infant mortality) that had not been reviewed systematically, we reviewed all the relevant primary studies that met our inclusion criteria.

## Key Questions Addressed in This Report

Two key questions are addressed in this report. Question 1 pertains to infant outcomes and question 2 pertains to maternal outcomes. The key questions are:

1 What are the benefits and harms for infants and children in terms of short-term outcomes, such as infectious diseases (including otitis media, diarrhea, and lower respiratory tract infections), sudden infant death syndrome and infant mortality, and longer-term outcomes such as cognitive development, childhood cancer (including leukemia), type 1 and 2 diabetes, asthma, atopic dermatitis, cardiovascular disease (including hypertension), hyperlipidemia, and obesity, compared among those who mostly breastfeed, mostly formula feed, and mixed feed; and how are these outcomes associated with duration of the type of feeding? Do the harms and benefits differ for any specific subpopulations based on socio-demographic factors?
2 What are the benefits and harms on maternal health short-term outcomes, such as postpartum depression and return to pre-pregnancy weight, and long-term outcomes, such as breast cancer, ovarian cancer, type 2 diabetes mellitus and osteoporosis, compared among breastfeeding, formula feeding, and mixed feeding, and how are these associated with duration of the type of feeding? Do the harms and benefits differ for any specific subpopulations based on socio-demographic factors?

It should be emphasized that the focus of this review is on the effects of breast milk feeding, not formula feeding. However, many studies did not distinguish between exclusive and partially breastfed infants; presumably, some of the effects reported from observational studies were from infants who received both breast milk and formula milk feedings. Studies that examined only formula fed infants were not included in this report. Lastly, studies on infant and maternal health outcomes of interventions to promote and support breastfeeding were not systematically covered in this review as that subject will be covered in a separate report. However, our panel of technical experts felt that the study of breastfeeding promotion in infants from Belarus^17^ was a landmark study and offered new directions into research on effects from breast milk that it warrants discussion in this report. The details of that study are described in the section Other Research in the results chapter.

## Definitions of Breastfeeding in This Report

None of the studies in this review explicitly examined the difference between “breastfeeding” an infant (infant suckling at her/his mother's nipple) and “feeding of expressed breast milk” to an infant. To distinguish between the two forms of feedings, we elected to use the term “breastfeeding” when the studies concerned primarily full-term infants (presumably they were, indeed, breastfed) and the term “breast milk feeding” when the studies concerned primarily preterm infants (as most of them received breast milk initially either by gavage- or by bottle-feeding). For term infants, “bottle-feeding” is used synonymously with “formula feeding.”

Definitions of “exclusive breastfeeding” varied widely in the literature. They ranged from “no supplement of any kind including water while breastfeeding” to “occasional formula is permissible while breastfeeding.” We elected to accept all definitions of “exclusive breastfeeding” as provided by the different study authors, but we qualified our findings by the details regarding those definitions.

## Literature Search Strategy

We conducted a comprehensive literature search to address the two key questions. The EPC used the Ovid search engine to conduct searches on the MEDLINE^®^ database, CINAHL database, and the Cochrane Database of Systemic Reviews. A wide variety of search terms were used to capture the many potential sources of information related to the myriad of different outcomes (see Appendix A).^*^ But the different outcomes were always searched in conjunction with the following: “breastfeeding,” “breast milk feeding,” “breast milk,” “human milk,” “nursing”, and “lactation”. Literature search of the outcomes alone without references to breast milk feeding was not conducted. The search included citations from 1966 to November of 2005. Updated searches on selected outcomes took place in April and May of 2006. We also supplemented our computer search by examining the bibliographies of the review articles. We also included articles suggested by reviewers, provided that the articles met the inclusion criteria for this review. For outcomes that were not slated for updates, additional articles suggested by reviewers were also included as an addendum if they provided useful information. We did not make efforts to identify unpublished studies.

* Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/brfouttp.htm

## Study Selection

### Selection of Outcomes for This Review

The TEP offered advice on selection of outcomes for review. Final selection of the list of outcomes for review took into account the following factors: the importance of the outcome, whether a systematic review of the outcome has previously been reported from a developed country, whether the existing systematic review of the outcome is outdated, whether the relationship between breastfeeding and the outcome is thought to be equivocal, whether a large number of primary studies has been published recently on the outcome, and the total number of outcomes that could be adequately reviewed for this report given the time constraint.

We included the following outcomes in this report:

Term infant outcomes: acute otitis media, hospitalization for lower respiratory tract infection, gastrointestinal infection, hypertension, cardiovascular diseases, hyperlipidemia, asthma, atopic dermatitis, type 1 and 2 diabetes, obesity, sudden infant death syndrome (SIDS), infant mortality, cognitive development, and childhood cancer (including leukemia)

Preterm infant outcomes: necrotizing enterocolitis (NEC) and cognitive development

Maternal outcomes: maternal weight changes, breast cancer, ovarian cancer, post-partum depression, osteoporosis, and type 2 diabetes

### Abstract Screening

All abstracts identified through the literature search were screened. At this stage, eligible studies included all English language primary experimental or observational studies that reported any health outcomes in human subjects in relation to a history of breast milk feeding. As the inclusion criteria were broad at this stage, the abstracts rejected at this stage did not undergo a second rescreening process. Abstracts that were accepted at this stage were examined a second time by different reviewers and categorized into the different outcomes of interest.

### Full Article Inclusion/Exclusion Criteria

Articles that passed the abstract screening process were retrieved and the full articles were reviewed for eligibility. Full articles were examined only once unless the articles were equivocal for inclusion or exclusion. In that event, the article in question was screened again by a different reviewer and a consensus was reached after discussion with the first reviewer.

Because the outcomes selected ranged from very broad topic with common occurrence (e.g., non-specific gastrointestinal infection) to a narrowly focused topic with relatively few occurrences (e.g., SIDS), the types of studies available for each outcome varied widely in the distribution of study designs, sample sizes, and quality of breastfeeding data, it was not possible (nor desirable) to design a strict set of inclusion and exclusion criteria that would be applicable to all outcomes. Therefore, additional inclusion/exclusion criteria germane to the specific outcome were also described in the Results section under each outcome.

General inclusion criteria for the studies are as follow:

Study Design. Systematic reviews, experimental (randomized controlled trials) and observational studies (prospective cohort and case-control studies only)

Population. Healthy term infants in developed countries; preterm infants in developed countries (for NEC and cognitive development); healthy mothers in developed countries

Intervention/Exposure. Breastfeeding, breast milk feeding (maternal term and preterm milk, banked term and preterm milk, fortified or unfortified), exclusive or mixed feeding

Comparator. Formula feeding (preterm or term formula, fortified or unfortified)

### Data Extraction and Analysis

For those outcomes that have been subjected to a systematic review/meta-analysis, we summarized their results into our report. In addition to the results from the systematic reviews, we have also extracted and summarized the relevant data from primary studies that were published after the latest search dates of the reports for the following infant and maternal outcomes: acute otitis media, childhood asthma, cognitive development, SIDS, infant mortality, NEC, and maternal breast cancer.

For systematic reviews/meta-analyses that reported data from both developed and developing countries, we reported only those results pertaining to developed countries, if the reported data permitted us to do so. In those instances where that were not possible, we noted that fact as a limitation of our findings.

For outcomes that have multiple systematic reviews, we noted the overlapping studies and examined whether their findings were interpreted similarly or differently across reviews and reported our analyses.

For NEC, maternal weight changes, and acute otitis media, in order to better clarify the overall findings, we also extracted relevant data from the primary studies cited in the systematic reviews and combined them with data from the primary studies that were published after the latest search dates of the reports and reanalyzed the data.

For the remaining included outcomes, we extracted and summarized the relevant data from the primary studies.

Data forms were developed separately for extraction of systematic reviews/meta-analysis and primary studies. For systematic reviews/meta-analysis, items extracted were: databases searched, study design, population characteristics, descriptions of intervention/exposure, models used for meta-analysis, results, and authors' conclusions. We reported the estimates in the meta-analyses. We also reported any attempt by the authors of the meta-analyses to explore heterogeneity using sub-group analyses or meta-regression. For primary studies, items extracted were: study design, population characteristics, eligibility criteria, descriptions of intervention/exposure, any adjustments for confounders, and results.

## Meta-Analysis

We used meta-analysis to expand on the individual studies' findings, if it was appropriate and feasible to do so. Minimal criteria for meta-analysis are comparable groupings, similar study designs, and quantifiable outcome data. Secondary criteria for consideration of meta-analysis are similar study quality, similar statistical adjustment of outcomes, and other factors. Before combining the reported odds ratios or risk ratios reported in the individual studies from the previous meta-analysis with the estimates from the updated primary studies into a new summary odds ratio or risk ratio, we verified the previous reported odds ratios or risk ratios by examining the data from the original studies.

We used the DerSimonian and Laird's random effects model for all meta-analyses.^18^ The random effects model assigns a weight to each study based both on the individual study variance and the between-study heterogeneity. Compared with the fixed effect model, the random effects model is more conservative in that it generally results in broader confidence intervals when between-study heterogeneity is present. We tested for heterogeneity using Cochran's Q and assessed its extent with I^2^, which evaluates the proportion of between study variability that is attributed to heterogeneity rather than chance.^19,^ ^20^ Intercooled Stata 8.2 was used for the calculations and graphics.

## Grading of Studies Analyzed in This Evidence Report

Studies accepted in evidence reports have been designed, conducted, analyzed, and reported with various degrees of methodological rigor and completeness. Deficiencies in any of these processes may lead to biased reporting or interpretation of the results. While it is desirable to have a simple evidence grading system using a single quantity, the quality of evidence is multi-dimensional. A single metric cannot adequately capture information needed to interpret a clinical study. However, grading of information can help the reader to interpret the studies properly.

## Grading of Systematic Reviews/Meta-Analyses

We assessed the methodological quality of studies based on predefined criteria. For the assessment of systematic reviews, the criteria for methodological quality was based on the QUOROM guidelines for meta-analyses and systematic reviews of RCTs (a checklist organized into 21 headings and subheadings for the preferred way to present the abstract, introduction, methods, results, and discussion sections of a report of a meta-analysis),^21^ and reporting guidelines for meta-analysis in observational studies in epidemiology (MOOSE) (a checklist for the specifications for presenting background, search strategy, methods, results, discussion, conclusion, and assessment of quality of individual studies and bias (e.g., publication bias)^a^).^22^ ^b^ As the QUOROM and the MOOSE statements were primarily concerned with the reporting standards of the reviews, we have also supplemented those criteria with our own checklist of items designed to evaluate the quality of the systematic review of observational studies (see Appendix B ^b^ for details). Items in this checklist consisted of questions on appropriate search strategy; justification for inclusion/exclusion criteria; how well-defined were the population, intervention, comparator, outcomes and study design; effort to minimize errors in data extraction; assessment of individual study quality; consideration on the effect of confounders; combinability of the data for meta-analysis; assessment of statistical and clinical heterogeneity; reporting accuracies; and appropriateness of the conclusions based on the reported data.

a Publication bias refers to selective publication of studies according to results. When studies with non-significant or negativeresults are not published, the available studies may overestimate the effect.

b Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/ brfouttp.htm.

We applied a three category summary grading system (A, B, C) to each systematic review/meta-analysis:

A (good)

Category A studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a rigorously conducted systematic review or meta-analysis; clear description of the population, setting, interventions and comparison groups; clear description of the content of the comparison groups; appropriate measurement of outcomes; appropriate statistical assumptions and analytic methods and reporting; appropriate consideration and adjustment for potential confounders; rigorous assessment of individual study quality; no reporting errors; and well-reasoned conclusions based on the data reported.

B (fair/moderate)

Category B studies are susceptible to some bias, but not sufficient to invalidate the results. They do not meet all the criteria in category A because they have some deficiencies, but none of which are likely to cause major biases. The study may have suboptimal adjustment for potential confounders. The study may also be missing information, making it difficult to assess limitations and potential problems.

C (poor)

Category C studies have significant biases that may invalidate the results. The study either did not consider potential confounders or did not adjust for them appropriately. These studies have serious errors in design, analysis or reporting; have large amounts of missing information, or discrepancies in reporting.

It should be noted that while we assessed the methodological quality of the systematic reviews or meta-analyses, it was not possible to evaluate the quality of the primary studies included in those reviews/analyses, as we did not examine those studies first hand. For systematic reviews/meta-analyses that had equivocal grading between moderate and poor, the results and the reasons for the initial grade assignments were presented to the entire group of project investigators and the final grades were adjudicated.

## Grading of Individual Primary Studies in Updates and New Reviews

A well-performed RCT with proper randomization, allocation concealment, clear definitions of breastfeeding exposure compared with non-breastfeeding, and blinded assessment of outcomes will yield the best evidence in supporting the causality of breast milk in affecting health outcomes. But with the recognized benefits of breast milk, this approach is ethically not feasible. Other types of studies involve following the health outcomes from randomization of intervention to promote and support breastfeeding (e.g., Belarus study^17^), this type of study will yield indirect evidence for the relationship between breastfeeding and health outcomes provided that there is a differential effect from the intervention on breastfeeding rates between the comparison groups. Prospective observational cohort studies with proper adjustment of potential confounders provide the bulk of data in this field. However, the possibility of residual confounding that could explain the observed association between breastfeeding and the specific health outcomes can never be completely ruled out. Case-controlled design is an even less attractive option because of the concern for case selection bias and suboptimal matching to control subjects.

For the assessment of RCTs, the criteria were based on the CONSORT statement for reporting RCTs (a checklist with specifications for reporting all aspects of a trial).^23,^ ^24^ We mainly considered the methods used for randomization, allocation concealment, and blinding as well as the use of intention-to-treat analysis, the report of well-described valid primary outcomes, and the dropout rate. For non-randomized trials, we used the report of eligibility criteria and assessed the adequacy of controlling for differences between comparative groups in terms of baseline characteristics and prognostic factors. We also considered the report of intention-to-treat analysis, and the crossovers when so designed, as well as important differential loss to followup between the comparative groups or overall high loss to followup. The validity and the adequate description of outcomes and results were also assessed. For the assessment of prospective cohorts and case-control studies (cross-over design and retrospective cohort studies were excluded from this review), we used a rating checklist largely based on the Newcastle-Ottawa Quality Assessment scales for cohort and case-control studies (www.ohri.ca/programs/clinical_epidemiology/oxford.htm). Items assessed included selection of cases and controls or cohorts, comparability, information concerning exposure/intervention, consideration for potential confounders, and percentage of withdrawals or dropouts. In particular, we paid close attention to the quality of the breastfeeding data, whether they were obtained prospectively or by retrospective recall, whether a distinction was made between exclusive and partial breastfeeding, and whether the duration of breastfeeding was reported. We also paid close attention to consideration of and appropriate adjustment for potential confounders.

We applied a three category summary grading system (A, B, C) to each study. This system defines a generic grading system that is applicable to each type of study design including randomized controlled trials, cohort, and case-control studies:

A (good)

Category A studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: clear description of the population, setting, interventions and comparison groups; clear description of the comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20 percent dropout; clear reporting of dropouts; and appropriate consideration and adjustment for potential confounders.

B (fair/moderate)

Category B studies are susceptible to some bias, but not sufficient to invalidate the results. They do not meet all the criteria in category A because they have some deficiencies, but none of which are likely to cause major biases. The study may have suboptimal adjustment for potential confounders. The study may also be missing information, making it difficult to assess limitations and potential problems.

C (poor)

Category C studies have significant biases that may invalidate the results. The study either did not consider potential confounders or did not adjust for them appropriately. These studies have serious errors in design, analysis or reporting; have large amounts of missing information, or discrepancies in reporting.

For primary studies that had equivocal grading between moderate and poor, those studies were reviewed and graded again by different reviewers and consensus was reached after discussion among the reviewers. Lastly, it should be noted that the summary quality grading system evaluates and grades the studies within their own design strata. It does not attempt to assess the comparative validity of studies across different design strata. Thus, one should be cognizant of the study design when interpreting the methodological quality grade of a study.

## Reporting of the Evidence

We reported each outcome separately in its own section in the results chapter. A brief explanation of the importance of the outcome is followed by a description of inclusion/exclusion criteria of studies examined that are specific to that outcome. A description of the relevant systematic review is followed by a description of the primary studies that were published after the latest search date of the systematic review. A summary table highlighted important findings. A summary conclusion regarding breast milk and that particular outcome is made in the last section. Conclusions were drawn only from studies of high or moderate (grade A or B) methodological quality. For dichotomous outcome, either the summary risk ratio or odds ratio is reported. For continuous outcome, the comparative difference in the actual measurement for that outcome is reported (e.g., IQ points, mm Hg of blood pressure). When only studies of C quality are available, we summarize the findings from those studies and explain the reasons for the "C' rating, but we do not draw conclusions from them.

Extracted data are compiled in evidence tables. The tables offer a detailed description of the studies that addressed each of the key questions. The tables (see Appendix C)^a^ provide detailed information about the study design, the sample size, the patient characteristics, the intervention and comparison group feeding methods, the followup, the major outcomes, and the methodological quality. In addition, for systematic reviews and meta-analyses, we reported the databases searched and for which time period, the number and the type of primary studies included, and the type of comparison addressed.

a Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/ brfouttp.htm.

Summary tables succinctly report summary measures of the main outcomes evaluated. They include information regarding study design, intervention and comparison group, feeding methods, study duration or followup, sample size (subjects enrolled and analyzed in each arm), potential confounders, results of major outcomes, and methodological quality. These tables were developed by condensing information from the evidence tables. They are designed to facilitate comparisons and synthesis across studies. A methodological quality was assigned to each study as described previously.