# Introduction

The Department of Health and Human Services (DHHS) Office on Women's Health has requested an evidence report from the Agency for Healthcare Research and Quality (AHRQ) through the Evidence-based Practice Center program (EPC) that would critically examine the literature concerning the relationship of breastfeeding and various infant and maternal health outcomes. EPC evidence reports summarize evidence addressing specific key questions; these reports do not make clinical practice or health policy recommendations.

Breast milk is the natural nutrition for all infants. According to the American Academy of Pediatrics (AAP), it is the preferred choice of feeding for all infants.^1^ The goals of Healthy People 2010 for breastfeeding are an initiation rate of 75 percent and continuation of breastfeeding of 50 percent at 6 months and 25 percent at 12 months postpartum.^2^ National Immunization Survey of U.S. children in 2005 (NIS 2005) indicated that 73 percent had ever been breastfed. The percentage of infants who continued to breastfeed to some extent is 39 percent at 6 months and 20 percent at 12 months (www.cdc.gov/breastfeeding/data/NIS_data/ data_2005.htm).

In addition to providing essential nutrients to infants, benefits of breastfeeding for both children and their mothers have been reported. Reports of the benefits for children include decreases in incidence of otitis media and gastroenteritis,^3^ lower risk of obesity,^4,^ ^5^ and lower risk of asthma.^6^ Other benefits reported include decreased rates of sudden infant death syndrome, reduction in the incidence of type 1 and type 2 diabetes mellitus, certain types of cancer, and improved performance on certain tests of cognitive development.^7^

Reported benefits for mothers who breastfed their infants include increased postpartum uterine activity (inferentially this would lead to reduced postpartum blood loss),^8^ greater weight loss postpartum compared with mothers who bottle-fed their infants,^9^ decreased incidence of premenopausal breast cancer^10^ and decreased incidence of ovarian cancer.^11^

In 2000, the DHHS Office on Women's Health, in cooperation with the Surgeon General of the United States and several governmental and non-governmental agencies, published the first departmental policy on breastfeeding, the HHS Blueprint for Action on Breastfeeding (www.womenshealth.gov). The DHHS Office on Women's Health endorses the recommendation from the American Academy of Pediatrics (AAP), American Academy of Family Physicians (AAFP), American College of Obstetricians and Gynecologists (ACOG), Association of Women's Health, Obstetrical, and Neonatal Nurses (AWHONN), Le Leche League International, National Medical Association (NMA), and many other health organizations, that mothers exclusively breastfeed for 6 months. The DHHS Office on Women's Health has commissioned a review to systematically examine the evidence for the effects of breastfeeding. The DHHS Office on Women's Health has also requested that the focus of the review be on studies from developed countries (i.e., “high income” classification by World Bank)^*^ as the findings from those studies are deemed more directly applicable to population in this country.

* http://web.worldbank.org/WBSITE/EXTERNAL/DATASTATISTICS/0,,contentMDK:20421402~pagePK:64133150~piPK:64133175~theSitePK:239419,00.html#High_income

As it is unethical to randomize subjects into breastfeeding versus non-breastfeeding groups (although there were some randomized controlled trials (RCTs) in the 1980s on preterm infants whose mothers desired not to breastfeed, their infants were randomized into those who received donor breast milk versus those who received preterm formula^12,^ ^13^), much of the evidence on the benefits of breastfeeding came from observational studies. Observational studies are subject to confounding. One of the well-known confounders in breastfeeding research is demographic difference between mothers who breastfeed and those who chose not to breastfeed due to self-selection. Consistent with previously reported data,^14^ NIS 2005 showed that mothers who breastfeed tend to be white (versus non-Hispanic black or African American), older, more educated, and in a higher socioeconomic stratum (www.cdc.gov/breastfeeding/data/NIS_data/ data_2005.htm). While it is possible to control for some of these demographic factors, it is not possible to control for behavioral or attitudinal factors intrinsic in the desire to breastfeed. Some authors have proposed strict standards in evaluating the quality of observational studies. These standards should include the quality of the feeding data, a clear definition of the outcome, the elimination of systematic differences in outcome assessment between comparison groups (detection bias), and the control of potential and well-known confounders. The feeding data should clearly define whether it was prospectively or retrospectively collected, whether there was a precise definition of exclusive breastfeeding, and whether the duration of breastfeeding was reported.^15,^ ^16^

Large number of infant and maternal outcomes has been examined in relation to a history of breastfeeding. It was not feasible to review all possible outcomes in mothers and children for this report; we sought guidance from our panel of technical experts in the field of breastfeeding research in deciding on the specific outcomes to review. After taking into consideration the following factors: relevance and importance of outcome in a developed country, date (recent or old) of the last systematic review on the outcome, availability or non-availability of data from a developed country, consistency or inconsistency of outcomes in previously reported studies, and consideration of the possibility that breastfeeding may have potential harms as well as benefits, the following outcomes from developed countries have been designated for review: for term infants, infectious diseases (including otitis media, diarrhea, and lower respiratory tract infections), sudden infant death syndrome, infant mortality, cognitive development, childhood cancer (including leukemia), type 1 and 2 diabetes, asthma, atopic dermatitis, cardiovascular disease (including hypertension), hyperlipidemia, and obesity; for preterm infants, necrotizing enterocolitis (NEC) and cognitive development; for mothers, post-partum depression, return to pre-pregnancy weight, breast cancer, ovarian cancer, diabetes and osteoporosis.

It is also outside the scope of this report to examine the biological mechanisms underpinning the effects of breast milk and therefore, studies on individual components of breast milk will not be part of this report. Lastly, studies on the effectiveness of interventions to promote and support breastfeeding are not systematically covered in this review, as this topic will be reviewed for a subsequent report. However, there is good quality evidence to support that some of these interventions do lead to an increase in breastfeeding rates and also an improvement of certain health outcomes in the study populations. Details of one landmark study^17^ and its implications for future research in the study of the effects of breastfeeding will be discussed in some details in this report.