# Appendix E. Peer Reviewers

The peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers. The authors gratefully acknowledge the peer reviewers.

David Atkins, MD, MPH | Pamela D. Hill, PhD, RN, CBE, FAAN
Chief Medical Officer | Professor
Center for Outcomes and Evidence | College of Nursing
Agency for Healthcare Research and Quality | University of Illinois at Chicago
Rockville, Maryland | Director, Quad Cities Regional Program
| Moline, Illinois
Lawrence M. Gartner, MD | International Formula Council
Professor Emeritus | Atlanta, Georgia
Departments of Pediatrics and Obstetrics/Gynecology | Peer Reviewers
The University of Chicago | Russell Merritt, MD, PhD, FAAP
Chicago, Illinois | Carol Lynn Berseth, MD, FAAP
| Jose Saavedra, MD, FAAP
Representative for the American Academy of Pediatrics | John Wallingford, PhD
Jeanne-Marie Guise, MD, MPH | Nanette Pazdernik, PhD
Associate Professor | Center for Breastfeeding Information
Director of Clinical Research | La Leche League International
Division of General Obstetrics & Gynecology | Schaumberg, Illinois
Oregon Health and Science University
Portland, Oregon
Jane Heinig, PhD, IBCLC | Laurie P. Shornick, PhD
Academic Administrator | Assistant Professor
Department of Nutrition | Department of Biology
Director, Human Lactation Center | Saint Louis University
University of California, Davis | St. Louis, Missouri