# Appendix D. List of Excluded Studies

## References

AbouSaleh MT, Ghubash R, Karim L, et al. Hormonal aspects of postpartum depression. Psychoneuroendocrinology. Jul. 1998;23(5):465-75. Developing country. [pmid: 9802121].
AbuSabha R, Greene G. Body weight, body composition, and energy intake changes in breastfeeding mothers. J Hum Lact. Jun. 1998;14(2):119-24. Non-comparative study. [pmid: 9775844].
Adair LS, Pollitt E, Mueller WH. Maternal anthropometric changes during pregnancy and lactation in a rural Taiwanese population. Hum Biol. Dec. 1983;55(4):771-87. Non-comparative study. [pmid: 6674101].
Affinito P, Tommaselli GA, di Carlo C, et al. Changes in bone mineral density and calcium metabolism in breastfeeding women: a one year follow-up study. J Clin Endocrinol Metab. Jun. 1996;81(6):2314-8. Less than 1 year follow-up. [pmid: 8964870].
Alder E, Bancroft J. The relationship between breast feeding persistence, sexuality and mood in postpartum women. Psychol Med. May. 1988;18(2):389-96. N<100. [pmid: 3399590].
Alder EM, Cox JL. Breast feeding and post-natal depression. J Psychosom Res. 1983;27(2):139-44. N<100. [pmid: 6864598].
Alm B, Wennergren G, Norvenius SG, et al. Breast feeding and the sudden infant death syndrome in Scandinavia. Arch Dis Child. June. 2002;86(6):400-2. Included in MA. [pmid: 12023166]. [pmcid: 1762985].
Andreev A, Arjas E. Acute middle ear infection in small children: a Bayesian analysis using multiple time scales. Lifetime Data Anal. 1998;4(2):121-37. Not relevant. [pmid: 9658771].
Aniansson G, Svensson H, Becker M, et al. Otitis media and feeding with breast milk of children with cleft palate. Scand J Plast Reconstr Surg Hand Surg. 2002;36(1):9-15. Otitis media in children with cleft palate. [pmid: 11925834].
Atalah E, Lagos I, Grez M, et al. [Effect of lactation on the weight and body composition of wet nurses]. [Spanish]. Archivos Latinoamericanos de Nutricion. Sep. 1983;33(3):649-63. Non-English language publication. [pmid: 6675554].
Auestad N, Scott DT, Janowsky JS, et al. Visual, cognitive, and language assessments at 39 months: a follow-up study of children fed formulas containing long-chain polyunsaturated fatty acids to 1 year of age. Pediatrics. Sep. 2003;112(3 Pt 1):e177-e183. Not relevant. [pmid: 12949309].
Barbosa L, Butte NF, Villalpando S, et al. Maternal energy balance and lactation performance of Mesoamerindians as a function of body mass index. Am J Clin Nutr. Sep. 1997;66(3):575-83. Not relevant. [pmid: 9280176].
Bastian LA, West NA, Corcoran C, et al. Number of children and the risk of obesity in older women. Prev Med. Jan. 2005;40(1):99-104. Case control study. [pmid: 15530586].
Batstra L, Neeleman J, Hadders-Algra M. Can breast feeding modify the adverse effects of smoking during pregnancy on the child's cognitive development?. J Epidemiol Community Health. Jun. 2003;57(6):403-4. Not relevant. [pmid: 12775783]. [pmcid: 1732491].
Bauer DC, Browner WS, Cauley JA, et al. Factors associated with appendicular bone mass in older women. The Study of Osteoporotic Fractures Research Group.[see comment]. Ann Intern Med. May 1. 1993;118(9):657-65. Cross-sectional study. [pmid: 8460853].
Becher H, Schmidt S, ChangClaude J. Reproductive factors and familial predisposition for breast cancer by age 50 years. A case-control-family study for assessing main effects and possible gene-environment interaction.[see comment]. Int J Epidemiol. Feb. 2003;32(1):38-48. Included in MA. [pmid: 12690006].
Bjorkelund C, Lissner L, Andersson S, et al. Reproductive history in relation to relative weight and fat distribution. Int J Obes Relat Metab Disord. Mar. 1996;20(3):213-9. Cross-sectional study. [pmid: 8653141].
Boonyaratavej N, Suriyawongpaisal P, Takkinsatien A, et al. Physical activity and risk factors for hip fractures in Thai women. Osteoporos Int. 2001;12(3):244-8. Developing country. [pmid: 11315244].
Bouwstra H, Dijck-Brouwer DA, Boehm G, et al. Long-chain polyunsaturated fatty acids and neurological developmental outcome at 18 months in healthy term infants. Acta Paediatr. Jan. 2005;94(1):26-32. Not relevant. [pmid: 15858956].
Bouwstra H, DijckBrouwer DA, Wildeman JA, et al. Long-chain polyunsaturated fatty acids have a positive effect on the quality of general movements of healthy term infants. Am J Clin Nutr. Aug. 2003;78(2):313-8. Not relevant. [pmid: 12885715].
Bradshaw MK, Pfeiffer S. Feeding mode and anthropometric changes in primiparas. Hum Biol. Apr. 1988;60(2):251-61. Insufficient sample size. [pmid: 3371965].
Butte NF, Garza C, Stuff JE, et al. Effect of maternal diet and body composition on lactational performance. Am J Clin Nutr. Feb. 1984;39(2):296-306. Non-comparative study. [pmid: 6695830].
Butte NF, Hopkinson JM. Body composition changes during lactation are highly variable among women. [Review][45 refs]. J Nutr 1998 Feb;128(2:Suppl):Suppl-385S. Review
Carranza-Lira S, Mera JP. Influence of number of pregnancies and total breast-feeding time on bone mineral density. Int J Fertil Womens Med. Jul. 2002;47(4):169-71. Developing country. [pmid: 12199413].
Chan GM, Ronald N, Slater P, et al. Decreased bone mineral status in lactating adolescent mothers. J Pediatr. Nov. 1982;101(5):767-70. Less than 1 year follow-up. [pmid: 6982323].
Chan SM, Nelson EA, Leung SS, et al. Bone mineral density and calcium metabolism of Hong Kong Chinese postpartum women—a 1-y longitudinal study. Eur J Clin Nutr. Jul. 2005;59(7):868-76. Less than 1 year follow-up. [pmid: 15915158].
Chang-Claude J, Eby N, Kiechle M, et al. Breastfeeding and breast cancer risk by age 50 among women in Germany. Cancer Causes Control. Sep. 2000;11(8):687-95. Pre 2001. [pmid: 11065005].
Coitinho DC, Sichieri R, quino Benicio MH. Obesity and weight change related to parity and breast-feeding among parous women in Brazil. Public Health Nutr. Aug. 2001;4(4):865-70. Developing country. [pmid: 11527509].
Cox JL, Chapman G, Murray D, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in non-postnatal women. J Affect Disord. Jul 29. 1996;39(3):185-9. Reference, not relevant. [pmid: 8856422].
Cox JL, Connor Y, Kendell RE. Prospective study of the psychiatric disorders of childbirth. Br J Psychiatry. Feb. 1982;140:111-7. N<100. [pmid: 7074291].
Cox JL, Holden JM, Sagovsky R. Detection of postnatal depression. Development of the 10-item Edinburgh Postnatal Depression Scale.[see comment]. Br J Psychiatry. Jun. 1987;150:782-6. N<100. [pmid: 3651732].
Cox ML, Khan SA, Gau DW, et al. Determinants of forearm bone density in premenopausal women: a study in one general practice. Br J Gen Pract. May. 1991;41(346):194-6. No BF exposure. [pmid: 1878269]. [pmcid: 1371655].
Cramer DW, Welch WR, Scully RE, et al. Ovarian cancer and talc: a case-control study. Cancer. Jul 15. 1982;50(2):372-6. Not relevant. [pmid: 7083145].
Dalton K. Prospective study into puerperal depression. Br J Psychiatry. Jun. 1971;118(547):689-92. N<100. [pmid: 5104005].
Dennis KJ, Bytheway WR. Changes in body weight after delivery. J Obstet Gynaecol Br Commonw 1965;(72):94–102. Breastfeeding exclusivity unclear
Dequeker J, Tobing L, Rutten V, et al. Relative risk factors for osteoporotic fracture: a pilot study of the MEDOS questionnaire. Clin Rheumatol. Mar. 1991;10(1):49-53. No exposure; study 2: crosssectional study. [pmid: 2065507].
Dewey KG, Cohen RJ, Brown KH, et al. Effects of exclusive breastfeeding for four versus six months on maternal nutritional status and infant motor development: results of two randomized trials in Honduras. J Nutr. Feb. 2001;131(2):262-7. Not relevant. [pmid: 11160544].
Duffy SW, Jakes RW, Ng FC, et al. Interaction of dense breast patterns with other breast cancer risk factors in a case-control study. Br J Cancer. Jul 19. 2004;91(2):233-6. Population not well-defined. [pmid: 15188001].
Dufour DL, Reina JC, Spurr GB. Energy intake and expenditure of free-living, lactating Colombian women in an urban setting. Eur J Clin Nutr. Mar. 2002;56(3):205-13. Developing country. [pmid: 11960295].
Dugdale AE, Eaton-Evans J. The effect of lactation and other factors on post-partum changes in bodyweight and triceps skinfold thickness. Br J Nutr. Mar. 1989;61(2):149-53. Unclear exclusive breastfeeding. [pmid: 2706221].
Egan KM, Stampfer MJ, Rosner BA, et al. Risk factors for breast cancer in women with a breast cancer family history. Cancer Epidemiol Biomarkers Prev. May. 1998;7(5):359-64. Pre 2001. [pmid: 9610783].
Engel J, Anteunis L, Volovics A, et al. Risk factors of otitis media with effusion during infancy. Int J Pediatr Otorhinolaryngol. May 25. 1999;48(3):239-49. High risk patients included, with 9 ventilated patients. [pmid: 10402121].
Enger SM, Ross RK, Paganini-Hill A, et al. Breastfeeding experience and breast cancer risk among postmenopausal women. Cancer Epidemiol Biomarkers Prev. May. 1998;7(5):365-9. Pre 2001. [pmid: 9610784].
Erkkola M, Pigg HM, Virta-Autio P, et al. Infant feeding patterns in the Finnish type I diabetes prediction and prevention nutrition study cohort. Eur J Clinl Nutr. Jan. 2005;59(1):107-13. No outcomes of interest.
Findeisen M, Vennemann M, Brinkmann B, et al. German study on sudden infant death (GeSID): design, epidemiological and pathological profile. Int J of Legal Med. Jun. 2004;118(3):163-9. Duplicate data of Venneman 2005. [pmid: 15042379].
Fituch CC, Palkowetz KH, Goldman AS, et al. Concentrations of IL-10 in preterm human milk and in milk from mothers of infants with necrotizing enterocolitis. Acta Paediatr. Nov. 2004;93(11):496-500. Not relevant.
Florey CD, Leech AM, Blackhall A. Infant feeding and mental and motor development at 18 months of age in first born singletons.[see comment]. Int J Epidemiol. 1995;24(Suppl 1):S21-S26. Included in systematic review. [pmid: 7558546].
Fox KM, Magaziner J, Sherwin R, et al. Reproductive correlates of bone mass in elderly women. Study of Osteoporotic Fractures Research Group. J Bone Miner Res. Aug. 1993;8(8):901-8. Cross-sectional study. [pmid: 8213252].
Fregene A, Newman LA. Breast cancer in sub-Saharan Africa: how does it relate to breast cancer in African-American women?. Cancer. Apr 15. 2005;103(8):1540-50. Developing country. [pmid: 15768434].
Furberg H, Newman B, Moorman P, et al. Lactation and breast cancer risk. Int J Epidemiol. Jun. 1999;28(3):396-402. Pre 2001. [pmid: 10405840].
Gale CR, Martyn CN. Breastfeeding, dummy use, and adult intelligence.[see comment]. Lancet. Apr 20. 1996;347(9008):1072-5. Included in systematic review. [pmid: 8602057].
Galler JR, Ramsey FC, Harrison RH, et al. Postpartum maternal moods and infant size predict performance on a national high school entrance examination. J Child Psychol Psychiatry. Sep. 2004;45(6):1064-75. No outcomes of interest. [pmid: 15257663].
Gao YT, Shu XO, Dai Q, et al. Association of menstrual and reproductive factors with breast cancer risk: results from the Shanghai Breast Cancer Study. Int J Cancer. Jul 15. 2000;87(2):295-300. Developing country. [pmid: 10861490].
Geervani P, Jayashree G. A study on nutritional status of adolescent and adult pregnant and lactating women and growth of their infants. J Trop Pediatr. Oct. 1988;34(5):234-7. Developing country. [pmid: 3199491].
Ghannam NN, Hammami MM, Bakheet SM, et al. Bone mineral density of the spine and femur in healthy Saudi females: relation to vitamin D status, pregnancy, and lactation. Calcif Tissue Int. Jul. 1999;65(1):23-8. Cross-sectional study, developing country. [pmid: 10369729].
Gilliland FD, Hunt WC, Baumgartner KB, et al. Reproductive risk factors for breast cancer in Hispanic and non-Hispanic white women: the New Mexico Women's Health Study. Am J Epidemiol. Oct 1. 1998;148(7):683-92. Pre 2001. [pmid: 9778175].
Greene GW, Smiciklas-Wright H, Scholl TO, et al. Postpartum weight change: how much of the weight gained in pregnancy will be lost after delivery?. Obstet Gynecol. May. 1988;71(5):701-7. Not relevant. [pmid: 3357658].
Hadji P, Ziller V, Kalder M, et al. Influence of pregnancy and breast-feeding on quantitative ultrasonometry of bone in postmenopausal women. Climacteric. Sep. 2002;5(3):277-85. Cross-sectional study. [pmid: 12419086].
Harlow BL, Weiss NS, Roth GJ, et al. Case-control study of borderline ovarian tumors: reproductive history and exposure to exogenous female hormones. Cancer Res. Oct 15. 1988;48(20):5849-52. Borderline tumor. [pmid: 3167840].
Harrison GA, Boyce AJ, Platt CM, et al. Body composition changes during lactation in a New Guinea population. Ann Hum Biology. Oct. 1975;2(4):395-8. Cross-sectional study.
Hart S, Boylan LM, Carroll S, et al. Brief report: breast-fed one-week-olds demonstrate superior neurobehavioral organization. J Pediatr Psychology. Dec. 2003;28(8):529-34. Not relevant.
Hartge P, Hoover R, McGowan L, et al. Menopause and ovarian cancer. Am J Epidemiol. May. 1988;127(5):990-8. Duplicate study to Harge '89; no additional data. [pmid: 3358417].
Hawker GA, Forsmo S, Cadarette SM, et al. Correlates of forearm bone mineral density in young Norwegian women: the Nord-Trondelag Health Study. Am J Epidemiol. Sep 1. 2002;156(5):418-27. Crosssectional study. [pmid: 12196311].
Hejar AR, Chong FB, Rosnan H, et al. Breast cancer and lifestyle risks among Chinese women in the Klang Valley in 2001. Med J Malaysia. Jun. 2004;59(2):226-32. Developing country. [pmid: 15559174].
Hildreth NG, Kelsey JL, Li Volsi VA, et al. An epidemiologic study of epithelial carcinoma of the ovary. Am J Epidemiol. Sep. 1981;114(3):398-405. No quantitative data. [pmid: 7304575].
Hilson JA, Rasmussen KM, Kjolhede CL. High prepregnant body mass index is associated with poor lactation outcomes among white, rural women independent of psychosocial and demographic correlates. J Hum Lact. Feb. 2004;20(1):18-29. No outcomes of interest. [pmid: 14974697].
Holt GM, Wolkind SN. Early abandonment of breast feeding: causes and effects. Child Care Health Dev. Nov. 1983;9(6):349-55. N<100. [pmid: 6678190].
Honda A, Kurabayashi T, Yahata T, et al. Lumbar bone mineral density changes during pregnancy and lactation. Int J Gynaecol Obstet. Dec. 1998;63(3):253-8. Cross-sectional study. [pmid: 9989894].
Horwood LJ, Fergusson DM. Breastfeeding and later cognitive and academic outcomes. Pediatrics. Jan. 1998;101(1):E9. Included in systematic review. [pmid: 9417173].
Hu JF, Zhao XH, Chen JS, et al. Bone density and lifestyle characteristics in premenopausal and postmenopausal Chinese women. Osteoporos Int. Nov. 1994;4(6):288-97. Cross-sectional study. [pmid: 7696820].
Hummel M, Fuchtenbusch M, Schenker M, et al. No major association of breast-feeding, vaccinations, and childhood viral diseases with early islet autoimmunity in the German BABYDIAB Study.[see comment]. Diabetes Care. Jul. 2000;23(7):969-74. No outcomes of interest. [pmid: 10895848].
Huo D, Lauderdale DS, Li L. Influence of reproductive factors on hip fracture risk in Chinese women. Osteoporos Int. Aug. 2003;14(8):694-700. Developing country. [pmid: 12879222].
Jacobson SW, Chiodo LM, Jacobson JL. Breastfeeding effects on intelligence quotient in 4- and 11-year-old children. Pediatrics. May. 1999;103(5):e71. Pre 2001. [pmid: 9917442].
Jacobson SW, Jacobson JL, Frye KF. Incidence and correlates of breast-feeding in socioeconomically disadvantaged women. Pediatrics. Oct. 1991;88(4):728-36. N<100. [pmid: 1896275].
Johnell O, Nilsson BE. Life-style and bone mineral mass in perimenopausal women. Calcif Tissue Int. Jul. 1984;36(4):354-6. Cross-sectional study. [pmid: 6435833].
Jones G, Scott FS. A cross-sectional study of smoking and bone mineral density in premenopausal parous women: effect of body mass index, breastfeeding, and sports participation. J Bone Miner Res. Sep. 1999;14(9):1628-33. No BF exposure, cross-sectional study. [pmid: 10469293].
Kac G, Benicio MH, Velasquez-Melendez G, et al. Breastfeeding and postpartum weight retention in a cohort of Brazilian women. Am J Clin Nutr. Mar. 2004;79(3):487-93. Developing country. [pmid: 14985226].
Kalkwarf HJ, Specker BL. Bone mineral loss during lactation and recovery after weaning. Obstet Gynecol. Jul. 1995;86(1):26-32. Less than 1 year follow-up. [pmid: 7784018].
Kamitsuka MD, Horton MK, Williams MA. The incidence of necrotizing enterocolitis after introducing standardized feeding schedules for infants between 1250 and 2500 grams and less than 35 weeks of gestation. Pediatrics. Feb. 2000;105(2):379-84. Not relevant. [pmid: 10654959].
Keeping JD, Najman JM, Morrison J, et al. A prospective longitudinal study of social, psychological and obstetric factors in pregnancy: response rates and demographic characteristics of the 8556 respondents. Br J Obstet Gynaecol. Mar. 1989;96(3):289-97. Not relevant. [pmid: 2713287].
Kendell RE, McGuire RJ, Connor Y, et al. Mood changes in the first three weeks after childbirth. J Affect Disord. Dec. 1981;3(4):317-26. N<100. [pmid: 6459348].
Khedr EM, Farghaly WM, Amry S, et al. Neural maturation of breastfed and formula-fed infants. Acta Paediatr. Jun. 2004;93(6):734-8. Not relevant. [pmid: 15244219].
Koetting CA, Wardlaw GM. Wrist, spine, and hip bone density in women with variable histories of lactation. Am J Clin Nutr. Dec. 1988;48(6):1479-81. Cross-sectional study. [pmid: 3202099].
Kramer FM, Stunkard AJ, Marshall KA, et al. Breastfeeding reduces maternal lower-body fat. J Am Diet Assoc. Apr. 1993;93(4):429-33. Insufficient sample size. [pmid: 8454811].
Laizner AM, Jeans ME. Identification of predictor variables of a postpartum emotional reaction. Health Care Women Int. 1990;11(2):191-207. Not relevant. [pmid: 2324028].
Lederman SA, Alfasi G, Deckelbaum RJ. Pregnancyassociated obesity in black women in New York City. Matern Child Health J. Mar. 2002;6(1):37-42. Not relevant. [pmid: 11926252].
Lee CY, Ko IS, Kim HS, et al. Development and validation study of the breast cancer risk appraisal for Korean women. Nurs Health Sci. Sep. 2004;6(3):201-7. No hormonal data given. [pmid: 15291768].
Lee EO, Ahn SH, You C, et al. Determining the main risk factors and high-risk groups of breast cancer using a predictive model for breast cancer risk assessment in South Korea. Cancer Nurs. Sep. 2004;27(5):400-6. Not relevant. [pmid: 15525868].
Li R, Jewell S, Grummer-Strawn L. Maternal obesity and breast-feeding practices. Am J Clin Nutr. Apr. 2003;77(4):931-6. Not relevant. [pmid: 12663294].
Lim S, Joung H, Shin CS, et al. Body composition changes with age have gender-specific impacts on bone mineral density. Bone. Sep. 2004;35(3):792-8. No BF exposure, cross-sectional study. [pmid: 15336618].
Lovelady CA, Garner KE, Moreno KL, et al. The effect of weight loss in overweight, lactating women on the growth of their infants.[see comment]. N Engl J Med. Feb 17. 2000;342(7):449-53. Not relevant. [pmid: 10675424].
Lumachi F, Ermani M, Brandes AA, et al. Breast cancer risk in healthy and symptomatic women: results of a multivariate analysis. A case-control study. Biomed Pharmacother. Oct. 2002;56(8):416-20. Population not well-defined. [pmid: 12442915].
Malloy MH, Berendes H. Does breast-feeding influence intelligence quotients at 9 and 10 years of age?. Early Hum Dev. Jan 9. 1998;50(2):209-17. Included in systematic review. [pmid: 9483393].
Marcus PM, Baird DD, Millikan RC, et al. Adolescent reproductive events and subsequent breast cancer risk. Am J Public Health. Aug. 1999;89(8):1244-7. Pre 2001. [pmid: 10432916]. [pmcid: 1508686].
Marini A, Vegni C, Gangi S, et al. Influence of different types of post-discharge feeding on somatic growth, cognitive development and their correlation in very low birthweight preterm infants. Acta Paediatr Suppl. Sep. 2003;91(441):18-33. Not relevant. [pmid: 14599038].
Matsumoto I, Kosha S, Noguchi S, et al. Changes of bone mineral density in pregnant and postpartum women. J Obstet Gynaecol. Oct. 1995;21(5):419-25. Less than 1 year follow-up. [pmid: 8542463].
McCredie M, Paul C, Skegg DC, et al. Reproductive factors and breast cancer in New Zealand. Int J Cancer. Apr 13. 1998;76(2):182-8. Pre 2001. [pmid: 9537578].
McCredie M, Paul C, Skegg DC, et al. Breast cancer in Maori and non-Maori women. Int J Epidemiol. Apr. 1999;28(2):189-95. Pre 2001. [pmid: 10342678].
McKeown T, Aaby P. The influence of reproduction on body weight in women. J Endocrinol. 1957;15:393-409. Cross-sectional study. [pmid: 13475599].
McLennan JD, Kotelchuck M, Cho H. Prevalence, persistence, and correlates of depressive symptoms in a national sample of mothers of toddlers. J Am Acad Child Adolesc Psychiatry. Nov. 2001;40(11):1316-23. Not relevant. [pmid: 11699806].
Meeske K, Press M, Patel A, et al. Impact of reproductive factors and lactation on breast carcinoma in situ risk. Int J Cancer. May 20. 2004;110(1):102-9. No hormonal data given. [pmid: 15054874].
Melton LJ III, Bryant SC, Wahner HW, et al. Influence of breastfeeding and other reproductive factors on bone mass later in life. Osteoporos Int. Mar. 1993;3(2):76-83. Cross-sectional study. [pmid: 8453194].
Mezzacappa ES, Katlin ES. Breast-feeding is associated with reduced perceived stress and negative mood in mothers. Health Psychol. Mar. 2002;21(2):187-93. N<100. [pmid: 11950109].
Mihatsch WA, von Schoenaich P, Fahnenstich H, et al. Randomized, multicenter trial of two different formulas for very early enteral feeding advancement in extremely-low-birth-weight infants.[erratum appears in J Pediatr Gastroenterol Nutr 2002 Nov;35(5):739]. J Pediatr Gastroenterol Nutr. Aug. 2001;33(2):155-9. Not relevant. [pmid: 11568516].
Milner JD, Stein DM, McCarter R, et al. Early infant multivitamin supplementation is associated with increased risk for food allergy and asthma. Pediatrics. Jul. 2004;114(1):27-32. Not relevant, 25% premature infants. [pmid: 15231904].
Minami Y, Ohuchi N, Taeda Y, et al. Risk factors for benign breast disease according to histopathological type: comparisons with risk factors for breast cancer. Jpn J Cancer Res. Feb. 1998;89(2):116-23. Pre 2001. [pmid: 9548437].
Minami Y, Tsubono Y, Nishino Y, et al. The increase of female breast cancer incidence in Japan: emergence of birth cohort effect. Int J Cancer. Mar 1. 2004;108(6):901-6. Review. [pmid: 14712495].
Misri S, Sinclair DA, Kuan AJ. Breast-feeding and postpartum depression: is there a relationship?. Can J Psychiatry. Dec. 1997;42(10):1061-5. N<100. [pmid: 9469238].
Modugno F, Ness RB, Allen GO, et al. Oral contraceptive use, reproductive history, and risk of epithelial ovarian cancer in women with and without endometriosis. Am J Obstet Gynecol. Sep. 2004;191(3):733-40. No breastfeeding data. [pmid: 15467532].
Monobe H, Ishibashi T, Fujishiro Y, et al. Factors associated with poor outcome in children with acute otitis media. Acta Otolaryngol (Stockh). Jun. 2003;123(5):564-8. Not relevant. [pmid: 12875576].
Montella M, De Marco MR, Romeo F, et al. Survival in ovarian cancers treated at National Cancer Institute in Naples Italy 1985-1990. Eur J Gynaecol Oncol. 1993;14(3):249-54. No BF exposure. [pmid: 8508884].
More C, Bettembuk P, Bhattoa HP, et al. The effects of pregnancy and lactation on bone mineral density.[see comment]. Osteoporos Int. 2001;12(9):732-7. Less than 1 year follow-up. [pmid: 11605738].
Morley R. Breast feeding and cognitive outcome in children born prematurely. Adv Exp Med Biol. 2002;503:77-82. Review. [pmid: 12026030].
Morley R, Fewtrell MS, Abbott RA, et al. Neurodevelopment in children born small for gestational age: a randomized trial of nutrient-enriched versus standard formula and comparison with a reference breastfed group. Pediatrics. Mar. 2004;113(3 Pt 1):515-21. Not relevant. [pmid: 14993543].
Morrison J, Najman JM, Williams GM, et al. Socioeconomic status and pregnancy outcome. An Australian study. Br J Obstet Gynaecol. Mar. 1989;96(3):298-307. Not relevant. [pmid: 2713288].
Motil KJ, Sheng H, Kertz BL, et al. Lean body mass of well-nourished women is preserved during lactation. Am J Clin Nutr. Feb. 1998;67(2):292-300. Exclusive and mixed feeding data combined. [pmid: 9459378].
Murphy S, Khaw KT, May H, et al. Parity and bone mineral density in middle-aged women. Osteoporos Int. May. 1994;4(3):162-16. Cross-sectional study. [pmid: 8069056].
Murray L, Woolgar M, Murray J, et al. Self-exclusion from health care in women at high risk for postpartum depression. J Public Health Med. Jun. 2003;25(2):131-7. Not relevant. [pmid: 12848402].
Naismith DJ, Ritchie CD. The effect of breast-feeding and artificial feeding on body-weights, skinfold measurements and food intakes of forty-two primiparous women. Proc Nutr Soc. Dec. 1975;34(3):116A-117A. 1975 Dec. Abstract.
Najman JM, Morrison J, Williams GM, et al. The employment of mothers and the outcomes of their pregnancies: an Australian study. Public Health 1989 Maya;103(3):189–98. Not relevant to any outcomes
Najman JM, Morrison J, Williams GM, et al. Unemployment and reproductive outcome. An Australian study. Br J Obstet Gynaecol 1989 Marb;96(3):308–13. Not relevant to any outcomes
Nasca PC, Greenwald P, Chorost S, et al. An epidemiologic case-control study of ovarian cancer and reproductive factors. Am J Epidemiol. May. 1984;119(5):705-13. No BF exposure. [pmid: 6539067].
Newcomb PA, Egan KM, TitusErnstoff L, et al. Lactation in relation to postmenopausal breast cancer. Am J Epidemiol. Jul 15. 1999;150(2):174-82. Pre 2001. [pmid: 10412962].
Niemela M, Uhari M, Mottonen M. A pacifier increases the risk of recurrent acute otitis media in children in day care centers. Pediatrics. Nov. 1995;95(5 Pt 1):884-8. Not relevant.
O'Neill T, Murphy P, Greene VT. Postnatal depression—aetiological factors. Irish Med J. Mar. 1990;83(1):17-8. N<100.
Oddy WH. Breastfeeding and asthma in children. A prospective cohort study. Adv Exp Med Bio. 2000;478:393-4. Duplicate with Oddy 1999, included in meta-analysis. [pmid: 11065098].
Oddy WH, de Klerk NH, Sly PD, et al. The effects of respiratory infections, atopy, and breastfeeding on childhood asthma. Eur Respir J. May. 2002;19(5):899-905. Duplicate with Oddy 1999, included in meta-analysis. [pmid: 12030731].
Oddy WH, Peat JK, de Klerk NH. Maternal asthma, infant feeding, and the risk of asthma in childhood. J Allergy Clin Immunol. Jul. 2002;110(1):65-7. Duplicate with Oddy 1999, included in meta-analysis. [pmid: 12110822].
Oddy WH, Sherriff JL, de Klerk NH, et al. The relation of breastfeeding and body mass index to asthma and atopy in children: a prospective cohort study to age 6 years. Am J Public Health. Sep. 2004;94(9):1531-7. Duplicate with Oddy 1999, included in meta-analysis. [pmid: 15333310]. [pmcid: 1448489].
Olsen LC, Mundt MH. Postpartum weight loss in a nurse-midwifery practice. J Nurse Midwifery. Jul. 1986;31(4):177-81. Breastfeeding exclusivity unclear. [pmid: 3641882].
Orwoll ES, Bauer DC, Vogt TM, et al. Axial bone mass in older women. Study of Osteoporotic Fractures Research Group. Ann Intern Med. Jan 15. 1996;124(2):187-96. Cross-sectional study. [pmid: 8533993].
Otto SJ, de Groot RH, Hornstra G. Increased risk of postpartum depressive symptoms is associated with slower normalization after pregnancy of the functional docosahexaenoic acid status. Prostaglandins Leukotr Essent Fatty Acids. Oct. 2003;69(4):237-43. Not relevant.
Paine BJ, Makrides M, Gibson RA. Duration of breast-feeding and Bayley's Mental Developmental Index at 1 year of age. J Paediatr Child Health. Feb. 1999;35(1):82-5. Pre 2001. [pmid: 10234642].
Parker JD. Postpartum weight change. [Review] [21 refs]. Clin Obstet Gynecol. Sep. 1994;37(3):528-37. Review. [pmid: 7955641].
Paton LM, Alexander JL, Nowson CA, et al. Pregnancy and lactation have no long-term deleterious effect on measures of bone mineral in healthy women: a twin study. Am J Clin Nutr. Mar. 2003;77(3):707-14. Not all had 2 year follow-up. [pmid: 12600865].
Pearson D, Kaur M, San P, et al. Recovery of pregnancy mediated bone loss during lactation. Bone. Mar. 2004;34(3):570-8. Less than 1 year follow-up. [pmid: 15003805].
Peters RK, Kjos SL, Xiang A, et al. Long-term diabetogenic effect of single pregnancy in women with previous gestational diabetes mellitus.[see comment]. Lancet. Jan 27. 1996;347(8996):227-30. No breastfeeding exposure. [pmid: 8551882].
Pettitt DJ, Knowler WC. Long-term effects of the intrauterine environment, birth weight, and breastfeeding in Pima Indians. Diabetes Care. Aug. 1998;21(Suppl 2):B138-B141. Included in systematic review. [pmid: 9704241].
Piers LS, Diggavi SN, Thangam S, et al. Changes in energy expenditure, anthropometry, and energy intake during the course of pregnancy and lactation in wellnourished Indian women. Am J Clin Nutr. Mar. 1995;61(3):501-13. Developing country. [pmid: 7872213].
Pitt B. “Atypical” depression following childbirth. Br J Psychiatry. Nov. 1968;114(516):1325-35. N<100. [pmid: 5750402].
Plagemann A, Harder T, Franke K, et al. Long-term impact of neonatal breast-feeding on body weight and glucose tolerance in children of diabetic mothers. Diabetes Care. Jan. 2002;25(1):16-22. Included in systematic review. [pmid: 11772895].
Plagemann A, Harder T, Kohlhoff R, et al. Impact of early neonatal breast-feeding on psychomotor and neuropsychological development in children of diabetic mothers. Diabetes Care. Mar. 2005;28(3):573-8. Not relevant. [pmid: 15735190].
Potter S, Hannum S, McFarlin B, et al. Does infant feeding method influence maternal postpartum weight loss?. J Am Diet Assoc. Apr. 1991;91(4):441-6. Retrospective study. [pmid: 2016492].
Prentice AM, Whitehead RG, Roberts SB, et al. Longterm energy balance in child-bearing Gambian women. Am J Clin Nutr. Dec. 1981;34(12):2790-9. Developing country. [pmid: 7315781].
Purdie D, Green A, Bain C, et al. Reproductive and other factors and risk of epithelial ovarian cancer: an Australian case-control study. Survey of Women's Health Study Group. Int J Cancer. Sep 15. 1995;62(6):678-84. Duplicate study to Siskind 1997, no additional data. [pmid: 7558414].
Purwanto H, Sadjimin T, Dwiprahasto I. Lactation and the risk of breast cancer. Gan to Kagaku Ryoho [Jpn J Cancer Chemotherapy]. May. 2000;27(Suppl 2):474-81. Pre 2001.
Rami B, Schneider U, Imhof A, et al. Risk factors for type I diabetes mellitus in children in Austria. Eur J Pediatr. May. 1999;158(5):362-6. Duplicate data - included in EURODIAB. [pmid: 10333115].
Richards M, Wadsworth M, Rahimi-Foroushani A, et al. Infant nutrition and cognitive development in the first offspring of a national UK birth cohort. Dev Med Child Neurol. Mar. 1998;40(3):163-7. Included in systematic review. [pmid: 9566652].
Rojahn A, Lindgren CG. Enteral feeding in infants <1250 g starting within 24 h post-partum. Eur J of Pediatr. Oct. 2001;160(10):629-32. Not relevant. [pmid: 11686510].
Rookus MA, Rokebrand P, Burema J, et al. The effect of pregnancy on the body mass index 9 months postpartum in 49 women. Int J Obes. 1987;11(6):609-18. Breastfeeding exclusivity unclear. [pmid: 3440682].
Rooney BL, Schauberger CW. Excess pregnancy weight gain and long-term obesity: one decade later. Obstet Gynecol. Aug. 2002;100(2):245-52. Breastfeeding exclusivity unclear. [pmid: 12151145].
Rosenblatt KA, Thomas DB. Lactation and the risk of epithelial ovarian cancer. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Int J Epidemiol. Apr. 1993;22(2):192-7. Included developing countries. [pmid: 8505173].
Rossner S. Weight gain in pregnancy. [Review][17 refs]. Human Reproduct 1997 Oct;12:Suppl-5. Review, duplicate with Ohlin study
Rush D, Lumey LH, Ravelli AC, et al. The indirect association of lactation with subsequent perimenopausal body weight. Eur J of Clin Nutr. Jan. 1996;50(1):12-6. Cross-sectional study. [pmid: 8617185].
Sadurskis A, Kabir N, Wager J, et al. Energy metabolism, body composition, and milk production in healthy Swedish women during lactation. Am J Clin Nutr. Jul. 1988;48(1):44-9. Non-comparative study. [pmid: 3389329].
Samuelsson U, Ludvigsson J. Seasonal variation of birth month and breastfeeding in children with diabetes mellitus. J Pediatr Endocrinol. Jan. 2001;14(1):43-6. Same subjects as Samuelsson, 1993 in the MA but include results from new analyses.
Schauberger CW, Rooney BL, Brimer LM. Factors that influence weight loss in the puerperium. Obstet Gynecol. Mar. 1992;79(3):424-9. No data. [pmid: 1738527].
Schneider AP. Risk factor for ovarian cancer. N Engl J Med. Aug 20. 1987;317(8):508-9. Abstract. [pmid: 3614298].
Schwartz SM, Weiss NS, Daling JR, et al. Incidence of histologic types of uterine sarcoma in relation to menstrual and reproductive history. Int J Cancer. Sep 30. 1991;49(3):362-7. No outcomes of interest. [pmid: 1917134].
Sheikh GN. Observations of maternal weight behavior during the puerperium. Am J Obstet Gynecol. Sep 15. 1971;111(2):244-50. Unclear exclusive breastfeeding. [pmid: 5098594].
Singh Y, Sayami P, Sayami G, et al. Nepalese breast cancer in relation to reproductive factors: comparison between Nepalese and Japanese cases. Anticancer Res. Jan. 2002;22(1A):319-23. Developing country. [pmid: 12017310].
Sinigaglia L, Varenna M, Binelli L, et al. Effect of lactation on postmenopausal bone mineral density of the lumbar spine. J Reprod Med. Jun. 1996;41(6):439-43. Cross-sectional study. [pmid: 8799922].
Soltesz G, Jeges S, Dahlquist G. Non-genetic risk determinants for type 1 (insulin-dependent) diabetes mellitus in childhood. Hungarian Childhood Diabetes Epidemiology Study Group. Acta Paediatr. Jul. 1994;83(7):730-5. Developing country. [pmid: 7949803].
Sowers M, Corton G, Shapiro B, et al. Changes in bone density with lactation.[see comment]. JAMA. Jun 23. 1993;269(24):3130-5. Less than 1 year follow-up. [pmid: 8505816].
Sowers M, Wallace RB, Lemke JH. Correlates of forearm bone mass among women during maximal bone mineralization. Prev Med. Sep. 1985;14(5):585-96. Cross-sectional study. [pmid: 3877927].
Sowers M, Zhang D, Janney CA. Interpregnancy weight retention patterning in women who breastfed. J Matern Fetal Med. Mar. 1998;7(2):89-94. No data. [pmid: 9584821].
Stene LC, Joner G. Norwegian Childhood Diabetes Study Group. Atopic disorders and risk of childhoodonset type 1 diabetes in individuals. Clin Exp Allergy. Feb. 2004;34(2):201-6. No BF exposure. [pmid: 14987298].
Steyn NP, Mann J, Bennett PH, et al. Diet, nutrition and the prevention of type 2 diabetes. [Review] [248 refs]. Public Health Nutr. Feb. 2004;7(1A):147-65. Review. [pmid: 14972058].
Susman VL, Katz JL. Weaning and depression: another postpartum complication. Am J Psychiatry. Apr. 1988;145(4):498-501. Case report. [pmid: 3279831].
Tamminen T. The impact of mother's depression on her nursing experiences and attitudes during breastfeeding. Acta Paediatr Scand Suppl No 344. 1988;77:87-94. N<100.
Tappin D, Ecob R, Brooke H. Bedsharing, roomsharing, and sudden infant death syndrome in Scotland: a case-control study.[see comment]. J Pediatr. Jul. 2005;147(1):32-7. No BF data. [pmid: 16027691].
Tarkka MT, Paunonen M, Laippala P. Factors related to successful breast feeding by first-time mothers when the child is 3 months old. J Adv Nurs. Jan. 1999;29(1):113-8. Not relevant. [pmid: 10064289].
Thomson AM, Billewicz WZ, Thompson B, et al. Body weight changes during pregnancy and lactation in rural African (Gambian) women. J Obstet Gynaecol Br Commonw. Oct. 1966;73(5):724-33. Developing country. [pmid: 5919091].
Titus-Ernstoff L, Egan KM, Newcomb PA, et al. Exposure to breast milk in infancy and adult breast cancer risk. J Natl Cancer Inst. Jun 17. 1998;90(12):921-4. Breast fed infant related cancer. [pmid: 9637142].
Tryggvadottir L, Olafsdottir EJ, Gudlaugsdottir S, et al. BRCA2 mutation carriers, reproductive factors and breast cancer risk. Breast Cancer Res. 2003;5(5):R121-R128. Included in MA. [pmid: 12927042].
Tryggvadottir L, Tulinius H, Eyfjord JE, et al. Breast cancer risk factors and age at diagnosis: an Icelandic cohort study. Int J Cancer. Apr 1. 2002;98(4):604-8. Pre 2001. [pmid: 11920622].
Tuppurainen M, Kroger H, Honkanen R, et al. Risks of perimenopausal fractures—a prospective populationbased study. Acta Obstet Gynecol Scand. Sep. 1995;74(8):624-8. No BF exposure. [pmid: 7660769].
Tuppurainen M, Kroger H, Saarikoski S, et al. The effect of gynecological risk factors on lumbar and femoral bone mineral density in peri- and postmenopausal women. Maturitas. Feb. 1995;21(2):137-45. Cross-sectional study. [pmid: 7752951].
Unay B, Sarici SU, Ulas UH, et al. Nutritional effects on auditory brainstem maturation in healthy term infants. Arch Dis in Child Fetal Neonatal Ed 2004 Mar;Edition 89(2):F177–F179. Not relevant
Ursin G, Bernstein L, Lord SJ, et al. Reproductive factors and subtypes of breast cancer defined by hormone receptor and histology. Br J Cancer. Aug 8. 2005;93(3):364-71. No hormonal data given. [pmid: 16079783].
Ursin G, Bernstein L, Wang Y, et al. Reproductive factors and risk of breast carcinoma in a study of white and African-American women. Cancer. Jul 15. 2004;101(2):353-62. No hormonal data given. [pmid: 15241834].
van Hemert AM, Vandenbroucke JP, Birkenhager JC, et al. Prediction of osteoporotic fractures in the general population by a fracture risk score. A 9-year follow-up among middle-aged women. Am J Epidemiol. Jul. 1990;132(1):123-35. No outcomes of interest. [pmid: 2192546].
Van Raaij JM, Schonk CM, Vermaat-Miedema SH, et al. Energy cost of lactation, and energy balances of well-nourished Dutch lactating women: reappraisal of the extra energy requirements of lactation. Am J Clin Nutr. Mar. 1991;53(3):612-9. Non-comparative study. [pmid: 2000814].
Vennemann MM, Bajanowski T, Butterfass-Bahloul T, et al. Do risk factors differ between explained sudden unexpected death in infancy (SUDI) and SIDS? Arch Dis Child Epub ahead of print doi:10 1136/adc 2006 101337 2006 Aug 25. Duplicate of Vennemann 2005
Verge CF, Howard NJ, Irwig L, et al. Environmental factors in childhood IDDM. A population-based, case-control study. Diabetes Care. Dec. 1994;17(12):1381-9. Included in MA. [pmid: 7882806].
Virtanen SM, Rasanen L, Ylonen K, et al. Early introduction of dairy products associated with increased risk of IDDM in Finnish children. The Childhood in Diabetes in Finland Study Group. Diabetes. Dec. 1993;42(12):1786-90. Studies in the MA. [pmid: 8243824].
Walker LO, FreelandGraves J. Lifestyle factors related to postpartum weight gain and body image in bottle- and breastfeeding women. J Obstet Gynecol Neonatal Nurs. Mar. 1998;27(2):151-60. Cross-sectional study.
Webster J, Moore K, McMullan A. Breastfeeding outcomes for women with insulin dependent diabetes. J Hum Lact. Sep. 1995;11(3):195-200. Not relevant. [pmid: 7669239].
Weiss NS, Lyon JL, Liff JM, et al. Incidence of ovarian cancer in relation to the use of oral contraceptives. Int J Cancer. Dec. 1981;28(6):669-71. No BF exposure. [pmid: 7333700].
Whiteman MK, Hillis SD, Curtis KM, et al. Reproductive history and mortality after breast cancer diagnosis. Obstet Gynecol. Jul. 2004;104(1):146-54. No outcomes of interest. [pmid: 15229014].
Winkvist A, Rasmussen KM. Impact of lactation on maternal body weight and body composition. [Review] [71 refs]. J Mammary Gland Biol Neoplasm. Jul. 1999;4(3):309-18. Review.
Wosje KS, Kalkwarf HJ. Lactation, weaning, and calcium supplementation: effects on body composition in postpartum women. Am J Clin Nutr. Aug. 2004;80(2):423-9. Breastfeeding exclusivity unclear. [pmid: 15277165].
Yasumizu T, Nakamura Y, Hoshi K, et al. Bone metabolism after human parturition and the effect of lactation: longitudinal analysis of serum bone-related proteins and bone mineral content of the lumbar spine. Endocr J. Oct. 1998;45(5):679-86. Less than 1 year follow-up. [pmid: 10395249].
Yen ML, Yen BL, Bai CH, et al. Risk factors for ovarian cancer in Taiwan: a case-control study in a low-incidence population. Gynecol Oncol. May. 2003;89(2):318-24. Developing country. [pmid: 12713998].
Young TK, Martens PJ, Taback SP, et al. Type 2 diabetes mellitus in children: prenatal and early infancy risk factors among native Canadians. Arch Pediatr Adolesc Med. Jul. 2002;156(7):651-5. Included in systematic review. [pmid: 12090830].
Zhang J, Liu G, Wu J, et al. Pregnancy-associated breast cancer: a case control and long-term follow-up study in China. J Exp Clin Cancer Res. Mar. 2003;22(1):23-7. Developing country. [pmid: 12725318].
Zhang M, Lee AH, Binns CW. Reproductive and dietary risk factors for epithelial ovarian cancer in China. Gynecol Oncol. Jan. 2004;92(1):320-6. Developing country. [pmid: 14751177].
Zhang M, Xie X, Lee AH, et al. Prolonged lactation reduces ovarian cancer risk in Chinese women. Eur J Cancer Prev. Dec. 2004;13(6):499-502. Developing country. [pmid: 15548943].
Zheng T, Duan L, Liu Y, et al. Lactation reduces breast cancer risk in Shandong Province, China. Am J Epidemiol. Dec 15. 2000;152(12):1129-35. No hormonal data given. [pmid: 11130618].
Zheng T, Holford TR, Mayne ST, et al. Lactation and breast cancer risk: a case-control study in Connecticut. Br J Cancer. Jun 1. 2001;84(11):1472-6. Pre 2001. [pmid: 11384096].
Ziegler AG, Schmid S, Huber D, et al. Early infant feeding and risk of developing type 1 diabetes-associated autoantibodies.[see comment]. JAMA. Oct 1. 2003;290(13):1721-8. No outcomes of interest. [pmid: 14519706].