# Appendix C. Evidence Tables

## Part I. Term Infant Outcomes

Acute Otitis Media

Alho 1996

Duffy 1997

Sassen 1994

Stenstrom 1997

Uhari 1994 SRMA*

Vernacchio 2004

* Systematic Review/Meta-Analysis

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Alho, 1996[ 8633605]
Mean GA (range): ND | Retrospective | All pregnant women in the two northernmost provinces of Finland with estimated dates of delivery between July 1,1985 and June 30,1986 were enrolled. | Breastfeeding among children older than 3 mo of age | Bottle feeding among children older than 3 mo of age | Diagnostic criteria for AOM: | Adjusted OR | OR=0.9 | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): ND | Mean follow-up = 22 mo | The research program investigated the fetal period and the later development and illnesses of the children. | | | At least one acute Symptom- | Confounders: | CI: 0.8 – 1.0 | Selection | | x
% Male: ND | | | | | Earache, fever, irritability, respiratory symptoms, Restless sleep, etc. | Day care | | Study design | | x
Race: ND | | | | | and | Parental smoking | | Confounder | | x
Enrolled/Evaluate: | | | | | one pneumo-otoscopic finding- | | | Blinding
2512/ 825 | | | | | distinct redness and outward bulging or reduced mobility of the eardrum | | | Data collection | | | x
Location: Northern Finland | | | | | | | | Withdraw and dropout | | | x
Sites: Single | | | | | | | | Analyses | | x
Funding: | | | | | | | | Intervention integrity | | x
| | | | | | | | Overall: C
| | | | | | | | High dropout rate
Duffy, 1997 [9310540]
Mean GA (range): | Prospective | Consecutive infants at well baby visits shortly after birth. | Changes in feeding modes were assessed at scheduled office visits; - Exclusive milk breastfeeding; - Combined breast- and formula-feeding | Changes in feeding modes were assessed at scheduled office visits; - Formula feeding | AOM defined by presence of one or more of Fever, irritability, ear pain, pulling at the ears, | RR | Exclusive BF at 3 mo was associated with RR= 0.62; 95%CI: 0.43–.89; | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): | Follow-up duration: 24 mo | Infants with craniofacial abnormalities, genetic disorders, immune deficiencies were excluded | Maternal guardians completed a questionnaire at 24months to determine the reliability of various postnatal parameters. | | And | Confounder: age of colonization | At 6 mo, RR=0.46; 95%CI: 0.29–0.74 | Selection | | x
% Male: 52 | | | K statistics: r>0.9 for classification and duration of feeding modes (birth, 3, 6, and 12 mo of age) | | Tympanic membrane changes including Increased thickness, bulging, loss of landmarks, Decreased mobility | | | Study design | x
Race: 99% Caucasian | | | | | | | | Confounder | | x
Enrolled/Evaluate: | | | | | | | | Blinding
306/238 | | | | | | | | Data collection | x
Location: USA | | | | | | | | Withdraw and dropout | | x
Sites: Multi | | | | | | | | Analyses | | x
Funding: National Institute Of Child Health and Human Development Grant 19679 | | | | | | | | Intervention integrity | x
| | | | | | | | Overall: B
Sassen, 1994 [7978038]
Mean GA (range): ND | Prospective | Children born between July 1987 and October 1988 | Before breastfeeding was stopped | Up to 4 mo after stopping | AOM diagnosis by physician; | Adjusted for; 1 Number of siblings; 2 Socio-economic status; 3 Duration of breastfeeding | OR= 0.92 95% | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): ND | Mean follow-up = 23.6 mo | | (or per month) | | If purulent otorrhea; or | | CI: 0.76–1.07 | Selection | | | x
% Male: 53 | | | | | if treatment for AOM given | | | Study design | x
Race: 96.6% Dutch | | | | | Criteria for AOM consisted of: | | | Confounder | | x
Enrolled/Evaluate: 289/232 | | | | | Acute symptoms-ear ache, fever, irritability, restless sleep, etc. | | | Blinding
Location: Netherlands | | | | | Otoscopic signs-distinct redness and/or | | | Data collection | | x
Sites: Multi; 1 urban and 2 rural | | | | | Outward bulging of the tympanic membrane | | | Withdraw and dropout | | | x
Funding: ND | | | | | Tympanometry results not used | | | Analyses | x
| | | | | | | | Intervention integrity | x
| | | | | | | | Overall: B
| | | | | | | | Parents who are not Dutch could not Enroll their infants because the Questionnaire was not translated
Stenstrom, 1997 [9039487]
Mean GA (range): | Case-control | All children born in the period 1978-81 registered to have had five or more episodes of AOM before age 30mo were selected and classified as cases (otitis-prone) | Ever breastfeeding | Never breastfeeding | AOM diagnosed otoscopically by an ENT physician, | Estimates not reported | No differences between the groups found | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): | At examination children were between 3 and 7 years old | From the official computerized population register in Malmo, 412 children with less than 5 episodes of AOM | | | Pediatrician or general practitioner | No adjustment for confounders | | Selection | x
% Male: 61 | Controls were between 4 and 6 years | Were selected at random as a control group, and matched with otitis-prone children for age and sex so that each otitis-prone child had two matched controls | | | | | | Study design | | x
Race: | | | | | | | | Confounder | | | x
Enrolled/Evaluate: | | | | | | | | Blinding
Location: Sweden | | | | | | | | Data collection | | x
Sites: Single/Multi | | | | | | | | Withdraw and dropout | | x
Funding: | | | | | | | | Analyses | | x
| | | | | | | | Intervention integrity | | x
| | | | | | | | Overall: C
| | | | | | | | No confounders adjusted

Evidence table for Systematic Reviews of Breastfeeding and Acute otitis media

Author, Year[UI] Topic | Uhari, 1996 Acute otitis media
Literature search (Dates) | Medline (1966-1994); Other databases searched? (yes); unpublished data used? (no)
Countries where primary studies conducted | Finland, USA, Scotland
Study eligibility / inclusion criteria | Search was limited to the English language and to human subjects. Only original studies of risk factors with adequate control groups and that reported actual numbers of patients were included
Study design [No. Of studies] | 2 Case-control [12,17] 8 Observational [[13,15,16,20,22,23,25,27]
No. of subjects | Case control: 671 Observational: 4455
| Breastfeeding > 3 months 2,548
| Breastfeeding > 6 months 3,384
| Breastfeeding (yes/no) 2, 193
Study population (definition in included studies) | Studies of association between breastfeeding and acute otitis media and recurrence of AOM; - Specific age groups of children in the cohorts are not specified
Intervention/Exposure (definition in included studies) | The studies reviewed reported breastfeeding as yes/no or breastfeeding ≥ 3months vs < 3 months or breastfeeding ≥ 6 months vs < 6 months
Comparator (definition in included studies) | Duration of breastfeeding
Outcomes (definition in included studies) | 10 studies evaluated the risk of Acute otitis media and recurrence of Acute otitis associated with breast milk feeding. The diagnosis of AOM varied, but pneumatic otoscopy was used in the diagnosis. There was no restriction on study inclusion according to the diagnostic criteria used. Twenty-two studies evaluating an array of risk factors for development and recurrence of AOM were included in the Meta-analysis. Seven of the twenty-two studies explicitly evaluated the association between breast milk feeding and AOM, while another 3/22 studies included breast milk feeding among other risk factors that were evaluated. All the studies agreed on the protective effect of breast milk feeding against AOM.
Heterogeneity assessments | Pooled estimate of the relative risk and the 95% CI were calculated from data from studies that were sufficiently homogeneous. Pooled estimates of risks were derived with the random effects model.
| Details of clinical and statistical heterogeneity assessment is published elsewhere
Quality assessments | Not done
Publication bias assessments | Not done
Statistical Analysis or meta-analytic methods | Random effects model used for the pooled estimates of risks
Results | - breastfeeding for at least 3 months and AOM; RR=0.87; 95% CI: 0.79 – 0.95; p = 0.003; - breastfeeding yes/no and recurrent AOM: RR=0.48; 95% CI: 0.32–0.72; p=0.0004; - breastfeeding ≥ 3 mo vs < 3 mo and recurrent AOM: RR= 0.69; 95% CI: 0.46–1.03; p=0.07; - breastfeeding ≥ 6 mo vs < 6 mo and recurrent AOM: RR= 0.69; 95% CI: 0.49–0.97; p=0.03
Quality of the systematic review | Not done
Author's interpretations of the results | - In the meta-analysis, breastfeeding was beneficial and breastfeeding even for only 3 months decreased the risk of AOM; - Breastfeeding for 6 months or more decreased the recurrence of AOM; - Breastfeeding should be promoted to protect against acute otitis media.
Comments / Limitations | There was no restriction on inclusion according to the diagnostic criteria used for AOM.
| There are no details on how breastfeeding data was collected or duration of follow-up.
| Meta-analyses combined both case-control and cohort studies and did not address the potential biases in the individual studies.

Author, yr: Uhari, 1994
Topic of the systematic review*/MA: Acute otitis media
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Yes
2 | Types of exposure or intervention used | Yes
3 | Types of study designs used | Yes
4 | Study population | Yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Yes
6 | Effort to include all available studies (contact with authors) | No (Medline only)
7 | Databases and registries searched | Yes
8 | Method of addressing published articles other than English | No
9 | Method of handling abstracts and unpublished studies | No
| Reporting of Methods
10 | Rationale for selection and/or coding of data | No
11 | Assessment of confounding | No
12 | Assessment of quality | No
13 | Assessment of heterogeneity | Yes
14 | Description of statistical methods sufficient to replicate | Yes
15 | Provision of appropriate tables and graphs | Yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Yes
17 | Tables giving descriptive information of each study included | Partially
18 | Results of sensitivity testing (subgroup analysis) | No
19 | Indication of statistical uncertainty of findings | Yes
20 | Quantitative assessment of bias (eg. publication bias) | No
| Overall quality | C

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Partially
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | Yes
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | No
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | No
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Yes
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Yes
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | N/A
9 | Were conclusions justified by the reported/collected data and analysis? | Yes

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Vernacchio, 2004 [15126021]
Mean GA (range): | Prospective | 6 mo old infants who participated in the infant care practices study | Breastfeeding | No breastfeeding | As part of the 6 mo questionnaire, each mother was asked health care provider in the month prior to date of completing the questionnaire. I so, they were asked to select a diagnosis from a menu of options that included “ear infection” | OR | Unadjusted OR=0.66 | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 3,400,median | Followup- 6 mo | | A child was considered to be breastfed at 6 mo if he or she was breastfeeding at the time of the 6 mo questionnaire, whether or not supplemental formula or solid foods were used | A child was considered not to be breastfed at 6 mo if he or she was not breastfeeding at the time of the 6 mo questionnaire | | Confounders | 95%CI: | Selection | | x
% Male: 50.8 | | | | | | Gender | 0.59–0.74 | Study design | | x
Race: 68.4% both parents white | | | | | | Daycare attendance | Adjusted OR=0.69 | Confounder | | x
Enrolled/Evaluate: 15,113/11,349 | | | | | | Mother's marital status | 95%CI: | Blinding
Location: USA | | | | | | Mother's age | 0.61–0.78 | Data collection | x
Sites: Multi | | | | | | Mother's parity | | Withdraw and dropout | x
Funding: Contract no. 1-HD-4-3221 National | | | | | | Number of children in the home | | Analyses | x
Institute of Child and Human Development and the National Institute on Deafness and other Communication Disorders | | | | | | | | Intervention integrity | | x
| | | | | | | | Overall: B

Asthma

Burgess 2006

Gdalevich 2001 SRMA*

Kull 2004

Sears 2002

Wright 2001

* Systematic Review/Meta-Analysis

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | Bias/limitations Comments
Burgess, 2006 [16585289]
Mean GA (range): 185 | Prospective cohort with questionnaires at birth, 6 months, 5 and 14 years. Breastfeeding data collected at 6 months | Mothers and term singletons | Categories: | NA | At 14 years, mother reported asthma, qualitative answers to episodes of asthma past in 6 months. | Chi-square for categorical variables | Outcome | Breastfeeding duration | | | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 3402 | | | Never breastfed | | Supplemental questionnaire at 14 year follow-up requesting data on frequency of asthma meds, asthma-related sick days from school, asthma-related hospital admissions, parental history of asthma | Logistic regression adjusting for breastfeeding, maternal asthma, paternal asthma, smoking early and late pregnancy, frequency of coughs and cold first 6 months, annual family income | | No BF | 3 wk–3 mo | ≥4 mo | Selection | x
% Male: 52 | | | < 3 weeks | | | | Asthma | 1.0 | 1.03 (0.9–1.2) | 1.03 (0.9–1.2) | Study design | | x
Race: ND | | | 3 – 6 weeks | | | | OR_unadj_ (95% CI) | | | | Confounder | | x
Enrolled/Evaluate: 7223/4964 | | | 7 weeks – 3 months | | | | Of 4,964 subjects with breastfeeding and asthma data, 1408 (28%) mother-reported cases of adolescent asthma | | | | Blinding | | x
Location: Australia | | | ≥ 4 months | | | | 3,720 returned 14 year follow-up questionnaire | | | | Data collection | | x
Sites: Single | | | | | | | Nonsignificant relationship between duration of breastfeeding and asthma. Stratification for parental asthma or child's sex had no effect. No association for breastfeeding duration and asthma meds, asthma-related sick days from school or hospitalization | | | | Withdraw and dropout | | | x
Funding: ND | | | | | | | | | | | Analyses | | | x
| | | | | | | | | | | Intervention integrity | NA
| | | | | | | | | | | No reporting of adjusted OR, discrepancy for % males in table, dropout/withdraw > 30%, significant differences between completers and noncompleters, no definition or description of breastfeeding.
| | | | | | | | | | | Overall C

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] Topic | Gdalevich, 2001 Asthma
Literature search (Dates) | Medline (1966 to 1999); Other databases searched? (no); unpublished data used? (no)
Countries where primary studies conducted | Developed only: USA, Canada, UK, Italy, Australia and New Zealand
Study eligibility / inclusion criteria | Prospective studies; maternal recall of the child's feeding history of not more than 12 months; duration of BF for 3 months or more.
Study design [No. Of studies] | Prospective study design [12]
No. of subjects | 8,183
Study population (definition in included studies) | Children (with and without family h/o atopy and asthma and combined population)
Intervention/Exposure (definition in included studies) | Exclusive breastfeeding (3 mo or more with no substitutes or supplements to mother's milk or solids)
Comparator (definition in included studies) | without ≥ 3 mo of exclusive breastfeeding
Outcomes (definition in included studies) | Asthma (Diagnosed by physician, consecutive reporting of wheezing beyond the age of 1 year, and treatment for lower respiratory tract allergy were defined as study outcomes)
Heterogeneity assessments | Yes by graphical presentation and application of heterogeneity test
Quality assessments | Unclear; studies critically appraised on 8 items (maternal recall; blinded to exposure; duration of bf; exclusivity of bf; diagnostic criteria; blinded ascertainment of outcome; age; control for confounding)
Publication bias assessments | Yes; calculation of the fail-safe N
Statistical Analysis or meta-analytic methods | Fixed effect model; was also compared to random effects model
| Metric used odds ratio
Results | The summary OR was 0.47 (95% CI, 0.34–0.66) in the 5 studies (1788 subjects) with less than 2 years of follow-up, and 0.72 (95% CI, 0.62–0.84) in the 12 studies with 2 or more years of follow-up.
| The protective effect estimate of BF was more pronounced in the children with a family history of atopy in the subset of studies that assessed this population separately, OR= 0.52 (95% CI, 0.35–0.79), than in the studies in which both unstratified population data and children without atopic first-degree relatives were included, OR = 0.73 (95% CI, 0.62–0.86). When we further restricted the analysis to studies involving only children without a family history of atopy, the OR was 0.99 (95% CI, 0.48–2.03).
| Exclusion from the analysis of the studies with borderline blinding of diagnosing physicians 10,15,19 or those lacking a statement of BF exclusivity 20 yielded respective ORs of 0.71 (95% CI, 0.61–0.84) and 0.72 (95% CI, 0.61–0.85).
Quality of the systematic review | A
Author's interpretations of the results | The summary analysis of the 12 prospective studies supports the role of exclusive BF in the prevention of childhood asthma. The protective effect was higher in the subgroup of children with a positive family history of asthma or atopy.
Comments / Limitations | Children age range not mentioned; included studies that did not adjust for confounding;

Author, yr: Gdalevich, 2001
Topic of the systematic review*/MA: Asthma
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Y
2 | Types of exposure or intervention used | Y
3 | Types of study designs used | Y
4 | Study population | Y
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Y
6 | Effort to include all available studies (contact with authors) | Y
7 | Databases and registries searched | Y
8 | Method of addressing published articles other than English | N
9 | Method of handling abstracts and unpublished studies | Y
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Y
11 | Assessment of confounding | Y
12 | Assessment of quality | Y
13 | Assessment of heterogeneity | Y
14 | Description of statistical methods sufficient to replicate | Y
15 | Provision of appropriate tables and graphs | Y
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Y
17 | Tables giving descriptive information of each study included | Y
18 | Results of sensitivity testing (subgroup analysis) | Y
19 | Indication of statistical uncertainty of findings | Y
20 | Quantitative assessment of bias (eg. publication bias) | N
| Overall quality | A

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Y
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Y
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Y
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | Y
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Y
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Y
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Y
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Y
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Y
9 | Were conclusions justified by the reported/collected data and analysis? | Y

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | | Bias/limitations Comments
Kull, 2004; Kull, 2002
Wickman 2003
Mean GA (range): ND | Prospective, longitudinal cohort with final data collection at 4 year follow-up | All newborns from February 1994 through November 1996 in a predefined area of Stockholm, Sweden were invited to the study. 4089 (75%) of all infants were included. | The independent variable of breast-feeding was categorized as follows: exclusive breast-feeding was dichotomized with the 25^th^ percentile as the cutoff point (<4 months and ≥4 months) and as a 3-level categorical variable (0–2, 3–4, and ≥5 months). | Exclusive breastfeeding 0–2 months | Asthma: At 4 years of age, asthma was defined as at least 4 episodes of wheezing during the last 12 months or at least 1 episode of wheezing during the same period if the child was receiving inhaled steroids. | The relationship between breast-feeding and health outcomes was analyzed with logistic regression, adjusted for maternal age, maternal smoking during pregnancy or at 2 months of age, and heredity. | Outcome | | Exclusive BF | | | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): ND | | Data from all 4 questionnaires (at 2 months, 1, 2, and 4 years of age) were available for 3619 (88%) children. | The variable for exclusive breast-feeding was used in combination with a dichotomized variable of partial breast-feeding (0–2 and ≥3 months) to disentangle the effects of exclusive breast-feeding and an additional period of partial breast-feeding. The period of additional partial breast-feeding was calculated from the point when exclusive breastfeeding was finished. | Exclusive breastfeeding <4 months | Early-onset persistent asthma implies that the child fulfilled the asthma criteria not only at 4 years but also during the first 2 years of life. | Heredity: Heredity for allergic diseases was defined as physician diagnosed asthma, hay fever, or both in combination with allergy to a furred pet, pollen, or both in 1 (single heredity) or 2 (double heredity) parents. | | | 0–2 mo | 3–4 mo | ≥5 mo | Selection | x
% Male: 50.5 | | Complete answers on the subjects of breast-feeding, potential confounders, and outcome were required to be included in the analyses, leaving 3601 children (88% of the original study base) for analyses. | | | Early-onset transient asthma denotes that the child was fulfilling asthma criteria during the first 2 years of life but not at 4 years of age. | | Asthma | n/N | 48/541 | 41/701 | 111/2142 | Study design | x
Race: ND | | | | | Late onset of asthma implies that the child was not classified as having asthma during the first 2 years of life but fulfilled the asthma criteria at 4 years. | | OR_adj_ (95% CI) | | 1.0 | 0.67 (0.43–1.03) | 0.61 (0.42–0.86) | Confounder | x
Enrolled/Evaluate: 4089/3601 | | | | | | | Asthma & No heredity | n/N | 30/383 | 24/502 | 55/1500 | Blinding | | x
Location: Sweden | | | | | | | OR_adj_ (95% CI) | | 1.0 | 0.61 (0.36–1.06) | 0.48 (0.30–0.77) | Data collection | x
Sites: Multiple | | | | | | | Asthma & Heredity | n/N | 18/158 | 17/199 | 56/642 | Withdraw and dropout | x
Funding: Nonprofit; government | | | | | | | OR_adj_ (95% CI) | | 1.0 | 0.76 (0.37–1.54) | 0.81 (0.46–1.44) | Analyses | x
| | | | | | | Early-onset & persistent asthma | n/N | 25/532 | 19/687 | 36/2118 | Intervention integrity | N/A
| | | | | | | OR_adj_ (95% CI) | | 1.0 | 0.56 (0.30–1.04) | 0.35 (0.21–0.60) | Overall: A
| | | | | | | Early-onset transient asthma | n/N | 36/532 | 19/687 | 73/2118
| | | | | | | OR_adj_ (95% CI) | | 1.0 | 0.39 (0.22–0.69) | 0.51 (0.30–0.77)
| | | | | | | Late onset of asthma | n/N | 22/532 | 21/687 | 73/2118
| | | | | | | OR_adj_ (95% CI) | | 1.0 | 0.71 (0.38–1.31) | 0.82 (0.50–1.35)
| | | | | | | Note: The interaction between asthma and heredity was not statistically significant.
| | | | | | | The prevalence of asthma among children exclusively breastfed for less than 4 months was 9.1% compared with 6.4% among children breast-fed for 4 months or more (OR_adj_, 0.72; 95% CI, 0.53–0.97). The OR_adj_ for asthma related to breast-feeding for 4 months or more was 0.58 (95% CI, 0.38–0.88) in children without heredity for allergic diseases and 0.73 (95% CI, 0.43–1.20) in children with heredity.
Sears, 2002 [16585289]
Mean GA (range): ND | Ambidirectional cohort study - enrolled at age 3 and followed prospectively up to 21 years. Accompanied and unaccompanied assessments at 3, 5, 7, 9, 11, 13, 15, 18, 21, and 26 years. | Population study of live-born children | Categories: | NA | At age 9 years, ever having asthma from comprehensive questionnaires by interviewers with data on frequency of wheezing, asthma diagnosis, drugs, clinical characteristics, admissions; current asthma defined as positive response as reported by child or parent with accompanied symptoms of last 12 months; some verification by airway hyper-responsiveness | Chi-square for categorical variables | Outcome | | BF status | | P value | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range):ND | | | Not breastfed | | | Multivariate regression controlling for SES, birth order, sheepskin use in infancy, maternal smoking | | | No BF | >4 weeks | | Selection | x
% Male: ND | | | Breastfed > 4 weeks | | | | | | (n=504) | n=(533) | | Study design | x
Race: ND | | | Breastfed definition includes some formula feeding during birthing stay at hospital. Feeding history including duration of breastfeeding from regular, initially weekly, home & clinic visits during first 2–3 years | | | | Asthma ever at 9 years | n/N | 27/417 | 47/398 | 0.0081 | Confounder | x
Enrolled/Evaluate: 1037/1037 | | | | | | | OR_adj_ (95% CI) | | (6%) | (12%) | | Blinding | x
Location: New Zealand | | | | | | | | | 1.0 | 1.93 | | Data collection | x
Sites: Single | | | | | | | | | | (1.18–3.17) | | Withdraw and dropout | x
Funding: Government | | | | | | | Current asthma at 26 years | n/N | 74/496 | 113/484 | 0.0008 | Analyses | x
| | | | | | | | | (15%) | (23%) | | Intervention integrity | N/A
| | | | | | | OR_adj_ (95% CI) | | 1.0 | 1.74 | | Overall: A
| | | | | | | | | | (1.26–2.40)
| | | | | | | Current asthma with AHR at 9 years | n/N | 11/409 | 28/385 | 0.0028
| | | | | | | | | (3%) | (7%)
| | | | | | | OR_adj_ (95% CI) | | 1.0 | 2.83
| | | | | | | | | | (1.39–5.78)
| | | | | | | Asthma ever at 9 years | n/N | 10/229 | 23/216
| | | | | | | Family history negative | | (4%) | (11%)
| | | | | | | OR_adj_ (95% CI) | | | 2.61
| | | | | | | | | | (1.21–5.62)
| | | | | | | Asthma ever at 9 years | n/N | 16/174 | 23/174 | 0.291
| | | | | | | Family history positive | | (9%) | (13%)
| | | | | | | OR_adj_ (95% CI) | | | 1.50
| | | | | | | | | | (0.77–2.96)
| | | | | | | AHR, airway hyper-responsiveness to methacholine or salbutamol
| | | | | | | Multivariate analysis of current asthma at 9 years with breastfeeding > 4 weeks with adjusted OR 2.40 (1.36–4.26), p = 0.0027
| | | | | | | Analysis for different duration of BF showed similar results of greater risk of asthma at 9 years for more
Wright, 2000 [11065066]
Wright, 2001 [11182011]
Mean GA (range): ND | Prospective, longitudinal newborn cohort with questionnaires ascertaining respiratory health at 2, 3, 6, 9, 11, 13 years | Healthy newborn infants | Children classified by duration of exclusive breast feeding: never breast fed, breast fed exclusively <4 months, breast fed exclusively >4 months | NA | Physician diagnosed asthma, wheezing or asthma symptoms reported ≥ 2 questionnaires from ages 6 to 13 years | Bivariate analyses between feeding history and asthma, and stratified by maternal asthma status | Age 6–13: | | | | | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): ND | Additional data collection by health surveillance visit to MD | | | | | Logistic regression to assess odds of asthma, recurrent wheeze were related to breast feeding and maternal asthma adjusting for confounders: maternal education, smoking status in 1^st^ year, sex, ethnicity, 2 or more siblings at home or day care use versus neither first 6 months, paternal asthma | Nonsignificant for breastfeeding duration and asthma | | | | | Selection | x
% Male: ND | | | | | | | Nonsignificant for breastfeeding duration and asthma for children with non-asthmatic mothers OR_adj_ 2.1 (0.9–5.1) | | | | | Study design | x
Race: ND | | | | | | | Significant for maternal asthmatics OR_adj_ 8.7 (3.4–22.2) | | | | | Confounder | x
Enrolled/Evaluate: 1,246/926 | | | | | | | Maternal asthma status | | BF status | | | Blinding | | x
Location: USA | | | | | | | | | Never BF | <4 mo | ≥4 mo | Data collection | | x
Sites: Multiple | | | | | | | Maternal asthma p<0.05 | % | 9.1 | 23.5 | 46 | Withdraw and dropout | | x
Funding: Government | | | | | | | | n/N | 1/11 | 12/51 | 17/37 | Analyses | | x
| | | | | | | No maternal asthma | | 11.4 | 12.3 | 13 | Intervention integrity | NA
| | | | | | | | | 15/132 | 48/390 | 38/294 | Overall B
| | | | | | | | | | | | No explanation for WD/dropouts, discrepancies in numbers for exclusive BF

Atopic Dermatitis

Gdalevich 2001 SRMA*

* Systematic Review/Meta-Analysis

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] Topic | Gdalevich 2001 (UI 11568741) Atopic dermatitis
Literature search (Dates) | Medline (1966 to 5/2000); Other databases searched? No; unpublished data used? No
Countries where primary studies conducted | Not reported; but all studies were performed in developed countries
Study eligibility / inclusion criteria | Prospective studies of full-term infants in whom the ORs of atopic dermatitis associated with breastfeeding were reported or could be calculated. Exclusion: breastfeeding duration of <3 months; see paper for additional inclusion/exclusion criteria
Study design [No. Of studies] | 18 prospective studies were included
No. of subjects | 4158 subjects
Study population (definition in included studies) | Full-term infants
Intervention/Exposure (definition in included studies) | Exclusive breastfeeding for ≥ 3 months
Comparator (definition in included studies)
Outcomes (definition in included studies) | Strict diagnostic criteria for atopic dermatitis provided by the authors of the primary studies
Heterogeneity assessments | Nonsignificant heterogeneity (P=0.27)
Quality assessments
Publication bias assessments
Statistical Analysis or meta-analytic methods
Results | Fixed effect, overall OR 0.68 (95% CI 0.52, 0.88);
| After exclusion of unblinded studies, OR 0.77 (95% CI 0.60, 0.98)
| Analyses restricted to those with positive family history, OR 0.58 (95%CI 0.41, 0.92)
| Analyses restricted to those without family history, OR 0.84 (95%CI 0.59, 1.19)
Quality of the systematic review | A
Author's interpretations of the results | There is a substantial protective effect of breastfeeding against atopic dermatitis in children with a family history of atopy.
Comments / Limitations

Author, yr: Gdalevich 2001
Topic of the systematic review*/MA: Atopic dermatitis
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Y
2 | Types of exposure or intervention used | Y
3 | Types of study designs used | Y
4 | Study population | Y
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Y
6 | Effort to include all available studies (contact with authors) | Y
7 | Databases and registries searched | Y
8 | Method of addressing published articles other than English | N
9 | Method of handling abstracts and unpublished studies | N
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Y
11 | Assessment of confounding | Y
12 | Assessment of quality | Y
13 | Assessment of heterogeneity | Y
14 | Description of statistical methods sufficient to replicate | Y
15 | Provision of appropriate tables and graphs | Y
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Y
17 | Tables giving descriptive information of each study included | N
18 | Results of sensitivity testing (subgroup analysis) | Y
19 | Indication of statistical uncertainty of findings | Y
20 | Quantitative assessment of bias (eg. publication bias) | N
| Overall quality

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Y
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Y
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Y
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | Y
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Y
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Y
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Y
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Y/N
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Y
9 | Were conclusions justified by the reported/collected data and analysis? | Y

CVD Mortality

Martin 2004 SRMA*

* Systematic Review/Meta-Analysis

Evidence table for Systematic Reviews of Breastfeeding

Author,Year[UI] Topic | Martin, 2004 Cardiovascular Mortality
Literature search (Dates) | Medline (up to April 2003); Other databases searched? (yes); unpublished data used? (yes)
Countries where primary studies conducted | Developed countries: US and UK
Study eligibility / inclusion criteria | Articles were considered eligible for inclusion in the current review if infants who had been breastfed were compared with those who had been bottle (artificially) fed, if the outcome was cardiovascular disease or ischemic heart disease mortality, and if estimates of the association between having been breastfed in infancy and cardiovascular disease or ischemic heart disease mortality could be obtained from the paper or after correspondence with the authors.
Study design [No. Of studies] | Historical cohort studies [4]
No. of subjects | 25,166 at baseline; 10,785 at follow-up
Study population (definition in included studies) | Wingard, 1994: 1373 birth children in California
| Hertfordshire cohort: 5908 women and 10374 men born in 11 of 12 districts in Hertfordshire
| Boyd Orr: 4999 men and women from a survey of diet and health in pre-war Britain
| Caerphilly, 2003: 2512 meddle-aged men living in Caerphilly, South Wales
Intervention/Exposure (definition in included studies) | - Any or exclusive breastfeeding. If results for both any or exclusive breastfeeding were presented in the paper, the exclusive breastfeeding association was used in the meta-analysis.; - Prolonged breastfeeding: any or exclusive breastfeeding >1 year.
Comparator (definition in included studies) | Exclusive bottle-feeding
Outcomes (definition in included studies) | Cardiovascular disease or ischemic heart disease mortality
Heterogeneity assessments | Cochran's Q statistic
| I^2^ test
Quality assessments | No quality score was used, although specific aspects of the quality of each study, including control of confounding, loss to follow-up, recall bias, definition of breastfeeding, and sample size, were discussed
Publication bias assessments | Not done, although there was a discussion on publication bias as one of the potential limitations of the meta-analyses.
Statistical Analysis or meta-analytic methods | Random effect model
Results | - All four studies were historical cohorts born between 1904 and 1939.; - Random-effect models showed little difference in all cause mortality between breast and bottle-fed subjects (pooled rate ratio: 1.01; 95% CI: 0.91–1.13, p=0.8), and there was little evidence of heterogeneity.; - Five observations from three studies suggested little or no association between breastfeeding and cardiovascular disease mortality in both males and females, and one suggested a possible adverse effect (Caerphilly cohort). In random effects meta-analysis, cardiovascular disease mortality was similar in breastfed versus bottlefed subjects (pooled rate ratio: 1.06; 95% CI: 0.94–1.20). There was no statistical evidence of between-study heterogeneity.; - Ischemic heart disease mortality was 6% lower amongst males who had been breastfed in the Hertfordshire cohort, but 56% higher amongst breastfed females. This result is in line with point estimates from the Boyd Orr cohort suggesting that ischemic heart disease mortality was 10% lower amongst males who had been breastfed, but 40% higher amongst breastfed females (although there was little statistical evidence of interaction: p=0.2). In Caerphilly, however, ischemic heart disease mortality was 73% higher amongst breastfed males. In a random effects meta-analysis, there was evidence of heterogeneity.; - There was little evidence that prolonged breastfeeding was associated with all-cause mortality (pooled rate ratio: 0.94; 95% CI: 0.71–1.24), although there was moderate statistical evidence of heterogeneity.; - There was weak evidence that prolonged breastfeeding was associated with a 16% increase (95% CI: 0.99–1.36; p=0.06) in cardiovascular disease mortality, and no evidence of inconsistency in estimates.; - There was little evidence that prolonged breastfeeding was associated with ischemic heart disease mortality (rate ratio: 1.08; 95% CI: 0.88–1.31; p=0.5) and there was no heterogeneity.
Quality of the systematic review | B
Author's interpretations of the results | - There are at least three possible sources of bias in the studies reviewed: selection bias, information bias or recall bias (except for one study) and publication bias. Only 2 of the 4 studies had at least 70% of the target population in the follow-up. Recall bias is unlikely in only Hertfordshire cohort as breastfeeding was prospectively ascertained. Publication bias is possible but the studies were relatively large and unpublished estimates were obtained.; - As confounding and bias may have distorted results from individual studies, the statistical combination of estimates into a combined rate ratio needs to be interpreted with caution. Our new analysis, together with evidence from published and unpublished literature, does not provide strong evidence that breastfeeding is related to all-cause or cardiovascular disease mortality. The confidence limits around our point estimates and the observed between-study heterogeneity for associations between breastfeeding and ischemic heart disease, however, do not rule out important beneficial or adverse cardiovascular effects of breastfeeding.; - Although we found little evidence to support a cardioprotective effect of breastfeeding extending into old age, its beneficial influence on infant and child health and cognitive development supports the idea that it should be promoted as the infant feeding method of choice.
Comments / Limitations | We agree with authors' conclusion and discussion on the limitations of the meta-analyses. However, given large heterogeneity across studies (especially for IHD mortality), meta-analyses might not be appropriate. At least for the outcome of IHD mortality, men and women should be combined separately because of apparent effect modification by gender.Results from Hertford cohort were only adjusted for age.

Author, yr: Martin, 2004
Topic of the systematic review*/MA: CVD mortality
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Yes
2 | Types of exposure or intervention used | Yes
3 | Types of study designs used | Yes
4 | Study population | Yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Yes
6 | Effort to include all available studies (contact with authors) | Yes
7 | Databases and registries searched | Yes
8 | Method of addressing published articles other than English | No
9 | Method of handling abstracts and unpublished studies | Yes
| Reporting of Methods
10 | Rationale for selection and/or coding of data | No
11 | Assessment of confounding | Yes
12 | Assessment of quality | Yes
13 | Assessment of heterogeneity | Partially
14 | Description of statistical methods sufficient to replicate | Yes
15 | Provision of appropriate tables and graphs | Yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Yes
17 | Tables giving descriptive information of each study included | Yes
18 | Results of sensitivity testing (subgroup analysis) | No
19 | Indication of statistical uncertainty of findings | Yes
20 | Quantitative assessment of bias (eg. publication bias) | No
| Overall quality | B

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Yes
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | No
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Yes
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Partially
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | No
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Partially
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Yes
9 | Were conclusions justified by the reported/collected data and analysis? | Yes

Leukemia

Beral 2001 SRMA*

Davis 1998 SRMA*

Guise 2005 SRMA*

Kwan 2004 SRMA*

* Systematic Review/Meta-Analysis

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] Topic | Beral (or USCCS Investigators), 2000; 2001 Leukemia
Literature search (Dates) | ND
Countries where primary studies conducted | Mixed developed and developing countries
Study eligibility / inclusion criteria | Not described. Meta-analyses were performed for the associations between breastfeeding and leukemia, Hodgkin's disease, non-Hodgkin's lymphoma, other childhood cancers and all childhood cancers combined. For the purpose of our review, we focus on childhood leukemia only.
Study design [No. Of studies] | Case-control studies [15]
No. of subjects | Cases: 7,401 Controls: 14,587
Study population (definition in included studies) | Cases: Children with all leukemia, including ALL
| Controls: ND
Intervention/Exposure (definition in included studies) | Ever breastfeeding
| Breastfeeding duration ≤ 6 months
| Breastfeeding duration > 6 months
Comparator (definition in included studies) | never breast fed
Outcomes (definition in included studies) | All leukemia, including ALL
Heterogeneity assessments | ND
Quality assessments | ND
Publication bias assessments | ND
Statistical Analysis or meta-analytic methods | This is a primary study (UKCCS study) plus meta-analyses.
| No methods of meta-analyses were described.
Results | The UKCCS results did not differ significantly from those of previous studies. Results from previous studies were combined with UKCCS results. For childhood leukemia, there is evidence of a statistically significant reduction in the OR associated with ever having been breastfed (OR=0.86, 95%CI 0.81–0.92) and having been breastfed for more than 6 months (OR=0.78, 95% CI 0.71–0.85).
Quality of the systematic review | C
Author's interpretations of the results | It is unclear whether the apparent small reduction in the risk of each type of childhood cancer reported here is a non-specific effect of breastfeeding on childhood cancer or whether it reflects some systematic bias shared by the majority of the case-control studies that have investigated etiological factors in childhood cancer. We are unable to decide which of these possibilities is the more likely.
Comments / Limitations | This is a primary study (UKCCS study) plus meta-analyses. Authors focused on their results regarding the association between breastfeeding and childhood cancer in UKCCS study. No methods for the meta-analyses were described. They did not report the standard steps required for a systematic review, including explicit search criteria, inclusion and exclusion criteria, and quality assessment.
| However, we agree with the author's interpretations of the results.

Author, yr: Beral 2000; 2001
Topic of the systematic review*/MA: Leukemia
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Yes
2 | Types of exposure or intervention used | Yes
3 | Types of study designs used | Yes
4 | Study population | No
| Reporting of Search strategy
5 | Search strategy, including time period and key words | No
6 | Effort to include all available studies (contact with authors) | No
7 | Databases and registries searched | No
8 | Method of addressing published articles other than English | No
9 | Method of handling abstracts and unpublished studies | No
| Reporting of Methods
10 | Rationale for selection and/or coding of data | No
11 | Assessment of confounding | No
12 | Assessment of quality | No
13 | Assessment of heterogeneity | Yes
14 | Description of statistical methods sufficient to replicate | Yes
15 | Provision of appropriate tables and graphs | Yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Yes
17 | Tables giving descriptive information of each study included | No
18 | Results of sensitivity testing (subgroup analysis) | No
19 | Indication of statistical uncertainty of findings | Yes
20 | Quantitative assessment of bias (eg. publication bias) | No
| Overall quality | C

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Unclear
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | No
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | No
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | No
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | No
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | No
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | No
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Yes
9 | Were conclusions justified by the reported/collected data and analysis? | Yes

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] Topic | Davis, 1998 Leukemia
Literature search (Dates) | Medline (“over the past 10 to 15 years”); Other databases searched? (no); unpublished data used? (no)
Countries where primary studies conducted | Primarily developed countries: UK, USA, Italy
| Included one developing country: China
| For the purpose of our review, we excluded the study from China
Study eligibility / inclusion criteria | Not described, except the author stated that hypothesis of the study was that artificial infant feeding (or never breast fed) increases the risk for cancer in childhood. For the purpose of our review, we focus on childhood leukemia only.
Study design [No. Of studies] | Case-control studies [5]
No. of subjects | All leukemia [reported in 1 study]- Cases: 171 Controls: 342
| Acute lymphoblastic leukemia (ALL) [reported in all 5 studies]- Cases:1,356 Controls: 1,336
| Acute non-lymphoblastic leukemia (ANLL) [reported in 2 studies]- Cases: 129 Controls: 379
Study population (definition in included studies) | Cases: Children with all leukemia, ALL or ANLL
| Controls: Children with no cancers, except for one study used children with rhabdomyosarcoma as controls
Intervention/Exposure (definition in included studies) | Any breastfeeding
| Long-term breastfeeding: more than 6 to 8 months
Comparator (definition in included studies) | Artificial infant feeding (or never breast fed)
Outcomes (definition in included studies) | “All leukemia, ALL, and ANLL”
Heterogeneity assessments | ND
Quality assessments | ND
Publication bias assessments | ND
Statistical Analysis or meta-analytic methods | No meta-analysis was performed.
| The odds ratio and 95% CI or p values for the relationship between infant feeding and cancer in childhood were provided in the papers; in other cases where the number of exposed and unexposed cases and controls were provided, additional effect estimates were calculated in order to compare studies.
Results | None of the included studies reported a significant association between all leukemia, ALL or ANLL and infant feeding.
Quality of the systematic review | C
Author's interpretations of the results | No evidence of an association between infant feeding and any childhood cancer except for Hodgkin's disease.
Comments / Limitations | The main purpose of this review was to examine the association between infant feeding and childhood cancer. Due to non-significant findings for leukemia, the author did not focus on the results on leukemia. Inclusion or exclusion criteria were not described, no assessments of study heterogeneity or methodology quality.

Author, yr: Davis, 1998
Topic of the systematic review*/MA: Leukemia
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Yes
2 | Types of exposure or intervention used | Yes
3 | Types of study designs used | Yes
4 | Study population | Yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | No
6 | Effort to include all available studies (contact with authors) | No
7 | Databases and registries searched | Yes
8 | Method of addressing published articles other than English | No
9 | Method of handling abstracts and unpublished studies | No
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Yes
11 | Assessment of confounding | No
12 | Assessment of quality | No
13 | Assessment of heterogeneity | No
14 | Description of statistical methods sufficient to replicate | N/A
15 | Provision of appropriate tables and graphs | Yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | No
17 | Tables giving descriptive information of each study included | Yes
18 | Results of sensitivity testing (subgroup analysis) | N/A
19 | Indication of statistical uncertainty of findings | N/A
20 | Quantitative assessment of bias (eg. publication bias) | N/A
| Overall quality | C

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | No
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | No
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | No
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | No
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | N/A
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | No
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Yes
9 | Were conclusions justified by the reported/collected data and analysis? | Partially

Evidence table for Systematic Reviews of Breastfeeding

Author,Year[UI] Topic | Guise, 2005 Leukemia
Literature search (Dates) | Medline (1990-March 2004); Other databases searched? (no); unpublished data used? (no)
Countries where primary studies conducted | Developed countries only: Netherlands, Italy, US, Germany, Australia, New Zealand, Canada, England, Wales, Scotland, Sweden, France
Study eligibility / inclusion criteria | Studies providing data regarding the association of breastfeeding and occurrence of childhood leukemia. A study must have been in full text, been published after 1990, contained more than 100 participants, had concurrent comparison groups, been conducted in a developed country, and been published in the English language.
Study design [No. Of studies] | Case-control studies [10]
No. of subjects | 9,653 leukemia cases
Study population (definition in included studies) | Cases: Childhood ALL or all childhood leukemias
| Controls: Matched or unmatched population (majority) and hospital controls
Intervention/Exposure (definition in included studies) | Any measures of breastfeeding
Comparator (definition in included studies) | Any
Outcomes (definition in included studies) | Childhood ALL or all childhood leukemias defined in the original studies
Heterogeneity assessments | ND
Quality assessments | 2 independent investigators rated study quality by using criteria from the US Preventive Services Task Force and the National Health Service Center for Reviews and Dissemination. Three levels of grade: good, fair and poor quality. Studies received a poor rating if the cases were not assessed reliably, if the groups assembled were not comparable, if there was considerable attrition or differences in nonrespondents between cases and controls, or if there was not adequate consideration given to confounding.
Publication bias assessments | ND
Statistical Analysis or meta-analytic methods | No meta-analysis or statistical analysis was performed.
Results | Ten studies met all inclusion criteria and were reviewed for study quality to identify 2 good-quality case-control studies, 2 fair-quality studies, and 6 poor-quality studies. Of the 10 studies, 6 were conducted in European countries. All studies but 1 focused solely on childhood leukemia. The majority included <1000 cases. Notably, 6 of the studies explicitly sought to characterize the relationship between breastfeeding and leukemia as the primary objective, whereas the others included breastfeeding measures from the perspective measuring broader characteristics of the immune system and early infections in the etiology.
| The presented results focus on details and findings of the 2 good-quality studies, comparisons to the 2 fair quality studies, factors that distinguish them from studies rated as “poor” in quality, and implications for future research.
| The 2 good-quality studies (UKCCS and CCG studies) present conflicting results regarding the association between breastfeeding and leukemia. Similarly, the 2 fair-quality studies disagreed on the protective effect of breastfeeding.
Quality of the systematic review | A
Author's interpretations of the results | Of the 10 studies reviewed, only 4 were sufficient to provide at least fair-quality evidence regarding the association between maternal breastfeeding and childhood leukemia. Half of these 4 studies associated breastfeeding with a lower risk of ALL. Our review differs in methodology from previous meta-analyses performed by Beral et al and Kwan et al. Either of these groups examined studies for quality or used quality ratings as a determinate for inclusion in analysis.
| The primary findings of our review indicate that there are few high-quality studies. The studies frequently failed to measure important factors such as breastfeeding exclusivity (reporting ever breastfed rather than quantifying breastfeeding by exclusivity combined with duration) and consideration of other important confounders such as SES and other infectious exposures (such as household or school contacts). None of the studies included in this systematic review ere without flaw. An optimal study might be conducted within the framework of a large population-based registry or cohort with full access to medical records, pathology, and demographic data that would be able to accurately identify all cases of ALL diagnosed (with pathologic confirmation) at >1 year of age within a defined time period.
Comments / Limitations | A meta-analysis by Beral, 2001 (or UKCCS investigators) seemed to have performed a comprehensive search, but they did not report the standard steps required for a systematic review, including explicit search criteria, inclusion and exclusion criteria, and quality assessment. This meta-analysis included 15 studies. Of these 15 studies, 8 were also included in Guise, 2005. Four were excluded because they were published before 1990, and 3 were conducted in developing countries.
| Guise, 2005 (10 studies included) and Kwan, 2004 (14 studies included) had same set of studies, except that Guise excluded studies published before1990, and in developing countries. Guise, 2005 did not include non-peer-reviewed studies.
| Guise et al. discussed the differences between their review and previous meta-analyses by UKCCS investigators and Guise, 2005 in details. We thought their comments were fair.
| It would have been preferable if meta-analyses by taking into account study quality grading were also performed.

Author, yr: Guise, 2005
Topic of the systematic review*/MA: Leukemia
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Yes
2 | Types of exposure or intervention used | Yes
3 | Types of study designs used | Yes
4 | Study population | Yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Yes
6 | Effort to include all available studies (contact with authors) | No
7 | Databases and registries searched | Yes
8 | Method of addressing published articles other than English | No
9 | Method of handling abstracts and unpublished studies | No
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Yes
11 | Assessment of confounding | Yes
12 | Assessment of quality | Yes
13 | Assessment of heterogeneity | N/A
14 | Description of statistical methods sufficient to replicate | N/A
15 | Provision of appropriate tables and graphs | Yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | No
17 | Tables giving descriptive information of each study included | Yes
18 | Results of sensitivity testing (subgroup analysis) | N/A
19 | Indication of statistical uncertainty of findings | N/A
20 | Quantitative assessment of bias (eg. publication bias) | N/A
| Overall quality | A

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Yes
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | Yes
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Yes
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Yes
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | No
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Yes
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Yes
9 | Were conclusions justified by the reported/collected data and analysis? | Partially

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] Topic | Kwan, 2004 Leukemia
Literature search (Dates) | Medline (up to 2003); Other databases searched? (yes); unpublished data used? (yes)
Countries where primary studies conducted | Mostly developed countries: Netherlands, Italy, US, Germany, Australia, New Zealand, Canada, England, Wales, Scotland, Sweden, France
| 2 developing countries: China, Russia,
Study eligibility / inclusion criteria | Studies that presented data on any type of leukemia on children 15 years or younger in terms of an odds ratio and confidence interval and analyzed duration of breastfeeding in months were selected for the analysis.
Study design [No. Of studies] | Case-control studies [n=14]
| *Note 12 studies in developed countries. Since this is a meta-analysis article, we could not separate these 12 studies. Three of the 14 studies were not peer-reviewed.
No. of subjects | 6,835 ALL cases and 1,216 acute myeloid leukemia (AML), which included ANLL
Study population (definition in included studies) | Eight of the 14 studies excluded cases of leukemia in infants (usually children younger than 1 year of age) to avoid possible biases associated with premature cessation of breastfeeding in children with cancer and also because most leukemias occurring during infancy are know to have different etiologies from childhood leukemias.
Intervention/Exposure (definition in included studies) | Short-term breastfeeding, defined as breastfeeding for six months or less
| Long-term breastfeeding, defined as breastfeeding for more than six months
Comparator (definition in included studies) | No breastfeeding or never been breast-fed
Outcomes (definition in included studies) | The ALL classification was generally straightforward, with only one study specifying “leukemia” instead of “ALL”.
| Four studies used the classifications “other leukemias” or ANLL instead of AML. Nevertheless, they were included in the AML group since the majority of such cases are AML cases.
Heterogeneity assessments | Chi-square statistic
Quality assessments | ND, although there are comments on the potential biases for each included study in the summary tables
Publication bias assessments | Funnel plot
Statistical Analysis or meta-analytic methods | Fixed- and random-effect models.
| For each of the 14 articles reviewed, and R and its 95% CI were extracted. When available, ORs adjusted for SES were selected since SES was the most widely used potential confounder in these studies.
Results | - No evidence of publication bias was apparent for studies reporting results on the association between long-term breastfeeding and risk of ALL (p=0.58) or AML (p=0.46).; - A significant negative association was observed between short-term breastfeeding and ALL (OR=0.88, 95%CI 0.80–0.96), but the AML results (OR=0.90, 95%CI 0.80–1.02) were not significant.; - A significant negative association was observed between long-term breastfeeding and ALL (OR=0.76, 95%CI 0.68–0.84), and AML (OR=0.85, 95%CI 0.73–0.98).; - Heterogeneity statistics for leukemia types and duration of breastfeeding were not significant except for the ALL analysis addressing short-term breastfeeding (p=0.03). However, the results from fixed- and random-effect models were almost exactly the same.; - The following table (modified from table 4 in the original table) shows the ORs for SES-adjusted data from the meta-analysis, as well as separately from the United Kingdom Childhood Cancer study (UKCCS) and the Children's Cancer Group (CCG) study. Overall, SES as a potential confounder appeared to play no substantial role in the findings of either the short-term or long-term breastfeeding studies.
| Duration of breastfeeding | OR (95% CI)
| | ALL | AML
| Meta-analysis | N=6470 (85%) | N=1179 (15%)
| ≤6 months | 0.90 (0.82, 0.99) | 0.91 (0.80, 1.04)
| >6 months | 0.75 (0.67, 0.85) | 0.85 (0.73, 0.98)
| UKCCS 2001 | N=1401 (87%) | N=214 (13%)
| ≤6 months | 0.90 (0.77, 1.04) | 0.85 (0.60, 1.20)
| >6 months | 0.89 (0.75, 1.05) | 0.65 (0.43, 1.00)
| CCG study 1999 | N=1744 (79%) | N=456 (21%)
| ≤6 months | 0.86 (0.73, 1.01) | 0.95 (0.68, 1.33)
| >6 months | 0.72 (0.60, 0.87) | 0.57 (0.39, 0.84)
Quality of the systematic review | A
Author's interpretations of the results | This meta-analysis demonstrated protective association between breastfeeding and risk of childhood ALL and possibly AML. However, three alternative explanations must be considered First, a systematic bias may be present in case-control studies of childhood leukemia arising from differential participation rates for case and control samples that differed in SES. In the current meta-analysis, participation rates could be calculated for only six of the 14 included studies. For five of these six studies, the participation rates for cases were higher than those for controls, and in most of these studies, the controls were higher SES than the cases. Therefore the association of breastfeeding with SES in combination with differential participation rates by SES could have biased the OR toward a protective effect. Second, the effect on ALL risk may be spurious, as suggested by the results of the two cohort studies (Ref#22 and 23), unfortunately, these studies provided no information regarding AML. Third, the protective effect of breastfeeding may not be limited to ALL. Further evaluation of the biological mechanisms while taking into consideration potential biases can be feasibly achieved with more large-scale case-control studies utilizing population-based, SES-matched controls.
| In conclusion, the potential protective effect of breastfeeding on risk of childhood ALL may be more complicated than the current literature suggests. Nevertheless, the available evidence suggests that such a protective effect exists for both ALL and AML, with the caveats noted.
Comments / Limitations | We agree with authors' concerns regarding potential biases in the included studies. Their conclusion was appropriately cautious. However, the review still combined all studies regardless of these potential biases, and over-emphasized the importance of the results from the meta-analysis. We could not determine whether specific study should be included in the analyses. Perhaps combining results from only high-quality studies would be preferable, but unfortunately the review did not appraise the methodological quality of the primary studies.

Author, yr: Kwan, 2004
Topic of the systematic review*/MA: Leukemia
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Yes
2 | Types of exposure or intervention used | Yes
3 | Types of study designs used | Yes
4 | Study population | Yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Yes
6 | Effort to include all available studies (contact with authors) | Yes
7 | Databases and registries searched | Yes
8 | Method of addressing published articles other than English | No
9 | Method of handling abstracts and unpublished studies | Yes
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Yes
11 | Assessment of confounding | Yes
12 | Assessment of quality | Yes
13 | Assessment of heterogeneity | Yes
14 | Description of statistical methods sufficient to replicate | Yes
15 | Provision of appropriate tables and graphs | Yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Yes
17 | Tables giving descriptive information of each study included | Yes
18 | Results of sensitivity testing (subgroup analysis) | Yes
19 | Indication of statistical uncertainty of findings | Yes
20 | Quantitative assessment of bias (eg. publication bias) | Yes
| Overall quality | A

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Yes
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | No
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Yes
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Yes
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Yes
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Yes
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Yes
9 | Were conclusions justified by the reported/collected data and analysis? | Yes

Cognitive

Agostoni 2001

Anderson 1999 SRMA*

Angelsen 2001

Der 2006

Drane 2000 SRMA*

GomezSanchiz 2003 2004

Jain 2002 SRMA*

Lawlor 2006

Mortensen 2002

Oddy 2003 2004

Quinn 2001

* Systematic Review/Meta-Analysis

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Agostoni, 2001 [11787675]
Mean GA (range): term | Prospective cohort; Bayley results at 1 y/o were compared in breastfeeding ≥6 mo with 3–6 mo | Term infants; exclusively breastfed ≥3 mo | | | Cognitive outcome of interest: Bayley Mental Development Index (MDI) | Adjustment for parity, maternal education, age, and smoking habits | After adjustment, Bayley MDI in 29 subjects breastfed >6 mo compared to 15 subjects breastfed 3–6 mo showed a 2.0 point advantage (95% CI -3.2, 7.3). | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): | | | | | | | | Selection | | | x
% Male: 55% | | | | | | | | Study design | | | x
Race: | | | | | | | | Confounder | | x
Enrolled/Evaluate: 44/44 | | | | | | | | Blinding | | x
Location: Italy | | | | | | | | Data collection
Sites: Single/Multi | | | | | | | | Withdrawal and dropout | | | x
Funding: | | | | | | | | Analyses | | | x
| | | | | | | | Intervention integrity
| | | | | | | | Overall: C
| | | | | | | | Small sample size, Bayley at young age

Evidence table for Systematic Reviews

Author, Year[UI] Topic | Anderson, 1999 [UI] Cognitive Development
Systematic reviews/Meta-analyses/Both | Meta-analysis
Databases searched (Dates of literature search) | Medline (1966-1996); references identified in bibliographies.
Countries where primary studies conducted (Developed countries only or mixed) | Developed countries only: UK, US, Australia, Germany, New Zealand, and Spain
Study design [No. of studies] | Observational (n=11)
No. of subjects | 7,081
Study population and sampling | - Studies of association between breastfeeding and cognitive development in full-term and low-birth weight infants (?premature)
Intervention/Exposure | Many of the studies that were reviewed only reported breastfeeding versus bottle feeding, without more detailed information on exclusivity, frequency, or duration. Information on timing and duration of breastfeeding were included where available.
Comparator
Outcomes
Methods used for meta-analyses | Both fixed effects and random effects were calculated
Heterogeneity assessments | See below
Results | - Unadjusted (fixed effects) pooled mean difference for the 11 observations was 5.32 (95% CI, 4.51, 6.14); heterogeneous across studies; - Adjusted (fixed effects) pooled mean difference was 3.16 (95% CI, 2.35, 3.98); homogeneous across studies; - An average adjusted benefit of 5.18 points was obtained for low-birth weight children across 6 available observations
Authors' conclusions | After adjustment for key cofactors, breast-feeding was associated with significantly higher scores for cognitive development than was formula feeding
Quality of the systematic review | B
Comments | No appraisals of study quality (other than confounding); effect score is a standardized mean difference score of different cognitive measurements

Author, yr: Anderson, 1999
Topic of the systematic review*/MA: Cognitive SR
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Y
2 | Types of exposure or intervention used | Y
3 | Types of study designs used | Y
4 | Study population | Y
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Y/N
6 | Effort to include all available studies (contact with authors) | N
7 | Databases and registries searched | Y
8 | Method of addressing published articles other than English | N
9 | Method of handling abstracts and unpublished studies | N
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Y
11 | Assessment of confounding | Y
12 | Assessment of quality (in addition to confounding) | N
13 | Assessment of heterogeneity | Y
14 | Description of statistical methods sufficient to replicate | Y
15 | Provision of appropriate tables and graphs | Y
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Y
17 | Tables giving descriptive information of each study included | Y
18 | Results of sensitivity testing (subgroup analysis) | Y
19 | Indication of statistical uncertainty of findings | Y
20 | Quantitative assessment of bias (eg. publication bias) | N
| Overall quality

*When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Y
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Y
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Y/N
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | N
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | N
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Y/N
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Y
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Y
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Y
9 | Were conclusions justified by the reported/collected data and analysis? | Y

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Angelsen, 2001 [11517096]
Mean GA (range): 39.6 wk | Prospective cohort; 10% randomly selected from eligible population; | White, parity 1 or 2, singleton, registered prior to 20^th^ wk gestation | <3 mo, 3–6 mo, ≥ 6 mo | | Cognitive outcomes of interest: Bayley mental scores at 13 mo Wechsler Preschool and Primary Scales of Intelligence (WPPSI-R) at 5 y/o | Maternal IQ, age, education, smoking | Bayley mental score at 13 mo: 117.7 (SD11.7) in ≥ 6 mo breastfeeding compared to 109.9 (SD13.1) in < 3 mo (P<0.001). | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 3656 g | Duration of breastfeeding: retrospectively recorded | Excluded: <37 wk gestation, congenital malformation | | | | | There was a linear increase in mental development index plotted against breastfeeding duration (P<0.001). Maternal intelligence (Raven test score) was also related to duration of breastfeeding. Adjustment for differences in maternal intelligence reduced the OR of having a low mental developmental index among children who were breast fed for <3 mo to 1.6 (95%CI 1.1–2.3) from 3.2 (95%CI 1.7–5.9). | Selection | | x
% Male: | | | | | | | Total IQ at 5 y/o: 111 (SD14.3) in ≥ 6 mo breastfeeding compared to 103.6 (SD14.6) in < 3 mo (P<0.001, Sheffe's test). Adjustment for differences in maternal intelligence reduced the OR of having a low IQ score among children who were breastfed for <3 mo to 1.5 (95%CI 1.0–2.1) from 2.8 (95%CI 1.4–5.3). | Study design | | | x
Race: white | | | | | | | | Confounder/bias | | x
Enrolled/Evaluate: 521/345/291 (5 yr) | | | | | | | | Blinding | | x
Location: Norway & Sweden | | | | | | | | Data collection | | x
Sites: Multi | | | | | | | | Withdrawal and dropout | | | x
Funding: | | | | | | | | Analyses | | x
| | | | | | | | Intervention integrity
| | | | | | | | Overall: B
| | | | | | | | Results from multivariate analyses not reported.
Der, 2006 UI 17020911
Mean GA (range): term | Database analysis of a prospective study; sibling pairs analysis, and meta-analysis; | Excluded <35 wk gestation, <2500 g, born before 1979 | Breastfeeding history obtained within a year of birth in most cases | | Cognitive outcome of interest: Peabody individual achievement test | Adjustment for variables associated with breastfeeding in the survey, home environment (HOME-SF), child demographics, maternal characteristics | Unadjusted effect of breastfeeding +4.7 compared to non-breastfeeding (3161 mothers, 5475 children, 16,744 assessments); after adjustment for maternal AFQT score, education, age, family poverty, HOME stimulation score, and birth order, the difference became +0.52 (P=0.149) | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): | Database from the US national longitudinal survey of youth 1979 (NLSY79) and children of the women in the survey, Peabody individual achievement test (PIAT) was administered to children between the ages of 5 and 14 biennially from 1986 to 2002, all outcomes standardized to a mean of 100 and SD of 15; maternal cognitive ability was measured with the Armed Forces Qualification Test (AFQT); | | | | | | 332 pairs of sibling discordant for breastfeeding status and 545 discordant for duration of breastfeeding, difference between groups (status) = -0.63 (P=0.506); (duration) = -0.13 (P=0.866) | Selection | | x
% Male: | For meta-analysis, only included studies that quantified the effect of breastfeeding status on cognitive ability after controlling for parental intelligence among full term infants (Medline 1966 to 1/2006 and other sources) | | | | | | Meta-regression of 9 unique studies (including the data from NLSY79): an advantage of breastfeeding of 0.16 after controlling for IQ and 8 additional confounders. | Study design | x
Race: | | | | | | | Combined data from NLSY79 and sibling analysis study by Evenhouse (see separate extraction): estimate 0.025 (P=0.54) for breastfeeding status and 0.04 (P=0.271) for duration of breastfeeding | Confounder | x
Enrolled/Evaluate: 3161 mothers and 5475 children | | | | | | | | Blinding
Location: US | | | | | | | | Data collection
Sites: Multi | | | | | | | | Withdraw and dropout | x
Funding: | | | | | | | | Analyses | x
| | | | | | | | Intervention integrity
| | | | | | | | Overall: A
| | | | | | | | No details regarding breastfeeding history

Domain/question | Place an “X” in one
Selection Bias
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias (RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Evidence table for Systematic Reviews of Breastfeeding

Author,Year[UI] Topic | Drane 2000 Cognitive Development
Literature search (Dates) | Database not specified; literature search from 1966-98
Countries where primary studies conducted
Study eligibility / inclusion criteria | Subjects born between 1960 and 1998, English language, studies examined some aspect of cognitive development
Study design [No. Of studies] | Studies were assessed to determine if they met 3 methodological standards: definition of outcome: operational definition of cognitive outcome and outcome measure using standardized tests; correct classification of type of feeding: measure breast feeding as a continuous variable (duration of exclusive breast feeding or proportion of diet as breast milk) or at least as a 3-level categorical variable (exclusive breast or formula fed; partial breast fed); and control for potential confounding variables: socio-economic status, maternal education, birth weight, gestational age, birth order, gender in studies measuring verbal ability
No. of subjects
Study population (definition in included studies) | Term and preterm infants
Intervention/Exposure (definition in included studies)
Comparator (definition in included studies)
Outcomes (definition in included studies)
Heterogeneity assessments
Quality assessments
Publication bias assessments
Statistical Analysis or meta-analytic methods
Results | 24/30 studies met entry criteria. 5 studies met the 3 methodological standards.
| Lucas 1992, Lucas 1994, Horwood 1998, Malloy 1998; Rogan 1993 (considered to have met 2.5 standards because the duration that a baby was mostly breast fed was measured)
| Lucas 1994 was a RCT, the remaining 5 studies were cohorts.
| Advantages in IQ as measured by the WISC-R, Bayley and McCarthy Scales were observed in Lucas 1992, Rogan 1993, Pollock 1994, and Horwood 1998.
| In term infants, effects on IQ in the range of 2–5 points (0.2–0.3 SD) were found.
| In low birth weight infants who received breast milk, Lucas 1992 reported an 8 IQ point advantage.
| Lucas 1994 did not find statistical significant difference in Bayley Mental Development Scale scores in infants fed solely on a diet of donor breast milk compared with infants fed solely on a diet of term formula. Malloy 1998 did not find an effect of infant feeding on WISC-R scores at 9–10 years of age in term infants.
Quality of the systematic review | B
Author's interpretations of the results | “The question of whether breast feeding and formula feeding have differential effects on cognitive development has not been comprehensively answered. A minority of the studies reviewed met acceptable standards for validity and, thus, are likely to provide inaccurate estimates of the association between infant feeding and cognitive development.”
Comments / Limitations | The methodological standards proposed may not be universally accepted. Study designs were not taken into consideration. Conclusions are also limited by the fact that almost all the studies were cohorts.

Author, yr: Drane, 2000
Topic of the systematic review*/MA: cognitive
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Y
2 | Types of exposure or intervention used | Y
3 | Types of study designs used | Y
4 | Study population | Y
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Y
6 | Effort to include all available studies (contact with authors) | N
7 | Databases and registries searched | N
8 | Method of addressing published articles other than English | N
9 | Method of handling abstracts and unpublished studies | N
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Y
11 | Assessment of confounding | Y
12 | Assessment of quality | Y
13 | Assessment of heterogeneity | Y/N
14 | Description of statistical methods sufficient to replicate | N/A
15 | Provision of appropriate tables and graphs | Y
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Y
17 | Tables giving descriptive information of each study included | Y/N
18 | Results of sensitivity testing (subgroup analysis) | N/A
19 | Indication of statistical uncertainty of findings | N/A
20 | Quantitative assessment of bias (eg. publication bias) | N/A
| Overall quality

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Y/N
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Y
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Y
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | N
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Y/N
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Y
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Y
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Y/N
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Y
9 | Were conclusions justified by the reported/collected data and analysis? | Y

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
GomezSanchiz, 2003 [12635980]
GomezSanchiz, 2004 [15494884]
Mean GA (range): 39.6 wk | Prospective cohort from 1 rural (born 10/1995-9/1997) and 1 urban (born 3/1996-2/1998) sites, comparing breastfed > 4 mo, <4 mo, and formula fed; parents were informed of the project at 15 mo, Bayley was administered at 18 mo and 24 mo | 37–42 wk gestation, Apgar at 5 minutes ≥7, birthweight 2500–4500 g; | Information about type and duration of feeding was taken from medical records | | Cognitive outcome of interest: Bayley Mental Development index | Adjusted for parental IQ | 249/296 completed the study at 18 mo; 238 completed the study at 24 mo; the only difference between children taking part in the study and those not taking part was that the latter were less frequently first in birth order. Parental IQ was obtained only for 164 couples; their children had Mental Development Index 2.3 points higher than the children whose parents did not take part in IQ testing (P<0.05). Infants were breastfed for a mean of 85.7 days ± SD 76.4 days. Duration of breastfeeding had a correlation with Mental Development Index at 18 mo (r=0.42; P<0.001) and at 24 mo (r=0.37; P<0.001). | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 3344 g | | Exclusion: multiple births, adopted babies, mechanical ventilation, hospitalization during the neonatal period, major physical malformation, chromosome disorder, psychosocial risks or any circumstances likely to result in “retarded development”, height or weight <3%tile at 18 mo | | | | | Mental Development Index at 18 mo | Selection | | | x
% Male: | | | | | | | Formula 106.0±9.2 | Study design | | | x
Race: | | | | | | | Breastfeeding ≤ 4 mo 111.5±9.6 | Confounder | | x
Enrolled/Evaluate: 296/249 at 18 mo; | | | | | | | Breastfeeding > 4 mo 118.2±8.9 | Blinding | | x
238 at 24 mo | | | | | | | P<0.05 by Bonferroni in all post hoc pair comparisons | Data collection | | x
Location: Spain | | | | | | | At both 18 mo and 24 mo, after multiple linear regression adjusting for parental IQ, difference between formula and breastfeeding ≤ 4 mo no longer significant; difference of 4.3 points remained significant when comparing breastfeeding > 4 mo with ≤ 4 mo. | Withdrawal and dropout | | x
Sites: 1 rural, 1 urban | | | | | | | | Analyses | | x
Funding: | | | | | | | | Intervention integrity
| | | | | | | | Overall: B

Domain/question | Place an “X” in one
Selection Bias
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias (RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Author, Year[UI] Topic | Jain, 2002 Cognitive Development
Literature search (Dates) | Medline (1996-2/2001); Other databases searched? (no); unpublished data used? (no)
Countries where primary studies conducted
Study eligibility / inclusion criteria | English language studies; independently assessed the relationship between breastfeeding and a cognitive outcome; tests of motor ability alone were not included
Study design [No. Of studies] | 30 birth cohorts; 2 RCTs; 5 school registry cohorts; 3 case-control studies
No. of subjects | Ranged from 50 to >11,000
Study population (definition in included studies) | Term and pre-term children
Intervention/Exposure (definition in included studies) | Breastfeeding, breast milk, or choice to breast feed
Comparator (definition in included studies)
Outcomes (definition in included studies) | Appropriate outcome: standardized individual measure of general intelligence and that the assessment be done when the child was at least 2 years of age
Heterogeneity assessments
Quality assessments | Following were examined for each article: overall design of the study, sample size, target population, quality of feeding data, control of susceptibility bias, blinding, outcome measures, and format of results
Publication bias assessments
Statistical Analysis or meta-analytic methods
Results | 40 studies from 1929 to 2/2001 were included in this review; 1 40 separate papers were published. Because some of these papers investigated the same sample, there were only studies of 33 different groups of children.; 2 30 cohorts (27 with full-term children), 2 RCTs in preterm children, 5 school registry cohorts, and 3 case-control studies.; 3 35 articles either studied mixed full-term and preterm infants, only full-term infants, or did not specify the gestational age or birth weight. 5 articles studied exclusively low birth weight infants.; 4 Sample size ranged from 50 to >11,000; 5 Quality of feeding data (exclusive breastfeeding or not, timing of feeding data collection, source of feeding data, duration of breastfeeding): 9 articles met all 4 criteria (8 full-term cohorts); 15 articles did not adequately define breastfeeding by failing to report whether infants only received breast milk or were supplemented with formula or food. 2 preterm observational birth cohorts did not meet standard for appropriate definition of breastfeeding, it was defined as the “intent to breastfeed.”; 21 studies did not meet the standard for timing of data collection because the information was obtained either too late or too early. 27 included a feeding group for whom breastfeeding duration was at least 1 month.; 6 9 studies controlled adequately for both socioeconomic status and level of stimulation of the child; 31 studies controlled for socioeconomic status.; 7 15 studies stated that observers of the outcome were blind to feeding status.; 8 22 studies used an appropriate measure of cognition. Of the remaining studies, 8 measured outcomes in children <2 years of age, 3 used screening measures to assess cognition, 1 case control study used the presence of a learning disorder as its outcome measure, the other 2 case control studies used the diagnoses of pervasive developmental disorder and infantile autism, respectively, as outcome measures.; 9 33 studies reported some way to interpret the clinical significance of results, and 21 allowed calculation of an effect size.; 10 7 studies that found that the effects of breastfeeding statistically significant in the unadjusted analysis, became insignificant when controlling for socioeconomic status, stimulation, or other factors.; 11 Only 2 studies met all the methodological standards. One study concluded that “any beneficial effect of breastfeeding on cognitive development is quite small in magnitude”, another study found that children who were breastfed had mean IQ scores 4.6 points higher than those never breastfed after controlling for socioeconomic status and other factors. Among the studies that controlled for socioeconomic status and stimulation/interaction of the child (not including the previous 2), 3 concluded that breastfeeding promotes cognitive development, and 4 did not.
Quality of the systematic review | A
Author's interpretations of the results | “No convincing evidence exists regarding he comparative effects of breastfeeding and artificial feeding on intelligence.”
Comments / Limitations | Selection of methodological standards may not be acceptable to all investigators.

Author, yr: Jain, 2002
Topic of the systematic review*/MA: cognitive
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Y
2 | Types of exposure or intervention used | Y
3 | Types of study designs used | Y
4 | Study population | Y
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Y
6 | Effort to include all available studies (contact with authors) | N
7 | Databases and registries searched | Y
8 | Method of addressing published articles other than English | Y
9 | Method of handling abstracts and unpublished studies | N
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Y
11 | Assessment of confounding | Y
12 | Assessment of quality | Y
13 | Assessment of heterogeneity | Y/N
14 | Description of statistical methods sufficient to replicate | Y
15 | Provision of appropriate tables and graphs | Y
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | N/A
17 | Tables giving descriptive information of each study included | Y
18 | Results of sensitivity testing (subgroup analysis) | N
19 | Indication of statistical uncertainty of findings | Y/N
20 | Quantitative assessment of bias (eg. publication bias) | N
| Overall quality

*When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Y
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Y
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Y
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | Y
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Y
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Y
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Y
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Y/N
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Y
9 | Were conclusions justified by the reported/collected data and analysis? | Y

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Lawlor 2006 [16466433]
Mean GA (range): term and preterm (>98% term in followup N=3794) | Prospective cohort; Peabody Picture Vocabulary test at 5 years and Raven's standard progressive matrices at 14 years | Live birth who did not die before discharge from hospital | Duration of breastfeeding (never, <4 mos, ≥ 4 mos) was obtained from mothers at the 6-month followup assessment | | Cognitive outcome of interest: Raven's standard progressive matrices at 14 years | Adjustment for sex, parental characteristics (maternal age, ethnicity, education, paternal education, family income, gravidity, maternal smoking), labor, Apgar scores, birthweight, height, BMI | At age 14 years, Never breastfed = 694, <4 months = 1372, ≥ 4 months = 1606 | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 3794 ( | | | | | | | All parental characteristics were related to offspring IQ score. | Selection | x
% Male: 52% | | | | | | | Unadjusted scores at age 14 showed a mean difference of 4.43 (95%CI 3.09 to 5.77) in <4 mos breastfeeding vs never breastfeeding; 8.20 (95% CI6.89 to 9.49) in ≥ 4 mos breastfeeding vs never breastfeeding (P<0.001) | Study design | | x
Race: | | | | | | | Adjusted scores at age 14 (N=3099) for sex, parental characteristics (maternal age, ethnicity, education, paternal education, family income, gravidity, maternal smoking), labor, Apgar scores, birthweight, height, BMI showed a mean difference of 4.07 (95%CI 2.61 to 5.53) in <4 mos breastfeeding vs never breastfeeding; 6.79 (95%CI 5.33 to 8.26) in ≥ 4 mos breastfeeding vs never breastfeeding (P<0.001) | Confounder | x
Enrolled/Evaluate: 7223/3999 (5 yrs)/3794 (14 yrs) | | | | | | | Family income, parental education and breastfeeding explained 7.5% of the variation in intelligence at age 14. | Blinding | | | x
Location: Australia | | | | | | | Loss to followup was selective, those subjects were more likely to have mothers who were from poorer social backgrounds, lower education, and younger; regression analysis repeated using Heckman's sample selection bias adjustment with maternal age, parental education, and family income as the selection variables; results of these regression models did not differ from those who had followup. | Data collection
Sites: Single | | | | | | | | Withdrawal and dropout | | | x
Funding: | | | | | | | | Analyses | x
| | | | | | | | Intervention integrity
| | | | | | | | Overall: B
| | | | | | | | No information on exclusivity of breastfeeding, unclear if cognitive evaluation is blinded, large drop out

Domain/question | Place an “X” in one
Selection Bias
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias (RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | | | Bias/limitations Comments
Mortensen 2002 [11988057]
Mean GA (range): | Prospective cohort but the breastfeeding information was collected retrospectively at the 1-year examination. | Excluded twins | | | Relationship of WAIS score and BPP score to duration of breastfeeding | Adjusted for parental social status and education, single mother status, mother's height, age, and weight gain during pregnancy, cigarette during 3rd trimester, number of pregnancies, estimated gestational age, birthweight, birth length, and indices of pregnancy and delivery complications | Breastfeeding duration | | | | | | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): | There were 2 sub-cohorts; one participated in an ongoing developmental research program between 1982-1994 and took the WAIS at 27.2 years old; the other one took the draft board intelligence test: Borge Priens Prove (BPP) at 18.7 years; the BPP has a correlation of 0.82 with the full scale WAIS IQ. | | | | | | | <1mo | 2–3 mo | 4–6 mo | 7–9 mo | >9 mo | Selection | | x
% Male: 490/973 (50% in cohort 1); 2280 (100% in cohort 2) | | | | | | | WAIS | 99.4 | 101.7 | 102.3 | 106.0 | 104.0 | Study design | | x
Race: | | | | | | | Adjusted | P=0.003 for overall F test | | | | | Confounder | | | x
Enrolled/Evaluate: 973 had WAIS, 2280 had BPP test | | | | | | | BPP | 38.0 | 39.2 | 39.9 | 40.1 | 40.1 | Blinding | | | x
Location: Denmark | | | | | | | Adjusted | P=0.01 for overall F test | | | | | Data collection | | x
Sites: Single/Multi | | | | | | | | | | | | | Withdrawal and dropout | | x
Funding: | | | | | | | | | | | | | Analyses | | x
| | | | | | | | | | | | | Intervention integrity
| | | | | | | | | | | | | Overall: B

Domain/question | Place an “X” in one
Selection Bias
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias (RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Oddy, 2003 [12562475] contains the same data as in Oddy, 2004 [15384602]
Mean GA (range): 37–39 wk | Prospective cohort comparing no breastfeeding, <4 mo, 4–6 mo, and >4 mo of breastfeeding; | Children with non-English speaking parents were excluded; preterm infants were also excluded | | | Score of PPV-R at 6 y/o and Block Design score at 8 y/o | Association between breastfeeding duration and PPVT-R at 6 years and Block Design at 8 years were adjusted for gender, gestational age, maternal age and education, parental smoking, and the presence of older siblings. | 90% of children were breastfed at some point, 28% were breastfed for >6 mo, solid foods were introduced at ≤6 mo in 88% of infants | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): | Peabody Picture Vocabulary Test (PPVT-R) was administered at 6 y/o and a Performance subtest (Perceptual organization WISC- Block Design) at 8 y/o | | | | | | Both verbal IQ and performance scores increase with increasing maternal education combined with a longer duration of breastfeeding, with the most profound effect of breastfeeding occurring in the highest education groups (P<0.005). In the lower education groups, these trends were less consistent. | Selection | | x
% Male: | | | | | | | After adjustment for covariates, there was an association between duration of breastfeeding and verbal IQ with a 3.56 point advantage for children breastfed >6 mo compared with children never breastfed (F=8.59, P=0.003). The adjusted association of full breastfeeding with the Performance subtest was not significant (F=1.49, P=0.223). | Study design | | x
Race: | | | | | | | | Confounder | | | x
Enrolled/Evaluate: 2393 term at birth, 1444 at 6 years, 1371 at 8 years | | | | | | | | Blinding | | | x
Location: Australia | | | | | | | | Data collection | | x
Sites: Single/Multi | | | | | | | | Withdrawal and dropout | | | x
Funding: | | | | | | | | Analyses | | x
| | | | | | | | Intervention integrity
| | | | | | | | Overall: B

Domain/question | Place an “X” in one
Selection Bias
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias (RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Quinn 2001 [11885710]
Mean GA (range): | Prospective cohort; data were collected at enrollment, shortly after birth, at 6 months and at 5 years. | Singleton; | | | Score on PPVT-R | Adjusted for birthweight, poverty, maternal education, maternal age, time in daycare or preschool, number of children in the household at 5 years | Breastfeeding ≥6 mo 103.6 (SD 13.1) | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): | Peabody Picture Vocabulary Test (PPVT-R) was administered at 5 years. Results were analyzed in relation to breastfeeding duration. | At 5 years, children with major neurological abnormalities and those for whom the data were incomplete were excluded | | | | | No breastfeeding 94.2 (SD 14.1) | Selection | | x
% Male: 53% | | | | | | | There was a significant trend towards increasing PPVT-R with increased duration of breastfeeding (P=0.0000) | Study design | | | x
Race: | | | | | | | After adjustment, the mean for those breastfed ≥6 mo was 8.2 points (95%CI 6.5, 9.9) higher for females and 5.8 points (95%CI 4.1, 7.5) higher for males when compared to those never breastfed. | Confounder | | x
Enrolled/Evaluate: 4049/3880 | | | | | | | | Blinding | | | x
Location: Australia | | | | | | | | Data collection | | x
Sites: Single | | | | | | | | Withdrawal and dropout | | x
Funding: | | | | | | | | Analyses | | x
| | | | | | | | Intervention integrity
| | | | | | | | Overall: B

Domain/question | Place an “X” in one
Selection Bias
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias (RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Gastrointestinal Infections

Chien 2001 SRMA*

Quigley 2006

* Systematic Review/Meta-Analysis

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] | Chien, 2001 UI 11795054 Gastrointestinal (GI) Infection
Literature search (Dates) | Medline (1996 to 1/1998); Other databases searched? (Yes) Science Citation Index was used to identify frequently cited articles in the reference lists of studies from MEDLINE; unpublished data used? No
Countries where primary studies conducted | Industrialized countries (UK, New Zealand, US, Australia, Scotland)
Study eligibility / inclusion criteria | GI infection was defined to be any illness associated with vomiting, change in consistency or frequency of stools, or isolation of a known enteropathogenic bacterial or viral agent; GI outcome restricted to first year of life; excluded studies in which mortality was employed as a combined outcome event; excluded studies in which all the various types of infections were combined as an outcome measure
Study design [No. Of studies] | Prospective (12 studies, 5473 subjects) and retrospective (2 studies, 504 subjects) cohort studies; case-control studies (2 studies, 331 pairs);
No. of subjects | See above
Study population (definition in included studies)
Intervention/Exposure (definition in included studies)
Comparator (definition in included studies) | Infant feeding practices grouped into either exclusive breastfeeding and partial/mixed feeding or exclusive artificial feeding
Outcomes (definition in included studies)
Heterogeneity assessments | Yes
Quality assessments
Publication bias assessments
Statistical Analysis or meta-analytic methods | Fixed effect model; pooled results weighted according to sample size
Results | Conflicting results on the effect of breastfeeding on GI infection: 9/16 studies (56%) yielded a statistically significant protective effect of breastfeeding on GI infections;
| Majority of studies suffered from methodological deficiencies; 4 studies fulfilled criteria of controlling for detection bias, analyses of confounders, having a clear definition of infant feeding practices and infectious outcomes; 3 of these studies reported breastfeeding was protective against GI infection;
| Pooled estimate of the cohort studies: OR 0.36 (95% CI 0.32, 0.41; heterogeneity P<0.01)
| Pooled estimate of 2 case-control studies: OR 0.54 (95% CI 0.36, 0.80; heterogeneity P=0.35)
Quality of the systematic review | B
Author's interpretations of the results | “No firm conclusion can be drawn about the magnitude of a protective effect of breastfeeding against infections in industrialized countries, there is no doubt that it is protective in the case of many infants. This trend is most obvious in the studies of the highest quality.”
Comments / Limitations | Random effect model would be more appropriate; weighted according to sample size; not analyzed for potential confounding

| Author, yr: Chien, 2001
| Topic of the systematic review*/MA:
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Y
2 | Types of exposure or intervention used | Y
3 | Types of study designs used | Y
4 | Study population | Y
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Y/N
6 | Effort to include all available studies (contact with authors) | N
7 | Databases and registries searched | Y
8 | Method of addressing published articles other than English | N
9 | Method of handling abstracts and unpublished studies | N
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Y
11 | Assessment of confounding | Y/N
12 | Assessment of quality | Y
13 | Assessment of heterogeneity | Y
14 | Description of statistical methods sufficient to replicate | Y
15 | Provision of appropriate tables and graphs | Y
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Y
17 | Tables giving descriptive information of each study included | Y
18 | Results of sensitivity testing (subgroup analysis) | N
19 | Indication of statistical uncertainty of findings | Y
20 | Quantitative assessment of bias (eg. publication bias) | N
| Overall quality

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Y/N
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Y
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Y
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | N
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Y/N
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Y
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Y/N
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Y/N
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Y
9 | Were conclusions justified by the reported/collected data and analysis? | Y

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Quigley, 2006 [16308409]
Mean GA (range): | Case-control study; stratified by age group (0–3 mo, 3–5.9 mo, 6–8.9 mo, ≥ 9 mo), social deprivation score, location of practice (London, not London); questionnaire on current milk feeding | < 1 yr old and had data on infant feeding | Current exclusive breast milk (only milk received was breast milk, but many had been weaned on to solids), mixed feeding | Current formula | A diarrheal case was defined as “someone who presented to the General Practitioner with loose stools or significant vomiting < 2 weeks, in the absence of a known non-infectious cause and preceded by a symptom-free period of 3 weeks.” | age, sex, weaning, social class, travel, no access to food mixer, contact with person with diarrhea/vomiting in and outside household | Completed questionnaire: 190 cases (60%); 161 controls (90%); excluded 23 cases and 24 controls (no feeding data, no match, “other” feeding) | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): | | | | | | Multivariate analysis | Analyzed: 167 cases/ 137 controls | Selection | | x
% Male: 58 | | | | | | | Adjusted OR of diarrhea | Study design | | x
Race: | | | | | | | Current BF 0.36 (95% CI 0.18, 0.74) | Confounder | x
Enrolled/Evaluate: | | | | | | | Current not BF 1 | Blinding
167 cases/ 137 controls | | | | | | | P=0.005 | Data collection | | x
Location: UK | | | | | | | “Little evidence of the protection of breastfeeding persisting beyond 2 months following breastfeeding cessation.” | Withdraw and dropout | | x
Sites: Multi | | | | | | | | Analyses | | x
Funding: | | | | | | | | Intervention integrity
| | | | | | | | Cannot rule out recall or response biases

Infant Mortality

Chen 2004

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Chen 2004 [15121986]
Mean GA (range): ND | Case control study design | Subjects included in the 1988 US National Maternal and Infant Health Survey data to analyze the association between breastfeeding and postneonatal death. | Ever vs Never | Ever vs Never | Post neonatal death: death after 28 days | Because of the oversampling of black and low birth weight infants SUDAAN adjusted analysis was performed to re-weight the sample for the overall estimates and to calculate the ORs and 95% confidence intervals in the final models. | Showed an OR of 0.79 (95% CI: 0.67–0.93) for ever breastfed. Race-specific analyses gave similar estimates for the OR, although the proportion ever breastfed was much lower in black infants. | A: strong B: moderate C: weak | A | B | C
Mean BW (range):<2500g 26% live birth (controls) and 24% postneonatal death (cases) | Follow-up NA | | | | | Logistic regression models | For duration of breastfeeding, comparing cases who survived 3 months (n = 691 in original sample and n = 5363 after adjustment with SUDAAN) and all controls, 3 months or more of breastfeeding showed an OR of 0.62 (95% CI: 0.46–0.82), less (ie, more protective) than the OR for ever/never breastfed (0.79; 95% CI:0.67–0.93). | Selection | | x
% Male: 50.3 live birth 59.8% postneonatal death | | | | | | Adjusted for mother's age, education, and smoking during pregnancy and infant's gender, race (except for race subgroup analyses), birth weight (except for birth weight subgroup analyses), congenital malformation reported at birth, live birth order, plurality, and WIC status. | The OR for overall postneonatal death was 0.74 (95% CI: 0.63–0.87). Among cases only, a proportional hazard model showed that the risk of death at any specific time was marginally lower in the ever breastfed infants (hazard ratio: 0.91; 95% CI: 0.79–1.06). | Study design | | x
Race: White 44.4 (controls) 50.0 (cases) | | | | | | | | Confounder | | x
Black 52.2 (controls) 46.6 (cases) | | | | | | | | Blinding | | x
Others 3.4 (controls) 3.4 (cases) | | | | | | | | Data collection | | x
Enrolled/Evaluate: NA | | | | | | | | Withdraw and dropout | | x
Location: national level data | | | | | | | | Analyses | | x
Sites: Multi (population based) | | | | | | | | Intervention integrity | | x
Funding: ND | | | | | | | | Overall B

Respiratory Tract Diseases

Bachrach 2003 SRMA*

* Systematic Review/Meta-Analysis

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] Topic | Bachrach, 2003 [12622672] Respiratory Illness
Literature search (Dates) | Medline (1966-2002); Other databases searched? (yes); unpublished data used? (yes)
Countries where primary studies conducted | Developed countries (US, Canada, New Zealand, Australia, Scotland, Norway)
Study eligibility / inclusion criteria | Included studies from developed countries; healthy full-term infants; and provided data on exclusive breast feeding
| Excluded studies on cystic fibrosis and allergic conditions; sick, premature, and/or low birth weight infants
Study design [No. Of studies] | Prospective cohort [5]; retrospective cohort [2]; ecological study [1]; cross-sectional [1]. Only cohort studies were combined.
No. of subjects | 3201 exposed / 1324 unexposed
Study population (definition in included studies) | Healthy full term infants
Intervention/Exposure (definition in included studies) | Exclusive breastfeeding at least of 2 months or 9 months of total (any) breastfeeding
Comparator (definition in included studies) | None breastfeeding
Outcomes (definition in included studies) | Hospitalization due to lower respiratory tract disease (LRTD) in infancy: bronchiolitis, asthma, pneumonia, empyema, and infections due to specific agents (eg, RSV)
Heterogeneity assessments | Yes; No statistical heterogeneity. Used sensitivity analysis to test appropriateness of combining studies.
Quality assessments | None
Publication bias assessments | None (but the authors examined unpublished data)
Statistical Analysis or meta-analytic methods | Random effects model; subgroup analyses for two covariates - smoking and SES
Results | Summary relative risk from 7 cohort studies: 0.28 (0.14 – 0.54)
Quality of the systematic review | A
Author's interpretations of the results | Consistent effect was found among all primary studies that indicated a protective role of breastfeeding in LRTD
Comments / Limitations | Included studies that had precise definition of breastfeeding

| Author, yr: Bachrach, 2003
| Topic of the systematic review*/MA: Breastfeeding and LRTI
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Y
2 | Types of exposure or intervention used | Y
3 | Types of study designs used | Y
4 | Study population | Y
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Y
6 | Effort to include all available studies (contact with authors) | Y
7 | Databases and registries searched | Y
8 | Method of addressing published articles other than English | Y
9 | Method of handling abstracts and unpublished studies | Y
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Y
11 | Assessment of confounding | Y
12 | Assessment of quality | N
13 | Assessment of heterogeneity | Y
14 | Description of statistical methods sufficient to replicate | Y
15 | Provision of appropriate tables and graphs | Y
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Y
17 | Tables giving descriptive information of each study included | Y
18 | Results of sensitivity testing (subgroup analysis) | Y
19 | Indication of statistical uncertainty of findings | N
20 | Quantitative assessment of bias (eg. publication bias) | N
| Overall quality | A

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)?
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | partially
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | no
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | yes
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | yes
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | yes
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | yes
9 | Were conclusions justified by the reported/collected data and analysis? | yes

Obesity

Arenz 2004 SRMA*

Harder 2005 SRMA*

Owen 2005 SRMA*

* Systematic Review/Meta-Analysis

Author,Year[UI] Topic | Arenz, 2004 [15314625] Obesity
Literature search (Dates) | Medline (1966-Dec 2003); Other databases searched? (yes); unpublished data used? (no)
Countries where primary studies conducted | Developed countries: Germany, USA, Britain, Australia, New Zealand, Czech Republic
Study eligibility / inclusion criteria | - Population-based cohort, cross-sectional or case-control studies with children older than 1 y at the last follow-up stage, published in English, French, Italian, Spanish or German.; - Only studies with adjustment for at least three of the following relevant confounding or interacting factors birth weight, parental overweight, parental smoking, dietary factors, physical activity and socioeconomic status were included in this meta-analysis.; - Odds ratio or relative risk had to be reported and age at the last follow-up had to be between 5 and 18 y; feeding-mode had to be assessed and reported and obesity as outcome had to be defined by body mass index (BMI) percentiles >90, 95 or 97 kg/m2. If risk estimates were calculated for different percentile values in a particular study, the estimate for the highest percentile-value was included in the meta-analysis.
Study design [No. Of studies] | Studies did not meet inclusion criteria for meta-analyses: prospective cohort study [11]; retrospective cohort [1]; cross-sectional study [4]; case-control study [2]
| Studies met inclusion criteria for meta-analyses: prospective cohort study [2]; cross-sectional study [7]
No. of subjects | For studies met inclusion criteria for meta-analyses only: 69,000
Study population (definition in included studies) | Children and adolescents. One study included some adult subjects but the various odds ratios were reported depending on age and not clear which odds ratio was used in the meta-analyses.
Intervention/Exposure (definition in included studies) | Definition of feeding mode varied across studies:
Comparator (definition in included studies) | Never BF or partly BF < 3 months vs. BF ≥ 3 month; mostly or only BF vs. mostly or only formula feeding in the first 6 months; BF never vs. ever; BF never vs. > 6 months, BF groups: <1 week, 1 week-1 months, 2–3 months, 4–6 months, 7–9 month, > 9 months (exclusivity of BF not reported)
Outcomes (definition in included studies) | Definition of childhood obesity varied across studies:
| BMI ≥97th percentile, >95th percentile, definition according to Cole et al.
Heterogeneity assessments | Sensitivity analyses by testing the stability of the findings across different approaches in study design, exposure ascertainment and selection of study participants.
Quality assessments | ND
Publication bias assessments | Funnel plot
Statistical Analysis or meta-analytic methods | Fixed-effect and random-effect model: both crude and adjusted odds ratios (AOR) of the studies were used.
Results | - In total, 28 studies met the inclusion criteria for the systematic review, 19 of them were not eligible for the meta-analysis.; - The pooled crude OR for breast-feeding and obesity defined as BMI >90th, 95th or 97th percentile could be calculated for six studies. In the fixed-effects model, the OR was 0.67, 95% CI (0.62, 0.73). In the random effects model an almost identical OR was found (data not shown).; - The AOR calculated for nine studies was 0.78, 95% CI (0.71, 0.85) for both fixed and random-effects model.; - Sensitivity analyses were performed, comparing the studies according to the following criteria: cohort study or cross-sectional study, different definitions of breast-feeding, different definitions of obesity, different age-groups and number of potential confounders considered for adjustment. The protective effect of breast-feeding was more pronounced in studies with adjustment for less than seven potential confounding factors compared to adjustment for seven or more potential confounding factors.; - The funnel plot showed an asymmetric pattern, which was due to a particular study. The funnel plot regression analysis did not reject the null hypothesis of symmetry (df=8, P=0.71), suggesting that there was no publication bias.
Quality of the systematic review | A
Author's interpretations of the results | “The results from meta-analysis indicate that breast-feeding is associated with a small but consistent protective effect against obesity risk in later childhood.”
Comments / Limitations | Highly heterogeneous definitions of breastfeeding across studies overall meta-analysis was inappropriate, but sensitivity analyses were performed to reduce heterogeneity. Sensitivity analyses are very important but very few studies in each stratum due to small number of studies met the criteria for meta-analyses.

| Author, yr: Arenz, 2004
| Topic of the systematic review*/MA:
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Yes
2 | Types of exposure or intervention used | Yes
3 | Types of study designs used | Yes
4 | Study population | Yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Yes
6 | Effort to include all available studies (contact with authors) | Yes
7 | Databases and registries searched | Yes
8 | Method of addressing published articles other than English | No
9 | Method of handling abstracts and unpublished studies | No
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Yes
11 | Assessment of confounding | Yes
12 | Assessment of quality | Yes
13 | Assessment of heterogeneity | Yes
14 | Description of statistical methods sufficient to replicate | Yes
15 | Provision of appropriate tables and graphs | Yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Yes
17 | Tables giving descriptive information of each study included | Yes
18 | Results of sensitivity testing (subgroup analysis) | Yes
19 | Indication of statistical uncertainty of findings | Yes
20 | Quantitative assessment of bias (eg. publication bias) | Yes
| Overall quality | A

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Yes
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | ND
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Yes
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Yes
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Yes
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Yes
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Partially
9 | Were conclusions justified by the reported/collected data and analysis? | Yes

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] Topic | Harder, 2005 [16076830] Obesity
Literature search (Dates) | Medline (1966-December 2003); Other databases searched? (yes); unpublished data used? (no)
Countries where primary studies conducted | Developed countries: UK, US, Canada, Germany, Australia, New Zealand, Czechoslovakia
Study eligibility / inclusion criteria | 1) an original report comparing breastfed subjects with exclusively formula-fed subjects (referent group) of any given age, 2) report the odds ratio and 95% CI (or data to calculate them) of overweight or obesity associated with breastfeeding, and 3) report the duration of breastfeeding for at least one exposure group.
Study design [No. Of studies] | Cohort (including cross-sectional design) [16]; case-control study [1]
No. of subjects | Ranged 66 to 32,200 total 120,831
Study population (definition in included studies) | Primarily children. Two studies included adults.
Intervention/Exposure (definition in included studies) | Median duration of breastfeeding categories: < 1 month (reference), 1–3 month, 4–6 months, 7–9 months, > 9month
Comparator (definition in included studies) | Each month increase in the duration of breastfeeding: We calculated a study specific regression coefficient and corresponding 95% CI for each study by use of a log-linear model. The resulting odds ratio and 95% CI for change in risk for each month of breastfeeding were pooled with a random-effect model
Outcomes (definition in included studies) | Any definition of overweight or obesity, varied across studies
Heterogeneity assessments | ND
Quality assessments | ND
Publication bias assessments | Funnel plot with Begg test and Egger test
Statistical Analysis or meta-analytic methods | Unadjusted odds ratios and 95% CI were calculated directly from the data given in the articles, where possible. Otherwise, the published odds ratio and 95% CI were used. Three approaches were taken: First, duration of breastfeeding as the independent variable and the weighted odds ratio for overweight in breastfed probands, compared with formula-fed subjects, as the dependent variable (for meta-regression). Second, the random-effect model pooled odds ratio for overweight in breastfed subjects was calculated separately for five predefined categories of duration of breastfeeding. Third, the pool-first method was used to combine the regression coefficients obtained from the studies (for trend estimation).
| For meta-regression analysis, all duration-specific odds ratios had to be related to the respective duration of breastfeeding. The median of the upper and lower limits of each category of duration of breastfeeding was assigned to the particular estimate in each study. Estimates were plotted against the respective duration of breastfeeding as independent variable. A weighted meta-regression with duration of breastfeeding as the covariate was perform (random-effects model).
| For studies that provided data for more than two categories of duration of breastfeeding, we applied the “pool-first method” to quantify the dose-response relation. This was possible for 11 studies. We calculated a study specific regression coefficient and corresponding 95% CI for each study by use of a log-linear model. The resulting odds ratio and 95% CI for change in risk for each month of breastfeeding were pooled with a random-effect model.
Results | - From the 17 studies that reported duration of breastfeeding, 14 gave data for more than one category of duration of breastfeeding, leading to 52 estimates included in the meta-regression analysis. In the weighted meta-regression, duration of breastfeeding was significantly negatively related to risk of overweight (regression coefficient: 0.94, 95%CI 0.89–0.98).; - From 1 month of breastfeeding onward, the risk of subsequent overweight continuously decreased up to a reduction of more than 30%, reaching a plateau at 9 months of breastfeeding.
| Duration of breastfeeding
| | <1 mo | 1–3 mo | 4–6 mo | 7–9 mo | >9 mo
| No. of duration-specific study estimates | 5 | 14 | 15 | 11 | 7
| OR for overweight | 1.0 | 0.81 | 0.76 | 0.67 | 0.68
| 95% CI | 0.65, 1.55 | 0.74, 0.88 | 0.67, 0.86 | 0.55, 0.82 | 0.50, 0.91
| - Each month of breastfeeding was found to be associated with a 4% decrease in risk (OR: 0.96/month of breastfeeding, 95%CI 0.94–0.98). A fixed-effects model revealed a similar pooled OR and a nearly identical 95% CI (OR: 0.96/month of breastfeeding, 95%CI 0.95–0.98); - In only two of these studies was the influence of the duration of exclusive breastfeeding analyzed. The pooled OR for risk of overweight per month of exclusive breastfeeding was 0.94 (95%CI 0.89–0.99, random-effect model); - Subgroup analyses revealed that the definition of overweight influenced the estimate only slightly. In studies that used BMI to define overweight, the pooled OR was 0.96 (95%CI 0.94–0.98) for 8 studies, while the OR was 0.93 (95%CI 0.87–0.99) for the 3 studies that used another measure to define overweight or obesity.; - The age at examination had only a marginal influence on the magnitude of the effect of duration of breastfeeding on risk of overweight. The pooled OR from all 5 studies investigating probands up to or including 5 years of age was 0.97 (95%CI 0.94–0.99), while in older subjects aged 6 or more years, it was 0.96 (95%CI 0.93–0.99) for 6 studies.; - No evidence of publication bias was observed, as indicated by a symmetric funnel plot and a nonsignificant Begg test and Egger test.
Quality of the systematic review | B
Author's interpretations of the results | “Using three different techniques, we show that a longer duration of breastfeeding is associated with a larger decrease in risk of overweight. Each of the three methods used in our study has its own advantages and limitations.”
| “In summary, we found that the duration of breastfeeding is inversely and linearly associated with the risk of overweight. The risk of overweight was reduced by 4% for each month of breastfeeding. This effect lasted up to a duration of breastfeeding of 9 months and was independent of the definition of overweight and age at follow-up. Even if interpreted as being of relatively small size, this association, if causal, might be of importance for the general population. Since the majority of studies analyzed here used partially breastfed subjects, it might be concluded that, beyond exclusive breastfeeding, also longer partial breastfeeding up to 9 months leads to a greater decrease in risk of overweight in later life, which might be considered in future clinical recommendation.”
Comments / Limitations | The meta-analyses addressing the relationship between duration of breastfeeding and the risk of overweight was well-performed. However, the authors' conclusion implied a causal relationship, which is not appropriate because most of the “cohort” studies included in the analyses were in fact cross-sectional studies because the breastfeeding exposure was ascertained retrospectively at the time of the assessment of obesity. Causality cannot be ascertained in cross-sectional design. Most importantly, crude OR was used in the meta-analyses, which is the major limitation.

| Author, yr: Harder, 2005
| Topic of the systematic review*/MA: Obesity
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Yes
2 | Types of exposure or intervention used | Yes
3 | Types of study designs used | Yes
4 | Study population | Yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Yes
6 | Effort to include all available studies (contact with authors) | Yes
7 | Databases and registries searched | Yes
8 | Method of addressing published articles other than English | No
9 | Method of handling abstracts and unpublished studies | No
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Yes
11 | Assessment of confounding | Partially
12 | Assessment of quality | Partially
13 | Assessment of heterogeneity | No
14 | Description of statistical methods sufficient to replicate | Yes
15 | Provision of appropriate tables and graphs | Yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Yes
17 | Tables giving descriptive information of each study included | Yes
18 | Results of sensitivity testing (subgroup analysis) | Yes
19 | Indication of statistical uncertainty of findings | Yes
20 | Quantitative assessment of bias (eg. publication bias) | Yes
| Overall quality | B

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Yes
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | ND
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Partially
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Yes
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Yes
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Partially
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Yes
9 | Were conclusions justified by the reported/collected data and analysis? | Yes

Author, Year[UI] Topic | Owen, 2005 Obesity
Literature search (Dates) | Medline (completed in September 2003); Other databases searched? (yes); unpublished data used? (no)
Countries where primary studies conducted | Developed and developing countries: UK, Germany, USA, Canada, Italy, Turkey, Australia, New Zealand, Slovak Republic, China, Czech Republic, Sweden
Study eligibility / inclusion criteria | 61 studies that compared a measure of obesity (quantitatively or narratively) among breastfed and formula-fed subjects were considered. Studies that defined the odds of obesity or being overweight for breastfed and formula-fed subjects were reported more often and were included in a meta-analysis; 28 studies with 29 estimates (1 study reported results for 2 populations) met this inclusion criterion.
Study design [No. Of studies] | Historical cohort, prospective cohort, cross-sectional studies: total 61 studies, and 28 studies included in the meta-analyses
No. of subjects | N=298,900 in the overall meta-analysis
Study population (definition in included studies) | 28 studies (298,900 subjects) provided 29 unadjusted odds ratios relating the initial infant feeding method and obesity. Four observations were for infants, 23 for children, and 2 for adults.
Intervention/Exposure (definition in included studies) | Breastfed vs. formula-fed.
Comparator (definition in included studies) | The exclusiveness of infant feeding was based on the classification given in each article. The feeding groups were defined as being mutually exclusive in 4 studies, the breastfed group included mixed feeders in 7 studies and the formula-fed group included mixed feeders in 7 studies. In 2 studies in which infants were breastfed exclusively, the exclusivity of formula feeding could not be determined.
Outcomes (definition in included studies) | Any measures of obesity or adiposity.
| Most studies used a percentile cutoff based on BMI, describing subjects at the tail of the distribution. The 95th or 97th percentile was used most often, although some studies used cutoff values as low as the 85th percentile. A smaller number of studies used absolute BMI values or cutoff values based on standardized weight or weight for height. Studies involving infants used definitions based on percentiles of weight for length or percentiles of weight only.
Heterogeneity assessments | Q test with chi-square statistics
Quality assessments | ND
Publication bias assessments | Begg funnel plot. Reporting bias was also assessed.
Statistical Analysis or meta-analytic methods | Results from fixed-effects models are reported throughout, because these reflect only the random error within each study, are more conservative because they are less affected by results of smaller studies that show stronger associations, and make no assumptions about the representativeness of the available studies.
| Meta-regression was used to examine the influence of the following factors (defined a priori) with a test for trend: study size (<500, 500–2500, or >2500 subjects), age group at outcome measurement (infants <=1 year of age, young children >1 to 9 years of age, older children 10 to <16 years of age, or adults >=16 years of age), year of birth, and response rates (analyzed as a continuous variable). The effects of adjustment for factors such as parental body size (mostly BMI), socioeconomic status, and maternal smoking were examined in 6 studies that provided data before and after adjustment for all 3 of these factors. The effects of study methods, particularly the method of ascertainment of infant feeding status (whether contemporary or recalled over a period of >=3 years), study response rate, and definition of obesity (equivalent to <95th percentile, 95th to <97th percentile, or >=97th percentile of BMI), were examined with meta-regression and sensitivity analyses.
Results | - Among 61 observational studies that reported on the effects of infant feeding on a measure of adiposity in later life, 28 studies (298 900 subjects) provided 29 unadjusted odds ratios relating the initial infant feeding method and obesity. Four observations were for infants, 23 for children, and 2 for adults.; - In a fixed-effects model including all studies, breastfed subjects were less likely to be defined as obese than were formula-fed subjects (OR: 0.87; 95% CI: 0.85–0.89). There was evidence of marked heterogeneity among studies (p<0.001).; - Odds ratios of 0.50 (95% CI: 0.26– 0.94) for infants, 0.90 (95% CI: 0.87– 0.92) for young children, 0.66 (95% CI: 0.60–0.72) for older children, and 0.80 (95% CI: 0.71– 0.91) for adults were observed (test for trend, P= .85, adjusted for study size; P=.99 with the exclusion of infants).; - In 6 studies, it was possible to examine the effect of adjustment for the following potentially important confounders: socioeconomic status, parental BMI, and current maternal smoking or maternal smoking in early life. The pooled odds ratio in these studies was reduced from 0.86 (95% CI: 0.81– 0.91) before adjustment to 0.93 (95% CI: 0.88–0.99) after combined adjustment.; - In 14 studies with information on breastfeeding duration, the effect of breastfeeding over formula feeding was greater among subjects breastfed for >=2 months (OR: 0.81; 95% CI: 0.77– 0.84), compared with those breastfed for any duration (OR: 0.89; 95% CI: 0.86–0.91) in the same studies.; - Studies that did not provide odds ratios were much less likely to report that breastfeeding was associated with a reduced risk of obesity, compared with studies that did provide odds ratios (1 of 35 studies and 18 of 29 studies, respectively; P<.001).
Quality of the systematic review | B
Author's interpretations of the results | “The association between breastfeeding and obesity could reflect selective reporting and/or publication. Our results indicated selective reporting of odds ratios by studies that showed a relationship between breastfeeding and reduced risk of obesity. However, because the studies that did not present odds ratios were on average much smaller than those that presented data, their inclusion had a minimal impact on effect estimates.”
Comments / Limitations | Why not use random-effect model?

| Author, yr: Owen, 2005
| Topic of the systematic review*/MA:
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Yes
2 | Types of exposure or intervention used | Yes
3 | Types of study designs used | Yes
4 | Study population | Yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Yes
6 | Effort to include all available studies (contact with authors) | Yes
7 | Databases and registries searched | Yes
8 | Method of addressing published articles other than English | No
9 | Method of handling abstracts and unpublished studies | No
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Yes
11 | Assessment of confounding | Partially
12 | Assessment of quality | Yes
13 | Assessment of heterogeneity | Yes
14 | Description of statistical methods sufficient to replicate | Yes
15 | Provision of appropriate tables and graphs | Yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Yes
17 | Tables giving descriptive information of each study included | Yes
18 | Results of sensitivity testing (subgroup analysis) | Yes
19 | Indication of statistical uncertainty of findings | Yes
20 | Quantitative assessment of bias (eg. publication bias) | Yes
| Overall quality | B

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Yes
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | Yes
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Yes
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Partially
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Yes
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Yes
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Yes
9 | Were conclusions justified by the reported/collected data and analysis? | Yes

Sudden Infant Death Syndrome

Hauck 2003

McVea 2000 SRMA*

Mitchell 1997

Schellscheidt 1997

Venneman 2005

* Systematic Review/Meta-Analysis

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Hauck, 2003 [UI# 12728140]
Mean GA (range): 89 days for cases and 85 days for controls | Case-control study | Cases: Included Chicago resident infants whose death between Nov 1993 and April 1996 was determined by the office of medical examiner of Cook County, Illinois to be caused by SIDS | Breastfeeding current yes and ever yes | Breastfeeding current no and ever no | SIDS: The sudden death of an infant under 1 yr of age, which remains unexplained after a thorough case investigation, including performance of a complete autopsy, examination of the death scene, and review of the clinical history. | Univariate and multivariate models | Breast feeding No was reference | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 2813 g cases and 2915g for controls | Follow-up NA | Two weeks after caregivers were asked 235 questions | | | | Adjusted for maternal age, marital status, education, and index of prenatal care | Breast feeding ever No (cases v controls)/Yes (cases v controls) N=205 v 130 / 55 v 130 | Selection | x
% Male: nd | | Controls: One living control infant was matched to each case infant on maternal race/ethnicity, age at death/interview; and birth weight. They were randomly selected in groups of 20 for white infants and in groups of 40 for Hispanic and black infants | | | | | OR=0.2 (0.1–0.3) | Study design | | x
Race: 75% black; 13.1% Hispanic white; 11.9% non-Hispanic white | | | | | | | Adj OR=0.4 (0.2–0.7) | Confounder | x
Enrolled/Evaluate: 260 SIDS and 260 matched controls | | | | | | | Breastfeeding current No (cases v controls)/Yes (cases v controls) | Blinding
Location: community | | | | | | | N=243 v 199 / 17 v 61 | Data collection
Sites: Single/Multi Population based | | | | | | | OR=0.2 (0.1–0.4) | Withdraw and dropout
Funding: Gov | | | | | | | Adj OR=0.3 (0.2–0.7) | Analyses
| | | | | | | | Intervention integrity | | x

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] | McVea 2000 [11138219] SIDS
Topic | The role of breastfeeding in sudden infant death syndrome (SIDS)
Key questions addressed | Question 1 - Infant mortality
Dates of literature search - | 1966-1997
Databases searched | MEDLINE-all English language literature search
| Dissertation Abstracts Online
| Bibliography of all relevant articles
Countries where primary studies conducted | Developed (Regions - North America, Europe, and Australia)
(Developed v developing)
Study eligibility / inclusion criteria | Minimal definition of SIDS was met (sudden unexplained death of an infant or young child)
| Original data presented that allowed calculation of an odds ratio for bottle feeding
Study design [No. Of studies] | Total = 23
| Case control [18]
| Nested case control [4]
| Cohort [1]
No. of subjects | Cases (n=99) Controls (n=47 413)
Study population (definition in included studies) | Children (Age range birth to 2 years when outcome occurred - 17 studies; 8 studies nd on age range)
Intervention (definition in included studies) | Breast feeding (No standard method of measuring breast feeding was used in the studies - breastfed at birth, breastfed at the time of death, “breast fed”, “partially breast fed”)
Comparator (definition in included studies) | Bottle fed (nd)
Outcomes (definition in included studies) | SIDS (autopsy proven in majority - 14 studies, death certificates or coroner's reports - 4 studies, unclear - 6 studies)
Heterogeneity | Not explored although studies were heterogeneous with respect to a variety of factors
Quality of Individual studies | Yes. Quality scores of studies ranged from 11 to 36 points (on a 42 point max score)
| Better quality studies reported slightly higher risks of bottle feeding
Publication bias | Yes. “The shape of the funnel graph endorsed the absence of publication bias of only positive studies”
Statistical Analysis | Random Effects model
| Used unadjusted odds ratio for the meta-analysis
| Separate meta-analysis was performed using only those studies with “good” quality scores and after 1988
| Dose-response relationship explored
Results | The pooled OR for the 23 studies using random effects model resulted in an OR = 2.11 (95% CI 1.66–2.68) i.e. the overall risk of SIDS was twice as great for bottle-fed infants compared to breastfed infants.
| The pooled OR from the higher quality studies also demonstrated a two fold increase in risk among bottle fed infants OR = 2.24
| The pooled OR from studies after 1988 OR = 2.32
| Confounders: Individual studies adjusted for potential confounders; 6 studies reported adjusted OR; 4 studies reported no protective effect of breastfeeding, while 2 reported adj OR that remained significant.
| Dose Response relationship: 4 out of 9 studies showed a dose response trend with the risk of SIDS increasing with increasing formula feeding. None of the studies had sufficient power to demonstrate a statistically significant difference between partial v no breastfeeding.
Quality of the systematic review | C (see limitations)
Comments / Limitations | Misclassification of SIDS and breastfeeding
| Unadjusted odds ratio for pooled analysis
| Heterogeneity not explored
| Unable to combine studies with adjusted OR in the pooled analysis because of differences in case matching

| Author, yr: McVea, 2000
| Topic of the systematic review*/MA: The role of breastfeeding in SIDS
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Y
2 | Types of exposure or intervention used | Y
3 | Types of study designs used | Y
4 | Study population | Y
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Y
6 | Effort to include all available studies (contact with authors) | N
7 | Databases and registries searched | Y
8 | Method of addressing published articles other than English | N
9 | Method of handling abstracts and unpublished studies | Y
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Y
11 | Assessment of confounding | N
12 | Assessment of quality | Y
13 | Assessment of heterogeneity | N
14 | Description of statistical methods sufficient to replicate | Y
15 | Provision of appropriate tables and graphs | Y
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Y
17 | Tables giving descriptive information of each study included | Y
18 | Results of sensitivity testing (subgroup analysis) | N
19 | Indication of statistical uncertainty of findings | Y
20 | Quantitative assessment of bias (eg. publication bias) | N
| Overall Quality | C

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | partially
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | partially
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | no
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | yes
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | yes
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | yes
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | no
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | yes
9 | Were conclusions justified by the reported/collected data and analysis? | partially

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Mitchell 1997 [UI# 9346984]
Mean GA (range): 2.6–9.1 wk for cases; 2.4–9.2 wk for controls | Case-cohort study design 2 yr cohort; follow-up duration NA | Cases: All deaths registered by the New Zealand Health Information Service as attributable to SIDS in the postneonatal age group (dying after 28 completed days and within the first year of life) form the cases of this study. 98% of deaths classified as SIDS have had a autopsy. | Three measures of breastfeeding reference yes | No for the three measures of the breastfeeding | SIDS: dying after 28 completed days and within the first year of life | Univariate and multivariate analysis | The three measures of breastfeeding were not statistically associated with a statistically significant reduction in the risk of SIDS | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): <2500 to 3500+ | | Controls: Randomly selected sample from a prospectively collected cohort on all births in the 2 yr period. The method of sampling was 1) a date of birth was randomly selected from all the days in the study period; 2) an obstetric hospital was randomly chosen in proportion to the number of births; 3) in the obstetric hospital with multiple births on nominated date of birth random numbers were used to select a particular infant from among those born on that day; 4) a direction variable which indicates to either go forward or back in looking for a birth in the situation where the hospital did not have one on the nominated day was also randomly chosen | Exclusive breastfeeding at discharge from the obstetric hospital; any breastfeeding at initial contact; and any breast feeding at 2 months | | | Controlled for: maternal age, marital status, age mother left school, previous number of pregnancies, infant's sex, ethnicity of infant, birthweight, sleep position, breastfeeding and bed sharing/maternal smoking combinations. | | Selection | | | x
% Male: 60% cases; 52% controls | | | | | | | | Study design | x
Race: Maori 56% cases and 22% controls | | | | | | | | Confounder | x
Non Maori 44% cases and 78% controls | | | | | | | | Blinding
Enrolled/Evaluate: 232 cases and 922 controls | | | | | | | | Data collection
Location: community | | | | | | | | Withdraw and dropout
Sites: Single/Multi Population based | | | | | | | | Analyses
Funding: Gov | | | | | | | | Intervention integrity | | | x
| | | | | Comments | The controls were randomly selected from a prospective cohort; however the analysis was conducted as a case-control study. Overall quality = B

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Schellscheidt J 1997 [UI# 9266202]
Mean GA (range): 8 days to one yr | Case-control study | For cases: No positive autopsy findings; minimal findings without any relationship to death; findings possibly related to death (but not explaining it) and autopsy findings explaining death. | Breastfeeding in weeks | Breastfeeding in weeks | Same as eligibility criteria | Variables were entered as dichotomous indicators | Breast feeding cases versus controls | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): nd | Follow-up Not applicable | For controls: Two controls were selected for each case of the same age ±4 weeks and sex randomly by the pediatrician or a general practitioner | >12 wks (ref) | 1–6 wks | | Analyses were univariate. No confounders were adjusted | None (N=29 vs 27) | Selection | x
% Male: nd | Incidence of SIDS during the 2 yrs | | | 7–12 wks | | | OR=7.7 (2.7, 22.3) | Study design | x
Race: nd | | | | None | | | 1–6 wk (N=12 vs 40) | Confounder | | | x
Enrolled/Evaluate: 59 | | | | | | | OR=2.1 (0.7, 6.7) | Blinding | | x
Location: community | | | | | | | 7–12 wk (N=10 vs 39) | Data collection | | x
Sites: Single/Multi | | | | | | | OR=1.8 (0.6, 6.0) | Withdraw and dropout
Population based study | | | | | | | >12 wk (N=7 vs 50) REF | Analyses | | | x
Funding: nd | | | | | | | | Intervention integrity

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Vennemann, 2005 [UI# 16188764]
Mean GA (range): nd | Case-control study design | Cases: All reported cases of sudden and unexpected deaths in the first year of life after the first 7 d and all cases were autopsied. | Breastfeeding >2 wk yes | Breastfeeding >2wk No | Sudden and unexpected deaths in the first year of life after the first 7 d and all cases were autopsied. | Univariate and multivariate analysis were done using conditional logistic regression. The multivariate model includes all variables which were found significant at the 5% level in the univariate analysis except gestational age, as this was closely related to birthweight | Breastfeeding >2wk | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): nd | Duration SIDS during 3 yr period | Controls: Three controls with the best age matching were chosen | | | | | Yes N=165/827 (cases/controls) | Selection | x
% Male: cases 60.4% | Follow-up duration NA | | | | | | No N=168/171 | Study design | x
Controls 60.3% | | | | | | | Univariate OR=5.36 (3.97–7.23) | Confounder | | x
Race: nd | | | | | | | Multivariate OR=1.71 (1.06–2.77) | Blinding | | x
Enrolled/Evaluate: SIDS cases 404/333 | | | | | | | | Data collection | | x
Location: population based | | | | | | | | Withdraw and dropout | | x
Sites: Single/Multi 18 centers involved | | | | | | | | Analyses | | x
Funding: nd | | | | | | | | Intervention integrity | | x
| | | | | | | | Overall = B

Type 1 DM

EURODIAS 2002

Gerstein 1994 SRMA*

Jones 1998

McKinney 1999

Meloni 1997

Norris 1996 SRMA*

Tai 1998

Visalli 2003

* Systematic Review/Meta-Analysis

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
EURODIAS, 2002 [12351473]
Age at Dx of IDDM: ND | Case-control study | Cases: cases were identified from a population-based register of childhood-onset diabetes operating in a sub-study of EURODIAB (5 participating centers) | Parents were interviewed or filled in the questionnaire regarding information about infant feeding (duration of breast-feeding, age at introduction of formula feeding, dairy milk, food containing fruit, vegetable, fish, meat, and egg). | Never breast-feeding | Pooled ORs of IDDM for exposures obtained from each center | Mantel Haenszel approach was used to pool odds ratio (ORs) for exposures (e.g. breastfeeding, early introduction of solid food) obtained from each center, to test the significance of the combined OR, and to test for heterogeneity in the ORs between centers. | Breast-feeding of any duration was associated with a reduction in risk, with a pooled OR of 0.75 (95% CI 0.58–0.96) and no evidence of heterogeneity between centers. | A: strong, B: moderate, C: weak | A | B | C
Mean GA (range): ND | | Controls: a population-based sample of control children, matched to the patients in age distribution, was obtained in each center using sources that depended on local circumstances as previously described (including schools, population register, polyclinics, and general practitioner register) | Breast-feeding of any duration (or ever breast-feeding) | | | To adjust for potential confounders, logistic regression analysis was used with terms included in the model to represent centers. Adjustments included height SDS, weight SDS, maternal age at delivery, neonatal jaundice, neonatal respiratory infection, vitamin D supplementation, and asthma. | The introduction of cow's milk before 3 months of age (OR 1.15, 95%CI 0.74–1.81), cow's milk or formula (OR 1.01, 95%CI 0.81–1.25), or solid foods (OR 0.74, 95%CI 0.57–0.95) was not associated with any significant elevation in risk. Indeed the finding for solid foods suggested a reduced risk, although there was significant heterogeneity between centers (p<0.001). | Selection | | x
Mean BW (range): ND | | | | | | | The OR associated with breastfeeding in multivariate analysis remained significant (OR=0.59, 95%CI 0.35–0.97) | Study design | | x
% Male: ND | | | | | | | | Confounder | x
Race: ND | | | | | | | | Blinding | | | x
Enrolled/Evaluate: 683/610 for cases; 2167/1616 for controls | | | | | | | | Data collection | | x
Location: Europe | | | | | | | | Withdraw and dropout | | x
Sites: Multi | | | | | | | | Analyses | x
Funding: Government | | | | | | | | Intervention integrity | N/A
| | | | | | | | Overall: B
| | | | | | | | Long-term recalls

Q1: Insulin-Dependent Diabetes Mellitus

Author, Year[UI] | Gerstein, 1994 [8112184] Type 1 Diabetes Mellitus
Literature search (Dates) | Medline (no data); Other databases searched? (no); unpublished data used? (yes)
Countries where primary studies conducted | Developed countries only: Norway, Denmark, Italy, US, Australia, Canada, Sweden, Finland, UK
Study eligibility / inclusion criteria | Articles or letters to the editor were eligible for inclusion if they reported original research dealing with both type I diabetes and cow's milk exposure or avoidance and were published in peer-reviewed journals. Articles were excluded if they exclusively used surrogate markers for either type I diabetes or cow's milk exposure.
Study design [No. Of studies] | Ecological and time-series studies [3]; Case-control studies [13]; Cohort study [1]; case series [1]
No. of subjects | Data available for case-control studies only:
| Cases: 3,708 Controls: 20,340
Study population (definition in included studies) | - Ecological and time-series studies in which the prevalence of type I DM was compared with the rate of breast-feeding or cow's milk consumption in different populations or over a specified period of time.; - Case-control studies in which the neonatal feeding histories of patients with type I DM and individually matched non-DM control subjects were compared. Studies that used population breast-feeding registries as control data also were included, because the low prevalence of type I DM in the general population ensures that population data is representative of the breast-feeding habits of non-DM individuals.; - There was a letter to the editor reporting an analysis of two cohort studies and an article that described the neonatal feeding history of a series of patients with DM.; - There were no controlled trials of exposure to cow's milk.
Intervention/Exposure (definition in included studies) | Cow's milk exposure (and therefore non-exclusive breastfeeding)
Comparator (definition in included studies) | Cow's milk avoidance (and therefore breastfeeding)
Outcomes (definition in included studies) | Type I DM.
| Surrogate markers of type I DM (such as the presence of islet cell antibodies) were excluded.
Heterogeneity assessments | Q statistics and chi-square distribution
Quality assessments | Six methodological criteria were assessed for case-control studies only. Each criterion was marked individually and listed in a summary table of all studies. There was no summary grading.
Publication bias assessments | Not done
Statistical Analysis or meta-analytic methods | Meta-analyses of ORs were done for case-control studies. Both adjusted (preferred) and unadjusted ORs were used. Fixed-effect model.
Results | - Time-series and ecological studies showed an association (geographically and temporally) between rate/prevalence of breastfeeding and the incidence of type I DM.; - Results from the 13 case-control studies were mixed. Some of these studies demonstrated that patients with type I DM were more likely to have a history of neonatal cow's milk exposure or a short/negative history of breast-feeding than non-DM control subjects; other studies failed to demonstrate such a relationship. When these results were meta-analyzed, the OR for type I DM in patients exposed to <3 months of breast-feeding was 1.38 (95% CI 1.22–1.53; p=0.11 for homogeneity). Similarly, the overall OR for cow's milk exposure before 3–4 months of age in patients with type I DM was 1.57 (95% CI 1.19–2.07; p=0.10 for homogeneity).; - An analysis of two cohorts of children born in the UK in 1958 and 1970 followed for 16 and 10 years, respectively, failed to show any association between breastfeeding for <1 month and type I DM.
Quality of the systematic review | B
Author's interpretations of the results | The results of this review are consistent with the hypothesis that avoidance of cow's milk products during the first few months of life may reduce the risk of type I DM. A feeding intervention trial in which susceptible newborns would be randomized to receive formula with or without cow's milk and followed for the development of DM would most clearly resolve the issue.
Comments / Limitations | This systematic review primarily aimed to examine the relationship between early cow's milk exposure and type I DM. However, exclusive breastfeeding is a way of avoidance of cow's milk exposure; then therefore this review also examined the association between breastfeeding and type I DM. The exclusivity of breastfeeding was not addressed in the meta-analyses.
| Combining both adjusted and crude OR.

| Author, yr: Gerstein, 1994
| Topic of the systematic review*/MA: Type 1 DM
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Yes
2 | Types of exposure or intervention used | Yes
3 | Types of study designs used | Yes
4 | Study population | Yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | No
6 | Effort to include all available studies (contact with authors) | No
7 | Databases and registries searched | Yes
8 | Method of addressing published articles other than English | No
9 | Method of handling abstracts and unpublished studies | No
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Yes
11 | Assessment of confounding | No
12 | Assessment of quality | Yes
13 | Assessment of heterogeneity | Yes
14 | Description of statistical methods sufficient to replicate | Yes
15 | Provision of appropriate tables and graphs | Yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Yes
17 | Tables giving descriptive information of each study included | Yes
18 | Results of sensitivity testing (subgroup analysis) | Yes
19 | Indication of statistical uncertainty of findings | Yes
20 | Quantitative assessment of bias (eg. publication bias) | Yes
| Overall quality | B

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Partially
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | No
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Yes
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Partially
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Partially
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Yes
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Yes
9 | Were conclusions justified by the reported/collected data and analysis? | Yes

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Jones, 1998 [9698133]
Age at Dx of IDDM: ND | Case-control study | Cases: Oxford Record Linkage Study (ORLS) records of hospital admissions for discharge diagnoses coded to diabetes mellitus were searched. Cases were identified as children who were diagnosed with diabetes 1965-1987, and who had been born during 1965-1986 (N=315). 98% of cases born 1970-1986 were matched with 5 or more controls each. | Breastfeeding at discharge | Not breastfeeding at discharge | Relative risk of IDDM | Relative risks were calculated by estimating rate ratios using conditional logistic regression for matched case-control studies. | There was a small, but not significant, raised risk of diabetes with not breastfeeding at discharge (RR=1.33, 95% CI: 0.76–2.31). | A: strong, B: moderate, C: weak | A | B | C
Mean GA (range): ND | | Controls: for cases born 1970-1986, 8 controls from all livebirths in the ORLS areas were randomly selected. Controls were individually matched to cases on sex, year and hospital of delivery, or if domiciliary to another domiciliary delivery. | | | | | | Selection | | | x
Mean BW (range): ND | | Exclusion: children with cystic fibrosis or major congenital anomalies, or who were part of twin or higher order deliveries. | | | | | | Study design | | x
% Male: 53 | | Breastfeeding data were routinely collected only from 1976 so this result is based upon 60 cases and 458 controls born 1976-1986, of which 7 controls had missing data. | | | | | | Confounder | | | x
Race: ND | | | | | | | | Blinding | | x
Enrolled/Evaluate: <76/60 for cases | | | | | | | | Data collection | | | x
Location: UK | | | | | | | | Withdraw and dropout | | | x
Sites: Multi | | | | | | | | Analyses | | | x
Funding: Government | | | | | | | | Intervention integrity | N/A
| | | | | | | | Overall: C
| | | | | | | | Poor adjustments for confounding; Poor definition of BF exposure

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | Bias/limitations Comments
McKinney, 1999 [10372244]
Age at Dx of IDDM: 0–15 | Case-control study | Cases: Incident cases included those diagnosed with type 1 DM over a 2-year period (1993-1994) and taken from the population-based Yorkshire Childhood Diabetes Register (YCDR). The register ascertained children from 3 independent sources and was estimated to be 97% complete. | Mothers were interviewed. Participation rates for the interview study were 93.6% and 81.9% for case and control mothers, respectively. | Initial exclusive breast feeding (no) | OR of IDDM | ORs with 95% CI and p values were calculated using conditional logistic regression with a single term in the model for univariate estimates. Variables significantly associated with disease obtained from the analysis of individual variables were modeled together in a multivariable analysis. | Factors in the model | Cases | Controls | OR (95% CI) | A: strong, B: moderate, C: weak | A | B | C
Mean GA (range): 11% ≤37 wks | | Controls: 2 control subjects per case, matched by sex and age, were randomly selected from the primary care registrations of the Family Health Service Authority (FHSA) of the matched case. | Initial exclusive breast feeding (yes): mothers were asked how the infant was first fed | | | Variables significant at the 5% level in a univariate analysis in our study were mother's age (<25, 25–35, >35), type 1 diabetes mothers, preeclampsia, delivery by cesarean section, neonatal illnesses, and breast feeding. These potential explanatory variables were modeled together in a multivariable analysis. | n | 196 | 325 | | Selection | x
Mean BW (range): 7% <2500g, 58% 2500–3500g; 35% ≥3500g | | Exclusion: 6 cases and 29 control subjects had no matching control subjects or cases and were lost to the matched analysis | | | | | Mother's age | | | | Study design | | x
% Male: 55 | | | | | | | 25–35 years | 123 | 182 | 1.69 (1.11–2.60) | Confounder | | x
Race: 95% White, 3.5% India or Pakistan | | | | | | | >35 years | | | 2.07 (0.97–4.43) | Blinding | | | x
Enrolled/Evaluate: 202/196 for cases 354/325 for controls | | | | | | | Mother with IDDM | 4 | 0 | — | Data collection | | | x
Location: UK | | | | | | | Preeclampsia | 44 | 49 | 1.60 1.01–2.54) | Withdraw and dropout | x
Sites: Single | | | | | | | Cesarean delivery | 34 | 35 | 1.45 (0.82–2.55 | Analyses | x
Funding: Private | | | | | | | Neonatal illnesses ≥1 | 61 | 35 | 1.55 (1.00–2.42) | Intervention integrity | N/A
| | | | | | | Initial exclusive breast feeding | 73 | 151 | 0.60 (0.41–0.89) | Overall: B
| | | | | | | Results show all variables retained their significance in the multivariate model. The addition of neonatal illnesses and breast feeding significantly improved the model fit (likelihood ratio test, chi squared 9.96, P = 0.007). | | | | No adj. for SES
| | | | | | | Note: Crude OR = (73*174)/(151*123)=0.68, p=0.04

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | Bias/limitations Comments
Meloni, 1997 [9051384]
Age at Dx of IDDM: 6 (1–15) yr | Case-control study | Cases: All diabetic subjects followed up at the university hospital who met the inclusion criteria: 1: age < 17 years at diagnosis of IDDM, 2) diagnosis of IDDM was achieved between 1983 and 1994, and 3) patient's mother was currently living, which was considered necessary to obtain accurate infant diet information. According to these criteria, 100 IDDM patients (of the 115 eligible) were included. | Long-term maternal recall of the duration of complete or partial breast-feeding during infant's 1st year of life. | Long-term maternal recall of the age at which dietary products containing cow's milk were introduced into the diet during infant's 1st year of life | Risk of IDDM, compared children who had been breast-fed to those who had not been breast fed | The OR of diabetes according to breast-feeding, the duration of breast-feeding, the age at introduction of dietary products containing cow's milk, and the age at introduction of solid food were estimated by means of conditional logistic regression, where the strata were defined by single year of age at interview and sex. | | IDDM cases | Controls | OR (95% CI) | A: strong, B: moderate, C: weak | A | B | C
Mean GA (range): ND | | Controls: children admitted at the same university hospital, matched each diabetic case for sex and age. None of the control subjects had a family history of IDDM. | | | Risk of IDDM, compared children who had been breast-fed for 1–2 months, 3–5 months, or >6 months to those who had not been breast-fed. | Also included in the models were terms for mother's education and number of siblings. | BF | | | | Selection | | x
Mean BW (range): ND | | | | | | | Yes | 84 | 70 | 1* | Study design | | x
% Male: 53 | | | | | | | No | 16 | 30 | 0.41 (0.19–0.91) | Confounder | | x
Race: ND | | | | | | | Duration of BF (mo) | | | | Blinding | | | x
Enrolled/Evaluate: 115/100 for cases | | | | | | | >6 | 25 | 19 | 1* | Data collection | | x
Location: Italy | | | | | | | 3–5 | 41 | 25 | 1.18 (0.52–2.68) | Withdraw and dropout | | x
Sites: Single | | | | | | | 1–2 | 18 | 26 | 0.48 (0.19–1.24) | Analyses | x
Funding: ND | | | | | | | 0 | 16 | 30 | 0.36 (0.14–0.94) | Intervention integrity | N/A
| | | | | | | Continuous coefficient** | | | 1.10 (0.99–1.22) | Overall: B
| | | | | | | *reference category | | | | Limitations: Long-term maternal recalls. Hospital controls
| | | | | | | **continuous per 1 month increase

Q1: Insulin-Dependent Diabetes Mellitus

Author, Year[UI] | Norris, 1996 [8664407] Type 1 Diabetes Mellitus
Literature search (Dates) | Medline (1966-1994); Other databases searched? (no); unpublished data used? (yes)
Countries where primary studies conducted | Developed countries only: Norway, Denmark, Italy, US, Australia, Canada, Sweden, Finland, British Isles, Ireland, UK
Study eligibility / inclusion criteria | Inclusion: all epidemiologic studies examining infant diet and IDDM risk
| Exclusion: studies with insufficient data for meta-analyses
Study design [No. Of studies] | Case-control studies [17]
No. of subjects | Cases: 4,656 Controls: 16,383
Study population (definition in included studies) | Cases: IDDM patients identified from diabetes clinics, school surveys, registries, physician surveys, or pediatric departments.
| Controls: non-IDDM controls selected from siblings, national population data, friends, classmates, physician referred samples, national population registry, random sample of household, child health system, or schools and day care
Intervention/Exposure (definition in included studies) | A=breastfeeding status (ever/never)
| B=total breastfeeding duration
Comparator (definition in included studies) | C=exposure to breast-milk substitutes
| D=exposure to cow's milk-based substitutes
Outcomes (definition in included studies) | Odds ratios for the risk of IDDM
Heterogeneity assessments | “The addition to the model of a variable for each study in the analyses resulted in an improvement in the overall fit of the model (as determined by the log-likelihood statistic) compared with the model containing only the exposure variable, indicating heterogeneity of effect across studies. We also evaluated study heterogeneity by adding to the model product terms obtained by multiplying the exposure variable by each study variable.”
Quality assessments | Sensitivity analyses on various study characteristics
Publication bias assessments | Including unpublished data
Statistical Analysis or meta-analytic methods | Stratified unconditional logistic regression was used to estimate OR and 95%CI. This method weights each study by its sample size. Variables for the individual studies and for the exposure of interest were included in the model. Both matched and unmatched ORs were used.
Results | - The summary odds ratio (OR) of the 18 studies that examined the association between never being breast-fed and IDDM was 1.13 (95% CI = 1.04–123).; - Meta-analyses of summary ORs were done in the 14 studies that examined IDDM risk by months of breastfeeding duration. The duration categories in the analyses were cumulative, rather than mutually exclusive. The summary OR for IDDM in subjects who were breast-fed for less than 3 months compared with those who were breast-fed for at least 3 months was 1.23 (95%CI = 1.12–1.35).; - When comparing the ORs by whether or not the studies relied on long-term recall to assess infant diet, studies using existing infant records to determine breastfeeding initiation and duration failed to show the associations reported in the studies relying on long-term recall for their exposure data.
Quality of the systematic review | B
Author's interpretations of the results | Our meta-analysis showed that the increased risk of IDDM associated with any of the infant diet exposures is small Interpretation of weak associations (that is, generally an OR<2) can be problematic, since weak associations can more readily be explained by bias.
Comments / Limitations | Very thoughtful analyses but the analysis cannot be replicated due to lack of individual study data.
| Only crude ORs were used in the meta-analyses due to limitation of meta-analytic technique.
| Conclusions were well justified.

| Author, yr: Norris, 1996
| Topic of the systematic review*/MA: Type 1 DM
| | Reporting of Background
1 | Description of study outcomes | yes
2 | Types of exposure or intervention used | yes
3 | Types of study designs used | yes
4 | Study population | yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | no
6 | Effort to include all available studies (contact with authors) | yes
7 | Databases and registries searched | yes
8 | Method of addressing published articles other than English | no
9 | Method of handling abstracts and unpublished studies | yes
| Reporting of Methods
10 | Rationale for selection and/or coding of data | yes
11 | Assessment of confounding | yes/no
12 | Assessment of quality | yes
13 | Assessment of heterogeneity | yes
14 | Description of statistical methods sufficient to replicate | yes
15 | Provision of appropriate tables and graphs | yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | no
17 | Tables giving descriptive information of each study included | yes
18 | Results of sensitivity testing (subgroup analysis) | yes
19 | Indication of statistical uncertainty of findings | yes
20 | Quantitative assessment of bias (eg. publication bias) | yes
| Overall quality | B

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Partially
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | Yes
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Yes
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Partially
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Yes
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Yes
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Yes
9 | Were conclusions justified by the reported/collected data and analysis? | Yes

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | Bias/limitations Comments
Tai, 1998 [9925351]
Age at Dx of IDDM: 8.3±3.3 SD | Case-control study | Cases: From 1984 to 1993, there were a total of 161 registered type 1 diabetes patients who were under the age of 30, born in Taipei City and continuously living in the same city. Among these, 119 (73%) subjects agreed to participate in the study. Their overnight fasting serum C-peptide concentration was < 0. 12 nmol/l and/or an increment in C-peptide from basal value after 1mg glucagons intravenous injection. | In the majority of the study subjects (79% cases and 75% controls), their mothers were interviewed by 2 trained nurses. In the remaining study subjects, the questionnaire interviews were answered by the subjects themselves or by their fathers with the help of their mothers. | Never breast-fed (totally on cow's milk) | OR of developing IDDM | Age and sex were adjusted using logistic regression analysis. The age-sex-adjusted ORs were estimated from the regression coefficient and its S.E. for the risk factor. | I. Age-sex-adjusted ORs of developing IDDM (univariate): | | | | A: strong, B: moderate, C: weak | A | B | C
Mean GA (range): 1% ≤36 wk; 99% >36 wk | | Controls: The control group was selected from normal classmates or colleagues of the type 1 diabetes subjects. They were frequency-mated for age, sex, and parental and individual educational levels. All controls had a plasma glucose concentration, 2 h after 1.75 g/kg glucose loading, <140 mg/dl, fasting C-peptide value >0.16 nmol/l and were negative for islet cell antibody. | Feeding style during infancy: breast-feeding | | | Multiple logistic regression analysis was then carried out by including risk factors which were statistically significant in univariate analyses as well as those reported in other studies in the model. | Risk factors | Cases N | Controls N | OR (95% CI) | Selection | | x
Mean BW (range): 21% <3 kg, 69% 3–3.9 kg; 10% ≥4 kg | | | Duration of breast-feeding: <6, ≥6 months | | | | Feeding style during infancy | | | | Study design | | x
% Male: 37 | | | | | | | Breast-feeding | 46 | 82 | 1.00 | Confounder | x
Race: Asian | | | | | | | Cow's milk | 70 | 109 | 1.43 (0.83–2.47) | Blinding | | | x
Enrolled/Evaluate: 117/117 for cases; 193/193 for controls | | | | | | | Duration of BF (months) | | | | Data collection | | | x
Location: Taipei, R.O.C. | | | | | | | Never | 70 | 109 | 1.00 | Withdraw and dropout | | x
Sites: Single | | | | | | | <6 | 32 | 52 | 0.82 (0.47–1.42) | Analyses | | x
Funding: Government | | | | | | | ≥6 | 10 | 25 | 0.39 (0.16–0.94) | Intervention integrity | N/A
| | | | | | | II. Multiple logistic regression in which the order of pregnancy, paternal age at the conception of the study subjects, gestational age, type of delivery, birth weight, duration of breast-feeding and monthly family income were included in the model. | | | | Overall: B
| | | | | | | Duration of BF (months) | | OR (95% CI) | | Inconsistent methods for BF exposure ascertainments
| | | | | | | Never | | 1.00
| | | | | | | <6 | | 0.84 (0.45–1.59)
| | | | | | | ≥6 | | 0.25 (0.09–0.69)
| | | | | | | The dose-response relationship with type 1 DM for pregnancy order and the reverse pattern for duration of breast-feeding remained statistically significant after adjustment for multiple risk factors.

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | Bias/limitations Comments
Visalli, 2003 [12876166]
Age at Dx of IDDM: ND | Case-control study | Cases: type 1 DM patients selected (330 cases) for this study were diagnosed within the EURODIAS ACE study, and were born between 1977 and 1989. | Questionnaires were distributed to all parents of cases and controls. | Duration of breast feeding < 3 months | OR of IDDM | Conditional logistic regression analysis was performed to adjust the possible confounders (those significant in univariate analyses). | I. Univariate analysis: | | | A: strong, B: moderate, C: weak | A | B | C
Mean GA (range): ND | | Controls: population based control subjects born in the same period were chosen from primary and secondary school enrolment records in the region, and the selection process was designed in collaboration with EURODIAS Substudy 2 group. Out of 1,100 controls replied to the questionnaires, 750 were randomly selected, matching 1 case with 5 controls by age. | Duration of breast feeding ≥ 3 months | End of breast feeding < 3 months | | | Risk factors | OR | 95% CI | Selection | | | x
Mean BW (range): ND | | | End of breast feeding ≥ 3 months | | | | Full term birth | 1.44 | 0.81–2.56 | Study design | | x
% Male: 50 | | | | | | | Duration of BF < 3 mo | 2.12 | 1.38–3.26 | Confounder | | x
Race: ND | | | | | | | Beginning of weaning < 3 mo | 1.81 | 1.06–3.07 | Blinding | | | x
Enrolled/Evaluate: 330/150 for cases; 1200/750 for controls | | | | | | | End of breast feeding < 3 mo | 2.03 | 1.24–3.33 | Data collection | | x
Location: Italy | | | | | | | Cow's milk before 23 mo | 1.49 | 0.72–3.11 | Withdraw and dropout | | | x
Sites: Multi | | | | | | | II. Multivariate logistic regression analysis for risk factors which have been found to be significant | | | Analyses | x
Funding: | | | | | | | Risk factors | OR | 95% CI | Intervention integrity | N/A
| | | | | | | Duration of BF < 3 mo | 1.74 | 1.40–2.45 | Overall: C
| | | | | | | Family history of type 1 DM | 1.17 | 1.05–1.76 | Only 45% of the eligible cases were able to be contacted.
| | | | | | | Presence of infectious disease during mother's pregnancy | 1.60 | 1.32–2.20
| | | | | | | Occurrence of eczema | 1.61 | 1.25–2.66

Infant Type 2 DM

Owen 2006 SRMA*

Taylor 2005 SRMA*

* Systematic Review/Meta-Analysis

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] Topic | Owen, 2006 Type 2 diabetes
Literature search (Dates) | Medline (1966-November 2004); Other databases searched? (yes); unpublished data used? (no)
Countries where primary studies conducted | Developed countries: UK, US, Canada, Dutch
Study eligibility / inclusion criteria | Exclusion criteria: infant feeding status or measures of diabetes were not recorded. Studies did not compare diabetic outcomes among those formula and breastfed. Studies did not provide the odds of type 2 diabetes, mean differences in blood glucose, or differences in plasma insulin between those breastfed and formula fed.
| Note: For the purpose of this review, we only focus on those studies reported OR of type 2 diabetes as an outcomes.
Study design [No. Of studies] | Historical cohort study [3]; Cross-sectional study [2]; Prospective cohort [1]; Case-control study [1]
No. of subjects | Total of 76,744 subjects
Study population (definition in included studies) | 6 studies conducted in adults and 1 conducted in adolescents
Intervention/Exposure (definition in included studies) | Ever breastfed vs. formula fed in all 7 studies.
Comparator (definition in included studies) | Feeding status was reported as being exclusive in one of these studies.
Outcomes (definition in included studies) | OR (95% CI) of type 2 diabetes
Heterogeneity assessments | Chi-squared test.
| Meta-regression and sensitivity analysis were used to examine potential heterogeneity across studies (see Quality assessment)
Quality assessments | The effect of study size, year of birth, the method of ascertainment of infant feeding status (whether contemporary or recalled up to 71 y after birth), type of formula fed, study response rate (analyzed as a continuous variable), study design (randomized controlled trial, case-control, or cohort), and whether infants were born pre- or full-term was examined by using meta-regression and sensitivity analysis.
| Sensitivity analyses were used to examine the effect of adjustment for important confounders and of fasting status.
Publication bias assessments | Funnel plots with Begg and Egger tests
Statistical Analysis or meta-analytic methods | Fixed-effect model.
Results | - Six of the 7 studies related breastfeeding to a lower risk of type 2 diabetes, and there was no evidence of heterogeneity across studies.; - Overall, the subjects who were breastfed showed a lower risk of type 2 diabetes than did those who were formula fed (pooled OR: 0.61; 0.44–0.85; p=0.003).; - Three studies had information on relevant confounders (birthweight, parental diabetes, socioeconomic status, and individual or maternal body size). However the OR relating breastfeeding and diabetes risk was similar before (0.55; 95% CI: 0.35–0.86; p=0.009) and after (0.55, 95% CI 0.34–0.90; p=0.017) adjustment.; - The method for ascertaining feeding exposure was unrelated to the ORs.
Quality of the systematic review | A
Author's interpretations of the results | In the present overview of published studies relating infant feeding and risk of diabetes, the pooled estimate from 6 studies conducted in adults and 1 study conducted in adolescents showed that early breastfeeding was consistently associated with a lower risk of type 2 diabetes in later life compared with those initially formula fed.
| Publication bias is an important potential explanation for the consistent associations observed in these published studies. The results provide no evidence of marked publication bias, although the statistical power of formal tests was limited by the small number of studies available for analysis.
| It is possible that confounding by birthweight and maternal factors could lead to overestimation of the association between breastfeeding and diabetes in later life.
Comments / Limitations | Pooled different study designs

| Author, yr: Owen, 2006
| Topic of the systematic review*/MA: Type 2 DM
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | yes
2 | Types of exposure or intervention used | yes
3 | Types of study designs used | yes
4 | Study population | yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | yes
6 | Effort to include all available studies (contact with authors) | no
7 | Databases and registries searched | yes
8 | Method of addressing published articles other than English | no
9 | Method of handling abstracts and unpublished studies | no
| Reporting of Methods
10 | Rationale for selection and/or coding of data | yes
11 | Assessment of confounding | yes
12 | Assessment of quality | yes
13 | Assessment of heterogeneity | yes
14 | Description of statistical methods sufficient to replicate | yes
15 | Provision of appropriate tables and graphs | yes
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Yes
17 | Tables giving descriptive information of each study included | yes
18 | Results of sensitivity testing (subgroup analysis) | yes
19 | Indication of statistical uncertainty of findings | yes
20 | Quantitative assessment of bias (eg. publication bias) | yes
| Overall quality | A

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Yes
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | Partially
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Yes
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Yes
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Yes
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Yes
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Yes
9 | Were conclusions justified by the reported/collected data and analysis? | Yes

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] Topic | Taylor, 2005 [UI] Type 2 diabetes
Literature search (Dates) | Medline (1966-2003); Other databases searched? (yes); unpublished data used? (no)
Countries where primary studies conducted | Developed countries only: US, Canada, Germany
Study eligibility / inclusion criteria | Search was limited to the English language and to human subjects. All studies involved term singleton infants unless otherwise noted.
Study design [No. Of studies] | Cohort studies [2]; case-control study [1]
No. of subjects | 1,514
Study population (definition in included studies) | - Studies of association between breastfeeding and type 2 diabetes; - Children of mothers with diabetes
Intervention/Exposure (definition in included studies) | Many of the studies that were reviewed only reported breastfeeding versus bottle feeding, without more detailed information on exclusivity, frequency, or duration.
Comparator (definition in included studies) | Information on timing and duration of breastfeeding were included where available.
Outcomes (definition in included studies) | - Impaired glucose tolerance (IGT): fasting glucose < 140 mg/dL and 2-hour glucose > 140 mg/dL (after 1.75 g/kg OGTT); - Type 2 diabetes (NIDDM): 2-hour glucose ≥ 200 mg/dL (after 75 g OGTT) or fasting glucose ≥ 126 mg/dL
Heterogeneity assessments | N/A
Quality assessments | N/A
Publication bias assessments | N/A
Statistical Analysis or meta-analytic methods | N/A
Results | Association between breastfeeding and type 2 DM:; 1. Consistently in 2 studies (1 retrospective cohort; 1 case-control study), exclusive breastfeeding is associated with lower risk of diabetes.
| Children of Mothers with DM:; - One retrospective cohort study found that DM in the next generation was less common among breastfed children than among bottle-fed children, of both mothers with DM and without DM.
Quality of the systematic review | C
Author's interpretations of the results | Based on the literature reviewed, breastfeeding should be strongly encouraged for all women, with or without diabetes.
Comments / Limitations | No synthesis of results or appraisals of study quality. Unclear how the conclusions were reached.

| Author, yr: Taylor, 2005
| Topic of the systematic review*/MA: Type 2 DM
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | yes
2 | Types of exposure or intervention used | yes
3 | Types of study designs used | yes
4 | Study population | yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | yes
6 | Effort to include all available studies (contact with authors) | no
7 | Databases and registries searched | yes
8 | Method of addressing published articles other than English | no
9 | Method of handling abstracts and unpublished studies | no
| Reporting of Methods
10 | Rationale for selection and/or coding of data | yes
11 | Assessment of confounding | partially
12 | Assessment of quality | no
13 | Assessment of heterogeneity | N/A
14 | Description of statistical methods sufficient to replicate | N/A
15 | Provision of appropriate tables and graphs | no
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | no
17 | Tables giving descriptive information of each study included | no
18 | Results of sensitivity testing (subgroup analysis) | N/A
19 | Indication of statistical uncertainty of findings | yes
20 | Quantitative assessment of bias (eg. publication bias) | no
| Overall quality | C

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Partially
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | No
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | No
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Partially
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | No
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Partially
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Unclear (no tables)
9 | Were conclusions justified by the reported/collected data and analysis? | No

## Part II. Preterm Infant Outcomes

Cognitive Premature Infants

Bier 2002

Eidelman 2004

Elgen 2002

Feldman 2003

Horwood 2001

O'Connor 2003

Pinelli 2003

Smith 2003

Vohr 2006

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Bier 2002 [2003020034]
Mean GA (range) breast milk group: 28.6 wk (23–34) | Non-randomized comparison of breast milk versus formula fed preterm infants (convenience sample) | Excluded infants with mothers who used illicit drugs, had mental illness, HIV infection, and others. | | | Bayley MDI at 7-month and at 12-month | Adjusted for maternal result of Peabody Picture Vocabulary Test (PPVT) and days of oxygen | Mean Bayley MDI at 7 month, human milk group = 94 ± 7, in formula group = 90 ± 9 (Difference NS) | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 1174 g (600–1965) | | | | | | | At 12 months, human milk group = 101 ± 11, formula group = 90 ± 9 (P<0.05) | Selection | | | x
% Male: 45% | | | | | | | ANOVA, adjusted for days of oxygen and maternal PPVT, Bayley MDI in human milk vs formula, 100 ± 12 vs 91 ± 10 (R2, P<0.025) | Study design | | | x
Race: | | | | | | | Regression analysis showed an association between the amount of milk infants received in the special care nursery (mL/wk) by gavage and/or bottle and the Bayley MDI at 7 mo (P<0.05) and 12 mo (P<0.025). | Confounder/bias | | x
Enrolled/Evaluate: 29 in human milk group; 10 in formula group | | | | | | | | Blinding | | x
Location: US | | | | | | | | Data collection | | | x
Sites: Multi | | | | | | | | Withdraw and dropout | | | x
Funding: | | | | | | | | Analyses | | | x
| | | | | | | | Intervention integrity
| | | | | | | | Actual number of mothers approached for participation was not accounted for, small sample size, cognitive test at young age, principal investigator was available to all mothers at all times to answer feeding related questions

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Eidelman 2004 [15384601]
Mean GA (range): 30.5 wk (26–33 wk) | Prospective cohort separated into 3 groups based on amount of human milk feeding; Bayley scales assessed at 6 months corrected age | <33 wk gestation; birth weight < 1750 g; exclusion criteria: intraventricular hemorrhage grade 3 or 4, perinatal asphyxia, metabolic or genetic disease | Exact amount of human milk and formula an infant received was recorded after each meal. | | MDI at 6 months corrected age | Number of breastfeeding episodes was used as a covariate; MANCOVA performed with human milk and infant gender as the between subject factors | The number of breastfeeding episodes was <5%. | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 1298 g (640–1720 g) | | | Divided into >75% of nutrition as human milk; 25–75%; and <25% | | | | Univariate analyses showed group differences on the MDI. | Selection | | | x
% Male: 53% | | | | | | | Post hoc comparisons reported significant differences between the substantial milk group and the other two groups: 94.2±8.8 vs 91.7±7.2 vs 90.5±8.5 (P<0.05) | Study design | | | x
Race: | | | | | | | | Confounder | | | x
Evaluated: 86 | | | | | | | | Blinding | | x
Location: Israel | | | | | | | | Data collection | | | x
Sites: Single | | | | | | | | Withdraw and dropout | | | x
Funding: | | | | | | | | Analyses | | | x
| | | | | | | | Intervention integrity
| | | | | | | | Not adjusted for SES, maternal education or intelligence; small sample size;, cognitive testing at young age

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Elgen, 2003 [14580653]
Mean GA (range): | Prospective cohort, followed 'til 11 yr | Born in the county of Hordaland, Norway, between 4/1986 and 8/1988; survived to 11 yr; low birth weight; no cerebral palsy, blindness, deafness, multiple malformations, or chromosomal abnormalities | 27% received <30% human milk in neonatal ward | | Weschler Preschool and Primary Scale of Intelligence- Revised at 5 yr; Weschler Intelligence Scale for Children-Revised at 11 yr | Breast milk, birth weight, paternal and maternal education, chorioamnionitis, gestational age, length of oxygen treatment, sex, Apgar at 5 minutes, smoking during pregnancy, intrapartum stress, cerebral hemorrhage in subjects with birth weight <1500 g | Unadjusted regression: lack of breast milk was associated with a mean reduction in IQ of 5.8 points (95% CI -11 to -1). After adjustment for parental confounding, breast milk was no longer a statistically significant predictor of IQ (paternal education was a significant confounder with breast milk). | A: strong, B: moderate, C: weak | A | B | C
BW (range): <2000 g | | | | | | | | Selection | | x
% Male: | | | | | | | | Study design | | | x
Race: | | | | | | | | Confounder/bias | | x
Evaluate: 130 | | | | | | | | Blinding | | x
Location: Norway | | | | | | | | Data collection | | | x
Sites: Single/Multi | | | | | | | | Withdraw and dropout | | | x
Funding: | | | | | | | | Analyses | | x
| | | | | | | | Intervention integrity
| | | | | | | | Lack of detailed information on breast milk exposure

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Feldman, 2003 [12918090]
Mean GA (range): 30 wk (26–33) | Prospective cohort; consecutive enrollment (6 declined) | <33 wk gestation; <1750 g | >75%, 25–75%, and <25% nutrition from breast milk; exact amount of breast milk and formula the infant received was recorded after each meal by nursing staff | | Bayley MDI at 6 months corrected age | Multivariate ANOCOVA with breast milk and infant gender as the between-subject factors and the number of breast-feeding episodes as the covariate was computed for the cognitive indices at 6 months | An overall main effect for breast milk group was found (F=3.14, P<0.05) | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 1298 (640–1720) | | Excluded infants with congenital malformation, severe hemorrhage; also excluded poverty, single parenting, teenage mothering, and maternal drug use | | | | | Univariate analysis: | Selection | x
% Male: | | | | | | | A (n=34) >75% group MDI 94.16 ± 8.75 | Study design | | | x
Race: | | | | | | | B (n=21) 25–75% 91.66 ± 7.20 | Confounder/bias | | | x
Enrolled/Evaluate: 86 | | | | | | | C (n=31) <25% 90.53 ± 8.54 | Blinding | | | x
Location: Israel | | | | | | | (F=3.34, P<0.05, A>B, C) | Data collection | | x
Sites: Single/Multi | | | | | | | | Withdraw and dropout | | x
Funding: | | | | | | | | Analyses | | | x
| | | | | | | | Intervention integrity
| | | | | | | | Not adjusted for SES, maternal education or intelligence; small sample size; cognitive testing at young age

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Horwood, 2001 [11124919]
Mean GA (range): | Cross-sectional; all 413 very low birth birthweight infants who were live born in 1986 who were admitted to one neonatal unit; retrospective recall of breast milk feeding and duration of feeding; children were assessed by WISC-R (excluded 17 children who could not reliably be assessed because of sensorineural disability; 1 child was excluded because the data on breastfeeding were missing) at 7 yr | Live born very low birthweight infants | Not breastfed (n=76) | | WISC-R | Controlled for perinatal, socio-demographic (family income, single/two parent family, child ethnicity), and maternal factors (age, education, smoking); the data were analyzed using multiple linear regression techniques in which the measures of verbal and performance IQ were regressed on the four level measure of breastfeeding treated as a continuous variable and significant covariate factors. | Children who were breastfed ≥8 months had mean verbal IQ 10.2 (SD 0.56) higher and mean performance IQ 6.2 (SD 0.35) higher than children who did not receive breast milk. | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): | | | Breastfed < 4 months (n=99) | | | | After adjustment for covariates, there remained a significant association between duration of receipt of breast milk and verbal IQ, with a 6 point advantage for infants who received breast milk for ≥8 months compared with no breastfeeding (P<0.001). | Selection | | x
% Male: | | | 4–7 months (n=46) | | | | | Study design | | | x
Race: | | | ≥8 months (n=59) | | | | | Confounder/bias | | x
Evaluated: 298/280 analyzed | | | | | | | | Blinding | | | x
Location: New Zealand | | | | | | | | Data collection | | | x
Sites: Single/Multi | | | | | | | | Withdraw and dropout | | x
Funding: | | | | | | | | Analyses | | x
| | | | | | | | Intervention integrity

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
O'Connor, 2003 [14508214]
GA ): <33 wk | Cohort, re-analysis of a previous RCT on supplemented formulas | Could be enrolled within 72 hours of first enteral feeding initiated by the 28th day of life; excluded congenital abnormalities that could affect growth and development, major surgery, and others | 4 mutually exclusive groups:; 1 predominantly human milk (see details in paper); 2 predominantly formula; 3 ≥ 50% of total energy as human milk; 4 < 50% of total energy as human milk | | Bayley at 12 mo; MacArthur Communicative Development Inventories at 9 mo, 14 mo | Maternal intelligence and home environment | No differences in the Bayley MDI were found among feeding groups. There was a positive association between duration of breastfeeding and the Bayley MDI at 12 months corrected age (P=0.032 in full, and P=0.073 in reduced statistical models) after controlling for home environment and maternal intelligence. | A: strong, B: moderate, C: weak | A | B | C
BW (range): 750–1805 g | | | | | | | | Selection | | | x
% Male: | | | | | | | | Study design | | x
Race: | | | | | | | | Confounder/bias | x
Enrolled/Evaluate: 463 | | | | | | | | Blinding | | | x
Location: US, UK and Chile | | | | | | | | Data collection | | | x
Sites: Multi | | | | | | | | Withdraw and dropout | | | x
Funding: | | | | | | | | Analyses | | x
| | | | | | | | Intervention integrity
| | | | | | | | Cognitive testing at a young age

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Pinelli, 2003 [2003083348]
Mean GA (range): <1500 g | Prospective cohort (consecutive enrollment); sample from a RCT on conventional breastfeeding support versus supplementary structured breastfeeding counseling; 20 totally formula fed infants were recruited as controls | Excluded: multiple births, severe congenital abnormalities; infants of non-English speaking parents | >80% breast milk vs <80% breast milk or no breast milk | | Bayley MDI at 12 mo | Sex, SES, birth weight, maternal age | 64/128 infants received breastmilk exclusively; | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): | | | | | | | Adjusted MDI at 6 mo (corrected age) for >80% breastmilk group: 93 (SD 16); for <80% breastmilk group: 94 (SD 15); | Selection | | x
% Male: | | | | | | | Adjusted MDI at 12 mo (corrected age) for >80% breastmilk group: 92 (SD 15); for <80% breastmilk group: 91 (SD 12); | Study design | | | x
Race: | | | | | | | P>0.05 for all comparisons | Confounder/bias | | x
Enrolled/Evaluate: 148/137 | | | | | | | | Blinding | | | x
Location: Canada | | | | | | | | Data collection | | | x
Sites: Single | | | | | | | | Withdraw and dropout | | x
Funding: | | | | | | | | Analyses | | | x
| | | | | | | | Intervention integrity
| | | | | | | | Cognitive test at a young age

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Smith, 2003 [14630603]
Median GA (range): 27.4 wk | Cohort; subjects were from Developmental Epidemiology Network cohort (n=1442), 439 enrolled in follow up studies at 6 to 8 yr | Surviving children with selected ultrasound abnormalities were included (n=119), and a random sample (1:4 ratio) of infants frequency matched for gestation were included; had undergone neuropsychological assessment and for whom parental questionnaires were complete by 9/2002 | Received expressed milk without progressing to direct breastfeeding, received direct breastfeeding | No human milk | Kaufman Assessment Battery for Children (an estimate for overall intellectual function); Peabody Picture Vocabulary Test and Clinical Evaluation of Language Fundamentals (verbal); California Children's Verbal Learning Test (memory); Wide Range Assessment of Visual Motor Abilities (visual-spatial skill) These measures were standardized with a mean of 100 points and standard deviation of 15 points. | Maternal verbal ability, Home Observation for Measurement of the Environment Inventory, SES, duration of hospitalization | Compared with nonparticipating mothers, those who participated were older, more educated, more likely to be married, be non-smokers, and have private medical insurance. | A: strong, B: moderate, C: weak | A | B | C
Median BW (range): 1014 g | | | | | | | 153 subjects did not receive human milk; 142 received expressed milk without progressing to direct breastfeeding; 125 received direct breastfeeding (the majority of them first received expressed breast milk); 20% of infants received breast milk >6 mo. | Selection | | | x
% Male: | | | | | | | Breast milk feedings were associated with higher unadjusted test scores for each domain of cognitive function except memory. | Study design | | | x
Race: | | | | | | | In the regression model that included social advantage and neonatal morbidity, the adjusted score in overall intellectual function associated with direct breastfeeding was reduced to 3.6 points (95% CI, -0.3, 7.5) from 10.7 (95%CI, 7.0, 14.4). Breastfed children had an advantage in visual-motor integration measure (adjusted IQ 5.1, 95% CI, 1.0, 9.2) | Confounder/bias | x
Enrolled/Evaluate: 439/420 | | | | | | | | Blinding | | | x
Location: US | | | | | | | | Data collection | | x
Sites: Multi | | | | | | | | Withdraw and dropout | | x
Funding: | | | | | | | | Analyses | | x
| | | | | | | | Intervention integrity
| | | | | | | | 27% of subjects with ultrasound abnormalities; the timing of collection of breastfeeding data was not reported

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Vohr, 2006 [16818526]
Mean GA (range): 26.5 wk | Prospective cohort; Bayley results at 18 to 22 mos corrected age; examiner blinded to feeding history, primary caretaker stayed with the child during the Bayley examination | Enrolled prospectively in the Glutamine Trial at 15 sites of Neonatal Research Network; survivors | Breast milk - received some breast milk during hospitalization; total volume received calculated per day, values were interpolated for days of the week in which the data were not collected | | Cognitive outcome of interest: Bayley Mental Development Index (MDI) | Adjustment for marital status, maternal education, age, race/ethnicity, infant's gestational age, gender, culture positive sepsis, grade 3 to 4 intraventricular hemorrhage, oxygen at 36 wks gestational age, necrotizing enterocolitis, and weight <10th %tile | There were 775 infants in the breast milk group and 260 in the no breast milk group. 95 subjects' Bayley could not be administered successfully; these data were not included. Mothers of infants who were seen at followup were more likely to have received prenatal care than mothers of infants who were not seen. There were no differences in infant characteristics. Information on breast milk feeding was not collected after discharge from hospital. 30.6% of infants in the breast milk group were still receiving breast milk. Mothers in the breast milk group were more likely to be white, married, have a college degree and have private health insurance. Mothers who had low household income, higher parity or were black were less likely to provide breast milk feeds. | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 785 g (BM), 794 (no) | | | | | | | Adjusted Bayley MDI 79.9 ± 18 in BM 75.8 ± 16 in noBM P=0.0709 | Selection | | x
% Male: 45% | | | | | | | MDI <85 421 (58.1%) in BM 168 (70.9%) in noBM P=0.0355 | Study design | | | x
Race: | | | | | | | Multiple regression with adjusted factors=0.53 for MDI, P=0.0002 | Confounder/bias | | | x
Enrolled/Evaluate: 1159/1035 | | | | | | | Breast milk intake was analyzed by quintile relative to the no breast milk group; for MDI, there was a 13.1 point difference between ≤20^th^ quintile and >80^th^ quintile (P<0.0044) | Blinding | | x
Location: US | | | | | | | | Data collection | | | x
Sites: Multi | | | | | | | | Withdraw and dropout | | x
Funding: | | | | | | | | Analyses | | | x
| | | | | | | | Intervention integrity
| | | | | | | | Residual confounding from home environment cannot be ruled out; Bayley at young age; proportion of subjects with MDI <85 could not have been adjusted; unclear if income was adjusted or not (Results did not indicate that it was, but the discussion said it was); unclear if Bayley was done blinded to feeding history (not stated in Methods, but the discussion said it was)

Necrotizing Enterocolitis

Furman 2003

Gross 1983

Lucas 1984 1990

McGuire 2001 SRMA*

Ronnestad 2005

Schanler 2005

Tyson 1983

* Systematic Review/Meta-Analysis

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | Bias/limitations Comments
Furman, 2003 [UI# 12517197]
Mean GA (range): 28 wk | Prospective cohort; The study compared the effect of varying dosages of maternal milk on neonatal outcomes | Singleton, birth weight 600–1499 g, gestational age < 33 wk, no positive drug screen, major congenital anomaly, intrauterine infection, or insurmountable maternal social factors | Intravenous dextrose during the first 24 hrs; enteral intake was begun by day 2 or 3 of life, parenteral nutrition was continued until a daily enteral intake of 120 mL/kg of body weight was reached. Infants received their mother's milk in the sequence it was expressed, except that fresh rather than frozen milk was given if available. Maternal milk was fortified, and preterm infant formula was offered when the infant reached a daily oral intake of at least 110 mL/kg. Limited availability of maternal milk was the sole reason infants were fed preterm formula in addition to maternal milk. | | NEC in the 4 subgroups: | Logistic regression; adjusted for birth weight, ethnicity, and sex | 0 maternal milk | 3/40 | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 1056 g | | | | | No maternal milk | | 1–24 mL/kg | 2/29 (OR 1.15 95% CI 0.8–12.13) | Selection
% Male: 57% | | | | | Daily 1–24 mL/kg of maternal milk | | 25–49 mL/kg | 2/18 (OR 1.99 95% CI 0.14–21.03) | Study design | | | x
Race: | | | | | Daily 25–49 mL/kg of maternal milk | | ≥50 mL/kg | 0/32 (OR 0 95% CI 0 – 3.56) | Confounder | | x
Enrolled/Evaluate: 119 | | | | | Daily ≥ 50 mL/kg of maternal milk | | | | Blinding | | | x
Location: Cleveland | | | | | | | | | Data collection | | x
Sites: Single | | | | | | | | | Withdraw and dropout | | x
Funding: | | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity | | | x
Gross, 1983 [UI#:6848932]
Mean GA (range): 31 wk | Random number assignment into 3 groups: mature human milk, preterm human milk, whey-based formula; any infant withdrawn from the study was replaced by the next infant enrolled, until there were 20 infants in each group; remained in the study until they reached 1800 g | 27 – 33 wk gestation; ≤ 1600 g; no congenital abnormalities or major diseases; ability to begin enteral feed by 6^th^ day of life; absence of breast milk from own mother | Feedings began between the first and sixth days of life. | | NEC (abdominal distention, gastric aspirates, guaiac-positive stools, and pneumatosis intestinalis) | NEC was analyzed as infants who withdrew from the study | 67 infants recruited for the study; | | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 1322 g | | | | | | | 1/41 (BM) vs. 3/26 (FM) with NEC | | Selection | x
% Male: | | | | | | | | | Study design | x
Race: | | | | | | | | | Confounder | | | x
Enrolled/Evaluate: | | | | | | | | | Blinding | | x
Location: US | | | | | | | | | Data collection | | x
Sites: Single | | | | | | | | | Withdraw and dropout | | x
Funding: | | | | | | | | | Analyses | | | x
| | | | | | | | | Intervention integrity
Lucas, 1984 [UI# 6476868]; 1990 [UI# 1979363]
Mean GA (range): 31 wk | Randomization within 48 h of birth for infants whose mothers decided not to breastfeed, randomized into banked donor human milk vs. preterm formula; only infants fed exclusively on donor milk or formula were compared | <1850 g, excluded severe congenital abnormalities | | | Confirmed NEC - required surgery or who died | Logistic regression was used to adjust for factors that have been associated with NEC. | 1/86 (BM) vs. 4/76 (FM) | | A: strong, B: moderate, C: weak | A | B | C
Mean BW (SD): 1370 g ( 320 g) | | | | | | | OR 4.7 (0.5 – 43) | | Selection | x
% Male: | | | | | | | | | Study design | x
Race: | | | | | | | | | Confounder | x
Enrolled/Evaluate: | | | | | | | | | Blinding | | x
Location: UK | | | | | | | | | Data collection | x
Sites: /Multi | | | | | | | | | Withdraw and dropout | x
Funding: | | | | | | | | | Analyses | x
| | | | | | | | | Intervention integrity

Evidence table for Systematic Reviews of Breastfeeding and NEC

Author, Year[UI] Topic | McGuire, 2001 [11687169] NEC
Literature search (Dates)1966-10/2003 | Medline; Other databases searched? (yes, CENTRAL, EMBASE, CINAHL); unpublished data used? (no)
Countries where primary studies conducted | ND
Study eligibility / inclusion criteria | RCT comparing feeding with formula milk versus term human milk in low birth weight or preterm infants
Study design [No. Of studies] | RCT: 3 studies with outcomes re: NEC
No. of subjects | 287
Study population (definition in included studies) | Gross 1983 27–33 wk, bw < 1600 g
| Tyson 1983 very low birth weight infants
| Lucas 1984 preterm infants < 1850 g
Intervention/Exposure (definition in included studies) | Gross 1983 unfortified term donor breast milk, fed until 1800 g or until withdrawal secondary to feed intolerance or NEC
| Tyson 1983 pooled banked term human milk, allocation at 10^th^ day of life, fed until 2000 g or until withdrawal secondary to illness requiring parenteral fat or protein
| Lucas 1984 banked term human milk 200 mL/kg/d, fed until 2000 g or until d/c
Comparator (definition in included studies) | Gross 1983 standard calorie (0.67 kcal/mL, protein enriched (1.9 g/100 mL) formula
| Tyson 1983 enriched calorie (0.87 kcal/mL), protein enriched (2.2 g/100 mL) formula
| Lucas 1984 enriched calorie (0.80 kcal/mL), protein enriched (2.0 g/100 mL) formula at 180 mL/kg/d
Outcomes (definition in included studies) | Necrotizing enterocolitis
Heterogeneity assessments
Quality assessments | Gross 1983 & Tyson 1983 The studies did not attempt blinding of parents, carers, or assessors. Adverse events were not reported as primary end points but rather as withdrawal criteria.
| Lucas 1984 The study did not attempt blinding of parents, carers, or assessors. Data on NEC on all 159 recruited infants were reported
Publication bias assessments
Statistical Analysis or meta-analytic methods | 3 trials were combined in a meta-analysis: formula vs human milk, RR: 2.5 (95% CI 0.9, 7.3); RD: 0.05 (95% CI 0.00, 0.1)
Results | Gross 1983 incidence of NEC in formula vs human milk: RR 2.4 (95% CI 0.3, 21.6); RD: 0.07 (95% CI 0.09, 0.22)
| Tyson 1983 incidence of NEC in formula vs human milk: RR 4.2 (95% CI 0.2, 85.3); RD: 0.05 (95% CI -0.03, 0.12)
| Lucas 1984 incidence of NEC in formula vs human milk: RR 2.2 (95% CI 0.6, 8.4); RD: 0.04 (95% CI -0.03, 0.12)
Quality of the systematic review
Author's interpretations of the results | We did not find any statistically significant difference in the risk of NEC with formula milk versus term human milk feeding.
Comments / Limitations | Donor milk, not mother specific milk

Author, yr: McGuire, 2001
Topic of the systematic review*/MA:
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Y
2 | Types of exposure or intervention used | Y
3 | Types of study designs used | Y
4 | Study population | Y
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Y
6 | Effort to include all available studies (contact with authors) | Y
7 | Databases and registries searched | Y
8 | Method of addressing published articles other than English | Y/N
9 | Method of handling abstracts and unpublished studies | N
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Y
11 | Assessment of confounding | Y/N
12 | Assessment of quality | Y
13 | Assessment of heterogeneity | Y
14 | Description of statistical methods sufficient to replicate | Y
15 | Provision of appropriate tables and graphs | Y
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Y
17 | Tables giving descriptive information of each study included | N
18 | Results of sensitivity testing (subgroup analysis) | Y
19 | Indication of statistical uncertainty of findings | Y
20 | Quantitative assessment of bias (eg. publication bias) | N
| Overall quality

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Y
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | Y
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Y
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | Y/N
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Y/N
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Y/N
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Y
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Y
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | Y/N
9 | Were conclusions justified by the reported/collected data and analysis? | Y

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Ronnestad, 2005 [UI# 15687416]
Mean GA (range): 22–27 wk | Prospective cohort | Participating centers had a common policy of achieving full enteral feeding with the mother's milk or banked donor milk as early as possible, although there was no consensus in terms of a detailed protocol for feeding strategies. | Tube feeding with human milk was usually started within a few hours after delivery, with 1 to 2 mL of milk every 2 or 3 hrs, increasing by 0.5 to 1 mL every 6 to 8 hours as tolerated. Enteral nutrition was supplemented with parenteral glucose from day, amino acids and lipids from day 2 and day 3, respectively. | | This was a study primarily examining late-onset septicemia (after day 6 of life) that also reported outcome on NEC after day 6 of life. | No analysis/adjustment specific to NEC was reported. | Enteral feeding with human milk was commenced within 1, 2, or 3 days for 61%, 92%, and 96% of the infants. 9/405 (2.2%) patients had confirmed NEC. | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 845 g (est.) | | All infants born in Norway in 1999 and 2000 with gestational age of <28 wk or birth weight < 1000 g. | | | | | | Selection
% Male: 56% | | | | | | | | Study design | | | x
Race: | | | | | | | | Confounder | | | x
Enrolled/Evaluate: 462 enrolled; 405 survived until day 7 | | | | | | | | Blinding | | | x
Location: Norway | | | | | | | | Data collection
Sites: Multi-center | | | | | | | | Withdraw and dropout | | x
Funding: | | | | | | | | Analyses | | | x
| | | | | | | | Intervention integrity | | | x
Schanler, 2005 [UI# 16061595]
Mean GA (range): 23–26wk & 27–29 wk | RCT | Infants with mother expected to breastfeed; if mother's own milk was unavailable; then infants were randomized to Donor Milk versus Preterm formula | Donor milk (DM) (+ mother's milk partially) | Preterm formula (PF) (+ mother's milk partially) | NEC | 17 infants (21%) in DM were switched to PF because of poor weight gain. All infants remained in the original assigned group for analysis. | Incidence of NEC: | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 952 g | 4 days to 90 days of age or discharge from the hospital | | Reference group: non-randomized, exclusive mother's milk (MM) | | Only cases of NEC that occurred after the infant attained a milk intake of ≥50 mL/kg were analyzed for the primary outcome. | | DM vs PF: 5/78 vs 10/88 (P=0.27) | Selection | | x
% Male: 53% | | | Small quantities of mother's milk (~20 mL/kg/day) was initiated in the first week and continued for ~3 to 5 days before the volume was advanced. Milk intake was increased by ~20 mL/kg daily to 100 mL/kg, at which time milk fortifier was added, this was advanced by ~20 mL/kg daily until 160 mL/kg per day was achieved. | | | | Non-randomized group MM had fewer repeated episodes of late-onset-sepsis and/or NEC (OR 0.18; 95% CI 0.04–0.79) compared with combined groups DM and PF | Study design | x
Race: ND | | | | | | | | Confounder | x
Enrolled/Evaluate: 243 | | | | | | | | Blinding | | x
Location: Texas Children's Hospital | | | | | | | | Data collection
Sites: Multi | | | | | | | | Withdraw and dropout | | x
Funding: government | | | | | | | | Analyses | | x
| | | | | | | | Intervention integrity | | x
Tyson, 1983 [UI# - 6864403]
Mean GA (range): 31.5 wk | RCT; infants were not enrolled until the 10^th^ day; enrolled into donor human milk or formula milk groups | Infants whose mothers continued to provide milk at 10 days were excluded, as infants with any significant illnesses | | | NEC confirmed at surgery; suspected NEC | NEC was analyzed as subjects who dropped out of the study. | 0/37 (BM) vs. 1/44 (FM) for confirmed NEC | A: strong, B: moderate, C: weak | A | B | C
Mean BW (range): 1232 g | | | | | | | | Selection | | | x
% Male: | | | | | | | | Study design | | x
Race: | | | | | | | | Confounder | | | x
Enrolled/Evaluate: | | | | | | | | Blinding | | x
Location: US | | | | | | | | Data collection | | x
Sites: Single | | | | | | | | Withdraw and dropout | | x
Funding: | | | | | | | | Analyses | | | x
| | | | | | | | Intervention integrity

## Part III. Maternal Outcomes

Breast Cancer

Bernier 2000 SRMA*

CGHFBC 2002 SRMA*

Gammon 2002

Jernstrom 2004

Lee 2003

Lipworth 2000 SRMA*

* Systematic Review/Meta-Analysis

Author, Year[UI] Topic | Bernier, 2000 Breast cancer
Literature search (Dates) | Medline (1980-1998); Other databases searched? (yes-Embase); unpublished data used? (no)
Countries where primary studies conducted | Developed and developing countries (Estonia, Canada, USA, Sicilia, Costa Rica, Australia, India, China, Greece, Italy, Mexico, New Zealand)
Study eligibility / inclusion criteria | A study was included in the analysis:; 1 it was published between 1980 and 1998; 2 it presented primary original data;; 3 it was published either in English or French;; 4 the type of study was either a case-control, or a prospective cohort study;; 5 data on breastfeeding exposure were reported and used in the analysis; 6 breast cancer was the event of interest; 7 specific odds ratio measuring the breastfeeding and breast cancer association were given or could be derived.
| Excluded were studies in which data from parous women who had not breastfed could not be separated from nulliparous women
Study design [No. Of studies] | 23 [Case-control studies]
No. of subjects | 25871 cases/44910 controls
Study population (definition in included studies) | Parous women with breast cancer
Intervention/Exposure (definition in included studies) | Breastfeeding (Ever)
Comparator (definition in included studies) | Breastfeeding (never)
Outcomes (definition in included studies) | Breast cancer (histologically diagnosed)
Heterogeneity assessments | Yes; homogeneity graph and by subgroup analysis (menopausal status; duration of breastfeeding)
Quality assessments | Unclear (MA discussed methodologic quality with subheading of origin of the women; breast cancer diagnosis; and data collection)
Publication bias assessments | Yes (funnel plot)
Statistical Analysis or meta-analytic methods | Both random and fixed effects model
Results | Breast cancer risk ever vs never breastfeeding
| Pooled OR using the fixed effects model 0.90 (0.86–0.94)
| Pooled OR using random effects model 0.84 (0.78–0.91
| These results were not modified using adjusted ORs
| Breast cancer risk according to the menopausal status at the time of the diagnosis in ever vs never breastfeeding mothers
| Menopausal at the time of breast cancer diagnosis
| Pooled OR using the fixed effects model 1.01 (0.94–1.09)
| Pooled OR using random effects model 0.84 (0.69–1.03)
| Non-menopausal at the time of breast cancer diagnosis
| Pooled OR using the fixed effects model 0.83 (0.76–0.91)
| Pooled OR using random effects model 0.81 (0.72–0.91)
| Breast cancer risk according to duration of breast feeding
| 0+ to 6 mo v never
| Pooled OR using the fixed effects model 1.02 (0.94–1.10)
| Pooled OR using random effects model 1.00 (0.86–1.16)
| 6+ to 12 mo v never
| Pooled OR using the fixed effects model 0.97 (0.88–1.06)
| Pooled OR using random effects model 0.97 (0.86–1.09)
| 12+ mo vs. never
| Pooled OR using the fixed effects model 0.75 (0.70–0.80)
| Pooled OR using random effects model 0.72 (0.65–0.80)
Quality of the systematic review | B
Author's interpretations of the results | Breastfeeding appeared to be a protective factor but was of small magnitude compared with other known risk factors of breast cancer
Comments / Limitations | Quality score for individual studies not assessed

Author, yr: Bernier 2000
Topic of the systematic review*/MA: Breast cancer and breastfeeding
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Y
2 | Types of exposure or intervention used | Y
3 | Types of study designs used | Y
4 | Study population | Y
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Y
6 | Effort to include all available studies (contact with authors) | N
7 | Databases and registries searched | Y
8 | Method of addressing published articles other than English | N
9 | Method of handling abstracts and unpublished studies | N
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Y
11 | Assessment of confounding | Y
12 | Assessment of quality | Unclear
13 | Assessment of heterogeneity | Y
14 | Description of statistical methods sufficient to replicate | Y
15 | Provision of appropriate tables and graphs | Y
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Y
17 | Tables giving descriptive information of each study included | Partially yes
18 | Results of sensitivity testing (subgroup analysis) | Y
19 | Indication of statistical uncertainty of findings | N
20 | Quantitative assessment of bias (eg. publication bias) | Y
| Authors' Conclusions
21 | Consistent with the presented results | Y
22 | Commenting on the validity of the conclusions | Y
23 | Presenting alternative explanations | Y
| Overall quality | B

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No/Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | Yes
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to studies of interest? | Partially
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | Yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | Partially
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | No
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | Yes
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | Yes
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | Yes
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | No
9 | Were conclusions justified by the reported/collected data and analysis? | Yes

Evidence table for Systematic Reviews of Breastfeeding

Author, Year[UI] Topic | Collaborative Group on Hormonal Factors in Breast Cancer (CGHFBC) 2002 [12133652] Breast Cancer
Literature search (Dates) | ND Available in prior publications
| Medline (nd); Other databases searched? (nd); unpublished data used? (yes)
Countries where primary studies conducted | International studies including developed and developing nations
Study eligibility / inclusion criteria | Studies that had data on at least 100 women with incident invasive breast cancer and had recorded information on each women with respect to reproductive factors and use of hormonal preparations. For the cohort studies, a nested case-control study design was used, in which four randomly selected controls per case were matched for age at diagnosis and where appropriate, broad geographical region
Study design [No. Of studies] | case-control and cohort studies [47]
No. of subjects | 50,302/96,973
Study population (definition in included studies) | Women with breast cancer and controls
Intervention/Exposure (definition in included studies) | Breastfeeding (Ever and lifetime months of breastfeeding (median))
Comparator (definition in included studies) | Breastfeeding Never
Outcomes (definition in included studies) | Breast cancer (ND)
Heterogeneity assessments | Subgroup analyses including women from developed and developing countries, women of different ages, ethnic origins, familial patterns of disease, and 11 other possible relevant factors
Quality assessments | None
Publication bias assessments | ND
Statistical Analysis or meta-analytic methods | Analyses were routinely stratified by study, by center within study, by fine divisions of age, by age at first birth and by menopausal status. Where appropriate, parous women are further stratified by fine divisions of parity.
| Data combined by means of the Mantel-Haenszel stratification technique, the stratum specific quantities calculated being the standard observed minus expected numbers of women with breast cancer, together with their variances and covariates.
Results | % reduction in relative risk of breast cancer per 12 months of breastfeeding and 99% (SE)= 4.3 (0.8)
| Data also available for floating absolute risk and floated SE for subgroups
| Parous women who never breastfed v ever breastfed
| Life time months of breastfeeding
Quality of the systematic review | A
Author's interpretations of the results | The longer women breastfeed the more they are protected against breast cancer. The lack of or short lifetime duration of breastfeeding typical of women in developed countries makes a major contribution to the high incidence of breast cancer in these countries.
Comments / Limitations | Individual patient level data

Author, yr: Collaborative group on Hormonal factors in breast cancer, 2002
Topic of the systematic review*/MA: Breast cancer and breastfeeding
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Y
2 | Types of exposure or intervention used | Y
3 | Types of study designs used | Y
4 | Study population | Y
| Reporting of Search strategy
5 | Search strategy, including time period and key words | N
6 | Effort to include all available studies (contact with authors) | N
7 | Databases and registries searched | N
8 | Method of addressing published articles other than English | N
9 | Method of handling abstracts and unpublished studies | N
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Y
11 | Assessment of confounding | Y
12 | Assessment of quality | N
13 | Assessment of heterogeneity | Y
14 | Description of statistical methods sufficient to replicate | Y
15 | Provision of appropriate tables and graphs | Y
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Y
17 | Tables giving descriptive information of each study included | Y
18 | Results of sensitivity testing (subgroup analysis) | Y
19 | Indication of statistical uncertainty of findings | N
20 | Quantitative assessment of bias (eg. publication bias) | N
| Authors' Conclusions
21 | Consistent with the presented results | Y
22 | Commenting on the validity of the conclusions | Y
23 | Presenting alternative explanations | Y
| Overall quality | A

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No/Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | No
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | yes
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | partially
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Individual patient level data
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | yes
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | yes
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | yes
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | yes
9 | Were conclusions justified by the reported/collected data and analysis? | yes

Study characteristics | Subjects' health conditions | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | Bias/limitations Comments
Gammon 2002 [12206514]
Mean age (range): <35 to 85+ yrs | Women with newly diagnosed breast cancer (invasive and in-situ) | Case control study design | Cases were women newly diagnosed with a first primary in situ or invasive breast cancer between August 1, 1996, and July 31, 1997, confirmed by the physician and the medical record, who were residents of either Nassau or Suffolk counties in New York at the time of their diagnosis, and who spoke English. (Over 97% of all residents in these two counties are English-speaking.) | By duration: | Never lactated | Risk for breast cancer among those who donated a blood sample | Unconditional and multiple logistic regression model identified using backward selection model | Among parous women lactation for 14 or more months decreased the odds of breast cancer (n=102) 0.70 (0.54, 0.92) compared to those who never lactated (ref group) or less than lactated <14 mo | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: mix | | Follow-up duration nd | | <2 months | | | | Lactation <2 mo, 2–5 mo, and 6–13 mo when compared to never lactated group had non significant results for the odds of breast cancer development. | | | | Selection | | | x
Race: white 92–93%; Black 5%; and other 2–3% | | | Controls: Control women were a sample of current residents of Nassau and Suffolk counties who spoke English, who did not have a personal history of breast cancer, and who were frequency matched to the expected distribution of case women by 5-year age group. | 2–5 months | | | | | | | | Study design | | x
Enrolled/Evaluate: 1508 cases/1556 controls | | | | 6–13 months | | | | | | | | Confounder | | | x
Location: population based | | | | 14+ months | | | | | | | | Blinding | | | x
Sites: Multi | | | | | | | | | | | | Data collection | x
Funding: Gov | | | | | | | | | | | | Withdraw and dropout
| | | | | | | | | | | | Analyses | | | x
| | | | | | | | | | | | Intervention integrity | | | x
| | | | | | | | | | | | Overall: C
Jernstrom 2004 [15265971]
Mean age (range): 39 | Women with carriers of gene mutation BRCA1 and BRCA2 | Case-control study design | Selected | For women who gave an approximate length of breastfeeding (e.g., 3–5 months), the midpoint of duration was used. | Exposure information on control subjects (e.g., breast-feeding, parity) was restricted to the period before the date of a diagnosis of breast cancer in the matched case subject. | Breast cancer among BRCA1 and BRCA 2 | Conditional logistic regression for odds ratios (ORs) in the univariate and multivariate analyses. In the first analysis, parity and oral contraceptive use were used as covariate variables. Because of the strong association between parity and breast-feeding, secondary analysis was performed a that excluded all nulliparous women. All analyses were adjusted for oral contraceptive use. | In univariate analyses subjects who had breastfed their kids >1y and had BRCA1 gene polymorphism (OR 0.56; 95% CI 0.41 to 0.76) had statistically significant reduced odds of breast cancer compared to none breastfeeding. Breastfeeding ≤1 yr + BRCA1 (OR 0.89; 95% CI 0.70, 1.15; p<.001) and breastfeeding + BRCA2 were not associated with reduced odds. | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: ND | | Follow-up 8.2 (time between breast cancer diagnosis and the completion of study questionnaire. | Eligible subjects who carried a mutation in either the BRCA1 or the BRCA2 gene were drawn from a database | The year of breast cancer diagnosis and years of all pregnancies were recorded. If both occurred during the same calendar year, it was not possible to establish the sequence of breast cancer and pregnancy. Only live births that occurred at least one calendar year before a diagnosis of breast cancer were captured. Twin births were considered to be one birth with respect to breast-feeding. | | | | In multivariate subjects who had breastfed their kids >1y and had BRCA1 gene polymorphism (OR 0.55; 95% CI 0.38 to 0.80) had statistically significant reduced odds of breast cancer compared to none breastfeeding. | | | | Selection | x
Race: Jewish 30% cases | | | | | | | | The trend per month of breast feeding also decreased the odds of breast cancer | | | | Study design | | x
French Canadian 10% | | | | | | | | | | | | Confounder | x
Other white 59% | | | | | | | | | | | | Blinding
Black1% | | | | | | | | | | | | Data collection | | x
Other 0.5% | | | | | | | | | | | | Withdraw and dropout | | x
Enrolled/Evaluate: 1927/1830 | | | | | | | | | | | | Analyses | | x
Location: hospital based | | | | | | | | | | | | Intervention integrity | | x
Sites: Multi | | | | | | | | | | | | Overall grade: B
Funding: ND
Lee SY, 2003 [12704674]
Mean age (range): 33–44 | Earlier menarche | Prospective observational cohort | Premenopausal women who were enrolled in the Korean Medical Insurance Corporation (KMIC) and participated in the Korean Women's cohort | Ever vs Never | Ever vs Never | Incident breast cancers | In bivariate analyses, the authors examined the relation between lactation and traditional breast cancer risk factors, adjusting for age. In these bivariate analyses, the authors tested for trends across categories of duration of lactation, using parous women who never breastfed as the reference. In Cox proportional hazard models, age, age at menarche, number of children, age at first pregnancy, oral contraceptives, smoking, exercise and obesity were controlled to delineate the independent effects of lifetime lactation. In all analyses, a 2-sided alpha level of 0.05 was considered statistically significant. | Compared to parous women who had no history of lactation, periods of lactation of 1–12 months or 13–24 months were associated with decreased risk of breast cancer (RR, 0.8; 95% CI, 0.7–1.0 or RR, 0.7; 95% CI, 0.5–1.1, respectively), and this risk decreased even further for those with who breastfed for more than 24 months (RR, 0.6; 95% CI, 0.3–1.0) | | | | A: strong, B: moderate C: weak | A | B | C
Menopause: Pre | Oral contraceptive use | Follow-up 6 yrs | | Periods of lactation | Periods of lactation | | | | | | | Selection | | x
Race: Asian 100% | Ever smoke | | | 1–12 months | 1–12 months | | | | Person-years | Breast cancer | Multivariate model | Study design | x
Enrolled/Evaluate: 110604 | Alcohol use | | | 13–24 months | 13–24 months | | | | | | RR | Confounder | x
Location: population based | Exercise (yes) | | | | | | | | | | (95%CI) | Blinding | | | x
Sites: Multi | [data available by duration of lactation] | | | | | | | Never | 263,472 | 161 | Ref | Data collection | | | x
Funding: Gov | | | | | | | | 1–12 | 256,199 | 149 | 0.8 | Withdraw and dropout | | x
| | | | | | | | | | | (0.7–1.0) | Analyses | | x
| | | | | | | | | | | NS | Intervention integrity | | x
| | | | | | | | 13–24 | 39,125 | 32 | 0.7 | Overall: B
| | | | | | | | | | | (0.5–1.1)
| | | | | | | | | | | NS
| | | | | | | | >24 | 23,556 | 18 | 0.6
| | | | | | | | | | | (0.3–1.0)
| | | | | | | | | | | p = 0.0438
| | | | | | | | p for trend | | | <0.001

Author, Year[UI] Topic | Lipworth, 2000 [10675379] Breast Cancer
Literature search (Dates) | Medline (1966-1998); Other databases searched? (no); unpublished data used? (no)
Countries where primary studies conducted | International studies including developed and developing nations
Study eligibility / inclusion criteria | Studies that included more than 200 cases overall and explicitly controlled for number of full-term pregnancies and age at first birth
Study design [No. Of studies] | Case-control studies
No. of subjects | 23461/52948
Study population (definition in included studies) | Premenopausal women with breast cancer and controls (nd)
Intervention/Exposure (definition in included studies) | Breastfeeding (ever)
Comparator (definition in included studies) | Breastfeeding (never)
Outcomes (definition in included studies) | Breast cancer (nd)
Heterogeneity assessments | None
Quality assessments | ND
Publication bias assessments | ND
Statistical Analysis or meta-analytic methods | No meta-analysis; only qualitative review
Results | “Ever” breastfeeding effect remains inconclusive with results indicating either no association or a weak protective effect against breast cancer. Few studies also reported an inverse association between increasing life-time breastfeeding and breast cancer risk in parous women.
Quality of the systematic review | B
Author's interpretations of the results | “Evidence supporting protective factor of breastfeeding for breast cancer is limited and should be interpreted with caution.”
Comments / Limitations

Author, yr: Lipworth, 2000 [10675379]
Topic of the systematic review*/MA: Breast Cancer
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes | Yes
2 | Types of exposure or intervention used | Yes
3 | Types of study designs used | Yes
4 | Study population | Yes
| Reporting of Search strategy
5 | Search strategy, including time period and key words | Yes
6 | Effort to include all available studies (contact with authors) | Partially
7 | Databases and registries searched | Partially
8 | Method of addressing published articles other than English | No
9 | Method of handling abstracts and unpublished studies | No
| Reporting of Methods
10 | Rationale for selection and/or coding of data | Yes
11 | Assessment of confounding | Yes
12 | Assessment of quality | No
13 | Assessment of heterogeneity | Yes
14 | Description of statistical methods sufficient to replicate | Not applicable
15 | Provision of appropriate tables and graphs | Partially
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall | Not applicable
17 | Tables giving descriptive information of each study included | Yes
18 | Results of sensitivity testing (subgroup analysis) | Not applicable
19 | Indication of statistical uncertainty of findings | Not applicable
20 | Quantitative assessment of bias (eg. publication bias) | Not applicable
| Overall quality | B

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)? | yes
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest? | no
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined? | yes
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)? | nd
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed? | Partially
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders? | yes
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate? | no
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)? | no
8 | Were results reported accurately (eg, no discrepancies between text and tables)? | no
9 | Were conclusions justified by the reported/collected data and analysis? | yes

Osteoporosis-BMD

Hansen 1991

Matsushita 2002

Sowers 1992

Uusi-Rasi 2002

Osteoporosis-Fracture

Alderman 1986

Chan 1996

Cumming 1993

Hoffman 1993

Kreiger 1982

Michaelsson 2001

Study characteristics | Subjects' health conditions | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | Bias/limitations Comments
Hansen, 1991 [UI#1790399]
Mean age (range): 51 | healthy | Prospective cohort (12 years) | In 1979, 178 women completed a 2-year, prospective study receiving placebo. They had been selected by questionnaire and a medical screening examination. All had passed a natural menopause 6 months to 3 years earlier and were free of disease or medications known to influence the calcium metabolism. | 111 women (92%) had experienced 1 or more pregnancies (mean: 2.6); 87% breast fed for a mean total lactation period of 13 months | No lactation | Lumbar spine BMD, measured by DEXA. BMD is calculated as BMC divided by the area of interest from L2 to L4 including the intervertebral discs. BMD only measured in the follow-up. | Student's t test for unpaired data | | ΔBMCarm% per year | ΔBMDspine | A: strong, B: moderate, C: weak | A | B | C
Menopause: post | | | In 1989, 12 years after the start of the original study, all 178 women were re-contacted for a follow-up examination. Of these, 24 (13%) were unable to participate: 6 women had died, 9 suffered from diseases which made participation impossible, 6 unwilling to participate for personal reasons, 2 had emigrated, and 1 could not be located. Among the 154 women underwent the follow-up examination, 24 women were excluded due to owing to post-trial treatment with sex hormones for more than 1 year and another 9 women presenting with disease known to influence calcium metabolism were excluded as well. | | | Forearm BMC was measured by single photon absorptiometry (125I). The rate of postmenopausal bone loss (% per year) was determined as the difference in % between the measurement in 1979 and the measurement obtained in 1989 divided by 10 years. | | Lactation (-) | -1.8±0.8 | 0.84±0.18 | Selection | | | x
Race: ND | | | | | | | | Lactation (+) | -1.7±0.8 | 0.88±0.14 | Study design | | x
Enrolled/Evaluate: 178/121 | | | | | | | | p-value | NS | NS | Confounder | | | x
Location: Denmark | | | | | | | | | | | Blinding | | x
Sites: Single | | | | | | | | | | | Data collection | | x
Funding: | | | | | | | | | | | Withdraw and dropout | | | x
| | | | | | | | | | | Analyses | | | x
| | | | | | | | | | | Intervention integrity
| | | | | | | | | | | Overall: C
| | | | | | | | | | | Univariate analyses for BMD/BMC outcomes and lactation. Unclear whether no lactation group including non-parous women

Study characteristics | Subjects' health conditions | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | | | Bias/limitations Comments
Matsushita, 2001 [UI#12200655]
Mean age (range): 30.1 | Healthy, well-nourished | Longitudinal cohort study | Postpartum Japanese women, aged 20–40 years, who delivered a singleton infant at the university hospital between 1994 and 1999. Women who had 2nd pregnancy were included. | Lactation information including length and source of lactation (breast-fed or formula-fed) was collected by questionnaire immediately after the subsequent delivery. | | BMD of the lumbar spine (L2–L4) was measured by DEXA within 7 days of delivery. 113 of women became pregnant again and they had 2nd BMD measurement within 7 days of the next delivery. | BMD and backgrounds of consecutive pregnancies were compared using a paired t-test. | Lumbar BMD of 110 women after the initial and the subsequent delivery was 1.006±0.117 and 1.019±0.115 g/cm^2^, respectively. BMD after the subsequent delivery was significantly higher than that after the initial delivery (p=0.001), with a ΔBMD% of 1.4±4.2%. | | | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: pre | | Mean interval between each delivery = 2.5 years | Exclusion criteria included complications and medications before or during pregnancy, that would affect bone metabolism, delivery before 36 weeks' gestation, or bed rest in excess of 7 days. | Only 1 woman had formula-fed, and the other breast fed with (n=46) or without (n=66) formula fed. | | The percent change in BMD (ΔBMD%) was calculated by subtracting the value at the time of the first pregnancy from the value at the time of the second pregnancy. | Multiple regression analysis was performed to look for independent predictors of ΔBMD%. BMD after the initial delivery was included as an independent variable to adjust for regression toward the mean. | Independent determinants of ΔBMD% were explored by multiple regression analysis: the length of lactation between the scans showed no correlation with ΔBMD% (coefficient=-0.06±0.157 SEM, p=0.702). Age was the most significant predictor for ΔBMD% in the model. | | | | | | Selection | x
Race: Asian (assumed) | | | | Whether breast-feeding had been exclusive, predominant, or on-demand, and when alternative food had been introduced, was not available because of ambiguous memory. | | | | | | | | | | Study design | x
Enrolled/Evaluate: 113/113 | | | | | | | | | | | | | | Confounder | x
Location: Japan | | | | | | | | | | | | | | Blinding | | x
Sites: Single | | | | | | | | | | | | | | Data collection | x
Funding: ND | | | | | | | | | | | | | | Withdraw and dropout | x
| | | | | | | | | | | | | | Analyses | | x
| | | | | | | | | | | | | | Intervention integrity
| | | | | | | | | | | | | | Overall: A
Sowers, 1992 [UI#4543]
Mean age (range): | ND | Prospective cohort (5 year) | In 1984, BMD of women In aged 22–54 years living in a single rural community were measured by single-photon densitometry. | Subjects were interviewed at baseline and follow-up for various factors, including lactation. | | BMD was expressed as the bone mineral to bone width ratio. | Multiple-variable regression analyses were used to assess relationships between BMD change or baseline BMD values and the explanatory variables adjusting for age and estrogen status. | Nulliparous women (n=12) had significantly lower BMD at baseline and follow-up than parous women (n=169) before and after adjusting for age and estrogen status. | | | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: mix | | | The community was selected for study because of the mineral characteristics of the community water supply. | | | Percent change was calculated as 100% - follow-up value/baseline value | Stepwise regression was used to generate models considering all other important variables, including age, estrogen status, parity, age at first pregnancy, and weight. | A recalled history of breast-feeding in parous women did not predict significant differences in BMD level or amount of BMD change. We had insufficient sample size to test whether duration of breast-feeding in excess of 6 months for a single infant or 6 months cumulative time from breast-feeding multiple infants was associated with significant differences in BMD. | | | | | | Selection | | X
Race: European | | | Women were eligible to participate in the baseline study if they had lived in the community the previous 5 years, were able to complete face-to-face interview, were ambulatory and reported themselves to be of northern European heritage. | | | | | | | | | | | Study design | | X
Enrolled/Evaluate: 217/181 | | | In 1989, a follow-up survey reexamined 181 of the 217 women who participated in the baseline survey. Nonrespondents to the follow-up survey were less likely to be married, were younger, had a greater Quetelet index, and had a slightly greater BMD than participants at baseline | | | | | | | | | | | Confounder | | X
Location: US | | | | | | | | | | | | | | Blinding | | X
Sites: Single | | | | | | | | | | | | | | Data collection | | X
Funding: Government | | | | | | | | | | | | | | Withdraw and dropout | | | X
| | | | | | | | | | | | | | Analyses | | X
| | | | | | | | | | | | | | Intervention integrity
| | | | | | | | | | | | | | Overall: B
Uusi-Rasi, 2002 [UI#11991440]
Mean age (range): 28.4 | healthy | Prospective cohort | Healthy, non-smoking women willing to participate in original cross-sectional study. Inclusion criteria were a daily dietary calcium intake of over 1200 mg (Ca+) or under 800 mg (Ca-) and vigorous physical activity more than twice a week, or light to moderate activity no more than once a week. Women who had intermediate levels of physical activity or calcium intake or used calcium supplements were excluded. | Total duration of breastfeeding (one long period or sum of many periods of breastfeeding | | BMC at the proximal femoral neck and total trochanter region and the distal radius of the dominant side was measured with dual energy X-ray absorptiometry. | Repeated-measures analyses of variance were used to analyze the between group differences in changes in site-specific BMC. | The mean decrease in BMC (95% CI) was 1.5% (0.7% to 2.4%) for the femoral neck, 0.6% (-0.8% to 1.9%) for the trochanter and 6.0% (4.5% to 7.4%) for the distal radius during the follow-up | | | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: pre | | 4.2 (range 3.2–5.4) years | Altogether 92 women out of the 132 original 25- to 30-year-old subjects participated in the follow-up measurements. | | | | Regression models for % bone loss using a multivariate stepwise regression analysis that included baseline variables: age, body weight, muscle strength, estimated maximal oxygen uptake and calcium intake, the absolute changes in body weight, muscle strength, estimated maximal oxygen uptake, calcium intake, physical activity, duration of breastfeeding and time from weaning. | According to the multiple stepwise regression analyses, the statistically significant independent predictors for site-specific bone loss were low calcium intake at the baseline and change in body weight both at the proximal femur and at the distal radius. High calcium intake, as well as an increase in body weight, were associated with less bone loss at all the measured bone site. | | | | | | Selection | | x
Race: ND | | | | | | | | In addition, breastfeeding was associated with radial bone loss; the longer the duration of breastfeeding the greater the bone loss (Multiple regression coefficient= -0.34 +- 0.14 SE, p=0.015). Breastfeeding was not associated with femoral neck or trochanter BMC loss | | | | | | Study design | | x
Enrolled/Evaluate: 132/92 | | | | | | | | | | | | | | Confounder | | | x
Location: Finland | | | | | | | | | | | | | | Blinding | | x
Sites: Single/Multi | | | | | | | | | | | | | | Data collection | | x
Funding: private | | | | | | | | | | | | | | Withdraw and dropout | | | x
| | | | | | | | | | | | | | Analyses | | x
| | | | | | | | | | | | | | Intervention integrity
| | | | | | | | | | | | | | Overall: B
Alderman, 1986 [UI#3728442]
Mean age (range): 50–74 | ND | Case-control study | Cases: Between 1976 and 1980, all women with hip fracture who sought care from a 62% sample of orthopedic surgeons were eligible. Women with forearm fracture who sought care from these orthopedists were eligible if the physician's practice had records that allowed tracing of all outpatients. Women who sought care for vertebral fractures were not eligible because we believed that they represented a small and probably unrepresentative group of women with vertebral fracture. Exclusion: nonwhite, younger than 50 or older than 74 years of age, nonresidents of King County, residents of institutions at the time of fracture, or if they had multiple or pathologic fractures. | The duration of lactation was calculated by summing the number of months of lactation associated with each birth, and was treated in separate analyses as a categorical variable (taking values 0, 1 to 12, 13 to 24 and more than 24 months) and as continuous variable (taking values from 0 to 109 months) | 253/562 control women missing data on lactation | Risk of hip or forearm fractures | Logistic regression was used. The logistic model was evaluated for confounding by forward selection method. Only parity and variables with independent confounding effects were included in the final model. The same procedure was repeated to examine the association between fracture and duration of lactation. | Logistic regression analysis did not reveal a substantial change in risk of fracture with increasing duration of lactation when lactation was treated as a categorical variable. Adjustment for confounding effects of age, relative weight, and duration of estrogen use did not alter these results. | | | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: post (assumed) | | | Controls: unmatched control women were identified through 3 door-to-door area-based surveys of the general population of King Country conducted in 1976, 1977, and 1979. Comparable exclusion criteria were used. | 11/355 cases missing data on lactation | | | | Similar results were obtained when lactation was treated as a continuous variable. Separate analysis of women with hip fracture suggested that an increase in months of breastfeeding was associated with an irregular decreased in risk of fracture. | | | | | | Selection | | x
Race: White | | | | | | | | | | | | | | Study design | | x
Enrolled/Evaluate: 355/344 for cases; 562/318 for controls | | | | | | | | | | | | | | Confounder | | x
Location: US | | | | | | | | | | | | | | Blinding | | | x
Sites: Multi | | | | | | | | | | | | | | Data collection | | | x
Funding: Government | | | | | | | | | | | | | | Withdraw and dropout | | x
| | | | | | | | | | | | | | Analyses | | x
| | | | | | | | | | | | | | Intervention integrity
| | | | | | | | | | | | | | Overall: B
Chan, 1996 [UI#8783297]
Mean age (range): 75 (70–79) | ND | Case-control study | Chinese women aged 70–79 years who were living in Geriatric Housing Scheme in Hong Kong. | Home-visit interviews by a standardized, structured questionnaire was administered by 2 trained research nurses who was blinded to the fracture status. | Period of lactation: never | Diagnosis of vertebral fracture according to Black et al.: definite vertebral fracture: when any of the 3 vertebral ratios was 3 SD or more away from the mean; doubtful fracture: any of the 3 vertebral ratios was 2–2.99 SD away from the mean. | Logistic regression: OR for vertebra fracture among definite case and control; doubtful cases and controls. | There were no significant differences in the age of menarche and menopause between definite cases, doubtful cases, and controls. The risk of definite fracture decreased with the number of children given birth to and the duration of breastfeeding. | | | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: post | | | Subjects with a known history of metabolic bone disorder, cancer, or who were on long-term steroid treatment, were excluded. No subjects with such histories but 3 subjects on steroid therapy were excluded from the study. | Period of lactation: less than 24 months, or 24 months or more | | A woman with 1 or more definite fractures was classified as a definite case, a woman with no definite fractures but one or more doubtful fractures as a doubtful case, and the rest as controls. | Analysis adjusted for age. | Period of lactation | % in definite cases (n=144) | % in doubtful cases (n=174) | % in controls (n=163) | Age-adj OR (95% CI) | | Selection | | X
Race: Chinese | | | Cases: definite or doubtful vertebral fracture | | | | | | | | | Definite cases & control | Doubtful cases & control | Study design | | X
Enrolled/Evaluate: 481/481 | | | Control: the remaining enrolled subjects (women with no fractures) | | | | | Never | 63 | 45 | 53 | 1.0 | 1.0 | Confounder | | | X
Location: Hong Kong | | | | | | | | <24 mo | 18 | 22 | 20 | 0.7 (0.4–1.3) | 1.3 (0.7–2.2) | Blinding | X
Sites: Single | | | | | | | | ≥24 mo | 19 | 33 | 27 | 0.6 (0.3–1.0 | 1.5 (0.9–2.4 | Data collection | | X
Funding: Government | | | | | | | | | | | | | | Withdraw and dropout | | X
| | | | | | | | | | | | | | Analyses | | X
| | | | | | | | | | | | | | Intervention integrity | N/A
| | | | | | | | | | | | | | Overall: C
| | | | | | | | | | | | | | Did not separate parous women.
Cumming, 1993 [UI#8225744]
Mean age (range): 65–100 | Self-reported heath (for directly interviewed subjects only: 104 cases and 114 controls) | Population-based case-control study | All people aged ≥65 living in a postcode-defined area in Sydney between 3/1990 and 8/1991. Total of 11 hospitals were included in the study. | For all women: | For all women: | Risk of hip fracture | Data analysis: crude, stratified and multivariate methods to produce OR for associations between hip fracture and exposure variables. Age is the strongest predictor of hip fracture and so all results were adjusted for age. | There were 311 women in this study: 174 cases and 137 controls. The response rate was 96% for cases and 82% for controls. Proxy interviews were required for 93 subjects. Most cases (78%) were recruited from 1 teaching hospital. A history of use of HRT was more common among controls than among cases (age-adj OR: 0.55, 95%CI 0.24–1.27). | | | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: post | Cases: 23% excellent, 50% good, 20% fair; 6% poor | | Cases: People with hip fractures presenting to the hospitals. The case ascertainment varied across hospitals. | Ever breastfeeding | Never breastfeeding | | Multiple logistic regressions were controlling for several confounding variables. Selection of confounders for inclusion in these models was based a priori knowledge of risk factors for hip fracture and the strength of univariate associations between exposure variables and hip fracture. Confounders (other than age) were entered into models as categorical variables. | | Age- and proxy-adjusted | | | Multivariate-adjusted | | Selection | | X
Race: D | Controls: 26% excellent, 51% good, 21% fair; 5% poor | | Controls: People living in private homes in the community and from people living in nursing homes and hostels. The controls comprised a probability sample of people aged ≥65 years living in the 11 postcodes of the study base during the same time period as the cases. | For parous women only: | | | | | Cases | Ctrl | OR (95%CI) | No. subjects in the model | OR (95%CI) | Study design | | X
Enrolled/Evaluate: | | | Proxy respondents were used for elderly people with cognitive impairment and those with various other health problems. A shortened questionnaire was used to interview proxy respondents. | Average duration of breastfeeding per child (months) | | | | All women | | | | | | Confounder | | X
Location: Australia | | | | | | | | BF- | | | | N=176 | | Blinding | | | X
Sites: Multi | | | | | | | | Never | 60 | 42 | 1.00 | | 1.00 | Data collection | | X
Funding: ND | | | | | | | | Ever | 106 | 95 | 0.72 (0.43–1.20) | | 0.64 (0.30–1.38) | Withdraw and dropout | | | X
| | | | | | | | Parous women | | | | | | Analyses | | X
| | | | | | | | BF- | | | | N=140 | | Intervention integrity | N/A
| | | | | | | | Never | 25 | 12 | 1.00 | | 1.00 | Overall: B
| | | | | | | | Ever | 106 | 95 | 0.47 (0.22–0.99) | | 0.55 (0.10–2.90) | Missing data for covariates in the multivariate model, so the number of subjects in the model is limited.
| | | | | | | | Average duration of BF per child (mo) | | | | N=136
| | | | | | | | 0 | 19 | 11 | 1.00 | | 1.00
| | | | | | | | 0.5–3 | 17 | 16 | 0.56 (0.19–1.68) | | 0.64 (0.13–3.06)
| | | | | | | | 3–6 | 17 | 24 | 0.41 (0.15–1.13) | | 0.79 (0.18–3.51)
| | | | | | | | 6–9 | 18 | 23 | 0.47 (0.19–1.19) | | 0.41 (0.09–1.82)
| | | | | | | | >9 | 7 | 10 | 0.28 (0.07–1.18) | | 0.24 (0.04–1.53)
| | | | | | | | For women who had one or two children, breastfeeding markedly reduce the risk of hip fracture in later life. After adjusting for age and number of children, the OR in parous women for breastfeeding all children versus breastfeeding none was 0.26 (95%CI 0.10–0.69)
Hoffman, 1993 [UI#8338971]
Mean age (range): 50–103 | Hospital cases and controls | Case-control study | Cases: a sample of radiologically confirmed cases of first hip fracture among white women aged 45 years and older was drawn from among admissions to one of 30 hospitals between 9/1987 and 7/1989 | Ever lactated | Never lactated | Risk of hip fracture | Conditional logistic regression models were used to remove the effect of matching cases and controls. Because the age intervals were wide, age was controlled for as continuous variable. | Lactation was associated with reduced odds of hip fracture among all women (OR=0.66 [0.41–1.05]) | | | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: post | | | Controls: white hospital controls, frequency-matched to cases by 10-year age group and by hospital of admission during the same time period. | Lactated ≤ 12 mo | | | Variables that changed crude estimates by 10% or greater were retained as confounding variables. For lactation, only the number of live births was retained. | Restricting the analysis to parous women and controlling for number of live births, there was no association between ever having lactated or duration of lactation and hip fracture (OR for lactation of 12 months or less=0.80 [0.42–1.55]); OR for lactation of more than 12 months=1.08 [0.45–2.60]) | | | | | | Selection | | | X
Race: White | | | Exclude subjects with a prior hip fracture, pathological fracture secondary to cancer, evidence of bony metastases, severe cognitive, language, or hearing impairment, died in the hospital shortly after surgery, or medically unstable | Lactated > 12 mo | | | | Duration of lactation did not confound the negative association between parity and hip fracture. | | | | | | Study design | | X
Enrolled/Evaluate: 286/174 cases; 311/174 controls | | | | | | | | | | | | | | Confounder | | X
Location: USA | | | | | | | | | | | | | | Blinding | | | X
Sites: Multi | | | | | | | | | | | | | | Data collection | | X
Funding: ND | | | | | | | | | | | | | | Withdraw and dropout | | | X
| | | | | | | | | | | | | | Analyses | | X
| | | | | | | | | | | | | | Intervention integrity
| | | | | | | | | | | | | | Overall: B
Kreiger, 1982 [UI#7102649]
Mean age (range): 45–74 | Hospital cases and controls | Case-control study | Women aged 45–74 years admitted to surgical services of 4 Connecticut hospitals between 9/1977 and 5/1979. | 98 of 149 cases (66%) of hip fracture and 884 of 1345 controls (66%) were interviewed. | Before the data analysis began, the controls were divided into 2 groups: trauma control group and nontrauma control. | Odds ratio of hip fracture, compared cases to trauma or nontrauma controls. | Linear logistic regression, adjusted for age and for Quetelet index (similar to BMI), bilateral ovariectomy, and estrogen replacement therapy. | Linear logistic regression, adjusted for age and for Quetelet index (0.01 increase), bilateral ovariectomy (yes/no), and estrogen replacement therapy (60-month increase): | | | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: post | | | Cases: women admitted to 1 of the 4 study hospitals with a first diagnosis of hip fracture, either intra- or extra- capsular, confirmed by x-ray. | Variable: Breastfeeding 12-month increase | | | | Variable | | Unit | | Cases and trauma control | Cases and non-trauma control | Selection | | x
Race: ND | | | Controls: systematic sample of women admitted to the inpatient surgical services of the 3 largest hospitals. Controls included had a wide variety of diagnoses, and no more than 5% of the controls were in any single diagnostic category. | | | | | | | | | Adj OR | Adj OR | Study design | | x
Enrolled/Evaluate: 149/98 for cases; 1345/884 | | | Exclusion: women with reproductive cancers, who did not speak English, who lived outside of Connecticut, or last menstrual period was within 1 year of hospital admission or if the admitting diagnosis of a disease related to estrogen use. | | | | | | | | | (95% CI) | (95% CI) | Confounder | | x
Location: US | | | | | | | | Breastfeeding | | 12-month increase | | 0.5 | 0.6 | Blinding | | | x
Sites: Multi | | | | | | | | | | | | (0.2, 0.9) | (0.3, 1.0) | Data collection | | | x
Funding: ND | | | | | | | | | | | | | | Withdraw and dropout | | | x
| | | | | | | | | | | | | | Analyses | | | x
| | | | | | | | | | | | | | Intervention integrity
| | | | | | | | | | | | | | Overall: C
| | | | | | | | | | | | | | Sample size in breastfeeding analysis was not described. Did not separate out parous women.
Michaelsson, 2001 [UI#2001082617]
Mean age (range): Cases=72.5; Controls=70.5 | ND | Case-control study; a comprehensive questionnaire at a mean interval of 95 days after the fracture; associations between lactation and hip fracture were only analyzed for parous women | Cases: All fractures of the proximal femur that occurred between 10/ 1993 and 2/1995 among women resident in 6 counties in Sweden who were born after 1913. Using clinical records or operation registers in all 24 hospitals in the study area, a total of 1,597 possible incident cases were identified. Those with a fracture due to malignancy (n=26); high-energy trauma (n-4); incorrect diagnosis (n=41); old fracture (n-10); blindness (n=5); birth outside Sweden (n=202); excluded: severe alcoholic abuse, psychosis, or senile dementia (n=576); or death within 3 months of the fracture (n=123). After exclusions, 1,610 eligible cases remained and were approached with. The Swedish inpatient register identified 34 additional cases. | Duration of breastfeeding was considered in 4 classes defined by the quartiles of either total duration or mean duration per child of breastfeeding among controls | | OR of hip fracture | Unconditional logistic regression were used as measure of association. The multivariate analyses included the covariates age, BMI, oral contraceptive use, HRT use, and smoking status. Interactions were considered. | Long total duration of breastfeeding was associated with a reduction in risk (table 3 in paper), but this association disappeared after adjustment for parity, body mass index, and use of exogenous estrogens. There were no substantial risk differences in analyses that considered mean duration of breastfeeding per child (quartiles 0–2, 3–4, 5–6, and 7 months per child or more) (data not shown). Long duration of breastfeeding also had no substantial association with hip fracture risk among those with their first pregnancy as a teenager or among those with their first pregnancy after age 30 years. The relative risk estimates for lactation and parity were similar for cervical and trochanteric hip fracture (data not shown). | | | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: post | | | Controls: Native-born women were randomly selected from the national population register in the month before the start of the study. Potential controls aged 70–80 years were frequency matched (2 controls per 1 case) to the expected hip fracture age distribution within county of residence. Controls aged 50–69 years were randomly selected from the population register as part of a breast cancer study being conducted at the same time with the same questionnaire. For these women, frequency matching to the expected number of breast cancer cases provided 2–4 times as many controls as hip fracture cases in each 5-year age group and country of residence. Of the 4,870 candidate controls in the hip fracture analysis, 4,059 were eligible for the study, 610 were born outside of Sweden, 257 died before being approached, 44 were senile or psychotic, and 2 were blind. | | | | Associations between lactation and hip fracture were only analyzed for parous women | | | | | | | Selection | x
Race: ND | | | | | | | | | | | | | | Study design | | x
Enrolled/Evaluate: 715/664 for cases evaluated | | | | | | | | | | | | | | Confounder | | x
Location: Sweden | | | | | | | | | | | | | | Blinding | | | x
Sites: Multi | | | | | | | | | | | | | | Data collection | | x
Funding: ND | | | | | | | | | | | | | | Withdraw and dropout | | x
| | | | | | | | | | | | | | Analyses | | x
| | | | | | | | | | | | | | Intervention integrity
| | | | | | | | | | | | | | Overall: B

Ovarian Cancer

Chiaffarino 2005

Cramer 1983

Greggi 2000

Gwinn 1990

Hartge 1989

John 1993

Modugno 2003

Ness 2000

Riman 2002

Risch 1983

Risch 1994

Siskind 1997

Titus-ernstoff 2001

Tung 2003, 2005

West 1966

Whittemore 1992

Wynder 1969

Yen 2003

Study characteristics | Subjects' health conditions | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | | Bias/limitations Comments
Chiaffarino, 2005 [UI# 15975644]
Median age (range): | Cases: ND | Case-control | Case: Histologicaly confirmed epithelial ovarian cancer diagnosed in past year, admitted to major or teaching hospital | Breast feeding status determined by questionnaire | Breast feeding status determined by questionnaire | Ovarian cancer confirmed by histology | Unconditioned multiple logistic regression adjusting for age, center, education, parity, oral contraceptive use, family history of ovarian/breast cancer in first degree relatives | Exposure status | Cases n (%) | Controls n (%) | OR_adj_ (95% CI) | | A: strong, B: moderate, C: weak | A | B | C
Cases: 56 (18–79) | Controls: traumatic conditions 26%, nontraumatic orthopedic disorders 28%, acute surgical conditions mostly abdominal diseases 15%, miscellaneous illnesses (ear, nose throat, teeth) 31% | Data collection by interviews using structured questionnaire | Control: residents of same geographic area, admitted to same network of hospitals for acute, non-neoplastic, unrelated to known or likely risk factors for ovarian cancer, exclusion include hormonal and gynecological diseases, or ovariectomized | | | | | Never breastfed | 368(36) | 878 (37) | 1.0 | | Selection | | X
Controls: 57 median (17–79) | | | | | | | | Ever breastfed | 660 (64) | 1512 (63) | 1.16 (0.93–1.43) | | Study design | | X
Menopause: ND | | | | | | | | Breastfed 1–4 months | 157 (15) | 358 (15) | 1.20 (0.91–1.59) | | Confounder | | | X
Race: ND | | | | | | | | Breastfed 5–8 months | 180 (18) | 366 (15) | 1.24 (0.95–1.62) | | Blinding | | X
Enrolled/Evaluate: | | | | | | | | Breastfed 9–16 months | 195 (19) | 451 (19) | 1.01 (0.77–1.33) | | Data collection | | | X
Cases: 1031/1028 | | | | | | | | Breastfed ≥17 months | 128 (12) | 337 (14) | 1.21 (0.85–1.71) | | Withdraw and dropout | | X
Controls: 2411/2390 | | | | | | | | X^2^ for trend | | | 0.03 (p=0.87) | | Analyses | X
Location: Italy | | | | | | | | Exposure status | Odds ratio_adj_(95% CI) | | | | Intervention integrity
Sites: Multi-center | | | | | | | | | Serous | Mucinous | Other subtypes | | Potential recall bias
Funding: Private, government | | | | | | | | Never breastfed | 1 | 1 | 1
| | | | | | | | Ever breastfed | 1.1 (0.85–1.48) | 1.59 (0.82–3.07) | 1.08 (0.71–1.62)
| | | | | | | | Breastfed 1–4 mo | 1.3 (0.90–1.85)
| | | | | | | | Breastfed 5–8 mo | 1.16 (0.81–1.65)
| | | | | | | | Breastfed 9–16 mo | 1.06 (0.74–1.51)
| | | | | | | | Breastfed ≥17 mo | 0.87 (0.55–1.39)
| | | | | | | | x^2^ for trend | 0.14 p=0.71
Cramer, 1983 [UI# 6578366]
Mean age: 53 | ND | Case-control | Cases: white females with epithelial ovarian cancer residing in greater Boston area | Breastfeeding status determined by questionnaire | Breastfeeding status determined by questionnaire | All types of epithelial ovarian cancer | Chi-square | Crude relative risks 1.11 (0.70–1.76) never breastfed parous cases (86/137) vs controls (106/176) | | | | | A: strong, B: moderate, C: weak | A | B | C
Menopause: ND | | Data collection by questionnaires | Controls: matched residents of same precinct, age within 2 years, race. Only bilateral oophorectomy excluded. | | | | | Non-significant trend in risk for ovarian cancer with number of children breastfed. | | | | | Selection | | X
Race: White | | | | | | | | | | | | | Study design | | X
Enrolled/Evaluate: | | | | | | | | | | | | | Confounder | | | X
Cases: 215 | | | | | | | | | | | | | Blinding | | X
Controls: 215 | | | | | | | | | | | | | Data collection | | | X
Location: USA | | | | | | | | | | | | | Withdraw and dropout | | X
Sites: Multi-center | | | | | | | | | | | | | Analyses | | | X
Funding: Government | | | | | | | | | | | | | Intervention integrity
| | | | | | | | | | | | | Minimal reporting of data
| | | | | | | | | | | | | Potential recall bias
Greggi, 2000 [UI# 11006030]
Median age (range): | Cases: ND | Case-control | Cases: admitted histologically confirmed diagnosis of epithelial ovarian cancer | Breast feeding status determined by interview | Breast feeding status determined by interview | Epithelial ovarian cancer confirmed by histology | Mantel-Haenzel adjusted for age; unconditional multiple logistic regression estimates including terms for age, education, parity, oral contraceptive use, family history of ovarian cancer | Exposure status* | Cases 330 (%) | Controls 721 (%) | OR_adj_ (95% CI) | | A: strong, B: moderate, C: weak | A | B | C
Cases: 54 (13–80) | Controls: traumatic conditions 29%, nontraumatic orthopedic disorders 21%, acute abdominal diseases generally requiring surgery 17%, miscellaneous illnesses (ear, nose throat, teeth) 33% | Data collection by hospital interviews | Controls: admitted to same hospital, similar age strata, acute nongynecological, nonhormonal, or nonneoplastic condition | | | | | | | | Mantel-Haenzel | Multivariate regression | Selection | | X
Controls: 55 (19–80) | | | | | | | | Never breastfed | 84 (25) | 120 (17) | 1.0 | 1.0 | Study design | | X
Menopause: mix | | | | | | | | Breastfed ≤12 months | 136 (41) | 294 (41) | 0.6 (0.5–0.9) | 0.8 (1.0–1.1) | Confounder | | X
Race: ND | | | | | | | | Breastfed >12 months | 110 (33) | 307 (43) | 0.5 (0.3–0.7) | 0.5 (0.4–0.8) | Blinding | | X
Enrolled/Evaluate*: | | | | | | | | *Parous | | | | | Data collection | | | X
Cases: 440/330 | | | | | | | | | | | | | Withdraw and dropout | | | X
Controls 868/721 | | | | | | | | | | | | | Analyses | | X
Location: Italy | | | | | | | | | | | | | Intervention integrity
Sites: Single | | | | | | | | | | | | | Potential recall bias
Funding: Private
*Parous
Gwinn, 1990 [UI# 2348208]
Mean age (range): ND | ND | Case-control | Cases: 20–54 year, resides in 1 of 8 study areas, ovarian cancer by histology | Breast feeding status determined by interview, duration in months regardless of pattern | Breast feeding status determined by interview | Epithelial ovarian cancer confirmed by histology | Logistic regression adjusted for pregnancy, oral contraceptive use, age, and age-pregnancy interaction | Breastfeeding duration (month)* | Cases n (%) | Controls n (%) | RR_adj_(95% CI) | | A: strong, B: moderate, C: weak | A | B | C
Menopause: mix | | Controls contacted by random telephone | Controls: matched for age, resides in same 8 areas, no ovaries or unknown number of ovaries are exclusion | | | | | 0 | 184 (57) | 1517 (46) | 1.0 | | Selection | | X
Race: ND | | Data collection by interview of standard questionnaire | | | | | | 1–2 | 40 (12) | 552 (17) | 0.6 (0.5–0.9) | | Study design | | X
Enrolled/Evaluate: | | | | | | | | 3–5 | 32 (10) | 330 (10) | 0.8 | | Confounder | | X
Cases: 494/436 | | | | | | | | 6–11 | 33 (10) | 379 (11) | 0.8 | | Blinding | | X
Controls: 4236/3833 | | | | | | | | 12–23 | 25 (8) | 321 (10) | 0.7 | | Data collection | | X
Location: USA | | | | | | | | ≥ 24 | 7 (2.2) | 213 (6.4) | 0.3 | | Withdraw and dropout | | X
Sites: Multi center | | | | | | | | * Parous women only | | | | | Analyses | X
Funding: | | | | | | | | β -0.024 | | | | | Intervention integrity
| | | | | | | | Each month of breastfeeding reduced risk by 2.4% | | | | | Ovarian cancer confirmed by histology in majority of cases
Hartge, 1989 [UI# 2750791]
Mean age (range): | Serous 28% | Case-control | Cases: primary epithelial ovarian cancer confirmed by microscopic slides and medical records, included low malignant potential tumors as well as malignant tumors | Breastfeeding status determined by interview | Breastfeeding status determined by interview | Primary epithelial ovarian cancer confirmed by microscopic slides and medical records | Rate ratio of ovarian cancer incidence in exposed group to corresponding unexposed group, adjusted for confounding variables by stratified contingency table analysis and by logistic regression models, adjustments for age and race, and parity, difficulty conceiving, oral contraceptives, surgical menopause, HRT, or family history of ovarian cancer as needed | Breastfeeding duration (month)* | Cases n (%) | Controls n (%) | Rate ratio_adj_(95% CI) | | A: strong, B: moderate, C: weak | A | B | C
Cases: 54 (20–79) | Serous, low malignant potential 12% | Data collection with interviewer of standard questionnaire and medical records review | Controls: hospitalized for other conditions, matched for age, hospital, race, at least one ovary. Excluded if psychiatric diagnosis or related to major exposures of interest | | | | | 0 | 112 (55) | 121 (47) | 1.0 | | Selection | | X
Controls: 55 | Mucinous 6% | | | | | | | 1–9 | 62 (31) | 84 (33) | 0.8 (0.5–1.2) | | Study design | | X
Menopause: mix | Mucinous, low malignant potential 3% | | | | | | | 10–18 | 16 (7.9) | 37 (18) | 0.5 (0.2–0.9) | | Confounder | | X
Race: | Endometrioid, low malignant potential 26% | | | | | | | 19–110 | 13 (6.4) | 15 (7.4) | 1.1 (0.5–2.6) | | Blinding | | X
Cases: 12% black | Clear cell 4% | | | | | | | * Parous women only | | | | | Data collection | | X
Controls: 14% black | Mixed epithelial 8% | | | | | | | Adjusted for age and race | | | | | Withdraw and dropout | | X
Enrolled/Evaluate: | Undifferentiated 10% | | | | | | | Trend test p = 0.14 | | | | | Analyses | | X
Cases: 296/203* | Controls: | | | | | | | Number of months breastfeeding not related to risk | | | | | Intervention integrity
Controls: 343/257* | Infectious 2%
Location: USA | Neoplasm 5%
Sites: Multi | Endocrine-metabolic 5%
Funding: Government | Blood disease or blood-forming organs 1%
*Parous women (evaluated) | Nervous system 8%
| Eye, ear, mastoid 8%
| Varicose veins, hemorrhoids 1%
| Respiratory 8%
| Digestive system 16%
| Urinary 5%
| Skin 2%
| Musculoskeletal 22%
| Congenital 1%
| Ill-defined 5%
| Fractures/injuries 11%
John, 1993 [UI# 8418303]
Mean age (range): | Invasive cancer 65% | Case-control | Epithelial ovarian cancer | Breastfeeding status determined by interview | Breastfeeding status determined by interview | Epithelial ovarian cancer | Conditional logistic regression adjusted for study, birth year, reference age, parity | Breastfeeding duration (month)* | Cases n (%) | Controls n (%) | RR_adj_ (95% CI) | | A: strong, B: moderate, C: weak | A | B | C
Cases: | Low malignant 32% | Data from 7 studies of cases diagnosed between 1971 and 1986. Individual patient data collected by interview from 7 case-control studies conducted in US | Controls: population and hospital subjects, bilateral oophorectomy excluded | | | | | Never breastfed | 24 (45) | 102 (39) | 1.0 | | Selection | | X
Invasive 53 | Unknown 3% | | | | | | | Ever breastfed | 29 (55) | 157 (61) | 0.90 (0.42–1.9) | | Study design | | X
Borderline 37 | | | | | | | | 1–5 | 11 (21) | 52 (20) | 1.0 (0.39–2.6) | | Confounder | | | X
Controls: ND | | | | | | | | ≥6 | 18 (34) | 103 (40) | 0.85 (0.36–2.0) | | Blinding | | X
Menopause: mix | | | | | | | | Trend per month | | | 0.99 p=0.57 | | Data collection | | | X
Race: Black | | | | | | | | * Parous | | | | | Withdraw and dropout | | X
Enrolled/Evaluate: | | | | | | | | | | | | | Analyses | | X
Cases: 110/53 | | | | | | | | | | | | | Intervention integrity
Controls: 365/259 | | | | | | | | | | | | | Data unavailable for use of oral contraceptives and years of ovulation
69% population
31% hospital
Location: USA
Sites: 7 of 12 studies
Funding: Government
Modugno, 2003 [UI# 12946038]
Mean age (range): | ND | Case-control | Jewish women with epithelial ovarian cancer, no breast cancer history, BRCA1/2 confirmed by data sequencing | ND | ND | Invasive epithelial ovarian cancer confirmed by histology | Unconditioned logistic regression adjusted for age at diagnosis, year of birth, number of live births, oral contraceptive use, history of tubal ligation. Mantel-Haenszel test for heterogeneity | | OR_adj_(95% CI) | | | | A: strong, B: moderate, C: weak | A | B | C
BRCA1 51 | | Cases screened for Ashkenazi founder mutations | | | | | | | BRCA-(n=147) | BRCA1/2 (n=95) | BRCA1 (n=64) | BRCA2 (n=31) | Selection | | | X
BRCA2 61 | | BRCA1 (185delAG or 5382insC) or BRCA2 (6174delT) | | | | | | Breastfeeding | 1.0 | 1.09 (0.61–1.97) | 1.36 (0.68–2.73) | 0.70 (0.28–1.72) | Study design | | X
BRCA- 58 | | Controls were ovarian cases without BRCA1/2 genotype | | | | | | Breastfeeding duration* | 1.0 | 1.02 (0.99–1.04) | 1.01 (0.98–1.04) | 1.02 (0.99–1.05) | Confounder | | | X
Menopause: mix | | Individual patient data collected by interview from 4 case-control studies. Two US population studies (100 cases), one hospital-based study from 11 US and Israel centers (208 cases), and one US genetic counseling center (14 cases) | | | | | | * Parous women | | | | | Blinding | | X
Race: 100% Jewish | | | | | | | | | | | | | Data collection | | | X
Enrolled/Evaluate: | | | | | | | | | | | | | Withdraw and dropout | | X
Cases: 95 | | | | | | | | | | | | | Analyses | | X
Controls: 147 | | | | | | | | | | | | | Intervention integrity
Location: USA, Israel | | | | | | | | | | | | | 10% overlap in samples between the US genetic center & hospital-based study
Sites: Multi | | | | | | | | | | | | | Classification of Jewish varied between studies
Funding: Government
Ness, 2000 [UI# 11021606]
Modugno, 2001 [UI# 11308435]
Mean age (range): | Invasive epithelial 616 | Case-control | Histologically confirmed epithelial ovarian cancer diagnosed past 6 months, 20–69 years | Breastfeeding status determined by interview, length recorded on life calendar | Breastfeeding status determined by interview, length recorded on life calendar | Epithelial ovarian cancer confirmed by histology | Multivariate unconditional logistic regression adjusted for age, number of pregnancies, family history of ovarian cancer, race, oral contraceptive use, tubal ligation, hysterectomy, breastfeeding | Breastfeeding duration (month)* | Cases n (%) | Controls n (%) | Odds ratio_adj_(95% CI) | | A: strong, B: moderate, C: weak | A | B | C
Cases: | Serous 45% | Data collection by interview | Controls: ≤ 65 years, matched by 5 years and 3 digit exchange | | | | For analyses by histology: multivariate unconditional logistic regression adjusted for age, number of live births, years of oral contraceptive use, years of noncontraceptive estrogen use and months breastfed, tubal ligation, hysterectomy, family history of ovarian and breast cancer, ethnicity | 0 | 299 (56) | 577 (48) | 1.0 | | Selection | | X
Invasive 53 | Mucinous 8% | Controls identified by random-digit dialing from HFCA lists | Exclusion: outside counties of referral hospital, prior diagnosis of ovarian cancer, non-English speaking, mentally incompetent, critically ill, prior bilateral oophorectomy | | | | | 1–5 | 117 (22) | 259 (22) | 0.9 (0.7–1.2) | | Study design | | X
Borderline 45 | Endometrioid 22% | | | | | | | 6–11 | 46 (8.7) | 119 (10) | 0.9 (0.6–1.3) | | Confounder | | X
Controls: 49 | Other 24% | | | | | | | 12–23 | 40 (7.5) | 124 (10) | 0.7 (0.5–1.1) | | Blinding | | | X
Menopause: mix | Borderline epithelial 151 | | | | | | | ≥24 | 29 (5.5) | 111 (9.3) | 0.6 (0.4–1.0) | | Data collection | | X
Race: ND | Serous 52% | | | | | | | * Parous women only | | | | | Withdraw and dropout | | | X
Enrolled/Evaluate: | Mucinous 40% | | | | | | | Histologic subgroup (N) | Months breastfed Odds ratio_adj_ (95% CI) | | | | Analyses | | X
Cases: 767/531* | Endometrioid 2% | | | | | | | Serous (357) | 1.00 (0.98–1.01) | | | | Intervention integrity
Controls: 1215/1190* | Other 6% | | | | | | | Mucinous (112) | 1.00 (0.98–1.02)
Location: USA | Other includes clear cell, mixed cell, undifferentiated or poorly differentiated | | | | | | | Endometrioid (139) | 0.97 (0.94–1.00)
Sites: Multi | | | | | | | | Other (159) | 0.97 (0.94–1.00)
Funding: Government | | | | | | | | All (767) | 0.99 (0.98–1.00)
*Parous women (evaluated)
Riman, 2002 [UI# 12181107]
Mean age (range): | All invasive (655) | Case-control | Swedish born women 50–74 years old with epithelial ovarian cancer confirmed by histology identified by national registry | Breastfeeding status determined by questionnaires | Breastfeeding status determined by questionnaires | Epithelial ovarian cancer confirmed by histology | Unconditional logistic regression adjusted for age, bmi, parity, age at menopause, duration of oral contraceptive use, HRT use | Breastfeeding duration (months) | Cases n (%) | Controls n (%) | OR_adj_ (95% CI) | | A: strong, B: moderate, C: weak | A | B | C
Cases: 62 | Serous (337) | Data collected by self-administered questionnaires followed up by phone for missing or inconsistent details | Controls: randomly selected population national registry | | | | | <1 | 33 (7.2) | 161 (15) | 1.0 | | Selection | X
Controls: 63 | Mucinous (60) | | Exclusion: previous ovarian malignancy or bilateral oophorectomy | | | | | 1–5 | 134 (29) | 612 (15) | 0.99 (0.64–1.52) | | Study design | | X
Menopause: mix | Endometrioid (180) | | | | | | | 6–11 | 134 (29) | 840 (19) | 0.77 (0.50–1.19) | | Confounder | | X
Race: ND | Clear cell (43) | | | | | | | ≥12 | 158 (34) | 1,024 (14) | 0.87 (0.56–1.35) | | Blinding | X
Enrolled/Evaluate: | Other/undifferentiated (35) | | | | | | | Parous women | | | | | Data collection | | X
Cases: 914/655 | | | | | | | | Breastfeeding duration (months) | Odds Ratio_adj_ (95% CI) | | | | Withdraw and dropout | | X
Controls: 4148/3899 | | | | | | | | | Serous | Mucinous | Endometrioid | Clear cell | Analyses | | X
Location: Sweden | | | | | | | | <1 | 1.0 | 1.0 | 1.0 | 1.0 | Intervention integrity
Sites:NA | | | | | | | | 1–5 | 0.87 (0.50–1.53) | 2.19 (0.49–9.87) | 1.05 (0.47–2.34) | 0.54 (0.16–1.87) | 50% of cases and controls were contacted by phone for missing or inconsistent data; unknown if breastfeeding status category <1 month includes no breastfeeding or data was unavailable
Funding: Private, government | | | | | | | | 6–11 | 0.61 (0.35–1.09) | 1.75 (0.39–7.87) | 1.10 (0.50–2.46) | 0.23 (0.06–0.88)
| | | | | | | | ≥12 | 0.87 (0.49.–1.54) | 0.83 (0.49–1.54) | 1.02 (0.44–2.37) | 0.24 (0.06–0.97)
Risch, 1983 [UI# 6681935]
Mean age (range): | ND | Case-control | Epithelial ovarian cancer diagnosed in past 18 months, reside in 6 specified counties of Washington and Utah and identified by population-based cancer reporting systems, age 34–74 for Washington cases, age 20–74 for Utah cases | Breastfeeding status determined by interview | Breastfeeding status determined by interview | Epithelial ovarian cancer | Linear logistic regression adjusted for age at diagnosis 20–44, nulliparous, no miscarriages, < 1 year total exposure to combined oral contraceptives, nonobese | RR 0.79 per year of lactation p=0.034, is associated with decreased ovarian cancer risk | | | | | A: strong, B: moderate, C: weak | A | B | C
Cases: 20–74 | | Data collection by interview | Controls: household survey conducted in same counties by standard geographic sampling methods or telephone selected from directories. Utah samples matched for age and Washington samples matched for age range. Exclusion included bilateral oophorectomy ≤ 1 year | | | | | Cases reported less time breastfeeding than controls | | | | | Selection | | | X
Controls: 21–75 | | Cases | Additional case-control exclusion: nonwhite, incomplete reproductive histories | | | | | 3+ total months lactation - RR 0.69 (0.50–0.96) p=0.026 | | | | | Study design | | X
Menopause: mix | | | | | | | | | | | | | Confounder | | X
Race: white | | | | | | | | | | | | | Blinding | | X
Enrolled/Evaluate: | | | | | | | | | | | | | Data collection | | | X
Cases: 284 | | | | | | | | | | | | | Withdraw and dropout | | X
Controls: 705 | | | | | | | | | | | | | Analyses | | X
Location: USA | | | | | | | | | | | | | Intervention integrity
Sites: Multi
Funding: Government
Risch, 1994 [UI# 7942759]
Mean age (range): | ND | Case-control | Primary malignant or borderline malignant epithelial ovarian cancer confirmed by histology, age 35–79, residents of Ontario located through Ontario Cancer Registry, living subjects | Breastfeeding status determined by interview | Breastfeeding status determined by interview | Primary malignant or borderline malignant epithelial ovarian cancer confirmed by pathology reports | Multivariate unconditional continuous logistic regression adjusted for 3 age groups, continuous variables age, total duration of oral contraceptive use | No of full-term pregnancies | Mean | | Odds ratio_adj_(95% CI) | | A: strong, B: moderate, C: weak | A | B | C
Cases: 57 | | Data collection by interview using questionnaire incorporating life events calendar - conducted at subject's home | Controls: obtained from Enumeration Composite Record listing compiled by Ontario Ministry of Revenue, matched for area of residence and age range, exclusion included bilateral oophorectomy < 1 year, living subjects | | | | | | Cases | Controls | | | Selection | | X
Controls: 58 | | | | | | | | Total duration* (year) | 0.51 | 0.65 | 0.89 (0.75–1.05) | | Study design | | X
Menopause: mix | | | | | | | | Average duration of lactation/pregnancy* (months) | 2.24 | 2.72 | 0.87 (0.76–0.99) | | Confounder
Race: 96% white | | | | | | | | *Adjusted for number of full-term pregnancies | | | | | Blinding | | X
Enrolled/Evaluate: | | | | | | | | Inverse association with total duration of lactation | | | | | Data collection | | X
Cases: 450 | | | | | | | | Inverse association with average duration per pregnancy, p=0.030 | | | | | Withdraw and dropout | | X
Controls: 564 | | | | | | | | Pregnancies with lactation slightly more protective than pregnancies without | | | | | Analyses | | | X
Location: Canada | | | | | | | | | | | | | Intervention integrity
Sites: Multi | | | | | | | | | | | | | Slightly greater number for controls born in Canada or US, smaller percentage of cases were parous or ever used OC and among those cases had fewer full-term pregnancies and used OC for shorter periods of time

Study characteristics | | | | Subjects' health conditions | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | | | | Bias/limitations Comments
Siskind, 1997 [UI# 9229212]
Mean age* (range): | | | | ND | Case-control | Cases: Histologically confirmed primary epithelial ovarian cancer, 18–79 years, ≥ 1 live birth | Breastfeeding status determined by questionnaire | Breastfeeding status determined by questionnaire | Primary epithelial ovarian cancer confirmed by histology | Multiple logistic regression with covariates: age, parity, age at 1^st^ birth, education, oral contraceptive use, smoking history, menopausal status | Breastfeeding duration (month) | Cases n (%) | Controls n (%) | Odds ratioadj (95% CI) | | | | A: strong, B: moderate, C: weak | A | B | C
Cases: 57 | | | | | Data collection by interviewer with questionnaire at discharge or clinic follow-up, in homes for all controls and homes or clinics for cases | Controls: similar age and region | | | | | 0 | 168 (27) | 155 (21) | 1 | | | | Selection | | X
Controls: 56 | | | | | Controls randomly selected through electoral roll | Exclusion: history of ovarian cancer or bilateral oophorectomy, incapable of completing questionnaire | | | | | 1–6 | 180 (29) | 190 (26) | 0.89 (0.65–1.2) | | | | Study design | | X
Menopause: mix | | | | | | | | | | | 7–12 | 125 (20) | 187 (26) | 0.68 (0.49–0.94) | | | | Confounder | | X
Premenopausal | | | | | | | | | | | 13–24 | 107 (17) | 141 (19) | 0.84 (0.59–1.2) | | | | Blinding | | | X
Cases: 35% | | | | | | | | | | | 25–36 | 25 (4) | 39 (5) | 0.69 (0.38–1.3) | | | | Data collection | | X
Controls: 36% | | | | | | | | | | | >36 | 13 (2) | 12 (2) | 0.77 (0.34–1.8) | | | | Withdraw and dropout | | X
Race: ND | | | | | | | | | | | Any | 450 (73) | 569 (79) | 0.80 (0.61–1.04) | | | | Analyses | X
Enrolled/Evaluate*: | | | | | | | | | | | Per month | | | 0.99 (0.98–1.0) | | | | Intervention integrity
Cases: 824/618 | | | | | | | | | | | * Parous women only
Controls: 855/724 | | | | | | | | | | | Breastfeeding duration (month) | Premenopausal | | Postmenopausal
Location: Australia | | | | | | | | | | | | Cases n (%) | Controls n (%) | Cases n (%) | Controls n (%)
Sites: Multi | | | | | | | | | | | | Odds ratioadj (95% CI) | | Odds ratioadj (95% CI)
Funding: Government, private | | | | | | | | | | | 0 | 75 (35) | 66 (25) | 93 (23) | 89 (19)
*Parous | | | | | | | | | | | | 1.00 | | 1.00
| | | | | | | | | | | 1–6 | 69 (32) | 78 (29) | 111 (27) | 112 (24)
| | | | | | | | | | | | 0.75 (0.46–1.21) | | 0.98 (0.65–1.47)
| | | | | | | | | | | 7–12 | 34 (16) | 72 (27) | 91 (23) | 115 (25)
| | | | | | | | | | | | 0.53 (0.31–0.94) | | 0.83 (0.54–1.26)
| | | | | | | | | | | 13–24 | 33 (15) | 36 (14) | 74 (18) | 105 (23)
| | | | | | | | | | | | 1.03 (0.54–1.95) | | 0.88 (0.56–1.38)
| | | | | | | | | | | >24 | 4 (4) | 12 (5) | ---
| | | | | | | | | | | | 0.29 (0.08–1.04)
| | | | | | | | | | | 25–36 | --- | | 21 (5) | 27 (6)
| | | | | | | | | | | | | | 0.93 (0.46–1.88)
| | | | | | | | | | | >36 | --- | | 13 (3) | 12 (3)
| | | | | | | | | | | | | | 1.27 (0.50–3.2)
| | | | | | | | | | | * Parous women only
Titus-Ernstoff 2001 [UI# 11237375]
Mean age (%): | | | | Serous borderline 86 | Case-control | Cancer registry and hospital board cases of epithelial ovarian cancer including lesions of borderline malignancy, 20–74 years, | Breastfeeding status determined by interview | Breastfeeding status determined by interview | Epithelial ovarian cancer by pathology report or microscopy slides | Unconditional logistic regression adjusted for age, state, parity | Breastfeeding duration (month)* | Cases n (%) | Controls n (%) | Odds ratio_adj_ (95% CI) | | | | A: strong, B: moderate, C: weak | A | B | C
| Cases | Controls | | Serous invasive 229 | Data collection by interviewer with questionnaire in homes for all controls and case | Controls: matched by age within 4 years and telephone sampling unit, >60 years were matched by age and precinct, exclusion included bilateral oophorectomy | | | | | 0 | 239 (63) | 223 (53) | 1.0 | | | | Selection | | X
<30 | 29(5.2) | 37(7.1) | | Mucinous 83 | Controls selected by random digit dialing, >60 years by Town Books | | | | | | <3 | 43 (11) | 48 (12) | 0.9 (0.6–1.4) | | | | Study design | | X
30–39 | 78(14) | 89(17) | | Endometrioid/clear cell 130 | | | | | | | 3–6 | 54 (14) | 76 (18) | 0.7 (0.5–1.1) | | | | Confounder | | X
40–49 | 159(28) | 136(26) | | * Parous women only | | | | | | | >6 | 42 (11) | 70 (17) | 0.7 (0.4–1.0) | | | | Blinding | | | X
50–59 | 126(22) | 118(23) | | | | | | | | | Ever | 139 (37) | 194 (47) | 0.7 (0.5–1.0) | | | | Data collection | | X
60–69 | 118(21) | 117(22) | | | | | | | | | P for trend | | | 0.21 | | | | Withdraw and dropout | | X
≥70 | 53(9.4) | 26(5.0) | | | | | | | | | * Parous women only | | | | | | | Analyses | | X
Menopause: mix | | | | | | | | | | | Breastfeeding Status | Odds Ratio_adj_ (95% CI) | | | | | | Intervention integrity
Race: ND | | | | | | | | | | | | Serous borderline (n=86) | Serous invasive (n=229) | Mucinous (n=83) | Endometrioid /Clear cell (n=130)
Enrolled/Evaluate: | | | | | | | | | | | Never breastfed | 1.0 | 1.0 | 1.0 | 1.0
Cases: 563/378* | | | | | | | | | | | Ever breastfed | 0.8 (0.4–1.6) | 1.0 (0.6–1.4) | 0.6 (0.3–1.2) | 0.4 (0.2–0.7)
Controls: 523/417* | | | | | | | | | | | P for trend^1^ | 0.61 | 0.34 | 0.88 | 0.04
Location: USA | | | | | | | | | | | ^1^Average duration (months) per breastfed child
Sites: Multi
Funding: Government
* Parous women only
Tung, 2003 [UI# 14507598], Tung 2005 [UI# 15692075]
Mean age (range): | | | | Invasive n=431 | Case-control | Cases: ≥18 years, epithelial ovarian cancer confirmed by histology, identified by population-based cancer registry, reside in Los Angeles, California or Hawaii for 1 year prior to diagnosis | Breastfeeding status determined by interview | Breastfeeding status determined by interview | Epithelial ovarian cancer confirmed by histology | Polytomous logistic model adjusted for age, ethnicity, study site, education, oral contraceptive use, tubal ligation | Breastfeeding | Odds ratio_adj_ (95% CI) | | | | | | A: strong, B: moderate, C: weak | A | B | C
Cases: 50 Mucinous | | | | Mucinous 11% | Data collection by interviewer with questionnaire including life calendar in homes for 95% of all interviewed | Controls: ≥18 years, reside in Los Angeles, California or Hawaii for 1 year prior to Interview, no prior history of ovarian cancer, ≥1 intact ovary, matched for age (±5 years), ethnicity, study site, randomly selected from neighborhood walk procedure in LA and Hawaii Department of Health state-wide annual survey list | | | | Unconditional logistic regression adjusted for age, ethnicity, study site, education, tubal ligation, HRT, ovulation variables | | All cases | Mucinous | Nonmucinous | | | | Selection | | X
55 Nonmucinous | | | | Serous 51% | | | | | | | Never | 1 | 1 | 1 | | | | Study design | | X
Controls: 56 | | | | Endometrioid 17% | | | | | | | Ever | 0.6 (0.4–0.7) | 0.8 (0.5–1.4) | 0.5 (0.4–0.7) | | | | Confounder | | X
Menopause: premenopausal 39% | | | | Clear cell 11% | | | | | | | Breastfeeding duration (month)* | | | | | | | Blinding | | | X
Race %: | | | | Other(undifferentiated, squamous, transitional) 10% | | | | | | | 0 | 1 | 1 | 1 | | | | Data collection | | X
| Cases Mucinous | Cases Nonmucinous | Controls | Borderline n=127 | | | | | | | ≤5 | 0.6 (0.4–0.9) | 0.6 (0.4–1.4) | 0.7 (0.4–0.9) | | | | Withdraw and dropout | | X
Asian | 51 | 34 | 42 | Mucinous 48% | | | | | | | 6–16 | 0.6 (0.4–0.9) | 0.7 (0.3–1.3) | 0.5 (0.3–0.7) | | | | Analyses | X
White | 30 | 50 | 44 | Serous 52% | | | | | | | >16 | 0.6 (0.4–0.8) | 0.9 (0.8–1.8) | 0.4 (0.3–0.7) | | | | Intervention integrity
Other | 19 | 16 | 14 | | | | | | | | P for trend* | 0.011 | 0.99 | 0.0005 | | | | Controls were better educated had greater number of full-term pregnancies, use oral contraceptive more, higher frequency of tubal ligation
Enrolled/Evaluate: | | | | | | | | | | | *Based on likelihood ratio test comparing models with and without a trend variable that was assigned median values for the categories
Cases: 558 | | | | | | | | | | | Total breastfeeding duration (year)* | Odds ratio_adj_ (95% CI)
Controls: 607 | | | | | | | | | | | | Premenopausal | Postmenopausal
Location: USA | | | | | | | | | | | 0 | 1
Sites: Multi | | | | | | | | | | | <0.5 | 0.96 (0.49–1.85) | 0.64 (0.41–1.02)
Funding: Government | | | | | | | | | | | 0.5–1.0 | 0.81 (0.43–1.54) | 0.60 (0.36–1.00)
| | | | | | | | | | | >1.0 | 0.46 (0.22–0.97) | 0.69 (0.43–1.12)
| | | | | | | | | | | P for trend | 0.003 | 0.08
| | | | | | | | | | | Odds ratio_adj_ (95% CI | Breastfeeding | | Breastfeeding duration (month)*
| | | | | | | | | | | Invasive cases | Never | Ever | ≤5 | 1–16 | >16 | P for trend*
| | | | | | | | | | | All cases | 1 | 0.5 (0.4–0.7) | 0.6 (0.4–0.9) | 0.5 (0.4–0.8) | 0.5 (0.3–0.7) | 0.002
| | | | | | | | | | | Mucinous | | 1.2 (0.6–2.7) | 0.7 (0.3–1.8) | 1.1 (0.5–2.6) | 1.2 (0.5–3.0) | 0.30
| | | | | | | | | | | Serous | | 0.5 (0.3–0.7) | 0.6 (0.4–0.9) | 0.5 (0.3–0.8) | 0.4 (0.2–0.7) | 0.96
| | | | | | | | | | | Endometrioid | | 0.5 (0.3–0.9) | 0.6 (0.3–1.2) | 0.6 (0.3–1.3) | 0.3 (0.1–1.0) | 0.10
| | | | | | | | | | | Clear cell | | 0.5 (0.2–1.0) | 0.6 (0.3–1.5) | 0.5 (0.3–1.4) | 0.3 (0.1–1.1) | 0.40
| | | | | | | | | | | Other | | 0.5 (0.3–1.1) | 0.7 (0.3–1.8) | 0.2 (0.1–0.8) | 0.6 (0.2–1.8) | 0.92
| | | | | | | | | | | Duration of breastfeeding nonsignificant for invasive ovarian types
| | | | | | | | | | | Duration of breastfeeding significant with risk of nonmucinous, p=0.03
| | | | | | | | | | | Breastfeeding duration (year)* | Odds ratio_adj_ (95% CI)
| | | | | | | | | | | | All women | Premenopausal | Postmenopausal
| | | | | | | | | | | | | Cases n=217 | Cases n=341
| | | | | | | | | | | | | Controls | Controls
| | | | | | | | | | | | | n=256 | n=351
| | | | | | | | | | | 0 | 1 | 1 | 1
| | | | | | | | | | | <0.5 | 0.69 (0.48–1.01 | 0.96 (0.49–1.85) | 0.64 (0.41–1.02)
| | | | | | | | | | | 0.5–1.0 | 0.62 (0.42–0.91) | 0.81 (0.43–1.54) | 0.6 (0.36–1.00)
| | | | | | | | | | | >1.0 | 0.6 (0.40–0.89) | 0.46 (0.22–0.97) | 0.69 (0.43–1.12)
| | | | | | | | | | | P for trend | 0.001 | 0.003 | 0.08
| | | | | | | | | | | (Log) year | 0.7 (0.46–1.05) | 0.51 (0.22–1.18) | 0.76 (0.46–1.24)
| | | | | | | | | | | Year | 0.91 (0.72–1.15) | 0.68 (0.40–1.17) | 0.95 (0.73–1.24)
| | | | | | | | | | | Breastfeeding lower in cases than controls, p=0.001
| | | | | | | | | | | Significant inverse dose-response relations for breastfeeding among premenopausal
West, 1966 [UI# 5939299]
Mean age (range): | | | | Cases: | Case-control | Cases: malignancy of ovary, 50 mile radius of Boston, exclusion includes >75 years and co-existent malignancy of another organ that was not metastatic from ovary and recurrent cases | Breast feeding status determined by interview | Breast feeding status determined by interview | Malignant ovarian cancer confirmed by pathology | T test with p level of 0.01 for significance | 76 matched pairs | | | | | | | A: strong, B: moderate, C: weak | A | B | C
Cases: 53 | | | | Pseudo-mucinous cystadenocarcinoma 23 | Data collection by interview | Controls: female hospital patients matched for age ± 5 years, residence and date of surgery, next operated case of benign ovarian neoplasms from same hospital as malignant case | | | | | Lactation (months) | | | | | | | Selection | | | X
Controls: 50 | | | | Serous cystadenocarcinoma 16 | | | | | | | Cases | Controls | | | | | | Study design | | X
Menopause: mix | | | | Cystadenocarcinoma and adenocarcinoma 43 | | | | | | | 6.6 | 5.8 | | | | | | Confounder | | | X
Race: ND | | | | Carcinoma 6 | | | | | | | p > 0.3 | | | | | | | Blinding | | | X
Enrolled/Evaluate: | | | | Granulosa cell 5 | | | | | | | | | | | | | | Data collection | | X
Cases: 97/76 | | | | Teratoma 1 | | | | | | | | | | | | | | Withdraw and dropout | | X
Controls: 91/76 | | | | Dysgerminoma 1 | | | | | | | | | | | | | | Analyses | | | X
Location: USA | | | | Meso-meta-nephroma 1 | | | | | | | | | | | | | | Intervention integrity
Sites: Multi | | | | Unclassified 1 | | | | | | | | | | | | | | Cases and controls classified as private and service with more control taken from service care implying differ SES. Only descriptive statistics given for education. Not adjusting for potential confounders
Funding: ND | | | | Controls: (25 diagnoses)
| | | | Endometriosis 19
| | | | Simple cyst 10
| | | | Pseudo-mucinous cystadenoma 9
| | | | Dermoid cyst 8

Study characteristics | Subjects' health conditions | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | Bias/limitations Comments
Whittemore, 1992 [UI# 1476141]
Mean age (range): | ND | Case-control | Studies with individual patient data collected from personal interviews through structured questionnaires, data coded and stored electronically, variable definitions documented | Breastfeeding status determined by interview | Breastfeeding status determined by interview | Invasive epithelial tumors | Conditional logistic regression with odds ratio adjusted for age, study, parity, oral contraceptive use | Breastfeeding duration (month)* | Cases n (%) | Controls n (%) | RR_adj_ (95% CI) | A: strong, B: moderate, C: weak | A | B | C
Cases: ND | | Data from 12 studies conducted from 1956-1986. 6 hospital and 6 population (random-digit dialing) controls. | Cases: newly diagnosed invasive epithelial tumors at US hospital | | | | | Hospital studies | | | | Selection | | X
Controls: ND | | Breastfeeding data from 7 studies; 2 hospital- and 5 population-based studies | Controls: reside in US, during time of case ascertainment, no gynecological condition if hospital controls | | | | | 0 | 117 (58) | 612 (57) | 1.0 | Study design | | X
Menopause: mix | | | | | | | | 1–5 | 49 (24) | 237 (22) | 0.95 (0.62–1.5) | Confounder | | | X
Race: White | | | | | | | | 6–11 | 13 (6) | 110 (10) | 0.40† (0.20–0.78) | Blinding | | X
Enrolled/Evaluate: | | | | | | | | 12–23 | 16 (8) | 78 (7) | 0.70 (0.36–1.4) | Data collection | | | X
Cases: 2197/1071 | | | | | | | | ≥24 | 6 (3) | 44 (4) | 0.59 (0.22–1.6) | Withdraw and dropout | | X
Controls: 8893/5705 | | | | | | | | Any breastfeeding | 84 (42) | 469 (43) | 0.73 (0.51–1.0) | Analyses | | X
Location: USA | | | | | | | | Trend per month | | | 0.99 p=0.18 | Intervention integrity
Sites: 12 studies, of which 7 with breastfeeding data | | | | | | | | Population studies
Funding: Government | | | | | | | | 0 | 478 (55) | 2152 (47) | 1.0
| | | | | | | | 1–5 | 208 (24) | 1188 (26) | 0.87 (0.72–1.1)
| | | | | | | | 6–11 | 88 (10) | 567 (12) | 0.74 (0.57–0.96)
| | | | | | | | 12–23 | 61 (7) | 449 (10) | 0.69 (0.51–0.94)
| | | | | | | | ≥24 | 35 (4) | 268 (6) | 0.74 (0.49–1.1)
| | | | | | | | Any breastfeeding | 392 (45) | 2472 (53) | 0.81† (0.68–0.95)
| | | | | | | | Trend per month | | | 0.99†
| | | | | | | | * Parous
| | | | | | | | † p<0.01
| | | | | | | | Risk reduction per month of breastfeeding within 6 months delivery exceeds that for subsequent breastfeeding
| | | | | | | | Hospital 2.5% vs 1.4% | Population 1.2% vs 0.9%

Hospital-based studies overlap with Hartge 1989

Population-based studies overlap with Cramer 1983

Study characteristics | Subjects' health conditions | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | | Bias/limitations Comments
Wynder, 1969 [UI# 5764976]
Mean age (range): | Serous cystadenocarcinoma 28 | Case-control | Epithelial ovarian cancer confirmed by histology, functionary or dysontogenetic tumors excluded | Breastfeeding status determined by interview | Breastfeeding status determined by interview | Epithelial ovarian cancer confirmed by histology | ND | No difference between groups for age of first nursing or never nursing | | | | | A: strong, B: moderate, C: weak | A | B | C
Cases: 52 | Pseudo-mucinous cystadenocarcinoma 10 | Hospital-based population | Eight additional cases of diagnosis other than adenocarcinoma and endometrioid cancers | | | | | | 158 Cases | | 300 Controls | | Selection | | | X
Controls: ND | Endometrioid carcinoma 11 | Data collection by interview | Controls matched for age | | | | | | Premenopausal (55) | Postmenopausal (95) | Premenopausal (95) | Postmenopausal (205) | Study design | | | X
Menopause: mix | Solid adenocarcinoma 91 | | | | | | | BF ≥12 months | 10% | 24% | 7% | 21% | Confounder | | | X
Race: | Miscellaneous | | | | | | | | | | | | Blinding | | X
Cases: | Granulose cell tumor 4 | | | | | | | | | | | | Data collection | | | X
91% White | Teratoma 1 | | | | | | | | | | | | Withdraw and dropout | | X
9% Black | Carcinoid 1 | | | | | | | | | | | | Analyses | | | x
Controls: | Others 2 | | | | | | | | | | | | Intervention integrity
94% White | Unspecified 10
6% Black
Enrolled/Evaluate:
Cases: 158
Controls: 300
Location: USA
Sites: Multi
Funding: Government
Yen, 2003 [UI# 12713998]
Median age (range): | Cases: | Case-control | Newly diagnosed primary invasive epithelial ovarian cancer confirmed by histology, Taiwan resident for > 20 years | Breast feeding status determined by interview | Breast feeding status determined by interview | Primary invasive epithelial ovarian cancer confirmed by histology | Conditional multivariate logistic regression model adjusted for number of live birth | Breastfeeding duration (years) | Cases n (%) | Controls n (%) | OR_adj_ (95% CI) | | A: strong, B: moderate, C: weak | A | B | C
Cases: 47 (20–75) | Serous (27%0 | Data collection by in-hospital interview | Controls: matched for age, same hospital admission at same time for nonmalignant, nongynecologic condition, nonhormonal or nondigestive tract diseases, no long term modification of diet | | | | | 0 | 41 (48) | 176 (48) | 1.0 | | Selection | | X
Controls: 44 (20–75) | Mucinous (27%) | | Exclusion: major gynecologic operation including hysterectomy with or without oophorectomy or oophorectomy only, severe illness | | | | | ≤1 | 8 (9) | 42 (11) | 0.82 (0.35–1.9) | | Study design | | X
Menopause: mix | Endometrioid (21%) | | | | | | | >1 | 37 (43) | 151 (41) | 0.55 (0.29–1.01) | | Confounder | | X
Race: ND | Clear cell (15%) | | | | | | | Breastfeeding for more than one year is trend for protection | | | | | Blinding | | | X
Enrolled/Evaluate: | Unspecified adenocarcinoma (2%) | | | | | | | | | | | | Data collection | | X
Cases: 86 | Controls: | | | | | | | | | | | | Withdraw and dropout | | X
Controls: 369 | Trauma (28%) | | | | | | | | | | | | Analyses | | X
Location: Taiwan | Nontraumatic orthopedic conditions (30%) | | | | | | | | | | | | Intervention integrity
Sites: Multi | Surgery (19%)
Funding: Government | Miscellaneous (23%)
| medical, eye, nose, throat, dental

Overlap with Hartge 1989 and Cramer 1983

One population study, Ness 2000, has been reported

Postpartum Depression

Chaudron 2001

Cooper 1993

Hannah 1992

Henderson 2003

Murray 2003

Seimyr 2004

Warner 1996

Study characteristics | Subjects' health conditions | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Chaudron 2001, [UI# 1446151]
Mean age (range): 29 yr (SD 4.4) | | Prospective cohort; the study examined predictors of new-onset postpartum depression during postpartum months 1–4; data from the Wisconsin Maternity Leave and Health Project (WMLHP); subjects participated in a 90-minute home interviews during the second trimester, and at 1 and 4 months after delivery; both the DIS and CES-D were administered at each interview; DIS questions about fatigue and sleep were modified to account for disturbances caused by night-time infant care | Between weeks 12 and 25 of a non-high-risk pregnancy; >18 yr; non-handicapped; living within Milwaukee or Dane counties; living with the baby's father; one of the couple was employed; had a telephone; spoke English well enough to understand interviewer; able to complete questionnaire; not depressed at 1 month postpartum; | | | Postpartum depression defined by:; 1 Diagnosis of major depression on NIMH Diagnostic Interview Schedule (DIS) per DSM-III-R criteria; 2 ≥16 on the Center for Epidemiologic Studies Depression Scale (CES-D); and /or; 3 receiving antidepressants | Age, depression during pregnancy, postpartum thoughts of death and dying, difficulty falling asleep (see full discussion in paper) | 327/465 breastfed; 27/465 became depressed between 1 and 4 months; | A: strong, B: moderate, C: weak | A | B | C
Race: 69% white | | | Excluded subjects who did not complete follow up at 4 months | | | | | Women who breastfed their infants were not significantly different in their development of depression from women who bottlefed their infants. Of those women who were breastfeeding at 1 month postpartum (n=327), women who worried about breastfeeding were significantly more likely to become depressed than those who did not worry (relative risk 3.0, CI 1.041–9.216, P=0.04) | Selection | | x
Enrolled/Evaluate: 465 | | | | | | | | | Study design | | x
Location: US | | | | | | | | | Confounder | | x
Sites: Multi | | | | | | | | | Blinding | | | x
Funding: | | | | | | | | | Data collection | | x
| | | | | | | | | Withdraw and dropout
| | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity
Cooper, 1993 [UI# 8463993]
Mean age (range): | | 2 separate prospective cohort studies (Oxford and Cambridge) | See ref 12 in paper for criteria for Oxford; | Of those who attempted to initiate breastfeeding, those who terminated before 8 wk were compared with those who did not | | At Oxford, Present State Examination (PSE) was used to determine psychiatric symptoms. | Social class, age, and education | At Oxford, 14/25 subjects (56%) with psychiatric symptoms versus 40/175 subjects (23%) without psychiatric symptoms had given up breastfeeding by 8 wk postpartum (P<0.01). In eight, depression preceded cessation of breastfeeding, in two depression was the subsequent event, and in four, the two events arose contemporaneously. Low social class and younger age were also determinants of early cessation of breastfeeding. Antenatal psychiatric status did not predict breastfeeding outcome. | A: strong, B: moderate, C: weak | A | B | C
Enrolled/Evaluate: 243 women at Oxford; 113 at Cambridge | | | For Cambridge: primiparous, 20–40 yr, had a partner, 37–42 wk gestation, infant ≥ 2.5 Kg, and no gross congenital abnormality | | | At Cambridge, prospective subjects were screened at 6 wk postpartum using the Edinburgh Postnatal Depression Scale (EPDS). All high scorers (≥13), 78% of the intermediate scorers (10–12), and a random sample of low scorers (≤ 9) received full psychiatric assessment between 2 and 3 months postpartum. 58 who met Research Diagnostic Criteria (RDC) criteria for major and minor depression, and 55 who were psychiatrically well were interviewed in full. | | At Cambridge, 30/54 subjects (56%) with an episode of depression versus 10/48 subjects (21%) without depression postpartum had given up breastfeeding by 8 wk (P<0.001). Lower educational attainment was also associated with early cessation of breastfeeding. In all cases, the onset of depression preceded the cessation of breastfeeding. | Selection | | x
Location: UK | | | | | | At Cambridge, Standardized Psychiatric Interview (SPI) was used. | | | Study design | | | x
Sites: Multi | | | | | | | | | Confounder | | x
Funding: | | | | | | | | | Blinding | | | x
| | | | | | | | | Data collection | | | x
| | | | | | | | | Withdraw and dropout | | | x
| | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity
Hannah 1992, [UI# 1617360]
Mean age (range): | ND | Prospective cohort, questionnaires (general questionnaire and Edinburgh Postnatal Depression Scale (EPDS)) on 5^th^ day postpartum and repeat EPDS at 6 weeks postpartum | Women who had delivered a live baby | ND | | Postpartum depression defined by EPDS score ≥ 13 at 6 weeks. | Chi-square | At 6 weeks, 8/26 (31%) women with EPDS score ≥ 13 vs 25/200 (12%) women with EPDS < 13 only did bottle feeding (P<0.04). | A: strong, B: moderate, C: weak | A | B | C
Evaluated: 231 | | | | | | | | [Or 18/26 (69%) women with EPDS score ≥ 13 vs 175/200 (88%) women with EPDS < 13 had ever breastfed.] | Selection | | | x
Location: UK | | | | | | | | | Study design | | | x
Sites: Multi | | | | | | | | | Confounder | | | x
Funding: | | | | | | | | | Blinding | | | x
| | | | | | | | | Data collection | | | x
| | | | | | | | | Withdraw and dropout | | | x
| | | | | | | | | Analyses | | | x
| | | | | | | | | Intervention integrity
Henderson 2003, [UI# 12911800]
Mean age (range): | | Prospective cohort, population from a RCT on the effectiveness of maternal debriefing on the incidence of postnatal psychological morbidity; self-reported questionnaires were completed at 2, 6, and 12 months after birth; the questionnaire included a measure of current breastfeeding status; The Edinburgh Postnatal Depression Scale (EPDS) was used to screen for symptoms of depression at each of the follow-up intervals. All subjects who scored > 12 on the scale, subjects being treated for a psychological disorder, subjects taking antidepressants, and a stratified sample of women with low EPDS scores were offered a diagnostic interview. The interview enabled a diagnosis of depression to be made based on DSM IV. | Before 72 hr postpartum, given birth to health infants >35 wk gestation, English speaking, >18 yrs, not under psychological care at the time of recruitment; cases were excluded if no information about breastfeeding status was given at any interval (n=56) | Primary endpoint was duration of breastfeeding | | Diagnosis of depression based on DSM IV (data obtained from diagnostic interview) | Adjusted for demographic, perinatal, and postnatal factors | Breastfeeding was initiated by 1670/1745 women (96%); 57% still breastfeeding at 6 months (30% fully); 22% still breastfeeding to some extent at 12 months. | A: strong, B: moderate, C: weak | A | B | C
Race: | | | | | | | | 314/1745 (18%) developed depression in the 12 months after birth, 63% showing the first symptom by 2 months. | Selection | | x
Enrolled/Evaluate: 1745 enrolled | | | | | | | | After adjustment for confounding factors, early cessation of breastfeeding was found to be associated with postnatal depression (adjusted hazard ratio 1.25, 95% CI 1.03 to 1.52). Onset of postnatal depression occurred before cessation of breastfeeding in most cases. | Study design | | x
Location: Australia | | | | | | | | | Confounder | | x
Sites: Multi | | | | | | | | | Blinding | | | x
Funding: | | | | | | | | | Data collection | | x
| | | | | | | | | Withdraw and dropout | | x
| | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity
Murray, 2003 [UI# 12848402]
Mean age (range): 25 yr in self-exclusion group; 28 yr in take-up group | History of depression was common, as were health problems, and depressed or anxious mood in pregnancy | Cohort study; 403 women from a RCT of a preventive intervention for postpartum depression were identified as being high risk for depression from antenatal screening; 2 groups were formed; one group from the control arm (routine care) of the RCT was willing to receive additional home-based Health Visiting in the last 5 weeks of pregnancy and the first 8 weeks postpartum; the other group refused the intervention | Vulnerable to postpartum depression per screening results | | | Predictive Index for Postpartum Depression | | Comparing the self-exclusion group (n=75) with the take-up group (n=81), the infants in the self-exclusion group were less likely to be breastfed, both immediately after birth (63% vs 83%, P=0.007) and at 10 days (31% vs 54%, P=0.01) | A: strong, B: moderate, C: weak | A | B | C
Menopause: pre/post/mix | | | | | | | | | Selection | | x
Race: 75 in self-exclusion group; 81 in take-up group | | | | | | | | | Study design | | | x
Location: UK | | | | | | | | | Confounder | | | x
Sites: Single/Multi | | | | | | | | | Blinding | | | x
Funding: | | | | | | | | | Data collection | | | x
| | | | | | | | | Withdraw and dropout | | x
| | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity
Seimyr 2004, [UI# 15376402]
Mean age (range): 29 yr (18–43) | | Prospective cohort, Edinburgh Postnatal Depression Scale (EPDS) result at 2 months before childbirth (I), 2 months (II )and 12 months (III) after childbirth | All Swedish speaking pregnant women at six antenatal clinics were invited to participate, with their partners or alone | | | Cut-off point of 9/10 on EPDS scale is used to set the threshold for vulnerability to depression | Did not report actual adjustment, but reported that there was no difference with regards to age, education, parity, and length of marital relationship between low and high-scoring women | 63 women (21%) scored high on EPDS at the end of pregnancy; 54 (17%) at 2 months; 28 (12%) at 12 months. ~50% of the high EPDS (I) scorers also scored high on EPDS (II), and 39% of those who were high EPDS (II) scorers continued to score high on EPDS (III). | A: strong, B: moderate, C: weak | A | B | C
Race: | | | | | | | | Fewer high EPDS (I) scorers breastfed compared to the low scorers (82% vs 94%, P<0.02) | Selection | | x
Enrolled/Evaluate: 352 women | | | | | | | | Fewer high EPDS (II) scorers breastfed compared to the low scorers (85% vs 93%, P<0.08) | Study design | | | x
Location: Sweden | | | | | | | | High EPDS scorers experienced breastfeeding more negatively than the women scoring low on EPDS (I) (40% vs 20%, P<0.03) and on EPDS (II) (51% vs 16%, P<0.0001). | Confounder | | | x
Sites: Multi | | | | | | | | High EPDS (II) scorers breastfed for a shorter time compared to the low-scoring women (4.6 months, SD 2.4 vs 5.3 months, SD 1.9, P<0.04) | Blinding | | | x
Funding: | | | | | | | | | Data collection | | x
| | | | | | | | | Withdraw and dropout | | x
| | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity
Warner, 1996 [UI# 8733800]
Mean age (range): 28 yr (15–46 yr) | Prospective cohort | Recruited subjects over a 20-month period from two postnatal wards prior to discharge, subjects agreed to a home visit 6–8 wk after delivery; Edinburgh Postnatal Depression Scale (EPDS) was completed at the interview | Living outside the district and insufficient English to understand the questionnaire | | | EPDS score > 12 | 13 socio-demographic and obstetric variables were entered individually into a logistic regression analysis with high and low EPDS as the outcome variable using a threshold of 12/13; those variables showing a significant association with high EPDS scores were entered into a stepwise logistic regression analysis | 280/2375 scored >12 on EPDS; | A: strong, B: moderate, C: weak | A | B | C
Race: | | | | | | | | Unplanned pregnancy, not breastfeeding at 6 wk (OR 1.52, 95%CI 1.12–2.06), unemployment in mother or head of household were associated with an EPDS score >12 in a stepwise logistic analysis | Selection | | x
Eligible/Enrolled: 2978/2375 | | | | | | | | | Study design | | | x
Location: UK | | | | | | | | | Confounder | x
Sites: Multi | | | | | | | | | Blinding | | | x
Funding: | | | | | | | | | Data collection | | x
| | | | | | | | | Withdraw and dropout | | x
| | | | | | | | | Analyses | | | x
| | | | | | | | | Intervention integrity

Maternal Weight

Brewer 1989

Janney 1997

Linne 2003

Ohlin 1990

Olson 2003

Sichieri 2003

Walker 2004

Study characteristics | Population | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Brewer 1989 [2916446]
Mean age (range): | Well-educated, middle to upper middle income range | Prospective cohort; to study postpartum changes in body weight in lactating vs. nonlactating women up to 6 mo postpartum; mothers were visited in the hospital within 1 to 2 d of delivery and at home at 3 and 6 mo postpartum, weights were objectively measured; detailed information on infant diet was collected by monthly questionnaires completed by the mothers. Mother's calorie intake measured. Three-day maternal food records were also completed at 3 and 6 months postpartum. Energy intake (kcal) was calculated by computer from food records with the Nutritional Analysis System (Louisiana State University, Baton Rouge, LA). | Good health,≥ 18 yr, mothers of full term infants | | | Exclusive breastfeeding; | ANCOVA; covariables included maternal age, parity, prepregnancy weight, initial postpartum measurement for each variable, and others | “If weight change during the first 3 mo is corrected for an initial fluid loss of 2 kg, weight loss averaged 1.6, 2.1, and 1.5 kg/mo for exclusive breastfeed, exclusive formula feed, and mixed feed, respectively. Exclusive breastfeed resulted in an additional 0.43 kg/mo loss over the second 3 mo with mixed feed averaging a 0.27 kg loss and nonlactating women experiencing essentially no change.” | A: strong, B: moderate, C: weak | A | B | C
Pre-pregnancy BW (range): ND | | | | | | exclusive formula feeding; mixed breast and formula feeding | | No significant differences in total weight loss were observed between the lactating and non-lactating groups. Exclusive breastfeeding resulted in a significant decrease in weight between 3 and 6 months (P < 0.05). | Selection | | x
Pre-pregnancy BMI (range): ND | | | | | | | | | Study design | | x
Race: white | | | | | | | | | Confounder | | x
Enrolled/Evaluate: 70/56 | | | | | | | | | Blinding | | | x
Location: US | | | | | | | | | Data collection | | x
Sites: Single | | | | | | | | | Withdraw and dropout | | | x
Funding: | | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity
| | | | | | | | | Overall: B
Janney, 1997 [9356528]
Mean age (range): 29.3 (20–40) | | Prospective, longitudinal study | Pregnant nulliparous and primiparous women aged 20–40 y in their 3^rd^ trimester were recruited from birthing education classes and obstetric practices. To be eligible for participation, the women must have declared either that they had no intention of breastfeeding or that they intended to breast-feed for >= 6 months. | Fully breast-feeding was defined as providing at least 2/3 of the needed energy intake per kilogram of the infant's weight in breast milk. See article for how this estimation was made. | Partly breast-feeding or bottle-fed | Postpartum weight retention over time | Longitudinal regression analysis: proc mixed and glm procedures | Most women (66.7%) fully breastfed for 6 mo. | A: strong, B: moderate, C: weak | A | B | C
Pre-pregnancy BW (range): 59.7 (43.1–93.0) kg | | (0.5, 2, 4, 6, 12, and 18 mo post-partum) | Exclusion criteria were a history of endocrine, renal, liver, or chronic respiratory illness; complications of pregnancy, including HTN and GDM; fetal complications or complications at delivery; delivery of an infant small for gestational age; and delivery of twins. | | | | | Duration of lactation practice was a significant predictor of postpartum weight retention over time -(P<0.001) - not only in the longitudinal regression model containing only lactation practice and months since parturition but also in the multiple-variable longitudinal regression model. | Selection | | x
Pre-pregnancy BMI (range): 22.2 (16.9–33.7) kg/m^2^ | | | | | | | | Regardless of lactation practice, women consistently lost weight from 0.5 to 18 mo after parturition. The weight-retention curve appeared to be curvilinear, with slower rates of weight loss occurring after 12 mo postpartum. | Study design | x
Race: 96% White | | | | | | | | Overall, less weight was retained by lactating women than by nonlactating women. Even women who breast-fed for < 4 mo retained less weight than women who bottle-fed their infants. Additionally, women who switched to partly breast-feeding had weight retention rates intermediate between those of women fully breast-feeding and those bottle-feeding. Once lactation was discontinued, slower rates of weight loss were observed. Breast-feeding women achieved their prepregnancy weights about 6 month earlier than women who only bottle-fed their infants (see Figure 5 in original paper). | Confounder | | | x
Enrolled/Evaluate: 110/71 | | | | | | | | The following data were [underlined: estimated from Figure 5 in the original paper:]; 1) Time returned to prepregnancy weights:; Bottle-feeding only: ~18 months postpartum; Partly breast-feeding at 2 mo, and bottle-feeding or infant weaned at 4, 6, 12, and 18 months: ~12 months postpartum; Fully breast-feeding for 6 month and bottle-feeding or infant weaned at 12 and 18 month: ~11 months postpartum; Fully breastfeeding for 6 month, partly breast-feeding for 12 month, and bottle-feeding or infant weaned at 18 month: ~ 10 months postpartum; 2) Weight retention at 6 months postpartum:; Fully breastfeeding for 6 months (n=57): ~ +3 kg; Partly breastfeeding at 2 month and bottle-feeding at 4 and 6 months (n=10): ~ +3.5 kg; Fully bottle-feeding for 6 months (n=12): ~ +5 kg | Blinding
Location: US | | | | | | | | | Data collection | x
Sites: Single | | | | | | | | | Withdraw and dropout | | | x
Funding: ND | | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity
| | | | | | | | | Overall: B
Linne, 2003 [14634683]
Mean age (range): 45 yr (at 15 yr follow up) | Cross section of the metropolitan population from both inner city of Stockholm and its suburbs; a range of socioeconomic groups | Prospective cohort; longitudinal study of women's weight gain during pregnancy, at 1 yr postpartum and at 15 yr follow up; feeding data were collected retrospectively by questionnaires at 2.5, 6, 12 mo and at 15 yr; for women who still lived in the Stockholm area, weights were measured in the University hospital (n=363); for women who lived far away, weights were self-reported (n=200) | 2 outliers were excluded: BMI of 47; first child at 49 yr | Measured by lactation score: every month of full lactation was given 4 points, every month of mixed lactation was given 2 points; total sum (0–48) indicated the individual lactation amount | | Overweight (BMI > 25), normal weight (BMI 20–25); | ANOVA was used to analyze weight change at four time points; women who were overweight at prepregnancy and at follow up and those who lost weight and regained a BMI in the normal range at 15 yr were excluded from the analysis | Those women who became overweight had lower lactation scores than women who remained normal weight at 15 years follow up (21.7 ± 11.0 vs. 24.0 ± 9.4, t=2.25, df = 488, P < 0.05). | A: strong, B: moderate, C: weak | A | B | C
Pre-pregnancy BW (range): 59.8 kg | | | | | | | | Responders were slightly older, had higher educational attainment, and higher income than non-responders. Nonresponse was more common in non-Nordic citizens. | Selection | | | x
Pre-pregnancy BMI (range): 21.5 kg/m^2^ | | | | | | | | | Study design | | x
Race: | | | | | | | | | Confounder | | | x
Enrolled/Evaluate: 1423/563 (at 15 yr) | | | | | | | | | Blinding | | | x
Location: Stockholm | | | | | | | | | Data collection | | x
Sites: Multi | | | | | | | | | Withdraw and dropout | | | x
Funding: | | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity
| | | | | | | | | Overall: C
Ohlin, 1990 [2341224]; Ohlin, 1996 [8732961]
Mean age (range): 29.5 (17–49) | | Women were studied retrospectively during pregnancy at maternity clinics, and monitored prospectively up to 1 year after delivery. | All mothers who, during one year, came to the maternity clinic for the last routine control, i.e. 6–15 weeks after the delivery, were invited by their midwives to take part in the study. Women who were going to move within a short time and those with obvious language and communication problems were not invited. | Lactation score: a scoring system was constructed in order to express duration and intensity of breast feeding. Every month with full lactation was given 4 points, and every month with mixed feeding was given 2 points. The total sum (0–48) indicated the individual lactation amount. | | The body weight 1 year after delivery (Δ weight) | Ranged influence of different factors on the Δ weight was analyzed by a multiple stepwise regression analysis | 30% lost weight, 56% gain 0–5 kg, 13% gained 5–10 kg and 1.5% gained >=10 kg 1 year after delivery. Frequency of overweight women (BMI>=23.9) increased from 13% before pregnancy to 21% 1 year post-partum (p<0.001) | A: strong, B: moderate, C: weak | A | B | C
Pre-pregnancy BW (range): 59.6 (39–129) kg | | | Exclusion: twin births, use of insulin during pregnancy, GI problems with severe energy losses (heavy vomiting or diarrhea) and pre-pregnant body weights were not available. | | | | | Ranged influence of different factors on the Δ weight: | Selection | | x
Pre-pregnancy BMI (range): 21.5 (15.4–43.0) kg/m^2^ | | | | | | | | The coefficients between the Δ weight and lactation score, age, pre-pregnancy weight and parity were very low (multiple r=0.38, p<0.001) and significant correlations do not necessarily indicate causality. | Study design | | x
Race: ND | | | | | | | | Weight gain during pregnancy had the strongest influence, and explained 12.7% of the variation of the Δ weight (p<0.001). | Confounder | | x
Enrolled/Evaluate: 2295 (at 2 mo) /1423 (at 1 yr) | | | | | | | | Lactation and age increased the total proportion of explained variance by about 1% each. | Blinding
Location: Sweden | | | | | | | | Simple correlation coefficient between the Δ weight and lactation score was -0.09 (p<0.01) | Data collection | | | x
Sites: Multi | | | | | | | | | Withdraw and dropout | | | x
Funding: Government | | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity
Olson, 2003 [12532163]
Mean age (range): | Rural, socio-economically diverse | Prospective cohort; to study the relative importance of gestational weight gain, postpartum exercise, food intake and breastfeeding to weight change from early pregnancy to 1 yr postpartum; weight was measured at antenatal and 1 yr postpartum visit (varied between 9 and 19 mo); 32/540 self-reported weight at 1 yr; breastfeeding data collected at 6 wk obstetric visit; 6 mo and 1 yr questionnaires. | ≥ 18 yr;healthy, gavebirth to fulltermsingletons | Breastfeeding after 6 mo was considered to be non-exclusive; a breastfeeding score similar to Ohlin and Rossner's was constructed: 1 point for each wk of exclusive breastfeeding and 0.5 point for each wk of mixed feeding | | Weight change from early pregnancy to 1 yr postpartum; major weight gain was defined as ≥ 4.55 kg at 1 yr postpartum | Univariate and multiple linear regression; weights taken between 9 and 19 mo were eligible for inclusion, actual number of mo postpartum at the measurement of the “1 yr postpartum body weight” was entered into all of the regression models; variables in the initial model included age, education, smoking status, income, marital status, prepregnancy BMI category and parity; 3 subjects with poor fit were removed from the analysis; a model reduction method was applied at the 10% significance level to produce an inclusive, reduced model | Only the 597 women who delivered full term infants were included in the sample; 540 had 1 yr weight recorded; | A: strong, B: moderate, C: weak | A | B | C
Pre-pregnancy BW (range): kg | | Food frequency questionnaires were completed at 1^st^ or 2^nd^ trimester of pregnancy, 6 months postpartum, and 1 yr postpartum. | | | | | Using food frequency data, the difference in the daily energy intake from 6 months to 1 yr postpartum was calculated for each woman. The Wilcoxon rank sum test was used to assess change in total daily energy intake across the five categories of self-reported behavior change in amount of food intake. | Women who were breastfeeding at 1 yr retained less weight compared with the women who weren't (P = 0.04). Breastfeeding at all other time points and the breastfeeding score were not significantly related to postpartum weight retention. | Selection | | x
Pre-pregnancy BMI (range): kg/m^2^ | | | | | | | | | Study design | | x
Race: white (96%) | | | | | | | | | Confounder | | x
Enrolled/Sample/Evaluate: 622/597/540 | | | | | | | | | Blinding | | | x
Location: US | | | | | | | | | Data collection | | x
Sites: Single | | | | | | | | | Withdraw and dropout | | x
Funding: | | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity
| | | | | | | | | Overall: B

Study characteristics | Subjects' health conditions | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Sichieri, 2003 [12821967]
Mean age (range): 24–40 yr | None documented | The cohort of the Nurse's Health Study II, with analysis restricted to women who were aged 24 to 40 y at baseline (1989), who had a history of no more than one past full-term pregnancy at baseline, gave birth to one child between 1990 and 1991, but had no other pregnancies during the follow-up. SUBJECTS: 1,538 of the 33,082 nulliparous women and 2,810 of the 20,261 primiparous, in 1989. | Excluded from analysis: those who reported use of insulin, hypoglycemic drugs, or thyroid disease at baseline or followup were excluded from analysis | For each birth, women were asked if they had breastfed for at least a month and if so they were asked to report the month in which they introduced the formula. | | To assess whether women who breastfed were different in terms of their weight changes than women who did not, weight change from prepregnancy (in 1989) to postpregnancy (in 1993) was estimated according to exclusive breastfeeding duration using linear regression models. | The longitudinal models were based on mixed effects analysis. These models permitted the authors to test differences in prepregnancy weight at baseline (group effect), weight gain with pregnancy (time-dependent effect of period I), and weight change after pregnancy (time-dependent effect of period II) by breastfeeding status. If breastfeeding groups differed at baseline but had the same change in weight during follow-up, a group effect but not a time-dependent effect would be seen. | After adjusting for age, physical activity, and BMI, lactation was associated with a weight gain from 1989 to 1993 of approximately 1 kg (statistically significant only for women nulliparous in 1989 with a BMI <25 kg/m^2^ (P=0.02) and for those women primiparous in 1989, with a BMI ≥25 kg/m^2^ (P=0.04)) comparing women who breastfed with women who did not. Duration of lactation was unrelated to the magnitude of weight change (P>0.40 for all comparisons). | A: strong, B: moderate, C: weak | A | B | C
Pre-pregnancy BW (range): | | The NHS II Cohort has been followed up every 2 yr to ascertain incident diseases and exposures including parity and body weight. | | Introduction of daily formula/milk was assumed to represent the end of exclusive breastfeeding period. Duration of exclusive breastfeeding was categorized into 0, 1–3, 4–7, 8–11, and 12 months or more. | | | | Maternal weight change associated with breastfeeding is minimal among normal weight women, and for overweight women the weight gained in pregnancy Is not reduced by breastfeeding. | Selection | x
Stratified by BMI at baseline | | Individual breastfeeding data were collected retrospectively in the 1997 follow-up. Women were asked to recall their lifetime breastfeeding history. | | [underlined: Exclusive breastfeeding:] Women were asked to recall their lifetime breastfeeding history. They were asked to answer 2 questions: 1) “Did you breastfeed at least one month?” 2) “Which month did you introduce formula?” If the answer to the 1^st^ questions was “no, not at all”, the duration was considered to be zero. Data from these 2 questions were combined with parity data from 1991 and 1993 questionnaires. | | | | | Study design | | x
Pre-pregnancy BMI (range): | | | | | | | | | Confounder | x
% BMI ≤ [underlined: 25kg/m^2^] in 1989: 81.5% | | | | | | | | | Blinding | | | x
BW mean, ALL: 58.0 kgs | | | | | | | | | Data collection | | x
% BMI > 25kg/m^2^ in 1989: 18.5% | | | | | | | | | Withdraw and dropout | | x
BW mean, ALL: 80.4 kgs | | | | | | | | | Analyses | x
Race: ND | | | | | | | | | Intervention integrity
Enrolled/Evaluate: | | | | | | | | | Overall: B
1,538/1,538 nulliparous at baseline; 2,810/2,810 primiparous at baseline
Location: USA
Sites: Single/Multi: mailed questionnaire
Funding: Supported by FundaCBo CAPESCoordenaq20 de Aperfeicoamento de Pessoal de Nivel Superior and Boston Obesity Nutrition Research Center (DK 46200)
Walker, 2004 [15778139]
Mean age (range): ND (>18 yr) | healthy | Prospective, longitudinal cohort | Healthy women, singleton pregnancies with prenatal care funded through Medicaid; had a parity not exceeding III; were conversant in English; and were age 18 or higher. | Full (exclusive) or partial breastfeeding, or bottle feeding, measured at post-delivery, 6 wk, and 3, 6, and 12 months postpartum | | Postpartum BMI | General linear mixed models, also known as hierarchical linear models, were used. | Infant feeding method was not associated with postpartum BMI (p=0.140) when ethnicity, time, pre-pregnant BMI and a bunch of other variables (such as parity, gestational weight gain, Cesarean section, etc) were included in the model. | A: strong, B: moderate, C: weak | A | B | C
Pre-pregnancy BW (range): ND | | (post-delivery, and 6 wk, and 3, 6, and 12 months postpartum). | | | | | Forward additive method (or forward selection) was used to select variables for inclusion in the model. | | Selection | | x
Pre-pregnancy BMI (range): ND | | Energy intakes were measured at above times by average of one 24-hour recall and two food records at each observation. Fat intakes measured by Food Habits Questionnaire (Kristal, 1990). | | | | | | | Study design | | x
Race: 26% African American, 44% Hispanic, 30% White | | | | | | | | | Confounder | | x
Enrolled/Evaluate: ND/382 | | | | | | | | | Blinding
Location: US | | | | | | | | | Data collection | | x
Sites: Single | | | | | | | | | Withdraw and dropout | | | x
Funding: Government | | | | | | | | | Analyses | | x
| | | | | | | | | Intervention integrity
| | | | | | | | | Overall: B

Type 2 DM

Stuebe 2005

Study characteristics | Subjects' health conditions | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions | Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Stuebe, 2005 [16304074]
Mean age (range): 52 at follow-up | ND | Prospective, longitudinal study | The Nurses' Health Studies consist of 2 large cohorts enrolled in prospective, longitudinal studies of women's health | Women in the Nurses' Health Studies (NHS) reported parity at baseline in 1976. Lactation history was assessed once, in 1986, when women were asked to report total lifetime duration lactation. | | Ascertainment of Type 2 Diabetes Mellitus | Lifetime lactation history among parous women was stratified into 6 groups: None (referent), > 0 to 3 mo, > 3 to 6 mo, > 6 to 11 mo,> 11 to 23 mo, and > 23 mo. In the NHS, lactation information was used from the 1986 questionnaire. In the NHS II analysis, lactation history was derived from self-reported pregnancies assessed every 2 years and lactation reports in 1997 and 2003. Lifetime duration was updated every 2 years. | In the NHS cohort, 83,585 parous women reported lifetime duration of lactation; of these, 64% had ever breastfed. In the NHS II cohort, 73,418 parous women reported duration of lactation, and 85% had ever breastfed. | A: strong, B: moderate, C: weak | A | B | C
Menopause: mix | | | The Nurses' Health Study (NHS) was initiated in 1976 and enrolled 121,700 women from 11 states. Participants were between 30 and 55 years of age at baseline, and each woman completed a detailed baseline questionnaire regarding diseases and health related topics. | In NHS II, women reported the number of pregnancies lasting more than 5 months at baseline and on each biennial questionnaire. Lactation history was assessed 3 times. In 1993, 1997, and 2003. Information on parity was used to derive retrospectively each participant's total cumulative lactation at each 2-year interval. | | A case of diabetes was confirmed if a woman reported 1 of the following: (1) 1 or more classic symptoms plus either a fasting glucose of ≥140 mg/dL or random plasma glucose ≥ 200 mg/dL; (2) at least 2 instances of elevated plasma glucose concentration (fasting glucose ≥140 mg/dL, random plasma glucose ≥200 mg/dL, or oral glucose tolerance test ≥200 mg/dL after 2 hours) on different occasions in the absence of symptoms; or (3) treatment with insulin or an oral hypoglycemic agent. | Linear trend was assessed using midpoints of lactation categories. | In the NHS, women who had ever breastfed had a covariate-adjusted HR for type 2 diabetes of 0.97 (95%CI 0.91 – 1.02) compared with women who never breastfed. There was a modest but statistically significant inverse association between duration of lactation and the risk of type 2 diabetes. In the multivariate-adjusted model including current BMI, each additional year of lactation was associated with an HR of 0.96 (95%CI 0.92 – 0.99) for type 2 diabetes. | Selection | x
Race: ND | | | The second cohort, the Nurses' Health Study II (NHS II), began in 1989, enrolling 116,671 women from 14 states. Participants were between 25 and 42 years of age and completed a similar baseline questionnaire as well as biennial follow-up questionnaires. | Total duration of lactation was calculated based on the number of months after birth that the participant reported stopping breastfeeding altogether. Using the 1997 and 2003 NHS II data, duration of exclusive lactation could be calculated based on the reported timing of introduction of formula or solid food. | | The criteria for diagnosis of diabetes changed in 1997, when a fasting glucose level of ≥126 mg/dL was made the diagnostic threshold. | All models were age-adjusted. Potential confounders, including parity, body mass index at age 18 years, diet, physical activity, family history of diabetes, and smoking status, were included in the multivariate model. | Among women who had ever breastfed in the NHS II, the covariate-adjusted HR for type 2 diabetes was 0.90 (95%CI 0.77 – 1.04). Each year of lactation was associated with a covariate-adjusted HR of 0.84 (95%CI 0.78 – 0.89). When BMI was added to this model, the HR was 0.88 (95%CI 0.82 – 0.94) for each additional year of lactation. | Study design | x
Enrolled/Evaluate: see results | | | | | | Ascertainment of Gestational Diabetes | | Women with a history of GDM had an increased risk of type 2 diabetes in the NHS II cohort, with 624 cases per 100,000 person years compared with 118 cases per 100,000 person-years among those without such a history. Lactation had no effect on diabetes risk in the GDM group, with a covariate-adjusted HR of 0.96 (95% CI 0.84 – 1.09) per additional year of lactation. | Confounder | x
Location: US | | | | | | Women in the NHS II were asked to report the diagnosis of gestational diabetes on each biennial questionnaire. To validate the study's diagnostic criteria, 20,422 participants completed a detailed questionnaire, and 92% corroborated their diagnosis. A review of medical records for 120 of these women confirmed definite or probable gestational diabetes in 94%. To assess screening for gestational diabetes, a random sample of 100 study participants was surveyed, of whom 83% reported undergoing a 50-g, 1-hour glucose challenge test. Gestational diabetes history was not assessed in the NHS cohort. | | The effects of exclusive versus total breastfeeding could be compared in the NHS II cohort data. In models controlling for age and parity, each year of lifetime exclusive breastfeeding was associated with an HR for type 2 diabetes of 0.63 (95%CI 0.54 – 0.73), while each year of total breastfeeding was associated with an HR of 0.76 (95%CI 0.71 – 0.81). | Blinding | | x
Sites: Multi | | | | | | | | | Data collection | x
Funding: Government | | | | | | | | | Withdraw and dropout | x
| | | | | | | | | Analyses | x
| | | | | | | | | Intervention integrity
| | | | | | | | | Overall: A