# Appendix B. Sample Data Abstraction Forms

Evidence table for Systematic Reviews

Author, Year[UI] Topic
Systematic reviews/Meta-analyses/Both
Databases searched (Dates of literature search)
Countries where primary studies conducted (Developed countries only or mixed)
Study design [No. of studies]
No. of subjects
Study population and sampling
Intervention/Exposure
Comparator
Outcomes
Methods used for meta-analyses
Heterogeneity assessments
Results
Authors' conclusions
Quality of the systematic review
Comments

| Author, yr: Topic of the systematic review*/MA:
| | Reporting yes/no
| Reporting of Background
1 | Description of study outcomes
2 | Types of exposure or intervention used
3 | Types of study designs used
4 | Study population
| Reporting of Search strategy
5 | Search strategy, including time period and key words
6 | Effort to include all available studies (contact with authors)
7 | Databases and registries searched
8 | Method of addressing published articles other than English
9 | Method of handling abstracts and unpublished studies
| Reporting of Methods
10 | Rationale for selection and/or coding of data
11 | Assessment of confounding
12 | Assessment of quality
13 | Assessment of heterogeneity
14 | Description of statistical methods sufficient to replicate
15 | Provision of appropriate tables and graphs
| Reporting of Results
16 | Graphic summarizing of individual study estimates and overall
17 | Tables giving descriptive information of each study included
18 | Results of sensitivity testing (subgroup analysis)
19 | Indication of statistical uncertainty of findings
20 | Quantitative assessment of bias (eg. publication bias)
| Overall quality

* When grading a systematic review, please skip item #14, 18–20

Please fill the white areas only

| Evaluation of quality of a systematic review or meta-analysis | Yes /No /Partially
1 | Is search strategy appropriate/relevant to the key question(s)?
2 | Did authors give justifications for inclusion/exclusion criteria pertaining to the studies of interest?
3 | Were Population, Intervention/Exposure, Comparator/Control, Outcomes, and Study Designs well-defined?
4 | Did authors attempt to minimize errors in data extraction (such as collecting the relevant data, double data extraction, verification of data extraction...etc.)?
5 | Was individual study quality (such as sample size, study design, blinding, various biases and confounders, study subject attrition rate...etc.) assessed?
6 | Did authors consider appropriate confounders and justification for adjusting or not adjusting for those confounders?
7 | Was the justification for combining or not-combining data for meta-analysis, or the use of a particular analytic method or model appropriate?
8 | Was heterogeneity explored (this is in addition to any statistical test of heterogeneity, did the authors look at the actual differences in PICOS, for example?)?
8 | Were results reported accurately (eg, no discrepancies between text and tables)?
9 | Were conclusions justified by the reported/collected data and analysis?

Study characteristics | Subjects' health conditions | Study design and follow-up duration | Eligibility criteria | Breastfeeding Exposures or Interventions | Control Exposures or Interventions
Author, Year, UI #
Mean age (range):
Pre-pregnancy BW (range):
Pre-pregnancy BMI (range):
Race:
Enrolled/Evaluate:
Location:
Sites:
Funding:

Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/confounders/limitations Comments
| | | A: strong, B: moderate, C: weak | A | B | C
| | | Selection | | x
| | | Study design | | x
| | | Confounder | | x
| | | Blinding
| | | Data collection | | x
| | | Withdraw and dropout | | | x
| | | Analyses | | x
| | | Intervention integrity
| | | Overall:

Domain/question | Place an “X” in one
Selection Bias
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias (RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confouncders”)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell