# Appendix A. MEDLINE^®^ Search Strategy

## MEDLINE 1966-April 2006

# | Search History | Results
1 | exp infant nutrition/ | 28620
2 | exp Milk, Human/ | 10900
3 | human milk.mp. | 5231
4 | (human adj2 milk).tw. | 6040
5 | breast milk.mp. | 4994
6 | breastmilk.mp. | 315
7 | breast feeding.mp. | 18905
8 | breastfeed$.mp. | 5099
9 | breast fed.mp. | 3434
10 | breastfed.mp. | 1339
11 | (breast adj2 fed).tw. | 3705
12 | exp lactation/ | 24059
13 | (lactating or lactation).mp. | 33361
14 | or/1–13 | 68554
15 | exp HIV Infections/ | 150356
16 | HIV.mp. | 151368
17 | *fatty acids/ | 21008
18 | *amino acids/ | 32481
19 | or/15–18 | 243664
20 | 14 not 19 | 66018
21 | limit 20 to animals | 32196
22 | 20 not 21 | 33822
23 | limit 22 to english language | 27054
24 | follow-up studies/ | 308818
25 | (follow-up or followup).tw. | 340039
26 | exp Case-Control Studies/ | 297283
27 | (case adj20 control).tw. | 44954
28 | exp Longitudinal Studies/ | 508275
29 | longitudinal.tw. | 62652
30 | exp Cohort Studies/ | 548011
31 | cohort.tw. | 73505
32 | (random$ or rct).tw. | 324163
33 | exp Randomized Controlled Trials/ | 39966
34 | exp random allocation/ | 54141
35 | exp Double-Blind Method/ | 84061
36 | exp Single-Blind Method/ | 9446
37 | randomized controlled trial.pt. | 208988
38 | clinical trial.pt. | 420410
39 | controlled clinical trials/ | 3005
40 | (clin$ adj trial$).tw. | 90860
41 | ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw. | 80586
42 | exp PLACEBOS/ | 24212
43 | placebo$.tw. | 91878
44 | exp Research Design/ | 197961
45 | exp Evaluation Studies/ | 539139
46 | exp Prospective Studies/ | 195111
47 | exp Comparative Study/ | 1233790
48 | or/24–47 | 2803651
49 | 23 and 48 | 8238
50 | limit 49 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or overall or patient education handout or periodical index) | 360
51 | 49 not 50 | 7878