# Appendixes

Appendix A. MEDLINE^®^ Search Strategy

Appendix B. Sample Data Abstraction Forms

Appendix C. Evidence Tables

Appendix D. List of Excluded Studies

Appendix E. Peer Reviewers