# Executive Summary

## Introduction

Cardiac resynchronization therapy (CRT) refers to atrial-synchronized biventricular pacing (i.e., pacing the right atrium, right ventricle, and left ventricle). CRT improves the electrical dyssynchrony found in many patients with heart failure (HF) and thereby can improve mechanical dyssynchrony leading to increased left ventricular filling time, reduced mitral regurgitation, and reduced septal dyskinesis.^1,^ ^2^ Implantable cardioverter defibrillators (ICD) have at least one lead which resides in the right ventricle dedicated to pacing and/or defibrillating lethal cardiac arrhythmias. More advanced ICD (dual-chamber devices) have leads in the right atrium and right ventricle to help discriminate arrhythmic events and have the potential to be programmed to provide dual chamber pacing (e.g., DDD pacing mode).

Although earlier systematic reviews of CRT and ICD did report benefits from both therapies when evaluated individually in patients with HF, questions remained. For one, as these earlier systematic reviews focused on randomized efficacy trials, the generalizability of their results to clinical practice were uncertain (particularly with respect to potential adverse effects). Second, neither of the earlier reviews (which focused on individual devices) was able to clarify the incremental benefits conferred by combined CRT-ICD devices over CRT alone or ICD alone devices, nor were these earlier reviews able to define which patient groups would benefit most from which devices. Finally, a number of large trials have been published since the earlier systematic reviews were performed and their impact on the pooled evidence base required assessment.

### Study Questions

1 In adult patients with symptomatic or asymptomatic LV systolic dysfunction, what is the efficacy and effectiveness of CRT alone, ICD alone, or combined CRT-ICD devices compared to usual medical therapy?
2 In adult patients with symptomatic or asymptomatic LV systolic dysfunction, what is the efficacy and effectiveness of single-chamber ICD compared to that of dual-chamber ICD?
3 In adult patients with symptomatic or asymptomatic LV systolic dysfunction, how safe is CRT alone, ICD alone, or combined CRT-ICD devices?
4 Which patients would benefit from ICD alone, CRT alone, or combined CRT-ICD devices?

## Methods

### Literature Search

We systematically searched various electronic databases (including trial registries and the website of the U.S. Food and Drug Administration), the reference lists of relevant reviews and identified studies, and contacted authors of included studies as well as device manufacturers: Medtronic Inc. (Minneapolis, MN), Boston Scientific (formerly Guidant Corp., Indianapolis, IN), and St. Jude Medical Inc. (St. Paul, MN). The search was not limited by language or publication status and is considered current to November 14, 2006. A full list of search strategies and search terms (adapted for each database) and search results are included in Appendix A * of the main report.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/defibtp.htm

### Selection and Inclusion

To address efficacy, we analyzed randomized controlled trials (RCTs) that compared active CRT, active ICD, or combined CRT-ICD devices with either placebo pacing, univentricular (right-sided) pacing, or drug therapy alone. To address effectiveness, we evaluated studies with contemporaneous comparison arms (e.g., cohort studies, RCTs, or controlled non-randomized trials). To address safety, we included evidence from both RCTs and observational studies (including those without contemporaneous control arms, such as case series and registry data).

For assessing efficacy or effectiveness, we selected those studies that enrolled greater than 25 participants with LV systolic dysfunction (LVEF ≤ 35 percent), whether they had HF symptoms or not, followed participants for at least 2 weeks, and reported at least one of the following outcomes of interest: mortality (all-cause, cardiac, HF, sudden cardiac death), quality of life, functional class (NYHA), 6-minute walk test, hospitalization (all-cause or HF), or LVEF. For assessing safety, we selected studies that enrolled greater than 25 participants with LV systolic dysfunction (LVEF ≤ 35 percent), whether they had HF symptoms or not, followed participants for at least 2 weeks, and reported at least one of the following outcomes of interest: implant success rates, peri-, or post-implantation risks with either device. On the advice of our expert panel, we also examined safety outcomes in all patients receiving ICDs (i.e., not just those with definite LV systolic dysfunction).

### Data Extraction and Analysis

Study selection, quality assessment, and data extraction were completed by several investigators in duplicate, independently, and blinded; random-effects models were used for analyses in Review Manager 4.2.5 (The Cochrane Collaboration, Copenhagen, DK). Only period one data were extracted from crossover studies. For dichotomous results (e.g., HF hospitalizations), we calculated relative risks (RR) and for continuous variables (e.g., 6-minute walk test) we calculated weighted mean difference (WMD) for the pooled estimates. All results were reported with 95 percent confidence intervals (CI). Statistical heterogeneity was quantified using the I-squared (I^2^) statistic.^3^ Relevant direct subgroup comparisons were summarized, including effects of CRT in patients with more severe HF symptoms (New York Heart Association [NYHA] Class III or IV). Meta-regression was used to examine the relation between a variety of covariates classified at the study level (e.g., percent of enrolled subjects with atrial fibrillation) and the efficacy of CRT, ICD, and combined CRT- ICD devices.

## Results

### Literature Search (Figures 2 and 3 in Evidence Report)

From 11,340 citations, we identified 14 RCTs^4^–^17^ (4,420 patients) for the CRT efficacy review, 106 studies for the CRT effectiveness review^17^–^122^ (9,209 patients from 2 controlled but non-randomized trials and 104 observational studies—13 retrospective and 91 prospective), and 89 studies for the CRT safety review,^4^–^17^ 2 clinical trials, and 73 observational studies^17,^ ^20,^ ^22,^ ^22,^ ^26,^ ^27,^ ^29^–^33,^ ^35,^ ^36,^ ^39,^ ^41,^ ^42,^ ^44^–^46,^ ^49,^ ^50,^ ^52,^ ^53,^ ^55^–^58,^ ^60,^ ^63^–^70,^ ^73,^ ^76,^ ^78,^ ^80,^ ^82,^ ^83,^ ^85^–^87,^ ^89,^ ^91^–^94,^ ^97,^ ^98,^ ^100,^ ^102^–^106,^ ^108,^ ^109,^ ^111^–^113,^ ^117,^ ^118,^ ^123^–^132^ (9,677 patients, 14 randomized trials, 2 controlled trials, and 73 observational studies—10 retrospective and 63 prospective). We identified 12 RCTs^11,^ ^133^–^143^ (8,516 patients) for the ICD efficacy review, 48 studies for the ICD effectiveness review^144^–^191^ (15,097 patients from 3 RCTs and 45 observational studies—25 retrospective and 20 prospective), and 49 studies for the ICD safety review,^11,^ ^133^–^136,^ ^138^–^145,^ ^147,^ ^148,^ ^152,^ ^155^–^159,^ ^161,^ ^162,^ ^164,^ ^165,^ ^169,^ ^171,^ ^176,^ ^178^–^181,^ ^184,^ ^186^–^189,^ ^191^–^202^ (12,592 patients from 11 RCTs, 6 RCTs without efficacy outcomes, and 32 observational studies—17 retrospective and 15 prospective). An additional 12 studies (68,848 patients) were included in our secondary analysis of peri-implant safety with ICD for all patients (i.e., not restricted to patients with LV systolic dysfunction).^203^–^214^

Figure 1. Treatment of systolic heart failure (Adapted from Canadian Cardiovascular Society Guidelines^244^)

Figure 2. Flow diagram of study retrieval and selection for CRT alone or combined CRT-ICD devices

Figure 3. Flow diagram of study retrieval and selection for ICD alone

### Description of Included Patients (Tables 5, 7, 9, and 11 in Evidence Report)

CRT. All patients in the CRT studies had LV systolic dysfunction (mean LVEF ranged from 21 to 30 percent), prolonged QRS duration (mean QRS ranged between 155 msec and 209 msec, with 64 percent of trial participants exhibiting a left bundle branch block), and HF symptoms (79 percent were NYHA class III functional status at baseline, 12 percent were NYHA class IV, and 9 percent were NYHA class II). The mean age of patients was 65.4 ± 10.8 years, 72 percent were male, and patients with atrial fibrillation constituted 5 percent of all trial participants. Of the patients in the intervention arms, 1,310 (47%) received CRT alone and 1,474 (53%) received a combined CRT-ICD device. Eleven of the trials (n = 2,166 patients) randomized patients after successful CRT implantation; 3 trials (n = 2,439 patients) randomized patients before attempted CRT implantation. Median follow-up in these trials was 6 months, with the longest follow-up duration being 29 months.

Table 5 Baseline characteristics of patients in trials included in the efficacy review: CRT alone or combined CRT-ICD devices

Author Year | Study group | Males, n (%) | Mean age, yr. mean ± SD | Ischemic % | NYHA class | | | Other measures | | | Baseline measures taken pre/post-implantation
Trial name | | | | | II, % | III, % | IV, % | Atrial fibrillation, n (%) | QRS interval, msec mean ± SD | LVEF, % mean ± SD
CRT alone
Abraham^4^ 2002 | CRT | 155 (68) | 64 ± 11 | 50 | 0 | 90 | 10 | 0 | 167 ± 21 | 22 ± 6 | Pre
MIRACLE | Control | 153 (68) | 65 ± 11 | 58 | 0 | 91 | 9 | 0 | 165 ± 20 | 22 ± 6 | Pre
Cazeau^5^ 2001 | CRT first | 19 (66) | 64 ± 11 | NR | 0 | 100 | 0 | NR | 172 ± 22 | NR | Post
MUSTIC-SR | Control first | 24 (83) | 64 ± 8 | NR | 0 | 100 | 0 | NR | 175 ± 19 | NR | Post
| All | 43 (74) | 64 ± 9 | 37 | 0 | 100 | 0 | NR | 174 ± 20 | 23 ± 7 | Post
Leclercq^7^ 2002a | CRT first | 21 (84) | 65 ± 9 | NR | 0 | 100 | 0 | 25 (100) | 209 ± 21 | 23 ± 7 | Post
MUSTIC-AF | Control first | 14 (78) | 66 ± 9 | NR | 0 | 100 | 0 | 18 (100) | 208 ± 12 | 30 ± 12 | Post
| All | 35 (81) | 65 ± 8 | 43 | 0 | 100 | 0 | 43 (100) | 209 ± 18 | 26 ± 10 | Post
Auricchio^8^ 2002a | CRT first | 11 (46) | 59 ± 7 | 42 | 0 | 88 | 13 | NR | 174 ± 30 | 21 ± 6 | Pre
PATH-CHF | Control first | 10 (59) | 60 ± 5 | 6 | 0 | 82 | 18 | NR | 178 ± 34 | 20 ± 7 | Pre
| All | 21 (50) | 60 ± 7 | 29 | 0 | 86 | 14 | NR | 175 ± 32 | 21 ± 7 | Pre
Leclercq^10^ 2003 | CRT | NR | 73 ± 8 | NR | 0 | III or IV = 100 | | 23 (52) | 206 ± 26 | 25 ± 9 | NR
RD-CHF
Kindermann^13^ 2006 | All | 23 (77) | 69.6 ± 8.1 | 17 | 0 | III or IV = 100 | | 12 (37) | 174 ± 42 | 26.1 ± 7.8 | Post
HOBIPACE
Cleland^15^ 2005 | OPT | 293 (73) | 66 median | 144 | 0 | 377 | 27 | 0 | 160 median | 25 median | Pre
| | | IQR 59–72 | | | | | | IQR 152–180 | IQR 22–29
CARE-HF | CRT+OPT | 304 (74) | 67 median | 165 | 0 | 386 | 23 | 0 | 160 median | 25 median | Pre
| | | IQR 60–73 | | | | | | IQR 152–180 | IQR 21–29
St. Jude ^16^ 2005 | All | 66 (62.5) | 67.1 ± 9.7 | NR | 29 | 65 | 6 | NR | ≥140 | ≤35 | Pre
VecTOR
Combined CRT-ICD
Young^6^ 2001 | CRT III/IV | 142 (76) | 67 ± 11 | 64 | 0 | 88 | 12 | NR | 165 ± 22 | 24 ± 7 | Pre
MIRACLE-ICD | Control III/IV | 141 (78) | 68 ± 9 | 76 | 0 | 89 | 11 | NR | 162 ± 22 | 24 ± 6 | Pre
Higgins^9^ 2003 | CRT II-IV | 210 (85) | 66 ± 11 | 67 | 32 | 60 | 8 | NR | 160 ± 27 | 21 ± 7 | Post
CONTAK-CD | Control II-IV | 211 (83) | 66 ± 11 | 70 | 33 | 57 | 10 | NR | 156 ± 26 | 22 ± 7 | Post
Abraham^14^ 2004 | CRT/ICD on | 75 (88) | 63 ± 12.8 | 55 | 100 | 0 | 0 | NR | 166 ± 25 | 24.4 ± 6.6 | Post
MIRACLE ICD II | Control CRT off | 91 (90) | 63.1 ± 12.1 | 58 | 100 | 0 | 0 | NR | 165 ± 23 | 24.6 ± 6.7 | Post
St. Jude^17^ 2004a | CRT on | NR | NR | NR | 5 | 87 | 7 | 0 | 169 ± 16 | 25.6 ± 8.3 | Post
RHYTHM ICD | Control CRT off | NR | NR | NR | 7 | 85 | 5 | 0 | 167 ± 15 | 23.3 ± 6.4 | Post
CRT alone and combined CRT-ICD
Bristow^11^ 2004 | CRT+OPT | 415 (67) | 67 | 54 | 0 | 87 | 13 | NR | 160 | 20 | Post
COMPANION | CRT+ICD+OPT | 401 (67) | 66 | 55 | 0 | 86 | 14 | NR | 160 | 22 | Post
| OPT | 213 (69) | 68 | 59 | 0 | 82 | 18 | NR | 158 | 22 | Post
Auricchio^12^ 2003 | All | 57 (66) | 60 ± 9 | 38 | II or III = 33 | | 67 | 16 | 155 ± 20 | 23 ± 7 | Post
PATH-CHF II | Inactive first | 27 (63) | 58 ± 8 | 33 | II or III = 28 | | 72 | 7 | 157 ± 23 | 23 ± 8 | Post
| Active first | 30 (70) | 61 ± 9 | 44 | II or III = 37 | | 63 | 26 | 154 ± 18 | 23 ± 7 | Post

CRT = cardiac resynchronization therapy; ICD = implanted cardioverter defibrillator; IQR = interquartile range; OPT = optimal pharmacological therapy; NR = not reported

Table 7 Baseline characteristics of patients in trials included in the efficacy review: ICD alone

Author Year | Study group | Males n (%) | Age, yr. mean ± SD | Ischemic, % | NYHA Class | | | Other measures | | | Baseline measures taken pre/post implantation
Trial name | | | | | II, % | III, % | IV, % | Atrial fibrillation, % | QRS interval, msec mean ± SD | ,%
Primary prevention
Moss^133^ 1996 | ICD | 87 (92) | 62 ± 9 | 34 | II or III = 63 | | 0 | NR | NR | 27 ± 7 | Pre
MADIT | CMT | 93 (92) | 64 ± 9 | 29 | II or III = 67 | | 0 | NR | NR | 25 ± 7 | Pre
Bigger^134^ 1997 | CABG+ICD | 386 (86.5) | 64 ± 9 | 100 | II or III = 71 | | NR | NR | 71% ≥ 100 msec | 27 ± 6 | Pre
CABG PATCH | CABG | 373 (82.2) | 63 ± 9 | 100 | II or III = 74 | | NR | NR | 74% ≥100 msec | 27 ± 6 | Pre
Moss^135^ 2002 | ICD | 623 (84) | 64 ± 10 | 100 | 35 | 25 | 5 | 9 | 50% ≥120 msec | 23 ± 5 | Pre
MADIT II | CMT | 417 (85) | 65 ± 10 | 100 | 34 | 23 | 4 | 8 | 51% ≥120 msec | 23 ± 6 | Pre
Bänsch^136^ 2002 | All | 83 (79.8) | 52 ± 11 | 0 | 65.3 | 34.6 | 0 | 15.76 | 108 ± 29 | 24 ± 7 | Pre
CAT | ICD | 43 (86) | 52 ± 12 | 0 | 66.7 | 33.3 | 0 | 20.4 | 102 ± 29 | 24 ± 6 | Pre
| Control | 40 (74) | 52 ± 10 | 0 | 64.1 | 35.8 | 0 | 11.3 | 114 ± 29 | 25 ± 8 | Pre
Strickberger^137^ 2003 | All | 72 (69.9) | 59 ± 11 | 0 | 64 | 19.4 | 0 | NR | NR | 22 ± 9 | Pre
AMIOVIRT | ICD | 34 (67) | 58 ± 11 | 0 | 64 | 16 | 0 | NR | NR | 22 ± 10 | Pre
| Amiodarone | 38 (74) | 60 ± 12 | 0 | 63 | 24 | 0 | NR | NR | 23 ± 8 | Pre
Bristow^11^ 2004 | CRT + OPT | 413 (67) | Median 67 | 54 | Exc | 87 | 13 | NR | ≥120 msec | Median 20 | Pre
COMPANION | CRT + ICD + OPT | 399 (67) | Median 66 | 55 | Exc | 86 | 14 | NR | ≥120 msec | Median 22 | Pre
| OPT only | 213 (69) | Median 68 | 59 | Exc | 82 | 18 | NR | ≥120 msec | Median 22 | Pre
Kadish^138^ 2004 | All | 326 (71.2) | 58 range 20–84 | 0 | 57.4 | 21 | 0 | 24.5 | 115.1 range 78–196 | 21.4 range 7–35 | Pre
DEFINITE | ICD | 166 (72.5) | 58 range 20–84 | 0 | 54.2 | 20.5 | 0 | 22.7 | 114.7 range 78–196 | 20.9 range 7–35 | Pre
| Control | 160 (69.9) | 58 range 22–79 | 0 | 60.7 | 21.4 | 0 | 26.2 | 115.5 range 79–192 | 21.8 range 10–35 | Pre
Hohnloser^139^ 2004 | ICD | 252 (75.9) | 61.5 ± 10.9 | 100 | NR | NR | 0 | NR | 107 ± 24 | 28 ± 5 | Pre
DINAMIT | Control | 262 (76.6) | 62.1 ± 10.6 | 100 | NR | NR | 0 | NR | 105 ± 23 | 28 ± 5 | Pre
Bardy^140^ 2005 | ICD | 639 (76) | 60 Median IQR 52–69 | 52 | 71 | 29 | 0 | 16 | NR | 25 median | Pre
SCD-HeFT | Amiodarone | 639 (77) | 60 Median IQR 52–68 | 50 | 70 | 30 | 0 | 17 | NR | 25 median | Pre
| Placebo | 655 (77) | 59.7 Median IQR 51–68 | 53 | 68 | 32 | 0 | 14 | NR | 25 median | Pre
Secondary prevention
AVID Investigators^141^ 1997 | ICD | 395 (78) | 65 ± 11 | 81 | I or II = 48 | 7 | 0 | 21 | 116 ± 26 | 32 ± 13 | Pre
AVID | Antiarrhythmics | 412 (81) | 65 ± 10 | 81 | I or II = 48 | 12 | 0 | 26 | 117 ± 26 | 31 ± 13 | Pre
Connolly^142^ 2000 | ICD | 280 (85.4) | 63.3 ± 9.2 | 82.2 | I or II = 37.8 | III or IV = 11.0 | | NR | NR | 34.3 ± 14.5 | Pre
CIDS | Amiodarone | 277 (83.7) | 63.8 ± 9.9 | 82.9 | I or II = 39.9 | III or IV = 10.6 | | NR | NR | 33.3 ± 14.1 | Pre
Kuck^143^ 2000 | ICD | 78 (79) | 58 ± 11 | 73 | 59 | 18 | 0 | NR | NR | 46 ± 19 | Pre
CASH | Antiarrhythmics | 152 (80) | 57.5 ± 10 | 73.5 | 56 | 16 | 0 | NR | NR | 46 ± 17 | Pre

CRT = cardiac resynchronization therapy, ICD = implanted cardioverter defibrillator; NR = not reported; OPT =optimal pharmacological therapy

Table 9 Baseline characteristics of patients in studies included in the effectiveness or safety reviews: CRT alone or combined CRT-ICD devices

Author Year | Study group | Males n (%) | Age, yr. Mean ± SD | Ischemic % | NYHA class | | | Other measures
Trial Name | | | | | II, % | III, % | IV, % | Atrial fibrillation % | QRS interval, msec mean ± SD | LVEF, % mean ± SD
CRT alone
Abraham^4^ 2002 | CRT | 155 (68) | 64 ± 11 | 50 | 0 | 90 | 10 | 0 | 167 ± 21 | 22 ± 6
MIRACLE | Control | 153 (68) | 65 ± 11 | 58 | 0 | 91 | 9 | NR | 165 ± 20 | 22 ± 6
Achilli^18^ 2003 | All | 31 (60) | 69.6 ± 9 | 40 | 0 | III or IV = 100 | | 0 | 152.6 ± 32.1 | 23.0 ± 4.6
Adamson^19^ 2004 | All | 169 (58.7) | 65.8 ± 11.3 | 47 | 0 | 96 | 4 | 0 | 164.9 ± 22.2 | 22 ± 6
InSync III
Albertsen^20^ 2005 | All | 94 (78.3) | 62 (4–8) | 52 | 22 | 69 | 8 | NR | NR | 22.3 ± 8.6
Ansalone^23^ 2002 | All | NR | NR | 0 | 0 | III or IV = 100 | | NR | 160.3 ± 27.3 | 31 ± 7
Aranda^24^ 2005 | All | 30 (58) | 63 ± 10 | 52 | NR | NR | NR | NR | NR | 18 ± 6
Auricchio^8^ 2002a | All | 21 (50) | 60 ± 7 | 29 | 0 | 86 | 14 | 0 | 175 ± 32 | 21 ± 7
PATH-CHF
Auricchio^25^ 2002b | All | 33 (66) | 60 ± 9 | 40 | II or III = 32 | | 67 | 0 | 163 ± 25 | 22 ± 5
Baker^27^ 2002 | All | 50 (83) | 70 ± 12 | 57 | 0 | 57 | 43 | NR | NR | 21 ± 8
Bax^28^ 2003 | All | 22 (88) | 62 ± 9 | 44 | 0 | 76 | 24 | NR | 185 ± 35 | 22 ± 5
Bleeker^30^ 2005a | < 70 | 80 (78) | 59 ± 9 | 48 | 0 | 81 | 19 | NR | 175 ± 28 | 21 ± 8
| > 70 | 57(84) | 76 ± 4 | 66 | 0 | 85 | 15 | NR | 171 ± 24 | 22 ± 8
| All | 137 (80.6) | 66 ± 11 | 55 | 0 | 83 | 17 | NR | 173 ± 27 | 21 ± 7
Bleeker^31^ 2005b | All | 44 (78.6) | 64 ± 11 | 52 | 0 | 89 | 11 | 13 | 176 ± 30 | 19 ± 6
Bleeker^32^ 2006 | NYHA II | 47 (94) | 65 ± 10 | 58 | 100 | 0 | 0 | 16 | 160 ± 30 | 25 ± 7
| NYHA III-IV | 41 (82) | 66 ± 11 | 56 | 0 | 86 | 14 | 12 | 168 ± 27 | 20 ± 7
| All | 88 (88) | 65.5 ± 10.5 | 57 | 50 | 43 | 7 | 14 | 164 ± 28.7 | 22.2 ± 7.4
Bonanno^34^ 2004 | All | 32 (86.5) | 73 ± 7 | 51 | 0 | III or IV = 100 | | 30 | 189.1 ± 35.4 | 27.4 ± 6.0
Bordachar^35^ 2004 | All | 33 (80) | 69 ± 6.5 | 56 | 0 | III or IV = 100 | | 0 | 170 ± 31 | 28 ± 6
Boriani^38^ 2006c | All | 22 (68.8) | 65 median (61–74) | 53 | 0 | 87.5 | 12.5 | NR | 168 median (142–180) | 25.5 median (22.2–30.7)
Braunschweig^40^ 2005 | All | 46 (82.1) | 65 ± 11 | 55 | 20 | 66 | 14 | 0 | 170 ± 24 | 24 ± 7
Cazeau^5^ 2001 | All | 50 (75) | 63 ± 10 | 37 | 0 | 100 | 0 | NR | 1764 ± 19 | 23 ± 7
MUSTIC-SR
Cazeau^41^ 2003 | All | NR | NR | 35 | 0 | 86 | 14 | 27 | 182 ± 33 | 28 ± 8
Chalil^42^ 2006 | All | 58 (77) | 67.8 ± 12.1 | 71 | 0 | 61 | 39 | 25 | 156.9 ± 21.7 | 32 ± 8.7
Chan^43^ 2003 | All | 49 (78) | 68.8 | 47 | 0 | III or IV = 100 | | NR | 182 ± 31 | 21.0 ± 5.9
Cleland^15^ 2005 | OPT | 293 (73) | 66 median (59–72) | 36 | 0 | 93 | 7 | 0 | 160 median, IQR 152–180 | 25 median IQR 22–29
CARE-HF | CRT + OPT | 39 (74) | 67 median (60–73) | 40 | 0 | 94 | 6 | 0 | 160 median, IQR 152–180 | 25 median IQR 21–29
Daubert^46^ 1998 | All | 42 (91) | 68 ± 9 | 53 | 0 | 13 | 87 | NR | 187 ± 27 | 17 ± 4
De Martino^125^ 2004 | All | NR | NR | NR | 0 | III or IV = 100 | | NR | ≥ 120 msec | NR
De Martino^126^ 2005 | All | NR | 61.5 ± 6.5 | 50 | 0 | III or IV = 100 | | NR | ≥ 120 msec | 24.5 ± 7
Dixon^50^ 2004 | All | 24 (89) | 64 ± 9 | 52 | 0 | III or IV = 100 | | NR | 177 ± 21 | < 30
Galvao^56^ 2002 | All | 23 (82.1) | 58.5 (36, 84) | 46 | 0 | 43 | 57 | NR | 187 ± 18.35 | 34 ± 5.7
Gras^58^ 2002 | All | 81 (78.6) | 67 ± 10 | 48 | 0 | 68 | 32 | NR | 178 ± 28 | 22 ± 6
Hua^60^ 2006 | All | 91 (64) | 60 ± NR | 31 | 0 | III or IV = 100 | | NR | 146.7 ± NR | 28.7 ± NR
Kautzner^128^ 2004 | All | 116 (84) | 61 ± 8 | NR | 0 | III or IV = 100 | | NR | ≥ 150ms | 21.8 ± 8.8
Kies^62^ 2006 | All | 67 (90.5) | 68 ± 8 | 43 | 0 | 82 | 18 | 100 | 176 ± 30 | 22 ± 7
Kindermann^13^ 2006 | All | 23 (77) | 69.6 ± 8.1 | 57 | NR | NR | NR | 37 | 174 ± 42 | 26.1 ± 7.8
HOBIPACE
Koos^63^ 2004 | All | 52 (64.2) | 65.4 ± 12.3 | 47 | NR | NR | NR | NR | 165.8 ± 21.1 | 23.6 ± 7.3
Leclercq^66^ 2000 | All | 34 (92) | 67.4 ± 7.2 | 38 | 0 | 70 | 30 | 41 | 181 ± 23 | 22.8 ± 5.3
Leclercq^7^ 2002a | All | 35 (81) | 65 ± 8 | 43 | 0 | 100 | 0 | 100 | 209 ± 18 | 26 ± 10
MUSTIC-AF
Leclercq^67^ 2002b | All | 81 (79) | 67 ± 11 | 47 | 0 | 70 | 30 | NR | 177.9 ± 27.9 | 22 ± 7.1
Leclercq^10^ 2003 | All | NR | 73 ± 8 | NR | 0 | III or IV = 100 | | 23 | 206 ± 26 | 25 ± 9
RD-CHF
Lecoq^68^ 2005 | All | 113 (81) | 68 ± 9 | 35 | 0 | 69 | 31 | 32 | 188 ± 28 | 21 ± 6
Leon^70^ 2005 | All | 211 (58.8) | 65.8 ± 10.8 | 46.2 | 0 | 91.6 | 8.4 | 89.7 | 163.9 ± 21.6 | 21.5 ± 6.9
Lindner^71^ 2005 | All | NR | 62 ± 8.4 | 26 | 0 | 100 | 0 | 2 | 185.1 ± 19.3 | 22.2 ± 6.6
Macioce^72^ 2005 | All | 26 (86.7) | 74.1 ± 6.1 | 47 | 0 | III or IV = 100 | | NR | 140 ± 10 | 28 ± 8
Mangiavacchi^74^ 2006 | All | 116 (74.4) | 65.6 ± 8.9 | 48.7 | 16.8 | III or IV = 83.2 | | NR | 171.7 ± 29.8 | 30.4 ± 6.9
Marai^75^ 2006 | All | 84 (85.7) | 69.8 ± 9.0 | 89.8 | 0 | III or IV = 100 | | 19.4 | 173.2 ± 35.1 | 22.3 ± 6.2
Mascioli^76^ 2002 | All | 53 (77.9) | 68 ± 8 | 51 | NR | NR | NR | 9 | 177 ± 30 | NR
Mele^77^ 2006 | All | 27 (73) | 68 ± 8 | 43 | 0 | 86 | 14 | 0 | 161 ± 24 | 25 ± 5
Mortensen^83^ 2004 | All | 137 (72.5) | 66.3 ± 10.6 | 42 | 18 | 68 | 14 | NR | 176.3 ± 27.0 | 24.2 ± 6.9
Nagele^85^ 2001 | All | 24 (75) | 60 ± 10 | 47 | NR | NR | NR | NR | 185 ± 30 | 26.5 ± 7
Niu^87^ 2006 | All | 86 (73.5) | 53 ± NR | NR | 0 | III-IV = 100 | | NR | 141.8 ± NR | 25.8 ± NR
O'Donnell^89^ 2005 | All | NR | NR | NR | NR | NR | NR | 0 | NR | 23
Oliva^90^ 2005 | All | 213 (82) | 62 ± 10 | 40 | NR | NR | NR | NR | 171 ± 31 | 26.1 ± 6.9
Ollitrault^91^ 2003 | All | 50 (81) | 71 ± 10 | NR | 0 | III or IV = 100 | | NR | > 150 | NR
Porciani^95^ 2006a | All | 28 (93.3) | 73.7 ± 6.3 | 46.7 | 0 | III or IV = 100 | | NR | 140 ± 10 | 27 ± 8.0
Porciani^96^ 2006b | All | 51 (78) | 73 ± 8 | 47.7 | 0 | III or IV = 100 | | 0 | 170 ± 30 | 28 ± 7
Puglisi^97^ 2004 | All | 262 (83) | 63 ± 10 | 40 | 0 | 85 | 15 | NR | 178 ± 34 | 26 ± 7
Reuter^99^ 2000 | All | 38 (81) | 64 ± 11 | NR | 8 | 47 | 47 | 40 | 173 ± 18 | 23 ± 7
Ricci^101^ 2002 | All | 40 (83.3) | 68 ± 8 | 40 | 0 | III or IV = 100 | | 15 | 154 ± 29 | 29 ± 9
Romeyer-Bouchard^131^ 2005 | All | 86 (83.5) | 71 ± 10 | 34 | 0 | 69 | 31 | 13 | 185 ± 25 | ≤ 35
Sawhney^105^ 2004 | All | 28 (70) | 59.8 ± 12.1 | 45 | 0 | III or IV = 100 | | 0 | 176 ± 22 | 25.6 ± 5.4
Schuchert^132^ 2004 | All | 71 (70) | 67 ± 10 | 27 | 0 | 67 | 33 | 12 | 148.2 ± 18.3 | < 35
Sogaard^107^ 2002 | All | 22 (88) | 61.2 ± 10 | 55 | 0 | 55 | 45 | NR | 189 ± 23 | 23.8 ± 6
Stahlberg^108^ 2005 | All | 38 (95) | 65 ± 10 | 65 | 0 | 88 | 12 | 30 | 173 ± 22 | 23 ± 9
St. Jude^16^ 2005 | All | 90 (62.5) | 67.1 ± 9.7 | NR | 29 | 65 | 6 | NR | ≥ 140 | ≤ 35
VecTOR
Taieb^109^ 2002 | All | 33 (66) | 71.4 ± 9.9 | 32 | 4 | 74 | 22 | 12 | > 150 ± 35 | < 35
Tedrow^110^ 2006 | All | 53 (70.7) | 65.5 ± 12.5 | 46.6 | NR | 73.3 | 9.3 | 50.1 | 171.1 ± 40.5 | 21 ± 9
Toussaint^113^ 2003 | All | 31 (91.2) | 64.5 ± 11 | 53 | 0 | III or IV = 100 | | NR | 179 ± 18 | 20.2 ± 8.1
Witte^116^ 2006 | All | NR | 68.4 ± 17.7 | 52 | NR | NR | NR | 28 | 188.3 ± 31.4 | 20 ± 8.8
Yu^119^ 2002b | All | 21(70) | 62 ± 14 | 40 | 0 | 60 | 40 | NR | 159.1 ± 25.8 | 25.1 ± 12.9
Yu^121^ 2005 | All | 103 (73) | 64 ± 11 | 48 | 9 | 75 | 16 | NR | 156.1 ± 37.4 | 24.8 ± 8
Zhang^122^ 2006 | All | 36 (72) | 66 ± 11 | 48 | 0 | 80 | 20 | NR | 151 ± 27 | 26.5 ± 9.3
Combined CRT-ICD
Abraham^14^ 2004 | CRT/ICD on | 75 (88) | 63 ± 12.8 | 55 | 100 | 0 | 0 | NR | 166 ± 25 | 24.4 ± 6.6
MIRACLE-ICD II | Control CRT off | 91 (90) | 63.1 ± 12.1 | 58 | 100 | 0 | 0 | NR | 165 ± 23 | 24.6 ± 6.7
Boriani^36^ 2006a | CRT+ICD | 100 (82.6) | 67 ± 8.6 | 63 | 0.8 | 92.6 | 6.6 | NR | 175 ± 22 | 24.2 ± 5.8
Chugh^123^ 2005 | CRT + ICD | 52 (67.5) | 61 ± 11 | 56 | NR | NR | NR | 29 | 168 ± 24 | 19 ± 7
de Cock^124^ 2004 | All | NR | NR | NR | 0 | III or IV = 100 | | NR | ≥ 140ms | ≤ 35
Gasparini^127^ 2005 | All | 177 (91) | 65.2 ± 8.5 | 70 | Mean = 3.0 ± 0.5 | | | NR | 164 ± 31 | 29.3 ± 6.2
Higgins^9^ 2003 | All | 176 (77.5) | 66 ± 11 | 68 | 13 | 72 | 15 | 0 | 158 ± 26.6 | 21.5 ± 7.0
CONTAK-CD
Kuhlkamp^65^ 2002 | All | 74 (91) | 63.8 ± 8.8 | 57 | 32 | 59 | 9 | 6 | 170 ± 30 | 25 ± 7
Murphy^84^ 2006 | All | 43 (80) | 61 22–85 | 54 | 6 | 87 | 7 | 9 | 157 ± 34 | 26.6 ± 8.4
Ritter^102^ 2006 | All | 32 (66.7) | 71 ± 8 | 89.6 | 0 | III or IV = 100 | | 0 | 162 ± 27 | 23 ± 3.7
Saxon^106^ 2006 | All | 142 (85) | 70.7 ± 10.3 | 78 | 0 | 88 | 13 | 23 | 150 ± 25 | 22.6 ± 6.4
St. Jude^17^ 2004a | All | NR | NR | NR | 6 | 87 | 6 | 0 | 168 ± 15 | 24.8 ± 7.7
RHYTHM ICD
St. Jude^17^ 2004b RHYTHM ICD | All | 132 (82) | 68.8 ± 9.9 | 78 | 0 | 92 | 8 | NR | 166 ± 21 | 22.5 ± 6.7
Quicksite®
Theuns^112^ 2005 | All | 66 (77) | 61 ± 10 | 59 | 26 | 74 | 0 | 27 | 174 ± 31 | 23 ± 8
Young^6^ 2003 | CRT III-IV | 142 (75.9) | 66.6 ± 11.3 | 64 | 0 | 88 | 12 | NR | 165 ± 22 | 24.2 ± 6.5
MIRACLE-ICD | Control III-IV | 141 (77.5) | 67.6 ± 9.2 | 76 | 0 | 89 | 11 | NR | 162 ± 22 | 23.9 ± 6
Ypenburg^117^ 2006 | All | 153 (79) | 64 ± 11 | 56 | 0 | III or IV = 100 | | 28 | 163 ± 30 | 21 ± 7
CRT or combined CRT-ICD
Alonso^21^ 1999 | All | 24 (92.3) | 66 ± 7 | 35 | 0 | 69 | 31 | 23 | 178 ± 24 | 23 ± 8
Ammann^22^ 2004 | All | 36 (83.7) | 65 ± 10 | 47 | 0 | III or IV = 100 | | 16 | 172 median IQR 158–196 | 20 median IQR 15–25
Auricchio^12^ 2003 | All | 57 (66.3) | 60 ± 9 | 38 | II or III = 33 | | 67 | 16 | 155 ± 20 | 23 ± 7
PATH-CHF II | Inactive first | 27 (62.8) | 58 ± 8 | 33 | II or III = 28 | | 72 | 7 | 157 ± 23 | 23 ± 8
| Active first | 30 (69.8) | 61 ± 9 | 44 | II or III = 37 | | 63 | 26 | 154 ± 18 | 23 ± 7
Azizi^26^ 2006 | All | 200 (82) | 64 ± 12 | 44 | 10 | 68 | 22 | 29 | NR | 24 ± 9
Bax^29^ 2004 | All | 64 (75.3) | 66 ± 12 | 55 | 0 | 80 | 20 | 0 | 178 ± 36 | 23 ± 7
Bocchiardo^33^ 2000 | All | 45 (94) | 63 ± 7 | 52 | 25 | 65 | 10 | NR | NR | 27 ± 5.5
Boriani^37^ 2006b | All | 383 (91) | 65 ± 9 | 69 | 23 | 66 | 11 | NR | 168 ± 32 | 26 ± 7
Braun^39^ 2005 | OPT | 40 (67.8) | 63 ± 9 | 70 | 0 | 93 | 7 | 0 | 175 ± 22 | 21.5 ± 5
| CRT and CRT + ICD | 45 (69.2) | 65 ± 11 | 74 | 0 | 90 | 10 | 0 | 172 ± 19 | 20.9 ± 4
Bristow^11^ 2004 | CRT + OPT | 415 (67) | 67 | 54 | 0 | 87 | 13 | NR | 160 | 20
COMPANION | CRT + ICD + OPT | 401 (67) | 66 | 55 | 0 | 86 | 14 | NR | 160 | 22
| OPT | 213 (69) | 68 | 59 | 0 | 82 | 18 | NR | 158 | 22
Cowburn^44^ 2005 | All | NR | 67 ± 12 | 66 | 0 | III or IV = 100 | NR | NR | NR | 19 ± 7
Da Costa^45^ 2006 | All | 56 (83.6) | 70 ± 10 | 34.3 | 0 | 59.7 | 40.3 | 26.9 | 190 ± 28 | 26 ± 5
Davis^47^ 2005 | All | 75 (88) | 66 ± 9 | 72 | 5 | 84 | 12 | NR | 168 ± 22 | 21 ± 6
De Sisti^48^ 2006 | All | 86 (84.3) | 68 ± 10 | 51 | 13.7 | 65.7 | 20.6 | 28.4 | 187 ± 35 | 20 ± 9
Diaz-Infante^49^ 2005 | All | 113 (79) | 68.3 ± 7 | 34 | 17 | 80 | 3 | 23 | 165 ± 26 | 27 ± 7
Duncan^51^ 2006 | All | 30 (77) | 65 ± 10 | 59 | 0 | 95 | 5 | 0 | 154 ± 75 | 21 ± 5.6
Ellery^52^ 2005 | All | 73 (76) | 68 ± 9 | 38 | 0 | 83 | 17 | NR | 163 ± 30 | NR
Ermis^53^ 2004 | All | 96 (76.1) | 69 ± 11.5 | 56 | NR | III or IV = 87 | | NR | NR | 22 ± 8.7
Fung^54^ 2005 | CRT | 26 (72.2) | 66.0 ± 10.4 | 36 | NR | NR | NR | 100 | NR | 31.7 ± 7.8
| Control | 26 (72.2) | 65.2 ± 8.1 | 33 | NR | NR | NR | 0 | NR | 32.8 ± 7
Gaita^55^ 2000 | All | 88 (92) | 66 ± 8 | NR | II, III or IV = 100 | | | NR | > 140 msec | 22 ± 6
Gasparini^57^ 2003a | All | 121 (76.6) | 65 ± 9 | 47 | 19 | III or IV = 81 | | NR | 173.7 ± 29.7 | 29.6 ± 7.0
Hernandez^59^ 2004 | All | 21 (75) | 66 ± 9 | 39 | 0 | III or IV = 100 | | 29 | 168 ± 23 | 30 ± 8
Kies^61^ 2005 | All | 75 (77.3) | 63.3 ± 10.6 | 62 | 0 | 84 | 16 | NR | 175.0 ± 23.4 | 22 ± 6
Krahn^64^ 2002 | All | 37 (82) | 65.3 ± 10.3 | 69 | 7 | 76 | 18 | 33 | 166 ± 20 | 19 ± 5
Lenom^69^ 2005 | All | 25 (69) | 76 ± 10 | 67 | 6 | 78 | 2 | 11 | 177 ± 27 | 24 ± 6
Lewicka-Nowak^129^ 2005 | All | 73 | 62.6 ± 9.6 | 52 | NR | NR | NR | 16 | 170 ± 29 | 22 ± 7
Mair^73^ 2005 | All | NR | 63.9 ± 9.8 | 31 | II or III = 8 | III or IV = 92 | | NR | 182 ± 22 | 21.9 ± 6.9
Molhoek^78^ 2002 | All | 31(78) | 64 ± 10 | 48 | 0 | III or IV = 100 | | NR | 120–240 msec | 24 ± 9
Molhoek^79^ 2004a | All | 51 (85) | 65 ± 9 | 48 | 0 | 80 | 20 | 50 | 192.5 ± 26.7 | 21.5 ± 9.7
Molhoek^80^ 2004b | All | 57 (77) | 64.5 ± 10.5 | 46 | 0 | 85 | 15 | NR | 176.6 ± 28.8 | 22.1 ± 11.3
Molhoek^81^ 2004c | All | 47 (77) | 64 ± 11 | 46 | 0 | 84 | 16 | NR | 177 ± 30 | 28 ± 14
Molhoek^82^ 2005 | All | 93 (74) | 64 ± 10 | 54 | 0 | 89 | 11 | 10 | 176 ± 25 | 23 ± 8
Navia^86^ 2005 | All | 31 (76) | 68 ± 10 | 51 | 37 | 39 | 2 | NR | 186 ± 23 | 20.0 ± 9.2
Notabartolo^88^ 2004 | All | 39 (80) | 66 ± 10 | 69 | 0 | III or IV = 100 | | 16 | 158 ± 31 | 24 ± 9
Pappone^92^ 2003 | All | 102 (76) | 64 ± 11 | 43 | 0 | III or IV = 100 | | 4 | 153 ± 11 | 28 ± 6
Penicka^93^ 2004 | All | NR | 71.3 ± 10.4 | 47 | NR | NR | NR | NR | 181.5 ± 30.0 | 25.3 ± 5.6
Pitzalis^94^ 2005 | All | 32 (53.3) | 62 ± 10 | 22 | 0 | 100 | 0 | NR | 171 ± 22 | 25 ± 5
Purerfellner^130^ 2000a | All | 31 (67) | 70 ± 10 | NR | NR | NR | NR | 98 | NR | NR
Purerfellner^130^ 2000b | All | 117 (78) | 64 ± 10 | 30 | 8 | 70 | 21 | NR | 165 ± 35 | NR
Purnode^98^ 2004 | All | 31(72) | 67 ± 11 | 53 | 7 | 72 | 21 | 79 | 182 ± 27 | 24.4 ± 7
Reuter^100^ 2002 | All | 87 (85.3) | 64 ± 11 | NR | 8 | 62 | 30 | 19 | 184 ± 38 | 24 ± 8
Rossillo^103^ 2004 | All | 170 (73) | 66.2 ± 5.8 | 61 | 0 | 89 | 11 | NR | 169.4 ± 33.4 | 19.0 ± 7.9
Salukhe^104^ 2005 | All | 32 (80) | 65 ± 10.5 | 58 | 10 | 83 | 7 | NR | 156.4 ± 18.3 | 35.6 ± 7.7
Teo^111^ 2003 | All | 26 (90) | 59.6 ± 12.8 | 62 | 0 | III or IV = 100 | | NR | 161 ± 21 | 22 ± 9
Vidal^114^ 2006 | All | 52 (81) | 70 ± 8 | 48 | 24 | 65 | 11 | NR | 176 ± 26 | 23 ± 6
Waggoner^115^ 2006 | All | 43 (75) | 61 ± 12 | 33 | | III or IV = 100 | | 0 | 180 ± 27 | 25.5 ± 5
Yu^118^ 2002a | All | 18 (72) | 65 ± 12 | 36 | 0 | 44 | 56 | NR | 162 ± 30 | 27.9 ± 10.2
Yu^120^ 2004 | All | 38 (66) | 66.1 ± 11.6 | 41 | 0 | 74 | 26 | NR | 154.3 ± 26.6 | 27.1 ± 10.6

CRT = cardiac resynchronization therapy; ICD = implanted cardioverter defibrillator; IQR = interquartile range; NR = not reported

Table 11 Baseline characteristics of patients in trials included in the effectiveness and safety reviews: ICD

Author Year | Study group | Males, n (%) | Age, yr mean ± SD | Ischemic, % | NYHA class | | | Other measures | | | Baseline measures pre/post implantation
Trial Name | | | | | II, % | III, % | IV, % | Atrial fibrillation, % | QRS interval, msec mean ± SD | LVEF, % mean ± SD
Alter^144^ 2005 | ICD | 357 (81.1) | 58 ± 14 | 48 | 49 | 37.3 | 2 | NR | NR | 34 ± 15 | Pre
Anti-arrhythmics vs. Implantable Defibrillators^141^ 1997 | ICD | 395 (78) | 65 ± 11 | 81 | I or II = 48 | 7 | 0 | 21 | 116 ± 26 | 32 ± 13 | Pre
AVID | Antiarrhythmics | 412 (81) | 65 ± 10 | 81 | I or II = 48 | 12 | 0 | 26 | 117 ± 26 | 31 ± 13
Backenkohler^145^ 2005 | All participants | 196 (80) | 62.8 ± 0.8 | 75.1 | NR | NR | NR | 15.9 | NR | 35.6 ± 15.4 | Pre
| Secondary prevention | 157 (78) | 63 ± 11 | 73.8 | NR | NR | NR | 16 | 52% ≥ 120 msec | 36 ± 16
| Primary prevention | 39 (91) | 62 ± 10 | 81 | NR | NR | NR | 14 | 49% ≥ 120 msec | 34 ± 12
Bänsch^136^ 2002 | All participants | 83 (79.8) | 52 ± 11 | 0 | 65.3 | 34.6 | 0 | 15.7 | 108 ± 29 | 24 ± 7 | Pre
CAT | ICD | 43 (86) | 52 ± 12 | 0 | 66.7 | 33.3 | 0 | 20.4 | 102 ± 29 | 24 ± 6
| Control | 40 (74.1) | 52 ± 10 | 0 | 64.1 | 35.8 | 0 | 11.3 | 114 ± 29 | 25 ± 8
Bardy^140^ 2005 | ICD | 639 (77) | 60.1 median IQR 51.9–69.2 | 52 | 57.4 | 21.0 | Exc | 16 | NR | 24.0 median IQR 19.0–30.0 | Pre
SCD-HeFT | Amiodarone | 639 (76) | 60.4 median IQR 61.7–68.3 | 50 | 54.2 | 21.5 | Exc | 17 | NR | 25.0 median IQR 20.0–30.0
| Placebo | 655 (77) | 59.7 median IQR 51.2–67.8 | 53 | 60.7 | 21.4 | Exc | 14 | NR | 25.0 median IQR 20.0–30.0
Bigger^134^ 1997 | CABG+ICD | 386 (86.5) | 64 ± 9 | 100 | II or III = 71 | | 0 | NR | 71% ≥ 100 msec | 27 ± 6 | Pre
CABG-Patch | CABG | 373 (82.2) | 63 ± 9 | 100 | II or III = 74 | | 0 | NR | 74% ≥ 100 msec | 27 ± 6
Blangy^146^ 2003 | Participants with LVEF ≤35% | 124 (86.1) | 60.5 ± 11.9 | 72.9 | NR | NR | NR | 18 | NR | 27 ± 5 | Unclear
Bode-Schnurbus^147^ 2003 | All participants | 132 (80) | 61.8 ±9.7 | 72.7 | 0 | 100 | 0 | NR | 85% < 150 msec | 32.5 ± 13.6 | Unclear
Bokhari^148^ 2004 | ICD | 50 (83) | 64 ± 9.2 | 80 | I or II = 95 | III or IV = 5 | | NR | NR | 33.9 ± 12.5 | Pre
CIDS | Amiodarone | 50 (83) | 64 ± 8.7 | 80 | I or II = 95 | III or IV = 5 | | NR | NR | 32.1 ± 11.1
Bristow^11^ 2004 | CRT + OPT | 413 (67) | Median 67 | 54 | Exc | 87 | 13 | NR | ≥ 120 msec | Median 20 | Pre
COMPANION | CRT + ICD + OPT | 399 (67) | Median 66 | 55 | Exc | 86 | 14 | NR | ≥ 120 msec | Median 22 | Pre
| OPT only | 213 (69) | Median 68 | 59 | Exc | 82 | 18 | NR | ≥ 120 msec | Median 22 | Pre
Bruch^149^ 2006 | All participants | 67 (80) | 60 ± 12 | 74 | | 2.7 ± 0.5 | | 0 | 153 ± 39 | 29 ±10 | Post
Brunckhorst^150^ 2004 | All participants | 97 (93.3) | 67 ± 10 | 100 | NR | NR | NR | NR | 383 ± 195 | 35 ± 15 | Unclear
Buxton^151^ 1999 | EP-Antiarrhythmics | 316 (90) | 67 median IQR 60–72 | 96 | 39 | 24 | 0 | NR | NR | 30 median IQR 20–35 | Pre
MUSTT | No Antiarrhythmics | 318 (90) | 66 median IQR 58–72 | 93 | 38 | 25 | 0 | NR | NR | 29 median IQR 22–35
Capoferri^152^ 2004 | Secondary prevention | NR | 55 ± 13 | 70 | NR | NR | NR | NR | NR | 35 ± 13 | Pre
| Primary prevention | NR | 49 ± 15 | 67 | NR | NR | NR | NR | NR | 36 ± 13
| All participants | NR | 53 ± 13.9 | 69 | NR | NR | NR | NR | NR | 35.3 ± 12.9
Carlsson^192^ 2003 | All participants | 86 (90) | 61 ± 10.3 | 67.7 | NR | NR | NR | NR | NR | 34.1 ± 13.2 | Pre
Chan^153^ | ICD | NR | 66.2 | 100 | NR | NR | NR | NR | NR | NR | Pre
| Control | NR | 68.6 | 100 | NR | NR | NR | NR | NR | NR
Chan^154^ | ICD | 339 (86) | 66 ± 9.9 | 100 | NR | NR | NR | 0 | 39% > 120 ms | 26.2 ± 6.0 | Pre
Connolly^142^ 2000 | ICD | 280 (85.4) | 63.3 ± 9.2 | 82.2 | I or II = 37.8 | III or IV = 11 | | NR | NR | 34.3 ± 14.5 | Pre
CIDS | Amiodarone | 277 (83.7) | 63.8 ± 9.9 | 82.9 | I or II = 39.9 | III or IV = 10.6 | | NR | NR | 33.3 ± 14.1
Cuesta^155^ 2003 | All participants | 115 (95.8) | 63.3 ± 9 | 66.7 | NR | III or IV = 22.5 | | NR | NR | 33.7 ± 10.9 | Pre
Dorian^193^ 2004a | All participants | 124 (83.2) | 60 ± 13 | 71.1 | 51.7 | 9.5 | 0 | 10.7 | NR | 35 ± 15 | Pre
ASTRID Investigators
Dorian^156^ 2004b | Placebo group | 199 (93) | 62 ± 12 | NR | 43 | 9 | Exc | NR | NR | 34 ± 14 | Pre
SHIELD Investigators
Dubner^157^ 2005 | All participants | 578 (75) | 60 ± 13 | 39.7 | I or II = 81 | III or IV = 19 | | NR | NR | 37.7 ± 14.3 | Pre
Duray^158^ 2005 | All participants | 309 (82) | 63.6 ± 10 | 84 | 43.5 | III or IV = 23.5 | | NR | NR | 32.8 ± 11.4 | Pre
Elhendy^159^ 2005 | ICD | 63 (70) | 65 ± 13 | 48.9 | NR | NR | NR | 15.6 | NR | 33.7 ± 11.9 | Post
Ellenbogen^160^ 2003 | ICD | 58 (78.4) | 62 ± 16 | 65 | NR | NR | NR | NR | NR | 34 ± 11 | Unclear
Ermis^161^ 2003 | All participants | 231 (74.5) | 49.3 ± 11.9 | 45.2 | 15.8 | 58.4 | 18.7 | NR | NR | NR | Unclear
| ICD | 40 (67.8) | 51.1 ± 9.9 | 44.1 | 13.6 | 61 | 25.4 | NR | NR | 18.7 ± 6.8
| No ICD | 191 (76.1) | 48.9 ± 12.3 | 45.4 | 16.3 | 57.8 | 17.1 | NR | NR | 20.8 ± 9.8
Evonich^162^ 2004 | All participants | 122 (79.7) | 65.6 ± 12.6 | 64.4 | 34 | 44 | 0 | NR | NR | 25.4 ± 9.01 | Pre
Friedman^194^ 2006 | ICD (dual chamber) | 163 (81) | 64.3 ± 11.3 | 81 | NR | NR | NR | 18 | NR | 32 ± 13 | Pre
| ICD (ventricular only) | 156 (78) | 65.1 ± 11.3 | 81 | NR | NR | NR | 20 | NR | 32 ± 13
Gatzoulis^163^ 2005 | All participants | 142 (84) | 59.9 ± 12.5 | 60 | NR | NR | NR | NR | NR | 34.2 ± 14 | Pre
| Primary prevention | 18 (100) | 57 ± 18 | 78 | NR | NR | NR | NR | NR | 28 ± 10
| Secondary prevention | 124 (82.1) | 61 ± 12 | 58 | NR | NR | NR | NR | NR | 35 ± 14
Greenberg^164^ 2002 | All participants | 630 (86) | 62.6 ± 12.4 | 79 | NR | NR | NR | NR | NR | 29.2 ± 11.2 | Unclear
Grimm^165^ 2002 | All participants | 82 (81) | 51 ± 14 | NR | 61 | 35 | 0 | 21 | NR | 25 ± 8 | Unclear
Grimm^195^ 2006 | All participants | 83 (89) | 56 ± 13 | 34.4 | 38 | 58 | 4 | 22 ± 7 | NR | NR | Pre
Ho^166^ 2005 | ICD | 288 (80) | 62 ± 13 | 68 | NR | NR | NR | 23 | NR | 33 ± 17 | Unclear
Hohnloser^139^ 2004 | ICD | 25.2 (75.9) | 61.5 ± 10.9 | 100 | 95 | 40 | Exc | NR | 107 ± 24 | 28 ± 5 | Pre
DINAMIT | CMT | 262 (76.6) | 62.1 ± 10.6 | 100 | 98 | 49 | Exc | NR | 105 ± 23 | 28 ± 5
Hreybe^196^ 2006 | All participants | 181(79) | 63 ±14 | 75 | NR | III or IV = 45 | | 17 | 123 ± 34 | 26 ± 13 | Pre
Kadish^138^ 2004 | All participants | 326 (71.2) | 58.3 range 20.3 – 83.9 | 0 | 57 | 21 | Exc | 24.5 | 115.1 range 78–196 | 21.4 range 7–35 | Pre
DEFINITE | ICD | 166 (72.5) | 58.4 range 20.3–83.9 | 0 | 54 | 21 | Exc | 22.7 | 114.7 range 78–196 | 20.9 range 7–35
| Control | 160 (69.9) | 58.1 range 21.8–78.7 | 0 | 61 | 21 | Exc | 26.2 | 115 range 79–192 | 21.8 range 10–35
Koplan^167^ 2006 | All participants | 285 (82) | 70 ± 8 | 80.6 | NR | NR | NR | NR | 51% > 120 ms | 30 ± 11 | Pre
Kuck^143^ 2000 | ICD | 78 (79) | 58 ± 11 | 73 | 59 | 18 | 0 | NR | NR | 46 ± 19 | Pre
CASH | Antarrhythmics | 152 (80) | 57.5 ± 10 | 74 | 59 | 18 | 0 | NR | NR | 46 ± 17
Lampert^168^ 2004 | All participants | 340 (85) | 67.4 SE ± 1.3 | 100 | NR | NR | NR | NR | > 120 = 24% | 31.6 SE ± 1.7 | Pre
Leosdottir^169^ 2006 | All participants | 44 (71) | 58 ± 14 | 62 | NR | NR | NR | NR | NR | 40% ≤ 40 | Pre
Lickfett^197^ 2004 | All participants | 87 (83) | NR | 65 | NR | NR | NR | NR | NR | 31 ± 7 | Unclear
Moss^133^ 1996 | ICD | 87 (92) | 62 ± 9 | 34 | II or III = 63 | | 0 | NR | NR | 27 ± 7 | Pre
MADIT | CMT | 93 (92) | 64 ± 9 | 29 | II or III = 67 | | 0 | NR | NR | 25 ± 7
Moss^135^ 2002 | ICD | 623 (84) | 64 ± 10 | 100 | 35 | 25 | 5 | 9 | ≥ 120 = 50% | 23 ± 5 | Pre
MADIT II | Conventional treatment | 417 (85) | 65 ± 10 | 100 | 34 | 23 | 4 | 8 | ≥ 120 = 51% | 23 ± 6
Nazarian^170^ 2005 | All participants | 69 (73) | 55 ± 11 | 45 | 20 | 35 | 33 | 27 | NR | 25 ± 10 | Pre
Niehaus^198^ 2003 | All participants | 20 (80) | 60.8 ± 12 | 72 | NR | NR | NR | 28 | NR | 35 ± 14 | Pre
Noseworthy^171^ 2004 | All participants | 169 (80) | 74.9 ± 4.4 | 80 | I or II = 90.1 | NR | NR | NR | NR | 34.1 ± 12.1 | Pre
Parkash^172^ 2006 | All participants | 356 (76) | 65 ± 15 | 62 | ≤ II = 81 | III or IV = 19 | | 31 | NR | 35 ± 16 | Pre
Pires^173^ 2002 | ICD | 1654 (81.5) | 64.4 ± 12.7 | 78 | 55 | III or IV = 19 | | NR | NR | 33.7 ± 13.8 | Pre
Piers^174^ 2006 | All participants | 641 (77) | 65.4 ± 12.7 | 57 | NR | NR | NR | NR | NR | 24.1 ± 10.4
Raitt^175^ 2005 | ICD (placebo arm) | 86 (86) | 62 ± 13 | 71 | 14 | 50 | 8 | NR | NR | 34 ± 15 | Pre
Raviele^176^ 2005 | All participants | 98 (71) | 66.5 ± 9.6 | 100 | NR | NR | Exc | 22 | > 114 msec | 31.1 ± 4.1 | Pre
BEST-ICD
Robin^177^ 2006 | All participants | 462 (79) | 63 ± 15 | 60 | NR | NR | NR | 10 | NR | 33 ± 15 | Pre
Russo^178^ 2003 | All participants | 41 (92) | 70 ± 9 range 41–98 | 100 | NR | NR | NR | NR | NR | 29 ± 9 | Pre
Saba^179^ 2003 | ICD | 29 (82.9) | 51 ± 12 | 20 | Exc | III or IV = 100 | | 17 | NR | 21.9 ± 6.8 | Unclear
| Control | 114 (71.7) | 51 ± 12 | 73 | Exc | III or IV = 100 | | 26 | NR | 22.1 ± 9.7
Saeed^199^ 2003 | All participants | 38 (79) | 64 ± 12 | 63 | 42 | 23 | 0 | NR | NR | 33.6 ± 14.8 | Unclear
Sanchez^180^ 2005 | ICD | 15 (79) | 60 ± 16 | 47 | NR | NR | Exc | NR | NR | 27 ± 7 | Unclear
| Conventional therapy | 26 (81) | 61 ± 13 | 59 | NR | NR | Exc | NR | NR | 27 ± 6
Sanchez^181^ 2006 | All participants | 93 (89) | 66.7 ± 9.3 | 100 | NR | NR | NR | NR | 119 ± 23 | 26.6 ± 7.7 | Pre
Schaer^182^ 2006 | All participants | 50 (86) | 56.4 ± 12.7 | 0 | NR | NR | NR | NR | NR | 25 ± 8.8 | Pre
Sears^183^ 2004 | All participants | 73 (83) | 65 ± 13 | 69 | NR | NR | NR | NR | NR | 30.5 ± 16.4 | Unclear
Strickberger^137^ 2003 | All | 72 (70) | 59 ± 11 | 0 | 64 | 19 | 0 | NR | NR | 22.5 ± 9 | Pre
AMIOVIRT | ICD | 34 (67) | 58 ± 11 | 0 | 64 | 16 | 0 | NR | NR | 22 ± 10
| Amiodarone | 38 (74) | 60 ± 12 | 0 | 63 | 24 | 0 | NR | NR | 23 ± 8
Takahashi^184^ 2002 | All participants | 144 (81) | 64 | 61 | NR | NR | NR | NR | NR | 33 ± 15 | Unclear
Tandri^185^ 2006 | All participants | 1050 (76) | 62 ± 11 | 72 | 38 | III or IV = 23 | | NR | NR | 33 ± 11 | Pre
Telfer^186^ 2002 | ICD | 26 (96) | 59 ± 13 | NR | NR | NR | NR | NR | NR | 22 ± 7 | Pre
Theuns^200^ 2004 | ICD-single | 24 (83) | 57 ± 17 | 72 | NR | NR | NR | 27.6 | NR | 29 ± 11 | Pre
| ICD-dual | 23 (74) | 61 ± 10 | 84 | NR | NR | NR | 22.6 | NR | 31 ± 10
| All participants | 47 (78) | 59 ± 14 | 78 | NR | NR | NR | 25 | NR | 30 ± 10.5
Theuns^201^ 2005a | All participants | 216 (83) | 60 ± 13 | 71 | NR | NR | NR | 29 | NR | 31 ± 14 | Pre
Theuns^187^ 2005b | All participants | 105 (83) | 59 ± 11 | 72 | ≤II = 72 | III or IV = 28 | | 0 | NR | 35 ± 15 | Pre
Tiroke^202^ 2003 | All participants | 136 (91.3) | 62 range 51–72 | 77 | 42 | 38 | 2 | NR | NR | NR | Unclear
Trappe^188^ 2002 | All participants | 368 (89.8) | 57 ± 11 | NR | I or II = 12 II = 37 | II or III = 29 III = 22 | 0 | NR | NR | NR | Pre
Wase^189^ 2004 | ICD | 66 (71) | 66.5 ± 12.2 | NR | NR | NR | NR | NR | NR | 29 ± 12.5 | Pre (at implantation)
Wilkoff^190^ 2006 | All participants | 731 (81.2) | 65 ± 12.6 | 69.4 | ≤II = 47 | III or IV = 14.5 | | 0 | NR | 32.0 ± 12.7 | Post
Zecchin^191^ 2004 | All participants | 43 (79.6) | 52.5 ± 17.2 | 0 | I or II = 76 | NR | NR | NR | NR | 26.5 ± 7.6 | Pre (at implantation)

ICD = implanted cardioverter defibrillator; IQR = interquartile range; NR = not reported

ICD. All patients in the ICD studies had LV systolic dysfunction (mean LVEF ranged from 21 to 28 percent in the primary prevention trials and from 32 to 46 percent in the secondary prevention trials) and the majority had HF symptoms (50 percent had NYHA class II symptoms at baseline, 36 percent NYHA class III symptoms, and 3 percent NYHA Class IV)—11 percent of trial participants were defined as NYHA class I at baseline. The mean age of enrolled patients was 60.8 ± 4.2 years and 74 percent were male. All but three of the primary prevention trials specified other electrocardiographic entry criteria to identify high-risk patients, such as a history of nonsustained ventricular tachycardia,^137,^ ^138^ elevated heart rate or reduced heart rate variability, or abnormal signal-averaged ECG. Although devices were specified to be single-chamber ICD in all but two trials, protocol adherence to single-chamber vs. dual-chamber ICD was not reported in any trial.

### Efficacy, Effectiveness, and Safety of CRT

Efficacy of CRT (Figures 4 to 14 and Table 19 in Evidence Report). CRT improved ejection fraction (WMD = 3.0 percent; 95% CI, 0.9 to 5.1 percent), quality of life (weighted mean reduction in Minnesota Living with Heart Failure Questionnaire 8.0 points [95% CI, 5.6 to 10.4 points]), and function (59 percent of CRT recipients vs. 37 percent of controls improved by at least one NYHA class) in trial participants. The proportion of patients hospitalized for HF was reduced by 37 percent (95% CI, 7 to 57 percent) and all-cause mortality was reduced by 22 percent (95% CI, 9 to 33 percent; Number Needed to Treat to prevent one death over 6 months = 29), driven largely by reductions in progressive HF deaths (RR = 0.64; 95% CI, 0.49 to 0.84).

Table 19 Univariate meta-regression subgroup analyses: CRT

Covariate | All-cause mortality (p-values) | Heart failure hospitalizations (p-values) | Quality of life (p-values)
Presence of ICD | 0.68 | 0.001 | 0.93
Length of followup | 0.28 | 0.17 | 0.14
Ischemic etiology (%) | 0.71 | 0.54 | 0.12
NYHA class IV (%) | 0.85 | 0.26 | 0.55
NYHA class II (%) | 0.76 | 0.003 | 0.31
Mean age (years) | 0.27 | 0.78 | 0.02
Mean LVEF (%) | 0.42 | 0.004 | 0.72
Randomization after implantation | 0.50 | 0.07 | 0.14

Figure 4. Metagraph of all-cause mortality: CRT alone

Figure 14. Funnel plot for all-cause mortality: CRT alone

Within the CRT trials, there was no consistent pattern of definitive differences in effects for different subgroups. Isolated trials reported greater effects in patients with longer QRS duration,^12^ patients with septal coronary sinus leads implanted outside of the anterolateral region,^215^ and patients with nonischemic disease,^216^ but these findings were either based on small numbers of patients or not confirmed in other studies.^9,^ ^11,^ ^15^ None of the CRT trials, however, were powered to detect subgroup effects of small to moderate magnitude. In univariate meta-regressions using trial-level data, no single factor was associated with the magnitude of CRT mortality benefit. Three factors suggestive of less severe HF—presence of an ICD in both controls and CRT patients, NYHA class II at baseline, and higher LVEF—were significantly associated with smaller CRT effects on HF hospitalizations (see Table 19 in main report). These analyses, however, are also underpowered to detect subgroup differences in the efficacy of CRT.

The efficacy of combination CRT-ICD devices and CRT-only devices appeared similar, based on meta-regression of aggregate trial data and indirect comparisons (i.e., comparisons between trials with different comparators but similar control groups). However, in the absence of head-to-head trials comparing the two devices, this conclusion should not be considered definitive. Two of the treatment arms of the COMPANION trial^11^ provide the only opportunity to compare combined CRT-ICD devices vs. CRT alone devices within the same trial, but this was not a primary pre-specified aim of this trial. Although the mortality benefits were slightly greater with the CRT-ICD device (hazard ratio [HR] = 0.64; 95% CI, 0.48 to 0.86) than with CRT alone (HR = 0.76; 95% CI, 0.58 to 1.01), this difference was not statistically significant (p=0.13) and HF hospitalizations did not differ between patients receiving the combined CRT-ICD device compared to those receiving the CRT alone device. ^11^ In the highest risk subgroup of COMPANION (NYHA class IV patients), the time to death analysis did not demonstrate any benefit of the CRT-ICD device over the CRT alone device (HR = 1.27; 95% CI 0.68 to 2.37).^6^

Effectiveness of CRT (Figures 4 to 14, Figures 22 and 24, and Table 21 in Evidence Report). Survival during follow-up was similar in the randomized trials and the observational studies for patients who received CRT devices. The pooled effectiveness estimates from the observational studies were consistent with our findings from the efficacy trials. For example, in the RCTs, 59 percent of patients implanted with a CRT device improved by at least one NYHA class and in the observational studies between 63 and 82 percent of CRT recipients improved by at least one NYHA class. No covariates were consistently shown across studies to predict CRT response. Only one observational study compared outcomes in patients with CRT to outcomes in contemporaneous controls without CRT - their findings of improved LVEF (WMD = 4.6 percent; 95% CI, 2.9 to 6.3 percent) and lower mortality rates (RR = 0.64; 95% CI, 0.26 to 1.56) in the CRT arm were consistent in magnitude to the findings from our meta-analysis of the CRT trials.

Table 21 Response rates reported in observational studies: CRT alone or combined CRT-ICD devices

Author Year | Definition of responder | Followup | Sample size | Proportion of responders, % | Independent predictors of positive response
Functional definition of response
CRT alone
Bleeker^30^ 2005a | Improved ≥ 1 NYHA class | 6 mo. | 170 | 78 | Analysis by age < 70 vs. ≥ 70 yrs. (NS)
Chan^43^ 2003 | 6MWT increased 10% | 3 mo. | 63 | 67 | Not done
Lecoq^68^ 2004 | Alive, no CHF hospitalizations, improved ≥ 70 yrs. (NS) 1 NYHA class or 10% increase VO_2_ max during 6MWT | 6 mo. | 139 | 72 | Δ QRS (step of 20 msec)
Lenom^69^ 2005 | Improved NYHA class | 6 mo. | 36 | 71 | Not done
Molhoek^82^ 2005 | Improved ≥ 1 NYHA class | 6 mo. | 74 | 68 | Analysis by etiology (NS)
Sawhney^105^ 2004 | Improved ≥ 1 NYHA class | 3 mo. | 40 | 63 | Acute response to CRT by aortic Doppler VTI
Stahlberg^108^ 2005 | Alive, no CHF hospitalizations, improved ≥ 1 NYHA class and/or 10% increase in 6MWT distance | 6 mo. | 35 | 66 | Not done
Combined CRT-ICD
Alonso^21^ 1999 | Alive, improved ≥ 1 NYHA class, 10% increase in peak VO_2_ | 6 mo. | 26 | 73 | Not done
Bax^29^ 2004 | Improved ≥ 1 NYHA class, improved 6MWT ≥ 25% | 6 mo. | 85 | 74 | Baseline LV dyssynchrony of ≥ 65ms
Diaz-Infante^49^ 2005 | Alive, no heart transplant, 10% increase in 6MWT | 6 mo. | 143 | 80 | Etiology, mitral regurgitation, LVEDD < 75mm
Hernandez^59^ 2004 | Improved 6MWT ≥ 10% | 6 mo. | 28 | 79 | BNP level, etiology, baseline NYHA
Kies^61^ 2005 | Improved ≥ 1 NYHA class | 6 mo. | 97 | 74 | Analysis by diabetes mellitus vs. no diabetes mellitus (NS)
Molhoek^79^ 2004a | Improved ≥ 1 NYHA class | 6 mo. | 60 | 72 | Not done
Molhoek^80^ 2004b | Improved ≥ 1 NYHA class | 6 mo. | 117 | 78 | NYHA = III vs. IV
Molhoek^81^ 2004c | Improved ≥ 1 NYHA class | 6 mo. | 61 | 74 | Analysis by baseline QRS (NS)
Reuter^100^ 2002 | Improved NYHA class associated with improved QOL score | 12 mo. | 102 | 82 | Etiology, cardiac output
Echocardiographic definition of response
CRT alone
Bax^28^ 2003 | Absolute Increase in LVEF ≥ 5% | 6 mo. | 25 | 68 | Septal to lateral delay
Penicka^93^ 2004 | Relative Increase in LVEF ≥ 25% | 6 mo. | 49 | 55 | Tissue doppler imaging derived indices of asynchrony
Yu^118^ 2002a | LV reverse modeling (reduction in LV end-systolic volume > 10%) | 3–6 mo. | 141 | 62 | Reduced LVESV ≥ 9.5% (significant predictor of all-cause mortality)
Multiple definitions of response
CRT alone
Mascioli^76^ 2002 | Improved ≥ 1 NYHA class, LVEF increased by ≥ 10% | 6 mo. | 68 | 69 | Analysis performed but none found
Yu^120^ 2004 | LV reverse modeling (reduction in LV end-systolic volume > 15%) | 3 mo. | 30 | 57 | Systolic dyssynchrony by tissue doppler imaging
Combined CRT-ICD
Notabartolo^88^ 2004 | 2 of 3: Improved ≥ 1 NYHA class; > 50 meter increase in 6MWT; decrease QOL score = 15 pts; or reduction in LV end-systolic volume >15% | 3 mo. | 49 | Echocardiographic response =59 clinical response = 75 | PVD predicted echocardiographic response; no significant predictors of clinical response

CRT = cardiac resynchronization therapy; CRT+ICD = CRT with implanted cardioverter defibrillator; LV = left ventricular; LVEF = left ventrular ejection fraction; NS = not significant; NYHA = New York Heart Association class; QOL = Quality of life; 6MWT = 6-minute walk test; VO_2_ max = maximal oxygen consumption

Figure 22. Scatter plot of all-cause mortality vs. length of followup: CRT alone

Figure 24. Scatter plot of all-cause mortality vs. length of followup: combined CRT-ICD devices

Safety of CRT (Tables 22 and 23 in Evidence Report). Implant success rate was 93 percent (95% CI, 92.2 to 93.7 percent) and peri-implant deaths occurred in 0.3 percent (95% CI, 0.1 to 0.6 percent) of individuals, with no appreciable differences either between those receiving CRT alone or combined CRT-ICD devices, or between participants in RCTs and observational studies. Over a median 11-month follow-up, lead problems occurred in 6.6 percent (95% CI, 5.6 to 7.4 percent) of CRT devices and 5 percent (95% CI, 4 to 7 percent) of these devices malfunctioned. Frequencies were similar in the RCTs and observational studies, and combined CRT-ICD devices demonstrated similar frequencies of device malfunction (5 percent; 95% CI, 4 to 6 percent) and lead problems (5.9 percent; 95% CI, 5 to 6.9 percent).

Table 22 Peri- and post-implantation risks: CRT alone

Trial name, Author Study year | n/N | Simple pool risk, % [95% CI]
Peri-implant deaths: RCT
COMPANION^11^ 2004 | 2/699 | 0.3 [0.0, 1.0]
MUSTIC-AF^7^ 2002 | 0/59 | 0.0 [0.0, 5.0]
MUSTIC-SR^5^ 2001 | 1/58 | 1.7 [0.0, 9.2]
PATH-CHF^8^ 2002a | 0/41 | 0.0 [0.0, 7.0]
Sub-Total: | 3/857 | 0.4 [0.1, 1.0]
Peri-implant deaths: Observational studies
Bleeker^31^ 2005b | 0/56 | 0.0 [0.0, 5.2]
Bordachar^35^ 2004 | 0/41 | 0.0 [0.0, 7.0]
Cazeau^41^ 2003 | 0/66 | 0.0 [0.0, 4.4]
Daubert^46^ 1998 | 0/47 | 0.0 [0.0, 6.2]
De Martino^125^ 2004 | 0/34 | 0.0 [0.0, 8.4]
Galvao^56^ 2002 | 3/28 | 10.7 [2.3, 28.2]
Kautzner^128^ 2004 | 0/46 | 0.0 [0.0, 6.3]
Koos^63^ 2004 | 0/81 | 0.0 [0.0, 3.6]
Leclercq^67^ 2002b | 0/139 | 0.0 [0.0, 2.1]
Lecoq^68^ 2005 | 0/158 | 0.0 [0.0, 1.9]
Leon^70^ 2005 | 1/422 | 0.2 [0.0, 1.3]
Mair^73^ 2005 | 0/80 | 0.0 [0.0, 3.7]
Molhoek^79^ 2004a | 0/74 | 0.0 [0.0, 4.0]
Nagele^85^ 2001 | 0/32 | 0.0 [0.0, 8.9]
Niu^87^ 2006 | 0/117 | 0.0 [0.0, 2.5]
Ollitrault^91^ 2003 | 0/62 | 0.0 [0.0, 4.7]
Penicka^93^ 2004 | 1/55 | 1.8 [0.0, 9.7]
Schuchert^132^ 2004 | 0/102 | 0.0 [0.0, 2.9]
Stahlberg^108^ 2005 | 0/40 | 0.0 [0.0, 7.2]
Toussaint^113^ 2003 | 0/34 | 0.0 [0.0, 8.4]
Sub Total | 5/1714 | 0.3 [0.1, 0.7]
Total [N=24] | 8/2571 | 0.3 [0.1, 0.6]
Implant success rate: RCT
COMPANION^11^ 2004 | 617/699 | 88.3 [85.6, 90.6]
MIRACLE^4^ 2002 | 528/571 | 92.5 [90.0, 94.5]
MUSTIC-AF^7^ 2002 | 54/59 | 91.5 [81.3, 97.2]
MUSTIC-SR^5^ 2001 | 58/64 | 90.6 [80.7, 96.5]
PATH-CHF^8^ 2002a | 41/41 | 100.0 [93.0, 100.0]
PATH-CHF II^12^ 2003 | 86/89 | 96.6 [90.5, 99.3]
Sub-Total: | 1384/1523 | 90.9 [89.3, 92.3]
Implant success rate: Observational studies
Albertsen^20^ 2005 | 120/120 | 100.0 [97.5, 100.0]
Baker^27^ 2002 | 54/60 | 90.0 [79.5, 96.2]
Bleeker^30^ 2005a | 170/170 | 100.0 [98.3, 100.0]
Bleeker^31^ 2005b | 56/56 | 100.0 [94.8, 100.0]
Bleeker^32^ 2006 | 100/100 | 100.0 [97.0, 100.0]
Bordachar^35^ 2004 | 41/41 | 100.0 [93.0, 100.0]
Daubert^46^ 1998 | 35/47 | 74.5 [59.7, 86.1]
De Martino^126^ 2005 | 82/83 | 98.8 [93.5, 100.0]
De Martino^125^ 2004 | 30/34 | 88.2 [72.5, 96.7]
Dixon^50^ 2004 | 27/27 | 100.0 [89.5, 100.0]
Galvao^56^ 2002 | 28/28 | 100.0 [89.9, 100.0]
Gras^58^ 2002 | 125/139 | 89.9 [83.7, 94.4]
Hua^60^ 2006 | 142/149 | 95.3 [90.6, 98.1]
Kautzner^128^ 2004 | 42/46 | 91.3 [79.2, 97.6]
Leclercq^67^ 2002b | 125/139 | 89.9 [83.7, 94.4]
Lecoq^68^ 2005 | 139/158 | 88.0 [81.9, 92.6]
Leon^70^ 2005 | 397/422 | 94.1 [91.4, 96.1]
Lewika-Nowak^129^ 2005 | 80/92 | 87.0 [78.3, 93.1]
Mair^73^ 2005 | 80/80 | 100.0 [96.3, 100.0]
Mascioli^76^ 2002 | 95/96 | 99.0 [94.3, 100.0]
Molhoek^80^ 2004b | 74/74 | 100.0 [96.0, 100.0]
Molhoek^78^ 2002 | 40/40 | 100.0 [92.8, 100.0]
Mortensen^83^ 2004 | 189/198 | 95.5 [91.5, 97.9]
Nagele^85^ 2001 | 28/32 | 87.5 [71.0, 96.5]
Niu^87^ 2006 | 111/117 | 94.9 [89.2, 98.1]
O'Donnell^89^ 2005 | 58/63 | 92.1 [82.4, 97.4]
Ollitrault^91^ 2003 | 38/62 | 61.3 [48.1, 73.4]
Penicka^93^ 2004 | 53/55 | 96.4 [87.5, 99.6]
Romeyer-Bouchard^131^ 2005 | 99/103 | 96.1 [90.4, 98.9]
Sawhney^105^ 2004 | 40/40 | 100.0 [92.8, 100.0]
Schuchert^132^ 2004 | 96/102 | 94.1 [87.6, 97.8]
Stahlberg^108^ 2005 | 35/40 | 87.5 [73.2, 95.8]
Tousaint^113^ 2003 | 34/34 | 100.0 [91.6, 100.0]
Yu^119^ 2002b | 30/30 | 100.0 [90.5, 100.0]
Yu^118^ 2002a | 25/25 | 100.0 [88.7, 100.0]
Sub-Total: | 2918/3102 | 94.1 [93.2, 94.9]
Total [N=41] | 4302/4625 | 93.0 [92.2, 93.7]
Implantation mechanical complication: RCT
CARE-HF^15^ 2005 | 16/409 | 3.9 [2.3, 6.3]
COMPANION^11^ 2004 | 12/617 | 1.9 [1.0, 3.4]
PATH CHF II^12^ 2003 | 6/98 | 6.1 [2.3, 12.9]
Sub-Total: | 34/1124 | 3.0 [2.1, 4.2]
Implantation mechanical complication: Observational studies
Albertsen^20^ 2005 | 2/120 | 1.7 [0.2, 5.9]
Baker^27^ 2002 | 1/60 | 1.7 [0.0, 8.9]
de Cock^124^ 2004 | 7/103 | 6.8 [2.8, 13.5]
De Martino^126^ 2005 | 4/83 | 4.8 [1.3, 11.9]
De Martino^125^ 2004 | 4/34 | 11.8 [.3, 27.5]
Dixon^50^ 2004 | 0/27 | 0.0 [0.0, 10.5]
Kautzner^128^ 2004 | 9/46 | 19.6 [9.4, 33.9]
Koos^63^ 2004 | 3/81 | 3.7 [0.8, 10.4]
Lecoq^68^ 2005 | 2/102 | 2.0 [0.2, 6.9]
Lenom^69^ 2005 | 1/36 | 2.8 [0.1, 14.5]
Leon^70^ 2005 | 28/422 | 6.6 [4.5, 9.4]
Mortensen^83^ 2004 | 3/189 | 1.6 [0.3, 4.6]
Nagele^85^ 2001 | 7/32 | 21.9 [9.3, 40.0]
Niu^87^ 2006 | 9/117 | 7.7 [3.6, 14.1]
Puglisi^97^ 2004 | 10/315 | 3.2 [1.5, 5.8]
Purnode^98^ 2004 | 1/43 | 2.3 [0.1, 12.3]
Romeyer-Bouchard^131^ 2005 | 1/103 | 1.0 [0.0, 5.3]
Schuchert^132^ 2004 | 10/102 | 9.8 [4.8, 17.3]
Sub Total | 102/2015 | 5.1 [4.1, 6.1]
Total [N=21] | 136/3139 | 4.3 [3.6, 5.1]
Post-implant mechanical malfunction: RCT
CARE-HF^15^ 2005 | 8/409 | 2.0 [0.8, 3.8]
MUSTIC-AF^7^ 2002 | 2/54 | 3.7 [0.5, 12.7]
MUSTIC-SR^5^ 2001 | 2/58 | 3.4 [0.4, 11.9]
Sub-Total | 12/521 | 2.3 [1.2, 4.0]
Post-implant mechanical malfunction: Observational studies
Dixon^50^ 2004 | 0/27 | 0.0 [0.0, 10.5]
Gras^58^ 2002 | 4/103 | 3.9 [1.1, 9.6]
Koos^63^ 2004 | 1/81 | 1.2 [0.0, 6.7]
Leclercq^66^ 2000 | 3/37 | 8.1 [1.7, 21.9]
Leclercq^67^ 2002b | 25/125 | 20.0 [13.4, 28.1]
Leon^70^ 2005 | 8/422 | 1.9 [0.8, 3.7]
Sub Total | 41/795 | 5.2 [3.7, 6.9]
Total [N=9] | 53/1316 | 4.0 [3.0, 5.2]
Post-implant device malfunction: RCT
MUSTIC-SR^5^ 2001 | 2/67 | 3.0 [0.4, 10.4]
VECTOR^16^ 2005 | 11/120 | 9.2 [4.7, 15.8]
Kindermann^13^ 2006 | 1/30 | 3.3 [0.1, 17.2]
Sub-Total: | 14/217 | 6.5 [3.6, 10.6]
Post-implant device malfunction: Observational studies
Albertsen^20^ 2005 | 11/120 | 9.2 [4.7, 15.8]
Bordachar^35^ 2004 | 1/41 | 2.4 [0.1, 12.9]
Braun^39^ 2005 | 1/65 | 1.5 [0.0, 8.3]
Chalil^42^ 2006 | 0/75 | 0.0 [0.0, 3.9]
Dixon^50^ 2004 | 0/27 | 0.0 [0.0, 10.5]
Galvao^56^ 2002 | 3/28 | 10.7 [2.3, 28.2]
Kautzner^128^ 2004 | 2/46 | 4.3 [0.5, 14.8]
Lecoq^68^ 2005 | 18/102 | 17.6 [10.8, 26.4]
Lenom^69^ 2005 | 1/36 | 2.8 [0.1, 14.5]
Lewicka-Nowak^129^ 2005 | 2/92 | 2.2 [0.3, 7.6]
Mortensen^83^ 2004 | 2/189 | 1.1 [0.1, 3.8]
Ollitrault^91^ 2003 | 2/62 | 3.2 [0.4, 11.2]
Penicka^93^ 2004 | 1/55 | 1.8 [0.0, 9.7]
Purnode^98^ 2004 | 1/43 | 2.3 [0.1, 12.3]
Romeyer-Bouchard^131^ 2005 | 1/10 | 10.0 [0.3, 44.5]
Schuchert^132^ 2004 | 8/96 | 8.3 [3.7, 15.8]
Stahlberg^108^ 2005 | 4/35 | 11.4 [3.2, 26.7]
Sub Total | 58/1122 | 5.2 [3.9, 6.6]
Total [N=20] | 72/1339 | 5.4 [4.2, 6.7]
Post-implant lead problems: RCT
CARE-HF^15^ 2005 | 24/409 | 5.9 [3.8, 8.6]
MIRACLE^4^ 2002 | 30/524 | 5.7 [3.9, 8.1]
MUSTIC-AF^7^ 2002 | 5/54 | 9.3 [3.1, 20.3]
MUSTIC-SR^5^ 2001 | 8/67 | 11.9 [5.3, 22.2]
VECTOR^16^ 2005 | 8/120 | 6.7 [2.9, 12.7]
Kindermann^13^ 2006 | 2/30 | 6.7 [0.8, 22.1]
Sub-Total: | 77/1204 | 6.4 [5.1, 7.9]
Post-implant lead problems: Observational studies
Albertsen^20^ 2005 | 6/120 | 5.0 [1.9, 10.6]
Baker^27^ 2002 | 1/60 | 1.7 [0.0, 8.9]
Braun^39^ 2005 | 1/65 | 1.5 [0.0, 8.3]
Chalil^42^ 2006 | 5/75 | 6.7 [2.2, 14.9]
Dixon^50^ 2004 | 0/27 | 0.0 [0.0, 10.5]
Galvao^56^ 2002 | 1/28 | 3.6 [0.1, 18.3]
Gras^58^ 2002 | 10/103 | 9.7 [4.8, 17.1]
Kautzner^128^ 2004 | 5/46 | 10.9 [3.6, 23.6]
Koos^63^ 2004 | 18/81 | 22.2 [13.7, 32.8]
Leclercq^66^ 2000 | 2/37 | 5.4 [0.7, 18.2]
Leclercq^67^ 2002b | 15/125 | 12.0 [6.9, 19.0]
Lecoq^68^ 2005 | 7/102 | 6.9 [2.8, 13.6]
Lenom^69^ 2005 | 1/36 | 2.8 [0.1, 14.5]
Leon^70^ 2005 | 22/422 | 5.2 [3.3, 7.8]
Lewicka-Nowak^129^ 2005 | 12/92 | 13.0 [6.9, 21.7]
Molhoek^78^ 2002 | 3/40 | 7.5 [1.6, 20.4]
Mortensen^83^ 2004 | 12/189 | 6.3 [3.3, 10.8]
Nagele^85^ 2001 | 2/32 | 6.3 [0.8, 20.8]
Niu^87^ 2006 | 2/117 | 1.7 [0.2, 6.0]
Ollitrault^91^ 2003 | 2/62 | 3.2 [0.4, 11.2]
Puglisi^97^ 2004 | 12/315 | 3.8 [2.0, 6.6]
Purnode^98^ 2004 | 1/43 | 2.3 [0.1, 12.3]
Romeyer-Bouchard^131^ 2005 | 7/103 | 6.8 [2.8, 13.5]
Sawhney^105^ 2004 | 2/40 | 5.0 [0.6, 16.9]
Stahlberg^108^ 2005 | 4/35 | 11.4 [3.2, 26.7]
Taieb^109^ 2002 | 10/50 | 20.0 [10.0, 33.7]
Sub Total | 163/2445 | 6.7 [5.7, 7.7]
Total [N=32] | 240/3649 | 6.6 [5.8, 7.4]
Post-implant infections: RCT
MIRACLE^4^ 2002 | 7/524 | 1.3 [0.5, 2.7]
Sub-Total: | 7/524 | 1.3 [0.5, 2.7]
Post-implant infections: Observational studies
Albertsen^20^ 2005 | 3/120 | 2.5 [0.5, 7.1]
Baker^27^ 2002 | 3/60 | 5.0 [1.0, 13.9]
Daubert^46^ 1998 | 0/47 | 0.0 [0.0, 6.2]
Dixon^50^ 2004 | 0/26 | 0.0 [0.0, 10.9]
Galvao^56^ 2002 | 1/28 | 3.6 [0.1, 18.3]
Gras^58^ 2002 | 2/103 | 1.9 [0.2, 6.8]
Koos^63^ 2004 | 0/79 | 0.0 [0.0, 3.7]
Leclercq^67^ 2002b | 15/125 | 12.0 [6.9, 19.0]
Leon^70^ 2005 | 3/422 | 0.7 [0.1, 2.1]
Lewicka-Nowak^129^ 2005 | 1/92 | 1.1 [0.0, 5.9]
Mortensen^83^ 2004 | 0/189 | 0.0 [0.0, 1.6]
Ollitrault^91^ 2003 | 1/38 | 2.6 [0.1, 13.8]
Romeyer-Bouchard^131^ 2005 | 1/99 | 1.0 [0.0, 5.5]
Schuchert^132^ 2004 | 0/102 | 0.0 [0.0, 2.9]
Toussaint^113^ 2003 | 1/34 | 2.9 [0.1, 15.3]
Sub Total | 31/1564 | 2.0 [1.4, 2.8]
Total [N=16] | 38/2088 | 1.8 [1.3, 2.5]
Post-implant arrhythmias: RCT
CARE-HF^15^ 2005 | 64/409 | 15.6 [12.3, 19.5]
MUSTIC-AF^7^ 2002 | 1/54 | 1.9 [0.0, 9.9]
PATH-CHF^8^ 2002a | 4/41 | 9.8 [2.7, 23.1]
PATH-CHF II^12^ 2003 | 2/86 | 2.3 [0.3, 8.1]
Sub-Total: | 71/590 | 12.0 [9.5, 14.9]
Post-implant arrhythmias: Observational studies
Dixon^50^ 2004 | 0/27 | 0.0 [0.0, 10.5]
Koos^63^ 2004 | 7/81 | 8.6 [3.5, 17.0]
Molhoek^78^ 2002 | 1/40 | 2.5 [0.1, 13.2]
Sub Total | 8/148 | 5.4 [2.4, 10.4]
Total [N=7] | 79/738 | 10.7 [8.6, 13.2]

RCT=randomized control trial

Table 23 Peri- and post-implantation risks: combined CRT-ICD devices

Study, Author Year | n/N | Simple pool risk, % [95% CI]
Peri-implant deaths: RCT
COMPANION^11^ 2004 | 3/595 | 0.5 [0.1, 1.5]
CONTAK-CD^9^ 2003 | 2/490 | 0.4 [0.0, 1.5]
Sub-Total | 5/1085 | 0.5 [0.1, 1.1]
Peri-implant deaths: Observational studies
Ammann^22^ 2004 | 0/43 | 0.0 [0.0, 6.7]
Azizi^26^ 2006 | 0/244 | 0.0 [0.0, 1.2]
Bax^29^ 2004 | 0/85 | 0.0 [0.0, 3.5]
Bocchiardo^33^ 2000 | 0/48 | 0.0 [0.0, 6.1]
Cowburn^44^ 2005 | 0/68 | 0.0 [0.0, 4.3]
Da Costa^45^ 2006 | 0/67 | 0.0 [0.0, 4.4]
de Sisti^48^ 2005 | 0/102 | 0.0 [0.0, 2.9]
Diaz-Infante^49^ 2005 | 2/147 | 1.4 [0.2, 4.8]
Ellery^52^ 2005 | 0/85 | 0.0 [0.0, 3.5]
Ermis^53^ 2004 | 0/62 | 0.0 [0.0, 4.7]
Molhoek^81^ 2004c | 0/61 | 0.0 [0.0, 4.8]
Navia^86^ 2005 | 0/41 | 0.0 [0.0, 7.0]
Pitzalis^94^ 2005 | 0/63 | 0.0 [0.0, 4.6]
Reuter^100^ 2002 | 0/102 | 0.0 [0.0, 2.9]
Salukhe^104^ 2005 | 0/40 | 0.0 [0.0, 7.2]
Saxon^106^ 2006 | 5/168 | 3.0 [1.0, 6.8]
Teo^111^ 2003 | 0/29 | 0.0 [0.0, 9.8]
Ypenburg^117^ 2006 | 1/191 | 0.5 [0.0, 2.9]
Sub Total | 8/1646 | 0.5 [0.2, 1.0]
Total [N=20] | 13/2731 | 0.5 [0.3, 0.8]
Implant success rate: RCT
COMPANION^11^ 2004 | 541/595 | 90.9 [88.3, 93.1]
CONTAK-CD^9^ 2003 | 501/501 | 100.0 [99.4, 100.0]
MIRACLE-ICD^6^ 2003 | 379/429 | 88.3 [84.9, 91.2]
Sub-Total | 1421/1525 | 93.2 [91.8, 94.4]
Implant success rate: Observational studies
Ammann^22^ 2004 | 43/47 | 91.5 [79.6, 97.6]
Azizi^26^ 2006 | 240/244 | 98.4 [95.9, 99.6]
Bax^29^ 2004 | 85/85 | 100.0 [96.5, 100.0]
Bocchiardo^33^ 2000 | 48/51 | 94.1 [83.8, 98.8]
Boriani^36^ 2006a | 118/127 | 92.9 [87.0, 96.7]
Cowburn^44^ 2005 | 63/68 | 92.6 [83.7, 97.6]
Da Costa^45^ 2006 | 68/71 | 95.8 [88.1, 99.1]
Diaz-Infante^49^ 2005 | 147/177 | 83.1 [76.7, 88.3]
Ellery^52^ 2005 | 85/96 | 88.5 [80.4, 94.1]
Ermis^53^ 2004 | 126/158 | 79.7 [72.6, 85.7]
Gasparini^57^ 2003a | 158/159 | 99.4 [96.5, 100.0]
Krahn^64^ 2002 | 40/45 | 88.9 [75.9, 96.3]
Kuhlkamp^270^ 2002 | 81/84 | 96.4 [89.9, 99.3]
Molhoek^82^ 2005 | 125/125 | 100.0 [97.6, 100.0]
Molhoek^81^ 2004c | 61/61 | 100.0 [95.2, 100.0]
Navia^86^ 2005 | 41/41 | 100.0 [93.0, 100.0]
Pitzalis^94^ 2005 | 63/65 | 96.9 [89.3, 99.6]
Pürerfellner^130^ 2000a | 36/44 | 81.8 [67.3, 91.8]
Pürerfellner^130^ 2000b | 135/150 | 90.0 [84.0, 94.3]
Reuter^100^ 2002 | 89/102 | 87.3 [79.2, 93.0]
Ritter^102^ 2006 | 48/48 | 100.0 [93.9, 100.0]
Rossillo^103^ 2004 | 233/244 | 95.5 [92.1, 97.7]
Salukhe^104^ 2005 | 40/40 | 100.0 [92.8, 100.0]
Teo^111^ 2003 | 29/29 | 100.0 [90.2, 100.0]
Theuns^112^ 2005 | 86/86 | 100.0 [96.6, 100.0]
Ypenburg^117^ 2006 | 191/191 | 100.0 [98.4, 100.0]
Sub-Total: | 2479/2638 | 94.0 [93.0, 94.9]
Total [N=28] | 3900/4163 | 93.7 [92.9, 94.4]
Implantation mechanical complication: RCT
COMPANION^11^ 2004 | 10/595 | 1.7 [0.8, 3.1]
MIRACLE ICD II^14^ 2004 | 6/210 | 2.9 [1.1, 6.1]
RHYTHM-ICD^17^ 2005 | 33/205 | 16.1 [11.3, 21.9]
Sub-Total: | 49/1010 | 4.9 [3.6, 6.4]
Implantation mechanical complication: Observational studies
Ammann^22^ 2004 | 1/47 | 2.1 [0.1, 11.3]
Azizi^26^ 2006 | 13/285 | 4.6 [2.5, 7.7]
Boriani^36^ 2006a | 3/121 | 2.5 [0.5, 7.1]
Pürerfellner^130^ 2000a | 2/44 | 4.5 [0.6, 15.5]
RHYTHM ICD^17^ 2005 | 8/162 | 4.9 [2.2, 9.5]
Teo^111^ 2003 | 1/29 | 3.4 [0.1, 17.8]
Ypenburg^117^ 2006 | 9/191 | 4.7 [2.2, 8.8]
Sub Total | 37/879 | 4.2 [3.0, 5.8]
Total [N=10] | 86/1889 | 4.6 [3.7, 5.6]
Post-implant mechanical malfunction: RCT
CONTAK-CD^9^ 2003 | 22/448 | 4.9 [3.1, 7.3]
MIRACLE-ICD^6^ 2003 | 25/364 | 6.9 [4.5, 10.0]
Sub-Total: | 47/812 | 5.8 [4.3, 7.6]
Post-implant mechanical malfunction: Observational studies
Kuhlkamp^270^ 2002 | 1/84 | 1.2 [0.0, 6.5]
Pürerfellner^130^ 2000a | 1/44 | 2.3 [0.1, 12.0]
RHYTHM ICD^17^ 2005 | 2/162 | 1.2 [0.1, 4.4]
Sub Total | 4/290 | 1.4 [0.4, 3.5]
Total [N=5] | 51/1102 | 4.6 [3.5, 6.0]
Post-implant device malfunction: RCT
RHYTHM-ICD^17^ 2005 | 20/205 | 9.8 [6.1, 14.7]
Sub-Total: | 20/205 | 9.8 [6.1, 14.7]
Post-implant device malfunction: Observational studies
Azizi^26^ 2006 | 5/285 | 1.8 [0.6, 4.0]
Bocchiardo^33^ 2000 | 2/42 | 4.8 [0.6, 16.2]
Boriani^36^ 2006a | 8/121 | 6.6 [2.9, 12.6]
Ellery^52^ 2005 | 7/95 | 7.4 [3.0, 14.6]
Gasparini^57^ 2003a | 2/142 | 1.4 [0.2, 5.0]
RHYTHM ICD^17^ 2005 | 25/162 | 15.4 [10.2, 21.9]
Saxon^106^ 2006 | 1/168 | 0.6 [0.0, 3.3]
Ypenburg^117^ 2006 | 1/191 | 0.5 [0.0, 2.9]
Sub Total | 51/1206 | 4.2 [3.2, 5.5]
Total [N=9] | 71/1411 | 5.0 [4.0, 6.3]
Post-implant lead problems: RCT
CONTAK-CD^9^ 2003 | 31/448 | 6.9 [4.7, 9.7]
MIRACLE ICD^6^ 2003 | 46/364 | 12.6 [9.4, 16.5]
MIRACLE ICD II^14^ 2004 | 19/191 | 9.9 [6.1, 15.1]
RHYTHM ICD^17^ 2005 | 22/205 | 10.7 [6.8, 15.8]
Sub-Total: | 118/1208 | 9.8 [8.2, 11.6]
Post-implant lead problems: Observational studies
Ammann^22^ 2004 | 3/47 | 6.4 [1.3, 17.5]
Azizi^26^ 2006 | 13/285 | 4.6 [2.5, 7.7]
Bocchiardo^33^ 2000 | 3/42 | 7.1 [1.5, 19.5]
Boriani^36^ 2006a | 31/121 | 25.6 [18.1, 34.4]
Cowburn^44^ 2005 | 4/68 | 5.9 [1.6, 14.4]
Da Costa^45^ 2006 | 3/67 | 4.5 [0.9, 12.5]
Diaz-Infante^49^ 2005 | 2/177 | 1.1 [0.1, 4.0]
Ellery^52^ 2005 | 5/95 | 5.3 [1.7, 11.9]
Ermis^53^ 2004 | 1/126 | 0.8 [0.0, 4.3]
RHYTHM ICD^17^ 2005 | 4/162 | 2.5 [0.7, 6.2]
Gasparini^127^ 2005 | 5/194 | 2.6 [0.8, 5.9]
Krahn^64^ 2002 | 4/40 | 10.0 [2.8, 23.7]
Kuhlkamp^270^ 2002 | 7/84 | 8.3 [3.4, 16.4]
Molhoek^82^ 2005 | 10/117 | 8.5 [4.2, 15.2]
Pürerfellner^130^ 2005a | 4/44 | 9.1 [2.5, 21.7]
Pürerfellner^130^ 2005b | 1/150 | 0.7 [0.0, 3.7]
Reuter^100^ 2002 | 4/91 | 4.4 [1.2, 10.9]
Ritter^102^ 2006 | 7/48 | 14.6 [6.1, 27.8]
Salukhe^104^ 2005 | 2/40 | 5.0 [0.6, 16.9]
Saxon^106^ 2006 | 11/168 | 6.5 [3.3, 11.4]
Teo^111^ 2003 | 2/29 | 6.9 [0.8, 22.8]
Sub Total | 126/2195 | 5.7 [4.8, 6.8]
Total [N=25] | 244/3403 | 7.2 [6.3, 8.1]
Post-implant infections: RCT
CONTAK CD^9^ (Knight 2004) | 5/443 | 1.1 [0.4, 2.6]
MIRACLE-ICD^6^ 2003 | 2/364 | 0.5 [0.1, 2.0]
Sub-Total: | 7/807 | 0.9 [0.3, 1.8]
Post-implant infections: Observational studies
Azizi^26^ 2006 | 2/285 | 0.7 [0.1, 2.5]
Cowburn^44^ 2005 | 1/68 | 1.5 [0.0, 7.9]
Da Costa^45^ 2006 | 1/67 | 1.5 [0.0, 8.0]
Ellery^52^ 2005 | 0/85 | 0.0 [0.0, 3.5]
Kuhlkamp^270^ 2002 | 2/84 | 2.4 [0.3, 8.3]
Molhoek^82^ 2005 | 0/125 | 0.0 [0.0, 2.4]
Reuter^100^ 2002 | 0/102 | 0.0 [0.0, 2.9]
Saxon^106^ 2006 | 7/168 | 4.2 [1.7, 8.4]
Sub Total | 13/984 | 1.3 [0.7, 2.2]
Total [N=10] | 20/1791 | 1.1 [0.7, 1.7]
Post-implant arrhythmias: RCT
CONTAK-CD^9^ 2003 | 36/245 | 14.7 [10.5, 19.8]
MIRACLE-ICD^6^ 2003 | 3/364 | 0.8 [0.2, 2.4]
Total [N=2] | 39/609 | 6.4 [4.6, 8.7]
Inappropriate shocks: RCT
RHYTHM ICD^17^ 2005 | 10/205 | 4.9 [2.4, 8.8]
Sub-Total: | 10/205 | 4.9 [2.4, 8.8]
Inappropriate shocks: Observational studies
Bocchiardo^33^ 2000 | 6/42 | 14.3 [5.4, 28.5]
Boriani^36^ 2006 | 4/121 | 3.3 [0.9, 8.2]
Chugh^123^ 2005 | 12/77 | 15.6 [8.3, 25.6]
Ermis^53^ 2004 | 3/62 | 4.8 [1.0, 13.5]
RHYTHM ICD^17^ 2005 | 1/162 | 0.6 [0.0, 3.4]
Gaita^55^ 2000 | 4/96 | 4.2 [1.1, 10.3]
Saxon^106^ 2006 | 1/168 | 0.6 [0.0, 3.3]
Theuns^112^ 2005 | 18/86 | 20.9 [12.9, 31.0]
Sub Total | 63/1005 | 6.3 [4.9, 7.9]
Total [N=9] | 73/1210 | 6.0 [4.8, 7.5]

### Efficacy, Effectiveness, and Safety of ICD

Efficacy of ICD (Figures 15 to 21 and Table 20 in Evidence Report). ICDs reduced all-cause mortality in patients with LV systolic dysfunction by 20 percent (95% CI, 10 to 29 percent; NNT = 20 over a median follow-up of 35 months but with significant heterogeneity between trials), due largely to a 54 percent reduction in sudden cardiac deaths (95% CI, 37 to 63 percent, with no appreciable heterogeneity between trials). In the two trials which reported such outcomes, ICDs did not demonstrate an appreciable impact on functional status or morbidity; however, insufficient studies have reported functional or quality of life outcomes with ICD to draw definitive conclusions. ICDs were equally beneficial in reducing all-cause mortality in both primary prevention trials (RR = 0.81; 95% CI, 0.69 to 0.95) and secondary prevention trials (RR = 0.77; 95% CI, 0.65 to 0.91) (see Figure 20 [p-value for comparison = 0.56]), although the absolute benefits were greater in the secondary prevention trials due to the higher baseline risk in those patients.

Table 20 Univariate meta-regression subgroup analyses: ICD alone

Covariate | All-cause mortality (p-values)
Presence of CRT | 0.92
Length of followup | 0.90
Ischemic etiology (%) | 0.46
NYHA class IV (%) | 0.62
NYHA class II (%) | 0.81
NYHA Class I (%) | 0.13
Mean age (years) | 0.995
Mean QRS interval (msec) | 0.82
Mean LVEF (%) | 0.84
Secondary vs. primary prevention | 0.56

Figure 15. Metagraph of all-cause mortality: ICD alone

Figure 20. Summary results for all-cause mortality: ICD alone, stratified by primary or secondary prevention

Figure 21. Funnel plot for all-cause mortality: ICD alone

Only the SCD-HeFT trial reported a significant subgroup effect (greater benefits in patients with NYHA class II symptoms vs. NYHA class III symptoms at baseline - p<0.001); however, these trials were not powered to detect such subgroup effects. In a series of univariate meta-regression analyses using trial-level data, none of the covariates we examined explained the heterogeneity of treatment effect on all-cause mortality. Of note, none of these RCTs compared single chamber with dual chamber ICDs directly. Although the Dual Chamber and Atrial Tachyarrhythmias Adverse Events Study^140^ reported fewer inappropriate shocks with dual-chamber ICD than with standard single right ventricular lead ICD, a secondary post-hoc analysis of the MADIT-II Trial comparing the 404 patients who received a single-chamber ICD with the 313 patients who received a dual-chamber ICD (the choice of which was left to the discretion of attending physicians and not randomized) revealed that dual-chamber ICD were associated with non-significant trends to higher rates of death (HR = 1.27; 95% CI, 0.76–2.12) or HF hospitalization (HR = 1.27; 95% CI, 0.87–1.86).

Effectiveness of ICD (Figures 15 to 21 and Figure 23 in Evidence Report). Survival during follow-up was similar in the randomized trials and the observational studies for patients who received ICD devices. The pooled effectiveness estimate from controlled observational studies, however, suggested a greater benefit from ICD on all-cause mortality (RR = 0.54; 95% CI 0.43 to 0.68) than that reported in the RCTs. The fact that the controlled observational studies also demonstrated a benefit of ICDs on non-cardiac death (RR = 0.74; 95% CI, 0.65 to 0.85; Figure 18) suggests that selection bias (clinicians preferentially selecting healthier patients for ICD insertion) may explain the exaggerated mortality benefit seen in observational studies.

Figure 18. Metagraph of mortality due to non-cardiac death: ICD alone

Figure 23. Scatter plot of all-cause mortality vs. length of followup: ICD alone

Between three-quarters and two-thirds of ICD recipients never received any therapeutic ICD discharges in the observational studies - this is consistent with the RCTs demonstrating that between 5 and 12 percent of trial participants receive a therapeutic ICD discharge per year.^217^

Safety of ICD (Table 24 in Evidence Report). ICD implant success rate was 99 percent (95% CI, 98.8 to 99.3 percent) and peri-implant deaths occurred in 1.2 percent (95% CI, 09 to 1.5 percent) of individuals (1.7 percent [1.2 to 2.4 percent] of RCT participants vs. 0.8 percent [0.5 to 1.2 percent] of subjects in observational studies). We also examined peri-implant deaths and success rates for 12 studies (68,848 patients) that enrolled all patients undergoing ICD implant (i.e., not just those patients with LV systolic dysfunction). The frequencies were similar to those reported in the studies restricted to patients with LV systolic dysfunction: implant success rate of 98.6 percent (95% CI, 98.3 to 98.9 percent) and peri-implant death rate of 1.3 percent (95% CI, 1.2 to 1.4 percent). The frequency of post-implantation complications per 100 patient-years of follow-up included 1.4 (95% CI, 1.2 to 1.6) device malfunctions, 1.5 (95% CI, 1.3 to 1.8) lead problems, 0.6 (95% CI, 0.5 to 0.8) implant site infections, and 19.1 (95% CI, 16.5 to 22.0) inappropriate discharges in RCT participants and 4.7 (95% CI, 4.3 to 5.1) inappropriate discharges in patients enrolled in observational studies.

Table 24 Peri- and post-implantation risks: ICD alone

Study, Author Year | n/N | Simple pool risk,% [95% CI]
Peri-implant deaths: RCT
AVID^141^ 1997 | 4/492 | 0.8 [0.2, 2.1]
CABG-Patch^134^ 1997 | 24/434 | 5.5 [3.6, 8.1]
CASH^143^ 2000 | 5/99 | 5.1 [1.7, 11.4]
CAT^136^ 2002 | 0/50 | 0.0 [0.0, 5.8]
CIDS^142^ 1999 | 2/310 | 0.6 [0.1, 2.3]
DEFINITE^138^ 2004 | 0/229 | 0.0 [0.0, 1.3]
DINAMIT^139^ 2004 | 0/310 | 0.0 [0.0, 1.0]
MADIT^133^ 1996 | 0/90 | 0.0 [0.0, 3.3]
Sub-Total: | 35/2014 | 1.7 [1.2, 2.4]
Peri-implant deaths: Observational studies
Alter^144^ 2005 | 1/440 | 0.2 [0.0, 1.3]
Backenkohler^145^ 2005 | 0/245 | 0.0 [0.0, 1.2]
Bode-Schnurbus^147^ 2003 | 5/165 | 3.0 [1.0, 6.9]
Bokhari^148^ 2004 | 0/60 | 0.0 [0.0, 4.9]
Carlsson^192^ 2003 | 0/96 | 0.0 [0.0, 3.1]
Cuesta^155^ 2003 | 0/120 | 0.0 [0.0, 2.5]
Duray^158^ 2005 | 0/375 | 0.0 [0.0, 0.8]
Ermis^161^ 2003 | 0/59 | 0.0 [0.0, 5.0]
Evonich^162^ 2004 | 0/153 | 0.0 [0.0, 1.9]
Grimm^165^ 2002 | 0/101 | 0.0 [0.0, 2.9]
Leosdottir^169^ 2006 | 1/62 | 1.6 [0.0, 8.7]
Niehaus^198^ 2003 | 0/25 | 0.0 [0.0, 11.3]
Noseworthy^171^ 2004 | 0/209 | 0.0 [0.0, 1.4]
Raviele^176^ 2005 | 0/24 | 0.0 [0.0, 11.7]
Russo^178^ 2003 | 0/51 | 0.0 [0.0, 5.7]
Takahashi^184^ 2002 | 0/178 | 0.0 [0.0, 1.7]
Telfer^186^ 2002 | 0/22 | 0.0 [0.0, 12.7]
Theuns^187^ 2005b | 0/127 | 0.0 [0.0, 2.3]
Trappe^188^ 2002 | 12/410 | 2.9 [1.5, 5.1]
Wase^189^ 2004 | 5/93 | 5.4 [1.8, 12.1]
Sub Total | 24/3015 | 0.8 [0.5, 1.2]
Total [N=28] | 59/5029 | 1.2 [0.9, 1.5]
Implant success rate: RCT
AVID^141^ 1997 | 488/492 | 99.2 [97.9, 99.8]
CABG-Patch^134^ 1997 | 434/446 | 97.3 [95.3, 98.6]
CASH^143^ 2000 | 99/99 | 100.0 [97.0, 100.0]
CIDS^142^ 2000 | 310/328 | 94.5 [91.5, 96.7]
DEFINITE^138^ 2004 | 227/229 | 99.1 [96.9, 99.9]
DINAMIT^139^ 2004 | 310/332 | 93.4 [90.1, 95.8]
Dorian^193^ 2004a | 149/149 | 100.0 [98.0, 100.0]
MADIT^133^ 1996 | 90/90 | 100.0 [96.7, 100.0]
MADIT II^135^ 2002 | 739/739 | 100.0 [99.6, 100.0]
SCD-HeFT^140^ 2005 | 811/812 | 99.9 [99.3, 100.0]
Sub-Total: | 3657/3716 | 98.4 [98.0, 98.8]
Implant success rate: Observational studies
Alter^144^ 2005 | 440/440 | 100.0 [99.3, 100.0]
Bode-Schnurbus^147^ 2003 | 165/165 | 100.0 [98.2, 100.0]
Bokhari^148^ 2004 | 60/60 | 100.0 [95.1, 100.0]
Capoferri^152^ 2004 | 100/100 | 100.0 [97.0, 100.0]
Carlsson^192^ 2003 | 96/96 | 100.0 [96.9, 100.0]
Cuesta^155^ 2003 | 120//120 | 100.0 [97.5, 100.0]
Dubner^157^ 2005 | 761/761 | 100.0 [99.6, 100.0]
Duray^158^ 2005 | 375/375 | 100.0 [99.2, 100.0]
Ermis^161^ 2003 | 59/59 | 100.0 [95.0, 100.0]
Niehaus^198^ 2003 | 25/25 | 100.0 [88.7, 100.0]
Raviele^176^ 2005 | 24/24 | 100.0 [88.3, 100.0]
Russo^178^ 2003 | 51/51 | 100.0 [94.3, 100.0]
Sanchez^180^ 2005 | 19/19 | 100.0 [85.4, 100.0]
Takahashi^184^ 2002 | 178/178 | 100.0 [98.3, 100.0]
Sub-Total: | 2473/2473 | 100.0 [99.9, 100.0]
Total [N=24] | 6130/6189 | 99.0 [98.8, 99.3]
Implantation mechanical complication: RCT
AVID^141^ 1997 | 28/507 | 5.5 [3.7, 7.9]
CASH^143^ 2000 | 11/99 | 11.1 [5.7, 19.0]
DEFINITE^138^ 2004 | 3/227 | 1.3 [0.3, 3.8]
MADIT^133^ 1996 | 5/95 | 5.3 [1.7, 11.9]
SCD-HeFT^140^ 2005 | 41/812 | 5.0 [3.6, 6.8]
Sub-Total: | 88/1740 | 5.1 [4.1, 6.2]
Implantation mechanical complication: Observational studies
Alter^144^ 2005 | 26/440 | 5.9 [3.9, 8.5]
Bokhari^148^ 2004 | 3/60 | 5.0 [1.0, 13.9]
Carlsson^192^ 2003 | 0/96 | 0.0 [0.0, 3.1]
Cuesta^155^ 2003 | 8/120 | 6.7 [2.9, 12.7]
Evonich^162^ 2004 | 17/153 | 11.1 [6.6, 17.2]
Grimm^165^ 2002 | 2/101 | 2.0 [0.2, 7.0]
Leosdottir^169^ 2006 | 13/62 | 21.0 [11.7, 33.2]
Noseworthy^171^ 2004 | 12/212 | 5.7 [0.0, 9.7]
Raviele^176^ 2005 | 0/24 | 0.0 [0.0, 11.7]
Russo^178^ 2003 | 1/51 | 2.0 [0.0, 10.4]
Saba^179^ 2003 | 0/35 | 0.0 [0.0, 8.2]
Takahashi^184^ 2002 | 6/178 | 3.4 [1.2, 7.2]
Telfer^186^ 2002 | 0/27 | 0.0 [0.0, 10.5]
Sub Total | 88/1559 | 5.6 [4.6, 6.9]
Total [N=18] | 176/3299 | 5.3 [4.6, 6.2]
Post-implant mechanical malfunction: RCT
CAT^136^ 2002 | 4/104 | 3.8 [1.1, 9.6]
DEFINITE^138^ 2004 | 3/227 | 1.3 [0.3, 3.8]
Friedman^194^ 2006 | 4/400 | 1.0 [0.3, 2.5]
Sub-Total: | 11/731 | 1.5 [0.8, 2.7]
Post-implant mechanical malfunction: Observational studies
Alter^144^ 2005 | 2/440 | 0.5 [0.1, 1.6]
Duray^158^ 2005 | 22/375 | 5.9 [3.7, 8.7]
Evonich^162^ 2004 | 4/153 | 2.6 [0.7, 6.6]
Grimm^165^ 2002 | 2/101 | 2.0 [0.2, 7.0]
Noseworthy^171^ 2004 | 1/212 | 0.5 [0.0, 2.6]
Post-implant mechanical malfunction: Observational studies
Takahashi^184^ 2002 | 2/178 | 1.1 [0.1, 4.0]
Sub Total | 33/1459 | 2.3 [1.6, 3.2]
Total [N=9] | 44/2190 | 2.0 [1.5, 2.7]
Post-implant device malfunction: RCT
CASH^143^ 2000 | 5/99 | 5.1 [1.7, 11.4]
CAT^136^ 2002 | 8/104 | 7.7 [3.4, 14.6]
CIDS^142^ 2000 | 2/328 | 0.6 [0.1, 2.2]
MADIT^133^ 1996 | 3/95 | 3.2 [0.7, 9.0]
SCD-HeFT^140^ 2005 | 73/812 | 9.0 [7.1, 11.2]
Sub-Total: | 91/1438 | 6.3 [5.1, 7.7]
Post-implant device malfunction: Observational studies
Alter^144^ 2005 | 26/440 | 5.9 [3.9, 8.5]
Duray^158^ 2005 | 15/375 | 4.0 [2.3, 6.5]
Evonich^162^ 2004 | 9/153 | 5.9 [2.7, 10.9]
Grimm^165^ 2002 | 4/101 | 4.0 [1.1, 9.8]
Leosdottir^169^ 2006 | 3/62 | 4.8 [1.0, 13.5]
Sub Total | 57/1131 | 5.0 [3.8, 6.5]
Total [N=10] | 148/2569 | 5.8 [4.9, 6.7]
Post-implant lead problems: RCT
AVID^141^ 1997 | 3/507 | 0.6 [0.1, 1.7]
CASH^143^ 2000 | 3/99 | 3.0 [0.6, 8.6]
CIDS^142^ 2000 | 8/328 | 2.4 [1.1, 4.7]
DEFINITE^138^ 2004 | 6/227 | 2.6 [1.0, 5.7]
Friedman^194^ 2006 | 5/400 | 1.3 [0.4, 2.9]
MADIT II^135^ 2002 | 13/742 | 1.8 [0.9, 3.0]
Sub-Total | 38/2303 | 1.7 [1.2, 2.3]
Post-implant lead problems: Observational
Alter^144^ 2005 | 52/440 | 11.8 [9.0, 15.2]
Bokhari^148^ 2004 | 18/60 | 30.0 [18.8, 43.2]
Ellenbogen^160^ 2003 | 19/74 | 25.7 [16.2, 37.2]
Evonich^162^ 2004 | 2/153 | 1.3 [0.2, 4.6]
Grimm^165^ 2002 | 8/101 | 7.9 [3.5, 15.0]
Leosdottir^169^ 2006 | 10/62 | 16.1 [8.0, 27.7]
Niehaus^198^ 2003 | 1/25 | 4.0 [0.1, 20.4]
Noseworthy^171^ 2004 | 1/212 | 0.5 [0.0, 2.6]
Sanchez^181^ 2006 | 1/105 | 1.0 [0.0, 5.2]
Takahashi^184^ 2002 | 11/178 | 6.2 [3.1, 10.8]
Sub-Total | 123/1410 | 8.7 [7.3, 10.3]
Total [N=16] | 161/3713 | 4.3 [3.7, 5.0]
Post-implant infections: RCT
AVID^141^ 1997 | 10/492 | 2.0 [1.0, 3.7]
CABG-Patch^134^ 1997 | 19/434 | 4.4 [2.7, 6.8]
CASH^143^ 2000 | 3/99 | 3.0 [0.6, 8.6]
CIDS^142^ 2000 | 15/310 | 4.8 [2.7, 7.9]
DEFINITE^138^ 2004 | 1/229 | 0.4 [0.0, 2.4]
Dorian^193^ 2004a | 3/141 | 2.1 [0.4, 6.1]
MADIT^133^ 1996 | 2/90 | 2.2 [0.3, 7.8]
MADIT II^135^ 2002 | 5/739 | 0.7 [0.2, 1.6]
Sub-Total: | 58/2534 | 2.3 [1.7, 2.9]
Post-implant infections: Observational studies
Alter^144^ 2005 | 2/440 | 0.5 [0.1, 1.6]
Bokhari^148^ 2004 | 3/60 | 5.0 [1.0, 13.9]
Cuesta^155^ 2003 | 2/120 | 1.7 [0.2, 5.9]
Duray^158^ 2005 | 1/375 | 0.3 [0.0, 1.5]
Evonich^162^ 2004 | 4/153 | 2.6 [0.7, 6.6]
Grimm^165^ 2002 | 0/101 | 0.0 [0.0, 2.9]
Leosdottir^169^ 2006 | 1/62 | 1.6 [0.0, 8.7]
Noseworthy^171^ 2004 | 2/209 | 1.0 [0.1, 3.4]
Takahashi^184^ 2002 | 3/178 | 1.7 [0.3, 4.8]
Sub Total | 18/1698 | 1.1 [0.6, 1.7]
Total [N=17] | 76/4232 | 1.8 [1.4, 2.2]
Inappropriate shocks: RCT
AVID^141^ 1997 | 106/171 | 62.0 [54.3, 69.3]
DEFINITE^138^ 2004 | 49/229 | 21.4 [16.3, 27.3]
Sub-Total: | 155/400 | 38.8 [33.9, 43.7]
Inappropriate shocks: Observational studies
Alter^144^ 2005 | 54/440 | 12.3 [9.4, 15.7]
Backenkohler^145^ 2005 | 6/245 | 2.4 [0.9, 5.3]
Bokhari^148^ 2004 | 30/44 | 68.2 [52.4, 81.4]
Capoferri^152^ 2004 | 19/90 | 21.1 [13.2, 31.0]
Dorian^193^ 2004a | 51/141 | 36.2 [28.3, 44.7]
Dorian^156^ 2004b | 57/212 | 26.9 [21.0, 33.4]
Ermis^161^ 2003 | 4/17 | 23.5 [6.8, 49.9]
Evonich^162^ 2004 | 37/153 | 24.2 [17.6, 31.8]
Grimm^165^ 2002 | 16/101 | 15.8 [9.3, 24.4]
Grimm^195^ 2006 | 8/93 | 8.6 [3.8, 16.2]
Hreybe^196^ 2006 | 32/230 | 13.9 [9.7, 19.1]
Leosdottir^169^ 2006 | 10/62 | 16.1 [8.0, 27.7]
Niehaus^198^ 2003 | 2/25 | 8.0 [1.0, 26.0]
Noseworthy^171^ 2004 | 1/212 | 0.5 [0.0, 2.6]
Raviele^176^ 2005 | 4/24 | 16.7 [4.7, 37.4]
Russo^178^ 2003 | 5/51 | 9.8 [3.3, 21.4]
Saeed^199^ 2003 | 5/48 | 10.4 [3.5, 22.7]
Sanchez^180^ 2005 | 4/17 | 23.5 [6.8, 49.9]
Sanchez^181^ 2006 | 7/105 | 6.7 [2.7, 13.3]
Takahashi^184^ 2002 | 3/176 | 1.7 [0.4, 4.9]
Telfer^186^ 2002 | 7/22 | 31.8 [13.9, 54.9]
Theuns^200^ 2004 | 37/98 | 37.8 [28.2, 48.1]
Theuns^201^ 2005a | 18/60 | 30.0 [18.8, 43.2]
Tiroke^202^ 2003 | 38/149 | 25.5 [18.7, 33.3]
Zecchin^191^ 2004 | 11/46 | 23.9 [12.6, 38.8]
Sub Total | 466/2861 | 16.3 [15.0, 17.7]
Total [N=27] | 621/3261 | 19.0 [17.7, 20.4]

RCT=randomized control trial

Table 25 Peri- and post-implantation risks with ICD in studies that were not restricted to patients with left ventricular systolic dysfunction

Trial name, Author Study year | n/N | Simple pool risk, % [95% CI]
Peri-implant deaths: RCT
Bansch^205^ 2004 | 0/50 | 0.0 [0.0, 5.8]
Boriani^206^ 2003 | 0/89 | 0.0 [0.0, 3.3]
Nademanee^210^ 2003 | 0/47 | 0.0 [0.0, 6.2]
Vollman^213^ 2003 | 0/539 | 0.0 [0.0, 0.6]
Sub-Total: | 0/725 | 0.0 [0.0, 0.4]
Peri-implant deaths: Observational studies
Al-Khatib^204^ 2005 | 237/9854 | 2.4 [2.1, 2.7]
Brockes^207^ 2002 | 3/76 | 3.9 [0.8, 11.1]
Reynolds^203^ 2006 | 208/23110 | 0.9 [0.8, 1.0]
Rosenqvist^211^ 1998 | 6/778 | 0.8 [0.3, 1.7]
Schlapfer^212^ 2002 | 0/41 | 0.0 [0.0, 7.0]
Wiegand^214^ 2004 | 0/372 | 0.0 [0.0, 0.8]
Sub Total | 454/34231 | 1.3 [1.2, 1.5]
Total [N=10] | 454/34956 | 1.3 [1.2, 1.4]
Implant success rate: RCT
Bansch^205^ 2004 | 102/102 | 100.0 [97.1, 100.0]
Boriani^206^ 2003 | 88/89 | 98.9 [93.9, 100.0]
Nademanee^210^ 2003 | 47/47 | 100.0 [93.8, 100.0]
Vollman^213^ 2003 | 529/539 | 98.1 [96.6, 99.1]
Sub-Total: | 766/777 | 98.6 [97.5, 99.3]
Implant success rate: Observational studies
Gradaus^208^ 2003 | 3294/3344 | 98.5 [98.0, 98.9]
Rosenqvist^211^ 1998 | 772/778 | 99.2 [98.3, 99.7]
Schapfer^212^ 2002 | 41/41 | 100.0 [93.0, 100.0]
Sub Total | 4107/4163 | 98.7 [98.3, 99.0]
Total [N=7] | 4873/4940 | 98.6 [98.3, 98.9]

### Implications of Findings

Table 1 summarizes the conclusions which are possible given the currently available evidence for therapeutic devices in patients with LV systolic dysfunction.

Table 1 Summary of evidence for devices in patients with left ventricular systolic dysfunction*

Device | Other characteristics | | Quantity of evidence for that patient subgroup | Quality of evidence | Magnitude of effect (95% CI) | Conclusion
| Symptom status | ECG criteria
CRT alone | NYHA class III or IV | QRS > 120 msec and sinus rhythm | 13 RCTs, 3,481 patients | High (multiple RCTs with homogeneous results) | Reduced mortality: RR = 0.78 (0.67 to 0.91) | Definite benefit
| | | | | Reduced HF hospitalizations: RR = 0.51 (0.41 to 0.64)
| NYHA class II | QRS > 120 msec and sinus rhythm | 5 RCTs, 344 patients | Moderate (one small RCT PLUS post-hoc meta-regression of aggregate trial data from 14 RCTs, but few patients in these RCTs had NYHA Class II) | No significant effect on mortality (RR = 1.19, 95% CI 0.17 to 8.26 in the one RCT); | Inconclusive
| | | | Ongoing RCTs: REVERSE, RAFT | In meta-regression, proportion of patients with Class II symptoms was not significantly associated with reduction in mortality (p = 0.76)
| | | | | Effect on hospitalization may be smaller in Class II HF than Class III/IV (in meta- regression, proportion of patients with Class II symptoms significantly associated with reduction in hospitalization (p = 0.003)
| NYHA class III or IV | QRS > 120 msec and bradyarrhythmia or atrial fibrillation | 3 RCTs, 191 patients | Low (post-hoc meta- regression of aggregate trial data from 14 RCTs) | No significant association in meta-regression between proportion of patients with atrial fibrillation and reduction in mortality or hospitalizations (p = 0.73 and 0.58, respectively) | Inconclusive
| | | | Ongoing RCTs: Trip HF, RAFT, APAF, BLOCK HF
| NYHA class III or IV | QRS duration < 120 msec; any rhythm | 5 studies, 120 patients | Low (secondary analyses of small observational studies) | Improvements in symptoms and LV remodelling not significantly different between patients with narrow QRS and patients with wide QRS in any of the Studies | Inconclusive
| NYHA class I | Any QRS duration; any rhythm | None | No published evidence | Not applicable | Inconclusive
| | | | Ongoing RCT: REVERSE
Combined CRT-ICD device (vs. no device) | NYHA class III or IV | QRS > 120 msec and sinus Rhythm | 1 RCT, 903 patients in relevant comparison arms | Moderate (one large RCT) | Reduced mortality: hazard ratio = 0.64 (0.48 to 0.86) | Definitebenefit
| | | | Ongoing RCTs: DECREASE, RAFT | Reduced mortality or all-cause hospitalization hazard ratio = 0.80 (0.68 to 0.95)
| All other patient subgroups | | None | No published evidence | Not applicable | Inconclusive
| | | | Ongoing RCTs: MADIT-CRT, RAFT
Combined CRT-ICD device (vs. CRT alone) | NYHA class III or IV | QRS > 120 msec and sinus rhythm | 1 RCT, 1,212 patients in relevant comparison arms | Moderate (one large RCT, but this comparison was not a priori specified or adequately powered) | No significant effect on mortality (RR = 0.83; 95% CI, 0.66 to 1.05) and no significant effect on time to death in NYHA class IV subgroup (hazard ratio = 1.27; 95% CI 0.68 to 2.37) | Inconclusive
| All other patient subgroups | | None | No published evidence | Not applicable | Inconclusive
ICD alone | Secondary prevention in patients with history of ventricular fibrillation or tachycardia | | 3 RCTs, 1,963 patients | High (multiple RCTs with homogeneous results) | Reduced mortality: RR = 0.77 (0.65 to 0.91) | Definitebenefit
| Primary prevention in NYHA class II or III patients | | 9 RCTs, 5,636 patients | High (multiple RCTs with homogeneous results) | Reduced mortality: RR = 0.81 (0.69 to 0.95) | Definitebenefit
| | | | | No significant effect on HF hospitalizations: 1.10 (0.76 to 1.59)
| Primary prevention in NYHA class I patients | | 6 RCTs, 721 patients | Low (post-hoc meta-regression using aggregate trial data from 12 RCTs) | No significant association in meta-regression between proportion of patients with Class I symptoms and reduction in mortality (p = 0.13) | Inconclusive
| Primary prevention in NYHA class IV patients | | 1 RCT, 217 patients | Moderate (within-RCT comparison, but not primary aim of RCT, PLUS post-hoc meta-regression using aggregate trial data from 12 RCTs) | Mortality hazard ratio = 1.27 (0.68 to 2.37) in CRT-ICD vs. CRT alone arms in the class IV patients in the COMPANION Trial, PLUS p = 0.62 for mortality meta-regression comparing impact of ICD in NYHA class IV patients vs. impact in class II or III patients | Inconclusive

CRT = cardiac resynchronization therapy; HF = heart failure; ICD = implantable cardiac defibrillator; LV = left ventricular; msec = microsecond; NYHA = New York Heart Association; RCT = randomized control trial

* Note that other considerations may outweigh the trial evidence in some situations (e.g., the patient who wishes to be “do not resuscitate”) and there is no data on the effects of either CRT or ICD in patients with advanced age or severe comorbidities (such as end-stage renal disease).

CRT. There is high quality evidence that CRT improves ventricular function and remodelling, symptoms, and exercise capacity, while also reducing HF hospitalizations and death in patients comparable to those enrolled in the trials: (1) NYHA class III or IV HF despite optimal medical management, (2) LVEF ≤ 35 percent, (3) sinus rhythm, and (4) ventricular dyssynchrony (i.e., prolonged QRS duration). Although the mortality reduction with CRT was evident by six months in these trials, a long-term extension of the CARE-HF Trial confirmed that over 3 years of follow-up the relative benefits of CRT were stable (i.e., constant HR) and as such the absolute magnitude of benefit increased over time (thus, although our meta-analysis demonstrates that one death will be prevented within 6 months for every 23 trial patients receiving CRT, the CARE-HF follow-up data suggest that one death would be prevented over 2 years for every 13 CRT recipients, and one death prevented over 3 years for every 9 CRT recipients.^218^

The magnitude of these benefits are similar to those reported for angiotensin converting enzyme inhibitors, beta-blockers, and aldosterone antagonists in recent trials.^219^–^223^ Balanced against these benefits, the peri-procedural risks of CRT appear modest: peri-implantation mortality was less than 1 percent (similar to the frequency reported for patients undergoing implantation of conventional dual-chamber pacemakers).^224^ In contrast to isolated reports raising concerns about a potential excess risk of ventricular arrhythmias or sudden deaths in patients receiving CRT,^225^ pooled results from multiple RCTs revealed no significant risk of sudden death (RR = 1.07; 95% CI, 0.79 to 1.46) or noncardiac death (RR = 0.81; 95% CI, 0.43 to 1.52) in recipients of a CRT device.

Implantation of a biventricular CRT pacemaker (in particular the LV lead) can be technically challenging, even in experienced hands. Our review identified an implantation failure rate of 7 percent; given that these results came from RCTs and early cohort studies that tend to be reported by acknowledged experts in the field, this estimate may be conservative. Further, as the estimates of safety outcomes with CRT are derived from only a few thousand patients, they should not be considered definitive. Given the recent experiences with ICD recalls and FDA advisories, it seems prudent to recommend that all patients with LV systolic dysfunction who have either a CRT or an ICD device implanted be entered into a registry and followed for long-term risks and benefits (and this would also permit evaluations to define patient, device, or operator characteristics which impact on the benefit:safety ratio of CRT devices).

CRT does not always restore mechanical synchrony, even when lead placement is felt to be successful—while 59 percent of CRT recipients in these RCTs improved by at least one NYHA class, 41 percent did not.^226^ In patients outside of RCTs, the rates of nonresponse to CRT have varied widely: from 20 to 28 percent in those studies using a functional status definition for response (an improvement of at least one in NYHA Class) and between 32 to 45 percent in studies employing an echocardiographic definition (most commonly a decrease of at least 15 percent in left ventricular end-systolic volume).^227^ Studies to define which patients are most likely to benefit from CRT (such as the ongoing Predictors of Response to Cardiac Resynchronization Therapy Study)^228^ and which positions in the ventricular wall are most appropriate for implantation of the pacing leads are clear research priorities. ^226,^ ^229^

ICD. There is also high quality evidence that ICD reduces all-cause mortality in patients with LVEF ≤ 35 percent and NYHA class II and III symptoms. The relative reduction in all-cause mortality—20 percent—equates to preventing one death over 35 months for every 20 patients receiving an ICD. Neither functional status nor morbidity outcomes are improved by ICDs in the existing RCTs. Our analyses of observational studies with contemporaneous control groups confirmed that the benefits of ICD extend beyond the trial setting.

Trial eligibility criteria are commonly cited as a means by which to identify patients who will benefit from an ICD; however, identifying particular patient groups who are at increased risk for sudden cardiac death and thus most likely to benefit from an ICD is vitally important.^230,^ ^231^ Two-quarters to two-thirds of ICD recipients in the reviewed trials never received any therapeutic ICD discharges;^217^ even in those who received an appropriate discharge, the benefits were offset over time by deaths due to progressive HF;^232^ and less than a quarter of cardiac arrest victims have a LVEF < 30 percent prior to their event.^233^ Although our meta-regression analyses did not reveal any statistically significant differences in the subgroups we examined, these analyses were post hoc and underpowered due to the small number of trials. A meta-analysis of individual patient data would be necessary to appropriately examine this issue. The establishment of the ICD Registry by the American College of Cardiology National Cardiovascular Data Registry (ACC-NCDR) in conjunction with the Heart Rhythm Society is also an important initiative which will permit the collection of comprehensive data on ICD implants and long-term outcomes. This data should help to identify whether particular patient subgroups derive more or less benefit than the average results reported in this report and whether specific devices or programming parameters are associated with better or worse outcomes.^234^

Combined CRT-ICD Devices. Our analyses indicate that the mortality benefits from CRT and ICD appeared to be independent (i.e. CRT provided mortality benefits whether or not an ICD was present, and ICD provided mortality benefits whether or not CRT was present) - this is consistent with our understanding of their distinct physiological mechanisms and their effects on different cardiac endpoints. This should not be taken to mean that the benefits of each device were additive, however. Indeed, the COMPANION Trial suggests that any incremental benefits with the combined device may be smaller than expected given the apparently independent mortality benefits with each component of the device; however, this comparison was not pre-specified or adequately powered in the COMPANION Trial and further studies are required to define the incremental benefits of the combined device.

### Recommendations for Future Research

A number of areas of uncertainty remain with respect to CRT and ICD therapy in patients with left ventricular systolic dysfunction, some of which are the subject of ongoing trials (for details, see “Implications of our Findings” on page 176 of the full Evidence Report):

1 Further information is still needed on the real world safety and effectiveness of CRT and/or ICD, since much of the data presented here comes from trials or selected cohorts, including trials which enrolled patients only after successful implantation of the device. These studies may overestimate the potential benefit:safety ratio from CRT and/or ICD. Although our review improves on previous reviews by including observational study data, expanding the prospective ACC-NCDR Registry to include CRT as well as ICD would add important “real world” estimates of benefits and risks with both of these devices.
2 Better information is needed on the effects of CRT, ICD, and combined CRT-ICD devices over longer time frames and in patient subgroups largely excluded from the trials conducted to date (such as those with atrial fibrillation, chronic kidney disease, or less symptomatic degrees of HF). In addition, registry data may help compare effectiveness and safety of single-vs. dual-chamber ICD-devices and track changes in complication rates as device implanters, the tools for implantation, and the sophistication of the devices change over time.
3 Collation of individual patient data from the available trials should be a priority to allow exploration for differential subgroup effects. In the words of one editorialist, “it is the entry criterion and not the group actually studied that has driven practice guidelines.”^235^
4 The incremental benefit of combined CRT- ICD devices over ICD alone is uncertain and is the subject of ongoing trials. The incremental benefit of combined CRT-ICD devices over CRT alone is also uncertain yet is not to our knowledge currently being tested in any randomized trials. Given the changing epidemiology of HF mortality (i.e., due to disease modifying agents such as ACE inhibitors and beta-blockers, patients are now more likely to die of progressive HF than sudden death),^236^ the incremental benefits of ICD therapy in a patient who has a CRT device may be smaller than suggested from the ICD trial data in this report. A trial targeting those patients who currently do not qualify for ICD therapy—for example, patients with LVEF in the range of 30 to 40 percent or patients with NYHA class IV symptoms—might require over 1,300 patients per arm followed for 3 years to establish (or refute) a clear marginal benefit of combined devices over CRT alone. Given the markedly higher costs for combined CRT-ICD devices and the rapidly expanding population of HF patients eligible for such devices, such a trial is nonetheless justified.