# Acknowledgments

We are grateful to members of the technical expert panel, Dr. Gillian Sanders (Department of Medicine, Duke University, Durham, NC), Dr. Mark Hlatky (Department of Health Research and Policy, Stanford University, Palo Alto), Dr. Richard Page (Division of Cardiology, University of Washington School of Medicine, Seattle), Dr. William Abraham (Division of Cardiovascular Medicine, Ohio State University, Columbus), and Mary Nix (AHRQ), who provided direction for the scope and content of the review. We also thank the external reviewers who submitted written comments on earlier drafts of this report: Dr. David Atkins (AHRQ), Dr. Eric Fain (St. Jude Medical Inc.), Dr. Martin Fromer (Centre Hospitalier Universtaire Vaudois, Lausanne), Dr. Gordon Moe (University of Toronto), Dr. Robert Rea (Mayo Clinic College of Medicine, Rochester, MN), Dr. John Spertus (University of Missouri—Kansas), Mr. Bob Thompson (Medtronic Inc.), and Dr. Clyde Yancy (Baylor Heart and Vascular Institute, Dallas).

The authors wish to thank Dr. W.T. Abraham, Dr. C. Leclerq, and Dr. S. Cazeau for providing further information about their studies.

The investigators acknowledge the following financial support: Dr. McAlister is a Population Health Scholar supported by the Alberta Heritage Foundation for Medical Research, a New Investigator of the Canadian Institutes of Health Research (CIHR), and holds the Merck Frosst/Aventis Chair in Patient Health Management at the University of Alberta, Edmonton. Dr. Ezekowitz is supported by CIHR. Dr. Rowe is supported by the CIHR as a Canada Research Chair in Emergency Airway Diseases (Ottawa, Canada). He is also supported by the Faculty of Medicine and Dentistry, University of Alberta, Edmonton and the Capital Health Authority, Edmonton.