# Discussion

## Benefits of CRT (CRT Efficacy/Effectiveness)

Using a comprehensive search strategy and concerted efforts to avoid publication and selection bias, this systematic review identified all of the available efficacy and effectiveness evidence on CRT therapy. Overall, our review reveals that CRT is both efficacious and effective when added to optimal medical therapy in certain HF patients. That is, in patients with LVEF ≤ 35 percent, prolonged QRS duration, and symptomatic HF despite optimal medical therapy, CRT reduced all-cause mortality by 22 percent (largely driven by a 36 percent reduction in progressive heart failure deaths) and HF hospitalizations by 37 percent while significantly improving LVEF (an absolute improvement of 3 percent), quality of life (by almost 8 points on the MLWHF score), and functional status (CRT recipients were 55 percent more likely to improve by at least one NYHA symptom class than non-recipients and were able to walk over 24 meters longer on the 6-minute walk test) in RCTs. As expected, the benefits of CRT were even more marked in patients with more severe HF (NYHA class III or IV): relative risk reductions were 22 percent for all-cause mortality, 44 percent for progressive heart failure deaths, and 49 percent for HF hospitalizations. While there was far less effectiveness data than efficacy data for CRT, those observational studies with contemporaneous controls that we identified reported reductions in all-cause mortality and improvements in 6-minute walk tests and LVEF with CRT which are consistent with the results of the RCTs.

The magnitude of these benefits are similar to those reported for angiotensin converting enzyme inhibitors, beta-blockers, and aldosterone antagonists in recent trials^219^–^223^ and translate into a NNT of 31 patients with symptomatic HF (or 14 with NYHA class III or IV symptoms) to prevent one death over 6 months. Balanced against these benefits, the immediate risks of CRT appear modest: peri-implantation mortality rates were less than 1 percent (similar to rates reported for patients undergoing implantation of conventional dual-chamber pacemakers).^224^ Although earlier reports raised concerns about a potentially higher risk of non-HF outcomes in patients with CRT (particularly an excess of ventricular arrythmias or sudden deaths),^225^ pooling the data from all of the RCTs currently available did not reveal any excess risk of sudden death (RR = 1.07; 95% CI, 0.79 to 1.46) or noncardiac death (RR = 0.81; 95% CI, 0.43 to 1.52) in recipients of a CRT device. Moreover, an analysis of ventricular arrhythmia frequency in patients with ICD who were randomized to CRT “on” or “off” in the MIRACLE-ICD Trial did not reveal any significant differences (26 percent vs. 22 percent, p>0.2).^6^

However, implantation of a biventricular CRT pacemaker (in particular the left ventricular lead) is technically challenging, even in experienced hands (our systematic review identified an implantation failure rate of 7 percent, even under the optimal conditions inherent in RCTs and early cohort studies which tend to be reported by acknowledged experts in the field). Furthermore, even in the “ideal patient” (i.e., trial participants), nearly 10 percent of devices malfunctioned and 7 percent of patients had post-implant lead problems (most frequently with the left-ventricular lead) over a median followup of 11 months. While we found that implantation success rates and the frequency of peri-implantation adverse events were no different in the CRT RCTs as in the observational studies conducted in non-trial settings, and in patients implanted with combined CRT-ICD devices as CRT alone devices, these conclusions are based on studies reporting data from less than 7,000 patients and thus should not be considered definitive. Further, it should be noted that the implant success rates and frequency of complications we found in the published literature may not reflect current rates in clinical practice since the experience of device implanters, the tools for implantation, and the sophistication of these devices change over time. This emphasizes the importance of ongoing surveillance programs for these devices, and as discussed under “The Challenge for Health Care Administrators and Funders” on page 177 of the Evidence Report, we believe there is a need to expand the recently established American College of Cardiology National Cardiovascular Data Registry (ACC-NCDR) to collect comprehensive data on CRT devices as well as ICD devices, and to include implants in all patients, not just Medicare beneficiaries. Given the recent experiences with ICD recalls and FDA advisories, it seems prudent to recommend that all patients with left ventricular systolic dysfunction who have either a CRT or an ICD device implanted be entered into a registry and followed for long-term risks and benefits.

The degree of heterogeneity within and between trials in the proportion of patients exhibiting functional improvements with CRT highlights an important issue with CRT. Although these trials enrolled similar patient populations and implanted similar (and in many cases identical) devices, 59 percent of CRT recipients improved by at least one NYHA class while 41 percent did not. Clearly, CRT does not always restore mechanical synchrony, even when lead placement is felt to be successful.^226^ While studies to define which patients are most likely to benefit from CRT and which positions in the ventricular wall are most appropriate for implantation of the pacing leads are clear research priorities,^226,^ ^229,^ ^229^ our examination of subgroup analyses in these trials was unable to identify any particular subgroups who are more (or less) likely to derive benefit from CRT. In nontrial participants, the rates of nonresponse to CRT have varied even more widely. Determining the true rate of nonresponse in clinical practice is hampered by the lack of a universally accepted definition for “response.” The most frequently cited definitions either rely on functional status (an improvement of at least one in NYHA class) or echocardiographic assessments of remodelling (most commonly a decrease of at least 15 percent in left ventricular end-systolic volume).^227^ Complicating matters is the fact that patients may demonstrate a response clinically but not echocardiographically, or vice versa (for example, there was only 76 percent agreement in one study which conducted both assessments as to whether patients were classified as responders/nonresponders under both definitions).^271^ Examining only those studies employing either of these definitions reveals that CRT non-response rates (after successful device implantation) range from 20 to 28 percent in those studies using a functional status definition but in studies employing the more objective echocardiographic remodelling definition CRT nonresponse rates range from 32 to 45 percent.

A variety of reasons have been advanced for the relatively high rates of nonresponse with CRT therapy.^227^ For one, the optimal pacing site in the left ventricle (i.e., the most delayed site on the left ventricular free wall) is not consistent between patients and thus it is not surprising that inserting leads in the same place in all individuals will have varying impacts.^272^ Second, it has been suggested that the etiology of HF is an important predictor of CRT responsiveness: however, although some studies have suggested that patients with ischemic cardiomyopathy exhibit less echocardiographic benefit from CRT than patients with idiopathic dilated cardiomyopathy,^4,^ ^273^ this has not translated into appreciable differences between the two groups in clinical outcomes in the RCTs conducted to date.^11,^ ^15^ Third, the most frequently cited reason for the relatively high rates of nonresponse with CRT therapy is that electrical dyssynchrony on the electrocardiogram does not always translate into mechanical dyssynchrony—a fact proven in several studies.^227,^ ^274,^ ^275^ Indeed, some authors have estimated that up to a quarter of all HF patients with QRS width < 120 msec may have sufficient mechanical dyssynchrony to potentially benefit from CRT.^276^–^278^ As a result, attention has focused on improving the assessment of mechanical dyssynchrony in HF patients with new echocardiographic techniques (such as Tissue Doppler Imaging) and the ongoing Predictors of Response to Cardiac Resynchronization Therapy (PROSPECT) Study is an attempt to prospectively test and validate which of the various echocardiographic indices will best identify those patients most likely to respond to CRT.^228^

An important question about CRT, as with any new therapy, is whether efficacy proven in trials translates into effectiveness when applied in clinical practice. This is of particular concern for novel therapies which either (1) have been tested in a selected spectrum of patients or (2) depend on specialized technical expertise. Both caveats apply to CRT. Thus, while the trials proving the efficacy of CRT enrolled relatively young subjects (mean age 65 years), 72 percent of whom were male, population-based cohort data^279^–^282^ demonstrate that HF patients in clinical practice are almost a decade older than trial participants and have a substantially greater burden of comorbid illnesses. The impact of CRT in these patients (particularly given the higher peri-implantation risks) is unknown. In addition, it bears emphasizing that only selected cases and experienced providers participated in these trials. Consequently, it is plausible that the efficacy and safety rates observed in these trials may not be applicable in usual clinical practice. In particular, recent analyses of Medicare files have confirmed that in the United States these devices are being implanted in older patients with more comorbidities^203^ than the participants in the RCTs reviewed in this report; in addition, CRT devices are being implanted by less experienced providers working in institutions with lower implant volumes^204^ than those centers that participated in the trials we have reviewed herein. This again emphasizes the importance of the prospective national device registry which the Centers for Medicare and Medicaid Services has established (https://www.accncdr.com/webncdr/ICD/Default_ssl.aspx) since any nonselective uptake of CRT beyond the highly specialized settings in which it was shown to be beneficial in these trials would be expected to attenuate its risk/benefit ratio and undermine its cost-effectiveness ratios.

In addition to providing “real world” estimates of complication rates, ongoing surveillance is required to assess (1) the effects of CRT on mortality and morbidity (including functional status and 6-minute walk distances) over longer timeframes than these RCTs have reported, (2) the effects of CRT in patient subgroups excluded from the trials conducted to date (such as those with atrial fibrillation, chronic kidney disease, or less symptomatic HF), (3) to what extent the reductions in HF hospitalizations seen in these trials with CRT may be offset by increased admissions for pacemaker revisions, and (4) to track changes in complication rates as device implanters, the tools for implantation, and the sophistication of the devices change over time.

## Caveats for CRT Efficacy/Effectiveness Data

It should be recognized that few participants in these trials had bradyarrhythmias or atrial fibrillation. As such, the role of CRT in such patients is unknown (despite promising reports from the small HOBIPACE trial^13^ and registry data^283^) and is an important area for further study, particularly since almost one-third of patients with HF have atrial fibrillation or indications for conventional pacemakers.^279^ Similarly, since less than one-tenth of CRT trial participants had a right bundle branch block pattern on their enrolment electrocardiograms, it remains a subject of debate whether to extrapolate the CRT trial findings published thus far to HF patients with right bundle branch block patterns (although a recent study suggested that the degree of left ventricular activation delay and the pattern of activation was similar in patients with right or left bundle branch blocks).^280,^ ^284^ In a similar vein, the benefits of CRT in patients with less symptomatic HF (NYHA class I or II symptoms) are uncertain due to a relative paucity of trial data and awaits further study, despite promising data in subgroup analyses from the CRT trials and observational studies.^32^

While none of the trials that examined subgroup effects reported differences in the efficacy of CRT across subgroups, and our meta-regression was unable to detect any statistically significant differences in the subgroups we examined (ischemic vs. nonischemic etiology, age strata, duration of followup), our meta-regression did reveal that studies with a higher proportion of NYHA class II patients and higher mean LVEF at baseline, and studies with ICD in both the control and CRT arms, found less beneficial effects of CRT on heart failure hospitalizations (but no differences in the survival benefits apparent with CRT). However, it should be emphasized that these subgroup analyses were underpowered (both within trials and between trials). Thus, individual patient data is essential to appropriately examine this issue. We have been involved in discussions with all manufacturers of CRT devices to provide individual patient data for this review; however, no individual patient data was available by January 9, 2007. Examination of the trial data for differential subgroup effects should be an urgent research priority in this field, particularly since, in the words of one editorialist, “it is the entry criterion and not the group actually studied that has driven practice guidelines.”^235^ For example, there are no data on the impact of CRT (with or without ICD) in different strata of baseline LVEF (for example, 10 to 20 percent vs. 20 to 30 percent vs. 31 to 35 percent) and thus CRT is currently advocated for patients who would have met trial eligibility criteria, even though the mean LVEF in the randomized trials proving the efficacy of these devices was substantially lower than the LVEF required for trial entry. In the same vein, the degree of heterogeneity within and between trials in the proportion of patients exhibiting functional improvements with CRT highlights the need for detailed subgroup analyses. Although these trials enrolled similar patient populations and implanted similar (and in many cases identical) devices, 59 percent of CRT recipients improved by at least one NYHA class while 41 percent did not. Clearly, CRT does not always restore mechanical synchrony, even when lead placement is felt to be successful.^226^ Moreover, studies to define which patients are most likely to benefit from CRT and which positions in the ventricular wall are most appropriate for implantation of the pacing leads are clear research priorities.^226,^ ^235^

Another limitation of these RCTs is that randomization occurred after implantation of the device in all but three trials. This design, similar to the run-in period used in some pharmaceutical trials, does not affect the internal validity of the trials since the randomly assigned groups should still be balanced for unmeasured confounders. However, it does affect the tests of statistical significance (as it causes narrower confidence intervals and increases the chance of type 1 errors) and does impact the generalizability of the results as patients who could not tolerate the procedure or in whom implantation was unsuccessful would not have been included in the final trial data. As a result, these trials likely overestimate the potential benefits and underestimate adverse events from cardiac resynchronization—although the univariate meta-regression did not demonstrate statistical significance on this factor (p = 0.18), this analysis was underpowered due to the small number of studies. This further emphasizes the importance of ongoing surveillance registries to track device effectiveness and complication rates (particularly given the marked paucity of data on the efficacy or complication rates with cardiac resynchronization therapy beyond one year).^285^

Mode of death analyses should always be viewed as hypothesis generating exercises given the well-documented uncertainties around the sub-classification of deaths, particularly in classifying cardiac deaths as being due to sudden arrhythmic events versus progressive HF.^286^

Finally, it is uncertain whether, and to what extent, the use of newer techniques to detect electro-mechanical dyssynchrony, such as Tissue Doppler Imaging rather than the current criteria based on QRS and LVEF, to select patients for CRT in the future will impact on the effectiveness and safety of these devices.^226^

## Safety of CRT

It is well known that trials under-estimate complication rates from both medical and surgical interventions due to their selection criteria, relatively short followup time-frames, and close monitoring of patients (and providers).^251^ Although our analysis of peri- and post-implantation risks revealed similar frequencies in the RCT data and the observational data at this point in time, it should be recognized that this is based on sample sizes of only a few thousand patients and reports of device implantations appearing early in the literature are most likely to come from larger institutions/more experienced investigators with early experience and competence with these devices. Regardless, our analysis demonstrated that CRT implantation was successful approximately 93 percent of the time and the peri-implantation risks included a 0.3 percent chance of peri-implantation death and a 4 to 5 percent chance of mechanical complication at the time of implantation—these rates were almost identical for CRT alone or combined CRT-ICD devices. Both types of devices exhibited a 7 percent frequency of post-implant lead problems, a 5 percent frequency of device malfunction, and a 1 to 2 percent frequency of post-implant infections) over a median followup of 6 months. However, it should be recognized that all of the published evidence thus far is relatively short-term and based on relatively few patients. This further emphasizes the importance of ongoing surveillance registries to track complication rates and costs (including costs and complications of failed implantation attempts) over the long-term.

## Cost-Effectiveness of CRT

Numerous decision analytic studies have explored the cost-effectiveness of CRT therapy. In an earlier AHRQ report (a Markov Model with a lifetime horizon, but based on data from the relatively short-term trials published to that point in time—most of which reported outcome data only within the first 3 months after CRT activation), a median incremental cost of US$107,800 per QALY with CRT vs. medical therapy was reported.^287^ However, three subsequent cost-utility analyses which have incorporated more recently published trials with substantially longer followup durations have reported markedly lower incremental costs per QALY gained for CRT devices: US$19,600 in an analysis of the COMPANION trial data,^288^ £19,319 in an analysis employing the CARE-HF trial data,^289^ and £16,598 in a Markov decision analytic model with a lifetime horizon developed for the NHS Research and Development Health Technology Assessment Programme from a meta-analysis of the five longest CRT trials.^290^ However, even these analyses found that the incremental cost-effectiveness of CRT-ICD over CRT alone was markedly higher ($171,538 per QALY in the United States and £34,664 in the United Kingdom) since the benefit of CRT-ICD over CRT is marginal, but at a much higher cost (for example, initial implant costs are $20,500 in the United States for CRT devices, but $29,500 in the United States for CRT-ICD devices and followup costs over 7 years are $39,400 vs. $52,700).^288^ In the words of one editorialist, although CRT alone devices are clearly cost-effective in patients similar to those enrolled in the trials, pending further trial data comparing CRT-ICD devices with CRT alone devices (see “Implications of our findings” section below), “the question of which device is most cost effective for patients with heart failure remains open.”^291^

## Proportion of HF Patients Likely To Be Eligible for CRT

Approximately 1 to 3 percent of all patients discharged alive after their index hospitalization for HF^280,^ ^292^ and 15 to 20 percent of patients seen in specialized heart failure clinics^280,^ ^293,^ ^294^ meet CRT trial eligibility criteria (LVEF ≤ 35 percent, QRS ≥ 120 msec, sinus rhythm, and NYHA class III or IV symptoms despite treatment with ACE inhibitor/angiotensin receptor blocker and beta-blocker). Of these patients, approximately one half also meet trial eligibility criteria for an ICD.^295^ Since clinicians tend to overestimate the severity of functional impairment in heart failure,^226^ and the NYHA classification system demonstrates substantial inter-rater variability,^296^ it is possible that even fewer patients would require CRT if an objective functional assessment (such as 6 minute walk test distance < 450 m) were included in the evaluation.

## Benefits of ICD (ICD Efficacy/Effectiveness)

Using a comprehensive search strategy and concerted efforts to avoid publication and selection bias, this systematic review identified all of the available efficacy and effectiveness evidence on ICD therapy in patients with left ventricular systolic dysfunction. Overall, our review reveals that ICD is both efficacious and effective when added to optimal medical therapy in patients with LVEF ≤ 35 percent, regardless of whether they have HF symptoms or not. In the randomized trials, ICD reduced all-cause mortality by 20 percent (largely driven by a 54 percent reduction in sudden cardiac deaths) and, given the control mortality rate of 24 percent, this relative risk reduction translates into a NNT of 20 to prevent one death over 35 months. The relative benefits were similar in the primary prevention and secondary prevention trials (19 percent relative risk reduction vs. 23 percent relative risk reduction, respectively), although given the differences in absolute risk (23 percent all-cause mortality in the primary prevention trials vs. 30 percent all-cause mortality in the secondary prevention trials) the NNTs to prevent one death were different: 23 in the primary prevention trials vs. 15 in the secondary prevention trials. The benefits of ICD outside of the trial setting were confirmed in our analyses of observational studies with contemporaneous control groups.

Although ICD did not appear to be associated with an increase in HF symptoms or deteriorations in functional status or quality of life in trial participants, these analyses are certainly not definitive given the lack of reporting of these endpoints in most of the trials published to date. For example, HF events were reported in just two trials (one of which^135^ did report a statistically significant excess risk of HF hospitalizations in ICD recipients: RR = 1.34; 95% CI, 1.04 to 1.73). A secondary analysis of data from the same trial has confirmed that it was those ICD recipients who were saved from sudden death by ICD shocks (as compared to those patients who had an ICD implanted but never received any shocks) who were most likely to subsequently be hospitalized for HF (hazard ratio 1.90 for first HF hospitalization and 1.74 for recurrent HF hospitalizations) and a factor predicting increased risk of subsequent HF was a QRS interval ≥ 120 msec.^297^ This finding may reflect the fact that sicker patients are those most likely to have ventricular arrythmias; however, it serves to highlight a subgroup of ICD eligible patients (those with symptomatic HF and QRS interval ≥ 120 msec, as well as the LVEF ≤ 35 percent currently advocated in the ACC/AHA/ESC guidelines)^298^ who should be considered for a combined CRT-ICD device rather than an ICD alone.

Another factor which clinicians and their patients must weigh in the decision about ICD implantation is their quality of life. Due to a paucity of data in the trials conducted thus far, this did not feature in our systematic review; however, there is some evidence that while quality of life improves in some patients after ICD implantation, it declines in others, especially those who experience frequent ICD firings.^299^ Indeed, it has been reported that ICD recipients not infrequently demonstrate substantial anxiety and can develop a psychological dependence on their device.^300^ Not unexpectedly, patient anxiety and psychologic distress scores are significantly and substantially higher after an ICD shock.^301^ Further, it has been shown that device recalls also substantially increase psychological distress in patients and their families,^302^ an increasingly relevant factor given analyses of FDA Enforcement Reports demonstrating marked increases in device advisories and recall rates over time (as devices get smaller and more complicated).^303^ Indeed, there have been 29 FDA advisories affecting nearly 337,000 ICDs since 1990—a figure which does not include the 62,000 Guidant ICDs recalled voluntarily by the company in June 2005.^304^

Akin to the situation with CRT (in which between one-quarter and one-half of patients may not respond to the device), three-quarters to two-thirds of ICD recipients never received any therapeutic ICD discharges in these trials (therapeutic ICD discharges ranged from 5 percent to 12 percent of patients per year in the trials included in this review).^217^ In fact, based on analyses from MADIT-II demonstrating 50 percent mortality rates within 2 years of an appropriate ICD firing,^230^ it has been estimated that 10 percent of those who receive an ICD for primary prevention will receive an appropriate shock and survive at least 1 year.^217^ Moreover, registry data has demonstrated that less than one-quarter of cardiac arrest victims have a LVEF < 30 percent prior to their event.^233^ While this clearly has implications for the cost-effectiveness of this therapy (see “Cost-Effectiveness of ICD” below) and resource distribution, it also serves to highlight the urgent research need to develop and validate tools which will permit adequate risk stratification to distinguish those patients who are at increased risk for sudden cardiac death and likely to benefit from an ICD from those patients unlikely to benefit.

Thus, while the MADIT-II and SCD-HeFT trial eligibility criteria are commonly cited as a means by which to identify patients who would potentially benefit from an ICD, the identification of particular patient groups who are more or less likely to benefit from an ICD is vitally important.^230,^ ^231^ Although our meta-regression analyses did not reveal any statistically significant differences in the sub-groups we examined (ischemic vs. non-ischemic etiology, patient age, duration of followup, presence of CRT or not, the use of concomitant medications, QRS width, or mean LVEF in the randomized trials—recognizing that since these trials enrolled patients within a narrow LVEF range its potential predictive ability would have been markedly reduced), it should be emphasized that these analyses were underpowered due to the small number of trials and a meta-analysis of individual patient data would be necessary to appropriately examine this issue. Indeed, the establishment of the ICD Registry by the ACC-NCDR in collaboration with the Heart Rhythm Society is an important initiative which will permit the collection of comprehensive data on ICD implants and long-term patient outcomes. This should help to identify whether particular patient subgroups derive more or less benefit than the averages reported in this report and whether specific devices or programming parameters are associated with better or worse outcomes.^234^

Regardless, the current evidence base does provide some guidance in the selection of candidates for a primary prevention ICD. For example, as ICD was not associated with a mortality benefit in the DINAMIT trial (in which ICD implants were performed within 40 days of an acute myocardial infarction)^139^ or in MADIT-II patients enrolled within 6 months of coronary revascularization (HR = 1.19; p = 0.76),^305^ it seems reasonable to infer that ICD implantation should be delayed for a period of time after acute coronary events (and the 40 day window specified in the ACC/AHA/ESC 2006 guidelines^298^ is supported by the literature). Other risk stratification tools, such as microvolt T-wave alternans, have been suggested as potential means to identify high and low risk groups and have now been formally tested in prospective observational cohorts^306^ and modelling suggests use of this test to identify those most likely to benefit from ICD may enhance the cost-effectiveness of ICD therapy.^307^ Indeed, CMS approved reimbursement for this test in 2006 to identify patients at increased risk who may derive most benefit from an ICD within the existing guidelines.

Although the effectiveness analyses suggest that the benefits of ICD demonstrated in the RCTs are achievable in clinical practice, the same cautions raised about the CRT randomized trial data apply to the ICD randomized trial data, namely that (1) the trials proving the efficacy of ICD enrolled relatively young and comparatively healthy subjects (while recent analyses in the United States suggest that ICD recipients in clinical practice are older and have a higher co-morbidity burden),^203^ and (2) only experienced ICD implanters from high volume institutions participated in these trials (while recent analyses in the United States suggest that ICD implants are most commonly performed by less experienced providers working in institutions with lower implant volumes).^204^ This again emphasizes the importance of the ACC-NCDR registry for surveillance of outcomes with ICD implantation over time since any nonselective uptake of ICD beyond the highly specialized settings in which it was shown to be beneficial in these trials may well attenuate its risk/benefit ratio and undermine its cost-effectiveness ratios.

## Caveats for ICD Efficacy/Effectiveness Data

In addition to the caveats listed above with respect to our inability to identify patient groups most likely to benefit from ICD with aggregate trial data, our analysis is also limited by a paucity of data on more complex dual-chamber ICD devices capable of antitachycardia pacing. Antitachycardia pacing offers another method by which ICD could prevent sudden cardiac death, conserve battery life, prevent a reduction in quality of life, and limit the number of inappropriate shocks patients receive.^308^ This device is not without risk, however, since antitachycardia pacing can accelerate ventricular tachycardia into ventricular fibrillation requiring a shock.^308^

While early reports suggested that dual-chamber (i.e., right atrium and right ventricle) pacing could improve symptoms in patients with advanced heart failure,^309^ theoretically at least there is a risk of inducing ventricular dyssynchrony with right ventricular pacing. Although three studies^194,^ ^310,^ ^311^ have failed to demonstrate a significant benefit with the addition of an additional atrial lead to the right ventricular ICD lead, and one study suggested that dual-chamber ICD may exacerbate heart failure in patients without an indication for dual-chamber pacing,^312^ one study^201^ did report a 47 percent improvement in the odds of detecting supraventricular tachycardias, thus averting potentially inappropriate shocks. Adding to the confusion, while one trial suggested potential harm with an increase in the composite endpoint of mortality and HF hospitalization with dual-chamber pacing compared to backup ventricular pacing in ICD patients with left ventricular dysfunction and without an indication for dual-chamber pacing,^313^ the Dual Chamber and Atrial Tachyarrhythmias Adverse Events (DATAS) Study^314^ reported fewer inappropriate shocks with dual-chamber ICD than with standard single right ventricular lead ICD. Importantly, the DATAS Trial used different settings with a longer AV delay in order to minimize pacing, and indeed the rate at which the right ventricular lead had to pace was halved, highlighting the need for clarity about both the device to be tested and the settings in a larger randomized trial to settle this issue. A secondary post hoc analysis of the MADIT-II Trial comparing the 404 patients who received a single-chamber ICD with the 313 patients who received a dual-chamber ICD demonstrated a higher risk of death or heart failure hospitalization with dual-chamber ICD.^263^ However, the choice of single vs. dual-chamber was not randomized in this trial but left to the discretion of the attending physician and those patients who received dual-chamber ICD were older, had more advanced heart failure symptoms, and more comorbidities. As a result, after adjustment the Cox proportional hazards regression revealed that dual-chamber ICD were associated with trends to higher rates of death (hazard ratio 1.27, 95% CI 0.76–2.12) or HF hospitalization (hazard ratio 1.27, 95% CI 0.87–1.86) which were not statistically significant. Thus, although dual-chamber ICD therapy is promising, it must be tested against single-chamber ICD in appropriately powered RCTs before definitive conclusions can be drawn. In the meantime, although the most recent guidelines for ICD and the prevention of sudden cardiac death are silent on the indications for dual-chamber devices,^298^ we believe it prudent to restrict the use of dual-chamber ICD to those patients who require an ICD and have conventional indications for dual-chamber pacing (such as chronotropic incompetence, sick sinus syndrome, or AV conduction abnormalities).^315^

## Safety of ICD

Although ICD alone devices are clearly easier to implant than CRT capable devices (implant success rates of 99 percent vs. 93 percent), rates of peri-implant deaths and/or mechanical complications did not differ appreciably between the CRT or ICD devices. As outlined earlier in our report, implantation success rates were significantly lower (98 percent vs. 100 percent), peri-implantation death rates were significantly higher (1.7 percent vs. 0.8 percent), and inappropriate ICD discharge rates were substantially higher (39 percent vs. 16 percent over 24 months) in the ICD RCTs compared to the observational studies, likely reflecting closer scrutiny in the randomized trial setting or publication bias in the observational data.

In addition to the data we report from our systematic review of randomized trials and observational studies, it is important to acknowledge that it is difficult to estimate the true incidence of ICD (or indeed CRT) device failures since the observed failure rates are likely to be an underestimate due to under-reporting and the tendency to attribute patient deaths to the underlying disease process rather than unrecognized device malfunction. While there have already been 29 FDA advisories affecting nearly 337,000 ICDs since 1990 (and that doesn't include lead advisories, which are more frequent, or the 62,000 ICDs Guidant recalled voluntarily in June 2005),^304^ analyses of FDA Enforcement Reports over the past decade demonstrated marked increases in device recall rates over time (as devices get smaller and more complicated). Currently, ICD recall rates are as high as 16.4 per 100 person years—54 percent for hardware malfunctions (electrical/circuitry malfunctions, battery/capacitor malfunctions, problems with hermetic seals, defective crystals, defective headers) and 41 percent for firmware malfunctions (integral device computer programming).^303^ It has been estimated that almost three-quarters of all ICD advisories result in device replacements and the resultant increases in monitoring, outpatient visits, hospitalizations, and use of hospital resources to replace recalled devices cost over US$90 million per year.^303^

Although there is inadequate long-term data to reliably define battery lifetime and the costs/risks of ICD replacement in patients with reduced LV systolic function, cost-effectiveness analyses commonly use a 5-year period as the average anticipated interval when ICD generators would need to be replaced in their models (based on observational data).^316^ However, this is clearly an over-simplification since the generator life of an ICD will depend on whether it is single or dual chamber, the various parameters it is set to, and the frequency of discharges.

## Cost-Effectiveness of ICD

The cost-effectiveness of ICD in patients with left ventricular dysfunction has recently been analyzed in four decision analyses. In an analysis incorporating data from eight of the trials included in our analysis, the incremental cost-effectiveness of ICD compared to medical therapy alone ranged between US$34,000 to US$70,200 per QALY gained over a lifetime horizon as long as the ICD was assumed to retain its effectiveness for at least 7 years.^317^ Using data from the SCD-HeFT trial the incremental cost-effectiveness ratio for ICD was estimated to be US$41,530 per QALY, but was also sensitive to long-term survival and only remained attractive if the ICD prolonged life for at least 8 years.^318^ On the other hand, an analysis using data from the MADIT-II Trial demonstrated a far less favourable incremental cost-effectiveness ratio for ICD of US$235,000 per life-year saved during the 3.5 years of the trial.^319^ Modelling the benefits and costs over a longer time frame (12 years) yielded lower incremental cost-effectiveness ratios of US$78,600 to US$114,000 per life-year saved. Finally, a modelling study based on up to 15 years of cost and survival data from the Duke University Medical Center revealed cost-effectiveness ratios ranging from US$367,200 per life-year gained when a 3-year time horizon was examined to US$67,800 per life-year gained over a 15-year time horizon for patients within the Duke databases who would have been eligible for the MADIT-II study.^320^ Thus, as the costs of ICD implantation are high initially but lower during followup, the results of ICD cost-effectiveness analyses are very sensitive to the time horizon used. Regardless, none of these analyses have taken into account the cost of device recalls to the healthcare system —whilst the device and replacement costs may be covered, the number of days lost from work, lower work productivity for spouses and family members and the delay for other patients waiting for appropriate and cost-effective therapy (e.g., a regular pacemaker) is sure to increase these estimates. As pointed out by the editorialist for one of these cost-effectiveness analyses, we need to strive “to identify the right patients at the right time for ICD implantation to deliver enough bangs for the bucks.”^217^

## Implications of Our Findings

Over the past decade, device therapy options have emerged as promising adjuncts to optimal medical therapy for patients with heart failure—CRT and ICD are the two that hold the most promise for the greatest proportion of heart failure patients. Although the evidence base underpinning these therapies has evolved rapidly and fulfilled much of this promise, there remain some areas of uncertainty.

Our findings allow us to summarize the areas of certainty as follows. CRT is a proven efficacious (and cost effective) therapy for patients with (1) NYHA class III or IV symptomatic HF despite optimal medical management, (2) LVEF ≤ 35 percent, (3) sinus rhythm, and (4) ventricular dyssynchrony (i.e., prolonged QRS duration) which improves ventricular function and remodelling, symptoms, and exercise capacity, while also reducing HF hospitalizations and death. ICD is also a proven efficacious (and cost effective) therapy for patients with LVEF ≤ 35 percent and predominantly NYHA class II and III symptoms which reduces sudden cardiac deaths (and all-cause mortality) without appreciably impacting on functional status or morbidity outcomes.

However, despite this apparent clarity, a number of areas of uncertainty surround CRT and/or ICD therapy in patients with left ventricular systolic dysfunction. This report will end with 3 challenges to address the key grey areas in the current evidence base—one for health outcome investigators, one for administrators and health care funders, and one for trialists and device manufacturers.

## The Challenge for Health Outcome Investigators

While the expected benefits with either CRT and/or ICD should be greater (and the cost-effectiveness ratios lower) in higher risk patients, a clear research need that this systematic review highlights is the current paucity of risk stratification tools to accurately identify those patients with left ventricular systolic dysfunction who are most likely to benefit from either (or both) of these devices.

## The Challenge for Health Care Administrators and Funders

The recently established ACC-NCDR will permit the collection of comprehensive data on ICD and combined CRT-ICD implants and outcomes in Medicare beneficiaries. While this registry will help to define the long-term benefits, risks, and costs of these devices and help to clarify whether particular patient subgroups derive more or less benefit from these devices than the averages reported in this report, we believe there is a need for this registry to be expanded. For example, inclusion of data on all implants (i.e., in all patients, not just those in the over 65 year old age group that comprises Medicare beneficiaries) and collection of data on patients who receive CRT alone devices should be considered. Given the recent experiences with ICD recalls and FDA advisories, it seems prudent to recommend that all patients with left ventricular systolic dysfunction who have either a CRT or an ICD device implanted be entered into a registry and followed for long-term risks and benefits, particularly in light of the small sample sizes of current studies reporting on CRT safety. In addition, we believe that the impact of these devices on outcomes other than mortality or hospitalizations (such as functional status and 6-minute walk distances over longer timeframes than these RCTs have reported) would be important to collect as such information would usefully inform clinical and policy decision making.

### The Challenge for Trialists and Device Manufacturers

Trialists and device manufacturers are to be congratulated for a plethora of ongoing studies designed to address a number of questions about CRT and/or ICD therapy which we raised earlier in our discussion under the “Caveats with efficacy/effectiveness data” for these devices. For example, the REVERSE (Resynchronization reverses Remodeling in Systolic left vEntricular dysfunction) Trial^321^ is evaluating the efficacy of CRT alone in patients with NYHA class I or II symptoms while the MADIT CRT (Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy) Trial^322^ is comparing combined CRT-ICD to ICD alone in patients with NYHA class I or II symptoms—a subgroup of HF patients who have been under-represented in the trials thus far. Similarly, the Trip HF (Triple resynchronization in paced Heart Failure patients - NCT00187265 on clinicaltrials.gov) and APAF (Assessment of cardiac resynchronization therapy in patients undergoing “Ablate and Pace” therapy for permanent Atrial Fibrillation—NCT00111527 on clinicaltrials.gov) Trials will provide much needed data on the efficacy and safety of CRT in patients with atrial fibrillation—another patient subgroup under-represented in CRT trials thus far. Furthermore, the BLOCK HF (Biventricular Versus Right Ventricular Pacing in Heart Failure Patients With Atrioventricular Block-NCT00267098 on clinicaltrials.gov) Trial will to provide data necessary to determine the efficacy and safety of CRT in patients with atrioventricular block. Although our analyses suggest that the efficacy of CRT is not altered by the presence of an ICD, two ongoing trials (The Resynchronization/Defibrillation for Advanced Heart Failure [RAFT] Trial-NCT00251251 on clinicaltrials.gov - and The Device Evaluation of CONTAK RENEWAL 2 and EASYTRAK 2: Assessment of Safety and Effectiveness in Heart Failure [DECREASE-HF]^236^ Trials) will provide further detail to solidify the evidence base and resolve the question of the incremental benefits of combined CRT-ICD devices over ICD alone in patients with more symptomatic left ventricular dysfunction (i.e., NYHA class III and IV).

A key area of residual uncertainty regarding device therapy in left ventricular systolic dysfunction is the incremental benefit of combined CRT-ICD devices over CRT alone. As others have pointed out, “the effects of these devices may not be additive.”^291^ While trials are ongoing (as detailed above) to evaluate the incremental benefit of combined CRT-ICD devices over ICD alone devices, we challenge device manufacturers and trialists to also test the incremental benefits of combined CRT-ICD devices over CRT alone devices. Although some may argue that CRT alone devices have been superseded by combined CRT-ICD devices, we would argue that the incremental benefits of combined CRT-ICD devices over CRT alone devices are still unknown (due to a paucity of trial data comparing these two devices head-to-head in patients with left ventricular systolic dysfunction). The indirect comparisons we described (between two arms of the COMPANION trial and the meta-regression across trials as discussed on page 123 of this report) certainly cannot be considered definitive evidence. Indeed, given the changing epidemiology of HF mortality (i.e., HF patients who are living longer due to disease modifying agents such as ACE inhibitors, beta-blockers, and spironolactone and multidisciplinary HF management clinics are now far more likely to die of progressive HF than sudden death than they were even a decade ago),^323^ we believe that the incremental benefits of ICD therapy in a patient who has a CRT device may well be substantially less than anticipated from the ICD trial data presented in this report. Clearly, any such trial would need to target those patients who currently fail to qualify for ICD therapy, for example, patients with LVEF in the range of 30 to 40 percent and/or patients with greater degrees of LV systolic dysfunction and more heart failure symptoms (NYHA class IV). It has been estimated that such a trial would require over 1,300 patients per arm followed for 3 years. To quote Dr. Daubert, “who will undertake such a study?”^324^ Given the markedly higher costs for combined CRT-ICD devices than CRT alone devices and the rapidly expanding population of HF patients eligible for such devices, perhaps this question is better framed "how can we not undertake such a study?