# Results

## Literature Search

### CRT Alone or Combined CRT-ICD Devices

Of 7,110 initial references retrieved from electronic databases and 48 references identified by hand searching reference lists in published studies or by contacting content experts (including primary study authors), we included 128 unique articles (reporting data from 130 studies). Fourteen RCTs^4^–^17^ were included for the efficacy review, 106 studies^17^–^122^ (2 clinical trials, 104 observational studies) for the effectiveness review, and 89 studies (14 RCTs,^4^–^17^ 2 clinical trials,^39,^ ^73^ and 73 observational studies^17,^ ^20,^ ^22,^ ^26,^ ^27,^ ^29^–^33,^ ^35,^ ^36,^ ^41,^ ^42,^ ^44^–^46,^ ^49,^ ^50,^ ^52,^ ^53,^ ^55^–^58,^ ^60,^ ^63^–^70,^ ^76,^ ^78,^ ^80,^ ^82,^ ^83,^ ^85^–^87,^ ^89,^ ^91^–^94,^ ^97,^ ^98,^ ^100,^ ^102^–^106,^ ^108,^ ^109,^ ^111^–^113,^ ^117,^ ^118,^ ^123^–^132^) for the safety review (Figure 2). Many of the studies were included in more than one of the efficacy, safety, and effectiveness reviews. Additional data to those reported in the journal publications or conference presentations were provided by the investigators from four trials^4^–^6,^ ^10^ and are included in these analyses.

Many of the included trials were associated with multiple publications that either expanded on the main results or reported secondary outcomes not included in the primary report. In such cases, only the primary report for each trial was included; however, data on secondary outcomes were extracted if they were only reported in these secondary publications. Appendix C * identifies the associated multiple publications for each included study (there were 49 in total).

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/defibtp.htm

There were three main reasons for excluding studies from the CRT review on the second detailed screening: (1) the intervention studied was not CRT (48 studies); (2) the article was a review, protocol, editorial, or did not present primary data (139 studies); or (3) the study did not report required outcomes (134 studies), leaving 32 studies which were excluded for other reasons (including small sample size). The list of excluded studies and reasons for exclusion are identified in Appendix D *.

## ICD Alone

Of 4,151 initial references retrieved from electronic databases and 31 references identified by hand searching reference lists in published studies or by contacting content experts (including primary study authors), we included 82 unique studies. Twelve RCTs^11,^ ^133^–^143^ were accepted for the efficacy review, 48 studies^144^–^191^ (3 trials, 45 observational studies) were accepted for the effectiveness review, and 49 studies (11 efficacy studies,^11,^ ^133^–^136,^ ^138^–^143^ 38 observational studies^144,^ ^145,^ ^147,^ ^148,^ ^152,^ ^155^–^159,^ ^161,^ ^162,^ ^164,^ ^165,^ ^169,^ ^171,^ ^176,^ ^178^–^181,^ ^184,^ ^186^–^189,^ ^191^–^202^) for the safety review (Figure 3). An additional 12 studies (68,848 patients) were included in our secondary analysis of peri-implant safety with ICD for all patients (i.e., not restricted to only those patients with LV systolic dysfunction).^203^–^214^

Many of the included trials were associated with multiple publications that either expanded on the main results or reported secondary outcomes not included in the primary report. In such cases, only the primary report for each trial was included; however, data on secondary outcomes were extracted if they were only reported in these secondary publications. Appendix C * identifies the associated multiple publications for each included study (there were three in total).

There were three main reasons for exclusion of studies from the ICD review on the second detailed screening: (1) the population did not have LVSD (61 studies); (2) the article was a review, protocol, editorial, or did not present primary data (105 studies); or (3) the study did not report required outcomes (64 studies), leaving 14 studies which were excluded for other reasons (including small sample size). The list of excluded studies and reasons for exclusion are identified in Appendix D *.

## Description of Included Studies: Efficacy Review

### CRT Alone or Combined CRT-ICD Devices

Fourteen randomized trials met the inclusion criteria for the efficacy review and are listed below:

1 The MIRACLE (Multicenter InSync Randomized Clinical Evaluation) Trial^4^
2 The MUSTIC-SR (Multisite Stimulation in Cardiomyopathies Sinus Rhythm) Trial^5^
3 The MIRACLE ICD (Multicenter InSync Randomized Clinical Evaluation ICD) Trial^6^
4 The MUSTIC-AF (Multisite Stimulation in Cardiomyopathies Atrial Fibrillation) Trial^7^
5 The PATH-CHF (Pacing Therapies for Congestive Heart Failure) Trial^8^
6 The CONTAK-CD Trial^9^
7 The RD-CHF Trial^10^
8 The COMPANION (Comparison of Medical Therapy, Pacing, and Defibrillation in Chronic Heart Failure) Trial^11^
9 The PATH-CHF II (Pacing Therapies for Congestive Heart Failure II) Trial^12^
10 The HOBIPACE (Homburg Biventricular Pacing Evaluation) Trial^13^
11 The MIRACLE ICD II (Multicenter InSync Randomized Clinical Evaluation ICD II) Trial^14^
12 The CARE-HF (Cardiac Resynchronization-Heart Failure) Trial^15^
13 The VecTOR (Ventricular Resynchronization Therapy Randomized) Trial^16^
14 The RHYTHM ICD (Resynchronization for Hemodynamic Treatment for Heart Failure Management) Trial^17^

Publication Status. Eleven of these trials have been published, and 3 three were located from other sources as mentioned in Figure 2. Seven of the trials were conducted in North America, and the other seven were conducted in Europe. Characteristics of the trials are summarized in Table 4.

Table 4 Description of studies in the efficacy review: CRT alone or combined CRT-ICD devices

Author Year | Country | Design | Control | Participants | | | | | | Device | Authors' primary outcomes | Other outcomes
Trial Name | | Duration | | Number enrolled | Number excluded | Number randomized | Number in treatment* | Number in Control* | Number of withdrawals | Method of implant
CRT alone
Abraham^4^ 2002 | United States, Canada (45 sites) | RCT parallel | Pacer inactive | 571 | NR | 453 | 228 | 225 | Treatment | Medtronic InSync^®^ 8040 | NYHA, QOL, 6MWT | Peak O_2_ consumption, time on treadmill, LVEF, severity of mitral regurgitation, QRS, clinical response, mortality, days in hospital
MIRACLE | | 6 mo. | | | | | | | 1 | Transvenous
| | | | | | | | | Control
| | | | | | | | | 8
Cazeau^5^ 2001 | Europe (15 sites) | RCT cross-over | Pacer inactive | 67 | 3 | 58 | 29 | 29 | Treatment | ELA Chorum™ 7336, Medtronic InSync^®^ 8040 | 6MWT | QOL, NYHA, peak O_2_ uptake, hospitalization due to CHF, patient preference, mortality
MUSTIC-SR | | 3 mo. | | | | | | | 4 | Transvenous
| | | | | | | | | Control
| | | | | | | | | 3
Leclercq^7^ 2002a | Europe (15 sites) | RCT cross-over | RV pacing | 64 | 10 | 43 | 25 | 18 | Treatment | NR | 6MWT | Peak O_2_ consumption, QOL, hospitalization for CHF, mortality, patient preference
MUSTIC-AF | | 3 mo. | | | | | | | 1 | Transvenous
| | | | | | | | | Control
| | | | | | | | | 2
Auricchio^8^ 2002a | Germany, Netherlands (5 sites) | RCT cross-over | Univentricular pacing (4 RV, 36 LV) | 42 | 1 | 41 | 24 | 17 | Treatment | Guidant Vigor^®^, Discovery^®^ | O_2_ uptake at peak exercise, O_2_ uptake at anaerobic threshold, 6MWT | NYHA, QOL
PATH-CHF | | 1 mo. | | | | | | | 2 | Transthoracic
| | | | | | | | | Control
| | | | | | | | | 5
Leclercq^10^ 2003 | France (NR) | RCT cross-over | RV pacing | 56 | NR | 44 | 22 | 22 | Treatment | NR | CHF hospitalization | NYHA, 6MWT, QOL
RD-CHF | | 3 mo. | | | | | | | NR | Transvenous
| | | | | | | | | Control
| | | | | | | | | NR
Kindermann^13^ 2006 | Germany (1 site) | RCT cross-over | RV pacing | 33 | 1 | 32 | 15 | 15 | Treatment | NR | LV end-systolic volume, LVEF, peak O_2_ consumption | NYHA, QOL, serum concentration, exercise testing, echocardiography
HOBIPACE | | 3 mo. | | | | | | | 0 | Transvenous
| | | | | | | | | Control
| | | | | | | | | 1
Cleland^15^ 2005 | Europe (82 sites) | RCT parallel | OPT | NR | NR | 813 | 409 | 404 | Treatment | Medtronic InSync^®^, InSync^®^ III | Composite all-cause mortality or unplanned hospitalization for major CV event | NYHA, QOL
CARE-HF | | 1, 3, 6, 9, 12,18 mo., then every 6 mo. | | | | | | | 14 | Transvenous
| | | | | | | | | Control
| | | | | | | | | 14
St. Jude^16^ 2005 | United States, Canada (41 sites) | RCT parallel | Pacer inactive | 144 | 0 | 106 | 59 | 47 | Treatment | St. Jude Medical Frontier^®^ 5508 | Peak VO_2_ | NYHA, QOL, 6MWT, echocardiographic parameters, mortality
VecTOR | | 6 mo. | | | | | | | 1 | NR
| | | | | | | | | Control
| | | | | | | | | 2
Combined CRT-ICD
Young^6^ 2003 | United States, Canada (53 sites) | RCT (post implant) parallel | CRT off + ICD on | 639 | 270 | 369 | 187 | 182 | Treatment | Medtronic InSync^®^ ICD | NYHA, QOL, 6MWT | Complications, QRS, peak O_2_ uptake, echocardiographic indices, VT response, hospitalization, mortality
MIRACLE-ICD | | 6 mo. | | | | | | | 6 | Transvenous
| | | | | | | | | Control
| | | | | | | | | 5
Higgins^9^ 2003 | United States (47 sites) | RCT | CRT off + ICD on | 581 | 15 | 490 | 245 | 245 | Treatment | Guidant Contak^®^ CD 1823 | Mortality, CHF hospitalization, VT requiring device therapy | Peak O_2_ consumption, 6MWT, QOL, complications
CONTAK-CD | | Phase I period 1 cross-over 3 mo.; Phase II parallel 6 mo. | | | | | | | 3 | Transvenous, transthoracic
| | | | | | | | | Control
| | | | | | | | | 1
Abraham^14^ 2004 | United States (53 sites) | RCT parallel | CRT off + ICD on | 222 | 36 | 186 | 85 | 101 | Treatment | Medtronic InSync^®^ ICD 7272 | Peak VO_2_ | VO_2_max, NYHA, QOL, 6MWT, LV volumes, LVEF, change in clinical status
MIRACLE-ICD II | | 6 mo. | | | | | | | 3 | NR
| | | | | | | | | Control
| | | | | | | | | 3
St. Jude^17^ 2004a | United States (49 sites) | RCT parallel | CRT off + ICD on | 205 | 1 | 179 | 119 | 59 | Treatment | St. Jude Medical Epic™ HF ICD | Complications | VF detection times, peak VO_2_, NYHA,6MWT, mortality
RHYTHM ICD | | 12 mo. | | | | | | | 3 | NR
| | | | | | | | | Control
| | | | | | | | | 0
CRT alone and combined CRT-ICD
Bristow^11^ 2004 | United States (128 sites) | RCT parallel 3 arms | OPT | NR | NR | 1,520 | CRT = 617; CRT + ICD = 595 | 308 | Treatment | Guidant Contak^®^ TR models 1241, 4510–4513, Contak^®^ CD 1823 | All-cause mortality, hospitalization | Cardiac morbidity, peak O_2_ uptake at exercise, complications, implant success
COMPANION | | 15 mo. | | | | | | | 37 | Transvenous
| | | | | | | | | Control
| | | | | | | | | 42
Auricchio^12^ 2003 | Germany, Netherlands (9 sites) | RCT cross-over | Pacer inactive | 101 | NR | 86 | 43 | 43 | Treatment | Guidant (various models) | Exercise capacity, peak VO_2_, VO_2_ max, 6MWT | NYHA, QOL
PATH-CHF II | | 3 mo. | | | | | | | 5 | Transvenous thoracotomy
| | | | | | | | | Control
| | | | | | | | | 9

CHF = congestive heart failure; CRT = cardiac resynchronization therapy; CRT+ICD = CRT with implanted cardioverter defibrillator; LV = left ventricular; LVEF = left ventricular ejection fraction; NA = not applicable; NR = not reported; NYHA = New York Heart Association class; O_2_ = oxygen; OPT = optimal pharmacological therapy; QOL = quality of life; RCT = randomized controlled trial; RV = right ventricular; 6MWT = 6-minute walk test; VO_2_ max = maximal oxygen consumption; VA = ventricular arrhythmia; VT = ventricular tachycardia

* The intervention that patients in crossover studies received in the first period

Trial Participants (Table 5). In total, 4,892 patients were enrolled in these trials and 4,420 (90.3 percent) were randomized to receive CRT (n = 2,703) or control (n = 1,717). Of the patients in the intervention arms, 1,310 (48 percent) received CRT alone and 1,393 (52 percent) received a CRT-ICD device. The majority of those who were enrolled but not randomized had failed implant attempts. The mean age of enrolled patients (in the 11 studies^4^–^9,^ ^13,^ ^14,^ ^16^ that reported patient age) was 65.4±10.8 years and 72 percent were male (in the 12 studies that reported patient gender^4^–^9,^ ^11^–^16^). Approximately 79 percent of trial participants were considered NYHA class III at baseline (range 0 to 100 percent), and 12 percent were classified as NYHA class IV at baseline (range 0 to 67 percent). Five trials included patients with NYHA class II symptoms (range 6 to 33 percent in four trials^9,^ ^16,^ ^17^ and 100 percent in the fourth trial^14^)—approximately 9 percent of all trial participants were judged to be NYHA Class II at baseline. Five trials specified a 6-minute walk test result of less than 450 meters as an inclusion criterion.^4,^ ^5,^ ^7,^ ^16,^ ^17^ The physical exam findings at baseline were similar among trials with systolic blood pressure (range 110 to 118 mm Hg), diastolic blood pressure (range 67 to 70 mm Hg), and heart rate (range 69 to 80 bpm) all similar to other trials in heart failure. No trial specifically recruited patients based on the etiology of their heart failure, although patients with uncorrectable valvular disorders and hypertrophic or restrictive cardiomyopathy were excluded from all trials. In the six trials that evaluated CRT-ICDs, the majority of patients had ischemic etiology (~59 percent);^6,^ ^9,^ ^11,^ ^12,^ ^14,^ ^17^ in the other trials, ischemic etiology ranged from 37 percent^5^ to 55 percent.^4^

Left Ventricular Ejection Fraction. Although PATH-CHF^8^ did not specify LVEF in entry criteria, 11 trials enrolled patients with LVEF < 35 percent, 1 trial^12^ enrolled those patients with LVEF < 30 percent, and 1 trial^13^ specified LVEF < 40 percent as an entry criterion. The mean ejection fractions were similar in all trials, and ranged from 21 to 30 percent. Nine trials also specified a left ventricular end diastolic diameter: ≥ 55 mm in four trials^4,^ ^6,^ ^14,^ ^16^ and ≥ 60 mm in the other four trials.^5,^ ^7,^ ^11,^ ^13^ The reported mean left ventricular end diastolic diameters for the trials were similar (66 to 75 mm).

QRS Width. QRS width was a criterion for all but one of the trials, with five trials specifying ≥ 120 msec, ^8,^ ^9,^ ^11,^ ^12,^ ^15^ three trials ≥ 130 msec,^4,^ ^6,^ ^14^ one trial > 140 msec,^16^ two trials > 150 msec,^5,^ ^17^ one trial > 180 msec,^10^ and one trial > 200 msec.^7^ Twelve of the 14 trials had a mean QRS between 155 msec and 175 msec, with the MUSTIC-AF trial having a mean QRS of 209 msec and RD-CHF having a mean QRS of 206 msec. Left bundle branch block was present in most patients (mean 64 percent; range 0 to 100 percent).

Rhythm. Nine trials^4,^ ^5,^ ^8,^ ^9,^ ^11,^ ^12,^ ^15^–^17^ were restricted to patients in normal sinus rhythm, one was restricted to patients with atrial fibrillation,^7^ and patients with atrial fibrillation constituted between 14 and 52 percent of trial participants in the three trials^6,^ ^10,^ ^13^ that enrolled patients with or without atrial fibrillation (5 percent of all trial participants had atrial fibrillation). One trial^14^ made no mention of whether or not patients with atrial fibrillation were included. Only one trial^13^ recruited patients with symptomatic bradycardia and an indication for traditional RV pacing, and two trials^8,^ ^11^ required a prolonged PR interval > 150 msec for inclusion (four trials reported PR intervals that ranged from 195 to 215 msec).

In the four trials testing combined CRT-ICD against ICD alone,^6,^ ^9,^ ^14,^ ^17^ there was a general requirement that study patients meet indications for ICD placement. (Note that although 34 of the 86 patients in PATH-CHF II had a combined CRT-ICD device, results for this subgroup were not reported separately.) Although it was not specified by which ICD criteria patients were evaluated, the indications in MIRACLE ICD^6^ and CONTAK-CD^9^ were consistent with the AHA/ACC guidelines for secondary prevention at the time of enrollment.^262^

Medications. Medication use was specified in all but three trials.^8,^ ^10,^ ^16^ ACE inhibitors were required or were taken by the vast majority of participants in all trials, beta-blockers were required in three trials,^4,^ ^11,^ ^13^ and spironolactone was required in one trial.^11^ Baseline medication use in the efficacy review trials is detailed in Table 5. Three trials reported that approximately one-third of trial participants used amiodarone,^5,^ ^8,^ ^13^ and between 24 and 38 percent of patients in three other trials^6,^ ^14,^ ^17^ were on non-beta-blocker anti-arrhythmic agents. Digoxin was used in 43 to 76 percent of patients, with four of the five largest trials having at least 75 percent of their patients on digoxin.^4,^ ^6,^ ^9,^ ^11,^ ^15^

Design. Nine of the trials employed a parallel study design.^4,^ ^6,^ ^9,^ ^11,^ ^14^–^17^ One of these had planned a crossover period but was required to change its protocol mid-study and excluded crossover data from its analysis;^9^ five others completed a crossover design.^5,^ ^7,^ ^8,^ ^12,^ ^13^ The duration of treatment was 4 weeks in PATH-CHF;^8^ 3 months per phase in MUSTIC AF,^7^ MUSTIC SR,^5^ PATH-CHF II,^12^ and HOBIPACE;^13^ 6 months in MIRACLE,^4^ MIRACLE ICD,^6^ MIRACLE ICD II,^14^ VecTOR,^16^ and RHYTHM ICD;^17^ 12 months in the COMPANION^11^ trial; and a mean of 29 months in the CARE-HF trial.^15^ Thirteen of the 14 trials used a transvenous approach for placement of the epicardial leads (54 patients in CONTAK-CD^9^ required a transthoracic approach), while PATH-CHF^8^ used a transthoracic approach (in PATH-CHF II^12^ 61 of 86 patients implanted with devices had this done transthoracically and 25 had transvenous implants performed).

Timing of Randomization. Eleven of the trials (n = 2,166 patients) randomized patients after successful CRT implantation; 3 trials (n = 2,439 patients) randomized patients before attempted CRT implantation.^11,^ ^15,^ ^16^ We explored the influence of randomization timing on efficacy results in meta-regression analysis as discussed later in this document.

Description of Each Trial.

Parallel-Arm trials. The MIRACLE trial^4^ enrolled 453 patients (NYHA Class III or IV); 228 were randomized to CRT “on,” 225 to CRT “off” after device implantation and the primary outcomes were quality of life, 6-minute walk test, and NYHA class.

The MIRACLE-ICD trial^6^ randomized 369 patients with NYHA Class III/IV symptoms at baseline: 187 to CRT “on” and 182 to CRT “off” after device implantation. All patients in MIRACLE-ICD^6^ received an ICD and the primary outcomes were quality of life, 6-minute walk test, and NYHA class.

CONTAK-CD^9^ was a two-part trial with an initial pilot crossover involving two 3-month phases and a parallel design study with 6-month followup in the second part. The primary outcome was progression of heart failure (all-cause mortality, HF hospitalization, and ventricular tachycardia/fibrillation requiring ICD intervention). As with MIRACLE-ICD, all patients in CONTAK-CD were implanted with a device with ICD capabilities and were randomized to CRT “on” or “off” after device implantation. The primary outcome was a composite of all-cause mortality, HF hospitalizations, and ventricular arrhythmias requiring device intervention.

COMPANION^11^ was a three-arm, parallel-group trial that compared optimal pharmacological therapy (n = 308), CRT alone (n = 617), and combined CRT-ICD (n = 595) randomized in a 1:2:2 manner before device implantation. The primary outcome was a composite of all-cause mortality and all-cause hospitalization (including emergency department [ED] presentations or unscheduled office visits requiring >4 hours of intravenous vasoactive or inotropic drugs).

The MIRACLE ICD II trial^14^ randomized 186 patients with an indication for an ICD and NYHA class II symptoms to CRT “on” or “off” after device implantation (all patients in both groups had the ICD function turned on). The primary outcome was change in peak VO_2_ from baseline and a variety of functional assessments were collected.

The CARE-HF trial^15^ randomized 813 patients (NYHA Class III or IV) to either medical therapy plus CRT (n = 409) or medical therapy alone (n = 404); randomization was before device implantation. The primary outcome was a composite of all-cause death or unplanned hospitalization for major cardiovascular event.

The VecTOR trial^16^ randomized 106 patients to either CRT “on” or “off” for 6 months, then all patients received CRT “on”—the outcomes were presented at 6 months (before all patients were crossed into the “on” arm). Randomization in VecTOR was conducted before device implantation.

The RHYTHM ICD Trial^17^ randomized 183 patients after device implantation to having the CRT function on their device on or off (all patients in both groups had the ICD function turned on).

Crossover Trials. In MUSTIC SR,^5^ 67 patients were enrolled and implantation attempted, followed by 8 to 12 weeks of observation; 58 patients were then randomized into a 3-month crossover of either CRT “on” or “off” phases after device implantation (Phase 1: n = 29, Phase 2: n = 29).

In MUSTIC AF,^7^ 64 patients were enrolled and implantation attempted, followed by 8 to 12 weeks of observation; 43 were then randomized into a 3-month crossover of CRT “on” or “off” phases after device implantation (Phase 1: n = 25, Phase 2: n = 18). Both trials used the 6-minute walk test as the primary outcome. Neither trial used a washout period between phases and neither detected a carryover effect.

PATH-CHF^8^ was a 4-week crossover study in which 42 patients were enrolled and implantation attempted; 41 patients were then randomized to CRT “on” or “off” in two phases after device implantation with a 4-week washout period between the two phases (Phase 1: n = 24, Phase 2: n = 17). The primary endpoint was peak oxygen uptake on a maximal exercise test. This trial did detect a carryover effect.

PATH-CHF II^12^ was a 6-month crossover study in which 86 patients had a CRT device implanted (34 of whom had a device with ICD capabilities) and were randomized to LV pacing lead “on” or “off” in two phases after device implantation without a washout phase. The primary endpoint was change in exercise capacity.

HOBIPACE^13^ was a 3-month crossover study in which 33 patients with indications for a conventional pacemaker had a CRT device implanted and were randomized to biventricular pacing or RV pacing in two phases after device implantation and medication optimization, without a washout phase.

Subgroup Analyses. Subgroup analyses were reported in seven of these trials,^4,^ ^6,^ ^9,^ ^11^–^13,^ ^15^ although three trials^11,^ ^12,^ ^15^ reported that their subgroups were specified a priori and only two^12,^ ^15^ stratified their randomization by subgroups. The subgroups reported in each trial were:

- MIRACLE: beta-blockers, ischemic etiology, LVEF, left or right bundle branch block, QRS duration, sex, age;
- MUSTIC-SR: none reported;
- MIRACLE ICD: beta-blocker, underlying heart disease (ischemic vs nonischemic), morphology of the QRS complex (left vs right bundle branch block), QRS duration;
- MUSTIC AF: none reported;
- PATH-CHF: none reported;
- CONTAK-CD: beta-blockers, ischemic etiology, LVEF, left or right bundle branch block, QRS duration, sex, age;
- RD-CHF: none reported;
- COMPANION: age, sex, ischemic etiology, NYHA, LVEF, LVEDD, QRS, LBBB, heart rate, systolic BP, diastolic BP, ACE inhibitor, beta-blocker, loop diuretic, spironolactone
- PATH-CHF II: QRS duration;
- HOBIPACE: atrial fibrillation, bundle branch block pattern, site of LV lead placement
- MIRACLE ICD II: none reported;
- CARE-HF: Age, sex, NYHA, dilated cardiomyopathy, systolic blood pressure, brain natriuretic peptide, LVEF, end-systolic volume index, QRS, IMD, glomerular filtration rate, medication;
- VecTOR: none reported; and
- RHYTHM ICD: none reported

Subgroup effects were tested using appropriate statistical methods (i.e., treatment*subgroup interaction (or heterogeneity) test) in 3 of these trials.^9,^ ^11,^ ^15^ The MIRACLE trial presented subgroup-stratified analyses but didn't report an interaction test. The 3 most frequently examined subgroups (and number of trials doing so) were QRS duration (6 trials), bundle branch block pattern (5 trials), and ischemic etiology (5 trials).

### ICD Alone

Twelve randomized trials^11,^ ^133^–^143^ met the inclusion criteria for the efficacy review and are listed below:

Primary Prevention Trials (i.e., trial participants did not have history of ventricular fibrillation or ventricular tachycardia requiring resuscitation):

1 MADIT (Multicenter Automatic Defibrillator Implantation Trial)^133^
2 The CABG Patch (Coronary Artery Bypass Graft Patch) Trial^134^
3 MADIT II (Multicenter Automatic Defibrillator Implantation Trial II)^135^
4 The CAT (Cardiomyopathy) Trial^136^
5 AMIOVIRT (Amiodarone vs. Implantable Defibrillator Randomized Trial)^137^
6 The DEFINITE (Defibrillators in Non-Ischemic Cardiomyopathy Treatment Evaluation) Trial^138^
7 DINAMIT (Defibrillator in Acute Myocardial Infarction Trial)^139^
8 SCD-HeFT (Sudden Cardiac Death in Heart Failure Trial) ^140^
9 The COMPANION (Comparison of Medical Therapy, Pacing, and Defibrillation in Chronic Heart Failure) Trial^11^

Secondary Prevention Trials (i.e., in patients with history of ventricular fibrillation or ventricular tachycardia requiring resuscitation):

1 The AVID (Antiarrhythmics Vs. Defibrillators) Trial^141^
2 The CIDS (Canadian Implantable Defibrillator Study) Trial^142^
3 The CASH (Cardiac Arrest Study Hamburg) Trial^143^

Publication Status. All of these trials have been published, and supplemental data were located from other sources as mentioned in Figure 2. Characteristics of the trials are summarized in Table 6.

Table 6 Description of studies included in the efficacy review: ICD alone

Author Year | Country | Design | Treatment | Control | Participants | | | | | Device | Outcomes
Study name | | Duration | | | Number enrolled | Number randomized | Number in treatment | Number in control | Number of withdrawals | Method of implant
| | Type of outcomes
Primary prevention
Moss^133^ 1996 | United States, Germany, Italy | RCT parallel | ICD | OPT | 253 | 196 | 95 | 101 | 18 | Guidant | All-cause mortality, arrhythmic death
MADIT | | 27mo. | | | | | | | | Transthoracic, transvenous
| | Efficacy, safety
Bigger^134^ 1997 | United States, Germany | RCT parallel | CABG+ ICD | CABG + usual care | 1,055 | 900 | 446 | 454 | 70 | Guidant | All-cause mortality, time to shock, adverse events
CABG-Patch | | 32 mo. | | | | | | | | Epicardial
| | Efficacy, safety
Moss^135^ 2002 | United States, Europe | RCT parallel | ICD | OPT | NR | 1,232 | 742 | 490 | 3 | NR | All-cause mortality adverse events
MADIT II | | 20 mo. | | | | | | | | Transvenous
| | Efficacy, safety
Bänsch^136^ 2002 | Germany | RCT parallel | ICD | Usual care | 104 | 104 | 50 | 54 | 0 | Guidant Ventak^®^ P2, P3, PrX II, CPI | All-cause mortality, sustained VT, VT requiring treatment, adverse events, inappropriate shocks
CAT | | 66 mo. | | | | | | | | Transvenous
| | Efficacy, safety
Strickberger^137^ 2003 | United States | RCT parallel | ICD | Amiodarone | NR | 103 | 51 | 52 | NR | NR | All-cause mortality, sudden cardiac death, QOL, cost, appropriate therapy
AMIOVIRT | | 2 yr. | | | | | | | | Transvenous
| | Efficacy
Bristow^11^ 2004 | United States | RCT parallel 3 arms | ICD+CRT | OPT | NR | 1,520 | CRT = 617; CRT+ ICD = 595 | 308 | Treatment = 37 Control = 42 | Guidant Contak^®^ TR models 1241, 4510–4513, Contak^®^ CD 1823 | All-cause mortality, hospitalization, cardiac morbidity, peak O_2_ uptake at exercise, complications, implant success
COMPANION | | 15 mo. | CRT | | | | | | | Transvenous
| | Efficacy, safety
Kadish^138^ 2004 | United States, Israel | RCT parallel | ICD | OPT | NR | 458 | 229 | 229 | 6 | St Jude | All-cause mortality, adverse events
DEFINITE | | 29 mo. | Single chamber | | | | | | | NR
| | Efficacy, safety
Hohnloser^139^ 2004 | Europe, Canada, United States | RCT parallel | ICD | OPT | NR | 674 | 332 | 342 | 24 | St Jude | All-cause mortality, adverse events
DINAMIT | | 30 mo. | Single chamber | | | | | | | NR
| | Efficacy, safety
Bardy^140^ 2005 | United States, Canada | RCT parallel 3 arms | ICD | Amiodarone, placebo | NR | 2,521 | 829 | Amiodarone = 845, Placebo = 847 | 50 | Medtronic 7223 | All-cause mortality, inappropriate shocks
SCD-HeFT | | 46 mo. (median) | single chamber | | | | | | | NR
| | Efficacy, safety
Secondary prevention
Antiarrhythmics vs. Implantable Defibrillators (AVID) | United States | RCT parallel | ICD | Amiodarone or Sotalol | 1,885 | 1,016 | 505 | 509 | 2 | Guidant, Medtronic, Ventritex, Sulzer Intermedics | All-cause mortality, QOL, cost, adverse events, time to rehospitalization
Investigators^141^ 1997 | | 18 mo. | | | | | | | | Transvenous, epicardial
AVID | | Efficacy, safety
Connolly^142^ 2000 | Canada | RCT parallel | ICD | Amiodarone | NR | 659 | 328 | 331 | NR | NR | All-cause mortality, arrhythmic death, adverse events
CIDS | | 35 mo. | | | | | | | | Transvenous, thoracotomy
| | Efficacy, safety
Kuck^143^ 2000 | Germany | RCT parallel 3 arms | ICD | Metoprolol | 293 | 288 | 99 | Metoprol = 97, | NR | Guidant Ventak^®^ AID, Ventak^®^ AICD, Ventak^®^ P, Ventak^®^ PRx, Ventak^®^ Mini™ | All-cause mortality, sudden cardiac death
CASH | | 57 mo. | | Amiodarone | | | | Amiodarone = 92 | | Epicardial, endocardial
| | Efficacy, safety

DER = defibrillation energy requirement; EPS = electrophysiological study; ICD = implanted cardioverter defibrillator; LV = left ventricular; LVEF = left ventricular ejection fraction; NA = not applicable; NR = not reported; OPT = optimal pharmacological therapy; QOL = quality of life; RCT = randomized controlled trial; RV = right ventricular; VO_2_ max = maximal oxygen consumption; VA = ventricular arrhythmia; VF = ventricular fibrillation; VT = ventricular tachycardia

Trial Participants (Table 7). In total, 8,516 patients were randomized in these trials to receive ICD (n = 4,301) or control (n = 4,215). The mean age of enrolled patients was 60.8 ± 4.2 years and 74 percent were male. The majority of trial participants had HF symptoms (in the trials that reported baseline functional class, 50 percent had NYHA class II symptoms at baseline, 36 percent NYHA class III symptoms, and 3 percent Class IV functional status). Seven trials enrolled asymptomatic patients (i.e., those with NYHA class I HF), and this percent ranged from 13 to 37 percent in these trials such that 11 percent of all ICD trial participants with left ventricular systolic dysfunction did not have HF symptoms at baseline.^142^ Most trials excluded Class IV patients. Four trials enrolled patients that had an ischemic etiology for their left ventricular dysfunction,^133^–^135,^ ^139^ 3 trials enrolled patients with a non-ischemic dilated cardiomyopathy^136^–^138^ and 5 trials included either etiology.^11,^ ^140^–^143^ Of note, patients with other indications for defibrillators were not enrolled in these trials, nor were patients with acute myocarditis, hypertrophic/ restrictive/or constrictive cardiomyopathy, or arrhythmogenic right ventricular dysplasia.

Left Ventricular Ejection Fraction. Although all trials enrolled patients with left ventricular systolic dysfunction (mean LVEF ranged from 21 percent to 28 percent in the primary prevention trials and from 32% to 46% in the secondary prevention trials), they used different entry criteria for ejection fraction: ≤30 percent;^135,^ ^136^ ≤35 percent,^11,^ ^133,^ ^134,^ ^137^–^140^; and ≤40 percent.^141^ Two trials did not specify an ejection fraction in their eligibility criteria but their mean ejection fractions were 34 percent^142^ and 46 percent.^143^

ECG Criteria. Of the primary prevention trials, all but 3 trials specified other electrocardiographic entry criteria to identify high risk patients.^135,^ ^136,^ ^140^ The other “primary prevention” trials identified higher risk patients for study using non-sustained ventricular tachycardia,^133,^ ^137,^ ^138^ elevated heart rate or reduced heart rate variability,^139^ or abnormal signal-averaged ECG^134^ as markers of increased risk.

Medications. Baseline medication use varied substantially, in part due to the range of years in which the trials were initiated and completed (Table 7). One trial enrolled the first patient before 1990,^143^ 5 trials between 1990 and 1995, ^133,^ ^134,^ ^136,^ ^141,^ ^142^ 5 trials between 1996 and 2000,^135,^ ^137^–^140^ and in one trial it was unclear.^11^ Baseline beta-blocker use varied between trials (4 to 87 percent), as did digoxin use (20 to 86 percent) and angiotensin-converting enzyme inhibitor use (42 to 96 percent).

Design. All trials employed a parallel study design and all randomized patients prior to implantation of the ICD. ICDs were compared to usual care,^133^–^136,^ ^138,^ ^139^ amiodarone alone,^137,^ ^141,^ ^142^ amiodarone or placebo, ^140^ and amiodarone or metoprolol.^143^ In the COMPANION trial, 2 of the 3 study arms (CRT vs. optimal medical therapy) were used in the CRT review while data from the combined CRT-ICD and CRT alone arms were used in the ICD analyses.^11^ In the trials in which amiodarone was not a comparator, amiodarone use ranged from 4 to 13 percent, with 84 percent of patients in the MADIT trial being placed on non-trial anti-arrhythmic agents.

Type of ICD. The type of devices used for the trials were unspecified^137^, epicardial or endocardial,^133,^ ^141^–^143^ epicardial only^134^ or endocardial only.^11,^ ^135,^ ^136,^ ^138^–^140^ Devices were specified to be single-chamber ICD in all but the COMPANION and MADIT-II trials, but protocol adherence to a single-chamber device was not reported in any trial.^11,^ ^135^ The MADIT-II Trial subsequently reported that 44% of intervention arm devices were in fact dual-chamber ICD in a second publication.^263^

Description of Each Trial:

Primary Prevention Trials. MADIT randomized 196 patients with a prior myocardial infarction and NYHA I-III to either an ICD (n = 95) or usual care (n = 101).^133^

CABG Patch enrolled 900 patients with ischemic cardiomyopathy undergoing CABG and abnormal signal-averaged ECG to either an ICD (n = 446) or usual care (n = 454).^134^

MADIT II enrolled 1,232 patients with a prior myocardial infarction >1 month prior and NYHA I-III to an ICD (n = 742) or usual care (n = 490) in a 3:2 manner.^135^

The Cardiomyopathy Trial (CAT) enrolled 104 patients with a dilated cardiomyopathy ≤ 9 months in duration to an ICD (n = 50) or usual care (n = 54).^136^

AMIOVIRT randomized 103 patients with non-ischemic cardiomyopathy with non-sustained VT, to either amiodarone (n = 52) or an ICD (n = 51).^137^

DEFINITE enrolled 458 patients with a non-ischemic dilated cardiomyopathy and NSVT to an ICD (n = 229) or usual care (n = 229).^138^

DINAMIT randomized 674 patients between 6 and 40 days post-MI with impaired autonomic function to an ICD (n = 332) or usual care (n = 342).^139^

SCD-HeFT enrolled 2,521 patients with either ischemic or non-ischemic NYHA II-III heart failure to an ICD (n = 829), amiodarone (n = 845) or placebo (n = 847). ^140^

COMPANION (described in full in the CRT trial section above) enrolled 1,520 patients randomized to optimal medical therapy (n = 308), CRT alone (n = 617) or CRT-ICD (n = 595).^11^

Secondary Prevention Trials. The AVID trial enrolled 1,016 patients (resuscitated after near-fatal VF, sustained VT with syncope or sustained VT with LVEF < 40 percent) randomized to an ICD (n = 507) or drug therapy (n = 509), mainly amiodarone.^141^

CIDS randomized 659 patients resuscitated from a cardiac arrest, or with ventricular tachycardia or fibrillation to either an ICD (n = 328) or amiodarone (n = 331).^142^

CASH randomized patients resuscitated from a cardiac arrest to one of four arms (ICD, amiodarone, metoprolol, or propafenone) in a 1:1:1:1 manner.^143^ The propafenone arm was stopped early due to increased harm, and the remaining 288 patients were randomized to an ICD (n = 99), amiodarone (n = 92), or metoprolol (n = 97).

Subgroup Analyses. Subgroup analyses were reported in 11 of these trials - 9 trials reported that their subgroups were specified a priori and 6 stratified their randomization by subgroups. The subgroups reported in each trial were:

Primary Prevention Trials:

- MADIT: age, sex, cardiac history (including NYHA class, treatment for VT, CHF, hypertension, IDDM, smoking, CABG, angioplasty, pacemaker), interval since MI, pulmonary edema, urea, cholesterol, LBBB, LVEF, NSVT, EP study results;
- CABG Patch: ischemic etiology, heart failure, diabetes, NYHA class, sex, age, LVEF, QRS, angiotensin-converting enzyme inhibitors, beta-blocker, class I or III antiarrhythmics;
- MADIT II: ischemic etiology, NYHA class, sex, age, LVEF, QRS, LBBB, time from MI, diabetes, hypertension, atrial fibrillation, type of ICD, urea;
- CAT: ischemic etiology, NYHA, sex, age, LVEF, LVEDD, LVESD, QRS, rhythm, Q-T interval, Holter findings, EP study findings, medications;
- AMIOVIRT: none reported;
- DEFINITE: amiodarone, age, sex, LVEF, QRS, NYHA, atrial fibrillation;
- COMPANION: age, sex, ischemic etiology, NYHA class, LVEF, LVEDD, QRS, LBBB, heart rate, systolic BP, diastolic BP, ACE inhibitor, beta-blocker, loop diuretic, spironolactone;
- DINAMIT: ischemic etiology, diabetes, NYHA class, sex, age, LVEF, QRS, atrial fibrillation, NSVT, heart rate, SDRR, reperfusion method; and
- SCD-HeFT: ischemic etiology, NYHA class, sex, age, race, LVEF, QRS, 6-minute walk test, beta-blocker, diabetes.

Secondary Prevention Trials:

- AVID: age, LVEF, etiology, qualifying arrhythmia, beta-blockers, heart failure, revascularization, atrial fibrillation;
- CIDS: age, sex, index arrhythmia, LVEF, NYHA class, etiology; and
- CASH: LVEF, NYHA class, ischemic etiology

Subgroup effects were tested using appropriate statistical methods (i.e., treatment × subgroup interaction or heterogeneity tests) in all but two of these trials.^137,^ ^139^ Six trials presented the results of their subgroup analysis in the primary manuscript.^11^ The three most frequently examined subgroups were LVEF (tested in 11 trials), NYHA class (examined in 10 trials, and age (examined in 10 trials).^138,^ ^140,^ ^141,^ ^143^

## Description of Included Studies: Effectiveness Review

### CRT Alone or Combined CRT-ICD Devices

In addition to the 14 RCTs, an additional 106 studies met the inclusion criteria for the review of effectiveness of CRT alone or combined CRT-ICD devices (Table 8). Forty-two of these studies met the inclusion criteria for the review of effectiveness but not safety. The 106 studies included two controlled clinical trials (CCTs), 91 prospective cohort studies' and 13 retrospective cohort studies. Sixty of these studies looked at CRT alone; the other 46 looked at a mix of patients receiving CRT alone and a combined CRT-ICD device. Sixty-eight studies reported that devices were implanted transvenously, two transthoracically,^56,^ ^97^ and five used a mixture of approaches.^12,^ ^63,^ ^73,^ ^84,^ ^86^ Medtronic Inc., Guidant Corp., ELA Medical, St. Jude Medical Inc., or Biotronik manufactured all implanted devices; the models and leads varied among and within trials.

Table 8 Description of studies in the effectiveness and safety reviews: CRT alone or combined CRT-ICD devices

Author | | Design | | | Participants
Year | Study location | Duration | Treatment | Control | Number enrolled | Number randomized | Number in treatment* | Number in control* | Number of withdrawals | Device | Outcomes
Trial name | | Type of outcomes | | | | | | | | Method of implant
CRT alone
Abraham^4^ 2002 | United States, Canada | RCT parallel | CRT | Pacer inactive | 571 | 453 | 228 | 225 | 9 | Medtronic InSync^®^ 8040 | NYHA, QOL, 6MWT, peak O_2_ consumption mortality, days in hospital
MIRACLE | | 6 mo. | | | | | | | | Transvenous
| | Efficacy, safety
Achilli^18^ 2003 | Italy | Prospective cohort | CRT | NA | 52 | NA | 52 | NA | 0 | NR | Interventricular asynchrony, 6 MWT, mortality
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness
Adamson^19^ 2004 | United States | Prospective cohort | CRT | NA | 397 | NA | 288 | NA | 0 | Medtronic In Syn^®^ III 8042 | Heart rate variability, mortality, hospitalization
InSync III | | 12 mo. | | | | | | | | NR
| | Effectiveness
Albertsen^20^ 2005 | Denmark | Prospective cohort | CRT | NA | 120 | NA | 114 | NA | 0 | Guidant 1241; InSync^®^ 8040, 8042 | Mortality, complications
| | 16.7 mo. | | | | | | | | NR
| | Effectiveness, safety
Ansalone^23^ 2002 | Italy | Prospective cohort | CRT | NA | 31 | NA | 31 | NA | 0 | NR | LVEF, NYHA
| | 1 mo
| | Effectiveness
Aranda^24^ 2005 | United States | Retrospective cohort | CRT | NA | 60 | NA | 52 | NA | 0 | NR | Change in beta-blocker treatment post CRT, NYHA, 6MWT, LVEF, VO_2_ max
| | 6 mo.
| | Effectiveness
Auricchio^8^ 2002a | Germany, Netherlands | RCT crossover | CRT | Univentricular pacing (4 RV, 36LV) | 42 | 41 | 24 | 17 | 7 | Guidant Vigor^®^, Discovery^®^ Transthoracic | O_2_ uptake at peak exercise, O_2_ uptake at anaerobic threshold, 6MWT, NYHA, QOL
PATH-CHF | | 1 mo.
| | Efficacy, safety
Auricchio^25^ 2002b | Germany | Retrospective cohort | CRT | NA | 135 | NA | 50 | NA | 0 | NR | Changes in metabolic, ventilation and heart rate parameters, NYHA, LVEF
| | 3 mo. | | | | | | | | Transvenous, thoracotomy
| | Effectiveness
Baker^27^ 2002 | United States | Prospective cohort | CRT | NA | 60 | NA | 60 | NA | 6 | NR | Fesaibility of upgrade from RV to LV pacing, LVEF, NYHA, complications
| | 18 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Bax^28^ 2003 | Netherlands | Prospective cohort | CRT | NA | 25 | NA | 25 | NA | 0 | NR | NYHA, 6MWT, QOL, LVEF
| | 6 mo.
| | Effectiveness
Bleeker^30^ 2005a | Netherlands | Prospective cohort | CRT | NA | 170 | NA | 170 | NA | NR | Guidant Contak^®^ TR, Contak^®^ CD; Medtronic InSync^®^ III, InSync^®^ CD | Mortality, NYHA, QOL, 6MWT, LVEF
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness safety
Bleeker^31^ 2005b | Netherlands | Prospective cohort | CRT | NA | 56 | NA | 56 | NA | 0 | Contak^®^ TR or CD | Evaluate RV remodeling post CRT
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Bleeker^32^ 2006 | Netherlands | Prospective cohort | CRT | NA | 100 | NA | 100 | NA | 0 | Guidant Contak^®^ TR, Renewal™ TR2/1/2/4; Medtronic InSync^®^ Marquis™ III, Sentry | NYHA, 6MWT, QOL, QRS, LVEF
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Bonanno^34^ 2004 | Italy | Prospective cohort | CRT | NA | 37 | NA | 37 | NA | | Medtronic InSync^®^ 8040, 8042, InSync^®^ ICD^®^ 7272; | NYHA, LVEF
| | 8.2 mo. | | | | | | | | Transvenous
| | Effectiveness
Bordachar^35^ 2004 | France | Prospective cohort | CRT | NA | 41 | NA | 41 | NA | 0 | Medtronic Insync^®^ III | 6MWT, QOL
| | 3 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Boriani^38^ 2006c | Italy | Prospective cohort | CRT | NA | 32 | NA | 32 | NA | 0 | NR | Neurohormones, inflammatory mediators, NYHA, LVEF
| | 3 mo.
| | Effectiveness
Braunschweig^40^ 2005 | Europe | Prospective cohort | CRT | NA | 56 | NA | 56 | NA | 0 | Medtronic Insync^®^ III 8042 | 6MWT, heart rate variability, NYHA
| | 3 mo. | | | | | | | | Transvenous
| | Effectiveness
Cazeau^5^ 2001 | Europe | RCT crossover | CRT | Pacer inactive | 67 | 58 | 29 | 29 | 7 | ELA Chorum™ 7336; Medtronic InSync^®^ 8040 | 6MWT, QOL, NYHA, peak O_2_ uptake, hospitalization due to heart failure, mortality
MUSTIC-SR | | 3 mo. | | | | | | | | Transvenous
| | Efficacy, safety
Cazeau^41^ 2003 | France | Prospective cohort | CRT | NA | 66 | NA | 66 | NA | 0 | NR | NYHA
| | NR | | | | | | | | Transvenous
| | Effectiveness, safety
Chalil^42^ 2006 | United Kingdom | Prospective cohort | CRT | NA | 75 | NA | 75 | NA | 0 | Medtronic InSync^®^ III 8042, InSync^®^ 8040, 8042, Sigma DR | Mortality, SCD
| | 2.2 yr | | | | | | | | Transvenous
| | Effectiveness, safety
Chan^43^ 2003 | Italy, Canada | Prospective cohort | CRT | NA | 95 | NA | 95 | NA | 0 | NR | 6MWT, NYHA, QRS, LVEF
| | 3 mo.
| | Effectiveness
Cleland^15^ 2005 | Europe | RCT parallel1, 3, 6, 9, 12, 18 mo., then every 6 mo. | CRT | OPT | NR | 813 | 409 | 404 | 64 | Medtronic InSync^®^, InSync^®^ III | Composite of all cause mortality or unplanned hospitalization for major CV event, NYHA, QOL
CARE-HF | | Efficacy, safety | | | | | | | | Transvenous
Daubert^46^ 1998 | France | Prospective cohort | CRT | NA | 47 | NA | 47 | NA | 10 | ELA Chorus™ RM 7034, Chorus™ 7234 | Complications, mortality
| | 10.2 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
de Cock^124^ 2004 | Netherlands | Prospective cohort | CRT | NA | 103 | NA | 103 | NA | 0 | NR | Complications
| | 3 mo.
| | Safety
De Martino^125^ 2004 | Italy | Prospective cohort | CRT | NA | 34 | 34 | 34 | NA | 0 | NR | Time to coronary sinus cannulation, complications
| | < 1 mo. | | | | | | | | Transvenous
| | Safety
De Martino^126^ 2005 | Italy | Prospective cohort | CRT | NA | 83 | 83 | 83 | NA | NR | NR | Complications
| | < 1 mo.
| | Safety
Dixon^50^ 2004 | United Kingdom | Prospective cohort | CRT | NA | 27 | NA | 27 | NA | 0 | NR | NYHA, hospitalization, 6MWT, mortality
| | 12 mo.
| | Effectiveness, safety
Galvao^56^ 2002 | Brazil | Prospective cohort | CRT | NA | 28 | NA | 28 | NA | 0 | NR | Mortality, complications, NYHA
| | 5 mo. | | | | | | | | Transvenous, mini-thoracotomy
| | Effectiveness, safety
Gras^58^ 2002 | Europe, Canada | Prospective cohort | CRT | NA | 117 | NA | 103 | NA | NR | Medtronic InSync^®^ 8040 | Feasibility, safety, long term effects, NYHA, QRS, 6MWT, QOL
InSync | | up to 1 yr. | | | | | | | | Transvenous
| | Effectiveness, safety
Hua^60^ 2006 | China | Prospective cohort | CRT | NA | 142 | NA | 142 | NA | 0 | Medtronic 2188 /2187 4189 /4191 4193 | Echocardiograph measures
| | 7 days | | | | | | | | ELA UC28D
| | Effectiveness, safety | | | | | | | | Biotronic lead
| | | | | | | | | | St Jude lead
Kautzner^128^ 2004 | Czechoslovakia | Retrospective cohort | CRT | NA | 138 | NA | 138 | NA | 0 | NR | Success rate of different LV lead insertions
| | 24 mo. | | | | | | | | Transvenous
| | Safety
Kies^62^ 2006 | Netherlands | Retrospective cohort | CRT | NA | 74 | NA | 74 | NA | 0 | InSync^®^ III/CD, Medtronic; Contak^®^ TR/Renewal, Guidant | Conversion from AF to SR; NYHA, QOL, 6MWT
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness
Kindermann^13^ 2006 | Germany | RCT crossover | CRT | RV pacing | 33 | 32 | 15 | 15 | 1 | CRT (triple and dual chamber) | LV end-systolic volume, LVEF, peak O_2_ consumption, NYHA, QOL
HOBIPACE | | 3 mo. | | | | | | | | Transvenous
| | Efficacy, safety
Koos^63^ 2004 | Germany | Retrospective cohort | CRT | NA | 81 | NA | 52 | NA | 7 | NR | Mortality, NYHA, LVEF, complications
| | 12 mo. | | | | | | | | Transvenous, thoracotomy
| | Effectiveness, safety
Leclercq^66^ 2000 | Europe (15 sites) | Prospective cohort | CRT | NA | 37 | NA | 37 | NA | 0 | Medtronic (various models) | 6MWT, peak O_2_ consumption, QOL, hospitalization, mortality
| | 1, 2, 6 mo., then every 6 mo. | | | | | | | | Transvenous, transthoracic
| | Effectiveness, safety
Leclercq^7^ 2002a | France | RCT crossover | CRT | RV pacing | 64 | 43 | 25 | 18 | 5 | NR | 6MWT, peak O_2_ consumption, QOL, hospitalization, mortality
MUSTIC-AF | | 3 mo. | | | | | | | | Transvenous
| | Efficacy, safety
Leclercq^57^ 2002b | France | Prospective cohort | CRT | NA | NR | NA | 125 | NA | NR | NR | Mortality, QRS, NYHA, LVEF, exercise tolerance
| | 1, 3, 6, then every 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Leclercq^10^ 2003 | France | RCT crossover | CRT | RV pacing | 56 | 44 | 22 | 22 | NR | NR | CHF hospitalization, QRS, 6MWT, QOL, NYHA
RD-CHF | | 3 mo. | | | | | | | | Transvenous
| | Efficacy, safety
Lecoq^68^ 2005 | France | Retrospective cohort | CRT | NA | 158 | NA | 139 | NA | 0 | ELA Chorum™ MSP; Guidant Contak^®^; Medtronic InSync^®^ | NYHA, 6MWT, VO_2_ max, QRS, LVEF, hospitalizations, mortality
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Leon^70^ 2005 | United States | Prospective cohort | CRT | NA | 422 | NA | 359 | NA | | InSync^®^ III 8042 Medtronic | 6MWT, NYHA, QoL
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Linder^71^ 2005 | Germany | Prospective cohort | CRT | NA | NR | NA | 42 | NA | 0 | NR | Myocardial oxygen consumption and blood flow, LVEF, NYHA, 6MWT
| | 4 mo.
| | Effectiveness
Macioce^72^ 2005 | Italy | Prospective cohort | CRT | NA | 30 | NA | 30 | NA | 0 | Guidant Contak^®^ TR CHFD; Medtronic InSync^®^ | Functional mitral regurgitation improvement, LVEF, NYHA
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness
Mangiavacchi^74^ 2006 | Italy | Prospective cohort | CRT | NA | 156 | NA | 156 | NA | | NR | Echocardiography, 6MWT
| | 1 yr.
| | Effectiveness
Marai^75^ 2006 | Isreal | Prospective cohort | CRT | NA | 98 | NA | 98 | NA | 0 | NR | NYHA, 6MWT, QRS
| | 3 mo. | | | | | | | | Transvenous
| | Effectiveness
Mascioli^76^ 2002 | Italy | Prospective cohort | CRT | NA | 96 | NA | 68 | NA | 0 | NR | All cause mortality, LVEF, NYHA, hospitalization
| | 36 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Mele^77^ 2006 | Italy | Prospective cohort | CRT | NA | 37 | NA | 37 | NA | 1 | Easytrak, Guidant | Association of baseline LV deformation dyssynchrony with CRT response.
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness
Molhoek^78^ 2002 | Netherlands | Prospective cohort | CRT | NA | 40 | NA | 40 | NA | 0 | Guidant Contak^®^ TR, Contak^®^ CD; Medtronic InSync^®^ III | Clinical benefit, long-term prognosis, NYHA, QOL, 6MWT, hospitalization, mortality
| | Up to 2 yr. | | | | | | | | Transvenous
| | Effectiveness, safety
Mortensen^83^ 2004 | Europe, Canada | Prospective cohort | CRT | NA | 198 | NA | 189 | NA | 15 | Medtronic InSync^®^ III 8042 | 6MWT, NYHA, complications, mortality
InSync III | | 3 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Nagele^85^ 2001 | Germany | Prospective cohort | CRT | NA | 32 | NA | 32 | NA | 0 | Biotronik Triplos DR; ELA Chorus™ MST; Guidant Contak^®^ TR | Complications, NYHA, LVEF
| | 8 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Niu^87^ 2006 | China | Prospective cohort | CRT | NA | 117 | NA | 111 | NA | 6 | Medtronic InSync^®^ 8040, 8042 | Implant complications
| | 1.7 yr | | | | | | | | Transvenous
| | Effectiveness, safety
O'Donnell^89^ 2005 | Australia | Prospective cohort | CRT | NA | 63 | NA | 40 | NA | 0 | Medtronic InSync^®^ III, InSync^®^ III Marquis CRT | NYHA, 6MWT, symptom status, determine optimal programmed settings
| | 9 mo | | | | | | | | Transvenous
| | Effectiveness, safety
Oliva^90^ 2005 | Italy | Prospective cohort | CRT | NA | 258 | NA | 258 | NA | 0 | NR | Clinical and hemodynamic benefits, mortality
| | 20 mo.
| | Effectiveness
Ollitrault^91^ 2003 | France | Prospective cohort | CRT | NA | 62 | NA | 62 | NA | 0 | NR | Complications
| | 15 mo.
| | Effectiveness, safety
Penicka^93^ 2004 | Belgium | Prospective cohort | CRT | NA | 55 | NA | 49 | NA | 0 | Guidant Contak^®^ TR, Contak^®^ CD | LVEF, inter/intraventricular asynchrony, mortality
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Porciani^95^ 2006a | Italy | Prospective cohort | CRT | NA | 30 | NA | 30 | NA | 0 | Medtronic InSync^®^; Guidant Contak^®^ TR CHFD | LV function parameters, NYHA, QoL,
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness
Porciani^96^ 2006b | Italy | Prospective cohort | CRT | NA | 65 | NA | 65 | NA | 0 | NR | All cause mortality or hospitalization for worsening HF
| | 1 yr
| | Effectiveness
Puglisi^97^ 2004 | Italy | Prospective cohort | CRT | NA | 315 | NA | 315 | NA | 0 | NR | NYHA, echocardiography, mortality
| | 12 mo. | | | | | | | | Transvenous, Thoracotomy
| | Effectiveness, safety
Reuter^99^ 2000 | France | Prospective cohort | CRT | NA | 47 | NA | 47 | NA | 0 | NR | Echocardiography, LVEF, NYHA, VO_2_ max, mortality
| | 8 mo. | | | | | | | | Transvenous
| | Effectiveness
Ricci^101^ 2002 | Italy | Prospective cohort | CRT | NA | 48 | NA | 48 | NA | NR | Medtronic 8040 | QRS, NYHA, 6MWT, LVEF
| | 8.8 mo. | | | | | | | | Transvenous
| | Effectiveness
Romeyer-Bouchard^131^ 2005 | France | Prospective cohort | CRT | NA | 103 | NA | 99 (CRT = 94, CRT+ICD = 5) | NA | 0 | Medtronic InSync^®^, InSync^®^ III, InSync^®^ Marquis™, InSync^®^ ICD | Feasibility of implantation technique, complications
| | 8 mo. | | | | | | | | Transvenous
| | Safety
Sawhney^105^ 2004 | United States | Prospective cohort | CRT | NA | 40 | NA | 40 | NA | NR | NR | NYHA, QOL, 6MWT, mortality
| | 3 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Schuchert^132^ 2004 | Germany, United Kingdom | Prospective cohort | CRT | NA | 102 | NA | 102 | NA | 0 | St. Jude Medical Affinity™ DR, Frontier^®^ 5510 | Complications, NYHA
| | 24 mo. | | | | | | | | Transvenous
| | Safety
Sogaard^107^ 2002 | Denmark | Prospective cohort | CRT | NA | 25 | NA | 25 | NA | 0 | Medtronic InSync^®^ | LV performance, NYHA, LVEF, QRS, mortality
| | 12 mo. | | | | | | | | Transvenous
| | Effectiveness
Stahlberg^108^ 2005 | Sweden | Prospective cohort | CRT | NA | 40 | NA | 40 | NA | 0 | ELA Chorum™, Talent; Medtronic InSync^®^, Thera, Kappa; St. Jude Medical Frontier^®^, Affinity™ | 6MWT, NYHA, QOL, mortality
| | 36 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
St. Jude^16^ 2005 | United States, Canada | RCT parallel | CRT | Pacer inactive | 144 | 106 | 59 | 47 | 3 | St. Jude Medical Frontier™ 508 | Peak VO_2_, NYHA, QOL, 6MWT, echocardiographic parameters, mortality
| | 6 mo. | | | | | | | | NR
VecTOR | | Efficacy, safety
Taieb^109^ 2002 | France | Retrospective cohort | CRT | NA | 50 | NA | 50 | NA | 0 | NR | Mortality, NYHA, cardiac hospitalization
| | 16.7 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Tedrow^110^ 2006 | United States | Retrospective cohort | CRT | NA | 75 | NA | 75 | NA | 0 | NR | Composite of death, cardiac transplant, or LVAD implantation
| | 4 yr
| | Effectiveness
Toussaint^113^ 2003 | France | Prospective cohort | CRT | NA | 34 | NA | 34 | NA | 0 | NR | Ventricular function, LVEF, interventricular dyssynchrony, mortality
| | 20 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Witte^116^ 2006 | Canada | Prospective cohort | CRT | NA | 71 | NA | 71 | NA | 0 | NR | Effect of CRT on LV dyssychrony, symptoms, renal function, echocardiographic indicies
| | 4 mo. | | | | | | | | Transvenous
| | Effectiveness
Yu^118^ 2002a | Hong Kong | Prospective cohort | CRT | NA | 25 | NA | 25 | NA | 0 | Guidant Contak^®^ TR, Contak^®^ CD; Medtronic InSync^®^ 8040 | Echocardiography, 6MWT, QOL, mortality
| | 4 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Yu^119^ 2002b | Hong Kong | Prospective cohort | CRT | NA | 30 | NA | 30 | NA | 0 | Guidant Contak^®^ TR 1241; Medtronic InSync^®^ 8040 | QRS, 6MWT, NYHA, LVEF, QOL
| | 3 mo. | | | | | | | | Transvenous
| | Effectiveness
Yu^121^ 2005 | Hong Kong | Prospective cohort | CRT | NA | 141 | NA | 141 | NA | 2 | NR | NYHA, QOL, 6MWT, LV reverse modeling, mortality
| | 24 mo. | | | | | | | | Transvenous
| | Effectiveness
Zhang^122^ 2006 | Switzerland | Prospective cohort | CRT | NA | 50 | NA | 50 | NA | 0 | Medtronic InSync^®^, InSync^®^ III, InSync^®^ ICD; Guidant Contak^®^ TR, Contak^®^ CD | LV volumes and EF, NYHA, 6MWT, QoL
| | 3 mo. | | | | | | | | NR
| | Effectiveness
Combined CRT-ICD
Abraham^14^ 2004 | United States | RCT parallel | CRT on + ICD on | CRT off + ICD on | 222 | 186 | 85 | 101 | 6 | Medtronic InSync^®^ ICD 7272 | Peak VO_2_, VO_2_ max, NYHA, QOL, 6MWT, LV volumes, LVEF, change in clinical status
MIRACLE-ICD II | | 6 mo. | | | | | | | | NR
| | Efficacy, safety
Boriani^36^ 2006a | Europe | Prospective cohort | CRT+ICD | NA | 127 | NA | 121 | NA | 3 | St..Jude Medical V-339 EPIC™ CRT-D | Complications, NYHA, 6MWT,QoL
| | 6 mo. | | | | | | | | NR
| | Effectiveness
Chugh^123^ 2005 | United States | Retrospective cohort | CRT+ICD | NA | 77 | NA | 77 | NA | 0 | Guidant Contak^®^ CD 1823; Medtronic Gem II, III DR, Marquis™ DR | Inappropriate therapy
| | ≤3 yr. | | | | | | | | Transvenous
| | Safety
Gasparini^127^ 2005 | Italy | Prospective cohort | CRT+ICD | NA | 194 | NA | 194 | NA | | NR | First shock effectiveness, device defibrillation failure, general outcome in the 2 month following implant, effectiveness of arrhythmia detection, ICD interventions
| | 2 mo. | | | | | | | | Transvenous
| | Safety
Higgins^9^ 2003 | United States | RCT | CRT+ICD | CRT off + ICD on | 581 | 490 | 245 | 245 | 4 | Guidant Contak^®^ CD 1823 | Mortality, CHF hospitalization, VT requiring device therapy, peak O_2_ consumption, 6MWT, QOL
CONTAK-CD | | Phase I period 1 of X-over 3 mo.; phase II parallel 6 mo. | | | | | | | | Transvenous, transthoracic
| | Efficacy, safety
Kuhlkamp^65^ 2002 | Germany | Prospective cohort | CRT+ICD | NA | 84 | NA | 81 | NA | NR | Medtronic InSync^®^ 7272 | 6MWT, QOL, NYHA, complictions, mortality
| | 3 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Murphy^84^ 2006 | United States | Prospective cohort | CRT+ICD | NA | 54 | NA | 54 | NA | 0 | NR | Placement of LV lead on LV reverse modelling and clinical outcomes
| | 6 mo. | | | | | | | | Transvenous, epicardial
| | Effectiveness
Ritter^102^ 2006 | Germany | Retrospective cohort | CRT+ICD | NA | 48 | NA | 48 | NA | 0 | Guidant Contak^®^ Renewal | NYHA, echocardiographic parameters and hospitalization for heart failure
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Saxon^106^ 2006 | United States | Prospective cohort | CRT+ICD | NA | 170 | NA | 168 | NA | 0 | Guidant Contak^®^ Renewal | Complication rate
| | 9 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
St. Jude^17^ 2004a | United States | RCT parallel | CRT+ICD | CRT off + ICD on | 205 | 179 | 119 | 59 | 3 | St. Jude Medical Epic™ HF ICD | Complications, VF detection times, peak VO_2_, NYHA, 6MWT, mortality
RHYTHM ICD | | 12 mo. | | | | | | | | NR
| | Efficacy, safety
St. Jude^17^ 2004b | United States | Prospective cohort | CRT+ICD | NA | 162 | NA | 162 | NA | NR | St. Jude Medical Quicksite^®^ Model 1056K LV lead with ICD/CRT system | Complications, adverse events
RHYTHM ICD | | NR | | | | | | | | NR
QuickSite | | Effectiveness, safety
Theuns^112^ 2005 | Netherlands | Prospective cohort | CRT+ICD | NA | 86 | NA | 86 | NA | NR | Guidant Contak^®^ CD, Renewal™ I, Renewal™ II; Medtronic InSync^®^ 7272, 7279; St. Jude Medical Epic™ HF | Mortality, incidence of VT, inappropriate therapy
| | 21 mo. | | | | | | | | NR
| | Effectiveness, safety
Young^6^ 2003 | United States, Canada (53 sites) | RCT (post implant) parallel | CRT+ICD | Pacer inactive | 639 | 369 | 187 | 182 | 11 | Medtronic InSync^®^ ICD | NYHA, QOL, 6MWT, complications, QRS, peak O_2_ uptake, hospitalization, mortality
MIRACLE-ICD | | 6 mo. | | | | | | | | Transvenous
| | Efficacy, safety
Ypenburg^117^ 2006 | Netherlands | Prospective cohort | CRT+ICD | NA | 195 | NA | 191 | NA | 3 | CONTAK^®^ RENEWAL 3 AVT | Number of ICD therapies in patients with and w/o prior VA who received a CRT+ICD; to determine predictors of VF/VT; response to CRT; mortality
| | 2 yr | | | | | | | | Guidant
| | Effectiveness, safety | | | | | | | | Transvenous
CRT alone or combined CRT-ICD
Alonso^21^ 1999 | France | Retrospective cohort | CRT, CRT+ICD | NA | 26 | NA | 26 (CRT = 20, CRT+ICD = 6) | NA | 0 | NR | Mortality, QRS, NYHA, VO_2_ max, LVEF
| | 12 mo. | | | | | | | | Transvenous
| | Effectiveness
Ammann^22^ 2004 | Switzerland | Prospective cohort | CRT, CRT+ICD | NA | 47 | NA | 43 (CRT = 19, CRT+ICD = 24) | NA | 0 | NR | Mortality, NYHA, LVEF hospitalization
| | 12 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Auricchio^12^ 2003 | Germany, Netherlands | RCT crossover | CRT, CRT+ICD | Pacer inactive | 101 | 86 | 43 | 43 | 14 | NR | Exercise capacity peak VO_2_, 6MWT, VO_2_ max, NYHA, QOL
PATH-CHF II | | 3 mo. | | | | | | | | Transvenous, thoracotomy
| | Efficacy, safety
Azizi^26^ 2006 | Germany | Retrospective cohort | CRT, CRT+ICD | NA | 244 | NA | 244 | NA | 0 | Biotronik, ELA Medical, Guidant, Medtronic, St. Jude Medical Vitatron | Mortality, peri-operative complications
| | 6 yr. | | | | | | | | Transvenous
| | Effectiveness, safety
Bax^29^ 2004 | Netherlands | Prospective cohort | CRT, CRT+ICD | NA | 85 | NA | 85 (CRT = 37, CRT+ICD = 48) | NA | 0 | Guidant Contak^®^ TR, Contak^®^ CD, Contak^®^ Renewal™ Medtronic InSync^®^ III, InSync^®^ III CD | NYHA, QOL, 6MWT, QRS, LV volumes, LVEF, mortality
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Bocchiardo^33^ 2000 | Italy | Prospective cohort | CRT, CRT+ICD | NA | 51 | NA | 48 | NA | 0 | Guidant Contak^®^ CD; Medtronic InSync^®^ ICD | Mortality, complications, inappropriate therapy, NYHA
| | 22 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Boriani^37^ 2006b | Italy (InSync ICD Registry) | Prospective cohort | CRT, CRT+ICD | NA | 421 | NA | CRT = 227CRTICD = 194 | NA | 0 | Medtronic InSync^®^ | Incidence of VT, LVEF, NYHA, mortality, hospitalization for heart failure
| | 4.yr. | | | | | | | | NR
| | Effectiveness
Braun^39^ 2005 | Germany | CCT | CRT, CRT+ICD | ODT | 124 | NA | 65 (CRT = 38, CRT+ICD = 27 | 57 | 0 | Biotronik Logos, Deikos; Guidant Contak^®^ TR, Contak^®^ CD; Medtronic InSync^®^ 8040, InSync^®^ 7272 | Mortality, hospitalization, NYHA, cardiac function, exercise performance, neurohormonal activation
| | 24 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Bristow^11^ 2004 | United States | RCT parallel, 3 arms | CRT + OPT, CRT+ICD + OPT | OPT | NR | 1,520 | CRT = 617CRTICD = 595 | 308 | 159 | Guidant Contak^®^ TR 1241, 4510–4513, Contak^®^ CD 1823 | All cause mortality, hospitalization, cardiac morbidity, peak O_2_ uptake at exercise
COMPANION | | 15 mo. | | | | | | | | Transvenous
| | Efficacy, safety
Cowburn^44^ 2005 | Canada | Retrospective cohort | CRT, CRT+ICD | NA | 68 | NA | 68 | NA | 0 | NR | Contrast nephropathy, mortality
| | 3 yr. | | | | | | | | Transvenous
| | Effectiveness, safety
Da Costa^45^ 2006 | France | Prospective cohort | CRT, CRT+ICD | NA | 71 | NA | 67 | NA | 0 | Medtronic InSync^®^, InSync^®^ III, InSync^®^ ICD, InSync^®^ | Hospital readmission for class IV CHF, heart transplant, CHF mortality
| | 12 mo. | | | | | | | | Marquis
| | Effectiveness, safety
Davis^47^ 2005 | Canada | Retrospective cohort | CRT, CRT+ICD | NA | 85 | NA | 85 (CRT = 67, CRT+ICD = 18) | NA | NR | Guidant Contak^®^ TR 1241; Medtronic InSync^®^ 8040, 8042 | Mortality, QRS
| | 36 mo. | | | | | | | | Transvenous
| | Effectiveness
De Sisti^48^ 2005 | France | Retrospective cohort | CRT, CRT+ICD | NA | 102 | NA | 102 | NA | 0 | Various | Death from any cause and HF death
| | 6 mo. | | | | | | | | Travenous
| | Effectiveness
Diaz-Infante^49^ 2005 | Spain | Prospective cohort | CRT, CRT+ICD | NA | 197 | NA | 143 (CRT = 90, CRT+ICD = 53) | NA | 0 | NR | Mortality, NYHA, 6MWT, QOL, QRS, LVEF
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Duncan^51^ 2006 | United Kingdom | Retrospective cohort | CRT or CRT+ICD | NA | 39 | NA | 39 | NA | 0 | Guidant Contak^®^ TR CHFD, Contak^®^ CD CHFD, Renewal; Medtronic InSync^®^ III 8040, InSync^®^ ICD 7272, | Reduce ventricular dyssynchrony with CRT
| | 6 mo. | | | | | | | | NR
| | Effectiveness
Ellery^52^ 2005 | Austria, Brazil, France, Germany, Hungary, Italy, Netherlands, United Kingdom | Prospective cohort | CRT, CRT+ICD | NA | 96 | NA | 85 (CRT = 71, CRT+ICD = 14) | NA | NR | NR | Mortality, complications
| | 12 mo.
| | Effectiveness, safety
Ermis^53^ 2004 | United States | Prospective cohort | CRT, CRT+ICD | CRT | 158 | NA | 126 (CRT = 62, CRT+ICD = 64) | NA | 0 | NR | Mortality, hospitalization
| | 12 mo.
| | Effectiveness, safety
Fung^54^ 2005 | Hong Kong | Prospective cohort | CRT, CRT+ICD | NA | 53 | NA | 36 | 36 | 0 | Guidant Contak^®^ TR Medtronic; InSync^®^, InSync^®^ III ICD | Development of atrial fibrillation
| | 36 mo. | | | | | | | | Transvenous
| | Effectiveness
Gaita^55^ 2000 | Italy | Prospective cohort | CRT, CRT+ICD | | 96 | NA | 96 (CRT = 29, CRT+ICD = 67) | NA | 0 | NR | Mortality, NYHA
| | 12 mo.
| | Effectiveness, safety
Gasparini^57^ 2003a | Italy | Prospective cohort | CRT, CRT+ICD | NA | 159 | NA | 158 (CRT = 102 CRT+ICD = 56) | NA | 0 | NR | QRS, NYHA, 6MWT, LVEF, QOL, hospitalization, mortality
| | 11 mo. (median)
| | Effectiveness, safety
Hernandez^59^ 2004 | Spain | Prospective cohort | CRT, CRT+ICD | NA | 28 | NA | 28 (CRT = 16, CRT+ICD = 12) | NA | 0 | NR | Mortality, NYHA, 6MWT, hospitalization, brain matriuretic peptide concentrations
| | 10 mo. | | | | | | | | Transvenous
| | Effectiveness
Kies^61^ 2005 | Netherlands | Prospective cohort | CRT, CRT+ICD | NA | 97 | NA | 97 (CRT = 45, CRT+ICD = 52) | NA | 0 | Guidant Contak^®^ TR, Contak^®^ Renewal™ CD; Medtronic InSync^®^ III, InSync^®^ CD | Mortality, hospitalizations, NYHA, QOL, 6MWT, LVEF
| | 18 mo. | | | | | | | | Transvenous
| | Effectiveness
Krahn^64^ 2002 | Canada | Prospective cohort | CRT, CRT+ICD | NA | 45 | NA | 40 | NA | NR | Guidant Contak^®^ TM, Contak^®^ CD; Medtronic, InSync^®^ pacemaker, ICD | QOL, NYHA, mortality, electrocardiographic measures
| | 1, 3, 6 mo., then every 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Lenom^69^ 2005 | France | Prospective cohort | CRT, CRT+ICD | NA | 36 | NA | 36 (CRT = 28, CRT+ICD = 7) | NA | 2 | Guidant Contak^®^ TR 1241, Contak^®^ CD; Medtronic InSync^®^ 8040, Renewal™ II, InSync^®^ ICD | NYHA, 6MWT, QOL, LVEF
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Lewicka-Nowak^129^ 2005 | Poland | Retrospective cohort | CRT, CRT+ICD | NA | 92 | NA | 92 (CRT = 70, CRT+ICD = 20) | NA | 0 | Biotronik Corox LV 415 | Complications
| | 48 mo. | | | | | | | | NR
| | Safety
Mair^73^ 2005 | Germany, Belgium | CCT | CRT, CRT+ICD | NA | 86 | NA | 86 (CRT = 53, CRT+ICD = 33) | NA | 0 | Guidant Contak^®^ TR Renewal™, Contak^®^ TR; Medtronic InSync^®^ 8040, 8042, InSync ICD, InSync^®^ II Marquis™ 7289 | Compare LV lead placement strategies, mortality, complications
| | 16.4 mo. | | | | | | | | Transvenous, epicardia
| | Effectiveness, safety
Molhoek^79^ 2004a | Netherlands | Prospective cohort | CRT, CRT+ICD | NA | NR | NA | 60 (CRT = 32, CRT+ICD = 28) | NA | 0 | Guidant Contak^®^ TR, Contak^®^ Renewal™ CD; Medtronic InSync^®^ III, InSync^®^ CD | NYHA, QOL, 6MWT, mortality
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness
Molhoek^80^ 2004b | Netherlands | Prospective cohort | CRT, CRT+ICD | NA | 74 | NA | 74 (CRT = 40, CRT+ICD = 34) | NA | 0 | Guidant Contak^®^ TR, Contak^®^ CD, Contak^®^ Renewal™ Medtronic InSync^®^ III, InSync^®^ CD | NYHA, QOL, 6MWT, LVEF, hospitalization, mortality
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Molhoek^81^ 2004c | Netherlands | Prospective cohort | CRT, CRT+ICD | NA | 61 | NA | 61 (CRT = 33, CRT+ICD = 28) | NA | 0 | Guidant Contak^®^ TR, Contak^®^ CD; Medtronic InSync^®^ III, InSync^®^ ICD | NYHA, QOL, 6MWT, LVEF, QRS
| | 6 mo. | | | | | | | | Transvenous
| | Effectiveness
Molhoek^82^ 2005 | Netherlands | Prospective cohort | CRT, CRT+ICD | NA | NR | NA | 125 (CRT = 42, CRT+ICD = 83) | NA | 0 | Guidant Contak^®^ TR, Contak^®^ CD; Medtronic InSync^®^ III, InSync^®^ CD | Mortality, hospitalization, NYHA, QRS, QOL, 6MWT, LVEF
| | up to 3 yr. | | | | | | | | Transvenous
| | Effectiveness, safety
Navia^86^ 2005 | United States | Prospective cohort | CRT, CRT+ICD | NA | 41 | NA | 41 (CRT = 13, CRT+ICD = 28) | NA | 0 | NR | Mortality, NYHA
| | 9 mo. | | | | | | | | Minithoracotomy, endoscopic
| | Effectiveness, safety
Notabartolo^88^ 2004 | United States | Prospective cohort | CRT, CRT+ICD | NA | 66 | NA | 49 | NA | 12 | Guidant H115, H135; Medtronic InSync^®^ 8040, InSync^®^ 7272 | NYHA, 6MWT, QOL, echocardiographic parameters
| | 3 mo. | | | | | | | | Transvenous
| | Effectiveness
Pappone^92^ 2003 | Italy | Prospective cohort | CRT, CRT+ICD | | 135 | NA | 135 (CRT = 47, CRT+ICD = 88) | NA | 0 | NR | Mortality, NYHA, LVEF
| | 28 mo.
| | Effectiveness, safety
Pitzalis^94^ 2005 | Italy | Prospective cohort | CRT, CRT+ICD | NA | 72 | NA | 72 (CRT = 42, CRT+ICD = 30) | NA | 12 | Guidant Contak^®^ TR CHFD, Contak^®^ CD CHFD, Contak^®^ Renewal™ Medtronic InSync^®^ III, InSync^®^ ICD, InSync^®^ Marquis™ St. Jude Medical Epic™ HFV-339 | Mortality, hospitalization, LVEF, LV asynchrony. Septal-to-posterior wall motion delay
| | 14 mo. | | | | | | | | Transvenous
| | (median)
| | Effectiveness, safety
Pürerfellner^130^ 2000a | Europe | Retrospective cohort | CRT, CRT+ICD | NA | 47 | NA | 47 | NA | 0 | Guidant Contak^®^ TR, HF, CD | LV pacing thresholds, LV lead impedance, LV R-wave amplitude, complications
| | 6 mo | | | | | | | | Transvenous
| | Safety
Pürerfellner^130^ 2000b | Europe | Registry data | CRT, CRT+ICD | NA | 150 | NA | 150 | NA | 0 | Guidant Contak^®^ TR, HF, CD | Complications,
| | 6 mo | | | | | | | | Transvenous
| | Safety
Purnode^98^ 2004 | France | Prospective cohort | CRT, CRT+ICD | NA | 43 | NA | 43 (CRT = 37, CRT+ICD = 6) | NA | 0 | ELA Chorum™ 7336; Guidant Contak^®^ TR, Contak^®^ CD, Renewal™ H135; Medtronic InSync^®^ 8040, InSync^®^ 7272; St. Jude Medical Trilogy™ DR, Affinity™ DR | NYHA, 6MWT, QOL, mortality
| | 12 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Reuter^100^ 2002 | France | Prospective cohort | CRT, CRT+ICD | NA | 102 | NA | 102 (CRT = 93, CRT+ICD = 9) | NA | 11 | ELA Chorum™ 7336 MSP; Medtronic InSync^®^ 8040, InSync^®^ ICD; | Mortality, NYHA, QOL, LVEF, O_2_ uptake, hospitalization
| | 12 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Rossillo^103^ 2004 | United States, Italy | Prospective cohort | CRT, CRT+ICD | NA | 244 | NA | 233 (CRT = 68, CRT+ICD = 165) | NA | 0 | NR | NYHA, echocardiographic parameters, mortality
| | 18 mo.
| | Effectiveness, safety
Salukhe^104^ 2005 | United Kingdom | Prospective cohort | CRT, CRT+ICD | NA | 43 | NA | 40 (CRT = 20, CRT+ICD = 20) | NA | 0 | NR | Mortality, NYHA, LVEF, efficiency of cardiac cycle
| | 6 mo.
| | Effectiveness, safety
Teo^111^ 2003 | Singapore, Indonesia, Thailand | Prospective cohort | CRT, CRT+ICD | NA | 29 | NA | 29 (CRT = 24, CRT+ICD = 5) | NA | 0 | Guidant Contak^®^ TR, CD ICD; Medtronic InSync^®^, InSync^®^ ICD | Mortality, NYHA, LVEF, complications
| | up to 28 mo. | | | | | | | | Transvenous
| | Effectiveness, safety
Vidal^114^ 2006 | Spain | Prospective cohort | CRT, CRT+ICD | NA | 64 | NA | 64 | NA | 0 | Contak^®^ HF, Contak^®^ Renewal, Renewal II, Guidant | Mortality, transplant, 6MWT
| | 12 mo.
| | Effectiveness
Waggoner^115^ 2006 | United States | Prospective cohort | CRT, CRT+ICD | NA | 57 | NA | 57 | NA | 0 | NR | Hospitalization for HF; cardiac transplantation; mortality
| | Effectiveness | | | | | | | | Transvenous
Yu^120^ 2004 | Hong Kong | Prospective cohort | CRT, CRT+ICD | NA | NR | NA | 58 (CRT = 54, CRT+ICD = 4) | NA | 0 | Guidant Contak^®^ CD, Contak^®^ TR; Medtronic InSync^®^, InSync^®^ III, InSync^®^ ICD | Echocardiographic parameters, 6MWT, QOL, NYHA
| | 3 mo. | | | | | | | | Transvenous
| | Effectiveness

CCT = controlled clinical trial; CHR = congestive heart failure; CRT = cardiac resynchronization therapy; CRT+ICD = CRT with implanted cardioverter defibrillator; LV = left ventricular; LVEF = left ventricular ejection fraction; NA = not applicable; NR = not reported; NYHA = New York Heart Association class; O_2_ = Oxygen; OPT = optimal pharmacological therapy; QOL = quality of life; RCT = randomized control trial; RV = right ventricular; 6MWT = 6-minute walk test; VO_2_ max = maximal oxygen consumption; VT = ventricular tachycardia

* The intervention that patients in crossover studies received in the first period

Study Participants (Table 9). In total, 9,846 patients were enrolled; of these, 9,209 patients received CRT alone or combined CRT-ICD devices. The mean age was 66 ± 11 years, and 78 percent were male. The majority of participants had NYHA class III (range 0 to 100 percent within studies), or NYHA class IV (range 0 to 87 percent within studies) symptoms at baseline (Table 9). Nineteen studies included patients with NYHA class II symptoms (range 0 to 100 percent).^8,^ ^12,^ ^20,^ ^26,^ ^32,^ ^36,^ ^40,^ ^48,^ ^69,^ ^74,^ ^83,^ ^84,^ ^98^–^100,^ ^109,^ ^114,^ ^121,^ ^130^ One study included patients with NYHA class I.^20^ No studies specifically based inclusion on the etiology of HF of the patients. Patients with correctable valvular disorders, hypertrophic or restrictive cardiomyopathy, unstable angina, or acute myocarditis were excluded from these studies.

Left Ventricular Ejection Fraction. Sixty-three studies limited inclusion to patients with an ejection fraction ≤ 35 percent, 3 of which enrolled patients with LVEF < 30 percent,^47,^ ^50,^ ^71^ 17 enrolled patients with LVEF < 40 percent, and 26 did not specify this criterion. The mean ejection fraction ranged from 17 percent to 35.6 percent in these studies. Thirteen studies specified a left ventricular end diastolic dimension inclusion criterion of ≥55 mm,^19,^ ^34,^ ^40,^ ^48,^ ^51,^ ^60,^ ^65,^ ^69,^ ^70,^ ^83,^ ^104,^ ^112,^ ^114^ and eleven studies specified a left ventricular diastolic dimension ≥60 mm in their eligibility criteria.^21,^ ^43,^ ^45,^ ^46,^ ^58,^ ^67,^ ^68,^ ^73,^ ^87,^ ^113,^ ^115^

QRS Duration. QRS width was a criterion for 81 studies, with 1 specifying ≥ 110 msec, 33 specifying ≥ 120 msec, 22 studies ≥ 130 msec, 11 studies ≥ 140 msec, and 13 studies > 150 msec. One study compared a 120-to-150 msec group to a ≥ 150 group.^120^ Fifty studies reported a mean QRS between 140 msec and 180 msec, and 15 ranged from 181 msec to 206 msec.

Medications. Concomitant medication use was not specified in 22 of the 106 studies included in our effectiveness review. ACE inhibitors and/or an angiotensin-receptor blocker use ranged from 12 percent to 100 percent and beta-blockers use ranged from 35 percent to 100 percent. Diuretic use ranged from 76 percent to 100 percent, and spironolactone use ranged from 25 percent to 100 percent in the studies that reported the use of these medications (55 studies and 32 studies, respectively). Importantly, use of amiodarone ranged from 14 percent to 79 percent (although amiodarone usage rates were only reported in 20 studies). In 34 studies reporting digoxin use, between 0 percent and 95 percent of participants were on digoxin.

### ICD Alone

In addition to the 12 RCTs, there were 48 additional studies that met the inclusion criteria for the review of effectiveness of ICD (Table 10). Twenty-one of these studies met the inclusion criteria for the review of effectiveness but not safety. The 48 additional studies included five parallel RCTs that did not report efficacy endpoints of interest, 20 prospective cohort studies, 22 retrospective cohort studies, and one case control study.^180^ Thirteen studies reported that devices were implanted transvenously,^145,^ ^147,^ ^162,^ ^163,^ ^165,^ ^169,^ ^173,^ ^174,^ ^181,^ ^184,^ ^187,^ ^189,^ ^193^ and five used a combination of transvenous, endocardial or epicardial approaches.^144,^ ^155,^ ^171,^ ^185,^ ^188^

Table 10 Description of studies included in the effectiveness and safety reviews: ICD

Author Year | Study location | Design | Treatment | Control | Participants | | | | | Device | Outcomes
Trial name | | Duration | Primary vs. secondary prevention | | Number enrolled | Number randomized | Number in treatment | Number in control | Number of withdrawals | Method of implant
| | Type of outcomes
Alter^144^ 2005 | Germany | Prospective cohort 46 mo. | ICD | NA | 440 | NA | 440 | NA | 0 | Guidant, Medtronic | Inappropriate shocks, adverse events, mortality
| | Effectiveness, safety | Primary and secondary | | | | | | | Transvenous, epicardial
Antiarrhythmics vs. Implantable Defibrillators (AVID) Investigators^141^ 1997 | United States | RCT parallel 18 mo. | ICD | Amiodarone, Sotalol | 1,885 | 1,016 | 505 | 509 | 2 | Guidant, Medtronic, Ventritex, Sulzer Intermedics | All-cause mortality, QOL, cost, adverse events, time to rehospitalization
AVID | | Efficacy, safety | Secondary | | | | | | | Transvenous, epicardial
Backenkohler^145^ 2005 | Germany | Prospective cohort 4 yr. | ICD | NA | 245 | NA | 245 | NA | 0 | NR | Inappropriate therapy, incidence of VA therapy, mortality
| | Effectiveness, safety | Primary and secondary | | | | | | | Transvenous
Bansch^136^ 2002 | Germany | RCT parallel 66 mo. | ICD | Usual care | 104 | 104 | 50 | 54 | 0 | Guidant Ventak^®^ P2, P3, PrX II, CPI | All-cause mortality, sustained VT, VT requiring treatment, adverse events, inappropriate shocks
CAT | | Efficacy, safety | Primary | | | | | | | Transvenous
Bardy^140^ 2005 | United States, Canada | RCT parallel, 3 arms 46 mo. (median) | ICD | Amiodarone placebo | NR | 2521 | 829 | Amiodaron e = 845, placebo = 847 | 50 | Medtronic 7223 | All-cause mortality, inappropriate shocks
SCD-HeFT | | Efficacy | Primary | | | | | | | NR
Bigger^134^ 1997 | United States, Germany | RCT parallel 32 mo. | CABG + ICD | CABG + usual care | 1,055 | 900 | 466 | 454 | 70 | Guidant Epicardial | All-cause mortality, time to shock, adverse events
CABG-Patch | | Efficacy, safety | Primary
Blangy^146^ 2003 | France | Retrospective cohort 25 mo. | ICD | NA | 283 | NA | 144 LVEF < 35% | NA | 0 | NR | All-cause mortality
| | Effectiveness | Primary
Bode-Schnurbus^147^ 2003 | Germany | Prospective cohort 24 mo. | ICD | NA | 603 | NA | 165 | NA | 0 | Biotronik Phylax 06; Guidant P2/P3/PRx, Mini™ II; Medtronic 7216, 7218, 7219; Jewel Plus, Ventritex V-100, Contour^®^; Telectronic Guardian ATP2/3 | Mortality, QRS duration
| | Effectiveness, safety | Primary and secondary | | | | | | | Transvenus epicardial
Bokhari^148^ 2004 | Canada | Prospective cohort up to 11 yr. | ICD | Amiodarone | 120 | 120 | 120 | NA | 0 | NR | All-cause mortality, side effects of amiodarone, VA recurrence, composite endpoint of total mortality, VA recurrence, discontinuation of amiodarone
CIDS | | Effectiveness, safety | Secondary
Bristow^11^ 2004 | USA | RCT parallel (OPT vs OPT+CRT vs OPT+CRT+ICD | OPT+CRT or OPT+CRT+ICD | OPT | 1520 | 1520 | CRT = 617 CRT + 1 CD = 595 | 308 | 159 | Guidant: Contak® TR Contak® CD | Time to mortality or hospitalization from any cause
COMPANION | | Efficacy, Safety | Primary | | | | | | | Transvenous
Bruch^149^ 2006 | Germany | Prospective cohort 1 yr. | ICD | NA | 98 | NA | 98 | NA | 0 | NR | Cardiac event Mortality from pump failure and/or appropriate therapy
| | Effectiveness | Primary and secondary
Brunckhorst^150^ 2004 | Germany | Prospective cohort 12 mo. | ICD | NA | 104 | NA | 104 | NA | 0 | St Jude, Guidant, Medtronic | Mortality
| | Effectiveness | Primary | | | | | | | NR
Buxton^151^ 1999 | United States, Canada | RCT parallel (antiarrythmic vs. no antiarrythmic therapy) 39 mo. (median) | OPT + EP guided therapy (antiarrhythmic drug therapy or ICD if drug therapy failed) | OPT | 2,202 | 704 | 351 | 353 | NR | NR | Cardiac arrest, arrhythmic death, all-cause mortality, sustained VT
MUSTT | | Effectiveness | Primary
Capoferri^152^ 2004 | Switzerland | Prospective cohort 20 mo. | ICD | NA | 100 | NA | 100 | NA | 0 | NR | Mortality, inappropriate shocks
| | Effectiveness, safety | Primary and secondary
Carlsson^192^ 2003 | Germany | RCT (pooled analysis) NR | ICD | NA | 96 | NA | 96 | NA | 0 | Guidant Ventak^®^ Mini™ IV, Ventak^®^ VR, Ventak^®^ Prizm™ VR, Ventak^®^ Prizm™ DR, Ventak^®^ AV III DR; Medtronic Gem VR, Gem DR | Success of DER+5J and DER+10J safety margins
| | Safety | Secondary | | | | | | | Transvenous
Chan^153^ | United States | Prospective cohort 5 yr. | ICD | NA | 6,996 | NA | 1,442 | 5,554 | 0 | NR | All-cause mortality, cardiovascular mortality
| | Effectiveness | Primary and secondary
Chan^154^ | United States (7 centers) | Prospective cohort 27 ± 12 mo. | ICD | NA | 395 | NA | 395 | NA | 0 | NR | All-cause mortality, cause specific mortality, appropriate shock therapy, symptomatic VA
| | Effectiveness | Primary
Connolly^142^ 2000 | Canada | RCT parallel 35 mo. | ICD | Amiodarone | NR | 659 | 328 | 331 | NR | NR | All-cause mortality, arrhythmic death, adverse events
CIDS | | Efficacy, safety | Secondary | | | | | | | Transvenous thoracotomy
Cuesta^155^ 2003 | Spain | Prospective cohort 30 mo. | ICD | NA | 120 | NA | 120 | NA | 0 | NR | Antiarrhythmia recurrence, mortality, adverse events
| | Effectiveness, safety | Primary and secondary | | | | | | | Abdominal, transvenous
Dorian^193^ 2004a | Canada | RCT parallel 12 mo. | ICD | NA | 149 | 149 | 149 | NA | 0 | Guidant Ventak^®^ 1810, 1820, 1821, 1831 | Time to first inappropriate therapy, mortality
ASTRID Investigators | | Effectiveness, safety | Primary | | | | | | | Transvenous
Dorian^156^ 2004b | United States, Canada, Germany, United Kingdom, Poland, France, Spain, Netherlands, Belgium, Italy | RCT parallel (placebo arm only) 12 mo. | ICD + placebo | NA | 214 | 214 | 214 | NA | 2 | NR | All-cause shocks, appropriate shocks for VT/VF
SHIELD Investigators | | Safety | Primary and secondary
Dubner^157^ 2005 | Argentina, Uruguay, Brazil, Mexico, Chile, Cuba, Venezuela | Retrospective cohort 27 mo. | ICD | NA | 770 | NA | 770 | NA | 0 | Biotronik | All-cause mortality sudden cardiac death
| | Effectiveness, safety | Secondary | | | | | | | NR
Duray^158^ 2005 | Germany | Retrospective cohort 2.2 ± 1.5 yr | ICD | NA | 375 | NA | 375 | NA | 0 | NR | Mortality, first appropriate therapy
| | Effectiveness safety | Primary and secondary
Elhendy^159^ 2005 | United States | Prospective cohort 2.8 yr. | ICD | NA | 90 | NA | 90 | NA | 0 | NR | Mortality
| | Effectiveness | Primary and secondary
Ellenbogen^160^ 2003 | United States | Prospective cohort 68.6 mo. | ICD | NA | 74 | NA | 74 | NA | 0 | Medtronic 7227, 7229, 7271, 7273 | Lead failure, mortality
| | Effectiveness, safety | NR | | | | | | | NR
Ermis^161^ 2003 | United States | Retrospective cohort 15 mo. | ICD | OPT | 310 | NA | 59 | 251 | 0 | NR | All-cause mortality
| | Effectiveness, safety | Primary and secondary
Evonich^162^ 2004 | United States | Retrospective cohort 6 yr. | ICD | NA | 153 | NA | 153 | NA | 0 | NR | Appropriate treatment, mortality
| | Effectiveness, safety | Primary and secondary | | | | | | | Tranvenous
Friedman^194^ 2006 | United States | RCT parallel 6 mo. | ICD dual chamber | ICD ventricular only pacing | 400 | 400 | 201 | 199 | 51 | St. Jude Medical | Inappropriately detected SVT episodes; inappropriate treatment, VT/VF sensitivity; arrhythmia-related hospitalizations or clinic visits; early termination rate
| | Safety | Primary and secondary
Gatzoulis^163^ 2005 | Greece | Prospective cohort 33 mo. | ICD | NA | 169 | NA | 169 | NA | 0 | NR | Occurrence of electrical storm, mortality
| | Effectiveness | Primary and secondary | | | | | | | Tranvenous
Greenberg^164^ 2002 | Israel | Retrospective cohort 2.6 yr. | ICD | NA | 732 | NA | 732 | NA | 0 | NR | Mortality
| | Effectiveness, safety | Primary and secondary
Grimm^165^ 2002 | Germany | Prospective cohort 35 mo. | ICD | NA | 101 | NA | 101 | NA | 0 | Guidant Ventak^®^ P2, Mini™ 2, Mini™ 4, Prizm^®^, Ventak^®^ AV; Medtronic 7202, 7219–7221, 7223, 7227, 7229, 7271–7273 | Appropriate interventions, mortality
| | Effectiveness, safety | Primary | | | | | | | Transvenous
Grimm^195^ 2006 | Germany | Retrospective cohort 3.2 ± 2.3 yr | ICD | NA | 93 | NA | 93 | NA | 0 | Medtronic 7220/21/23/27/ 29/30/31/71/72 /74/75/79. Guidant Mini/Prizm/Ven takAV/ Contak® H135 | To decrease rapid VT using antitachycardia pacing (ATP), inappropriate shocks
| | Safety | Primary | | | | | | | Transvenous
Ho^166^ 2005 | United States | Retrospective cohort 4.4 yr. | ICD | NA | 360 | NA | 360 | NA | 0 | NR | All-cause mortality
| | Effectiveness | Primary and secondary
Hohnloser^139^ 2004 | Europe, Canada, United States | RCT parallel 30 mo. | ICD | OPT | NR | 674 | 332 | 342 | 24 | NR | All-cause mortality adverse events
DINAMIT | | Efficacy, safety | Primary
Hreybe^196^ 2006 | United States | Prospective cohort 4 yr. | ICD | NA | 230 | NA | 230 | NA | 0 | NR | Inappropriate ICD shocks
| | Safety | Primary and secondary
Kadish^138^ 2004 | United States, Israel | RCT parallel 29 mo. | ICD | OPT | NR | 458 | 229 | 229 | 6 | NR | All-cause mortality, adverse events
DEFINITE | | Efficacy, safety | Primary
Koplan^167^ 2006 | United States | Retrospective cohort 3.3 yrs | ICD | NA | 348 | NA | 348 | NA | 0 | NR | All-cause mortality
| | Effectiveness | Primary and secondary
Kuck^143^ 2000 | Germany | RCT parallel 3 arms 57 mo. | ICD | Metoprolol, amiodarone | 293 | 288 | 99 | Metoprolol = 97, Amiodarone = 92 | NR | Guidant Ventak^®^ AID, Ventak^®^ AICD, Ventak^®^ P, Ventak^®^ PRx, Ventak^®^ Mini™ | All-cause mortality sudden cardiac death
CASH | | Efficacy, safety | Secondary | | | | | | | Epicardial, endocardial
Lampert^168^ 2004 | United States | Retrospective cohort 2.5 yr | ICD | NA | 650 | NA | 399 | NA | 0 | Guidant 1705 and beyond | Mortality, VT/VF events, differences by sex
| | Effectiveness | Primary and secondary | | | | | | | NR
Leosdottir^169^ 2006 | Iceland | Retrospective cohort 10 yr | ICD | NA | 62 | NA | 62 | NA | 0 | NR | Review all ICD implant experience since first implant in 1992
| | Effectiveness, safety | Secondary | | | | | | | Transvenous
Lickfett^197^ 2004 | Germany | Retrospective cohort 47 mo. | ICD | NA | 105 | NA | 105 | NA | 0 | NR | Incidence of venous obstruction
| | Safety | NR | | | | | | | Transvenous
Moss^133^ 1996 | United States, Germany, Italy | RCT parallel 27 mo. | ICD | OPT | 253 | 196 | 95 | 101 | 18 | Guidant | All-cause mortality arrhythmic death
MADIT | | Efficacy, safety | Primary | | | | | | | Transthoracic, transvenous
Moss^135^ 2002 | United States, Europe | RCT parallel 20 mo. | ICD | OPT | NR | 1,232 | 742 | 490 | 3 | NR | All-cause mortality adverse events
MADIT II | | Efficacy, safety | Primary | | | | | | | Transvenous
Nazarian^170^ 2005 | United States | Retrospective cohort 3 yr. | ICD | NA | 94 | NA | 94 | NA | 0 | NR | Time to rehospitalization and death
| | Effectiveness | Primary and secondary
Niehaus^198^ 2003 | Germany | Retrospective cohort 12 mo. | ICD | NA | 25 | NA | 25 | NA | 0 | NR | Implant success, adverse events
| | Safety | Secondary | | | | | | | Transvenous
Noseworthy^171^ 2004 | Canada | Retrospective cohort 7 yr. | ICD | NA | 637 | NA | 212 | NA | 0 | NR | All-cause mortality, cause specific mortality, inappropriate shocks, adverse events
| | Effectiveness, safety | Primary and secondary | | | | | | | Tranvenous epicardial
Parkash^172^ 2006 | United States | Retrospective cohort 3.2 yr. | ICD | NA | 469 | NA | 469 | NA | 0 | NR | Mortality
| | Effectiveness | Primary and secondary
Pires^173^ 2002 | United States | Retrospective cohort 24 mo. | ICD | NA | 2,030 | NA | 2,030 | NA | 0 | Angstrom Contour^®^ MD, Photon DR | Mortality, arrhythmic events
| | Effectiveness | Primary and secondary | | | | | | | Transvenous
Pires^174^ 2006 | United States | Retrospective cohort 22 ± 14 mo. | ICD | NA | 861 | NA | 861 | NA | 26 | Medtronic, Guidant, St. Jude Medical, Biotronik | Success of anti-tachycardia therapies, mortality
| | Effectiveness | NR | | | | | | | Transvenous
Raitt^175^ 2005 | United States | RCT (placebo arm only) 10 yr. | ICD | NA | NR | 100 | 100 | NA | 26 | NR | Time to first VT/VF leading to therapy, mortality, hospitalization
| | Effectiveness | Primary
Raviele^176^ 2005 | Italy | RCT (analyzed as prospective cohort) 24 mo. | EPC guided or ICD | OPT | 143 | 138 | 79 | 59 | 0 | NR | All-cause mortality, appropriate/inappropriate shocks, non-fatal sustained VT
BEST ICD | | Effectiveness, safety | Secondary
Robin^177^ 2006 | United States | Retrospective cohort 11 yr. | ICD | NA | 585 | NA | 585 | NA | 0 | NR | First appropriate ICD therapy for VT/VF, mortality
| | Effectiveness | Primary
Russo^178^ 2003 | United States | Prospective cohort 15.7 mo. | ICD | NA | 51 | NA | 51 | NA | 0 | NR | Treatment events, inappropriate therapy, mortality
| | Effectiveness, safety | Primary
Saba^179^ 2003 | United States | Retrospective cohort 4 yr. | ICD | NA | 35 | NA | 35 | NA | 0 | NR | Mortality, adverse events
| | Effectiveness, safety | Primary and secondary
Saeed^199^ 2003 | United States | Prospective cohort 8.4 mo. | ICD | NA | 229 | NA | 48 | NA | 0 | Guidant Ventak^®^ 1810, 1831, 1820, 1821 | Sensing abnormalities in dual-chamber ICD
| | Safety | NR | | | | | | | NR
Sanchez^180^ 2005 | United States | Case-control NR | ICD | OPT | 102 | NA | 19 | 32 | 0 | NR | Mortality, cardiac arrest, appropriate therapy
| | Effectiveness, safety | Primary and secondary
Sanchez^181^ 2006 | United States | Retrospective cohort 22 ± 14 mo. | ICD | NA | 123 | NA | 123 | NA | 0 | NR | Survival free of appropriate ICD therapy
| | Effectiveness, safety | Primary | | | | | | | Transvenous
Schaer^182^ 2006 | Switzerland | Prospective cohort 18 m0. | ICD | NA | 58 | NA | 58 | NA | 0 | NR | Appropriate therapy, mortality, drug therapy, LVEF
| | Effectiveness | Primary and secondary
Sears^183^ 2004 | United States | Prospective cohort 14.3 mo. | ICD | NA | 88 | NA | 88 | NA | 0 | NR | QOL, mortality
| | Effectiveness | Primary
Takahashi^184^ 2002 | United States | Retrospective cohort 12 mo. | ICD | NA | 178 | NA | 178 | NA | 0 | Guidant Ventak^®^ Mini™, Ventak^®^ AV; Medtronic Micro Juel, Gem Gem DR; Ventritex Angstrom™, Contour^®^, Profile | Adverse events requiring surgical correction, comparison of dual vs. single-chamber ICD, mortality
| | Effectiveness, safety | NR | | | | | | | Tranvenous
Tandri^185^ 2006 | United States | Retrospective cohort 23 yr. | ICD | NA | 1382 | NA | 1382 | NA | 0 | NR | Appropriate ICD therapy, mortality
| | Effectiveness | Primary and secondary | | | | | | | Thoracotomy, abdominal, transvenous, endocardial
Telfer^186^ 2002 | United States | Retrospective cohort 2.2 yr. | ICD | NA | 379 | NA | 29 | NA | 2 | NR | Mortality, inappropriate therapy
| | Effectiveness, safety | Primary
Theuns^200^ 2004 | Netherlands | RCT parallel 12 mo. | ICD | ICD | NR | 60 | | NA | 0 | Biotronik achos DR; Guidant Prizm DR | Inappropriate ICD therapy for atrial arrhythmias, comparison of dual vs. single-chamber ICD
| | Safety | Primary and secondary | | | | | | | NR
Theuns^187^ 2005b | Netherlands | Prospective cohort 5 yr. | ICD | NA | 127 | NA | 127 | NA | 0 | Biotronik Guidant ELA Medical Medtronic | Mortality
| | Effectiveness, safety | Primary and secondary | | | | | | | Transvenous
Theuns^201^ 2005a | Netherlands | Prospective cohort 4 yr. | ICD | NA | 326 | NA | 260 | NA | 0 | Biotronik Phylax AV, Tachos DR, Belos^®^ VR-T; | Inappropriate shocks
| | | | | | | | | | ELA Defender IV, Alto DR;
| | | | | | | | | | Guidant Mini™ IV, Contak^®^ CD, Renewal™ I, Renewal™ II;
| | | | | | | | | | Medtronic 7227, 7250, 7271, 7272
| | Safety | Primary and secondary | | | | | | | Transvenous
Tiroke^202^ 2003 | Germany | Retrospective cohort 5 yr. | ICD | NR | 149 | NA | 149 | NA | NR | NR | Inappropriate shocks
| | Safety | NR
Trappe^188^ 2002 | Germany | Prospective cohort 28 mo. | ICD | NA | 410 | NA | 410 | NA | 0 | NR | Mortality, inappropriate shocks
| | Effectiveness, safety | NR | | | | | | | Epicardial, non-thoracotomy
Wase^189^ 2004 | United States | Retrospective cohort 4 yr. | ICD | NA | 256 | 95 | 93 | NA | 0 | NR | Mortality
| | Effectiveness, safety | Primary and secondary | | | | | | | Transvenous
Wilkoff^190^ 2006 | United States | RCT parallel 12 mo. | ICD EMPIRIC | ICD TAILORED | 900 | 900 | 455 | 455 | 0 | Medtronic | Shock related morbidity [health-care utilization, death, syncope, ED visits]
| | Effectiveness | Primary and secondary
Zecchin^191^ 2004 | Italy | Retrospective cohort 24 mo. | ICD | NA | 54 | NA | 54 | NA | 0 | Biotronik Belos^®^; Guidant Ventak^®^ Mini™ II, AV II-IV, Prizm™ I, Prizm™ II, Vitality™, Renewal™ Medtronic Jewel II, ATK Gem III, Defender II; St. Jude Medical Ventitrex Contour^®^ II | Mortality, effectiveness for primary prevention, inappropriate shocks
| | Effectiveness, safety | Primary and secondary | | | | | | | NR

DER = defibrillation energy requirement; EPS = electrophysiological study; ICD = implanted cardioverter defibrillator; LV = left ventricular; LVEF = left ventricular ejection fraction; NA = not applicable; NR = not reported; OPT = optimal pharmacological therapy; QOL = quality of life; RCT = randomized controlled trial; RV = right ventricular; VO_2_ max = maximal oxygen consumption; VA = ventricular arrhythmia; VF = ventricular fibrillation; VT = ventricular tachycardia

Study Participants (Table 11). In total, 25,111 patients were enrolled in these studies of ICD effectiveness; of these, 15,097 patients received ICD. Some patients were excluded or withdrew due to unsuccessful implants, death, heart transplantation, or miscellaneous reasons. The mean age was 62.6 ± 13.2 years, 79 percent were male. Most studies included patients with NYHA class II symptoms (range 0 to 95 percent within studies) and NYHA class III symptoms (range 9 to 100 percent within studies). Fifteen studies reported including patients in NYHA class IV, with a range between 2 percent and 33 percent (Table 11).^144,^ ^148,^ ^155,^ ^157,^ ^158,^ ^161,^ ^165,^ ^170,^ ^172,^ ^173,^ ^175,^ ^179,^ ^185,^ ^187,^ ^190^ Two studies required patients to be survivors of sudden cardiac death,^146,^ ^157^ and eight studies required patients to have other high risk features. ^147,^ ^148,^ ^176,^ ^183,^ ^186,^ ^191,^ ^193^ Eighteen studies did not state exclusion criteria. Ischemic etiology was present in approximately 70 percent of patients (range 0 to 100 percent).

Left Ventricular Ejection Fraction. Ejection fraction was a criterion for 10 studies, with 5 studies specifying LVEF < 35 percent,^146,^ ^148,^ ^154,^ ^176,^ ^191^ 3 specifying LVEF < 40 percent,^151,^ ^162,^ ^189^ and 2 specifying LVEF < 45 percent.^145,^ ^149^ The remaining studies did not specify an entry criterion. The mean ejection fraction ranged from 19 to 46 percent.

Medications. Concomitant medication use was not reported in 16 studies. ACE inhibitors were reported in 23 studies (range 55 to 95 percent), beta-blockers were reported in 33 studies (range 10 to 89 percent), and spironolactone was reported in three studies (5 to 36 percent). Thirty-two studies reported the use of antiarrhythmic drugs, including amiodarone (range 10 to 61 percent).

## Description of Included Studies: Safety Review

### CRT Alone or Combined CRT-ICD Devices

Fourteen randomized trials and 75 additional studies met the inclusion criteria for the review of safety of CRT (Table 8). The 75 additional studies included 2 controlled but not randomized trials,^39,^ ^73^ one registry study, 9 retrospective cohort studies,^26,^ ^44,^ ^63,^ ^68,^ ^102,^ ^109,^ ^123,^ ^128,^ ^129^ and 63 prospective cohort studies. Sixty-five studies reported that devices were implanted transvenously, two transthoracically,^85,^ ^97^ and six using both approaches.^9,^ ^12,^ ^56,^ ^63,^ ^66,^ ^73^ Medtronic Inc., Guidant Corp., ELA Medical Inc, St. Jude Medical Inc., or Biotronik manufactured all implanted devices; the models and leads varied among and within trials.

Study Participants (Table 9). In total, 12,471 patients were enrolled; of these, 9,677 patients received CRT alone or combined CRT-ICD device. The mean age was 66 ± 10 years, and 77 percent were male. Approximately 80 percent of these study participants had NYHA class III symptoms at baseline (range 13 to 100 percent), and 11 percent were NYHA class IV (range 0 to 100 percent) (Table 9). Twenty-two studies included patients with NYHA class II symptoms (range 4 to 50 percent).^9,^ ^12,^ ^16,^ ^17,^ ^20,^ ^26,^ ^32,^ ^33,^ ^36,^ ^48,^ ^49,^ ^57,^ ^69,^ ^83,^ ^86,^ ^98,^ ^100,^ ^104,^ ^109,^ ^130,^ ^264^ Five studies included patients with NYHA class I.^16,^ ^17,^ ^32,^ ^86^ No studies specifically based inclusion on the etiology of HF, although patients with correctable valvular disorders, hypertrophic or restrictive cardiomyopathy, unstable angina, or acute myocarditis were excluded from these studies.

Left Ventricular Ejection Fraction. Fifty-five studies limited inclusion to patients with an ejection fraction < 35 percent. Three of these enrolled patients with LVEF < 30 percent,^12,^ ^50,^ ^128^ nine enrolled patients with LVEF < 40 percent,^13,^ ^31,^ ^35,^ ^57,^ ^98,^ ^104,^ ^111,^ ^113,^ ^119^ and 24 did not specify this criterion.^8,^ ^10,^ ^20,^ ^26,^ ^27,^ ^44,^ ^49,^ ^52,^ ^53,^ ^56,^ ^63,^ ^64,^ ^76,^ ^85^–^87,^ ^91,^ ^100,^ ^108,^ ^123,^ ^125,^ ^126,^ ^130,^ ^264^ The mean ejection fraction ranged from 19 percent to 36 percent in these studies. Twenty-five studies specified a left ventricular end diastolic dimension inclusion criterion of ≥55 mm,^4,^ ^6,^ ^14,^ ^16,^ ^60,^ ^65,^ ^69,^ ^70,^ ^83,^ ^104,^ ^112^ or ≥60 mm.^5,^ ^7,^ ^13,^ ^45,^ ^46,^ ^58,^ ^66^–^68,^ ^73,^ ^87,^ ^113,^ ^129,^ ^131^ One study specified ≥33 indexed to height.^15^

QRS Duration. QRS width was a criterion for 72 studies, with 1 study specifying ≥110 msec,^57^ 28 ≥ 120 msec,^7^–^9,^ ^11,^ ^12,^ ^15,^ ^22,^ ^29^–^32,^ ^35,^ ^42,^ ^67,^ ^69,^ ^73,^ ^78,^ ^80,^ ^82,^ ^87,^ ^103,^ ^106,^ ^109,^ ^112,^ ^117,^ ^125,^ ^126,^ ^129^ 18 ≥ 130 msec, ^4,^ ^6,^ ^14,^ ^17,^ ^49,^ ^50,^ ^60,^ ^64,^ ^65,^ ^70,^ ^83,^ ^92^–^94,^ ^102,^ ^104,^ ^111,^ ^132^ 9 ≥ 140 msec,^16,^ ^33,^ ^55,^ ^56,^ ^85,^ ^89,^ ^98,^ ^119,^ ^124^ 15 > 150 msec,^5,^ ^17,^ ^36,^ ^39,^ ^45,^ ^46,^ ^58,^ ^68,^ ^91,^ ^105,^ ^108,^ ^113,^ ^128,^ ^130,^ ^131^ and 1 > 200 msec.^66^ Forty-seven studies reported a mean QRS between 142 msec and 187 msec, and 15 ranged from 181 msec to 206 msec.^27,^ ^41,^ ^45,^ ^46,^ ^56,^ ^66^–^68,^ ^73,^ ^85,^ ^86,^ ^93,^ ^98,^ ^99,^ ^131^

Rhythm. Ten studies were restricted to patients in normal sinus rhythm,^5,^ ^8,^ ^11,^ ^12,^ ^89,^ ^104,^ ^113,^ ^128,^ ^130,^ ^131^ but one was restricted to patients with atrial fibrillation.^7^ In the others, 6 percent to 90 percent of patients had atrial fibrillation.

Medications. Concomitant medication use was not specified in 30 of the 89 studies included in our safety review. ACE inhibitors and/or an angiotensin-receptor blocker use ranged from 62 percent to 100 percent, beta-blockers use ranged from 35 percent to 88 percent, loop diuretic use from 43 percent to 100 percent, and spironolactone use ranged from 32 percent to 59 percent. Importantly, use of amiodarone ranged from 14 percent to 79 percent (in the 13 studies reporting amiodarone usage rates). In 17 studies reporting digoxin use, between 0 percent to 95 percent of participants were on digoxin.

### ICD Alone

Forty-nine studies met the inclusion criteria for the review of safety of ICD (Table 10). Eleven of the 12 trials included in the efficacy review were eligible: Strickberger et al. did not include any safety outcomes.^137^ The 38 additional studies included 6 trials that did not report efficacy endpoints of interest and were treated as cohort studies,^156,^ ^176,^ ^192^–^194,^ ^200^ 15 prospective cohort studies,^144,^ ^145,^ ^147,^ ^148,^ ^152,^ ^155,^ ^160,^ ^165,^ ^178,^ ^187,^ ^188,^ ^196,^ ^198,^ ^199,^ ^201^ 16 retrospective cohort studies,^157,^ ^158,^ ^161,^ ^162,^ ^164,^ ^169,^ ^171,^ ^179,^ ^181,^ ^184,^ ^186,^ ^189,^ ^191,^ ^195,^ ^197,^ ^202^ and 1 case control study.^180^ Ten studies reported that devices were implanted transvenously,^135,^ ^136,^ ^145,^ ^156,^ ^162,^ ^165,^ ^184,^ ^189,^ ^192,^ ^197^ two used both transvenous and transthoracic approaches,^133,^ ^142^ and six used a combination of transvenous, endocardial or epicardial approaches.^134,^ ^143,^ ^144,^ ^147,^ ^171,^ ^188^

Study Participants (Table 11). In total, 22,044 patients were enrolled in the studies of ICD safety; of these, 12,592 patients received ICD. Some patients were excluded or withdrew due to unsuccessful implants, death, heart transplantation, or miscellaneous reasons. The mean patient age was 61.4 ± 11.9 years and 80 percent were male. Approximately 50 percent of each study population was NYHA class II (range 16 to 70 percent) and 38 percent were NYHA class III (range 9 to 100 percent). Ten studies reported including patients in NYHA class IV, with a range between 2 and 18 percent (Table 11).^11,^ ^133,^ ^135,^ ^142,^ ^144,^ ^148,^ ^155,^ ^157,^ ^179,^ ^202^ Six studies required patients to be survivors of sudden cardiac death,^141^–^144,^ ^156,^ ^157^ and 13 studies required patients to have other high-risk features.^135,^ ^139,^ ^148,^ ^155,^ ^156,^ ^161,^ ^176,^ ^183,^ ^186,^ ^191^–^193,^ ^201^ Twenty-one studies did not state exclusion criteria.^144,^ ^146^–^148,^ ^150,^ ^152,^ ^155,^ ^157,^ ^158,^ ^160,^ ^163^–^166,^ ^169,^ ^178,^ ^179,^ ^187,^ ^189,^ ^195,^ ^196^ Ischemic etiology was present in approximately 55 percent of patients (range 0 to 100 percent).

Left Ventricular Ejection Fraction. Ejection fraction was a criterion for 19 studies, with 3 studies specifying an ejection fraction of < 30 percent,^135,^ ^136,^ ^191^ 11 specifying LVEF < 35 percent,^11,^ ^133,^ ^134,^ ^138^–^140,^ ^146,^ ^148,^ ^176,^ ^189,^ ^195^ three specifying LVEF < 40 percent,^141,^ ^162,^ ^193^ and one specifying LVEF < 45 percent.^145^ The mean ejection fraction ranged from 19 to 46 percent.

Medications. Concomitant medication use was not reported in 14 studies. ACE inhibitors were reported in 25 studies (range 42 to 98 percent), beta-blockers were reported in 31 studies (range 4 to 89 percent), and spironolactone was reported in two studies (5 and 14 percent). Thirty studies reported the use of antiarrhythmic drugs, including amiodarone (range 2 to 96 percent).

Additional Studies of all ICD Implants (i.e., studies not restricted to patients with left ventricular systolic dysfunction). Twelve additional ICD studies that did not meet the inclusion criterion of a mean baseline LVEF ≤ 35 percent were examined for implantation success rates and peri-implant safety data after input from the Technical Expert Panel who reviewed our initial draft report (Table 12).^203^–^214^ Five were randomized (two parallel, three crossover), two each were retrospective or prospective cohorts, and three involved registry data. Implant techniques varied and included transvenous, thoracotomy, pectoral, subpectoral, abdominal, epicordial and nonthoracic approaches. In total, 68,930 patients were enrolled in these 12 studies of ICD safety; of these, 68,848 received ICD (Table 13). The mean age across studies was 61 years, and approximately 80 percent were male. Half of the studies reported baseline NYHA class: approximately 35 percent of each study population was in NYHA class I (range 19 to 100 percent): 54 percent were NYHA class II (range 39 to 62 percent) and 19 percent were NYHA class III (range 13 to 24 percent). Two studies reported patients in NYHA class IV (0.09 and 1 percent).^208,^ ^211^ One author reported 23 percent of the population was greater than NYHA class II.^212^ None of these studies required patients to be survivors of sudden cardiac death, but one only included patients who had suffered Sudden Unexplained Death Syndrome^210^ though otherwise apparently healthy. Ischemic etiology was present in approximately 66 percent of patients (median 71; range 0 to 100 percent). Ejection fraction was not a criterion for enrolment into these studies; however, 66 percent of studies reported a baseline LVEF that ranged from an average of 36 ± 12.4 to 66 ± 10.3 percent. Concomitant medication use was not reported in two studies. ACE inhibitors were reported in one study (88 percent), beta-blockers were reported in five (range 24 to 44.3 percent), Sotalol in four (range 5–8 percent), amiodarone in six (0 to 39 percent) and other antiarrhythmic therapy in four studies (range 3.1 to 79 percent).

Table 12 Description of additional studies included in the ICD safety review for peri-implant complications only

Author Year | Study location | Design | Intervention | Participants | | Device | Data or patient source | Primary or Secondary prevention
| | Duration | | Treatment (n) | Control (n) | Method of implant
Al-khatib^204^ 2005 | United States | Retrospective cohort | ICD | 9,854 | NA | Defender III, IV | 20% of Part B Medicare files & 100% MEDPAR files January 1999–September 2001 | NR (61% urgent or emergency implants)
| | Registry data 2 yr. 9 mo. | | | | ELA Medical
Bänsch^205^ 2004 | Germany | RCT crossover | Dual-chamber vs. single-chamber ICD | 102 | NA | NR | Multiple centers in Germany | Mixed
| | 1 yr.
Boriani^206^ 2003 | Italy | RCT crossover | ICD-atrial enhancements on v. off | 89 | NA | Guidant | Multiple centers in Europe and Canada | Primary
| | 6 mo. | | | | NR
Brockers^207^ 2002 | Switzerland | Retrospective cohort | ICD | 130 | NA | NR | One center | Secondary
| | 5 yr. | | | | Thoracotomy, subxiphoid, transvenous
Gradaus^208^ 2003 | Germany | Retrospective cohort | ICD | 3,344 | NA | NR | European Registry of Implantable Defibrillators (EURID) | Mixed
| | Registry data 2 yr. 10 mo. | | | | Transvenous
Hlatky^209^ 2002 | United States | Retrospective cohort | ICD | 22,565 | NA | NR | Health Care Finance Administration for Medicare Beneficiaries files Jan. 1984-Sept. 1995; California Statewide Health Planning and Development hospital discharge database, 1991-1995 | Mixed
| | Registry data 9 yr.
Nademanee^210^ | Thailand, United States | RCT parallel | ICD vs. propanalol | 47 | Not included | NR | NR | Secondary
| | 3 yr. | | | | Guidant Transvenous
Reynolds^203^ 2006 | United States | Retrospective cohort | ICD | 30,984 | NA | NR | MEDPAR files fiscal yr. 2003 | Mixed
| | 1 yr.
Rosenqvist^211^ 1998 | Europe | Prospective cohort | ICD | 778 | NA | Medtronic 7219 C & D | 63 European centers | Mixed
| | 4 mo. | | | | Pectoral or abdominal
Schläpfer^212^ 2002 | Switzerland | Prospective cohort | ICD vs. amiodarone | 41 | Not included | NR Epicardial, non-thoracotomy | One center | Secondary
| | 63 ± 30 mo.
Vollmann^213^ 2003 | Europe, United States, Canada | RCT parallel | ICD Single-chamber vs. dual-chamber | 542 | NA combined groups | Medtronic 6942 or 6944 | 48 centers | Mixed
| | 1 year | | | | Pectoral
Wiegand^214^ 2004 | Germany | Retrospective cohort | ICD | 372 | Not included | NR | Single center | Mixed
| | 12 yr. | | | | Sub-pectoral

ICD = implanted cardioverter defibrillator; MEDPAR = Medicare Provider Analysis and Review; NA = not applicable; NR = not reported; RCT = randomized controlled trial

Table 13 Baseline characteristics of patients in additional studies included in the ICD safety review for peri-implant complications only

Author Year | Study Group | Males, n (%) | Mean age, yr. mean ± SD | Ischemic, % | NYHA class | | | | Other measures | | Inclusion criteria
Trial name | | | | | I% | II, % | III, % | IV, % | Atrial fibrillation % | LVEF, mean ± SD
Al-khatib^204^ 2005 | ICD | 7,724 (78.4) | NR | NR | NR | NR | NR | NR | NR | NR | ICD for any indication
Bänsch^205^ 2004 | ICD | NR | NR | 82.4 | 24.5 | 58.8 | 16.6 | 0 | NR | 37.5 ± 13.5 | Spontaneous or inducible monomorphic VTs with a cyclic length > = 300 ms
Boriani^206^ 2003 | ICD | 69 (77.5) | 64.1 ± 12.5 | 60 | 32 | 60 | NR | NR | 100 | 46 ± 16 | History of persistent of paroxysmal AF or AT in past yr.
Brockers^207^ 2002 | ICD | 115 (88.5) | 61 ± 11 | 100 | NR | NR | NR | NR | NR | 36 ± 12 | CAD patients undergoing ICD implant
Gradaus^208^ 2003 | ICD | 2,682 (80.2) | 61.1 ± 12.1 | 64.6 | 19.3 | 54.3 | 20.9 | 1.1 | NR | 70.6% > 30 | ICD patients in EURID registry Jan. 1998–Oct. 2000
Hlatky^209^ 2002 | ICD | 18,255 (80.9) | 71.5 ± NR | 6 | NR | NR | NR | NR | NR | NR | ≥65 yr, ICD9 37.94 (implantation or replacement of ICD).
Nademanee^210^ 2003 | ICD | 45 (95.7) | 40.9 ± 11 | NR | 100 | 0 | 0 | 0 | NR | 66.1 ± 10.3 | SUDS survivor or probable SUDS patient
DEBUT
Reynolds^203^ 2006 | ICD | 24,401 (78.8) | NR | NR | NR | NR | NR | NR | NR | NR | ICD9 37.94 (implantation or replacement of ICD) or ICD9 00.51 (CRT +ICD)
Rosenqvist^211^ 1998 | ICD | 635 (81.6) | 58 ± 13 | 58 | 22.6 | 53.3 | 23.1 | 0.9 | NR | 39 ± 17 | Patients with abdominal or pectoral ICD implant
Schläpfer^212^ 2002 | ICD | 78 (93) | 60 ± 10 | NR | NR | NR | III or IV = 23 | | NR | 36 ± 11 | Age 20–80 yr. with MI and first episode of sustained VT or VT
Vollmann^213^ 2003 | ICD | 452 (83.4) | 64.8 ± 10.9 | 79 | NR | NR | NR | NR | NR | 35.5 ± 14.4 | Indication for conventional ICD; pectoral implantation was possible
Wiegand^214^ 2004 | ICD | 306 (82.3) | 62.5 ± 11 | 71 | NR | NR | NR | NR | 28 | NR | Pectoral implantation; generator replacements or lead revision

AF = atrial fibrillation; AT = atrial tachycardia; CAD = coronary artery disease; CRT = cardiac resychronization therapy; EURID = European Registry of Implantable Defibrillators; ICD = implanted cardioverter defibrillator; ICD9 = International Classification of Diseases, 9th Revision; MI = myocardial infarction; NR = not reported, SUDS = Sudden Unexplained Death Syndrome, VF = ventricular fibrillation; VT = ventricular tachycardia,

## Methodological Quality of Included Studies: Efficacy Review

### CRT Alone or Combined CRT-ICD Devices

As a measure of methodological quality for the included trials, the Jadad^253^ score (maximum 5 points) was 5 for one trial,^4^ 4 for three trials,^6,^ ^8,^ ^14^ 3 for four trials,^5,^ ^7,^ ^16,^ ^17^ 2 for five trials,^9,^ ^11^–^13,^ ^15^ and 1 for the remaining study^10^ (Table 14).

Table 14 Methodological quality of randomized trials included in the efficacy review: CRT alone or combined CRT-ICD devices

Author Year | Randomization | | Double-blinding | | Description of withdrawals/ dropouts | Jadad score | Allocation concealment
Trial name | Stated | Method described | Stated | Method described
Abraham 2002^4^ | Yes | Adequate | Yes | Adequate | Adequate | 5 | Clear
MIRACLE
Cazeau 2001^5^ | Yes | Adequate | No | NR | Adequate | 3 | Unclear
MUSTIC-SR
Young 2003^6^ | Yes | Unclear | Yes | Adequate | Adequate | 4 | Unclear
MIRACLE-ICD
Leclercq 2002^7^ | Yes | Adequate | No | NR | Adequate | 3 | Unclear
MUSTIC-AF
Auricchio 2002^8^ | Yes | Unclear | Yes | Adequate | Adequate | 4 | Unclear
PATH-CHF
Higgins^9^ 2003 | Yes | Unclear | No | NR | Adequate | 2 | Unclear
CONTAK-CD
Leclercq^10^ 2003 | Yes | NA | No | NA | NA | 1 | NA
RD-CHF
Bristow^11^ 2004 | Yes | Unclear | No | NR | Adequate | 2 | Unclear
COMPANION
Auricchio^12^ 2003 | Yes | Unclear | No | NR | Adequate | 2 | Unclear
PATH-CHF II
Kindermann^13^ 2006 | Yes | Unclear | No | NR | Adequate | 2 | Unclear
HOBIPACE
Abraham^14^ 2004 | Yes | Unclear | Yes | Adequate | Adequate | 4 | Clear
MIRACLE ICD II
Cleland^15^ 2005 | Yes | Unclear | No | NR | Adequate | 2 | Unclear
CARE-HF
St. Jude^16^ 2005 | Yes | Unclear | Yes | Unclear | Adequate | 3 | Unclear
VecTOR
St. Jude^17^ 2004a | Yes | Unclear | Yes | Unclear | Adequate | 3 | Unclear
RHYTHM ICD

NA = not available; NR = not reported

All trials were described as randomized; however, the description of randomization detail varied. Three were adequately randomized^4,^ ^5,^ ^7^ and the rest were unclear. Two reported clear concealment of allocation^4,^ ^14^ and the remaining trials were unclear. Six trials were double-blind (patient and the outcome assessor blinded), ^4,^ ^6,^ ^8,^ ^14,^ ^16,^ ^17^ four were single-blind,^5,^ ^7,^ ^12,^ ^13^ and four were not blinded.^9^–^11,^ ^15^ In CONTAK CD,^9^ MIRACLE,^4^ MIRACLE ICD,^6^ and CARE-HF,^15^ the independent events committee was blinded to the trial arm the patient was in; no information was available for COMPANION.^11^ Three trials randomized patients before device implantation,^11,^ ^15,^ ^16^ while all other trials randomized patients after their device was successfully implanted. An intention-to-treat statistical analysis was specified in all trials, and MIRACLE^4^ and PATH-CHF^8^ performed an intention-to-treat analysis. Withdrawals and dropouts were clearly described in all trials. Unscheduled crossovers occurred in 0 to 9 percent of the patients in these trials and the number of patients were generally balanced between study arms. Withdrawals ranged from 0 to 3 percent for the cardiac resynchronization group and from 0 to 2.5 percent for the control groups.

Industry sponsored 12 of the 14 trials; 2 also received funding from government sources.^5,^ ^7^ Guidant Corp. sponsored four,^8,^ ^9,^ ^11,^ ^12^ Medtronic Inc. sponsored six,^4^–^7,^ ^14,^ ^15^ ELA Medical Inc. funded two,^5,^ ^7^ and St. Jude Medical Inc. funded two.^16,^ ^17^ Kindermann did not receive industry funding.^13^ Funding for RD-CHF^10^ is not known.

### ICD Alone

As a measure of methodological quality for the included trials, the Jadad^253^ score was 3 for three trials,^134,^ ^139,^ ^140^ 2 for six trials,^11,^ ^133,^ ^135,^ ^137,^ ^138,^ ^142^ and 1 for the remaining three (Table 15).^136,^ ^141,^ ^143^ All trials were described as randomized; however, the description of randomization detail varied. Four described their randomization methods adequately,^133,^ ^134,^ ^139,^ ^142^ and the rest were unclear. Three reported clear concealment of allocation,^134,^ ^136,^ ^139^ and the rest were unclear. One ICD trial was double-blind; ^140^ however, in five trials the independent events committee was blinded to the trial arm the patient was in,^136^–^139,^ ^142^ and in seven trials blinding was unclear.^11,^ ^133^–^135,^ ^140^–^142^ An intention-to-treat statistical analysis was specified and performed in all trials. Withdrawals and dropouts were clearly described in all but five trials.^133,^ ^136,^ ^141^–^143^ Unscheduled crossovers occurred in 0 to 22 percent of the patients in these trials and were generally balanced between study arms. Withdrawals ranged from 0 to 6 percent for the ICD group and from 0 to 32 percent for the control groups. Allocation concealment was unclear for all but three trials.^134,^ ^136,^ ^139^

Table 15 Methodological quality of randomized trials included in the efficacy review: ICD

Author Year | Randomization | | Double blinding | | Description of withdrawals/ dropouts | Jadad score | Allocation concealment
Trial name | Stated | Method described | Stated | Method described
Moss^133^ 1996 | Yes | Clear | No | NR | Unclear | 2 | Unclear
MADIT
Bigger^134^ 1997 | Yes | Clear | No | NR | Adequate | 3 | Adequate
CABG-Patch
Moss^135^ 2002 | Yes | Unclear | No | NR | Adequate | 2 | Unclear
MADIT II
Bänsch^136^ 2002 | Yes | Unclear | No | NR | Unclear | 1 | Adequate
CAT
Strickberger^137^ 2003 | Yes | Unclear | No | NR | Adequate | 2 | Unclear
AMIOVIRT
Kadish^138^ 2004 | Yes | Unclear | No | NR | Adequate | 2 | Unclear
DEFINITE
Bristow^11^ 2004 | Yes | Unclear | No | NR | Adequate | 2 | Unclear
COMPANION
Hohnloser^139^ 2004 | Yes | Clear | No | NR | Adequate | 3 | Adequate
DINAMIT
Bardy^140^ 2005 | Yes | Unclear | Yes | NR | Adequate | 3 | Unclear
SCD-HeFT
AVID Investigators^141^ 1997 | Yes | Unclear | No | NR | Unclear | 1 | Unclear
AVID
Connolly^142^ 2000 | Yes | Clear | No | NR | Unclear | 2 | Unclear
CIDS
Kuck^143^ 2000 | Yes | Unclear | No | NR | Unclear | 1 | Unclear
CASH

NR = not reported

Industry sponsored 10 of the 12 trials; 4 also received funding from institute or foundation sources^134,^ ^140^–^142^ and 3 from pharmaceutical companies. ^140,^ ^142,^ ^143^ Guidant Corp. sponsored seven,^11,^ ^133^–^137,^ ^143^ Medtronic Inc. sponsored one^140^ and St. Jude Medical Inc. funded two.^138,^ ^139^

## Methodological Quality of Included Studies: Effectiveness and Safety Reviews

### CRT Alone or Combined CRT-ICD Devices

Overall, the studies were rated as having “good” quality on the Downs and Black^254^ scoring system. Fourteen studies were described as randomized (described in Table 14) and the remaining 113 were observational studies. (Table 16). Reporting ranged from fair to good with 51 percent rating 10 or 11 out of 11, the rest ranging from scores of 3 to 9. External validity assessment posed some problems because authors did not report the source population for patients or the proportion of eligible patients selected for inclusion, nor compare the distribution of main confounding factors with the source population. For this review we defined the source population as those with symptomatic HF. Since this procedure can only be performed in specialized centers, we determined that all facilities were representative of patients in usual practice. Internal validity concerning assessment of bias ranged from scores of 0 to 7 out of 7 (median = 5); the lack of blinding was the main shortfall. Internal validity assessments concerning confounding ranged from scores of 0 to 5 out of 6 (median = 4), with 17 studies scoring 2 or less. This is in part due to the studies having no randomization component. Many authors did not state the period of time over which patients were recruited or the source of patients. Three studies included a power calculation,^36,^ ^83,^ ^125^ and 102 out of 113 had sufficient sample sizes to determine a clinically important effect.

Table 16 Methodological quality assessment of included studies in the effectiveness and safety reviews: CRT alone or combined CRT-ICD devices

Author Year | | Downs and Black quality score | | | | | Funding
| Reporting | External validity | Internal validity (bias) | Internal validity (confounding) | Power | Overall
| Maximum 11 | Maximum 3 | Maximum 7 | Maximum 6 | Maximum 2 | Maximum 29
Achilli^18^ 2003 | 11 | 3 | 6 | 4 | 1 | 25 | NR
Adamson^19^ 2004 | 11 | 1 | 5 | 3 | 1 | 21 | NR
Albertsen^20^ 2005 | 11 | 3 | 5 | 3 | 1 | 23 | Foundation
Alonso^21^ 1999 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Ammann^22^ 2004 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Ansalone^23^ 2002 | 6 | 1 | 5 | 2 | 1 | 15 | NR
Aranda^24^ 2005 | 9 | 3 | 5 | 4 | 1 | 22 | NR
Auricchio^25^ 2002b | 10 | 1 | 5 | 3 | 1 | 20 | Private industry
Azizi^26^ 2006 | 8 | 3 | 5 | 3 | 1 | 20 | NR
Baker^27^ 2002 | 11 | 1 | 4 | 4 | 1 | 21 | Private industry
Bax^28^ 2003 | 8 | 2 | 5 | 3 | 1 | 19 | Foundation
Bax^29^ 2004 | 9 | 3 | 6 | 4 | 1 | 23 | NR
Bleeker^30^ 2005a | 9 | 3 | 6 | 4 | 1 | 23 | Foundation
Bleeker^31^ 2005b | 10 | 3 | 6 | 3 | 1 | 23 | Foundation
Bleeker^32^ 2006 | 9 | 3 | 6 | 4 | 1 | 23 | Foundation
Bocchiardo^33^ 2000 | 8 | 1 | 3 | 4 | 1 | 17 | NR
Bonanno^34^ 2004 | 10 | 1 | 4 | 4 | 0 | 19 | NR
Bordachar^35^ 2004 | 11 | 2 | 5 | 4 | 1 | 23 | NR
Boriani^36^ 2006a | 11 | 2 | 5 | 5 | 2 | 25 | Private industry
Boriani^37^ 2006b | 9 | 3 | 5 | 4 | 1 | 22 | None
Boriani^38^ 2006c | 10 | 2 | 5 | 4 | 1 | 22 | Foundation
Braun^39^ 2005 | 10 | 2 | 5 | 4 | 1 | 22 | None
Braunschweig^40^ 2005 | 9 | 1 | 5 | 2 | 1 | 18 | Private industry
Cazeau^41^ 2003 | 6 | 0 | 3 | 3 | 1 | 13 | NR
Chalil^42^ 2006 | 10 | 3 | 5 | 4 | 1 | 23 | Private industry
Chan^43^ 2003 | 7 | 2 | 5 | 4 | 1 | 19 | NR
Chugh^123^ 2005 | 10 | 3 | 4 | 4 | 1 | 22 | NR
Cowburn^44^ 2005 | 8 | 3 | 4 | 4 | 1 | 20 | Foundation
Da Costa^45^ 2006 | 11 | 1 | 6 | 4 | 1 | 23 | NR
Daubert^46^ 1998 | 11 | 1 | 4 | 3 | 1 | 20 | NR
Davis^47^ 2005 | 10 | 3 | 5 | 4 | 1 | 23 | NR
de Cock^124^ 2004 | 4 | 3 | 5 | 3 | 1 | 16 | NR
De Martino^125^ 2004 | 9 | 3 | 5 | 5 | 2 | 24 | NR
De Martino^126^ 2005 | 10 | 3 | 5 | 4 | 1 | 23 | NR
De Sisti^48^ 2005 | 11 | 1 | 5 | 2 | 1 | 20 | NR
Diaz-Infante^49^ 2005 | 11 | 3 | 5 | 4 | 1 | 24 | Private industry
Dixon^50^ 2004 | 10 | 1 | 5 | 4 | 1 | 21 | NR
Duncan^51^ 2006 | 10 | 1 | 6 | 3 | 1 | 21 | Internal
Ellery^52^ 2005 | 8 | 1 | 4 | 2 | 1 | 16 | Private industry
Ermis^53^ 2004 | 11 | 3 | 5 | 4 | 1 | 24 | NR
Fung^54^ 2005 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Gaita^55^ 2000 | 8 | 2 | 4 | 4 | 1 | 19 | NR
Galvao^56^ 2002 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Gasparini^57^ 2003a | 9 | 2 | 5 | 2 | 1 | 19 | NR
Gasparini^127^ 2005 | 10 | 3 | 5 | 3 | 0 | 21 | NR
Gras^58^ 2002 | 9 | 1 | 5 | 1 | 1 | 17 | NR
Hernandez^59^ 2004 | 8 | 1 | 3 | 1 | 0 | 13 | Private industry
Hua^60^ 2006 | 8 | 1 | 5 | 2 | 1 | 17 | NR
Kautzner^128^ 2004 | 10 | 2 | 5 | 4 | 1 | 22 | Government
Kies^128^ 2005 | 9 | 3 | 5 | 4 | 1 | 22 | Private industry
Kies^62^ 2006 | 9 | 3 | 5 | 2 | 1 | 20 | Foundation
Koos^63^ 2004 | 11 | 1 | 5 | 4 | 1 | 22 | NR
Krahn^64^ 2002 | 10 | 3 | 5 | 4 | 0 | 22 | Foundation
Kuhlkamp^65^ 2002 | 11 | 1 | 5 | 3 | 0 | 20 | Private industry
Leclercq^66^ 2000 | 10 | 2 | 5 | 2 | 0 | 19 | NR
Lecoq^68^ 2005 | 10 | 2 | 4 | 4 | 1 | 21 | NR
Lenom^69^ 2005 | 5 | 0 | 2 | 0 | 0 | 7 | NR
Leon^70^ 2005 | 11 | 1 | 5 | 3 | 1 | 21 | Private industry
Lindner^71^ 2005 | 9 | 2 | 5 | 4 | 1 | 21 | NR
Macioce^72^ 2005 | 9 | 1 | 5 | 1 | 1 | 17 | NR
Mair^73^ 2005 | 10 | 1 | 4 | 4 | 1 | 20 | NR
Mangiavacchi^74^ 2006 | 9 | 1 | 5 | 3 | 1 | 19 | NR
Marai^75^ 2006 | 9 | 3 | 5 | 1 | 1 | 19 | NR
Mascioli^76^ 2002 | 8 | 2 | 5 | 4 | 1 | 20 | NR
Mele^77^ 2006 | 10 | 1 | 6 | 2 | 1 | 20 | Private industry
Molhoek^78^ 2002 | 10 | 2 | 5 | 3 | 1 | 21 | NR
Molhoek^79^ 2004a | 9 | 3 | 5 | 4 | 1 | 22 | NR
Molhoek^80^ 2004b | 9 | 3 | 5 | 4 | 1 | 22 | NR
Molhoek^81^ 2004 | 9 | 3 | 5 | 4 | 0 | 21 | NR
Molhoek^82^ 2005 | 10 | 1 | 5 | 3 | 1 | 20 | NR
Mortensen^83^ 2004 | 10 | 1 | 5 | 4 | 2 | 22 | Private industry
Murphy^84^ 2006 | 9 | 1 | 5 | 4 | 1 | 20 | NR
Navia^86^ 2005 | 11 | 3 | 5 | 4 | 1 | 24 | NR
Niu^87^ 2006 | 5 | 3 | 5 | 1 | 1 | 15 | NR
Notabartolo^88^ 2004 | 10 | 3 | 5 | 4 | 1 | 23 | NR
O'Donnell^89^ 2005 | 7 | 3 | 6 | 4 | 1 | 21 | NR
Oliva^90^ 2005 | 7 | 1 | 2 | 1 | 1 | 12 | NR
Ollitrault^91^ 2003 | 7 | 1 | 4 | 0 | 1 | 13 | NR
Pappone^92^ 2003 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Penicka^93^ 2004 | 10 | 3 | 6 | 4 | 1 | 24 | Foundation
Pitzalis^94^ 2005 | 9 | 3 | 5 | 4 | 1 | 22 | NR
Porciani^95^ 2006a | 9 | 1 | 5 | 3 | 1 | 19 | NR
Porciani^96^ 2006b | 8 | 3 | 5 | 3 | 1 | 20 | NR
Puglisi^97^ 2004 | 11 | 3 | 5 | 3 | 1 | 23 | NR
Purerfellner^130^ 2000 | 7 | 2 | 5 | 3 | 1 | 23 | NR
Purnode^98^ 2004 | 4 | 1 | 2 | 0 | 1 | 8 | NR
Reuter^99^ 2000 | 9 | 1 | 5 | 2 | 1 | 18 | NR
Reuter^100^ 2002 | 11 | 3 | 5 | 3 | 1 | 23 | NR
Ricci^101^ 2002 | 8 | 1 | 3 | 2 | 1 | 15 | NR
Ritter^102^ 2006 | 10 | 1 | 5 | 4 | 1 | 21 | NR
Romeyer- Bouchard^131^ 2005 | 10 | 1 | 5 | 1 | 0 | 17 | NR
Rossillo^103^ 2004 | 10 | 3 | 5 | 3 | 1 | 22 | NR
Salukhe^104^ 2005 | 10 | 3 | 7 | 4 | 1 | 25 | NR
Sawhney^105^ 2004 | 11 | 2 | 6 | 5 | 1 | 25 | NR
Saxon^106^ 2006 | 10 | 1 | 5 | 2 | 0 | 18 | Private industry
Schuchert^132^ 2004 | 10 | 1 | 5 | 4 | 1 | 21 | NR
Sogaard^107^ 2002 | 9 | 3 | 5 | 4 | 1 | 22 | NR
Stahlberg^108^ 2005 | 11 | 3 | 5 | 4 | 1 | 24 | Foundation
St Jude^17^ 2004 | 11 | 2 | 5 | 4 | 0 | 22 | Private industry
Taieb^109^ 2002 | 3 | 0 | 0 | 1 | 1 | 5 | NR
Tedrow^110^ 2006 | 9 | 3 | 5 | 4 | 1 | 22 | NR
Teo^111^ 2003 | 10 | 3 | 4 | 3 | 1 | 21 | NR
Theuns^112^ 2005 | 9 | 1 | 5 | 2 | 1 | 18 | NR
Toussaint^113^ 2003 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Vidal^114^ 2006 | 9 | 1 | 6 | 3 | 1 | 20 | Spanish Society of Cardiology
Waggoner^115^ 2006 | 8 | 1 | 5 | 4 | 1 | 19 | Government
Witte^116^ 2006 | 8 | 1 | 6 | 3 | 1 | 19 | Private industry
Ypenburg^117^ 2006 | 11 | 3 | 5 | 4 | 1 | 24 | NR
Yu^118^ 2002 | 9 | 3 | 5 | 3 | 1 | 21 | Private industry
Yu^119^ 2003 | 10 | 1 | 5 | 4 | 1 | 21 | NR
Yu^120^ 2004 | 9 | 1 | 5 | 4 | 1 | 20 | NR
Yu^121^ 2005 | 10 | 1 | 6 | 3 | 1 | 21 | NR
Zhang^122^ 2006 | 10 | 1 | 5 | 2 | 1 | 19 | Li Ka Shing Institute of Health Sciences

NR = not reported

Most studies did not report funding, but the majority of those that did received funding from industry.^17,^ ^25,^ ^27,^ ^36,^ ^40,^ ^42,^ ^49,^ ^52,^ ^59,^ ^61,^ ^65,^ ^70,^ ^77,^ ^83,^ ^106,^ ^116,^ ^118^ Sixteen received funding from either government or foundations.^20,^ ^28,^ ^30^–^32,^ ^36,^ ^44,^ ^51,^ ^62,^ ^64,^ ^93,^ ^108,^ ^114,^ ^115,^ ^122,^ ^128^

### ICD Alone

Overall, the studies were rated as having “good” quality on the Downs and Black scoring system. Twelve studies were described as randomized (Table 15) and the remaining 57 were observational studies (Table 17). Reporting was generally good with 37 of 57 scoring 10 or 11 out of 11, the rest scoring from 4 to 9. External validity assessment posed some problems because authors did not report the source population for patients or the proportion of eligible patients selected for inclusion, nor did they compare the distribution of main confounding factors with the source population. For this review we defined the source population as those with left ventricular dysfunction. Since this procedure is mainly performed in specialized centers, we determined that the facilities were representative. Internal validity concerning assessment of bias ranged from scores of 0 to 7 out of 7 (median = 5); the lack of blinding was the main shortfall. Internal validity assessments concerning confounding ranged between scores of 0 to 6 out of 6 (median = 4), with four studies receiving scores of 2 or less.^146,^ ^173,^ ^186,^ ^199^ Seven studies included a power calculation.^151,^ ^156,^ ^175,^ ^192^–^194,^ ^200^

Table 17 Methodological quality assessment of included studies in the effectiveness and safety reviews: ICD alone

Author Year | Downs and Black quality score | | | | | | Funding
| Reporting | External validity | Internal validity (bias) | Internal validity (confounding) | Power | Overall
| Maximum 11 | Maximum 3 | Maximum 7 | Maximum 6 | Maximum 2 | Maximum 29
Alter^144^ 2005 | 10 | 3 | 4 | 4 | 1 | 22 | NR
Backenkohler^145^ 2005 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Blangy^146^ 2003 | 4 | 0 | 2 | 0 | 1 | 7 | NR
Bode-Schnurbus^147^ 2004 | 10 | 3 | 5 | 4 | 1 | 23 | Foundation
Bokhari^148^ 2004 | 10 | 2 | 5 | 5 | 1 | 23 | NR
Bruch^149^ 2006 | 8 | 3 | 6 | 4 | 1 | 22 | NR
Brunckhorst^150^ 2004 | 0 | 2 | 0 | 0 | 0 | 2 | NR
Buxton^151^ 1999 | 10 | 3 | 6 | 5 | 2 | 26 | Private industry
Capoferri^152^ 2004 | 9 | 2 | 5 | 4 | 1 | 21 | NR
Carlsson^192^ 2003 | 10 | 3 | 5 | 5 | 2 | 25 | NR
Chan^153^ 2005 | 8 | 3 | 5 | 4 | 1 | 21 | NR
Chan^154^ 2006 | 10 | 3 | 5 | 3 | 1 | 22 | Private industry, government
Cuesta^155^ 2003 | 10 | 3 | 5 | 4 | 0 | 22 | Foundation
Dorian^193^ 2004a | 11 | 2 | 7 | 6 | 2 | 28 | Private industry
Dorian^156^ 2004b | 11 | 2 | 7 | 5 | 2 | 27 | Private industry
Dubner^157^ 2005 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Duray^158^ 2005 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Elhendy^159^ 2005 | 11 | 3 | 5 | 4 | 1 | 24 | NR
Ellenbogen^160^ 2003 | 10 | 1 | 5 | 4 | 0 | 20 | Private industry
Ermis^161^ 2003 | 10 | 3 | 5 | 4 | 1 | 23 | Foundation
Evonich^162^ 2004 | 11 | 3 | 5 | 4 | 1 | 24 | NR
Friedman^194^ 2006 | 10 | 1 | 6 | 6 | 2 | 25 | Private industry
Gatzoulis^163^ 2005 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Greenberg^164^ 2002 | 9 | 3 | 5 | 4 | 1 | 22 | NR
Grimm^165^ 2002 | 11 | 1 | 5 | 4 | 1 | 22 | NR
Grimm^195^ 2006 | 10 | 1 | 5 | 3 | 1 | 20 | NR
Ho^166^ 2005 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Hreybe^196^ 2006 | 9 | 3 | 5 | 4 | 1 | 22 | NR
Koplan^167^ 2006 | 9 | 3 | 5 | 4 | 1 | 22 | NR
Lampert^168^ 2004 | 9 | 3 | 5 | 4 | 1 | 22 | NR
Leosdottir^169^ 2006 | 9 | 3 | 5 | 4 | 1 | 22 | NR
Lickfett^197^ 2004 | 11 | 3 | 4 | 3 | 1 | 22 | NR
Nazarian^170^ 2005 | 7 | 3 | 5 | 4 | 1 | 20 | NR
Niehaus^198^ 2003 | 10 | 1 | 5 | 3 | 1 | 20 | Private industry
Noseworthy^171^ 2004 | 11 | 3 | 5 | 4 | 1 | 24 | NR
Parkash^172^ 2006 | 9 | 3 | 5 | 4 | 1 | 22 | NR
Pires^173^ 2002 | 9 | 1 | 5 | 2 | 1 | 18 | NR
Pires^174^ 2006 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Raitt^175^ 2005 | 10 | 2 | 7 | 5 | 2 | 26 | Private industry, government
Raviele^176^ 2005 | 10 | 2 | 5 | 5 | 1 | 23 | Private industry
Robin^177^ 2006 | 10 | 2 | 5 | 4 | 1 | 22 | Private industry, government
Russo^178^ 2003 | 7 | 2 | 5 | 4 | 0 | 18 | NR
Saba^179^ 2003 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Saeed^199^ 2003 | 11 | 2 | 4 | 2 | 1 | 20 | NR
Sanchez^180^ 2005 | 8 | 3 | 5 | 4 | 1 | 21 | NR
Sanchez^181^ 2006 | 11 | 3 | 6 | 4 | 1 | 25 | NR
Schaer^182^ 2006 | 7 | 3 | 5 | 4 | 1 | 20 | NR
Sears^183^ 2004 | 6 | 1 | 4 | 3 | 1 | 15 | NR
Takahashi^184^ 2002 | 11 | 3 | 4 | 4 | 1 | 23 | NR
Tandri^185^ 2006 | 10 | 3 | 5 | 4 | 1 | 23 | Private industry
Telfer^186^ 2002 | 10 | 1 | 5 | 2 | 0 | 18 | NR
Theuns^200^ 2004 | 9 | 3 | 4 | 6 | 2 | 24 | Private industry
Theuns^201^ 2005a | 10 | 2 | 5 | 4 | 1 | 22 | NR
Theuns^187^ 2005b | 9 | 3 | 5 | 4 | 1 | 22 | NR
Wase^189^ 2004 | 9 | 3 | 5 | 4 | 1 | 22 | NR
Wilkoff^190^ 2006 | 10 | 3 | 6 | 6 | 2 | 27 | Private industry
Zecchin^191^ 2004 | 10 | 1 | 5 | 3 | 1 | 20 | NR

NR = not reported

Most studies did not report on funding. Thirteen reported sponsorship funding from industry, ^151,^ ^154,^ ^156,^ ^160,^ ^175^–^177,^ ^185,^ ^187,^ ^190,^ ^193,^ ^194,^ ^198^ and three reported government funding in addition to industry.^154,^ ^175,^ ^177^ Two received funds from foundations.^147,^ ^161^

Safety Review for Peri-Implant Complications of ICD Alone

These 12 observational studies were rated as having “good” quality on the Downs and Black scoring system. Reporting was generally good with eight studies scoring 10 or 11 out of 11, the rest ranging from 5 to 9 (Table 18). External validity assessment posed some problems because authors did not report the source population for patients or the proportion of eligible patients selected for inclusion, nor did they compare the distribution of main confounding factors with the source population. For this review, we defined the source population as those having an ICD implanted for any reason, such that not all had left ventricular systolic dysfunction. Since this procedure is mainly performed in specialized centers, we determined that the facilities were representative. Internal validity concerning assessment of bias ranged from 3 to 6 out of 7 (median = 5); the lack of blinding was the main shortfall. Internal validity assessments concerning confounding ranged between scores of 1 to 4 out of 6 (median = 4), with two receiving scores of 2 or less.^208,^ ^209^ Two studies included a power calculation,^205,^ ^210^ and six (50%) had sufficient sample sizes to determine a clinically important effect.^156,^ ^175,^ ^192,^ ^193,^ ^200^

Table 18 Methodological quality assessment of additional studies included in the ICD safety review for peri-implant complications only

Author Year | | Downs and Black quality score | | | | | Funding
| Reporting | External validity | Internal validity (bias) | Internal validity (confounding) | Power | Overall
| Maximum 11 | Maximum 3 | Maximum 7 | Maximum 6 | Maximum 2 | Maximum 29
Al-Khatib^204^ 2005 | 10 | 3 | 5 | 3 | 1 | 22 | Private Industry
Bänsch^205^ 2004 | 9 | 1 | 6 | 4 | 2 | 22 | Private Industry
Boriani^206^ 2003 | 10 | 2 | 5 | 3 | 0 | 20 | NR
Brockes^207^ 2002 | 9 | 1 | 5 | 3 | 0 | 18 | NR
Gradaus^208^ 2003 | 9 | 3 | 5 | 2 | 1 | 20 | NR
Hlatky^209^ 2002 | 5 | 3 | 3 | 1 | 0 | 12 | Government
Nademanee^210^ 2003 | 10 | 1 | 5 | 4 | 2 | 22 | Foundation
Reynolds^203^ 2006 | 10 | 3 | 5 | 4 | 1 | 23 | NR
Rosenqvist^211^ 1998 | 10 | 1 | 5 | 3 | 0 | 19 | NR
Schlapfer^212^ 2002 | 11 | 3 | 5 | 4 | 1 | 24 | Foundation
Vollmann^213^ 2003 | 11 | 1 | 5 | 4 | 1 | 22 | Private Industry
Wiegand^214^ 2004 | 11 | 3 | 5 | 4 | 1 | 24 | NR

NR = not reported

Half of the studies did not report on funding. Three reported sponsorship funding from industry,^204,^ ^205,^ ^213^ one reported government funding,^209^ two received funds from foundations.^210,^ ^212^

## Quantitative Results: Efficacy Review

### CRT Alone

All-Cause Mortality. Based on data pooled from all 14 RCTs (n = 544 deaths/3,825 patients), CRT alone significantly reduced all-cause mortality (RR = 0.78; 95% CI, 0.67 to 0.91, Figure 4). There was negligible statistical heterogeneity among trials (I^2^ = 0 percent). The results were identical when the analysis was restricted to trials which enrolled only those patients with NYHA class III or IV symptoms (n = 498 deaths/2,778 patients, RR = 0.78; 95% CI, 0.67 to 0.91; I^2^ = 0 percent). All-cause mortality in the control patients with symptomatic heart failure (NYHA class II-IV) was 15 percent and the number needed to treat (NNT) to prevent one death was 29 over a median followup of 6 months in patients with symptomatic heart failure. All-cause mortality in the control patients with NYHA class III or IV symptoms was 20 percent and the NNT to prevent one death was 23 over a median followup of 3 months. Although no differences were detected in all-cause mortality (RR = 0.86; 95% CI, 0.54 to 1.39) in the four trials^6,^ ^9,^ ^14,^ ^17^ that included an ICD in both the experimental and control arms (i.e., combined CRT-ICD vs. ICD alone), this analysis is based on just 88 deaths in 1,224 patients. Thus, while the data from the other 10 trials comparing CRT alone vs. medical therapy conclusively demonstrated reduced mortality (RR = 0.77; 95% CI, 0.66 to 0.91) with CRT, the difference between the pooled effect estimates from the CRT+ICD vs. ICD alone trials and the pooled effect estimates from the CRT alone vs. medical therapy trials was not statistically significant (p = 0.67).

Progressive Heart Failure Mortality. Eight trials reported progressive heart failure mortality in NYHA class II to IV patients (n = 203 deaths/3,004 patients); CRT alone conferred a statistically significant reduction in this endpoint (RR = 0.64; 95% CI, 0.49 to 0.84) with negligible heterogeneity (I^2^ = 0 percent; Figure 5). Restricting this analysis to patients with NYHA class III or IV symptoms provided similar results (n = 103 deaths/1,408 patients, RR = 0.56; 95% CI, 0.38 to 82; I^2^ = 0 percent). In the two trials which tested combined CRT-ICD vs. ICD alone and reported this outcome, the benefits of CRT were similar (n = 13 deaths/671 patients, RR = 0.44; 95% CI, 0.14 to 1.42; p = 0.53 for comparison with non-ICD trials).

Figure 5. Metagraph of mortality due to progressive heart failure: CRT alone

Sudden Cardiac Death. Using data pooled from the 11 trials that reported this outcome, the incidence of sudden cardiac death (n = 165 deaths/3503 patients) was no different between CRT recipient and control groups (RR = 1.07; 95% CI, 0.79 to 1.46; Figure 6). This result demonstrated no statistical heterogeneity (I^2^ = 0 percent) and was similar if restricted to trials of 6 months or longer (RR = 1.02; 95% CI, 0.75 to 1.40; I^2^ = 0 percent) or if restricted to patients with NYHA class III or IV symptoms (n = 85 deaths/1,452 patients, RR = 0.91; 95% CI, 0.60 to 1.38, I^2^ = 0 percent). Although results were slightly more favorable toward control for the three trials which tested combined CRT-ICD vs. ICD alone and reported this outcome, they were still nonsignificant (RR = 1.45; 95% CI, 0.43 to 4.91; p = 0.62 for comparison with non-ICD trials).

Figure 6. Metagraph of mortality due to sudden cardiac death: CRT alone

Noncardiac Death. Pooled data from the six trials (n = 40/1,738 patients) reporting this outcome did not demonstrate any significant differences in noncardiac deaths between patients with CRT alone vs. controls (RR = 0.81; 95% CI, 0.43 to 1.52; Figure 7). This result was not statistically heterogeneous (I^2^ = 0 percent).

Figure 7. Metagraph of mortality due to noncardiac death: CRT alone

Heart Failure Hospitalizations. Pooled results from the seven trials that reported HF hospitalizations demonstrated a significant reduction in the number of patients hospitalized at least once for HF (n = 514/2,270 patients, RR = 0.63; 95% CI, 0.43 to 0.93; Figure 8) in favor of CRT alone compared to control. This result was substantially heterogeneous (I^2^ = 74 percent). Restricting the analysis to patients with more advanced HF (those with NYHA class III or IV symptoms) revealed greater reductions (n = 280 hospitalized for HF/1,411 patients, RR = 0.51; 95% CI, 0.41 to 0.64) and was statistically homogeneous (I^2^ = 0 percent). However, no benefits were seen in the two combined CRT-ICD vs. ICD trials which reported this outcome (RR = 1.00; 95% CI, 0.80 to 1.24; p < 0.0001 for comparison with non-ICD trials), and the presence of an ICD in both arms of these studies seemed to be the main cause of the heterogeneity present in this outcome for the seven CRT trials.

Figure 8. Metagraph of heart failure hospitalizations: CRT alone

6-minute Walk Test. CRT was associated with an improved 6-minute walk test distance (WMD = 24m; 95% CI, 13m to 35m; Figure 9) compared to controls, although there was substantial heterogeneity in this estimate (I^2^ = 53 percent). This improvement was similar in those patients with more advanced HF, i.e., NYHA class III or IV symptoms (WMD = 32m; 95% CI, 13 to 51; I^2^ = 64 percent). The magnitude of change for the 6-minute walk test of 24m is difficult to interpret in light of other trials that have shown a weak correlation between this and other functional testing (e.g., NYHA class, LVEF, VO_2_ max.). Importantly, the change in 6-minute walk test is highly dependent on age and less so on NYHA class.^265^ Subgrouping by the presence of an ICD showed that those trials without an ICD (WMD = 31m; 95% CI, 16m to 46m; I^2^ = 56 percent) showed greater improvement than those with an ICD (WMD = 12m; 95% CI, 0m to 25m; I^2^ = 0 percent). However, the difference was not statistically significant (p = 0.06) and did not explain all the heterogeneity as the ICD group still contained substantial heterogeneity.

Figure 9. Metagraph of 6-minute walk test: CRT alone

New York Heart Association Functional Class. Functional class data from three studies were combined in a meta-analysis (although 10 studies reported NYHA class at baseline and at conclusion of followup, only three reported it in a format which permitted pooling of data across studies). Combining these three studies showed improvements in NYHA class in 59 percent of CRT patients and 37 percent of controls (CRT was associated with a 1.55 times increased chance of improving at least one NYHA class; 95% CI, 1.25 to 1.92; Figure 10). This result was heterogeneous (I^2^ = 59 percent). In patients with NYHA class III or IV symptoms, the relative risk of improving at least one NYHA class was greater (RR = 1.69; 95% CI, 1.47 to 1.94) and demonstrated less heterogeneity (I^2^ = 0 percent). The data from MIRACLE-ICD^6^ were not reported in a format that permitted pooling with the other three trials; however, the median NYHA Class for both groups was III at baseline and was II in the CRT group vs. III in the control group at the end of the study. This improvement in NYHA Class was significant (p = 0.01) and favored CRT; the specific statistical test used was not reported. Although the data from CARE-HF^15^ were not reported in a format that permitted pooling with the other trials, the CARE-HF investigators documented statistically significantly improved NYHA class 90 days after randomization in patients receiving CRT alone compared to controls (mean NYHA class 2.7 vs. 2.1, p < 0.001). This was also true for the PATH-CHF II, HOBIPACE, and RHYTHM-ICD trials (mean changes of 0.25, 0.6, and 0.2 respectively in favor of CRT).^12,^ ^13,^ ^17^ Only the PATH-CHF Trial^8^ (which also could not be combined with the other trials due to the manner in which the data were reported) failed to identify a difference between treatment arms; however, both arms demonstrated significant improvements from baseline and the sample was underpowered to detect a difference.

Figure 10. Metagraph of improvement in NYHA functional class: CRT alone

Quality of Life. Quality of life was measured by the Minnesota Living With Heart Failure Instrument^266^–^268^ for 11 trials; pooled results showed a significant improvement in favor of CRT (WMD = -8.0 points; 95% CI, -10.4 to -5.6 points; Figure 11). Although this result demonstrated substantial heterogeneity (I^2^ = 61 percent), the results were consistent in direction across studies. Restricting the analysis to only those patients with NYHA class III or IV symptoms slightly increased the difference between the CRT and control groups (WMD = -8.6 points; 95% CI, -12.1 to -5.1 points; I^2^ = 73 percent). Subgrouping by presence of ICD also did not explain the heterogeneity as the no ICD group (WMD = -8.1 points; 95% CI, -11.2 to -5.0) and ICD group (WMD = -7.8 points; 95% CI, -12.1 to -3.5) were nearly identical. These differences are clinically significant since the minimal clinically important difference for the Minnesota Living with Heart Failure Questionnaire has been established to be 5 points.^266^–^268^

Figure 11. Metagraph of quality of life (MLHFI): CRT alone

Left Ventricular Ejection Fraction. Ejection fraction significantly improved in the CRT alone arm compared to the control arm in the 5 trials in which it was reported (WMD = 3.0 percent; 95% CI, 0.9 to 5.1 percent; I^2^ = 75 percent; Figure 12).

Figure 12. Metagraph of left ventricular ejection fraction: CRT alone

Sensitivity Analyses. Many a priori subgroup and sensitivity analyses (including examining any interactions between the effects of CRT in patients with different etiologies of heart failure, or by ethnic background, gender, age, comorbidities, and baseline medication use) could not be performed due to our inability to obtain individual patient-level data from these trials. None of the CRT trials reported definitive subgroup effects. For example, although the PATH CHF II Investigators^12^ reported significantly larger improvements in exercise capacity in patients with QRS duration > 150 msec at baseline than those with shorter QRS width, this was based on only 16 patients; similarly, the report from the HOBIPACE Investigators^13^ that the functional improvements with CRT were greater in those patients with septal coronary sinus leads outside of the anterolateral region was based on 17 patients. Further, while a post hoc analysis of the MIRACLE trial suggested that patients with an ischemic etiology demonstrated less improvements in LVEF and ventricular volumes with CRT than those patients with nonischemic disease,^216^ mortality benefits with CRT did not differ between ischemic and nonischemic patients in the COMPANION, CARE-HF, or CONTAK CD Trials (i.e., those trials which specifically examined for this interaction in analyses specified a priori).^9^ However, it should be noted that these trials were not powered to detect such subgroup effects.^11,^ ^15^

A series of univariate meta-regressions on our three most important outcomes (all-cause mortality, HF hospitalizations, and quality of life as assessed by the Minnesota Living With Heart Failure Instrument) revealed that while no factors influenced the all-cause mortality results, several factors (presence of an ICD in both controls and CRT patients, NYHA class II at baseline, and higher LVEF) were significantly associated with a reduced magnitude of beneficial effects from CRT (see table below). It should be noted that these analyses are based on aggregate level data from a small number of relatively homogenous trials.

The COMPANION trial^11^ provides the only direct comparison between combined CRT-ICD vs. CRT alone devices. Although this was not a primary pre-specified comparison within this trial (which was designed to compare both arms against optimal medical therapy alone), the chi-square test for all-cause mortality was not significant [p = 0.13] and the reductions in HF hospitalizations were similar in the combined CRT-ICD vs. CRT alone arms.^269^

When the data were pooled for all-cause mortality from the four trials^6,^ ^9,^ ^14,^ ^17^ that included an ICD in both the experimental and control arms (i.e., combined CRT-ICD vs. ICD alone), no differences were detected (RR = 0.86; 95% CI, 0.54 to 1.39), but this analysis is based on just 88 deaths in 1,224 patients. On the other hand, pooling data from the other 10 trials comparing CRT alone vs. medical therapy demonstrated reduced mortality (RR = 0.77; 95% CI, 0.66 to 0.91) with CRT (Figure 13). However, this difference between the pooled effect estimates from the combined CRT-ICD vs. ICD alone trials and the pooled effect estimates from the CRT alone vs. medical therapy trials was not statistically significant (p = 0.67), supporting the assertion arising from the COMPANION trial data that the benefits of CRT (at least on all-cause mortality) are not appreciably altered by addition of an ICD. However, using the same meta-regression model revealed that CRT appeared to have less impact on HF hospitalizations when it was added to patients with an ICD (RR = 1.00; 95% CI, 0.80 to 1.24 in the 2 trials [234 of 859 patients hospitalized] comparing combined CRT-ICD devices with ICD alone) than when CRT was compared to patients treated with medical therapy alone (RR = 0.51, 95% CI 0.41 to 0.64 in the five non-ICD trials reporting this outcome [280 of 1411 patients hospitalized]); p < 0.0001 for comparison between those trials with/without ICD in both arms of the trial.

Figure 13. Metagraph of all-cause mortality: CRT alone or combined CRT-ICD devices

Publication Bias. Publication bias was examined for our primary outcome, all cause mortality. The funnel plot (Figure 14) did appear somewhat asymmetric indicating possible publication bias. Both Begg's rank correlation test (p = 0.06) and Egger's test (p = 0.06) just failed to achieve statistical significance. Using the trim and fill correction added four studies to our meta-analysis, but the new estimate was largely unchanged from the original (RR = 0.77, 95% CI, 0.62 to 0.92). Interestingly, the bias indicated in all of these tests was that studies which favoured CRT were less likely to be published — the opposite of what one usually would expect in funnel plot asymmetry. This would imply that if publication bias truly did exist, the true relative risk reduction with CRT could be even greater than that observed.

### Combined CRT-ICD Devices

Only one trial compared combined CRT-ICD to medical therapy alone.^11^ Its effect on all-cause mortality was statistically significant (hazard ratio = 0.64; 95% CI, 0.48 to 0.86), and although larger than the effect size reported for the CRT alone vs. medical therapy comparison (hazard ratio = 0.76; 95% CI, 0.58 to 1.01), this difference was not statistically significant (p = 0.13). The effects of the combined CRT-ICD device in COMPANION for nonmortality outcomes were similar to the results reported in those trials which compared CRT alone vs. medical therapy: statistically significant improvements were seen in six minute walk test (Mean Difference = 45m; 95% CI, 27 to 63), NYHA functional class (RR = 1.49; 95% CI, 1.23 to 1.81, for improving at least one NYHA class), and quality of life (Mean difference = -14 points; 95% CI, -18 to -10, on the Minnesota Living with Heart Failure Instrument).

### ICD Alone

All-Cause Mortality. Based on data pooled from all 12 randomized controlled trials (1851 deaths in 8,516 patients), ICD alone significantly reduced all-cause mortality (RR = 0.80; 95% CI, 0.71 to 0.90; Figure 15 in patients with left ventricular systolic dysfunction). All-cause mortality in the control patients with left ventricular systolic dysfunction was 25 percent, so the NNT to prevent one death was 20 over a median followup of 35 months in these patients. There was moderate statistical heterogeneity among trials (I^2^ = 44 percent). The results were similar (but more homogeneous) when the analysis was restricted to patients with NYHA Class II or III symptoms (RR = 0.77; 95% CI, 0.65 to 0.90; I^2^ = 0 percent). All-cause mortality in the control patients with left ventricular systolic dysfunction and NYHA class II or III symptoms was 29 percent and the NNT to prevent one death was 15 over a median followup of 72 months in these patients.

Mode of Death Analysis. Unlike the CRT trials (in which the majority of trials classified deaths into those due to progressive heart failure mortality vs. sudden cardiac death vs. non-cardiac death), the ICD trials focused almost exclusively on all-cause mortality and sudden cardiac death. Two trials reported progressive heart failure mortality and the data was not conclusive (n = 125 deaths/1668 patients; RR = 0.99; 95% CI, 0.70 to 1.38; I^2^ = 0 percent ) (Figure 16). Ten ICD trials reported rates of sudden cardiac death and confirmed the benefits of ICD for this outcome (n = 414 deaths/5608 patients; RR = 0.46; 95% CI, 0.37 to 0.57; Figure 17). This result was not statistically heterogeneous (I^2^ = 0 percent). All studies enrolled patients with NYHA class I to III, thus without individual patient data no sub-analysis by NYHA class could be performed. Pooled data from 8 trials reporting non-cardiac deaths did not demonstrate any significant differences between patients with ICD compared to controls (n = 183/4304 patients; RR = 1.27; 95% CI, 0.95 to 1.69; Figure 18). This result was not statistically heterogeneous (I^2^ = 0 percent).

Figure 16. Metagraph of death due to progressive heart failure: ICD alone

Figure 17. Metagraph of mortality due to sudden cardiac death: ICD alone

Heart Failure Hospitalizations. Pooled results from the two trials that reported HF hospitalizations suggested no difference between ICD and control, but was not conclusive due to the small number of events (810 of 2,248 patients hospitalized for HF; RR = 1.10; 95% CI, 0.76 to 1.59; Figure 19).

Figure 19. Metagraph of heart failure hospitalizations: ICD alone

6-Minute Walk Test. One study comparing ICD to control had data on 6-minute walk test. ICD patients did not appear to walk further than control patients, although the data was not conclusive (MD = 6 m; 95% CI, -8 m to 19 m).^11^

New York Heart Association Functional Class. One study reported data on NYHA functional class and there was no statistically significant difference between ICD and control patients during followup (RR = 0.93; 95% CI, 0.84 to 1.04).^11^

Quality of Life. Quality of life as measured by the Minnesota Living with Heart Failure Instrument was reported in one trial and there was no significant difference between ICD and control (MD = -1.0 points; 95% CI, -4.5 to 2.5).^11^ One other trial used a generic quality of life score and found no difference between ICD and control.^137^

Sensitivity Analyses. Many a priori subgroup and sensitivity analyses (including examining any interactions between the effects of ICD in patients with different etiologies of HF, or by ethnic background, gender, age, comorbidities, NYHA class, and baseline medication use) could not be performed due to our inability to obtain individual patient-level data from these trials. Although only one trial reported a significant subgroup effect (the SCD-HeFT Investigators^140^ reported that the mortality benefits of ICD were greater in patients with NYHA class II symptoms than those with NYHA class III symptoms at baseline - p<0.001), it should be noted that these trials were not powered to detect such subgroup effects. A series of univariate meta-regression sensitivity analyses on the primary outcome (all-cause mortality) were performed. As shown in the table below, none of the covariates we examined contributed to the moderate heterogeneity observed in our meta-analysis of all-cause mortality. As with our meta-regressions with the CRT trials, it should be noted these analyses are based on aggregate level data from a small number of relatively homogenous trials. There were too few studies reporting HF hospitalizations or any of the other secondary outcomes to do meta-regressions on those outcomes.

Although the single trial that included CRT in the two study arms for its comparison of ICD vs. control failed to achieve statistical significance for all-cause mortality (RR = 0.83; 95% CI, 0.66 to 1.05), the point estimate was almost identical to that reported in the remainder of the studies which did not contain CRT in either arm (RR = 0.79; 95% CI, 0.69 to 0.91). The difference between this single trial and the other CRT trials was not statistically significant (p = 0.93), supporting the assertion that the benefits of ICD on all-cause mortality are not appreciably altered by addition of a CRT. ICDs were equally beneficial in reducing all-cause mortality in both primary prevention trials (RR = 0.81; 95% CI, 0.69 to 0.95) and secondary prevention trials (RR = 0.77; 95% CI, 0.65 to 0.91)—see Figure 20 (p-value for comparison = 0.59).

Publication Bias. There was no indication of any publication bias for our primary outcome (all-cause mortality) when comparing ICD to control. The funnel plot did not appear asymmetric (Figure 21), and Begg's rank correlation test (p = 0.54), Egger's regression test (p = 0.81) and Duval's trim and fill (no studies added) all indicated that there was little possibility that publication bias influenced these results.

## Quantitative Results: Effectiveness Review

### CRT Alone

All-Cause Mortality. As shown in Figure 22, mortality over time was similar in the randomized trials and the observational studies for patients who received CRT devices. One observational study had contemporaneous control group permitting calculation of a relative risk for all-cause mortality and mode of death analyses—the effectiveness point estimates were almost identical to the efficacy estimates, although none were statistically significant due to the small number of events (all-cause mortality RR = 0.64; 95% CI, 0.26 to 1.56; Figure 4; progressive HF mortality RR = 0.68; 95% CI, 0.16 to 2.92; Figure 5; and sudden cardiac death RR = 0.61; 95% CI, 0.18 to 2.04; Figure 6).

Left Ventricular Ejection Fraction. The effectiveness estimate from the one controlled observational study that reported this outcome was consistent with our findings in the efficacy trials (WMD = 4.6 percent; 95% CI, 2.68 to 6.34 percent; Figure 12).

Other Endpoints. No controlled observational studies reported non-cardiac deaths, heart failure hospitalizations, New York Heart Association functional class, 6-minute walk test results, or quality of life assessments.

Nonresponse Rates. As outlined in Table 21, 22 studies reported on response rates in CRT recipients. Since the definitions varied between studies, these data were not meta-analyzed. The reported response rates varied between 63 percent and 82 percent in those studies using definitions of response based on functional status and between 55 percent and 69 percent in those studies employing echocardiographic definitions for response. Various parameters have been reported in some of these studies to predict response to CRT, but no factors were found to be independent predictors consistently across studies (Table 21). Without access to individual patient data from these studies it was not possible to perform multivariate analyses to define predictors of response in the pooled data.

### Combined CRT-ICD Devices

There were no controlled effectiveness studies which compared combined CRT-ICD to contemporaneous controls.

### ICD Alone

All-Cause Mortality. The benefit of ICD on all-cause mortality was greater in the 11 observational studies with contemporaneous control groups than in the RCTs (Figure 15). The pooled relative risk was 0.54 (95% CI, 0.43 to 0.68), although heterogeneity was substantial (I^2^ = 60 percent). As shown in Figure 23, mortality over time was similar in the randomized trials and the observational studies for patients who received ICD devices.

Progressive Heart Failure Mortality. Three observational controlled studies reported this outcome, although the result was not significant (RR = 1.15; 95% CI, 0.50 to 2.66; I^2^ = 30 percent).

Sudden Cardiac Death. The effectiveness estimate derived from eight observational studies with control groups was greater than the estimate from the RCTs (RR = 0.33; 95% CI, 0.23 to 0.46; I^2^ = 0 percent; Figure 17).

Non-Cardiac Death. The effectiveness estimate derived from the eight observational studies with control groups revealed a benefit in favor of ICD (RR = 0.74; 95% CI, 0.65 to 0.85; I^2^ = 0 percent; Figure 18). This unexpected result suggests that clinicians do select healthier patients for ICD insertion since ICD alone should not impact noncardiac deaths.

No controlled observational studies reported HF hospitalizations, quality of life, or changes in NYHA functional class or 6-minute walk test with ICD.

### Mortality Comparison Across Devices and Study Types

We evaluated all-cause mortality vs. length of followup in all studies that followed patients with CRT alone, ICD alone, or combined CRT-ICD. Mortality increased as length of followup increased; however, we were interested in differences in rates of increase in each of the three groups. A weighted regression was performed for each group. The plots, along with best fitting regression line, are represented in Figures 22, 23, and 24.

The CRT studies had an increase in mortality of approximately 5.9 percent with each followup year. This was slightly higher for the combined CRT-ICD device group with a per annum increase of 6.2 percent. However, the ICD alone group had the smallest increase in annual mortality at 3.7 percent. It should be noted that the ICD studies tended to be much longer in duration than the CRT studies and this may have skewed these results.

## Quantitative Results: Safety Review

### CRT Alone

Fifty-four studies (n = 6,123 patients) reported data which permitted us to examine the safety of CRT. Table 22 reports peri-implantation and post-implantation risks from individual studies as well as pooled results for CRT alone devices. During data pooling, studies that did not report any data for particular outcomes were excluded.

Peri-Implantation Risks. Twenty-four studies reported data on deaths while undergoing implantation of a biventricular pacemaker. There were 8 deaths in 2,571 patients (pooled risk = 0.3 percent, 95% CI, 0.1 to 0.6 percent). Implants of devices were successful in 93 percent (95% CI, 92.2 to 93.7 percent) of attempts in 4,625 patients from 41 studies. Twenty-one studies that reported on peri-implantation mechanical complications showed a frequency of 4.3 percent (95% CI, 3.6 to 5.1 percent) in 3,139 patients. Of note, implant success rates and peri-implantation risks were no different in the CRT RCTs as in the observational studies conducted in non-trial settings.

Post-Implantation Risks. Post-implant mechanical malfunction was reported to be 4.0 percent (95% CI 3.0 to 5.2 percent) over a median followup of 12 months in 9 studies (1,316 patients), with no appreciable difference between the frequencies reported in observational studies vs. RCTs (Table 17). The device malfunction frequency was 5.4 percent (95% CI, 4.2 to 6.7 percent) over a median followup of 6 months in 20 studies (1,339 patients), post-implant lead problems were reported in 6.6 percent (95% CI, 5.8 to 7.4 percent) of patients over a median followup of 11 months in 32 studies (3,649 patients), and post-implant infections occurred in 1.8 percent (95% CI, 1.3 to 2.5 percent) of patients as reported in 16 studies (2,088 patients)—none of these outcomes differed between the CRT RCTs and the observational studies. The frequency of post-implant arrythmias attributed to the CRT device occurred in a far higher proportion of patients in the CRT RCTs (12 percent; 95% CI, 9.5 to 14.9 percent) than in the observational studies (5.4 percent; 95% CI, 2.4 to 10.4 percent), likely reflecting the closer followup in RCTs.

### Combined CRT-ICD Devices

Thirty-six studies (5,199 patients) reported data which permitted the examination of the safety of combined CRT-ICD. Table 21 report peri-implantation and post-implantation risks from individual studies as well as pooled results. During data pooling, studies that did not report any data for particular outcomes were excluded.

Peri-Implantation Risks. Twenty studies reported data on deaths while undergoing implantation of a CRT and ICD: there were 13 deaths in 2,731 patients (pooled risk = 0.5 percent; 95% CI, 0.2 to 0.8 percent). Implants of devices were successful in 93.7 percent (95% CI, 92.9 to 94.4 percent) of attempts in 4,163 patients from 28 studies. Ten studies that reported on peri-implantation mechanical complications showed a frequency of 4.6 percent (95% CI, 3.7 to 5.6 percent) in 1,889 patients. Of note, implant success rates and peri-implantation risks were no different in the combined CRT-ICD RCTs as in the observational studies of these devices conducted in non-trial settings (Table 21).

Post-Implantation Risks. Post-implant mechanical malfunction was reported in 4.6 percent (95% CI, 3.5 to 6.0 percent) of patients from five studies (n = 1,102 patients), the device malfunction frequency was 5.0 percent (95% CI, 4.0 to 6.3 percent) over 12 months in nine studies (1,411 patients), and the frequency of post-implant infections was 1.1 percent (95% CI, 0.7 to 1.7 percent) over 12 months in 10 studies (1,791 patients)—none of these outcomes differed between the combined CRT-ICD RCTs and the observational studies. Post-implant lead problems were reported in 9.8 percent (95% CI, 8.2 to 11.6 percent) of RCT participants compared to 5.7 percent (95% CI, 4.8 to 6.8 percent) of patients in observational studies, again likely reflecting closer scrutiny in the RCT setting or a publication bias in the observational data. While post-implant arrythmias occurred in 6.4 percent (95% CI, 4.6 to 8.7 percent) of patients in two studies (609 patients) which recorded this outcome, inappropriate shocks occurred in 6.0 percent (95% CI, 4.8 to 7.5 percent) of patients over 12 months in the nine studies (1,210 patients) which evaluated this outcome.

### ICD Alone

As previously described, 49 studies were used to examine the safety of ICD alone. Table 22 reports peri-implantation and post-implantation risks from individual studies as well as pooled results. During data pooling, studies that did not report any data for particular outcomes were excluded.

Peri-Implantation Risks. Twenty-eight studies reported data on deaths while undergoing implantation of an ICD: there were 59 deaths in 4,902 patients (pooled risk 1.2 percent, 95% CI, 0.9 to 1.5 percent). Implants of devices were successful in 99.0 percent (95% CI, 98.8 to 99.3 percent) of attempts in 6,189 patients from 24 studies. Eighteen studies that reported on peri-implantation mechanical complications showed a frequency of 5.3 percent (95% CI, 4.6 to 6.2 percent) in 3,299 patients. Of note, implantation success rates were significantly lower and peri-implantation death rates were significantly higher in the ICD RCTs compared to the observational studies. This difference likely reflects closer scrutiny in the RCT setting or a publication bias in the observational data.

We also examined peri-implant deaths and success rates for studies that enrolled all patients undergoing ICD implant, not just those patients with left ventricular systolic dysfunction. Ten studies (34,956 patients) demonstrated a peri-implant death rate of 1.3 percent (95% CI, 1.2 to 1.4 percent). Seven studies (4,940 patients) reported an implant success rate of 98.6 percent (95% CI, 98.3, 98.9). Both of these frequencies (for implant success and peri-implant death) were very similar to the rates reported in studies restricted to patients with left ventricular systolic dysfunction.

Post-Implantation Risks. Implantation mechanical malfunction was reported in 18 studies representing 3,299 patients. The malfunction frequency was 5.3 percent (95% CI, 4.6 to 6.2 percent). The frequency of post-implant mechanical malfunction from 9 studies (2,190 patients) was 2.0 percent (95% CI, 1.5 to 2.7 percent; 0.6 per 100 patient-years [95% CI 0.5 to 0.8]) and the frequency of post-implant device malfunction from 10 studies (2,569 patients) was 5.8 percent (95% CI, 4.9 to 6.7 percent; 1.4 per 100 patient-years [95% CI 1.2 to 1.6])—both frequencies were similar in RCTs as in observational studies. Post-implant lead problems were reported in 16 studies (3,713 patients) and although the pooled rate was 4.3 percent (95% CI, 3.7 to 5.0 percent; 1.5 per 100 patient-years [95% CI 1.3 to 1.8] ), the rate was far lower in RCT data (1.7 percent, 95% CI 1.2 to 2.3 percent) compared to observational data (8.7 percent, 95% CI 7.3 to 10.3 percent). The frequency of post-implant infections was 1.8 percent (95% CI, 1.4 to 2.2 percent; 0.6 per 100 patient-years [95% CI 0.5 to 0.8]) as reported in 17 studies of 4,232 patients, but was lower in observational studies (1.1 percent, 95% CI, 0.6 to 1.7 percent) than RCTs (2.3 percent, 95% CI 1.7 to 2.9 percent). The different direction for these two outcomes (one more frequent in RCTs, the other more frequent in observational studies) raises the possibility that lead infections may have been classified as “lead problems” in some studies but “lead infections” in other studies. The frequency of inappropriate shocks was substantially higher in RCT participants—38.8 percent, 95% CI, 33.9 to 43.7 percent, or 19.1 per 100 patient years [95% CI, 16.5 to 22.0] over 24 months of followup vs. 16.3 percent, 95% CI, 15.0 to 17.7 percent, or 4.7 per 100 patient-years [95% CI, 4.3 to 5.1] over 24 months of followup in the observational studies (pooled 5.8 per 100 patient-years [95% CI, 5.4 to 6.2]).