# Methods

## Literature Search

We systematically searched the following 17 electronic resources: MEDLINE^®^, Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations, Cochrane Central Register of Controlled Trials (which contains the Cochrane Heart Group's Trial Registry; this group hand searches journals pertinent to its content area and adds relevant trials to the registry), Cochrane Database of Systematic Reviews (CDSR), Database of Abstracts of Reviews of Effects (DARE), Health Technology Assessment Database (HTA), EMBASE, Science Citation Index Expanded (via Web of Science^®^), International Pharmaceutical Abstracts, PubMed^®^, National Library of Medicine (NLM) Gateway, OCLC Proceedings First and Papers First, CRISP (Computer Retrieval of Information on Scientific Projects), The National Research Register (UK), Australian Clinical Trials Registry, ClinicalTrials.gov, and Current Controlled Trials. We also searched for relevant reports from the U.S. Food and Drug Administration and for abstracts from the annual Heart Rhythm Society meetings. The reference lists of relevant reviews and included studies were reviewed, and authors of included studies were contacted for additional citations and information. Finally, additional unpublished data (including individual patient data) were sought from the following CRT and ICD manufacturers: Medtronic Inc. (Minneapolis, MN), Guidant Corporation (Indianapolis, IN), and St. Jude Medical Inc. (St. Paul, MN). The search was not limited by language of publication or publication status and is considered current up to November 14, 2006.

The search terms were adapted from the search strategies used in two previous reviews^248,^ ^250^ and included “biventricular pacing,” “biventricular pacer,” “biventricular stimulation,” “BiV,” “artificial cardiac pacing,” “chronic cardiac failure resynchronization therapy,” “single chamber pacing,” “dual chamber pacing,” “cardiac resynchronization,” “Medtronic,” “InSync,” “ELA medical,” “Guidant,” “St. Jude,” “implantable defibrillators,” “AICD,” “ICD,” “single chamber ICD,” “dual chamber ICD,” “congestive heart failure,” “CHF,” “chronic heart failure,” and “heart diseases.” Along with the terms for randomized controlled trials (RCTs), the following terms were used to refine the search for evidence: “controlled clinical trial,” “meta-analysis,” “multi-center trial,” “safety,” “risk,” “adverse effects,” or “adverse symptoms,” “side effects,” “harm,” “contraindications,” “causation,” “causality,” “predict,” “complications,” “inappropriate shocks” or “inappropriate pacing,” “bleeding,” “hemorrhage,” and “infection.”

The complete search strategies (adapted for each database) and search results are included in Appendix A *.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/defibtp.htm

## Selection and Inclusion

To address efficacy questions, we limited our analyses to randomized controlled trials (RCTs). To address effectiveness questions, our inclusion criteria were expanded to include non-RCTs that used contemporaneous comparison arms (e.g., cohort studies). To address safety questions, we included evidence from both RCTs and non-RCTs (including study designs without contemporaneous control arms, such as case series, registry data, etc.) since adverse events are uncommon and uncommonly reported in RCTs (which generally have short followup durations)

To assess efficacy and effectiveness of CRT, ICD, and combined CRT-ICD devices, we selected studies that enrolled greater than 25 participants with a left ventricular ejection fraction (LVEF) ≤ 35 percent, followed patients for at least 2 weeks, and reported at least one outcome of interest: mortality (all-cause, cardiac, HF, sudden cardiac death), quality of life, NYHA functional class, 6-minute walk test, hospitalization (all-cause or HF), or LVEF. To assess the safety of CRT alone or with ICD, we selected studies that enrolled greater than 25 participants with LVEF ≤ 35 percent, followed patients for at least 2 weeks, and reported at least one outcome of interest: implant success rates, or peri-, and post-implantation risks. To assess the safety of ICD, we selected studies that enrolled greater than 25 participants with LVEF ≤ 35 percent, followed patients for at least 2 weeks, and reported at least one outcome of interest: implant success rates, or peri-, and post-implantation risks. After reviewing our draft report, the Technical Expert Panel suggested that we also examine the implant success rates and peri-implant safety of ICD in all patients (not just those patients with LV systolic dysfunction). Although we recognize that many of these patients would have symptomatic HF or asymptomatic LV systolic dysfunction, we decided to analyze peri-implant safety of ICD for all patients, but to report the results for patients known to have LV systolic dysfunction as a subgroup analysis.

## Quality Assessments

### Efficacy Review

The methodological quality of RCTs was assessed independently by two reviewers using two quality assessment methods without being blinded to authors, setting, or results. First, allocation concealment was assessed as adequate, inadequate, or unclear using the Cochrane approach.^252^ Second, a five-point scoring system validated by Jadad^253^ was used to assess randomization, double blinding, and reporting of withdrawals and dropouts. In addition, the funding source and whether authors reported the use of intention-to-treat analysis were noted. Decision rules regarding the application of the tool were developed a priori and discrepancies were resolved through discussion between the two reviewers.

### Effectiveness and Safety Review

The methodological quality of RCTs was assessed as outlined above. The quality of observational studies included in the effectiveness and safety review were assessed independently by two reviewers using a validated checklist developed by Downs and Black.^254^ The checklist includes 28 questions evaluating five criteria: reporting (10 questions, total score 11), external validity (three questions, total score 3), internal validity—bias (seven questions, total score 7), internal validity—confounding (six questions, total score 6) and power (two questions, total score 2). Decision rules regarding the application of the tool were developed a priori and discrepancies in quality assessment were resolved through discussion between the two reviewers.

## Data Extraction

Data were extracted using standardized forms and entered into an Excel (Microsoft Corp., Redmond, WA) spreadsheet. Data were extracted by one reviewer (DD, NH, or CS) and checked for accuracy and completeness by a second (BV). Extracted data included the outcomes described in Tables 2 and 3, study characteristics, inclusion/exclusion criteria, baseline drug use, characteristics of participants, and procedural data.

Table 2 Inclusion and exclusion criteria for efficacy review

Study design | Include: RCT (parallel or crossover) > 2 weeks duration.
| Exclude: non-RCTs, acute physiological studies and studies that do not involve human subjects.
Participants | ICD alone: Include patients with asymptomatic LV systolic dysfunction or symptomatic HF and LVEF ≤ 35%.
| CRT alone or combined CRT-ICD devices: Include patients with symptomatic HF (NYHA Class II-IV) while receiving stable optimal drug therapy, LVEF ≤ 35%, and prolonged QRS. Studies with < 25 participants were excluded.
Interventions | Treatment with active CRT, active ICD, or combined CRT-ICD compared to either placebo pacing, or uni-ventricular (right-sided) pacing, or drug therapy alone. Studies comparing combined CRT-ICD to ICD alone were also included.
Outcomes | Mortality (all-cause, cardiac, HF, sudden cardiac death), quality of life, NYHA functional class, 6-minute walk test, morbidity (including all-cause or HF hospitalization, ED visit), and LVEF.

ED = emergency department; HF = heart failure; LV = left ventricular; LVEF = left ventricular ejection fraction; NYHA = New York Heart Association; = RCT = randomized controlled trial

Table 3 Inclusion and exclusion criteria for effectiveness and safety review

Study design | Include: RCT (parallel or crossover) or non-RCT (e.g., registry data, prospective cohort, case series, FDA document, etc.) > 2 weeks duration.
| Exclude: acute physiological studies and studies not involving human subjects.
Participants | ICD alone: Include patients with asymptomatic LV systolic dysfunction or symptomatic HF and LVEF ≤ 35% (but for peri-implant success rates and complications, include all ICD patients).
| CRT alone or combined CRT-ICD devices: Include patients with symptomatic HF (NYHA Class II-IV) while receiving stable optimal drug therapy, LVEF ≤ 35%, and prolonged QRS.
| Studies with < 25 participants were excluded.
Interventions | Treatment with active CRT, active ICD, or combined CRT-ICD.
| Comparison group not necessary.
Outcomes | Effectiveness: Mortality (all-cause, cardiac, HF, sudden cardiac death), quality of life, NYHA functional class, 6-minute walk test, morbidity (including all-cause or HF hospitalization, ED visit), LVEF.
| Safety: Successful implant rate, risks during implantation (death, lead misplacement, device-related malfunctions, procedural complications, implant tools, heart function, and patient complaints), risks following implantation (mechanical malfunction, lead dislodgment, infection, pain), and battery longevity. For ICD devices, data on inappropriate delivery of therapy, need for additional medication, and need for hospitalization for HF.

Ed = emergency department; HF = heart failure; LV = left ventricular; LVEF = left ventricular ejections fraction; NYHA = New York Heart Association; RCT = randomized controlled trial

## Data Analysis

### Efficacy Review

The following data assumptions were made and imputations performed to transform reported data into the form required for this review. Standard errors (SE) were converted into standard deviations (SD). Graph extraction was performed using CorelDRAW^®^ 9.0 (Corel Corp., Ottawa, Canada). Means were approximated by medians, and 95 percent empirical intervals were used to calculate approximate SDs. Change from baseline data were used wherever possible for continuous data; however, since correlations between baseline and endpoint data were never reported, a correlation of 0.5 was assumed^255^ to calculate the appropriate standard deviation for change from baseline data. Change from baseline and endpoint data were combined; both entities estimate differences between treatment groups. When provided, efficacy results were extracted rather than intention-to-treat results.

Numerical results were meta-analyzed primarily in Review Manager version 4.2.5 (The Cochrane Collaboration, Copenhagen, Denmark). For dichotomous results (e.g., CHF hospitalizations), the review reported relative risks (RR) for each individual study as well as a pooled result among those studies that could be combined. For continuous variables (e.g., 6-minute walk test) mean differences were calculated for separate studies and the weighted mean difference (WMD) was calculated for the pooled estimate. All results were reported with 95 percent confidence intervals (CIs) where possible.

Due to the differences expected between studies (particularly in control group therapies),we decided a priori to combine results primarily using random effects models.^256^ Statistical heterogeneity was quantified and appropriated using the I-squared (I^2^) statistic.^3^ This statistic can be roughly interpreted as the percentage of total variance in the meta-analysis that is due to between-study variation. Inclusion of studies with active control arms was assessed in sensitivity analyses. Relevant direct subgroup comparisons were summarized, including effects of CRT in patients with more severe heart failure symptoms (NYHA Class III or IV). ICDs were considered in an indirect subgroup comparison using meta-regression. Any other reasons for heterogeneity were also explored using meta-regression.

Estimates of carryover effect were extracted from crossover designs. Only period one data were used for irreversible outcomes (i.e., death and CHF hospitalizations). Standard errors for crossover WMD were calculated according to Curtin.^257^

For our primary outcome, all-cause mortality, we tested for publication bias visually using the funnel plot and quantitatively using the rank correlation test,^258^ the graphical test,^259^ and the trim and fill method.^260^ Meta-regression and publication bias calculations were performed using STATA 7.0 (StataCorp., College Station, TX).

### Effectiveness Review

The procedures used for the analysis of efficacy were also used to test for effectiveness, although we did not test for publication bias in observational studies. In addition, mortality rates for both RCTs and observational studies were plotted against followup time and a regression coefficient was computed for each of the three groups (CRT alone, ICD Alone, and CRT+ICD).

### Safety Review

Quantitative results were meta-analyzed primarily in S-PLUS^®^ 6.0 (Insightful Corp., Seattle, WA). Risks were simply pooled and all results were reported with 95% CIs. Statistical heterogeneity was assessed using the Chi-square test; p<0.10 was considered heterogeneous.^261^ Also, heterogeneity was quantified and appropriated using the I^2^ statistic.^3^ The exclusion of NYHA class II data and studies with active control arms was assessed in sensitivity analyses; however, these are not reported here. The possibility that reports may have been less judicious in reporting adverse events was considered. Sensitivity analyses were performed where studies (RCT or cohort) did not report a particular risk (e.g., death); zero adverse events were assumed for these studies. In addition, some implantation risks were reported by event and not by patient. This nonindependence was small and was not expected to affect the results importantly.

Which HF Patients Would Benefit From CRT, ICD, or Combined CRT-ICD Devices?

Within-trial subgroup reports and meta-regression across trials were used to examine the relation between a variety of covariates and the efficacy of CRT, ICD, and combined CRT-ICD devices. Individual patient data was requested from each device manufacturer; however, insufficient data were available to perform an individual patient data meta-analysis by January 9, 2007.