# Introduction

The American College of Cardiology (ACC), the American Heart Association (AHA), and the Heart Rhythm Society (HRS) commissioned this report to review the current evidence about the efficacy, safety, and effectiveness of implantable cardioverter defibrillators (ICD), cardiac resynchronization therapy (CRT), and combined CRT-ICD devices in patients with heart failure (HF) or asymptomatic left ventricular (LV) systolic dysfunction.

## Background

Heart failure (HF) leads to significant morbidity and mortality; in 2001 it accounted for almost one million hospitalizations in the United States (as the most responsible diagnosis) and $29.6 billion in direct and indirect costs.^237^ HF is the fastest growing cardiovascular diagnosis in North America: the community prevalence is estimated at 0.4 percent to 2.4 percent in adults,^237^–^240^ with the annual incidence approaching 10 cases/1,000 in people over 65 years of age.^237^ Indeed, the lifetime risk of developing HF is estimated at 20 percent in North America.^241^ Despite many advances in diagnosis and therapy over the past two decades, HF still carries a poor prognosis.^237,^ ^242^ The functional status of patients with HF is described using the New York Heart Association (NYHA) Classification system: NYHA Class I patients are those who are asymptomatic; NYHA Class II patients are those who develop symptoms (dyspnea or fatigue) with moderate exertion (climbing two flights of stairs or walking two blocks); NYHA Class II patients are symptomatic with mild exertion (climbing one flight of stairs or walking one block); and NYHA Class IV patients are symptomatic at rest.

HF is a clinical syndrome characterized by specific symptoms and is accompanied in most cases by a decreased ejection fraction (“left ventricular systolic dysfunction”).^243^ A plethora of randomized trials over the past 2 decades have established a variety of treatment options for systolic heart failure, as outlined in schematic form below.^243,^ ^244^

In general, management of HF involves a combination of nonpharmacological (e.g., lifestyle modification, education, smoking cessation) and pharmacological approaches. Pharmacological treatment of HF involves a combination of the use of vasodilators (e.g., nitrates), neuro-hormonal agents (e.g., angiotensin-receptor blocker [ARB] and angiotensin-converting enzyme [ACE] inhibitors), beta-blockers, diuretics (e.g., furosemide, spironolactone) and inotropes (e.g., digoxin). In special cases, such as atrial fibrillation, cardiac rate control and/or antiarrhythmic therapy may also be warranted. Prevention of complications such as cardiac embolism (using ASA, warfarin, or both) and infectious diseases (through immunization) are also warranted in this patient group. Finally, due to the complexity of the disease, multidisciplinary approaches to management, including specialized heart function clinics, are strongly encouraged.

Despite evidence-based care using optimal combinations of the nonpharmacologic and pharmacologic approaches summarized above, rates of morbidity and mortality remain high and quality of life is poor for many patients with systolic HF. Attempts to reduce mortality in HF are directed at the two main causes of cardiac death in these patients: sudden cardiac death (electrical failure) and progressive heart failure (mechanical failure).^245^ Sudden cardiac death accounts for more deaths than progressive heart failure in patients with NYHA Class I or II symptom status. On the other hand, progressive heart failure is the predominant cause of death in those with NYHA Class III or IV symptoms.^246^ It is important to emphasize that not all therapies that improve functional outcomes (such as symptoms, quality of life, ejection fraction, and other hemodynamic measurements) in HF patients confer survival benefits.^247^ Thus, it is essential that any novel therapies for patients with HF be evaluated for their impact on hospitalization and/or death.

Clearly, there is a need for additional treatment strategies in HF that can improve function, diminish symptoms, reduce hospitalizations, and increase survival. Recently, attention has focused on the potential for cardiac resynchronization therapy (CRT)—atrial-synchronized biventricular pacing (i.e., pacing the right atrium, right ventricle, and left ventricle)—to reduce the mechanical dyssynchrony common in patients with left ventricular systolic dysfunction, and thereby improve left ventricular filling time, reduce mitral regurgitation, and reduce septal-posterior wall dyskinesis.^1,^ ^2^ An earlier systematic review of the clinical trials of CRT established that, in selected patients with advanced HF and mechanical LV dyssynchrony, CRT improves quality of life, NYHA class, 6-minute walk test results, and reduces both hospitalizations and all-cause mortality (produced primarily by a 40 percent reduction in progressive HF deaths).^248^ However, the previous systematic review had two important weaknesses: (1) it was unable to clarify the relative survival benefits conferred by CRT alone vs. combined CRT-ICD devices given the relative paucity of data at that time, and (2) it was based on efficacy data derived from randomized controlled trials conducted on highly select patients (NYHA III/IV symptoms, sinus rhythm, LVEF < 35 percent, QRS ≥ 120 msec, and on optimal medical therapy) seen at large-volume hospitals by clinicians experienced in CRT device implantation and monitoring.^249^ Thus, this earlier systematic review needed to be updated to (1) incorporate randomized efficacy trials published in the subsequent 3 years, (2) expand the analyses beyond randomized trial evidence to examine the safety and effectiveness of CRT devices when they are used in clinical practice (which may possibly differ from the effect estimates reported in trial participants and settings), and (3) clarify the incremental benefits conferred by combined CRT-ICD devices over CRT alone or ICD alone (which could not be properly evaluated before due to a paucity of evidence at that time) and to define the patient groups most appropriate to receive a CRT device.

ICDs are devices consisting of at least one lead which resides in the right ventricle dedicated to pacing and/or defibrillating lethal cardiac arrhythmias. More advanced ICDs (dual-chamber devices) consist of leads in the right atrium and right ventricle and have the potential to be programmed as a dual-chamber pacemaker (e.g., DDD pacing mode) and for the atrial lead to help discriminate arrhythmic events. ICDs do not improve functional outcomes in patients with HF; however, they do confer a substantial mortality benefit (through the prevention of sudden cardiac death) in patients who have a history of ventricular arrhythmias or who are at high risk for ventricular ectopy due to the severity of their left ventricular dysfunction.^250^ Since an earlier systematic review of ICDs proving the benefits of these devices in the secondary prevention of ventricular arrhythmia deaths in high risk patients, a number of large trials have evaluated the effects of ICDs for primary prevention in patients with symptomatic or asymptomatic left ventricular systolic dysfunction but without known ventricular arrhythmias. As with the CRT review, there are issues concerning the impact of ICDs when used in clinical practice compared with their impact in the optimal settings and highly select participants involved in efficacy trials. Thus, there is a need to (1) update the earlier meta-analysis to incorporate randomized efficacy trials published in the subsequent 4 years, and (2) expand our analyses to examine the safety and effectiveness of ICDs when they are used in clinical practice.

The issue of device effectiveness and safety in clinical practice is particularly important as the rates of implantation for CRTs and ICDs are increasing exponentially. In 2001, 48,127 ICDs were implanted in the United States, of which only two percent were combined CRT-ICD devices.^251^ However, in 2005 over 156,000 ICDs were implanted in the United States, with 42 percent being combined CRT-ICD (Merril Lynch Industry Model Book, May 2006).

This review will examine the evidence for the efficacy, effectiveness, and safety of CRT alone, ICD alone, or combined CRT-ICD in patients with LV systolic dysfunction and will attempt to define the potential role of CRT and/or ICD in managing these patients.

## Study Questions

1 In adult patients with symptomatic or asymptomatic LV systolic dysfunction, what is the efficacy and effectiveness of CRT alone, ICD alone, or combined CRT-ICD devices compared to usual medical therapy?
2 In adult patients with symptomatic or asymptomatic LV systolic dysfunction, what is the efficacy and effectiveness of single-chamber ICD compared to that of dual-chamber ICD?
3 In adult patients with symptomatic or asymptomatic LV systolic dysfunction, how safe is CRT alone, ICD alone, or combined CRT-ICD devices?
4 Which patients would benefit from ICD alone, CRT alone, or combined CRT-ICD devices?