# Appendix E: Technical Expert Panel and Peer Reviewers

## Technical Expert Panel

- William T. Abraham, M.D., F.A.C.P., F.A.C.C., F.A.H.A.
- Professor of Medicine, Chief Division of Cardiovascular Medicine
- The Ohio State University, Columbus, OH

- Mark A. Hlatky, M.D.
- Department of Health Research and Policy
- Stanford University, Stanford, CA

- Richard L. Page, M.D., FA.C.C., F.A.H.A.
- Professor and Head, Division of Cardiology, Department of Medicine
- University of Washington School of Medicine
- Seattle, WA

- Gillian D. Sanders, Ph.D.
- Associate Professor or Medicine
- Duke University Medical Center
- Durham, NC

## Peer Reviewers

- David Atkins, M.D., M.P.H.
- Chief Medical Officer, Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Eric Fain, M.D.
- Executive Vice President, Development and Clinical/Regulatory Affairs
- St. Jude Medical
- Sunnyvale, CA

- Martin Fromer, M.D., F.E.S.C.
- Service de Cardiologie
- Centre Hospitalier Universtaire Vaudois (CHUV)
- Lausanne, Switzerland

- Gordon Moe, M.S., M.D., F.R.C.P.(C), F.A.C.C.
- Director, Heart Failure Program and Biomarker Laboratory, St. Michael's Hospital
- Associate Professor of Medicine, University of Toronto
- Toronto, ON

- Robert F. Rea, M.D.
- Division of Cardiovascular Diseases
- Mayo Clinic
- Rochester, MN

- John Spertus, M.D., M.P.H., F.A.C.C.
- Professor, School of Medicine; Director, Cardiovascular Education and Outcomes Research
- University of Missouri - Kansas City
- Kansas City, MO

- Bob Thompson, M.S., M.A.
- Senior Director, Reimbursement, Economics and Health Policy
- Medtronic
- Minneapolis, MN

- Clyde W.Yancy, M.D., F.A.C.C., F.A.H.A., F.A.C.P.
- Medical Director, Baylor Heart and Vascular Institute
- Baylor University Medical Center
- Dallas, TX