# Appendix D: List of Excluded Studies

## Excluded Studies: CRT Alone and Combined CRT-ICD

The four main reasons for exclusion were based on the publication not having the right study design, population, intervention or outcomes.

### Population

1 Becker R, Ruf-Richter J, Senges-Becker JC, et al. Patient alert in implantable cardioverter defibrillators: toy or tool?. J Am Coll Cardiol. 2004;44(1):95-8. [pmid: 15234415].
2 D'Andrea A, Ducceschi V, Caso P, et al. Usefulness of Doppler tissue imaging for the assessment of right and left ventricular myocardial function in patients with dual-chamber pacing. Int J Cardiol. 2001;81(1):75-83. [pmid: 11690667].
3 Daoud EG, Kalbfleisch SJ, Hummel JD, et al. Implantation techniques and chronic lead parameters of biventricular pacing dual-chamber defibrillators. J Cardiovasc Electrophysiol. 2002;13(10):964-70. [pmid: 12435180].
4 De Souza FSO, Mortati NL, Braile DM, et al. Technical aspects of coronary sinus catheterization based on the atrial component of the intracavitary electrogram and radiological anatomy during the implantation procedure of a biventricular pacemaker. Arq Bras Cardiol. 2006;86(4):261-7. [pmid: 16680290].
5 Dorwarth U, Frey B, Dugas M, et al. Transvenous defibrillation leads: high incidence of failure during long-term follow-up. J Cardiovasc Electrophysiol. 2003;14(1):38-43. [pmid: 12625608].
6 Doshi RN, Daoud EG, Fellows C, et al. Left ventricular-based cardiac stimulation post AV nodal ablation evaluation (the Pave Study). J Cardiovasc Electrophysiol. 2005;16(11):1160-5. [pmid: 16302897].
7 Ferro A, Duilio C, Santomauro M, Cuocolo A. Walk test at increased levels of heart rate in patients with dual-chamber pacemaker and with normal or depressed left ventricular function. Eur Heart J. 2003;24(23):2123-32. [pmid: 14643273].
8 Gould PA, Krahn AD. Complications associated with implantable cardioverter-defibrillator replacement in response to device advisories. JAMA. 2006;295(16):1907-11. [pmid: 16639049].
9 Greenberg JM, Leon AR, Book WM, et al. Benefits of cardiac resynchronization therapy in outpatients with indicators for heart transplantation. J Heart Lung Transplant. 2003;22(10):1134-40. [pmid: 14550823].
10 Hansky B, Vogt J, Gueldner H, et al. Left heart pacing-experience with several types of coronary vein leads. J Interv Card Electrophysiol. 2002;6(1):71-5. [pmid: 11839886].
11 Hauser RG, Hayes DL, Epstein AE, et al. Multicenter experience with failed and recalled implantable cardioverter-defibrillator pulse generators. Heart Rhythm. 2006;3(6):640-4. [pmid: 16731462].
12 Hoffmeister P, Chaudhry GM, Orlov MV, Shukla G, Haffajee CI. Sheathless implantation of permanent coronary sinus-LV pacing leads. Pacing Clin Electrophysiol. 2006;29(2):117-23. [pmid: 16492295].
13 James KB, Militello M, Barbara G, Wilkoff BL. Biventricular pacing for heart failure patients on inotropic support: a review of 38 consecutive cases. Tex Heart Inst J. 2006;33(1):19-22. [pmid: 16572863]. [pmcid: 1413603].
14 Janousek J, Tomek V, Chaloupecky VA, et al. Cardiac resynchronization therapy: a novel adjunct to the treatment and prevention of systemic right ventricular failure. J Am Coll Cardiol. 2004;44(9):1927-31. [pmid: 15519030].
15 Kolb C, Deisenhofer I, Schmieder S, et al. Long-term follow-up of patients supplied with single-chamber or dual-chamber cardioverter defibrillators. Pacing Clin Electrophysiol. 2006;29(9):946-52. [pmid: 16981917].
16 Kuhlkamp V, Wilkoff BL, Brown AB, et al. Experience with a dual chamber implantable defibrillator. Pacing Clin Electrophysiol. 2002;25(7):1041-8. [pmid: 12164444].
17 Porterfield JG, Porterfield LM, Smith BA, Bray L. Experience with three different third-generation cardioverter-defibrillators in patients with coronary artery disease or cardiomyopathy. Am J Cardiol. 1993;72(3):301-4. [pmid: 8342508].
18 Proclemer A, Facchin D, Pagnutti C, Fioretti P, De Michele C. Safety of pacemaker implantation prior to radiofrequency ablation of atrioventricular junction in a single session procedure. Pacing Clin Electrophysiol. 2000;23(6):998-1002. [pmid: 10879385].
19 Sadoul N, Jung W, Jordaens L, et al. Diagnostic performance of a dual-chamber cardioverter defibrillator programmed with nominal settings: a European prospective study. J Cardiovasc Electrophysiol. 2002;13(1):25-32. [pmid: 11843479].
20 Seif M, Al-Ajmi T, Khokhar A, Idris M, Al-Khadra A. Doppler echocardiographic assessment of left ventricular diastolic function following biventricular pacing in patients with congestive heart failure. The XIIth World Congress on Cardiac Pacing & Electrophyiology. Tse HF, Lee KLF, Lau CPMonduzzi, 2003: 833–6.
21 Senges-Becker JC, Klostermann M, Becker R, et al. What is the ‘optimal’ follow-up schedule for ICD patients?. Europace. 2005;7(4):319-26. [pmid: 15944090].
22 Thackray SD, Witte KK, Nikitin NP, Clark AL, Kaye GC, Cleland JG. The prevalence of heart failure and asymptomatic left ventricular systolic dysfunction in a typical regional pacemaker population. Eur Heart J. 2003;24(12):1143-52. [pmid: 12804929].

### Intervention

1 Al-Khadra AS. Use of preshaped sheath to plan and facilitate cannulation of the coronary sinus for the implantation of cardiac resynchronization therapy devices: preshaped sheath for implantation of biventricular devices. Pacing Clin Electrophysiol. 2005;28(6):489-92. [pmid: 15955179].
2 Blanc JJ, Bertault-Valls V, Fatemi M, Gilard M, Pennec PY, Etienne Y. Midterm benefits of left univentricular pacing in patients with congestive heart failure. Circulation. 2004;109(14):1741-4. [pmid: 15023885].
3 Blanc JJ, Fatemi M, Bertault V, Baraket F, Etienne Y. Evaluation of left bundle branch block as a reversible cause of non-ischaemic dilated cardiomyopathy with severe heart failure. A new concept of left ventricular dyssynchrony-induced cardiomyopathy. Europace. 2005;7(6):604-10. [pmid: 16216764].
4 Bongiorni MG, Soldati E, Arena G, et al. Multicenter clinical evaluation of a new SSIR pacemaker. Pacing Clin Electrophysiol. 1992;15(11 Pt 2):1798-803. [pmid: 1279550].
5 Bordachar P, Garrigue S, Reuter S, et al. Hemodynamic assessment of right, left, and biventricular pacing by peak endocardial acceleration and echocardiography in patients with end-stage heart failure. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1726-30. [pmid: 11139910].
6 Bracke FALE, Meijer A, van Gelder LM. Lead extraction for device related infections: a single-centre experience. Europace. 2004;6(3):243-7. [pmid: 15121078].
7 Butter C, Gras D, Ritter P, et al. Comparative prospective randomized efficacy testing of different guiding catheters for coronary sinus cannulation in heart failure patients. J Interv Card Electrophysiol. 2003;9(3):343-51. [pmid: 14618054].
8 Butter C, Meisel E, Tebbenjohanns J, et al. Transvenous biventricular defibrillation halves energy requirements in patients. Circulation. 2001;104(21):2533-8. [pmid: 11714646].
9 Capucci A, Romano S, Puglisi A, et al. Dual chamber pacing with optimal AV delay in congestive heart failure: a randomized study. Europace. 1999;1(3):174-8. [pmid: 11225793].
10 da Silva Menezes A. Outcome of right ventricular bifocal pacing in patients with permanent atrial fibrillation and severe dilated cardiomiopathy due to Chagas disease: three years of follow-up. J Interv Card Electrophysiol. 2004;11(3):193-8. [pmid: 15548885].
11 Doll N, Opfermann UT, Rastan AJ, et al. Facilitated minimally invasive left ventricular epicardial lead placement. Ann Thorac Surg. 2005;79(3):1023-5. [pmid: 15734427].
12 Ector B, Willems R, Heidbuchel H, et al. Epicardial pacing: a single-centre study on 321 leads in 138 patients. Acta Cardiol. 2006;61(3):343-51. [pmid: 16869458].
13 Etienne Y, Mansourati J, Touiza A, et al. Evaluation of left ventricular function and mitral regurgitation during left ventricular-based pacing in patients with heart failure. Eur J Heart Fail. 2001;3(4):441-7. [pmid: 11511430].
14 Fatemi M, Etienne Y, Gilard M, Mansourati J, Blanc JJ. Short and long-term single-centre experience with an S-shaped unipolar lead for left ventricular pacing. Europace. 2003;5(2):207-11. [pmid: 12633648].
15 Feruglio GA, Petz E, Zanuttini D, Ragonese P. Un'esperienza regionale di elettrostimolazione cardiaca: nel Friuli-Venezia Giulia la maggior densita di portatori di pacemaker in Italia, oggi [A regional experience with permanent cardiac pacing: in Friuli-Venezia Giulia the highest density of pacemaker patients in Italy, to-day (author's transl)]. (Ita). G Ital Cardiol. 1978;8(Suppl 1):159-65.
16 Fonarow GC, Feliciano Z, Boyle NG, et al. Improved survival in patients with nonischemic advanced heart failure and syncope treated with an implantable cardioveter-defibrillator. Am J Cardiol. 2000;85(8):981-5. [pmid: 10760339].
17 Galizio NO, Pesce R, Valero E, et al. Which patients with congestive heart failure may benefit from biventricular pacing?. Pacing Clin Electrophysiol. 2003;26(1 Pt 2):158-61. [pmid: 12687804].
18 Gasparini M, Bocchiardo M, Lunati M, et al. Comparison of 1-year effects of left ventricular and biventricular pacing in patients with heart failure who have ventricular arrhythmias and left bundle-branch block: the Bi vs Left Ventricular Pacing: an International Pilot Evaluation on Heart Failure Patients with Ventricular Arrhythmias (BELIEVE) multicenter prospective randomized pilot study. Am Heart J 2006;152(1):155.e1–7.
19 Giudici MC, Lee M, Higgins S, West GR, Moeller AK, Decker JB. Experience with a higher impedance, fixed helix, steroid-eluting pacing lead. Pacing Clin Electrophysiol. 2000;23(7):1103-8. [pmid: 10914365].
20 Gold MR, Brockman R, Peters RW, et al. Acute hemodynamic effects of right ventricular pacing site and pacing mode in patients with congestive heart failure secondary to either ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. 2000;85(9):1106-9. [pmid: 10781760].
21 Hayes DL, Graham KJ, Irwin M, et al. Multicenter experience with a bipolar tined polyurethane ventricular lead. Pacing Clin Electrophysiol. 1995;18(5 Pt 1):999-1004. [pmid: 7659573].
22 Higgins SL, Pak JP, Barone J, et al. The first-year experience with the dual chamber ICD. Pacing Clin Electrophysiol. 2000;23(1):18-25. [pmid: 10666749].
23 Joglar JA, Welch PJ, Wilkinson WE, Hamdan MH, Page RL. Initial experience with a high-impedance tined endocardial pacemaker lead: evidence for increased lead failure. Am Heart J. 1997;134(2 I):161-4. [pmid: 9313592].
24 Kasravi B, Tobias S, Barnes MJ, Messenger JC. Coronary sinus lead extraction in the era of cardiac resynchronization therapy: single center experience. Pacing Clin Electrophysiol. 2005;28(1):51-3. [pmid: 15660803].
25 Kay GN, Brinker JA, Kawanishi DT, et al. Risks of spontaneous injury and extraction of an active fixation pacemaker lead: report of the accufix multicenter clinical study and worldwide registry. Circulation. 1999;100(23):2344-52. [pmid: 10587339].
26 Kettering K, Mewis C, Dornberger V, et al. Long-term experience with subcutaneous ICD leads: a comparison among three different types of subcutaneous leads. Pacing Clin Electrophysiol. 2004;27(10):1355-61. [pmid: 15511244].
27 Krupa W, Kozlowski D, Derejko P, Swiatecka G. Permanent cardiac pacing and its influence on tricuspid valve function. Folia Morphol (Warsz). 2001;60(4):249-57. [pmid: 11770335].
28 Lupi G, Brignole M, Oddone D, Bollini R, Menozzi C, Bottoni N. Effects of left ventricular pacing on cardiac performance and on quality of life in patients with drug refractory heart failure. Am J Cardiol. 2000;86(11):1267-70. [pmid: 11090807].
29 Meisel E, Rauwolf T, Burghardt M, Kappenberger L. [Pacemaker therapy of hypertrophic obstructive cardiomyopathy. PIC (Pacing in Cardiomyopathy) Study Group]. Herz. 2000;25(4):1267-70. (Ger).
30 Morichika N, Okamoto M, Honda T, et al. Left ventricular wall motion analysis during ventricular pacing. J Cardiol. 1993;23(Suppl 37):85-8.
31 Munoz P, Blanco JR, Rodriguez-Creixems M, Garcia E, Delcan JL, Bouza E. Bloodstream infections after invasive nonsurgical cardiologic procedures. Arch Intern Med 2001;161(17):2110–5. Erratum in: Arch Intern Med 2002;162(1):110.
32 Nagele H, Schomburg R, Petersen B, Rodiger W. Dual chamber pacing in patients with severe heart failure on beta blocker and amiodarone treatment: preliminary results of a randomised study. Heart. 2002;87(6):566-7. [pmid: 12010943]. [pmcid: 1767124].
33 Oldershaw PJ, Sutton MG, Ward D, Jones S, Miller GA. Ten-year experience of 359 epicardial pacemaker systems: complications and results. Clin Cardiol. 1982;5(10):515-9. [pmid: 6756737].
34 Perrins EJ, Morely CA, Chan SL, Sutton R. Randomised controlled trial of physiological and ventricular pacing. Br Heart J. 1983;50(2):112-7. [pmid: 6349666]. [pmcid: 481382].
35 Pires LA, Hassan SA, Johnson KM. Coronary sinus lead placement via the internal jugular vein in patients with advanced heart failure: a simplified percutaneous approach. J Int Cardiac Electrophysiol. 2005;12(2):157-62.
36 Schwaab B, Frohlig G, Berg M, Schwerdt H, Schieffer H. Five-year follow-up of a bipolar steroid-eluting ventricular pacing lead. Pacing Clin Electrophysiol. 1999;22(8):1226-8. [pmid: 10461300].
37 Schwaab B, Kindermann M, Frohlig G, Berg M, Kusch O, Schieffer H. Septal lead implantation for the reduction of paced QRS duration using passive-fixation leads. Pacing Clin Electrophysiol. 2001;24(1):28-33. [pmid: 11227965].
38 Sharma AD, Rizo-Patron C, Hallstrom AP, et al. Percent right ventricular pacing predicts outcomes in the DAVID trial. Heart Rhythm. 2005;2(8):830-4. [pmid: 16051118].
39 Shinke T, Takeuchi M, Takaoka H, Yokoyama M. Beneficial effects of heart rate reduction on cardiac mechanics and energetics in patients with left ventricular dysfunction. Jpn Circ J. 1999;63(12):957-64. [pmid: 10614841].
40 Tatarchenko IP, Iskenderov BG, Koledinov VI. Results of 5-year follow-up of patients suffering from chronic circulatory insufficiency and having an implantable pacemaker. [abst]. Kardiologiia. 1992;32(2):45-8.
41 Tse HF, Yu C, Lee KL, et al. Initial clinical experience with a new self-retaining left ventricular lead for permanent left ventricular pacing. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1738-40. [pmid: 11139913].
42 Tse HF, Yu C, Paul VE, et al. Effect of left ventricular function on long-term left ventricular pacing and sensing threshold. J Interv Card Electrophysiol. 2003;9(1):21-4. [pmid: 12975566].
43 Valls-Bertault V, Mansourati J, Gilard M, Etienne Y, Munier S, Blanc JJ. Adverse events with transvenous left ventricular pacing in patients with severe heart failure: early experience from a single centre. Europace. 2001;3(1):60-3. [pmid: 11271954].
44 Vogt P, Goy JJ, Kuhn M, et al. Single versus double chamber rate responsive cardiac pacing: comparison by cardiopulmonary noninvasvice exercise testing. Pacing Clin Electrophysiol. 1988;11(11 Pt 2):1896-901. [pmid: 2463564].
45 Wilkoff BL, Cook JR, Epstein AE, et al. Dual-chamber pacing or ventricular backup pacing in patients with an implantable defibrillator: the Dual Chamber and VVI Implantable Defibrillator (DAVID) Trial. JAMA. 2002;288(24):3115-23. [pmid: 12495391].
46 Yu CM, Lin H, Zhang Q, Sanderson JE. High prevalence of left ventricular systolic and diastolic asynchrony in patients with congestive heart failure and normal QRS duration. Heart. 2003;89(1):54-60. [pmid: 12482792]. [pmcid: 1767510].
47 Yu CM, Yang H, Lau CP, et al. Regional left ventricle mechanical asynchrony in patients with heart disease and normal QRS duration: implication for biventricular pacing therapy. Pacing Clin Electrophysiol. 2003;26(2 Pt 1):562-70. [pmid: 12710315].
48 Zagrodzky JD, Ramaswamy K, Page RL, et al. Biventricular pacing decreases the inducibility of ventricular tachycardia in patients with ischemic cardiomyopathy. Am J Cardiol 2001;87(10):1208–10; A7.

### Outcomes

1 Adamson PB, Kleckner KJ, VanHout WL, Srinivasan S, Abraham WT. Cardiac resynchronization therapy improves heart rate variability in patients with symptomatic heart failure. Circulation. 2003;108(3):266-9. [pmid: 12860899].
2 Alonso C, Leclercq C, d'Allonnes FR, et al. Six year experience of transvenous left ventricular lead implantation for permanent biventricular pacing in patients with advanced heart failure: technical aspects. Heart. 2001;86(4):405-10. [pmid: 11559679]. [pmcid: 1729936].
3 Alonso C, Ritter P, Leclercq C, et al. Effects of cardiac resynchronization therapy on heart rate variability in patients with chronic systolic heart failure and intraventricular conduction delay. Am J Cardiol. 2003;91(9):1144-7. [pmid: 12714168].
4 Aranda JM Jr, Conti JB, Johnson JW, Petersen-Stejskal S, Curtis AB. Cardiac resynchronization therapy in patients with heart failure and conduction abnormalities other than left bundle-branch block: analysis of the Multicenter InSync Randomized Clinical Evaluation (MIRACLE). Clin Cardiol. 2004;27(12):678-82. [pmid: 15628109].
5 Arya A, Haghjoo M, Dehghani MR, et al. Effect of cardiac resynchronization therapy on the incidence of ventricular arrhythmias in patients with an implantable cardioverter-defibrillator. Heart Rhythm. 2005;2(10):1094-8. [pmid: 16188588].
6 Auricchio A, Ding J, Spinelli JC, et al. Cardiac resynchronization therapy restores optimal atrioventricular mechanical timing in heart failure patients with ventricular conduction delay. J Am Coll Cardiol. 2002;39(7):1163-9. [pmid: 11923041].
7 Auricchio A, Spinelli JC, Trautmann SI, Kloss M. Effect of cardiac resynchronization therapy on ventricular modeling. J Card Fail. 2002;8(2):S549-55. [pmid: 12555172].
8 Auricchio A, Stellbrink C, Block M, et al. Effect of pacing chamber and atrioventricular delay on acute systolic function of paced patients with congestive heart failure. The Pacing Therapies for Congestive Heart Failure Study Group. The Guidant Congestive Heart Failure Research Group. Circulation. 1999;99(23):2993-3001. [pmid: 10368116].
9 Auricchio A, Stellbrink C, Sack S, et al. The Pacing Therapies for Congestive Heart Failure (PATH-CHF) study: rationale, design, and endpoints of a prospective randomized multicenter study. Am J Cardiol. 1999;83(5B):130D-5D.
10 Baumann LS, Kadhiresan VA, YU Y, et al. Optimization of cardiac resynchronization therapy in heart failure patients by measuring transient cycle length changes. [abst]. Eur Heart J. 2001;22:443.
11 Berenbom LD, Weiford BC, Vacek JL, et al. Differences in outcomes between patients treated with single-versus dual-chamber implantable cardioverter defibrillators: a substudy of the Multicenter Automatic Defibrillator Implantation Trial II. Ann Noninvasive Electrocardiol. 2005;10(4):429-35. [pmid: 16255753].
12 Berger T, Hanser F, Hintringer F, et al. Effects of cardiac resynchronization therapy on ventricular repolarization in patients with congestive heart failure. J Cardiovasc Electrophysiol. 2005;16(6):611-7. [pmid: 15946359].
13 Birnie D, Soucie LP, Smith S, Tang ASL. Effects of cardiac resynchronisation on maximal and submaximal exercise performance in advanced heart failure patients with conduction abnormality. Heart. 2001;86:703-4. [pmid: 11711474]. [pmcid: 1730000].
14 Bleeker GB, Bax JJ, Fung JW, et al. Clinical versus echocardiographic parameters to assess response to cardiac resynchronization therapy. Am J Cardiol. 2006;97(2):260-3. [pmid: 16442375].
15 Bleeker GB, Kaandorp TA, Lamb HJ, et al. Effect of posterolateral scar tissue on clinical and echocardiographic improvement after cardiac resynchronization therapy. Circulation. 2006;113(7):969-76. [pmid: 16476852].
16 Bleeker GB, Schalij MJ, Boersma E, Steendijk P, Van Der Wall EE, Bax JJ. Does a gender difference in response to cardiac resynchronization therapy exist?. Pacing Clin Electrophysiol. 2005;28(12):1271-5. [pmid: 16403158].
17 Bocchiardo M, Achtelik M, Gaita F, et al. Efficacy of biventricular sensing and treatment of ventricular arrhythmias. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1989-91. [pmid: 11139974].
18 Bordachar P, Lafitte S, Reuter S, et al. Biventricular pacing and left ventricular pacing in heart failure: similar hemodynamic improvement despite marked electromechanical differences. J Cardiovasc Electrophysiol. 2004;15(12):1342-7. [pmid: 15610275].
19 Braunschweig F, Sorensen J, Von Bibra H, et al. Effects of biventricular pacing on myocardial blood flow and oxygen consumption using carbon-11 acetate positron emission tomography in patients with heart failure. Am J Cardiol. 2003;92(1):95-9. [pmid: 12842260].
20 Breithardt OA, Stellbrink C, Herbots L, et al. Cardiac resynchronization therapy can reverse abnormal myocardial strain distribution in patients with heart failure and left bundle branch block. J Am Coll Cardiol. 2003;42(3):486-94. [pmid: 12906978].
21 Brignole M, Gammage M, Puggioni E, et al. Comparative assessment of right, left, and biventricular pacing in patients with permanent atrial fibrillation. Eur Heart J. 2005;26(7):712-22. [pmid: 15618036].
22 Bulava A, Ansalone G, Ricci R, et al. Triple-site pacing in patients with biventricular device-incidence of the phenomenon and cardiac resynchronization benefit. J Interv Card Electrophysiol. 2004;10(1):37-45. [pmid: 14739748].
23 Butter C, Auricchio A, Stellbrink C, et al. Effect of resynchronization therapy stimulation site on the systolic function of heart failure patients. Circulation. 2001;104(25):3026-9. [pmid: 11748094].
24 Calvert MJ, Freemantle N, Cleland JG. The impact of chronic heart failure on health-related quality of life data acquired in the baseline phase of the CARE-HF study. Eur J Heart Fail. 2005;7(2):243-51. [pmid: 15701474].
25 Cappola TP, Harsch MR, Jessup M, et al. Predictors of remodeling in the CRT era: influence of mitral regurgitation, BNP, and gender. J Cardiac Fail. 2006;12(3):182-8.
26 Cazeau S, Bordachar P, Jauvert G, et al. Echocardiographic modeling of cardiac dyssynchrony before and during multisite stimulation: a prospective study. Pacing Clin Electrophysiol. 2003;26(1 Pt 2):137-43. [pmid: 12687799].
27 Cholewinski W, Tarkowska A, Kutarski A, Stefaniak B, Poniatowicz-Frasunek E, Oleszczak K. Effect of biventricular pacing on heart function evaluated by gated blood pool study in patients with end-stage heart failure. Nucl Med Rev. 2002;5(2):155-7.
28 Cleland JG, Daubert JC, Erdmann E, et al. Baseline characteristics of patients recruited into the CARE-HF study. Eur J Heart Fail. 2005;7(2):205-14. [pmid: 15701468].
29 Curnis A, Caprari F, Mascioli G, et al. Valutazione economica della resincronizzazione cardiaca nei pazienti affetti da scompenso cardiaco moderato-avanzato. [Biventricular resynchronization in heart failure: analysis of hospital costs and clinical effectiveness]. (Ita). Pharmacoeconomics Italian Research Articles. 2003;5(1):11-22.
30 De Cock CC, Jessurun ER, Allaart CA, Visser CA. Repetitive intraoperative dislocation during transvenous left ventricular lead implantation: usefulness of the retained guidewire technique. Pacing Clin Electrophysiol. 2004;27(12):1589-93. [pmid: 15613120].
31 De Lurgio DB, Foster E, Higginbotham MB, Larntz K, Saxon LA. A comparison of cardiac resynchronization by sequential biventricular pacing and left ventricular pacing to simultaneous biventricular pacing: rationale and design of the DECREASE-HF clinical trial. J Cardiac Fail. 2005;11(3):233-9.
32 De Marco T, Foster E, Schafer J, et al. Effect of chronic cardiac resynchronization on left ventricular remodeling and neurohormonal activation [abst]. J Am Coll Cardiol. 2001;37(2):118A-9A.
33 Diaz-Infante E, Berruezo A, Mont L, et al. Predictores de ausencia de mejoria clinica a medio plazo con la terapia de resincronizacion cardiaca [Predictors of lack of clinical improvement at mid-term follow-up with cardiac resynchronization therapy]. (Spa). Rev Esp Cardiol. 2004;57(4):306-12.
34 DiCarlo LA Jr, Morady F, Krol RB, et al. The hemodynamic effects of ventricular pacing with and without atrioventricular synchrony in patients with normal and diminished left ventricular function. Am Heart J. 1987;114(4 Pt 1):746-52. [pmid: 3661364].
35 Dohi K, Suffoletto MS, Schwartzman D, Ganz L, Pinsky MR, Gorcsan J 3rd. Utility of echocardiographic radial strain imaging to quantify left ventricular dyssynchrony and predict acute response to cardiac resynchronization therapy. Am J Cardiol. 2005;96(1):112-6. [pmid: 15979447].
36 Duncan A, Wait D, Gibson D, Daubert JC. MUSTIC (Multisite Stimulationin Cardiomyopathies) Trial. Left ventricular remodelling and haemodynamic effects of multisite biventricular pacing in patients with left ventricular systolic dysfunction and activation disturbances in sinus rhythm: sub-study of the MUSTIC (Multisite Stimulationin Cardiomyopathies) trial. Eur Heart J. 2003;24(5):430-41. [pmid: 12633545].
37 Ferreira Santos J, Caetano F, Parreira L, et al. Ecocardiografia com doppler tecidcular para avaliaca~o de doentes com terapeutica de ressincronizaca~o ventricular [Tissue doppler echocardiography for evaluation of patients with ventricular resynchronization therapy]. (Por). Rev Port Cardiol. 2003;22(11):1363-71.
38 Ferreira Santos J, Caetano F, Parreira L, et al. Efeitos da terapeutica de ressincronizaca~o ventricular na funca~o ventricular direita-avaliaca~o por ecocardiografia com doppler tecidular [Effects of cardiac resynchronization therapy on right ventricular function: evaluation with tissue doppler echocardiography]. (Por). Rev Port Cardiol. 2003;22(11):1347-55.
39 Ferro A, Duilio C, Santomauro M, Salvatore M, Cuocolo A. Haemodynamic effects of dual-chamber pacing versus ventricular pacing during a walk test in patients with depressed or normal left ventricular function. Eur J Nucl Med Mol Imaging. 2005;32(9):1075-80. [pmid: 15891919].
40 Filzmaier K, Sinha AM, Breithardt OA, et al. Short-term effects of cardiac resynchronization on brain natriuretic peptide release in patients with systolic heart failure and ventricular conduction disturbance [abst]. J Am Coll Cardiol. 2002;39(5):111A.
41 Gasparini M, Auricchio A, Regoli F, et al. Four-year efficacy of cardiac resynchronization therapy on exercise tolerance and disease progression: the importance of performing atrioventricular junction ablation in patients with atrial fibrillation. 2006;48(4):734–43.
42 Gasparini M, Lunati M, Bocchiardo M, et al. Cardiac resynchronization and implantable cardioverter defibrillator therapy: preliminary results from the InSync Implantable Cardioverter Defibrillator Italian Registry. Pacing Clin Electrophysiol. 2003;26(1 Pt 2):148-51. [pmid: 12687801].
43 Gasparini M, Mantica M, Galimberti P, et al. Is the left ventricular lateral wall the best lead implantation site for cardiac resynchronization therapy?. Pacing Clin Electrophysiol. 2003;26(1 Pt 2):162-8. [pmid: 12687805].
44 Gasparini M, Mantica M, Galimberti P, et al. Is the outcome of cardiac resynchronization therapy related to the underlying etiology?. Pacing & Clin Electrophysiol. 2003;26(1 Pt 2):175-80.
45 Gold MR, Auricchio A, Hummel JD, et al. Comparison of stimulation sites within left ventricular veins on the acute hemodynamic effects of cardiac resynchronization therapy. Heart Rhythm. 2005;2(4):376-81. [pmid: 15851339].
46 Gorcsan J 3rd, Kanzaki H, Bazaz R, Dohi K, Schwartzman D. Usefulness of echocardiographic tissue synchronization imaging to predict acute response to cardiac resynchronization therapy. Am J Cardiol. 2004;93(9):1178-81. [pmid: 15110219].
47 Gras D, Mabo P, Tang T, et al. Multisite pacing as a supplemental treatment of congestive heart failure: preliminary results of the Medtronic Inc. InSync Study. Pacing Clin Electrophysiol. 1998;21(11 Pt 2):2249-55. [pmid: 9825328].
48 Greenberg JM, Baker CN, Mera FV, et al. Cardiac resynchronization improves ventricular function and symptoms of congestive heart failure in the absence of any mechanical atrial contribution. [abst]. J Am Coll Cardiol. 2002;39(5):77A.
49 Gurevitz O, Nof E, Carasso S, et al. Programmable multiple pacing configurations help to overcome high left ventricular pacing thresholds and avoid phrenic nerve stimulation. Pacing Clin Electrophysiol. 2005;28(12):1255-9. [pmid: 16403156].
50 Hamdan MH, Barbera S, Kowal RC, et al. Effects of resynchronization therapy on sympathetic activity in patients with depressed ejection fraction and intraventricular conduction delay due to ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. 2002;89(9):1047-51. [pmid: 11988193].
51 Hamdan MH, Zagrodzky JD, Joglar JA, et al. Biventricular pacing decreases sympathetic activity compared with right ventricular pacing in patients with depressed ejection fraction. Circulation. 2000;102(9):1027-32. [pmid: 10961968].
52 Hansen C, Sperzel J, Neumann T, Pitschner HF, Neuzner J. Akute hamodynamische Effekte einer biventrikularen und linksventrikularen Stimulation bei Patienten mit fortgeschrittener Herzinsuffizienz unter einer chronischen Herzschrittmachertherapie [Acute hemodynamic effects of biventricular and left ventricular pacing in chronic pacemaker-dependent patients with advanced heart failure]. (Ger). Z Kardiol. 2003;92(10):862-8.
53 Hay I, Melenovsky V, Fetics BJ, et al. Short-term effects of right-left heart sequential cardiac resynchronization in patients with heart failure, chronic atrial fibrillation, and atrioventricular nodal block. Circulation. 2004;110(22):3404-10. [pmid: 15557370].
54 Heist EK, Fan D, Mela T, et al. Radiographic left ventricular-right ventricular interlead distance predicts the acute hemodynamic response to cardiac resynchronization therapy. Am J Cardiol. 2005;96(5):685-90. [pmid: 16125496].
55 Heist EK, Taub C, Fan D, et al. Usefulness of a novel “response score” to predict hemodynamic and clinical outcome from cardiac resynchronization therapy. Am J Cardiol. 2006;97(12):1732-6. [pmid: 16765123].
56 Higgins SL, Yong P, Sheck D, et al. Biventricular pacing diminishes the need for implantable cardioverter defibrillator therapy. Ventak CHF Investigators. J Am Coll Cardiol. 2000;36(3):824-7. [pmid: 10987605].
57 Kanzaki H, Bazaz R, Schwartzman D, Dohi K, Sade LE, Gorcsan J 3rd. A mechanism for immediate reduction in mitral regurgitation after cardiac resynchronization therapy: insights from mechanical activation strain mapping. J Am Coll Cardiol. 2004;44(8):1619-25. [pmid: 15489094].
58 Kanzaki H, Jacques D, Sade LE, Severyn DA, Schwartzman D, Gorcsan J 3rd. Regional correlation by color-coded tissue Doppler to quantify improvements in mechanical left ventricular synchrony after biventricular pacing therapy. Am J Cardiol. 2003;92(6):752-5. [pmid: 12972128].
59 Kerwin WF, Botvinick EH, O'Connell JW, et al. Ventricular contraction abnormalities in dilated cardiomyopathy: effect of biventricular pacing to correct interventicular dyssynchrony. J Am Coll Cardiol. 2000;35(5):1221-7. [pmid: 10758964].
60 Kitamura S, Satomi K, Kurita T, et al. Long-term follow-up of transvenous defibrillation leads-high incidence of fracture in coaxial polyurethane lead. Circ J. 2006;70(3):273-7. [pmid: 16501292].
61 Knaapen P, van Campen LM, de Cock CC, et al. Effects of cardiac resynchronization therapy on myocardial perfusion reserve. Circulation. 2004;110(6):646-51. [pmid: 15302806].
62 Knuuti J, Sundell J, Naum A, et al. Assessment of right ventricular oxidative metabolism by PET in patients with idiopathic dilated cardiomyopathy undergoing cardiac resynchronization therapy. Eur J Nucl Med Mol Imaging. 2004;31(12):1592-8. [pmid: 15290120].
63 Kowal RC, Wasmund SL, Smith ML, et al. Biventricular pacing reduces the induction of monomorphic ventricular tachycardia: a potential mechanism for arrhythmia suppression. Heart Rhythm. 2004;1(3):295-300. [pmid: 15851173].
64 Kurzidim K, Reinke H, Sperzel J, et al. Invasive optimization of cardiac resynchronization therapy: role of sequential biventricular and left ventricular pacing. Pacing Clin Electrophysiol. 2005;28(8):754-61. [pmid: 16105000].
65 Lancellotti P, Melon P, Sakalihasan N, et al. Effect of cardiac resynchronization therapy on functional mitral regurgitation in heart failure. Am J Cardiol. 2004;94(11):1462-5. [pmid: 15566929].
66 Leclercq C, Cazeau S, Ritter P, et al. A pilot experience with permanent biventricular pacing to treat advanced heart failure. Am Heart J. 2000;140(6):862-70. [pmid: 11099989].
67 Leclercq C, Gras D, Tang A, et al. Comparative effects of ventricular resynchronization therapy in heart failure patients with or without coronary artery disease. Ann Cardiol Angeiol. 2004;53(4):171-6.
68 Lehmann A, Lang J, Thaler E, Zeitler C, Weisse U, Boldt J. Considerations in patients undergoing implantation of a biventricular pacemaker. J Cardiothorac Vasc Anesth. 2002;16(2):175-9. [pmid: 11957166].
69 Linde C, Braunschweig F, Gadler F, Bailleul C, Daubert JC. Long-term improvements in quality of life by biventricular pacing in patients with chronic heart failure: results from the MUltisite STimulation In Cardiomyopathy study (MUSTIC). Am J Cardiol. 2003;91(9):1090-5. [pmid: 12714152].
70 Linde C, Leclercq C, Rex S, et al. Long-term benefits of biventricular pacing in congestive heart failure: results from the MUltisite STimulation In Cardiomyopathy (MUSTIC) study. J Am Coll Cardiol. 2002;40(1):111-8. [pmid: 12103264].
71 Lozano I, Bocchiardo M, Achtelik M, et al. Impact of biventricular pacing on mortality in a randomized crossover study of patients with heart failure and ventricular arrhythmias. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1711-2. [pmid: 11139906].
72 Lunati M, Paolucci M, Oliva F, et al. Patient selection for biventricular pacing. J Cardiovasc Electrophysiol. 2002;13(1 Suppl):S63-7. [pmid: 11843470].
73 Macias A, Gavira JJ, Alegria E, Azcarate PM, Barba J, Garcia-Bolao I. Efecto de la localizaci_on del electrodo ventricular izquierdo sobre los parametros ecocardiograficos de asincronia en pacientes sometidos a terapia de resincronizaci_on cardiaca [Effect of the left ventricular pacing site on echocardiographic parameters of ventricular dyssynchrony in patients receiving cardiac resynchronization therapy]. (Spa). Rev Esp Cardiol. 2004;57(2):138-45.
74 Mair H, Jansens JL, Lattouf OM, Reichart B, Dabritz S. Epicardial lead implantation techniques for biventricular pacing via left lateral mini-thoracotomy, video-assisted thoracoscopy, and robotic approach. Heart Surg Forum. 2003;6(5):412-7. [pmid: 14721823].
75 Mansourati J, Etienne Y, Gilard M, et al. Left ventricular-based pacing in patients with chronic heart failure: comparison of acute hemodynamic benefits according to underlying heart disease. Eur J Heart Fail. 2000;2(2):195-9. [pmid: 10856734].
76 Marcus GM, Rose E, Viloria EM, et al. Septal to posterior wall motion delay fails to predict reverse remodeling or clinical improvement in patients undergoing cardiac resynchronization therapy. J Am Coll Cardiol. 2005;46(12):2208-14. [pmid: 16360048].
77 Meluzin J, Novak M, Mullerova J, et al. A fast and simple echocardiographic method of determination of the optimal atrioventricular delay in patients after biventricular stimulation. Pacing Clin Electrophysiol. 2004;27(1):58-64. [pmid: 14720156].
78 Najem B, Preumont N, Unger P, et al. Sympathetic nerve activity after thoracoscopic cardiac resynchronization therapy in congestive heart failure. J Cardiac Fail. 2005;11(7):529-33.
79 Nelson GS, Berger RD, Fetics BJ, et al. Left ventricular or biventricular pacing improves cardiac function at diminished energy cost in patients with dilated cardiomyopathy and left bundle-branch block. Circulation 2000;102(25):3053–9. Erratum in: Circulation 2001;103(3):476
80 Neri G, Zanco P, Bertaglia E, Zerbo F, Zanon F, Buchberger R. Myocardial perfusion and metabolic changes induced by conventional right and biventricular pacing in dilated cardiomyopathy evaluated by positron emission tomography. Ital Heart J. 2002;3(11):637-42. [pmid: 12506521].
81 Neri G, Zanco P, Zanon F, Buchberger R. Effect of biventricular pacing on metabolism and perfusion in patients affected by dilated cardiomyopathy and left bundle branch block: evaluation by positron emission tomography. Europace. 2003;5(1):111-5. [pmid: 12504650].
82 Nowak B, Sinha AM, Schaefer WM, et al. Cardiac resynchronization therapy homogenizes myocardial glucose metabolism and perfusion in dilated cardiomyopathy and left bundle branch block. J Am Coll Cardiol. 2003;41(9):1523-8. [pmid: 12742293].
83 Nowak B, Stellbrink C, Sinha AM, et al. Effects of cardiac resynchronization therapy on myocardial blood flow measured by oxygen-15 water positron emission tomography in idiopathic-dilated cardiomyopathy and left bundle branch block. Am J Cardiol. 2004;93(4):496-9. [pmid: 14969635].
84 Olshansky B, Day J, McGuire M, Hahn S, Brown S, Lerew DR. Reduction of right ventricular pacing in patients with dual-chamber ICDs. Pacing Clin Electrophysiol. 2006;29(3):237-43. [pmid: 16606390].
85 Padeletti L, Musilli N, Porciani MC, et al. Atrial fibrillation and cardiac resynchronization therapy: the MASCOT study. Europace. 2004;5(Suppl 1):S49-54. [pmid: 15450280].
86 Padelitti L, Porciani MC, Colella A, et al. Cardiac resynchronization reverses left ventricular remodeling and reduces cytokine activation in patients with dilated cardiomyopathy and left bundle branch block [abst]. J Am Coll Cardiol. 2002;39(5):78A.
87 Pappone C, Rosanio S, Oreto G, et al. Cardiac pacing in heart failure patients with left bundle branch block: impact of pacing site for optimizing left ventricular resynchronization. Ital Heart J. 2000;1(7):464-9. [pmid: 10933328].
88 Pitzalis MV, Iacoviello M, Romito R, et al. Cardiac resynchronization therapy tailored by echocardiographic evaluation of ventricular asynchrony. J Am Coll Cardiol. 2002;40(9):1615-22. [pmid: 12427414].
89 Popovic ZB, Grimm RA, Perlic G, et al. Noninvasive assessment of cardiac resynchronization therapy for congestive heart failure using myocardial strain and left ventricular peak power as parameters of myocardial synchrony and function. J Cardiovasc Electrophysiol. 2002;13(12):1203-8. [pmid: 12521333].
90 Porciani MC, Puglisi A, Colella A, et al. Echocardiographic evaluation of the effect of biventricular pacing: The InSync Italian Registry. Eur Heart J Suppl. 2000;2(J):J23-J30.
91 Porciani MC, Sabini A, Colella A, et al. Interatrial septum pacing avoids the adverse effect of interatrial delay in biventricular pacing: an echo-Doppler evaluation. Europace. 2002;4(3):317-24. [pmid: 12134979].
92 Proclemer A, Ghidina M, Cicuttini G, Gregori D, Fioretti PM. The Italian Implantable Cardioverter-Defibrillator Registry. A survey of the national activity during the years 2001-2003. Ital Heart J. 2005;6(3):272-80. [pmid: 15875520].
93 Reynolds MR, Joventino LP, Josephson ME. Miracle ICD Investigators. Relationship of baseline electrocardiographic characteristics with the response to cardiac resynchronization therapy for heart failure. Pacing Clin Electrophysiol. 2004;27(11):1513-8. [pmid: 15546306].
94 Ricci R, Ansalone G, Toscano S, et al. Cardiac resynchronization: materials, technique and results. The InSync Italian Registry. Eur Heart J Suppl. 2000;2(J):J6-J15.
95 Riedlbauchova L, Fridl P, Kautzner J, Peichl P. Performance of left ventricular versus biventricular pacing in chronic heart failure assessed by stress echocardiography. Pacing Clin Electrophysiol. 2004;27(5):626-31. [pmid: 15125719].
96 Riedlbauchova L, Kautzner J, Fridl P. Influence of different atrioventricular and interventricular delays on cardiac output during cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2005;28(Suppl 1):S19-23. [pmid: 15683494].
97 Saxon LA, De Marco T, Schafer J, et al. Effects of long-term biventricular stimulation for resynchronization on echocardiographic measures of remodeling. Circulation. 2002;105(11):1304-10. [pmid: 11901040].
98 Scharf C, Li P, Muntwyler J, et al. Rate-dependent AV delay optimization in cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2005;28(4):279-84. [pmid: 15826259].
99 Senatore G, Carreras G, Taglieri C, et al. Role of biventricular pacing in congestive heart failure: randomized study: EUROPACE 2001;2SupplA:A56. Thomsen PEBW.B.Saunders, 2001: 551–4.
100 Skobel EC, Sinha AM, Norra C, et al. Effect of cardiac resynchronization therapy on sleep quality, quality of life, and symptomatic depression in patients with chronic heart failure and Cheyne-Stokes respiration. Sleep Breath. 2005;9(4):159-66. [pmid: 16283229].
101 Sogaard P, Egeblad H, Pedersen AK, et al. Sequential versus simultaneous biventricular resynchronization for severe heart failure: evaluation by tissue Doppler imaging. Circulation. 2002;106(16):2078-84. [pmid: 12379577].
102 Sogaard P, Kim WY, Jensen HK, et al. Impact of acute biventricular pacing on left ventricular performance and volumes in patients with severe heart failure. A tissue Doppler and three-dimensional echocardiographic study. Cardiology. 2001;95(4):173-82. [pmid: 11585992].
103 Sperzel J, Schwarz T, Neumann T, et al. Biventrikulare stimulation: zentrumserf ahrung ahrung mit transvenosen und epimyokardialen linksventrikularen elektrodensystemen [Biventricular stimulation: a center experience with transvenous and epimyocordial left ventricular electrode systems]. (Ger). Herzschrittmacherther Elektrophysiol. 2002;13(suppl 1):73-4.
104 St John Sutton MG, Plappert T, Abraham WT, et al. Effect of cardiac resynchronization therapy on left ventricular size and function in chronic heart failure. Circulation. 2003;107(15):1985-90. [pmid: 12668512].
105 Stellbrink C, Auricchio A, Butter C, et al. Pacing therapies in congestive heart failure II study. Am J Cardiol. 2000;86(9A):138K-43K.
106 Stellbrink C, Auricchio A, Diem B, et al. Potential benefit of biventricular pacing in patients with congestive heart failure and ventricular tachyarrhythmia. Am J Cardiol. 1999;83(5 B):143D-50D. [pmid: 10073811].
107 Strohmer B, Mermi J, Castellanos E, et al. Impact of dual chamber pacing on the incidence of atrial and ventricular tachyarrhythmias in recipients of implantable cardioverter defibrillators. Pacing Clin Electrophysiol. 2005;28(Suppl 1):S249-54. [pmid: 15683508].
108 Sukhija R, Aronow WS, Sorbera C, et al. Left ventricular ejection fraction and prevalence of new left ventricular wall motion abnormality at long-term follow-up in patients with automatic implantable cardioverter-defibrillators treated with dual-chamber rate-responsive pacing at a rate of 70/minute versus backup ventricular pacing at a rate of 40/minute. Am J Cardiol. 2005;96(3):412-3. [pmid: 16054470].
109 Sun JP, Chinchoy E, Donal E, et al. Evaluation of ventricular synchrony using novel Doppler echocardiographic indices in patients with heart failure receiving cardiac resynchronization therapy. J Am Soc Echocardiogr. 2004;17(8):845-50. [pmid: 15282488].
110 Sundell J, Engblom E, Koistinen J, et al. The effects of cardiac resynchronization therapy on left ventricular function, myocardial energetics, and metabolic reserve in patients with dilated cardiomyopathy and heart failure. J Am Coll Cardiol. 2004;43(6):1027-33. [pmid: 15028362].
111 Sutton MG, Plappert T, Hilpisch KE, Abraham WT, Hayes DL, Chinchoy E. Sustained reverse left ventricular structural remodeling with cardiac resynchronization at one year is a function of etiology: quantitative Doppler echocardiographic evidence from the Multicenter InSync Randomized Clinical Evaluation (MIRACLE). Circulation. 2006;113(2):266-72. [pmid: 16401777].
112 Taieb J, Barnay C, Benchaa T, et al. Resynchronisation cardiaque dans l'insuffisance cardiaque: interet de l'echodoppler pour la selection des patients et l'evaluation de la stimulation [Cardiac resynchronisation in congestive heart failure: role of Doppler echocardiography in patient selection]. (Fre). Ann Cardiol Angeiol. 2003;52(6):353-7.
113 Thibault B, Roy D, Guerra PG, et al. Anodal right ventricular capture during left ventricular stimulation in CRT-implantable cardioverter defibrillators. Pacing & Clin Electrophysiol. 2005;28(7):613-9.
114 Toussaint JF, Lavergne T, Ollitraut J, et al. Biventricular pacing in severe heart failure patients reverses electromechanical dyssynchronization from apex to base. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1731-4. [pmid: 11139911].
115 Tse HF, Lee KL, Wan SH, et al. Area of left ventricular regional conduction delay and preserved myocardium predict responses to cardiac resynchronization therapy. J Cardiovasc Electrophysiol. 2005;16(7):690-5. [pmid: 16050824].
116 Tsurugaya H, Tada H, Toyama T, et al. Usefulness of quantitative gated single-photon emission computed tomography to evaluate ventricular synchrony in patients receiving biventricular pacing. Am J Cardiol. 2004;94(1):127-30. [pmid: 15219524].
117 Ukkonen H, Beanlands RS, Burwash IG, et al. Effect of cardiac resynchronization on myocardial efficiency and regional oxidative metabolism. Circulation. 2003;107(1):28-31. [pmid: 12515738].
118 Van Gelder BM, Bracke FA, Meijer A, Lakerveld LJM, Pijls NHJ. Effect of optimizing the VV interval on left ventricular contractility in cardiac resynchronization therapy. Am J Cardiol. 2004;93(12):1500-3. [pmid: 15194020].
119 Varma C, O'Callaghan P, Mahon NG, et al. Effect of multisite pacing on ventricular coordination. Heart. 2002;87(4):322-8. [pmid: 11907001]. [pmcid: 1767081].
120 Varma C, O'Callaghan P, Rowland E, et al. Comparison between biventricular pacing and single site pacing in patients with poor ventricular function: a hemodynamic study. Pacing Clin Electrophysiol. 2003;26(2 Pt 1):551-8. [pmid: 12710313].
121 Varma C, Sharma S, Firoozi S, McKenna WJ, Daubert JC. MUltisite STimulation In Cardiomyopathy (MUSTIC) Study Group. Atriobiventricular pacing improves exercise capacity in patients with heart failure and intraventricular conduction delay. J Am Coll Cardiol. 2003;41(4):582-8. [pmid: 12598069].
122 Vinereanu D, Bleasdale R, Turner M, Frenneaux MP, Fraser AG. Comparison of left ventricular-biventricular pacing on ventricular synchrony, mitral regurgitation, and global left ventricular function in patients with severe chronic heart failure. Am J Cardiol. 2004;94(4):519-21. [pmid: 15325945].
123 Vollmann D, Erdogan A, Himmrich E, et al. Patient Alert™ to detect ICD lead failure: efficacy, limitations, and implications for future algorithms. Europace. 2006;8(5):371-6. [pmid: 16635998].
124 Vural A, Agacdiken A, Ural D, et al. Effect of cardiac resynchronization therapy on left atrial appendage function and pulmonary venous flow pattern. Int J Cardiol. 2005;102(1):103-9. [pmid: 15939105].
125 Waggoner AD, Faddis MN, Gleva MJ, et al. Cardiac resynchronization therapy acutely improves diastolic function. J Am Soc Echocardiog. 2005;18(3):216-20.
126 Walker S, Levy TM, Rex S, et al. Usefulness of suppression of ventricular arrhythmia by biventricular pacing in severe congestive cardiac failure. Am J Cardiol. 2000;86(2):231-3. [pmid: 10913492].
127 Woo GW, Petersen-Stejskal S, Johnson JW, Conti JB, Aranda JA Jr, Curtis AB. Ventricular reverse remodeling and 6-month outcomes in patients receiving cardiac resynchronization therapy: analysis of the MIRACLE study. J Interv Card Electrophysiol. 2005;12(2):107-13. [pmid: 15744462].
128 Yu CM, Fung JW, Zhang Q, et al. Improvement of serum NT-ProBNP predicts improvement in cardiac function and favorable prognosis after cardiac resynchronization therapy for heart failure. 2005;11(5 Suppl):42–6.
129 Yu CM, Fung JW, Zhang Q, et al. Tissue Doppler imaging is superior to strain rate imaging and postsystolic shortening on the prediction of reverse remodeling in both ischemic and nonischemic heart failure after cardiac resynchronization therapy. Circulation. 2004;110(1):66-73. [pmid: 15197148].
130 Yu CM, Lin H, Fung WH, Zhang Q, Kong SL, Sanderson JE. Comparison of acute changes in left ventricular volume, systolic and diastolic functions, and intraventricular synchronicity after biventricular and right ventricular pacing for heart failure. Am Heart J. 2003;145(5):E18.
131 Yu CM, Zhang Q, Fung JW, et al. A novel tool to assess systolic asynchrony and identify responders of cardiac resynchronization therapy by tissue synchronization imaging. J Am Coll Cardiol. 2005;45(5):677-84. [pmid: 15734610].
132 Zanon F, Aggio S, Baracca E, et al. Reduced mitral regurgitation in heart failure patients submitted to cardiac resynchronization therapy: a short-term prospective study. Ital Heart J. 2004;5(11):826-30. [pmid: 15633437].
133 Zardini M, Tritto M, Bargiggia G, et al. The InSync Italian registry: analysis of clinical outcome and considerations on the selection of candidates to left ventricular resynchronization. Eur Heart J Suppl. 2000;2(J):J16-J22.
134 Zhang Q, Yu CM, Fung JW, et al. Assessment of the effect of cardiac resynchronization therapy on intraventricular mechanical synchronicity by regional volumetric changes. Am J Cardiol. 2005;95(1):126-9. [pmid: 15619410].

### Study Design

1 Anonymous. Long term benefits of pacemaker-like device for heart failure patients. Can J Cardiol 2000;16(4):539–9.
2 Ansalone G, Giannantoni P, Ricci R, et al. Doppler myocardial imaging in patients with heart failure receiving biventricular pacing treatment. Am Heart J. 2001;142(5):881-96. [pmid: 11685178].
3 Auricchio A, Klein HU. Beyond expectations: a decade of positive results with cardiac resynchronization therapy on ventricular remodeling. Eur Heart J Supp. 2002;8(2):D95-D101.
4 Auricchio A, Stellbrink C, Block M, Mortensen P. Clinical and objective improvements in severe congestive heart failure patients using univentricular or biventricular pacing: preliminary results of a randomized prospective study. J Am Coll Cardiol. 1998;31(2):31A. [pmid: 9426014].
5 Barbieri A, Bursi F, Bonatti S, et al. Evidence of reverse remodeling after long-term biventricular stimulation for resynchronization in patients with wide QRS selected on the basis of echocardiographic electromechanical delays. Ital Heart J. 2004;5(11):818-25. [pmid: 15633436].
6 Barold SS, Ovsyshcher IE. Pacemaker-induced mitral regurgitation. Pacing Clin Electrophysiol. 2005;28(5):357-60. [pmid: 15869664].
7 Belardinelli R, Capestro F, Misiani A, Scipione P, Georgiou D. Moderate exercise training improves functional capacity, quality of life, and endothelium-dependent vasodilation in chronic heart failure patients with implantable cardioverter defibrillators and cardiac resynchronization therapy. Eur J Cardiovasc Prev Rehabil. 2006;13(5):818-25. [pmid: 17001224].
8 Blanc JJ, Fatemi M. A new cause of pacemaker-mediated tachycardia in patients implanted with a biventricular device. Pacing Clin Electrophysiol. 2001;24(12):1711-2. [pmid: 11817802].
9 Bradley DJ, Bradley EA, Baughman KL, et al. Cardiac resynchronization and death from progressive heart failure: a meta-analysis of randomized controlled trials. JAMA. 2003;289(6):730-40. [pmid: 12585952].
10 Braunschweig F, Gadler F, Linde C, Kjellstrom B, Ryden L. Biventrikular pacing ny behandlingsmetod vid hjartsvikt. Alternativ for patienter med intraventrikulara retledningsrubbningar [Biventricular pacing as a new therapeutic method in heart failure. An alternative for patients with intraventricular conduction disorders]. (Swe). Lakartidningen. 4455;97(40):4450-2.
11 Braunschweig F, Linde C, Gadler F, Ryden L. Reduction of hospital days by biventricular pacing. Eur J Heart Fail. 2000;2(4):399-406. [pmid: 11113717].
12 Breithardt G, Kuhn H, Hammel D, et al. Cardiac resynchronization therapy into the next decade: from the past to morbidity/mortality trials. Eur Heart J Supp. 2002;4(D):D102-D110.
13 Brophy J, Costa V. The use of biventricular pacemakers at the McGill University Health Centre: a technology assessment: A Report by the Technology Assessment Unit (TAU) of the McGill University Health Centre (MUHC) [database on internet]. [cited 2006 Dec7]. Available from: http://www.mcgill.ca/files/tau/biventricular_pacemaker_final_report1.pdf.
14 Bulava A, Lukl J. Postmortem anatomy of the coronary sinus pacing lead. Pacing Clin Electrophysiol. 2005;28(7):736-9. [pmid: 16008815].
15 Castellanos A, Aranda JM. Simultaneous biventricular stimulation for ventricular arrhythmias. Am J Cardiol. 2001;88(10):1217-8.
16 Cazeau S, Gras D, Lazarus A, et al. Multisite stimulation for correction of cardiac asynchrony. Heart. 2000;84(6):579-81. [pmid: 11083728]. [pmcid: 1729514].
17 Cazeau S, Ritter P, Lazarus A, et al. Multisite pacing for end-stage heart failure: early experience. Pacing Clin Electrophysiol. 1996;19(11 Pt 2):1748-57. [pmid: 8945034].
18 Cazeau S, Ritter P, Lazarus A, et al. Premiere experience de traitement de l'insuffisance cardiaque terminale par la stimulation multisite [First experience in treatment of terminal cardiac insufficiency using multisite stimulation]. (Fre). Bull Acad Natl Med. 1996;180(9):2065-75. discussion 2075–8.
19 Cleland JG, Daubert JC, Erdmann E, et al. The CARE-HF study (CArdiac REsynchronisation in Heart Failure study): rationale, design and endpoints. Eur J Heart Fail. 2001;3(4):481-9. [pmid: 11511435].
20 Conaway DG, Sullivan R, McCullough PA. Improved symptoms, physical limitation, and self-efficacy after resynchronization in a patient with heart failure and a prolonged QRS duration. Rev Cardiovasc Med. 2004;5(1):53-7. [pmid: 15029112].
21 Cowburn PJ, Patel H, Jolliffe RE, Wald RW, Parker JD. Cardiac resynchronization therapy: an option for inotrope-supported patients with end-stage heart failure?. Eur J Heart Fail. 2005;7(2):215-7. [pmid: 15701469].
22 Cuzin B, Kirkorian G, Maisonneuve H. Cardiac pacemakers: when clinical evluation lags behind technological process. Int J Technol Assess Health Care. 2000;16(3):910-23. [pmid: 11028147].
23 De Cock CC, Van Campen LM, Jessurun ER, Allaart CA, Vos DS, Visser CA. Long-term follow-up of patients with refractory heart failure and myocardial ischemia treated with cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2005;28(Suppl 1):S8-S10. [pmid: 15683533].
24 De Maria E, Gallo P, Damiano M, et al. Predictive parameters of left ventricular reverse remodeling in response to cardiac resynchronization therapy in patients with severe congestive heart failure. Ital Heart J. 2005;6(9):734-9. [pmid: 16212075].
25 De Sutter J, De Bondt P, Van de Wiele C, et al. Prevalence of potential candidates for biventricular pacing among patients with known coronary artery disease: a prospective registry from a single center. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1718-21. [pmid: 11139908].
26 DeLacey WA, Dow MT. Upgrade of a chronic unipolar pacemaker to a biventricular pacemaker system. Pacing Clin Electrophysiol. 2003;26(12):2324-5. [pmid: 14675022].
27 Di Cori A, Bongiorni MG, Arena G, et al. New-onset ventricular tachycardia after cardiac resynchronization therapy. J Interv Card Electrophysiol. 2005;12(3):231-5. [pmid: 15875116].
28 Dohi K, Suffoletto M, Ganz L, Zenati M, Gorcsan J 3rd. Utility of echocardiographic tissue synchronization imaging to redirect left ventricular lead placement for improved cardiac resynchronization therapy. Pacing Clin Electrophysiol. 2005;28(5):461-5. [pmid: 15869683].
29 Egoavil CA, Ho RT, Greenspon AJ, Pavri BB. Cardiac resynchronization therapy in patients with right bundle branch block: analysis of pooled data from the MIRACLE and Contak CD trials. Heart Rhythm. 2005;2(6):611-5. [pmid: 15922268].
30 Ellery SM, Paul VE. Complications of biventricular pacing. Eur Heart J Suppl. 2004;6(D):D117-D121.
31 Erol MK, Sevimli S, Ates A. Pericardial tamponade caused by transvenous temporary endocardial pacing. Heart. 2005;91(4):459. [pmid: 15772198]. [pmcid: 1768826].
32 Faerestrand S, Schuster P, Ohm OJ. Biventrikulaer pacemakerbehandling av pasienter med alvorlig hjertesvikt [Biventricular pacemaker treatment of patients with severe heart failure]. (Nor). Tidss Nor Laegeforen. 2001;121(8):925-30.
33 Filho MM, Pedrosa AA, Costa R, et al. Biventricular pacing improves clinical behavior and reduces prevalence of ventricular arrhythmia in patients with heart failure. Arq Bras Cardiol. 2002;78(1):110-3. [pmid: 11826352].
34 Franzen D. Langzeitverlauf nach biventrikulärer Herzschrittmachertherapie bei Herzinsuffizienz [Long-term follow up of biventricular pacing in heart failure-a case report]. (Ger). Med Welt. 2004;55(3):45-8.
35 Gabor JY, Newman DA, Barnard-Roberts V, et al. Improvement in Cheyne-Stokes respiration following cardiac resynchronisation therapy. Eur Respir J. 2005;26(1):95-100. [pmid: 15994394].
36 Garcia-Bolao I, Macias A, Alegria E, et al. Tratamiento de la insuficiencia cardiaca avanzada mediante estimulacion biventricular. Experiencia inical en una serie de 22 casos consecutivos [Biventricular pacing as a treatment for advanced heart failure. Preliminary experience in a series of 22 consecutive patients]. (Spa). Rev Esp Cardiol. 2003;56(3):245-52.
37 Garrigue S, Bordachar P, Reuter S, Jais P, Haissaguerre M, Clementy J. Comparison of permanent left ventricular and biventricular pacing in patients with heart failure and chronic atrial fibrillation: a prospective hemodynamic study. [Review] [46 refs]. Cardiac Electrophysiol Rev. 2003;7(4):315-24.
38 Garrigue S, Bordachar P, Reuter S, et al. Comparison of permanent left ventricular and biventricular pacing in patients with heart failure and chronic atrial fibrillation: prospective haemodynamic study. Heart. 2002;87(6):529-34. [pmid: 12010933]. [pmcid: 1767120].
39 Garrigue S, Jais P, Espil G, et al. Comparison of chronic biventricular pacing between epicardial and endocardial left ventricular stimulation using Doppler tissue imaging in patients with heart failure. Am J Cardiol. 2001;88(8):858-62. [pmid: 11676947].
40 Garrigue S, Reuter S, Labeque JN, et al. Usefulness of biventricular pacing in patients with congestive heart failure and right bundle branch block. Am J Cardiol. 2001;88(12):1436-41. [pmid: 11741571].
41 Gasparini M, Galimberti P, Simonini S, et al. Cardiac resynchronization therapy in patients with narrow QRS [5] (multiple letters). J Am Coll Cardiol. 2004;44(10):2096-7. [pmid: 15542305].
42 Gasparini M, Mantica M, Galimberti P, et al. Relief of drug refractory angina by biventricular pacing in heart failure. Pacing Clin Electrophysiol. 2003;26(1 Pt 2):181-4. [pmid: 12687808].
43 Gerber TC, Nishimura RA, Holmes DR Jr, et al. Left ventricular and biventricular pacing in congestive heart failure. Mayo Clin Proc. 2001;76(8):803-12. [pmid: 11499820].
44 Ghosh J, Freemantle N, Cleland J, Salukhe TV, Francis DP. Meta-analysis does not show that cardiac resynchronisation reduces all-cause mortality [3] (multiple letters). Int J Cardiol. 2005;103(2):230-3. [pmid: 16080992].
45 Gras D, Ruffy R, Cebron JP, Brunel P, Leurent B, Banus Y. Treatment of refractory congestive heart failure by cardiac resynchronization. Minerva Cardioangiol. 2003;51(2):185-95. [pmid: 12783074].
46 Grassi G, Vincenti A, Brambilla R, et al. Sustained sympathoinhibitory effects of cardiac resynchronization therapy in severe heart failure. Hypertension. 2004;44(5):727-31. [pmid: 15381677].
47 Greenberg JM, Mera F, Smith AL, DeLurgio DB, Langberg JJ, Leon AR. Biventricular pacing in CHF and chronic atrial fibrillation. Cardiol Rev. 2003;20(7):30-4.
48 Guerra JM, Wu J, Miller JM, Groh WJ. Increase in ventricular tachycardia frequency after biventricular implantable cardioverter defibrillator upgrade. J Cardiovasc Electrophysiol. 2003;14(11):1245-7. [pmid: 14678142].
49 Gururaj AV. Cardiac resynchronization therapy: effects on exercise capacity in the patient with chronic heart failure. J Cardiopulm Rehabil. 2004;24(1):1-7. [pmid: 14758096].
50 Heinzel F, Sack S, Wolfhardt U, Dagres N, Herold U, Erbel R. Erfahrungen mit einer neuen transvenosen Sonde zur linksventrikularen Stimulation[Experiences with a new transvenous electrode for left ventricular stimulation]. (Ger). Herz. 2001;26(1):79-83.
51 Hoijer CJ, Meurling C, Brandt J. Upgrade to biventricular pacing in patients with conventional pacemakers and heart failure: a double-blind, randomized crossover study. Europace. 2006;8(1):51-5. [pmid: 16627409].
52 Hoppe UC, Erdmann E. Cardiac resynchronization in heart failure. Dtsch Med Wochenschr. 2002;127(13):667-81. [pmid: 11928058].
53 Horwich T, Foster E, De Marco T, Tseng Z, Saxon L. Effects of resynchronization therapy on cardiac function in pacemaker patients “upgraded” to biventricular devices. J Cardiovasc Electrophysiol. 2004;15(11):1284-9. [pmid: 15574179].
54 Hummel JP, Lindner JR, Belcik JT, et al. Extent of myocardial viability predicts response to biventricular pacing in ischemic cardiomyopathy. Heart Rhythm. 2005;2(11):1211-7. [pmid: 16253911].
55 Inoue N, Ishikawa T, Sumita S, et al. Long-term follow-up of atrioventricular delay optimization in patients with biventricular pacing. Circ J. 2005;69(2):201-4. [pmid: 15671613].
56 Issa ZF, Jaradat Z, Bhakta D, Miller JM. Appropriate or inappropriate ICD therapy?. Heart Rhythm. 2005;2(10):1150-2. [pmid: 16188600].
57 Jais P, Douard H, Shah DC, Barold S, Barat JL, Clementy J. Endocardial biventricular pacing. Pacing Clin Electrophysiol. 1998;21(11 Pt 1):2128-31. [pmid: 9826866].
58 Jansens JL, Jottrand M, Preumont N, Stoupel E, de Canniere D. Robotic-enhanced biventricular resynchronization: an alternative to endovenous cardiac resynchronization therapy in chronic heart failure. Ann Thorac Surg. 2003;76(2):413-7. discussion 417. [pmid: 12902075].
59 Jarcho JA. Resynchronizing ventricular contraction in heart failure. N Engl J Med. 2005;352(15):1594-7. [pmid: 15829542].
60 Kanhai SM, Viergever EP, Bax JJ. Cardiogenic shock shortly after initial success of cardiac resynchronization therapy. Eur J Heart Fail. 2004;6(4):477-81. [pmid: 15182774].
61 Kies P, Bax JJ, Molhoek SG, et al. Effect of left ventricular remodeling after cardiac resynchronization therapy on frequency of ventricular arrhythmias. Am J Cardiol. 2004;94(1):130-2. [pmid: 15219525].
62 Kies P, Bax JJ, Molhoek SG, et al. Effect of cardiac resynchronization therapy on inducibility of ventricular tachyarrhythmias in cardiac arrest survivors with either ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. 2005;95(9):1111-4. [pmid: 15842986].
63 Kikuchi F, Miura T, Yamamoto T, Misawa A. [Usefulness and short-term results of biventricular pacing using modified monorail lead system improved on usual endocardilal pacing lead in patients with chronic heart failure]. (Jap). Ther Res. 2003;24(8):1528-31.
64 Kloss M, Auricchio A, Trautmann S, Klein H. Cardiac resynchronization therapy improves chronotropic response in patients with heart failure [abst]. Eur Heart J. 2001;22:443.
65 Kusaba T, Tanda S, Kameyama H, et al. Efficacy of biventricular pacing for dialysis-related hypotension due to idiopathic dilated cardiomyopathy. Clin Exp Nephrol. 2005;9(3):255-9. [pmid: 16189637].
66 Lafitte S, Garrigue S, Perron JM, et al. Improvement of left ventricular wall synchronization with multisite ventricular pacing in heart failure: a prospective study using Doppler tissue imaging. Eur J Heart Fail. 2004;6(2):203-12. [pmid: 14984728].
67 Lau CP, Yu CM, Chau E, et al. Reversal of left ventricular remodeling by synchronous biventricular pacing in heart failure. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1722-5. [pmid: 11139909].
68 Lawo T, Pfeiffer U, Deneke T, Calcum B, Lemke B. Einfluss der linkscentrikularen stimulation auf die QRS-breite bei linksschenkeiblock im rahmen der resynchronisationsherapie [Influence of left ventricular stimulation on the QRS width in left bundle branch block in the framework of resynchronization therapy]. (Ger). Herzschrittmacherther Elektrophysiol. 2002;13(suppl 1):69-70.
69 Le Rest C, Couturier O, Turzo A, et al. Use of left ventricular pacing in heart failure: evaluation by gated blood pool imaging. J Nucl Cardiol. 1999;6(6):651-6. [pmid: 10608593].
70 Leclercq C, Cazeau S, Ritter P, Daubert C. Stimulation cardiaque et insuffisance cardiaque [Pacing and cardiac failure]. (Fre). Arch Mal Coeur Vaiss. 1998;91(11):1389-97.
71 Lehmann MH, Aaronson KD. CRT-D therapy in heart failure: How much do NYHA class IV patients benefit?. J Cardiovasc Electrophysiol. 2006;17(5):491-4. [pmid: 16684020].
72 Leon AR, Abraham WT, Curtis AB, et al. Safety of transvenous cardiac resynchronization system implantation in patients with chronic heart failure: combined results of over 2,000 patients from a multicenter study program. J Am Coll Cardiol. 2005;46(12):2348-56. [pmid: 16360070].
73 Leon AR, Greenberg JM, Kanuru N, et al. Cardiac resynchronization in patients with congestive heart failure and chronic atrial fibrillation: effect of upgrading to biventricular pacing after chronic right ventricular pacing. J Am Coll Cardiol. 2002;39(8):1258-63. [pmid: 11955841].
74 Lewicka-Nowak E, Dabrowska-Kugacka A, Faran A, et al. Stymulcaja dwukomorowa u pacjentow z zaawansonwana niewydolnoscia serca-doswiadczenie wiasne [Biventricular pacing in patients with advanced heart failure-single center experience]. (Pol). Folia Cardiol. 2003;10(1):91-103.
75 Linde C, Gold M, Abraham WT, Daubert JC, REVERSE Study. Rationale and design of a randomized controlled trial to assess the safety and efficacy of cardiac resynchronization therapy in patients with asymptomatic left ventricular dysfunction with previous symptoms or mild heart failure—the REsynchronization reVErses Remodeling in Systolic left vEntricular dysfunction (REVERSE) study. 2006;151(2):288–94.
76 Livanis EG, Flevari P, Theodorakis GN, Kolokathis F, Leftheriotis D, Kremastinos DT. Effect of biventricular pacing on heart rate variability in patients with chronic heart failure. Eur J Heart Fail. 2003;5(2):175-8. [pmid: 12644009].
77 Lux RL, Hamdan MH. Cardiac resynchronization therapy and the arrhythmogenic substrate. J Cardiovasc Electrophysiol. 2005;16(6):618-9. [pmid: 15946360].
78 Mahaux V, Demoulin JC, Pierard L, Soyeur D. Biventricular stimulation in congestive heart failure: initial clinical experience: cardiac pacing: Europace '95: 7th European Symposium on Cardiac Pacing. 1995: 533–6.
79 Mahaux V, Legrand V, Waleffe A, Soyeur D. Acute hemodynamics of biventricular stimulation in congestive heart failure: cardiac pacing: Europace '95: 7th European Symposium on Cardiac Pacing. 1995: 359–62.
80 Makaryus AN, Arduini AD, Mallin J, et al. Echocardiographic features of patients with heart failure who may benefit from biventricular pacing. Echocardiography. 2003;20(3):217-23. [pmid: 12848658].
81 Martinelli Filho M, Pedrosa AA, Costa R, et al. Biventricular pacing improves clinical behavior and reduces prevalence of ventricular arrhythmia in patients with heart failure. Arq Bras Cardiol. 2002;78(1):110-3. [pmid: 11826352].
82 McAlister FA, Ezekowitz JA, Wiebe N, et al. Systematic review: cardiac resynchronization in patients with symptomatic heart failure. [Review][52 refs]. Ann Intern Med 2004;141(5): 381–90. Erratum in: Ann Intern Med. 2005;142(4):311.
83 Memon RA, Buckley J, O'Donnell A. Percutaneous extraction of entrapped infective transvenous pacing lead. Asian Cardiovasc Thorac Ann. 2002;10(1):69-71. [pmid: 12079978].
84 Merkely B, Vago H, Bartha E, Zima E, Moravcsik E, Geller L. Sulyos szivelegtelenseg kezelese biventricularis ingerlessel [Biventicular pacing in patients with severe heart failure]. (Hun). Orv Hetil. 2001;142(51):2835-40.
85 Moshenyat R, Kupfer YY, Tessler S. Efficacy of biventricular pacing in congestive heart failure. J Am Coll Cardiol. 2003;41(4):709. author reply 709–10.
86 Neri G, Zanco P, Buchberger R. Myocardial perfusion and metabolic changes induced by biventricular pacing in dilated cardiomyopathy and left bundle branch block: description of a case evaluated by positron emission tomography. Ital Heart J. 2001;2(6):472-4. [pmid: 11453586].
87 Nielsen JC, Bottcher M, Jensen HK, Nielsen TT, Pedersen AK, Mortensen PT. Regional myocardial perfusion during chronic biventricular pacing and after acute change of the pacing mode in patients with congestive heart failure and bundle branch block treated with an atrioventricular sequential biventricular pacemaker. Eur J Heart Fail. 2003;5(2):179-86. [pmid: 12644010].
88 Nishimura M, Ogiwara M, Ishikawa M, et al. Successful bridge to resynchronization therapy with a left ventricular assist system in a patient with idiopathic dilated cardiomyopathy. J Artif Organs. 2005;8(3):210-3. [pmid: 16235039].
89 Oginosawa Y, Abe H, Nakashima Y. Right pneumothorax resulting from an endocardial screw-in atrial lead in an implantable cardioverter defibrillator system. Pacing Clin Electrophysiol. 2002;25(8):1278-9. [pmid: 12358182].
90 Oguz E, Dagdeviren B, Bilsel T, et al. Echocardiographic prediction of long-term response to biventricular pacemaker in severe heart failure. Eur J Heart Fail. 2002;4(1):83-90. [pmid: 11812668].
91 Okusu Y, Ishikawa T, Takahashi N, et al. [Efficacy of biventricular pacing on myocardial glucose metabolism in a patient with heart failure using 2-deoxy-2[18F]fluoro-d-glucose positron emission tomography: a case report]. (Jap). J Cardiol. 2002;39(3):165-70.
92 Pacemaker resynchronization of ventricular rhythm in chronic heart failure-early assessment briefs (Alert). [database on internet]. Stockholm: Swedish Council on Technology Assessment in Health Care. [cited 2006 Dec 7]. Available from: http:, www.sbu.se/www/index.asp.
93 Pastore CA, Tobias NM, Kaiser E, et al. Electrocardiographic, vectorcardiographic and body surface potential mapping analyses of patients with congestive heart failure and left bundle branch block, treated with biventricular pacing: electrocardiology; electrocardiology and neurophysiology. Int Soc Bioelectromagnetism. 2002;4(2):317-18.
94 Pelicano N, Oliveira M, Da Silva N, et al. Long-term clinical outcome in patients with severe left ventricular dysfunction and an implantable cardioverter-defibrillator after ventricular tachyarrhythmias. Rev Port Cardiol. 2005;24(4):487-98. [pmid: 15977773].
95 Peters RW, Gold MR. Pacing for patients with congestive heart failure and dilated cardiomyopathy. Cardiol Clin. 2000;18(1):55-66. [pmid: 10709685].
96 Petutschnigg B, Fruhwald F, Prenner G, Marte W, Tscheliessnigg KH. Multisite-stimulation als bridging fur transplantationspatienten [Multisite cardiac stimulation as bridging for transplantation patients]. (Ger). Z Kardiol. 1999;6(4):199-202.
97 Philippon F. Cardiac resynchronization therapy: device-based medicine for heart failure. [Review] [56 refs]. J Cardiac Surg. 2004;19(3):270-4.
98 Poullis M, Shackcloth M, D'Ancona G. Coronary grafts flow and cardiac pacing modalities: the importance of the cardiac resynchronisation trials [4] (multiple letters). Eur J CardioThorac Surg. 2005;27(1):177-8. [pmid: 15621502].
99 Richardson K, Cook K, Wang PJ, Al-Ahmad A. Loss of biventricular pacing: what is the cause?. Heart Rhythm. 2005;2(1):110-1. [pmid: 15851277].
100 Ritter P, Lazarus A, Jauvert G, Alonso C, Cazeau S. Endovenous implantation of the left ventricular lead for cardiac resynchronization therapy in congestive heart failure: new developments in cardiac pacing and electrophysiology. Ovsyschcher IE Futura Publishing Co, 2002: 229–38.
101 Rust H, Achtelik M, Horstmann E, Trappe HJ. Globale und regionale kontraktilitat bei patienten mit schwerer chronischer linksherzinsuffizienz unter biventrikularer schrittmachertherapie: eine echokardiographische studie. [Global and regional contractility in patients with severe chronic left heart failure during biventricular pacing: an echocardiographic study]. (Ger). Herzschrittmacherther Elektrophysiol. 2001;12(suppl):77-8.
102 Rust H, Meine M, Achtelik M, Trappe HJ. Echokardiographische av-zeit-optimierung bei patienten mit biventrikularer schmittmachertherapie [Echocardiographic atrioventricular time optimization in patients with biventricular pacing]. (Ger). Herzschrittmacherther Elektrophysiol. 2001;12(suppl):73-4.
103 Sack S, Heinzel F, Dagres N, et al. Stimulation of the left ventricle through the coronary sinus with a newly developed ‘over the wire’ lead system-early experiences with lead handling and positioning. Europace. 2001;3(4):317-23. [pmid: 11678391].
104 Salukhe TV, Dimopoulos K, Francis D. Cardiac resynchronisation may reduce all-cause mortality: meta-analysis of preliminary COMPANION data with CONTAK-CD, InSync ICD, MIRACLE and MUSTIC. Int J Cardiol. 2004;93(23):101-3. [pmid: 14975534].
105 Sassara M, Achilli A, Bianchi S, et al. Long-term effectiveness of dual site left ventricular cardiac resynchronization therapy in a patient with congestive heart failure. Pacing Clin Electrophysiol. 2004;27(6 Pt 1):805-7. [pmid: 15189538].
106 Satish OS, Yeh KH, Wen MS, Wang CC. Cardiac resynchronisation therapy versus dual site right ventricular pacing in a patient with permanent pacemaker and congestive heart failure. Europace. 2005;7(4):380-4. [pmid: 15944097].
107 Saxon LA, Boehmer JP, Hummel J, et al. Biventricular pacing in patients with congestive heart failure: two prospective randomized trials. The VIGOR CHF and VENTAK CHF Investigators. [Review] [20 refs]. Am J Cardiol. 1999;83(5B):120D-3D. [pmid: 10073799].
108 Sbragia P, Nait-Saidi L, Alexandre Trigano J, Saadjian A, Barnay P, Levy S. Intra-atrial thrombosis and pulmonary embolism complicating pacemaker leads for cardiac resynchronization therapy. J Interv Card Electrophysiol. 2003;9(1):25-7. [pmid: 12975567].
109 Scharf C, Attenhofer Jost CH. Concepts and questions in programming cardiac resynchronization devices. Heart Rhythm. 2005;2(10):1073-5. [pmid: 16188584].
110 Schuster P, Faerestrand S, Ohm OJ. Reverse remodelling of systolic left ventricular contraction pattern by long term cardiac resynchronisation therapy: Colour Doppler shows resynchronisation. Heart. 2004;90(12):1411-6. [pmid: 15547015]. [pmcid: 1768584].
111 Sciagra R, Giaccardi M, Porciani MC, et al. Myocardial perfusion imaging using gated SPECT in heart failure patients undergoing cardiac resynchronization therapy. J Nucl Med. 2004;45(2):164-8. [pmid: 14960631].
112 Seidl K, Rameken M, Vater M, Senges J. Cardiac resynchronization therapy in patients with chronic heart failure: pathophysiology and current experience. [Review] [53 refs]. Am J Cardiovasc Drugs. 2002;2(4):219-26. [pmid: 14727967].
113 Sharma A, Epstein AE, Herre JM, et al. A comparison of the AVID and DAVID trials of implantable defibrillators. Am J Cardiol. 2005;95(12):1431-5. [pmid: 15950565].
114 Shi HY, Pan CZ, Shu XH, et al. [Immediate effect of cardiac resynchronization therapy by tissue synchronization imaging and tissue tracking in patients with congestive heart failure]. [Chinese]. Chung-Hua Hsin Hsueh Kuan Ping Tsa Chih [Chin J Cardiol]. 2005;33(1):26-9.
115 Shukla G, Chaudhry GM, Orlov M, Hoffmeister P, Haffajee C. Potential proarrhythmic effect of biventricular pacing: fact or myth?. Heart Rhythm. 2005;2(9):951-6. [pmid: 16171749].
116 Singh JP, Ruskin JN. Cardiac resynchronization therapy: the MGH experience. Ann Noninvasive Electrocardiol. 2005;10(4 Suppl):44-54. [pmid: 16274415].
117 Sinha AM, Filzmaier K, Breithardt OA, et al. Usefulness of brain natriuretic peptide release as a surrogate marker of the efficacy of long-term cardiac resynchronization therapy in patients with heart failure. Am J Cardiol. 2003;91(6):755-8. [pmid: 12633819].
118 Sinha AM, Skobel EC, Breithardt OA, et al. Cardiac resynchronization therapy improves central sleep apnea and Cheyne-Stokes respiration in patients with chronic heart failure. J Am Coll Cardiol. 2004;44(1):68-71. [pmid: 15234409].
119 Stellbrink C, Breithardt OA, Hanrath P. Technical considerations in implanting left ventricular pacing leads for cardiac resynchronisation therapy. Eur Heart J Suppl. 2004;6(D):D43-D46.
120 Stellbrink C, Sinha AM, Diem B, et al. Implantable cardioveter-defibrillators with or without cardiac resynchronization therapy-multiple therapy in a single device: a review with special reference to the PACMAN study. Eur Heart J Suppl. 2002;4(D):D88-D94.
121 Sterlinski M, Lewicka-Nowak E, Przybylski A, et al. Zastosowanie kardiowerterow-defibrylatorow z funkcja resynchronizujacej stymulacji dwukomoroej u chorych z ciezka niewydolnoscia serca i ziosliwymi komorowymi zamurzeniami rytmu [Implantable cardioverter-defibrillator with biventricular resynchronization therapy in patients with severe congestive heart failure and malignant ventricular arrhythmias]. (Pol). Folia Cardiol. 2003;10(5):603-10.
122 Tada H, Toide H, Naito S, et al. Tissue Doppler imaging and strain Doppler imaging as modalities for predicting clinical improvement in patients receiving biventricular pacing. Circ J. 2005;69(2):194-200. [pmid: 15671612].
123 Takemoto M, Sakamoto M, Kawagoe J, et al. Effect of biventricular pacing therapy in patients with dilated cardiomyopathy with severe congestive heart failure. Jpn J Thorac Cardiovasc Surg. 2004;52(4):175-80. [pmid: 15141704].
124 Tanabe M, Onishi K, Kitamura T, et al. Effective cardiac resynchronization after Dor procedure and mitral annuloplasty. Can J Cardiol. 2004;20(4):449-51. [pmid: 15057322].
125 Tanaka H, Okishige K, Mizuno T, et al. Temporary and permanent biventricular pacing via left ventricular epicardial leads implanted during primary cardiac surgery. Jpn J Thorac Cardiovasc Surg. 2002;50(7):284-9. [pmid: 12166267].
126 Tavazzi L. Electrical stimulation of the failing heart: a new therapeutical strategy?. Eur Heart J Suppl. 2000;2(J):J2-J5.
127 Tavazzi L. Ventricular pacing: a promising new therapeutic strategy in heart failure. For whom?. Eur Heart J. 2000;21(15):1211-4. [pmid: 10924309].
128 Thaman R, Murphy RT, Firoozi S, et al. Restrictive transmitral filling patterns predict improvements in left ventricular function after biventricular pacing. Heart. 2005;91(7):920-5. [pmid: 15958362]. [pmcid: 1768999].
129 Toff WD, Skehan JD, De Bono DP, Camm AJ. The United Kingdom Pacing And Cardiovascular Events (UKPACE) trial. Heart. 1997;78(3):221-3. [pmid: 9391280]. [pmcid: 484920].
130 Touiza A, Etienne Y, Gilard M, Fatemi M, Mansourati J, Blanc JJ. Long-term left ventricular pacing: assessment and comparison with biventricular pacing in patients with severe congestive heart failure. J Am Coll Cardiol. 2001;38(7):1966-70. [pmid: 11738301].
131 Valls-Bertault V, Fatemi M, Gilard M, Pennec PY, Etienne Y, Blanc JJ. Assessment of upgrading to biventricular pacing in patients with right ventricular pacing and congestive heart failure after atrioventricular junctional ablation for chronic atrial fibrillation. Europace. 2004;6(5):438-43. [pmid: 15294269].
132 Van Gelder BM, Bracke FA, Pilmeyer A, Meijer A. Triple-site ventricular pacing in a biventricular pacing system. Pacing Clin Electrophysiol. 2001;24(7):1165-7. [pmid: 11475836].
133 Vanderheyden M, De Backer T, Rivero-Ayerza M, et al. Tailored echocardiographic interventricular delay programming further optimizes left ventricular performance after cardiac resynchronization therapy. Heart Rhythm. 2005;2(10):1066-72. [pmid: 16188583].
134 Vanderheyden M, Wellens F, Bartunek J, et al. Cardiac resynchronization therapy delays heart transplantation in patients with end-stage heart failure and mechanical dyssynchrony. J Heart Lung Transplant. 2006;25(4):447-53. [pmid: 16563976].
135 Walker S, Levy TM, Coats AJS, et al. Bi-ventricular pacing in congestive cardiac dailure: current experience and future directions. Eur Heart J. 2000;21(11):884-9. [pmid: 10806011].
136 Wang L. Cardiac resynchronization therapy in congestive heart failure: the state of the art and future perspectives. Exp Clin Cardiol. 2003;7(4):212-5.
137 Wilkoff BL. Dual Chamber VVI Implantable Defibrillator trial investigators. The Dual Chamber and VVI Implantable Defibrillator (DAVID) Trial: rationale, design, results, clinical implications and lessons for future trials. Cardiac Electrophysiol Rev. 2003;7(4):468-72.
138 Yu CM, Abraham WT, Bax J, et al. Predictors of response to cardiac resynchronization therapy (PROSPECT)-study design. Am Heart J. 2005;149(4):600-5. [pmid: 15990740].
139 Yu CM, Lau CP, Tang AS. Case report: resolution of pulsus alternans by synchronous atrio-biventricular pacing. J Interv Card Electrophysiol. 2000;4(4):595-7. [pmid: 11141205].

### Not Obtained

1 Abdul-Khaliq H, Rentzsch A, Schuck R, et al. Midterm effects of resynchronization therapy on left ventricular performance: a prospective study in 28 patients with congenital heart disease and dilatative cardiomyopathy. Cambridge University Press, 2006: O6.
2 Eksik A, Akyol A, Norgaz T, et al. Takilabilir kardiyoverter defibrilator ile tedavi edilen malign ventrikul tasiaritmili hastalarm uzun donem sonculari [Long-term results of cardioverter defibrillator implantation in patients with malignant ventricular tachyarrhythmias]. (Tur). Turk Kardiyoloji Dernegi Arsivi. 2005;33(7):398-403.
3 Hansky B, Vogt J, Guldner H, et al. Komplikationen linksventrikularer kornonarvene (CV)-elektroden [Complications of left ventricular coronary arteries-electrodes]. (Ger). Herzschrittmacherther Elektrophysiol. 2001;12(suppl):69-70.
4 Huth C, Friedl A, Klein H, Auricchio A. Schrittmachertherapie der Herzinsuffizienz unter Berucksichtigung der Ergebnisse der PATH-CHF-Studie [Pacing therapies for congestive heart failure considering the results of the PATH-CHF study]. (Ger). Z Kardiol. 2001;90(Suppl 1):10-5.
5 Kazmierczak J, Zielonka J, Rzeuski R, et al. Hospital readmission in patients with implantable cardioverter- defibrillators. Kardiol Pol. 2006;64(7):684-91. [pmid: 16886125].
6 Malinowski K, Bondke HJ, Witte J, et al. Biventrikulare stimulation mit einer helikal geformten koronarsinus-elektrode: erste ergebnisse einer anwendungsbeobachtung [Biventricular stimulation with a coronary sinus electrode: first results of an observational study]. (Ger) Herzschrittmacherther Elektrophysiol. 2003;14(suppl 1):53-4.
7 Poschmann U, Steiner S, Knake W, Oster H, Vallbracht C. Vergleich der transvenosen und epikardialen implantation von LV-elektroden zur kardialen resynchronisationstherapie [Comparison of transvenous and epicardial implantation of LV electrodes for cardiac resynchronization therapy]. (Ger). Herzschrittmacherther Elektrophysiol. 2002;12(suppl 1):71-2.
8 Salerno-Uriarte JA, Tritto M. Effetti della stimolazione biventricolare nei pazienti con insufficienza cardiaca e ritardo di conduzione intraventricolare [Effects of multisite biventricular pacing in patients with heart failure and intraventricular conduction delay]. (Ita). Ital Heart J Supp. 2001;2(8):912-4.
9 Spitzer SG, Wacker P, Malinowski K, Schibgilla V, Gazarek S. Multisite pacing im rechten vorhof - unterscheiden sich intraoperative messwerte, opzeiten und peri-/post-operative komplikationen im vergleich zur standardtherapie? [Does multisite pacing into the right atrium differ in intraoperatively measured values, surgery times and peri- and postoperative complications compared to standard therapy?]. (Ger). Herzschrittmacherther Elektrophysiol. 2003;13(suppl 1):55-6.
10 Wang DM, Han YL, Zang HY, et al. [Long-term effects and mortality of biventricular pacing therapy in patients with congestive heart failure]. (Chi). Chung-Hua Hsin Hsueh Kuan Ping Tsa Chih [Chin J Cardiol]. 2005;33(8):717-9.

## Excluded Studies: ICD Alone

The four main reasons for exclusion were based on the publication not having the right study design, population,intervention or outcomes.

### Population

1 Aronow WS, Sorbera C, Chagarlamudi A, Tabandeh H, Gupta S, Cohen M. Indications for and long-term survival in patients with automatic implantable cardioverter-defibrillators. Cardiol Rev. 2005;13(1):50-1. [pmid: 15596030].
2 Ashwath ML, Sogade FO. Ejection fraction and QRS width as predictors of event rates in patients with implantable cardioverter defibrillators. South Med J. 2005;98(5):513-7. [pmid: 15954506].
3 Cabell CH, Heidenreich PA, Chu VH, et al. Increasing rates of cardiac device infections among Medicare beneficiaries: 1990-1999. Am Heart J. 2004;147(4):582-6. [pmid: 15077071].
4 Cappato R, Boczor S, Kuck KH. CASH Investigators. Response to programmed ventricular stimulation and clinical outcome in cardiac arrest survivors receiving randomised assignment to implantable cardioverter defibrillator or antiarrhythmic drug therapy. Eur Heart J. 2004;25(8):642-9. [pmid: 15084368].
5 Carroll DL, Hamilton GA. Quality of life in implanted cardioverter defibrillator recipients: the impact of a device shock. Heart Lung. 2005;34(3):169-78. [pmid: 16015221].
6 Chow BJW, Hassan AH, Chan KL, Tang ASL. Prevalence and significance of lead-related thrombi in patients with implantable cardioverter defibrillators. Am J Cardiol. 2003;91(1):88-90. [pmid: 12505581].
7 Crevenna R, Stix G, Pleiner J, et al. Electromagnetic interference by transcutaneous neuromuscular electrical stimulation in patients with bipolar sensing implantable cardioverter defibrillators: a pilot safety study. Pacing Clin Electrophysiol. 2003;26(2 I):626-9. [pmid: 12710324].
8 del Rio A, Anguera I, Miro JM, et al. Surgical treatment of pacemaker and defibrillator lead endocarditis: the impact of electrode lead extraction on outcome. Chest. 2003;124(4):1451-9. [pmid: 14555579].
9 Deneke T, Lawo T, Gerritse B, Lemke B. The European GEM DR Trade Mark Investigators. Mortality of patients with implanted cardioverter/defibrillators in relation to episodes of atrial fibrillation. Europace. 2004;6(2):151-8. [pmid: 15018875].
10 Dogra V, Oliver R, Lapidus J, et al. Apparent protective effect of increased left ventricular wall thickness in an ICD population. J Card Fail. 2003;9(5):412-5. [pmid: 14583904].
11 Fitchet A, Doherty PJ, Bundy C, Bell W, Fitzpatrick AP, Garratt CJ. Comprehensive cardiac rehabilitation programme for implantable cardioverter-defibrillator patients: a randomised controlled trial. Heart. 2003;89(2):155-60. [pmid: 12527665]. [pmcid: 1767543].
12 Garcia-Moran E, Mont L, Cuesta A, Matas M, Brugada J. Low recurrence of syncope in patients with inducible sustained ventricular tachyarrhythmias treated with an implantable cardioverter-defibrillator. Eur Heart J. 2002;23(11):901-7. [pmid: 12042012].
13 Godemann F, Butter C, Lampe F, et al. Panic disorders and agoraphobia: side effects of treatment with an implantable cardioverter/defibrillator. Clin Cardiol. 2004;27(6):321-6. [pmid: 15237689].
14 Godemann F, Butter C, Lampe F, Linden M, Werner S, Behrens S. Determinants of the quality of life (QoL) in patients with an implantable cardioverter/defibrillator (ICD). Qual Life Res. 2004;13(2):411-6. [pmid: 15085913].
15 Gold MR, Sulke N, Schwartzman DS, Mehra R, Euler DE. Worldwide Jewel AFOnly I. Clinical experience with a dual-chamber implantable cardioverter defibrillator to treat atrial tachyarrhythmias. J Cardiovasc Electrophysiol. 2001;12(11):1247-53. [pmid: 11761411].
16 Gradaus R, Gonska BD, Stellbrink C, et al. European clinical experience with a dual chamber single pass sensing and pacing defibrillation lead. Pacing Clin Electrophysiol. 2002;25(7):1079-86. [pmid: 12164450].
17 Gronefeld GC, Israel CW, Padmanabhan V, et al. Ventricular rate stabilization for the prevention of pause dependent ventricular tachyarrhythmias: results from a prospective study in 309 ICD recipients. Pacing Clin Electrophysiol. 2002;25(12):1708-14. [pmid: 12520671].
18 Gunderson BD, Patel AS, Bounds CA, Shepard RK, Wood MA, Ellenbogen KA. An algorithm to predict implantable cardioverter-defibrillator lead failure. J Am Coll Cardiol. 2004;44(9):1898-902. [pmid: 15519026].
19 Hauser RG, Kallinen L. Deaths associated with implantable cardioverter defibrillator failure and deactivation reported in the United States Food and Drug Administration Manufacturer and User Facility Device Experience Database. Heart Rhythm. 2004;1(4):399-405. [pmid: 15851191].
20 Hennersdorf MG, Niebch V, Vester EG, Winter J, Perings C, Strauer BE. Long-term follow-up of sudden cardiac arrest survivors and electrophysiologically guided antiarrhythmic therapy. Cardiology. 2003;99(4):190-7. [pmid: 12845245].
21 Herzog CA, Li S, Weinhandl ED, Strief JW, Collins AJ, Gilbertson DT. Survival of dialysis patients after cardiac arrest and the impact of implantable cardioverter defibrillators. Kidney Int. 2005;68(2):818-25. [pmid: 16014061].
22 Kamke W, Dovifat C, Schranz M, Behrens S, Moesenthin J, Voller H. Cardiac rehabilitation in patients with implantable defibrillators. Feasibility and complications. Z Kardiol. 2003;92(10):869-75. [pmid: 14579052].
23 Kamphuis HC, De Leeuw JR, Derksen R, Hauer R, Winnubst JA. A 12-month quality of life assessment of cardiac arrest survivors treated with or without an implantable cardioverter defibrillator. Europace. 2002;4(4):417-25. [pmid: 12408262].
24 Kamphuis HC, de Leeuw JR, Derksen R, Hauer RN, Winnubst JA. Implantable cardioverter defibrillator recipients: quality of life in recipients with and without ICD shock delivery: a prospective study. Europace. 2003;5(4):381-9. [pmid: 14753636].
25 Kettering K, Mewis C, Dornberger V, Vonthein R, Bosch RF, Kuhlkamp V. Efficacy of metoprolol and sotalol in the prevention of recurrences of sustained ventricular tachyarrhythmias in patients with an implantable cardioverter defibrillator. Pacing Clin Electrophysiol. 2002;25(11):1571-6. [pmid: 12494613].
26 Klein G, Lissel C, Fuchs AC, et al. Predictors of VT/VF-occurrence in ICD patients: Results from the PROFIT-Study. Europace. 2006;8(8):618-24. [pmid: 16864615].
27 Kouakam C, Kacet S, Hazard JR, et al. Performance of a dual-chamber implantable defibrillator algorithm for discrimination of ventricular from supraventricular tachycardia. Europace. 2004;6(1):32-42. [pmid: 14697724].
28 Kozak M, Sepsi M, Vlasinova J. Dlouhodobe prezivani pacientu s implantabilnimi kardiovertery-defibrilatory implantovanymi ze sekundarne preventivnich indikaci [Long-lasting survival of patients with implantable cardioverter-defibrillators implanted for secondary preventive reasons]. (Cze). Cas Lek Cesk. 2005;144(5):309-12. discussion 313–4.
29 Krivan L, Kozak M, Sepsi M, Svobodnik A, Spinar J. Specificke komplikace terapie implantabilnimi kardiovertery defibrilatory [Specific complications in the treatment with implantable cardioverter-defibrillators]. (Cze). Cas Lek Cesk. 2004;143(8):521-5. discussion 526–7.
30 Krivan L, Kozak M, Sepsi M, Svobodnik A, Spinar J. Treatment of arrhythmic storm in implantable defibrillator patients. Med Sci Monit. 2005;11(9):CR426-CR429. [pmid: 16127361].
31 Ladwig KH, Marten-Mittag B, Deisenhofer I, et al. Exaggerated electrodermal startle responses after intracardiac shock discharges in patients with implanted cardioverter defibrillators. Psychosom Med. 2003;65(2):222-8. [pmid: 12651989].
32 Lampert R, Joska T, Burg MM, Batsford WP, McPherson CA, Jain D. Emotional and physical precipitants of ventricular arrhythmia. Circulation. 2002;106(14):1800-5. [pmid: 12356633].
33 Lau EW, Griffith MJ, Pathmanathan RK, et al. The Midlands Trial of Empirical Amiodarone versus Electrophysiology-guided Interventions and Implantable Cardioverter-defibrillators (MAVERIC): a multi-centre prospective randomised clinical trial on the secondary prevention of sudden cardiac death. Europace. 2004;6(4):257-66. [pmid: 15172648].
34 Lin G, Nishimura RA, Connolly HM, Dearani JA, Sundt TM 3rd, Hayes DL. Severe symptomatic tricuspid valve regurgitation due to permanent pacemaker or implantable cardioverter-defibrillator leads. J Am Coll Cardiol. 2005;45(10):1672-5. [pmid: 15893186].
35 Liu QM, Zhang Y, Zhou SH. [Implantable cardioventer defibrillator in the treatment of malignant ventricular arrhythmias and its short-term follow-up]. (Chi). Hunan Yi Ke Da Xue Xue Bao. 2002;27(2):179-80.
36 Matsushita T, Chun S, Liem LB, Friday KJ, Sung RJ. Significance of inducible ventricular flutter/fibrillation in risk stratification in patients with coronary artery disease. Int J Cardiol. 2004;94(1):67-71. [pmid: 14996477].
37 Mletzko R, Aliot E, Seidl K, et al. Safety and efficacy of a dual chamber implantable cardioverter defibrillator capable of slow ventricular tachycardia discrimination: a randomized study. Pacing Clin Electrophysiol. 2003;26(12):2275-82. [pmid: 14675012].
38 Nanthakumar K, Dorian P, Paquette M, et al. Is inappropriate implantable defibrillator shock therapy predictable?. J Interv Card Electrophysiol. 2003;8(3):215-20. [pmid: 12815308].
39 Nanthakumar K, Newman D, Paquette M, Dorian P. Systematic evaluation of the determinants of defibrillation efficacy. Heart Rhythm. 2005;2(1):36-41. [pmid: 15851263].
40 Newman DM, Dorian P, Paquette M, et al. Effect of an implantable cardioverter defibrillator with atrial detection and shock therapies on patient-perceived, health-related quality of life. Am Heart J. 2003;145(5):841-6. [pmid: 12766741].
41 Ommen SR, Hammill SC, Gibbons RJ. The relative lymphocyte count predicts death in patients receiving implantable cardioverter defibrillators. Pacing Clin Electrophysiol. 2002;25(10):1424-8. [pmid: 12418738].
42 Pelletier D, Gallagher R, Mitten-Lewis S, McKinley S, Squire J. Australian implantable cardiac defibrillator recipients: quality-of-life issues. Int J Nurs Pract. 2002;8(2):68-74. [pmid: 11993579].
43 Przybylski A, Baranowski R, Zebrowski JJ, Szwed H. Verification of implantable cardioverter defibrillator (ICD) interventions by nonlinear analysis of heart rate variability-preliminary results. Europace. 2004;6(6):617-24. [pmid: 15519267].
44 Ricci R, Pignalberi C, Disertori M, et al. Efficacy of a dual chamber defibrillator with atrial antitachycardia functions in treating spontaneous atrial tachyarrhythmias in patients with life-threatening ventricular tachyarrhythmias. Eur Heart J. 2002;23(18):1471-9. [pmid: 12208228].
45 Rinaldi CA, Simon RD, Baszko A, et al. Can we predict which patients with implantable cardioverter defibrillators receive appropriate shock therapy? A study of 155 patients. Int J Cardiol. 2003;88(1):69-75. [pmid: 12659987].
46 Rinaldi CA, Simon RD, Geelen P, et al. A randomized prospective study of single coil versus dual coil defibrillation in patients with ventricular arrhythmias undergoing implantable cardioverter defibrillator therapy. Pacing Clin Electrophysiol. 2003;26(8):1684-90. [pmid: 12877701].
47 Ruskin JN, Camm AJ, Zipes DP, Hallstrom AP, McGrory-Usset ME. Implantable cardioverter defibrillator utilization based on discharge diagnoses from Medicare and managed care patients. J Cardiovas Electrophysiol. 2002;13(1):38-43.
48 Schimpf R, Wolpert C, Bianchi F, et al. Congenital short QT syndrome and implantable cardioverter defibrillator treatment: inherent risk for inappropriate shock delivery. J Cardiovas Electrophysiol. 2003;14(12):1273-7.
49 Schuchert A, Boriani G, Wollmann C, et al. Implantable dual-chamber defibrillator for the selective treatment of spontaneous atrial and ventricular arrhythmias: arrhythmia incidence and device performance. J Interv Card Electrophysiol. 2005;12(2):149-56. [pmid: 15744468].
50 Schuchert A, Schmitz D, Bondke HJ, et al. Erste erfahrungen zur detektion von tachyarrhythmien mit einem single-pass ICD in verbrindung mit einer defibrillationssonde mit freiflottierendem atrialem bipol [First experience for detection of tachyarrhtthmias with a single-pass ICD in connection with a defibrillation lead with free-floating atrial bipole]. (Ger). Herzschrittmacherther Elektrophysiol. 2003;14(suppl 1):33-4.
51 Sharma AD, Fain E, O'Neill PG, et al. Shock on T versus direct current voltage for induction of ventricular fibrillation: a randomized prospective comparison. Pacing Clin Electrophysiol. 2004;27(1):89-94. [pmid: 14720161].
52 Sterk B, van Alem AP, Tukkie R, Simmers TA, Koster RW. ICD-implantation guidelines versus clinical practice: a prospective study of out-of-hospital cardiac arrest survivors. Europace. 2004;6(3):179-83. [pmid: 15121066].
53 Sukhija R, Aronow WS, Sorbera C, Yalamanchili K, Cohen M. Patients, mean age 70 years, with automatic implantable cardioverter-defibrillators treated with dual-chamber rate responsive pacing (DDDR-70) have a higher mortality than patients with backup ventricular pacing (VVI-40) at 3.7-year follow-up. J Gerontol A Biol Sci Med Sci. 2005;60(5):603-4. [pmid: 15972611].
54 Tsai CT, Huang SK, Lin JL, Lai LP. Taiwan ICD Registry Investigators. Distinct clinical features in the recipients of the implantable cardioverter defibrillator in Taiwan: a multicenter registry study. Pacing Clin Electrophysiol. 2003;26(11):2083-90. [pmid: 14622308].
55 Voigt A, Ezzeddine R, Barrington W, et al. Utilization of implantable cardioverter-defibrillators in survivors of cardiac arrest in the United States from 1996 to 2001. J Am Coll Cardiol. 2004;44(4):855-8. [pmid: 15312871].
56 Wallace RL, Sears SF Jr, Saia Lewis T, Griffis JT, Curtis A, Conti JB. Predictors of quality of life in long-term recipients of implantable cardioverter defibrillators. J Cardiopulm Rehabil. 2002;22(4):278-81. [pmid: 12202849].
57 Weiss JP, Saynina O, McDonald KM, McClellan MB, Hlatky MA. Effectiveness and cost-effectiveness of implantable cardioverter defibrillators in the treatment of ventricular arrhythmias among medicare beneficiaries. Am J Med. 2002;112(7):519-27. [pmid: 12015242].
58 Weretka S, Michaelsen J, Becker R, et al. Ventricular oversensing: a study of 101 patients implanted with dual chamber defibrillators and two different lead systems. Pacing Clin Electrophysiol. 2003;26(1 Pt 1):65-70. [pmid: 12685142].
59 Wu LA, Kottke TE, Friedman PA, Luria DM, Grill DE, Maurer MJ. Implantable cardioverter defibrillator implantation rates in the Olmsted County, Minnesota, population: 1989-1999. J Clin Epidemiol. 2002;55(5):458-61. [pmid: 12007548].
60 Zareba W, Moss AJ, Daubert JP, Hall WJ, Robinson JL, Andrews M. Implantable cardioverter defibrillator in high-risk long QT syndrome patients. J Cardiovas Electrophysiol. 2003;14(4):337-41.
61 Zhou X, Gunderson BD, Olson WH. Gem DR ICD Clinical Worldwide Investigators. Incidence of nonsustained and sustained ventricular tachyarrhythmias in patients with an implantable cardioverter defibrillator. J Cardiovas Electrophysiol. 2004;15(1):14-20.

### Intervention

1 Baessler C, Murphy S, Gebhardt L, et al. Time to resumption of driving after implantation of an automatic defibrillator (from the Dual chamber and VVI Implantable Defibrillator [DAVID] trial). Am J Cardiol. 2005;95(5):665-6. [pmid: 15721116].
2 Baravelli M, Salerno-Uriarte D, Guzzetti D, et al. Predictive significance for sudden death of microvolt-level T wave alternans in New York Heart Association class II congestive heart failure patients: a prospective study. Int J Cardiol. 2005;105(1):53-7. [pmid: 16207545].
3 Bloom H, Heeke B, Leon A, et al. Renal insufficiency and the risk of infection from pacemaker or defibrillator surgery. Pacing Clin Electrophysiol. 2006;29(2):142-5. [pmid: 16492298].
4 Byrd CL, Wilkoff BL, Love CJ, Sellers TD, Reiser C. Clinical study of the laser sheath for lead extraction: the total experience in the United States. Pacing Clin Electrophysiol. 2002;25(5):804-8. [pmid: 12049372].
5 Khaleal F, Paterson HS, Cousins KL, Cooper MJ. Incidence of defribillator patch infection due to pulmonary erosion. Heart Lung Circ. 2004;13(2):157-60. [pmid: 16352187].
6 Marti Almor J, Delclos Baulies M, Delclos Urgell J, Comin Colet J, Cladellas Capdevila M, Bruguera Cortada J. Revalencia y evolucion en espan~a de los pacientes con infarto agudo de miocardio y fraccion de eyeccion severalmente deprimida, con criterios de implantacion de desfibrilador automaatico [Prevalence and clinical course of patients in Spain with acute myocardial infarction and severely depressed ejection fraction who meet the criteria for automatic defibrillator implantation]. (Spa). Rev Esp Cardiol. 2004;57(7):705-8.
7 Mathur G, Stables RH, Heaven D, et al. Cardiac pacemaker lead extraction using conventional techniques: a single centre experience. Int J Cardiol. 2003;91(23):215-9. [pmid: 14559133].
8 Meier-Ewert HK, Gray ME, John RM. Endocardial pacemaker or defibrillator leads with infected vegetations: a single-center experience and consequences of transvenous extraction. Am Heart J. 2003;146(2):339-44. [pmid: 12891205].
9 Rinaldi CA, Bostock J, Patel N, Bucknall CA. Determinants of procedural outcome of chronically implanted pacemaker and defibrillator leads using the Excimer laser sheath. Heart. 2002;87(2):160-1. [pmid: 11796559]. [pmcid: 1766991].

### Outcomes

1 Al-Khatib SM, Anstrom KJ, Eisenstein EL, et al. Clinical and economic implications of the Multicenter Automatic Defibrillator Implantation Trial-II. Ann Intern Med. 2005;142(8):593-600. [pmid: 15838065].
2 Arya A, Haghjoo M, Nikoo MH, Dehghani MR, Fazelifar AF, Sadr-Ameli MA. Effect of first ventricular tachycardia cycle length on rate of ventricular arrhythmia recurrence in patients with implantable cardioverter-defibrillator. J Electrocardiol. 2006;39(4):404-8. [pmid: 16895771].
3 Berkowitsch A, Zareba W, Neumann T, et al. Risk stratification using heart rate turbulence and ventricular arrhythmia in MADIT II: usefulness and limitations of a 10-minute holter recording. Ann Noninvasive Electrocardiol. 2004;9(3):270-9. [pmid: 15245344].
4 Bracke F, Meijer A, Van Gelder B. Venous occlusion of the access vein in patients referred for lead extraction: influence of patient and lead characteristics. Pacing Clin Electrophysiol. 2003;26(8):1649-52. [pmid: 12877695].
5 Brodine WN, Tung RT, Lee JK, et al. Effects of beta-blockers on implantable cardioverter defibrillator therapy and survival in the patients with ischemic cardiomyopathy (from the multicenter automatic defibrillator implantation trial-II). Am J Cardiol. 2005;96(5):691-5. [pmid: 16125497].
6 Butter C, Meisel E, Engelmann L, et al. Human experience with transvenous biventricular defibrillation using an electrode in a left ventricular vein. Pacing Clin Electrophysiol. 2002;25(3):324-31. [pmid: 11990662].
7 Chan P, Hayward R. Predicting 1-year mortality in patients receiving implantable cardioverter-defibrillators for congestive heart failure, ischemic heart disease, and ventricular arrhythmias. Circulation. 2004;110(17):504.
8 Chen RH, Chen KP, Wang FZ, Hua W, Chen X, Zhang S. Incidence and causes of inappropriate detection and therapy by implantable defibrillators of cardioversion in patients with ventricular tachyarrhythmia. Chin Med J. 2006;119(7):557-63. [pmid: 16620696].
9 Church TR, Hodges M, Bailey JJ, Mongin SJ. Risk stratification applied to CAST registry data: combining 9 predictors. Cardiac Arrhythmia Suppression Trial. J Electrocardiol. 2002;35(Suppl):117-22. [pmid: 12539108].
10 Crevenna R, Wolzt M, Fialka-Moser V, et al. Long-term transcutaneous neuromuscular electrical stimulation in patients with bipolar sensing implantable cardioverter defibrillators: a pilot safety study. Artif Organs. 2004;28(1):99-102. [pmid: 14720294].
11 Davids JS, McPherson CA, Earley C, Batsford WP, Lampert R. Benefits of cardiac rehabilitation in patients with implantable cardioverter-defibrillators: a patient survey. Arch Phys Med Rehabil. 2005;86(10):1924-8. [pmid: 16213232].
12 Domanski MJ, Epstein A, Hallstrom A, Saksena S, Zipes DP. Survival of antiarrhythmic or implantable cardioverter defibrillator treated patients with varying degrees of left ventricular dysfunction who survived malignant ventricular arrhythmias. J Cardiovas Electrophysiol. 2002;13(6):580-3.
13 Ellenbogen KA, Levine JH, Berger RD, et al. Are implantable cardioverter defibrillator shocks a surrogate for sudden cardiac death in patients with nonischemic cardiomyopathy?. Circulation. 2006;113(6):776-82. [pmid: 16461817].
14 Fiek M, Zieg B, Matis T, Hahnefeld A, Reithmann C, Steinbeck G. Analyse der Todesursachen von ICD-Patienten in der Langzeitbeobachtung [Analysis of the cause of death of ICD patients during long-term follow-up]. (Ger). Herzschrittmacherther Elektrophysiol. 2006;17(1):6-12.
15 Fries R, Steuer M, Schafers HJ, Bohm M. The R-on-T phenomenon in patients with implantable cardioverter-defibrillators. Am J Cardiol. 2003;91(6):752-5. [pmid: 12633818].
16 Gold MR, Shorofsky SR, Thompson JA, et al. Advanced rhythm discrimination for implantable cardioverter defibrillators using electrogram vector timing and correlation. J Cardiovas Electrophysiol. 2002;13(11):1092-7.
17 Goldberger JJ, Subacius H, Schaechter A, et al. Effects of statin therapy on arrhythmic events and survival in patients with nonischemic dilated cardiomyopathy. J Am Coll Cardiol. 2006;48(6):1228-33. [pmid: 16979011].
18 Goldenberg I, Moss AJ, Hall WJ, et al. Causes and consequences of heart failure after prophylactic implantation of a defibrillator in the multicenter automatic defibrillator implantation trial II. Circulation. 2006;113(24):2810-7. [pmid: 16769917].
19 Greenberg H, Case RB, Moss AJ, et al. Analysis of mortality events in the Multicenter Automatic Defibrillator Implantation Trial (MADIT-II). J Am Coll Cardiol. 2004;43(8):1459-65. [pmid: 15093884].
20 Guevara E, Torino AF, Casabe JH, et al. Endocarditis infecciosa ascoiada a marcapasos: ecocardiografia, manejo y evolucion [Infective endocarditis associated to pacemakers: sonography, management and evolution]. (Spa). Prensa Med Argent. 2003;90(5):390-3.
21 Herrmann-Lingen C, Fritzsche K, Kanwischer H, et al. Kardiologische und psychosoziale Befunde bei Patienten mit malignen ventrikularen Herzrhythmusstorungen vor Implantation eines internen Defibrillators—Erste Ergebnisse aus der deutsch-osterreichischen Multizenterstudie zu Krankheitserleben und -verlauf bei Patienten mit implantiertem Defibrillator [Cardiological and psychosocial status of patients with malignant ventricular arrhythmias before implantation of a cardioverter defibrillator. First results from the German Austrian ICD Multicenter Study (GAIMS)]. (Ger). Psychother Psychosom Med Psychol. 2004;54(8):308-19.
22 Hreybe H, Ezzeddine R, Bedi M, et al. Renal insufficiency predicts the time to first appropriate defibrillator shock. Am Heart J. 2006;151(4):852-6. [pmid: 16569548].
23 Irvine J, Dorian P, Baker B, et al. Quality of life in the Canadian Implantable Defibrillator Study (CIDS). Am Heart J. 2002;144(2):282-9. [pmid: 12177646].
24 Kadish A, Schaechter A, Subacius H, et al. Patients with recently diagnosed nonischemic cardiomyopathy benefit from implantable cardioverter-defibrillators. J Am Coll Cardiol. 2006;47(12):2477-82. [pmid: 16781376].
25 Kempa M, Lubinski A, Zienciuk A, et al. Mechanizmy wyzwalajace grozne arytmie komorowe-analiza elektrogramow rejestrowanych w pamieci holterowskieji implantowanych kardiowerterow-defibrylatorow serca [Mechanisms inducing malignant ventricular arrhythmias-analysis of the electrograms stored in holter memory of implantable cardioverter-defibrillators]. (Pol). Folia Cardiol. 2002;9(4):349-59.
26 Klein RC, Raitt MH, Wilkoff BL, et al. Analysis of implantable cardioverter defibrillator therapy in the Antiarrhythmics Versus Implantable Defibrillators (AVID) Trial. J Cardiovas Electrophysiol. 2003;14(9):940-8.
27 Klein RC, Schron EB, Renfroe EG, et al. Factors determining ICD implantation in drug therapy patients after termination of antiarrythmics versus implantable defibrillators trial. Pacing Clin Electrophysiol. 2003;26(12):2235-40. [pmid: 14675006].
28 Kozak M, Krivan L, Semrad B. Circadian variations in the occurrence of ventricular tachyarrhythmias in patients with implantable cardioverter defibrillators. Pacing Clin Electrophysiol. 2003;26(3):731-5. [pmid: 12698674].
29 Kron J. Clinical significance of device-related complications in clinical trials and implications for future trials: insights from the Antiarrhytmics Versus Implantable Defibrillators (AVID) trial. Cardiac Electrophysiol Rev. 2003;7(4):473-8.
30 Lampert R, Shusterman V, Burg MM, et al. Effects of psychologic stress on repolarization and relationship to autonomic and hemodynamic factors. J Cardiovas Electrophysiol. 2005;16(4):372-7.
31 Larsen G, Hallstrom A, McAnulty J, et al. Cost-effectiveness of the implantable cardioverter-defibrillator versus antiarrhythmic drugs in survivors of serious ventricular tachyarrhythmias: results of the Antiarrhythmics Versus Implantable Defibrillators (AVID) economic analysis substudy. Circulation. 2002;105(17):2049-57. [pmid: 11980684].
32 Lee KL, Hafley G, Fisher JD, et al. Effect of implantable defibrillators on arrhythmic events and mortality in the multicenter unsustained tachycardia trial. Circulation. 2002;106(2):233-8. [pmid: 12105164].
33 Mark DB, Nelson CL, Anstrom KJ, et al. Cost-effectiveness of defibrillator therapy or amiodarone in chronic stable heart failure: results from the Sudden Cardiac Death in Heart Failure Trial (SCD-HeFT). Circulation. 2006;114(2):135-42. [pmid: 16818817].
34 Melzer C, Bohm M, Bondke HJ, Combs W, Baumann G, Theres H. Chronotropic incompetence in patients with an implantable cardioverter defibrillator: prevalence and predicting factors. Pacing Clin Electrophysiol. 2005;28(10):1025-31. [pmid: 16221258].
35 Meyborg M, Mura R, Tiefenbacher C, Becker R, Michaelsen J, Niroomand F. Comparative follow up of patients with implanted cardioverter-defibrillators after induction of sustained monomorphic ventricular tachycardias or ventricular fibrillation by programmed stimulation. Heart. 2003;89(6):629-32. [pmid: 12748217]. [pmcid: 1767667].
36 Mitchell LB, Powell JL, Gillis AM, Kehl V, Hallstrom AP. AVID Investigators. Are lipid-lowering drugs also antiarrhythmic drugs? An analysis of the Antiarrhythmics Versus Implantable Defibrillators (AVID) trial. J Am Coll Cardiol. 2003;42(1):81-7. [pmid: 12849664].
37 Moss AJ, Vyas A, Greenberg H, et al. Temporal aspects of improved survival with the implanted defibrillator (MADIT-II). Am J Cardiol. 2004;94(3):312-5. [pmid: 15276094].
38 Parkash R, Tang A, Wells G, et al. Use of implantable cardioverter defibrillators after out-of-hospital cardiac arrest: a prospective follow-up study. Can Med Assoc J. 2004;171(9):1053-6. [pmid: 15505267]. [pmcid: 526330].
39 Perucca A, Parravicini U, Iraghi G, et al. Il decubito tardivo della tasca pacemaker o defibrillatore implantabile: indagine epidemiologica di tre anni in Piemonte-Valle d'Aosta [The late pacemaker pocket erosion or implantable defibrillator: epidemiological survey for three years in Piedmont-Valle d'Aosta]. (Ita). 2005;(3):157–64.
40 Pratt CM, Dorian P, Al-Khalidi HR, et al. Design of the SHock Inhibition Evaluation with Azimilide (SHIELD) study: a novel method to assess antiarrhythmic drug effect in patients with an implantable cardioverter-defibrillator. Am J Cardiol. 2005;95(2):274-6. [pmid: 15642569].
41 Raitt MH, Klein RC, Wyse DG, et al. Comparison of arrhythmia recurrence in patients presenting with ventricular fibrillation versus ventricular tachycardia in the Antiarrhythmics Versus Implantable Defibrillators (AVID) trial. Am J Cardiol. 2003;91(7):812-6. [pmid: 12667566].
42 Rankovic V, Karha J, Passman R, Kadish AH, Goldberger JJ. Predictors of appropriate implantable cardioverter-defibrillator therapy in patients with idiopathic dilated cardiomyopathy. Am J Cardiol. 2002;89(9):1072-6. [pmid: 11988198].
43 Russo AM, Hafley GE, Lee KL, et al. Racial differences in outcome in the Multicenter UnSustained Tachycardia Trial (MUSTT): a comparison of whites versus blacks. Circulation. 2003;108(1):67-72. [pmid: 12821551].
44 Russo AM, Stamato NJ, Lehmann MH, et al. Influence of gender on arrhythmia characteristics and outcome in the Multicenter UnSustained Tachycardia Trial. J Cardiovas Electrophysiol. 2004;15(9):993-8.
45 Schaechter A, Kadish AH. DEFibrillators In Non-Ischemic Cardiomyopathy Treatment Evaluation. DEFibrillators In Non-Ischemic Cardiomyopathy Treatment Evaluation (DEFINITE). Cardiac Electrophysiol Rev. 2003;7(4):457-62.
46 Schron EB, Exner DV, Yao Q, et al. Quality of life in the antiarrhythmics versus implantable defibrillators trial: impact of therapy and influence of adverse symptoms and defibrillator shocks. Circulation. 2002;105(5):589-94. [pmid: 11827924].
47 Shinde AA, Juneman EB, Mitchell B, et al. Shocks from pacemaker cardioverter defibrillators increase with amiodarone in patients at high risk for sudden cardiac death. Cardiology. 2003;100(3):143-8. [pmid: 14631135].
48 Singh JP, Hall WJ, McNitt S, et al. Factors influencing appropriate firing of the implanted defibrillator for ventricular tachycardia/fibrillation: findings from the Multicenter Automatic Defibrillator Implantation Trial II (MADIT-II). J Am Coll Cardiol. 2005;46(9):1712-20. [pmid: 16256874].
49 Sinha AM, Stellbrink C, Schuchert A, et al. Clinical experience with a new detection algorithm for differentiation of supraventricular from ventricular tachycardia in a dual-chamber defibrillator. J Cardiovas Electrophysiol. 2004;15(6):646-52.
50 Steinbeck G, Andresen D, Senges J, et al. Immediate Risk-Stratification Improves Survival (IRIS): study protocol. Europace. 2004;6(5):392-9. [pmid: 15294263].
51 Steinberg JS, Arshad A, Kowalski M, et al. Increased incidence of life-threatening ventricular arrhythmias in implantable defibrillator patients after the World Trade Center attack. J Am Coll Cardiol. 2004;44(6):1261-4. [pmid: 15364329].
52 Steinberg JS, Fischer A, Wang P, et al. The clinical implications of cumulative right ventricular pacing in the multicenter automatic defibrillator trial II. J Cardiovas Electrophysiol. 2005;16(4):359-65.
53 Tanno K, Miyoshi F, Watanabe N, et al. Are the MADIT II criteria for ICD implantation appropriate for Japanese patients?. Circ J. 2005;69(1):19-22. [pmid: 15635196].
54 Tiroke A, Syrkin AL, Ganeeva ON. Prediktory vozniknoveniia zhizneugrozhaiushchikh narushenii ritma kardioverterami-defibrilliatorami [Predictors of life-threatening arrhythmias in patients with implanted cardioverters-defibrillators]. (Rus). Klin Med. 2003;81(3):16-8.
55 Van Ittersum M, De Greef M, Van Gelder I, Coster J, Brugemann J, Van Der Schans C. Fear of exercise and health-related quality of life in patients with an implantable cardioverter defibrillator. Int J Rehabil Res. 2003;26(2):117-22. [pmid: 12799605].
56 Voigt A, Shalaby A, Saba S. Rising rates of cardiac rhythm management device infections in the United States: 1996 through 2003. 2006-;48( 3):590–1.
57 Vollmann D, Luethje L, Zenker D, Domhof S, Unterberg C. Subthreshold test pulses versus low energy shock delivery to estimate high energy lead impedance in implanted cardioverter defibrillator patients. Pacing Clin Electrophysiol. 2003;26(1 II):457-60. [pmid: 12687867].
58 Watanabe H, Chinushi M, Izumi D, et al. Decrease in amplitude of intracardiac ventricular electrogram and inappropriate therapy in patients with an implantable cardioverter defibrillator. Int Heart J. 2006;47(3):363-70. [pmid: 16823242].
59 Werling C, Weisse U, Siemon G, et al. Biventricular pacing in patients with ICD: how many patients are possible candidates?. Thorac Cardiovasc Surg. 2002;50(2):67-70. [pmid: 11981703].
60 Whang W, Mittleman MA, Rich DQ, et al. Heart failure and the risk of shocks in patients with implantable cardioverter defibrillators: results from the Triggers Of Ventricular Arrhythmias (TOVA) study. Circulation. 2004;109(11):1386-91. [pmid: 14993132].
61 Wittenberg SM, Cook JR, Hall WJ, et al. Comparison of efficacy of implanted cardioverter-defibrillator in patients with versus without diabetes mellitus. Am J Cardiol. 2005;96(3):417-9. [pmid: 16054472].
62 Zareba W, Moss AJ, Jackson Hall W, et al. Clinical course and implantable cardioverter defibrillator therapy in postinfarction women with severe left ventricular dysfunction. J Cardiovas Electrophysiol. 2005;16(12):1265-70.
63 Zareba W, Piotrowicz K, McNitt S, Moss AJ. MADIT II Investigators. Implantable cardioverter-defibrillator efficacy in patients with heart failure and left ventricular dysfunction (from the MADIT II population). Am J Cardiol. 2005;95(12):1487-91. [pmid: 15950580].
64 Zareba W, Steinberg JS, McNitt S, Daubert JP, Piotrowicz K, Moss AJ. Implantable cardioverter-defibrillator therapy and risk of congestive heart failure or death in MADIT II patients with atrial fibrillation. Heart Rhythm. 2006;3(6):631-7. [pmid: 16731460].

### Study Design

1 Al-Ahmad A, Link M, Estes NA 3rd, Wang PJ. Inappropriate shock and pacing?. J Cardiovas Electrophysiol. 2003;14(2):220-2.
2 Al-Ahmad A, Wang PJ, Homoud MK, Estes NA 3rd, Link MS. Frequent ICD shocks due to double sensing in patients with bi-ventricular implantable cardioverter defibrillators. J Interv Card Electrophysiol. 2003;9(3):377-81. [pmid: 14618060].
3 Al-Khadra AS. Implantation of pacemakers and implantable cardioverter defibrillators in orally anticoagulated patients. Pacing Clin Electrophysiol. 2003;26(1 Pt 2):511-4. [pmid: 12687880].
4 Barbone A, Pini D, Grossi P, et al. Aspergillus left ventricular assist device endocarditis. Ital Heart J. 2004;5(11):876-80. [pmid: 15633446].
5 Basarakodu K, Lakkireddy D, Li H, Tchou P. “Porcelain pocket”: dystrophic calcification of an implantable cardiac defibrillator pocket presenting as impending erosion. Heart Rhythm. 2005;2(7):787-8. [pmid: 15992742].
6 Bokhari F, Newman D, Mangat I, et al. Which is better over the long term: Amiodarone or the implantable cardioverter defibrillator?. Cardiol Rev. 2005;22(11):21-3.
7 Bourke JP, Turkington D, Thomas G, McComb JM, Tynan M. Florid psychopathology in patients receiving shocks from implanted cardioverter-defibrillators. Heart. 1997;78(6):581-3. [pmid: 9470875]. [pmcid: 1892332].
8 Bracke F, van Gelder B, Dijkman B, Meijer A. Lead system causing twiddler's syndrome in patients with an implantable cardioverter-defibrillator. J Thorac Cardiovasc Surg. 2005;129(1):231-2. [pmid: 15632856].
9 Brilakis ES, Friedman PA, Maounis TN, et al. Programmed ventricular stimulation in patients with idiopathic dilated cardiomyopathy and syncope receiving implantable cardioverter-defibrillators: a case series and a systematic review of the literature. [Review] [23 refs]. Int J Cardiol. 2005;98(3):395-401. [pmid: 15708170].
10 Bryant J, Brodin H, Loveman E, Payne E, Clegg A. The clinical and cost-effectiveness of implantable cardioverter defibrillators: A systematic review. Health Technol Assess (Winchester, England).
11 Burkhardt JD, Wilkoff BL. Malfunctions in implantable cardiac devices: putting the risk in perspective. [Review][11 refs]. Cleve Clin J Med 2005;72(9):736, 738, 742.
12 Cawley PJ, Al-Khatib SM. Amiodarone versus implantable cardioverter defibrillator for asymptomatic nonsustained ventricular tachycardia in nonischemic dilated cardiomyopathy. Am Heart J. 2004;147(5):790-1. [pmid: 15131532].
13 Centre for Reviews and Dissemination. Effectiveness of implantable defibrillators for preventing arrhythmic events and death: a meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effectiveness 2005;(4).
14 Centre for Reviews and Dissemination. Outcomes from the use of the implantable cardiac defibrillator: a critical appraisal of the literature (Structured abstract). Database of Abstracts of Reviews of Effectiveness 2005;(4).
15 Chan NY, Wai-Ling Ho L. Inappropriate implantable cardioverter-defibrillator shock due to external alternating current leak: report of two cases. Europace. 2005;7(2):193-6. [pmid: 15763537].
16 Coleman DB, DeBarr DM, Morales DL, Spotnitz HM. Pacemaker lead thrombosis treated with atrial thrombectomy and biventricular pacemaker and defibrillator insertion. [Review] [26 refs]. Ann Thorac Surg. 2004;78(5):e83-4. [pmid: 15511419].
17 Cook RJ, Orszulak TA, Nkomo VT, Shuford JA, Edwards WD, Ryu JH. Aspergillus infection of implantable cardioverter-defibrillator. [Review] [21 refs]. Mayo Clin Proc. 2004;79(4):549-52. [pmid: 15065620].
18 Cron TA, Schaer B, Osswald S. Implantable cardioverter defibrillator proarrhythmia due to an interaction with ‘noncompetitive atrial pacing’: an algorithm to prevent atrial arrhythmias. Pacing Clin Electrophysiol. 2002;25(11):1656-9. [pmid: 12494629].
19 De Sousa J. Efficacy of implantable cardioverter-defibrillators: from trials to the real world. Rev Port Cardiol. 2005;24(4):501-4. [pmid: 15977774].
20 Dilling-Boer D, Ector H, Willems R, Heidbuchel H. Pericardial effusion and right-sided pneumothorax resulting from an atrial active-fixation lead. Europace. 2003;5(4):419-23. [pmid: 14753641].
21 Disertori M, El-Sherif N. Primary prevention of sudden cardiac death. Do we need to implant a defibrillator in all the patients with low ejection fraction?. Ital Heart J. 2004;5(9):643-7. [pmid: 15568590].
22 Eldadah ZA, Donahue JK. Successful implantable cardioverter defibrillator placement in an ambulatory patient without thoracic venous access. J Cardiovas Electrophysiol. 2004;15(6):716-8.
23 Emori T, Ohta K, Kusano K, et al. Clusters of ventricular fibrillation in a patient with an implantable cardioverter difibrillator treated with amiodarone. Circ J. 2003;67(2):163-5. [pmid: 12548001].
24 Estes NAM, Weinstock J, Wang PJ, Homoud MK, Link MS. Use of Antiarrhythmics and Implantable Cardioverter Defibrillators in Congestive Heart Failure: Resynchronizing the rhythm in congestive heart failure. Naccarelli GVExcerpta Medica, 2003: 45D–52D.
25 Ezekowitz JA, Armstrong PW, McAlister FA. Implantable cardioverter defibrillators in primary and secondary prevention: a systematic review of randomized, controlled trials. [Review] [39 refs]. Ann Intern Med. 2003;138(6):445-52. [pmid: 12639076].
26 Fontaine G, Prost-Squarcioni C. Implantable cardioverter defibrillator in arrhythmogenic right ventricular cardiomyopathies. Circulation. 2004;109(12):1445-7. [pmid: 15051647].
27 Goeb JL, Galloyer-Fortier A, Dupuis JM, Victor J, Gohier B, Garre JB. Consequence psychiatrique apres l'implantation dun defibrillateur automatique: a propos d'un cas [Psychiatric complication of an implanted automatic defibrillator]. (Fre). Arch Mal Coeur Vaiss. 2003;96(12):1235-8.
28 Grimm W. Is prophylactic ICD therapy effective in dilated cardiomyopathy?. Cardiol Rev. 2002;19(13):20-4.
29 Gronefeld G, Connolly SJ, Hohnloser SH. Defibrillator in Acute Myocardial Infarction Trial investigators. The Defibrillator in Acute Myocardial Infarction Trial (DINAMIT): rationale, design and specific aims. [Review] [39 refs]. Cardiac Electrophysiol Rev. 2003;7(4):447-51.
30 Gronefeld G, Kleine P, Israel CW, Hohnloser SH. ‘Twiddler syndrome’ in a subpectorally implanted cardioverter defibrillator. J Cardiovas Electrophysiol. 2002;13(1):94.
31 Gurevitz O, Lipchenca I, Yaacoby E, et al. ST-segment deviation following implantable cardioverter defibrillator shocks: incidence, timing, and clinical significance. Pacing Clin Electrophysiol. 2002;25(10):1429-32. [pmid: 12418739].
32 Healy E, Goyal S, Browning C, et al. Inappropriate ICD therapy due to proarrhythmic ICD shocks and hyperpolarization. Pacing Clin Electrophysiol. 2004;27(3):415-6. [pmid: 15009877].
33 Helmberger TK, Roth U, Empen K. Massive air embolism during interventional laser therapy of the liver: Successful resuscitation without chest compression. Cardiovasc Intervent Radiol. 2002;25(4):335-6. [pmid: 12324822].
34 Herweg B, Barold SS. Ventricular asystole during atrial antitachycardia pacing by implanted cardioverter-defibrillator. Pacing Clin Electrophysiol. 2005;28(5):432-3. [pmid: 15869677].
35 Ho ICK, Milan DJ, Mansour MC, et al. Fungal infection of implantable cardioverter-defibrillators: case series of five patients managed over 22 years. Heart Rhythm. 2006;3(8):919-23. [pmid: 16876740].
36 Hohnloser SH, Ikeda T, Bloomfield DM, Dabbous OH, Cohen RJ. T-wave alternans negative coronary patients with low ejection and benefit from defibrillator implantation. Lancet. 2003;362(9378):125-6. [pmid: 12867114].
37 Kanagaratnam L, Pavia S, Schweikert R, et al. Matching approved “nondedicated” hardware to obtain biventricular pacing and defibrillation: feasibility and troubleshooting. Pacing Clin Electrophysiol. 2002;25(7):1066-71. [pmid: 12164448].
38 Karchmer AW, Longworth DL. Infections of intracardiac devices. [Review] [114 refs]. Cardiol Clin. 2003;21(2):253-71. [pmid: 12874897].
39 Khan MN, Joseph G, Khaykin Y, Ziada KM, Wilkoff BL. Delayed lead perforation: A disturbing trend. Pacing Clin Electrophysiol. 2005;28(3):251-3. [pmid: 15733190].
40 Khoo MSC, Scholl F, Dignan R, Rottman JN. Migration and infection of a pace-sense lead from an abdominal defibrillator system. Pacing Clin Electrophysiol. 2002;25(11):1652-5. [pmid: 12494628].
41 Kolb C, Schmieder S, Schmitt C. Inappropriate shock delivery due to interference between a washing machine and an implantable cardioverter defibrillator. J Interv Card Electrophysiol. 2002;7(3):255-6. [pmid: 12510137].
42 Kostopoulou A, Sbarouni E, Livanis EG, Theodorakis GN, Kremastinos D. Superior vena cava syndrome and syncope in an implantable cardioverter defibrillator recipient. Europace. 2004;6(3):205-8. [pmid: 15121071].
43 Kouakam C. Le suivi du patient portuer d'un defibrillateur implantable [Follow-up of patients with implantable defibrillators]. (Fre). Arch Mal Coeur Vaiss 2004;(127):18–9.
44 Kubota T, Tomita M, Sakurai T, et al. An ICD implanted DCM patient due to sustained VT. (Jap). Ther Res. 2002;23(10):2012-5.
45 Kurita T, Mitamura H, Aizawa Y, et al. Japanese randomized trial for investigation of a combined therapy of amiodarone and implantable cardioverter defibrillator in patients with ventricular tachycardia and fibrillation: the Nippon ICD Plus Pharmachologic Option Necessity study design. Circ J. 2006;70(3):316-20. [pmid: 16501299].
46 Kutalek SP. Pacemaker and defibrillator lead extraction. [Review] [29 refs]. Curr Opin Cardiol. 2004;19(1):19-22. [pmid: 14688629].
47 Lau EW, Birnie DH, Lemery R, Tang AS, Green MS. Acupuncture triggering inappropriate ICD shocks. Europace. 2005;7(1):85-6. [pmid: 15670973].
48 Lau EW, Green MS, Birnie DH, Lemery R, Tang ASL. Ventricular tachycardia terminated by an ICD: Is there more than what meets the eye?. Pacing Clin Electrophysiol. 2004;27(12):1656-8. [pmid: 15613130].
49 Lee DS, Green LD, Liu PP, et al. Effectiveness of implantable defibrillators for preventing arrhythmic events and death: a meta-analysis. J Am Coll Cardiol. 2003;41(9):1573-82. [pmid: 12742300].
50 Lee DSY, Green LD, Liu PP, Grant FC, Alter DA. Implantable defibrillators vs antiarrhythmic drugs for left ventricular dysfunction. Cochrane Database Syst Rev 2005;4.
51 Levine PA, Stanton MS, Sims JJ. High quality performance of pacemakers and implantable defibrillators. Pacing Clin Electrophysiol. 2002;25(12):1667-9. [pmid: 12520665].
52 Lin D, Dixit S, Russo AM, Hsia HH. Total failure to sense ventricular fibrillation with inappropriate defibrillator sensitivity adjustment. Pacing Clin Electrophysiol. 2004;27(9):1321-3. [pmid: 15461727].
53 Liu BC, Villareal RP, Hariharan R, Rasekh A, Massumi A. Inappropriate shock delivery and biventricular pacing cardiac defibrillators. Tex Heart Inst J. 2003;30(1):45-9. [pmid: 12638671]. [pmcid: 152836].
54 Manolis AG, Chatzis DG. Electrical storm in ICD recipients: Incidence, causes, and prognosis. Mediterranean J Pacing Electrophysiol. 2003;5(3):135-8.
55 Manolis AG, Katsivas AG, Vassilopoulos C, Tsatiris CG. Electrical storms in an ICD-recipient with 429 delivered appropriate shocks: therapeutic management with antiarrhythmic drug combination. J Interv Card Electrophysiol. 2002;6(1):91-4. [pmid: 11839890].
56 McBride BF, Guertin D, White CM, Kluger J. Inappropriate implantable cardioverter defibrillator discharge following consumption of a dietary weight loss supplement. Pacing Clin Electrophysiol. 2004;27(9):1317-20. [pmid: 15461726].
57 McClellan MB, Tunis SR. Medicare coverage of ICDs. New Engl J Med. 2005;352(3):222-4. [pmid: 15659721].
58 Meisel SR, Mazur A, Chetboun I, et al. Usefulness of implantable cardioverter-defibrillators in refractory variant angina pectoris complicated by ventricular fibrillation in patients with angiographically normal coronary arteries. Am J Cardiol. 2002;89(9):1114-6. [pmid: 11988204].
59 Melon P. Prevention primaire de la mort subite en 2003: role due defibrillateur automatique implantable [Implantable cardioverter-defibrillator in primary prevention of sudden cardiac death]. (Fre). Rev Med Liege. 2003;58(6):396-9.
60 Messali A, Thomas O, Chauvin M, Coumel P, Leenhardt A. Death due to an implantable cardioverter defibrillator. J Cardiovas Electrophysiol. 2004;15(8):953-6.
61 Moore DR, Kok LC, Vijayaraman P. Apparent inappropriate shocks from an implantable cardioverter defibrillator. J Cardiovas Electrophysiol. 2004;15(1):116-7.
62 Morishima I, Sone T, Tsuboi H, Kondo J, Mukawa H. Follow-up X rays play a key role in detecting implantable cardioverter defibrillator lead fracture: a case of incessant inappropriate shocks due to lead fracture. Pacing Clin Electrophysiol. 2003;26(4 Pt 1):911-3. [pmid: 12715854].
63 Moss A, Zareba W, Hall J, et al. Prophylactic implantation of a defibrillator improves survival in people with prior myocardial infarction and advanced left ventricular dysfunction. Evid Based Cardiovasc Med. 2002;6(4):141-2.
64 Mykytsey A, Maheshwari P, Dhar G, et al. Ventricular tachycardia induced by biventricular pacing in patient with severe ischemic cardiomyopathy. J Cardiovas Electrophysiol. 2005;16(6):655-8.
65 Nandakumar R, Broadhurst P. An unusual obstacle in lead extraction. Pacing Clin Electrophysiol. 2004;27(11):1576-7. [pmid: 15546319].
66 Nanthakumar K, Epstein AE, Kay GN, Plumb VJ, Lee DS. Prophylactic implantable cardioverter-defibrillator therapy in patients with left ventricular systolic dysfunction: a pooled analysis of 10 primary prevention trials. J Am Coll Cardiol. 2004;44(11):2166-72. [pmid: 15582314].
67 Neu P, Godemann F. Ersterkrankung einer Panikstorung mit Agoraphobie induziert durch eine Schockserie eines defekten Defibrillators [First onset of panic disorder and agoraphobia induced by a series of inappropriate shocks of an implanted cardioverter/defibrillator]. (Ger). Nervenarzt. 2003;74(3):266-8.
68 O'Rourke S, Kapoor S, Carter-Adkins D, Pachulski RT. ICD nocardiosis. J Intervent Cardiol. 2003;16(5):375-6. [pmid: 14603793].
69 Oliveira M, da Silva N, Antunes E, et al. Detection of minor myocardial damage during implantation of transvenous cardioverter-defibrillators. Mediterranean J Pacing Electrophysiol. 2004;6(1):1-6.
70 Omoto T, Hansky B, Minami K, Vogt J, Lamp B, Korfer R. Successful bridging by biventricular pacing for heart transplantation. Ann Thorac Surg. 2002;74(5):1684-5. [pmid: 12440630].
71 Pai RK, Cadman CS. Subcutaneous implantable cardioverter-defibrillator lead erosion after weight loss. Cardiol Rev. 2005;13(1):27. [pmid: 15596025].
72 Pai RK, Pergam SA, Kedia A, Cadman CS, Osborn LA. Pacemaker lead infection secondary to Haemophilus parainfluenzae. Pacing Clin Electrophysiol. 2004;27(7):1008-10. [pmid: 15271026].
73 Paraskevaidis S, Polymeropoulos KP, Louridas G. Inappropriate ICD therapy due to electrical interference: external alternating current leakage. J Invasive Cardiol. 2004;16(6):339. [pmid: 15156008].
74 Pezawas T, Stix G, Kastner J, et al. Unexplained syncope in patients with structural heart disease and no documented ventricular arrhythmias: value of electrophysiologically guided implantable cardioverter defibrillator therapy. Europace. 2003;5(3):305-12. [pmid: 12842649].
75 Pickett RA 3rd, Saavedra P, Ali MF, Darbar D, Rottman JN. Implantable cardioverter-defibrillator malfunction due to mechanical failure of the header connection. J Cardiovas Electrophysiol. 2004;15(9):1095-9.
76 Prudente LA. Phantom shock in a patient with an implantable cardioverter defibrillator: case report. Am J Crit Care. 2003;12(2):144-6. [pmid: 12625172].
77 Pyatt JR, Trenbath D, Chester M, Connelly DT. The simultaneous use of a biventricular Implantable Cardioverter Defibrillator (ICD) and Transcutaneous Electrical Nerve Stimulation (TENS) unit: implications for device interaction. Europace. 2003;5(1):91-3. [pmid: 12504647].
78 Raitt MH. Have increasing rates of defibrillator implantation reduced the incidence of out-of-hospital cardiac arrest?. Heart Rhythm. 2004;1(3):260-1. [pmid: 15851166].
79 Rinaldi CA, Simon RD, Baszko A, et al. A 17 year experience of inappropriate shock therapy in patients with implantable cardioverter-defibrillators: are we getting any better?. Heart. 2004;90(3):330-1. [pmid: 14966063]. [pmcid: 1768130].
80 Sato Y, Horiguchi T, Nishikawa T. Anesthetic management of cardiac tamponade after dual-chamber implantable cardioverter defibrillator implantation in a patient with dilated cardiomyopathy. J Clin Anesth. 2004;16(7):554-6. [pmid: 15590264].
81 Schliamser JE, Avramovitch NA, Karkabi B, Flugelman MY, Militianu A, Lewis BS. Rhabdomyolysis induced by repeated internal cardioverter defibrillator discharges. Pacing Clin Electrophysiol. 2002;25(4 Pt 1):516-7. [pmid: 11991382].
82 Shah KB, Gottlieb SS. Implantable cardioverter-defibrillator therapy after myocardial infarction. N Engl J Med. 2005;352(10):1039-41. author reply 1039–41.
83 Shapiro M, Hanon S, Schweitzer P. A rare, late complication after automated implantable cardioverter-defibrillator placement. Indian Pacing Electrophysiol J. 2004;4(4):213-6. [pmid: 16943935]. [pmcid: 1502064].
84 Sharifi M, Inbar S, Neckels B, Shook H. Twiddling to the extreme: development of twiddler syndrome in an implanted cardioverter-defibrilllator. J Invasive Cardiol. 2005;17(3):195-6. [pmid: 15867459].
85 Shevchenko IuL, Stonogin AV, Popov LV, et al. [A case of electrodeinduced endocarditis]. (Rus). Klin Med. 2005;83(5):66-8.
86 Sinclair CT, Marymount JH III, Rozner MA, DiMarco JP. Implantable cardioverter-defibrillators and complications [5] (multiple letters). N Engl J Med. 2004;350(7):734-5.
87 Siu CW, Tse HF, Lau CP. Inappropriate implantable cardioverter defibrillator shock from a transcutaneous muscle stimulation device therapy. J Interv Card Electrophysiol. 2005;13(1):73-5. [pmid: 15976983].
88 Sochman J, Bytesnik J, Skalsky I, Peregrin JH. Percutaneous extraction of a severed and frayed permanent pacing lead. Pacing Clin Electrophysiol. 2004;27(3):412-4. [pmid: 15009876].
89 Sola CL, Bostwick JM. Implantable cardioverter-defibrillators, induced anxiety, and quality of life. [Review] [43 refs]. Mayo Clin Proc. 2005;80(2):232-7. [pmid: 15704778].
90 Srivathsan K, Bazzell JL, Lee RW. Biventricular implantable cardioverter defibrillator and inappropriate shocks. J Cardiovas Electrophysiol. 2003;14(1):88-9.
91 Steinbeck G, Andresen D, Senges J. Implantable cardioverter-defibrillator therapy after myocardial infarction. New Engl J Med. 2005;352(10):1039-41. author reply 1039–41.
92 Steinbrook R. The controversy over Guidant's implantable defibrillators. New Engl J Med. 2005;353(3):221-4. [pmid: 16034006].
93 Straburzynska-Migaj E, Baszko A, Ochotny R, Cieslinski A. Bezpieczenstwo i przydatnosc kliniczna testo w wysikowych u chorych z niewydolnoscia serca oraz wszczepionym kariowerterem-defibrylatorem [Safety and clinical usefulness of exercise stress tests in patients with heart failure and implantable cardioverter-defibrillator]. (Pol). Folia Cardiol. 2004;11(12):953-60.
94 Swanton BJ, Keane D, Vlahakes GJ, Streckenbach SC. Intraoperative transesophageal echocardiography in the early detection of acute tamponade after laser extraction of a defibrillator lead. Anesth Analg. 2003;97(3):654-6. [pmid: 12933378].
95 Swerdlow CD. Reappraisal of implant testing of implantable cardioverter defibrillators. J Am Coll Cardiol. 2004;44(1):92-4. [pmid: 15234414].
96 Tanabe Y, Chinushi M, Washizuka T, et al. Suppression of electrical storm by biventricular pacing in a patient with idiopathic dilated cardiomyopathy and ventricular tachycardia. Pacing Clin Electrophysiol. 2003;26(1 Pt 1):101-2. [pmid: 12685146].
97 Vollmann D, Luthje L, Vonhof S, Unterberg C. Inappropriate therapy and fatal proarrhythmia by an implantable cardioverter-defibrillator. Heart Rhythm. 2005;2(3):307-9. [pmid: 15851324].
98 Waheed A, Romano J, Raman AA, Raman A. Candida glabrata: an unexpected culprit in endocarditis from an ICD lead. J Crit Illn. 2003;18(4):171-3.
99 Wase A. Random internal component failure of an implantable cardioverter defibrillator. J Interv Card Electrophysiol. 2004;10(2):175-6. [pmid: 15014220].
100 Wasson S, Aggarwal K, Flaker G, Reddy HK. Role of transesophageal echocardiography in detecting implantable cardioverter defibrillator lead infection. Echocardiography. 2003;20(3):289-90. [pmid: 12848668].
101 Wayar L, Mont L, Silva RMFL, et al. Electrical interference from an abdominal muscle stimulator unit on an implantable cardioverter defibrillator: report of two consecutive cases. Pacing Clin Electrophysiol. 2003;26(5):1292-3. [pmid: 12765461].
102 Wever EF, Hauer RN, van Capelle FL, et al. Randomized study of implantable defibrillator as first-choice therapy versus conventional strategy in postinfarct sudden death survivors. Circulation. 1995. 91:2195-203. [pmid: 7697849].
103 Wonisch M, Lercher P, Scherr D, et al. Influence of permanent right ventricular pacing on cardiorespiratory exercise parameters in chronic heart failure patients with implanted cardioverter defibrillators. Chest. 2005;127(3):787-93. [pmid: 15764758].
104 Yagi S, Tsuda E, Shimizu W, et al. Two adults requiring implantable defibrillators because of ventricular tachycardia and left ventricular dysfunction caused by presumed Kawasaki disease. Circ J. 2005;69(7):870-4. [pmid: 15988116].
105 Yasuda M, Nakazato Y, Sasaki A, et al. Ventricular fibrillation refractory to ICD therapy. Intern Med. 2005;44(8):829-31. [pmid: 16157981].

### Not Obtained

1 Bondke H, Witte J, Schonfeld G, Baumann G. Verlauf bei 221 ICD-patienten ohne Pra-Hospital-Discharge (PHD)-tests. [Course in 221 ICD patients without prehospital discharge tests]. (Ger). Herzschrittmacherther Elektrophysiol. 2003;14(suppl 1):74-5.
2 McGregor M CJ. Use of the implantable cardiac defibrillator (ICD) at the McGill University Health Centre (MUHC). 2003.
3 Mendoza Gonzalez C, Iturralde Torres P, Guevara Valdivia ME, et al. Seguimiento de un grupo de pacientes con desfibrilador automatico implantable [Follow-up of a group of patients with automatic implantable defibrillator]. (Spa). Arch Cardiol Mex. 2002;72(3):220-6.
4 Schuchert A, Winter J, Binner L, Meinertz T. Kurzere lmplantationszeiten und weniger sondenkomplikationen mit neueren implantierbaren defibrillatoren [Shorter implantation times and fewer lead complications with new implantable cardioverter defibrillators]. (Ger). Herzschrittmacherther Elektrophysiol. 2003;14(suppl 1):24-5.
5 Suga C, Matsumoto K, Kato R, et al. [Clinical characteristics of inappropriate therapy delivery of implantable cardioverter defibrillator]. (Jap). Ther Res. 2004;25(10):2029-3.