# Appendix C: Primary Publications and Associated Publications of Included Studies

## Cardiac resynchronization therapy studies

CARE-HF
Primary report: Cleland JG, Daubert JC, Erdmann E, et al. The effect of cardiac resynchronization therapy on morbidity and mortality in heart failure. N Engl J Med 2005; 352(15):1539–49.
| Other publications associated with CARE-HF
| Cleland JG, Daubert JC, Erdmann E, et al. Baseline characteristics of patients recruited into the CARE-HF study. Eur J Heart Fail 2005; 7(2):205–14t
| Cleland JG, Daubert JC, Erdmann E, et al. Longer-term effects of cardiac resynchronization therapy on mortality in heart failure [the CArdiac REsynchronization-Heart Failure (CARE-HF) trial extension phase]. Eur Heart J 2006; 27(16):1928–1932.
COMPANION
Primary report: Bristow MR, Saxon LA, Boehmer J, et al. Cardiac resynchronization therapy with or without an implantable defibrillator in advanced chronic heart failure.
| Other publications associated with COMPANION
| Bristow MR, Feldman AM, Saxon LA. Heart failure management using implantable devices for ventricular resynchronization: Comparison of medical therapy, pacing, and defibrillation in chronic heart failure (COMPANION) trial. J Card Fail 2000; 6(3):276–85
| Bristow MR, et al. Comparison of medical therapy, pacing and defibrillation in heart failure. Presented at the 52nd Annual Scientific Conference, American College of Cardiology, Chicago, Illinois, USA, March 31st, 2003.
| Carson P, Anand I, O'Connor C, et al. Mode of death in advanced heart failure: the Comparison of Medical, Pacing, and Defibrillation Therapies in Heart Failure (COMPANION) trial. J Am Coll Cardiol 2005; 46(12): 2329–34
CONTAK CD
Primary report: Higgins SL, Hummel JD, Niazi IK, et al. Cardiac resynchronization therapy for the treatment of heart failure in patients with inraventricular conduction delay and malignant ventricular tachyarrhythmia. J Am Coll Cardiol 2003; 42(12):2109–16
| Other publications associated with CONTAK CD
| Knight BP, Desai A, Coman J, Faddis M, Yong P. Long-term retention of cardiac resynchronization therapy. J Am Coll Cardiol 2004; 44(1):72–7
| GUIDANT Corporation, Cardiac Rhythm Management. Summary of safety and effectiveness: Guidant
| CONTAK CD CRT-D system including the CONTACK CD CRT-D pulse generator model 1823, and software application model 2848. PMA: P010012. Food and Drug Administration July 10, 2002.
| Boehmer JP, DeMarco T, Jaski BE, et al. Why ICD patients with heart failure (Class II–IV) are hospitalized: Do the reasons differ for patients who are treated with cardiac resynchronization therapy? [abst] J Am Coll Cardiol 2002;39(5):159A
| Higgins SL, Yong P, Sheck D, et al. Biventricular pacing diminishes the need for implantable cardioverter defibrillator therapy. Ventak CHF Investigators. J Am Coll Cardiol 2000;36(3):824–7
| Lozano I, Bocchiardo M, Achtelik M, et al. Impact of biventricular pacing on mortality in a randomized crossover study of patients with heart failure and ventricular arrhythmias. Pacing Clin Electrophysiol 2000;23(11Pt2):1711–12
| Saxon LA, Boehmer JP, Hummel J, et al. Biventricular pacing in patients with congestive heart failure: two prospective randomized trials. The VIGOR CHF and VENTAK CHF Investigators. Am J Cardiol 1999;83(5B):120–23D
| Saxon LA, De Marco T, Schafer J, et al. Effects of long-term biventricular stimulation for resynchronization on echocardiographic measures of remodeling. Circulation 2002;105(11):1304–10
Leclercq studies
Primary report: Leclercq C, Victor F, Alonso C, et al. Comparative effects of permanent biventricular pacing for refractory heart failure in patients with stable sinus rhythm or chronic atrial fibrillation. Am J Cardiol 2000;85(9):1154–56.
| Other publications associated with Leclercq study
| Leclercq C, Cazeau S, Ritter P, et al. A pilot experience with permanent biventricular pacing to treat advanced heart failure. Am Heart J 2000;140(6): 862–70
MIRACLE
Primary report: Abraham WT, Fisher WG, Smith AL, et al. Cardiac resynchronization in chronic heart failure. N Engl J Med 2002;346(24):1845–1853
| Other publications associated with the MIRACLE study
| Abraham WT. Rationale and design of a randomized clinical trial to assess the safety and efficacy of cardiac resynchronization therapy in patients with advanced heart failure: The Multicenter InSync
| Randomized Clinical Evaluation (MIRACLE). J Card Fail 2000;6(4):369–80
| Abraham WT, Fisher W, Smith A, et al. Cardiac resynchronization therapy reduces morbidity in patients with moderate to severe systolic heart failure and intraventricular conduction delays [abst]. J Am Coll Cardiol 2002;39(5):171A
| Abraham WT, Fisher W, Smith A, et al. Long-term improvement in functional status, quality of life and exercise capacity with cardiac resynchronization therapy: The MIRACLE Trial experience [abst]. J Am Coll Cardiol 2002;39(5):171A
| Aranda JM, Curtis AB, Conti JB, et al. Rationale and design of a randomized clinical trial to assess the safety and efficacy of cardiac resynchronization therapy in patients with advanced heart failure: The Multicenter InSync Randomized Clinical Evaluation (MIRACLE) [abst]. J Am Coll Cardiol 2002;39(5):96A
| Packer M & Abraham WT. Effect of cardiac resynchronization on a composite clinical status endpoint in patients with chronic heart failure: Results of the MIRACLE trial [abst]. Circulation 2001;104(17):1995
| Sutton MGS, Plappert T, Abraham WT, et al. Cardiac resynchronization improves diastolic ventricular function in advanced heart failure: The MIRACLE trial [abst]. Circulation 2001;104(17):2920
| Wagoner LE, Zengel PW, Abraham WT, et al. Cardiac resynchronization therapy with the InSync stimulation system improves exercise performance in patients with heart failure: MIRACLE trial substudy results [abst]. Circulation 2001;104(17):2919
MIRACLE-ICD
Primary report: Young JB, Abraham WT, Smith AL, et al. Combined cardiac resynchronization and implantable cardioversion defibrillation in advanced chronic heart failure: the MIRACLE ICD trial. JAMA 2003; 289 (20):2685–94.
| Other publications associated with MIRACLE ICD
| Medtronic, Inc. Summary of Safety and Effectiveness: InSync ICD Model 7272 dual chamber implantable cardioverter defibrillator with biventricular pacing for cardiac resynchronization, Attain Models 2187, 2188, 4189 leads. PMA: P010031. Food and Drug Administration, Dec 3, 2001
| Medtronic, Inc. Summary of Safety and Effectiveness: InSync ICD Model 7272 dual chamber implantable cardioverter defibrillator with cardiac resynchronization therapy and the model 9969
| Application Software. PMA: P010031. Food and Drug Administration, March 5, 2002
PATH CHF
Primary report: Auricchio A, Stellbrink C, Sack S, et al. Long-term clinical effect of hemodynamically optimized cardiac resynchronization therapy in patients with heart failure and ventricular conduction delay. J Am Coll Cardiol 2002;39(12):2026–33
| Other publications associated with PATH-CHF
| Auricchio A, Stellbrink C, Sack S, et al. The Pacing Therapies for Congestive Heart Failure (PATH-CHF) study: rationale, design, and endpoints of a prospective randomized multicenter study. Am J Cardiol 1999;83(5B):130D
| Auricchio A, Klein H, Spinelli J. Pacing for heart failure: selection of patients, techniques and benefits. Eur J Heart Fail 1999;1(3);275–79
| Auricchio A, Stellbrink C, Block M, et al. Effect of pacing chamber and atrioventricular delay on acute systolic function of paced patients with congestive heart failure. Circulation 1999;99(23):2993–3001
| Auricchio A, Ding J, Spinelli JC, et al. Cardiac resynchronization therapy restores optimal atrioventricular mechanical timing in heart failure patients with ventricular conduction delay. J Am Coll Cardil 2002;39(7):1163–69
| Baumann LS, Kadhiresan VA, Yu Y, et al. Optimization of cardiac resynchronization therapy in heart failure patients by measuring transient cycle length changes [abst]. Eur Heart J 2001;22:443
| Butter C, Auricchio A, Stellbrink C, et al. Effect of resynchronization therapy stimulation site on the systolic function of heart failure patients. Circulation 2001;104(25):3026–29
| Cuesta F, Sack S, Auricchio A, et al. Long-term benefit of cardiac resynchronization therapy in heart failure patients: results of the PATH-CHF study. Eur Heart J 2001;22:130
| Cuesta F, Stellbrink C, Auricchio A, et al. Cardiac resynchronization therapy reduces heart failure hospitalization in the PATH-CHF study [abst]. Eur Heart J 2001;22:441
| Huth C, Friedl A, Klein H, Auricchio A. Pacing therapies for congestive heart failure considering the results of the PATH-CHF study] Zeitschrift fur Kardiologie 2001; 90 (Supp 1):10–15
| Stellbrink C, Auricchio A, Butter C, et al. Pacing therapies in congestive heart failure II study. Am J Cardiol 2000;86 (9 Supp 1):138K
| Stellbrink C, Breithardt OA, Franke A, et al. Impact of cardiac resynchronization therapy using hemodynamically optimized pacing on left ventricular remodeling in patients with congestive heart failure and ventricular conduction disturbances. Am J Cardiol 2001;38(7):1957–65
| Vogt J, Krahnefeld O, Lamp B, et al. Electrocardiographic remodeling in patients paced for heart failure. Am J Cardiol 2000;86(Supp 1):152–56K
PATH CHF II
Primary report: Auricchio A., Stellbrink C, Butter C, Sack S, et al. Clinical efficacy of cardiac resynchronization therapy using left ventricular pacing in heart failure patients stratified by severity of ventricular conduction delay.[see comment]. J Am Coll Cardiol.;42(12):2109–16
| Other publications associated with PATH-CHF II
| Butter C, Auricchio A, Stellbrink C, et al. Clinical efficacy of one year cardiac resynchronization therapy in heart failure patients stratified by QRS duration: Results of the PATH-CHF II trial. Eur Heart J 2003;24:363
INSYNC (observational)
Primary report: Gras D, Leclercq C, Tang AS, et al. Cardiac resynchronization therapy in advanced heart failure the multicenter InSync clinical study. Eur J Heart Fail 2002;4(3):311–20.
| Other publications associated with InSync
| Gasparini M, Lunati M, Bocchiardo M, et al. Cardiac resynchronization and implantable cardioverter defibrillator therapy: preliminary results from the InSync Implantable Cardioverter Defibrillator Italian Registry. Pacing Clin Electrophysiol 2003;26(1 Pt 2): 148–151
| Gras D, Mabo P, Tang T, et al. Multisite pacing as a supplemental treatment of congestive heart failure: preliminary results of the Medtronic Inc. InSync Study. Pacing Clin Electrophysiol 1998;21(11 pt2):2249–55
| Gras D, Cazeau S, Ritter P, et al. Long term results of cardiac resynchronization for heart failure patients: The InSync Clinical Trial [abst] Circulation 1999;100(18):2714
| Gras D, Cazeau S, Mabo P, et al. Long-term benefit of cardiac resynchronization in heart failure patients: The 12 month results of the InSync trial. [abst] J Am Coll Cardiol 2000;35(2):230A.
| Gras D, Mabo P, Bucknall C, et al. Responders and nonresponders to cardiac resynchronization therapy: Results from the InSync trial. J Am Coll Cardiol 2000;35(2):230A–230A
| Tang ASL, Gras D, Mabo P, et al. Mortality and outcome differences between survivors and nonsurvivors in the InSync cardiac resynchronization trial [abst] Circulation 1999;100(18):2715
| Zardini M, Tritto M, Bargiggia G, et al. The InSync-Italian Registry: analysis of clinical outcome and considerations on the selection of candidates to left ventricular resynchronization. Eur Heart J Supp 2002;2:J16–22

## Implantable cardioverter defibrillator studies

AVID
Primary report: The Antiarrhythmics vs. Implantable Defibrillators (AVID) Investigators. A comparison of antiarrhythmic-drug therapy with implantable defibrillators in patients rescuscitated from near-fatal ventricular arrhythmias. N Engl J Med 1997; 337(22):1576–83
| Other publications associated with AVID
| Kron J. Clinical significance of device-related complications in clinical trials and implications for future trials: insights from the Antiarrhythmics Versus Implantable Defibrillators (AVID) Trial. Card Electrophysiol Rev 2003; 7(4)473–8
| Klein RC, Raitt MH, Wilkoff BL et al. Analysis of implantable cardioverter defibrillator therapy in the Antiarrhythmics Versus Implantable Cardioverter Defibrillators (AVID) Trial. J Cardiovasc Electrophysiol 2003; 14(9):940–8
AMIOVIRT
Primary report: Strickberger SA, Hummel JD, Bartlett TG et al. Amiodarone versus implantable cardioverter-defibrillator: randomized trial in patients with nonischemic dilated cardiomyopathy and aymoptomatic nonsustained ventricular tachycardia—AMIOVIRT. J Am Coll Cardiol 2003; 41(10): 1707–12.
| Other publications associated with AMIOVIRT
| Wijetunga M, Strickberger SA, Amiodarone Versus Implantable Defibrillators Randomized Trial. Amiodarone versus Implantable Defibrillator(AMIOVIRT): background, rationale, design, methods, results and implications. Card Electrophysiol Rev 2003; 7(4):452–6.