# Appendix B: Sample Data Extraction Form

To see the Sample Data Extraction Form, please select the link below. This link will take you to a PDF version of the forms.

Sample Data Extraction Forms