# Appendix A: Exact String Searches

Electronic Databases Searched | Search Strategies and Results
MEDLINE ^ ® ^ | CRT - efficacy/effectiveness
Ovid Version: rel10.3.2 | Results: 272
2005 to November Week 1 2006 | 1 resynchroni?ation therapy.mp.; 2 biv.mp.; 3 ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 4 ((cardiac or heart) adj resynchroni?ation$).mp.; 5 medtronic.mp.; 6 insync.mp.; 7 “ela medical”.mp.; 8 exp cardiac pacing, artificial/; 9 or/1–8; 10 exp heart failure, congestive/; 11 “congestive heart failure$”.mp.; 12 “congestive cardiac failure$”.mp.; 13 “chronic cardiac failure$”.mp.; 14 “chronic heart failure$”.mp.; 15 chf.mp.; 16 exp heart diseases/; 17 or/10–16; 18 RANDOMIZED CONTROLLED TRIAL.pt.; 19 CONTROLLED CLINICAL TRIAL.pt.; 20 RANDOMIZED CONTROLLED TRIALS/; 21 RANDOM ALLOCATION/; 22 DOUBLE BLIND METHOD/; 23 SINGLE-BLIND METHOD/; 24 or/18–23; 25 ANIMAL/ not HUMAN/; 26 24 not 25; 27 CLINICAL TRIAL.pt.; 28 exp CLINICAL TRIALS/; 29 (clin$ adj25 trial$).ti,ab.; 30 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.; 31 PLACEBOS/; 32 placebo$.ti,ab.; 33 random$.ti,ab.; 34 RESEARCH DESIGN/; 35 or/27–34; 36 35 not 25; 37 36 not 26; 38 COMPARATIVE STUDY/; 39 exp EVALUATION STUDIES/; 40 FOLLOW UP STUDIES/; 41 PROSPECTIVE STUDIES/; 42 (control$ or prospectiv$ or volunteer$).ti,ab.; 43 or/38–42; 44 43 not 25; 45 44 not (26 or; 37 46) 26 or 37 or 45; 47 “Case series”.mp.; 48 “time series”.mp.; 49 (efficacy or effectiveness).ti,ab.; 50 meta-analysis.pt.; 51 multicenter study.pt.; 52 or/47–51; 53 52 not 25; 54 or/46,53; 55 and/9,17,54
Searched November 14, 2006 | CRT Safety
| Results: 90
| 1 ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 2 resynchroni?ation therapy.mp.; 3 biv.mp.; 4 ((cardiac or heart) adj resynchroni?ation$).mp.; 5 medtronic.mp.; 6 insync.mp.; 7 “ela medical”.mp.; 8 exp cardiac pacing, artificial/; 9 or/1–8; 10 exp heart failure, congestive/; 11 exp heart diseases/; 12 “congestive cardiac failure$”.mp.; 13 “congestive heart failure$”.mp.; 14 “chronic cardiac failure$”.mp.; 15 “chronic heart failure$”.mp.; 16 chf.mp.; 17 or/10–16; 18 (safe or safety).mp.; 19 risk$.mp.; 20 exp risk/; 21 (adverse adj1 (effect$ or symptom$)).mp.; 22 side effect$.mp.; 23 harm.mp.; 24 etiology.mp.; 25 aetiology.mp.; 26 contraindicat$.mp.; 27 (cause or causation or causing or causal$).mp.; 28 exp causality/; 29 predict$.mp.; 30 or/18–29; 31 and/9,17,30; 32 limit 31 to yr=“2005 - 2006”
| ICD efficacy/effectiveness
| Results: 194
| 1 exp Defibrillators, Implantable/; 2 icd.ti,ab.; 3 aicd.ti,ab.; 4 (implant$ adj2 (defibrillat$ or defibrilat$)).mp.; 5 or/1–4; 6 exp heart failure, congestive/; 7 “congestive heart failure$”.mp.; 8 “congestive cardiac failure$”.mp.; 9 “chronic cardiac failure$”.mp.; 10 “chronic heart failure$”.mp.; 11 chf.mp.; 12 exp heart diseases/; 13 or/6–12; 14 RANDOMIZED CONTROLLED TRIAL.pt.; 15 CONTROLLED CLINICAL TRIAL.pt.; 16 RANDOMIZED CONTROLLED TRIALS/; 17 RANDOM ALLOCATION/; 18 DOUBLE BLIND METHOD/; 19 SINGLE-BLIND METHOD/; 20 or/14–19; 21 ANIMAL/ not HUMAN/; 22 20 not 21; 23 CLINICAL TRIAL.pt.; 24 exp CLINICAL TRIALS/; 25 (clin$ adj25 trial$).ti,ab.; 26 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.; 27 PLACEBOS/; 28 placebo$.ti,ab.; 29 random$.ti,ab.; 30 RESEARCH DESIGN/; 31 or/23–30; 32 31 not 21; 33 32 not 22; 34 COMPARATIVE STUDY/; 35 exp EVALUATION STUDIES/; 36 FOLLOW UP STUDIES/; 37 PROSPECTIVE STUDIES/; 38 (control$ or prospectiv$ or volunteer$).ti,ab.; 39 or/34–38; 40 39 not 21; 41 40 not (22 or; 42 22 or 33 or 41; 43 “Case series”.mp.; 44 “time series”.mp.; 45 (efficacy or effectiveness).ti,ab.; 46 meta-analysis.pt.; 47 multicenter study.pt.; 48 or/43–47; 49 48 not 21; 50 or/42,49; 51 and/5,13,50
| ICD safety
| Results: 127
| 1 exp Defibrillators, Implantable/; 2 icd.ti,ab.; 3 aicd.ti,ab.; 4 (implant$ adj2 (defibrillat$ or defibrilat$)).mp.; 5 or/1–4; 6 exp heart failure, congestive/; 7 exp heart diseases/; 8 “congestive cardiac failure$”.mp.; 9 “congestive heart failure$”.mp.; 10 “chronic cardiac failure$”.mp.; 11 “chronic heart failure$”.mp.; 12 chf.mp.; 13 or/6–12; 14 (safe or safety).mp.; 15 risk$.mp.; 16 exp risk/; 17 (adverse adj1 (effect$ or symptom$)).mp.; 18 side effect$.mp.; 19 harm.mp.; 20 etiology.mp.; 21 aetiology.mp.; 22 contraindicat$.mp.; 23 (cause or causation or causing or causal$).mp.; 24 exp causality/; 25 predict$.mp.; 26 complicat$.mp.; 27 shock$.mp.; 28 bleeding.mp.; 29 exp HEMORRHAGE/; 30 exp INFECTION/; 31 infect$.mp.; 32 (inappropriate adj2 pacing).mp.; 33 or/14–32; 34 and/5,13,33
Ovid MEDLINE ^ ® ^ In-Process & Other Non-Indexed Citations | CRT
Ovid Version: rel10.3.2 | Results: 0
Searched November 14, 2006 | 1 ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 2 resynchroni?ation therapy.mp.; 3 biv.mp.; 4 ((cardiac or heart) adj resynchroni?ation$).mp.; 5 medtronic.mp.; 6 insync.mp.; 7 “ela medical”.mp.; 8 or/1–7; 9 “congestive heart failure$”.mp.; 10 “congestive cardiac failure$”.mp.; 11 “chronic cardiac failure$”.mp.; 12 “chronic heart failure$”.mp.; 13 heart disease$.mp.; 14 chf.mp.; 15 or/9–14; 16 8 and 15
| ICD
| Results: 1
| 1 icd.ti,ab.; 2 aicd.ti,ab.; 3 (implant$ adj2 (defibrillat$ or defibrilat$)).mp.; 4 or/1–3; 5 “congestive heart failure$”.mp.; 6 “congestive cardiac failure$”.mp.; 7 “chronic cardiac failure$”.mp.; 8 “chronic heart failure$”.mp.; 9 heart disease$.mp.; 10 chf.mp.; 11 or/5–10; 12 4 and 11
Cochrane Central Register of Controlled Trials | CRT
Ovid Version: rel10.3.2 | Results: 0
2005 - 4th Quarter 2006 | 1 ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 2 resynchroni?ation therapy.mp.; 3 biv.mp.; 4 ((cardiac or heart) adj resynchroni?ation$).mp.; 5 medtronic.mp.; 6 insync.mp.; 7 “ela medical”.mp.; 8 or/1–7; 9 “congestive heart failure$”.mp.; 10 “congestive cardiac failure$”.mp.; 11 “chronic cardiac failure$”.mp.; 12 “chronic heart failure$”.mp.; 13 heart disease$.mp.; 14 chf.mp.; 15 or/9–14; 16 8 and 15
Searched November 14, 2006 | ICD
| Results: 2
| 1 icd.ti,ab.; 2 aicd.ti,ab.; 3 (implant$ adj2 (defibrillat$ or defibrilat$)).mp.; 4 or/1–3; 5 “congestive heart failure$”.mp.; 6 “congestive cardiac failure$”.mp.; 7 “chronic cardiac failure$”.mp.; 8 “chronic heart failure$”.mp.; 9 heart disease$.mp.; 10 chf.mp.; 11 or/5–10; 12 4 and 11
Cochrane Database of Systematic Reviews (CDSR) | CRT
Ovid Version: rel10.3.2 2005 - 4th Quarter 2006 | Results: 2
Searched November 14, 2006 | 1 ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 2 resynchroni?ation therapy.mp.; 3 biv.mp.; 4 ((cardiac or heart) adj resynchroni?ation$).mp.; 5 medtronic.mp.; 6 insync.mp.; 7 “ela medical”.mp.; 8 or/1–7; 9 “congestive heart failure$”.mp.; 10 “congestive cardiac failure$”.mp.; 11 “chronic cardiac failure$”.mp.; 12 “chronic heart failure$”.mp.; 13 heart disease$.mp.; 14 chf.mp.; 15 or/9–14; 16 8 and 15
| ICD
| Results: 5
| 1 icd.ti,ab.; 2 aicd.ti,ab.; 3 (implant$ adj2 (defibrillat$ or defibrilat$)).mp.; 4 or/1–3; 5 “congestive heart failure$”.mp.; 6 “congestive cardiac failure$”.mp.; 7 “chronic cardiac failure$”.mp.; 8 “chronic heart failure$”.mp.; 9 heart disease$.mp.; 10 chf.mp.; 11 or/5–10; 12 4 and 11
Database of Abstracts of Reviews of Effects (DARE) | CRT
Ovid Version: rel10.3.2 2005 - 4th Quarter 2006 | Results: 0
Searched November 14, 2006 | 1 ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 2 resynchroni?ation therapy.mp.; 3 biv.mp.; 4 ((cardiac or heart) adj resynchroni?ation$).mp.; 5 medtronic.mp.; 6 insync.mp.; 7 “ela medical”.mp.; 8 or/1–7; 9 “congestive heart failure$”.mp.; 10 “congestive cardiac failure$”.mp.; 11 “chronic cardiac failure$”.mp.; 12 “chronic heart failure$”.mp.; 13 heart disease$.mp.; 14 chf.mp.; 15 or/9–14; 16 8 and 15
| ICD
| Results: 1
| 1 icd.ti,ab.; 2 aicd.ti,ab.; 3 (implant$ adj2 (defibrillat$ or defibrilat$)).mp.; 4 or/1–3; 5 “congestive heart failure$”.mp.; 6 “congestive cardiac failure$”.mp.; 7 “chronic cardiac failure$”.mp.; 8 “chronic heart failure$”.mp.; 9 heart disease$.mp.; 10 chf.mp.; 11 or/5–10; 12 4 and 11
Health Technology Assessment Database (HTA) via The Cochrane Library | CRT
Wiley InterScience^®^ | Results: 1
Searched November 14, 2006 | MeSH descriptor Cardiac Pacing, Artificial explode all trees
| ICD
| Results: 2
| MeSH descriptor Defibrillators, Implantable explode all trees
EMBASE | CRT efficacy/effectiveness
Ovid Version: rel10.3.2 | Results: 431
2005 - 2006 Week 45 | 1 ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 2 exp heart pacing/; 3 resynchroni?ation therapy.mp.; 4 biv.mp.; 5 ((cardiac or heart) adj resynchroni?ation$).mp.; 6 medtronic.mp.; 7 insync.mp.; 8 “ela medical”.mp.; 9 or/1–8; 10 exp congestive heart failure/; 11 “congestive heart failure$”.mp.; 12 chf.mp.; 13 exp heart disease/; 14 “congestive cardiac failure$”.mp.; 15 “chronic cardiac failure$”.mp.; 16 “chronic heart failure$”.mp.; 17 or/10–16; 18 Randomized Controlled Trial/; 19 exp Randomization/; 20 Double Blind Procedure/; 21 Single Blind Procedure/; 22 or/18–21; 23 Clinical Trial/; 24 (clin$ adj25 trial$).mp.; 25 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).mp.; 26 exp Placebo/; 27 (placebo$ or random$).mp.; 28 exp Methodology/; 29 exp Comparative Study/; 30 exp Evaluation/; 31 exp Follow Up/; 32 exp Prospective Study/; 33 (control$ or prospectiv$ or volunteer$).mp.; 34 or/23–33; 35 22 or 34; 36 limit 35 to human; 37 Nonhuman/; 38 36 not 37; 39 exp Controlled Study/; 40 “systematic review”/; 41 Meta Analysis/; 42 ((multi center or multi centre or multicenter or multicentre) adj1 trial$).mp.; 43 exp Case Study/; 44 “Case series”.mp.; 45 “Time series”.mp.; 46 (efficacy or effectiveness).ti,ab.; 47 or/39–46; 48 limit 47 to human; 49 48 not 37; 50 38 or 49; 51 and/9,17,50
Searched November 14, 2006 | CRT safety
| Results: 91
| 1 ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 2 exp heart pacing/; 3 resynchroni?ation therapy.mp.; 4 biv.mp.; 5 ((cardiac or heart) adj resynchroni?ation$).mp.; 6 medtronic.mp.; 7 insync.mp.; 8 “ela medical”.mp.; 9 or/1–8; 10 exp congestive heart failure/; 11 “congestive heart failure$”.mp.; 12 chf.mp.; 13 exp heart disease/; 14 “congestive cardiac failure$”.mp.; 15 “chronic cardiac failure$”.mp.; 16 “chronic heart failure$”.mp.; 17 or/10–16; 18 (safe or safety).mp.; 19 exp risk/; 20 risk$.mp.; 21 exp side effect/; 22 side effect$.mp.; 23 (adverse adj1 (effect$ or symptom$)).mp.; 24 harm.mp.; 25 exp etiology/; 26 aetiology.mp.; 27 treatment contraindication/; 28 contraindicat$.mp.; 29 (cause or causation or causing or causal$).mp.; 30 *epidemiology/; 31 exp prediction/; 32 or/18–31; 33 and/9,17,32; 34 limit 33 to yr=“2005 - 2006”
| ICD efficacy/effectiveness
| Results: 350
| 1 exp defibrillator/; 2 icd.ti,ab.; 3 aicd.ti,ab.; 4 exp DEFIBRILLATION/; 5 (implant$ adj2 (defibrillat$ or defibrilat$)).mp.; 6 or/1–5; 7 exp congestive heart failure/; 8 “congestive heart failure$”.mp.; 9 chf.mp.; 10 exp heart disease/; 11 “congestive cardiac failure$”.mp.; 12 “chronic cardiac failure$”.mp.; 13 “chronic heart failure$”.mp.; 14 or/7–13; 15 Randomized Controlled Trial/; 16 exp Randomization/; 17 Double Blind Procedure/; 18 Single Blind Procedure/; 19 or/15–18; 20 Clinical Trial/; 21 (clin$ adj25 trial$).mp.; 22 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).mp.; 23 exp Placebo/; 24 (placebo$ or random$).mp.; 25 exp Methodology/; 26 exp Comparative Study/; 27 exp Evaluation/; 28 exp Follow Up/; 29 exp Prospective Study/; 30 (control$ or prospectiv$ or volunteer$).mp.; 31 or/20–30; 32 19 or 31; 33 limit 32 to human; 34 Nonhuman/; 35 33 not 34; 36 exp Controlled Study/; 37 “systematic review”/; 38 Meta Analysis/; 39 ((multi center or multi centre or multicenter or multicentre) adj1 trial$).mp.; 40 exp Case Study/; 41 “case series”.mp.; 42 “time series”.mp.; 43 (efficacy or effectiveness).ti,ab.; 44 or/36–43; 45 limit 44 to human; 46 45 not 34; 47 or/35,46; 48 and/6,14,47
| ICD safety
| Results: 239
| 1 exp defibrillator/; 2 icd.ti,ab.; 3 aicd.ti,ab.; 4 exp DEFIBRILLATION/; 5 (implant$ adj2 (defibrillat$ or defibrilat$)).mp.; 6 or/1–5; 7 exp congestive heart failure/; 8 “congestive heart failure$”.mp.; 9 chf.mp.; 10 exp heart disease/; 11 “congestive cardiac failure$”.mp.; 12 “chronic cardiac failure$”.mp.; 13 “chronic heart failure$”.mp.; 14 or/7–13; 15 (safe or safety).mp.; 16 exp risk/; 17 risk$.mp.; 18 exp side effect/; 19 side effect$.mp.; 20 (adverse adj1 (effect$ or symptom$)).mp.; 21 harm.mp.; 22 exp etiology/; 23 aetiology.mp.; 24 treatment contraindication/; 25 contraindicat$.mp.; 26 (cause or causation or causing or causal$).mp.; 27 *epidemiology/; 28 exp prediction/; 29 complicat$.mp.; 30 shock$.mp.; 31 exp BLEEDING/; 32 bleeding.mp.; 33 exp Infection/; 34 infect$.mp.; 35 (inappropriate adj2 pacing).mp.; 36 or/15–35; 37 and/6,14,36; 38 limit 37 to yr=“2005 - 2006”
Science Citation Index Expanded (via Web of Science^®^), 2005 - 2006 | CRT, ICD efficacy/effectiveness
Searched November 14, 2006 | Results: 20
| #10 | #9 NOT #7
| #9 | #8 AND #6 AND #1
| #8 | TS=(implantable same defibrillat*) or
| | TS=(implantable same defibrilat*)
| #7 | #6 AND #2 AND #1
| #6 | #5 OR #4 OR #3
| #5 | TS=(randomized controlled trial* or controlled clinical trial* or research design or comparative stud* or evaluation stud* or controlled trial* or follow-up stud* or prospective stud*)
| #4 | TS=(single blind* or double blind* or clinical trial* or placebo* or random*)
| #3 | TS=(case series or time series or efficacy or effectiveness or meta-analysis or multicenter study or multicentre study)
| #2 | TS=(biventricular pacing or biventricular pacer* or resynchronization therap* or resynchronization therap* or biv or dual-chamber pacing or dual-chamber pacer* or dual-chamber stimulat* or single-chamber pacing or single-chamber pacer* or single-chamber stimulat* or cardiac resynchronization or cardiac resynchronisation or heart resynchronization or heart resynchronization or cardiac pacing or medtronic or insync or ela medical)
| #1 | TS=(congestive heart failure* or chf or heart disease or congestive cardiac failure* or chronic cardiac failure* or chronic heart failure*)
| CRT/ICD safety (Searched from 2005-2006)
| Results: 20
| #16 | #15 NOT (#7 OR #10 OR #13)
| #15 | #14 AND #8 AND #1
| #14 | TS=(safe or safety or risk* or adverse effect* or adverse symptom* or side effect* or harm or etiology or aetiology or contraindicat* or cause or causation or causing or causal* or predict* or complicat* or shock* or bleeding or hemorrhag* or infect*) or TS=(inappropriate same pacing)
| #13 | #12 NOT (#7 OR #10)
| #12 | #11 AND #2 AND #1
| #11 | TS=(safe or safety or risk* or adverse effect* or adverse symptom* or side effect* or harm or etiology or aetiology or contraindicat* or cause or causation or causing or causal* or predict*)
| #10 | #9 NOT #7
| #9 | #8 AND #6 AND #1
| #8 | TS=(implantable same defibrillat*) or
| | TS=(implantable same defibrilat*)
| #7 | #6 AND #2 AND #1
| #6 | #5 OR #4 OR #3
| #5 | TS=(randomized controlled trial* or controlled clinical trial* or research design or comparative stud* or evaluation stud* or controlled trial* or follow-up stud* or prospective stud*)
| #4 | TS=(single blind* or double blind* or clinical trial* or placebo* or random*)
| #3 | TS=(case series or time series or efficacy or effectiveness or meta-analysis or multicenter study or multicentre study)
| #2 | TS=(biventricular pacing or biventricular pacer* or resynchronization therap* or resynchronization therap* or biv or dual-chamber pacing or dual-chamber pacer* or dual-chamber stimulat* or single-chamber pacing or single-chamber pacer* or single-chamber stimulat* or cardiac resynchronization or cardiac resynchronisation or heart resynchronization or heart resynchronization or cardiac pacing or medtronic or insync or ela medical)
| #1 | TS=(congestive heart failure* or chf or heart disease or congestive cardiac failure* or chronic cardiac failure* or chronic heart failure*)
International Pharmaceutical Abstracts | CRT
Ovid Version: rel10.3.2 | Results: 0
2005 to November 2006 Searched November 14, 2006 | 1 ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 2 resynchroni?ation therapy.mp.; 3 biv.mp.; 4 ((cardiac or heart) adj resynchroni?ation$).mp.; 5 medtronic.mp.; 6 insync.mp.; 7 “ela medical”.mp.; 8 or/1–7; 9 “congestive heart failure$”.mp.; 10 “congestive cardiac failure$”.mp.; 11 “chronic cardiac failure$”.mp.; 12 “chronic heart failure$”.mp.; 13 heart disease$.mp.; 14 chf.mp.; 15 or/9–14; 16 8 and 15
PubMed ^ ® ^ | CRT/ICD efficacy/effectiveness and safety
U.S. National Library of Medicine | Results: 50
Searched from June | #16 Search #15 NOT (#6 OR #8 OR #13)
2006 to November 2006 | #15 Search #3 AND #7 AND #14
| #14 Search safe OR safety OR risk* OR risk[MeSH] OR (adverse AND (effect* OR symptom*)) OR side effect* OR harm OR etiology OR aetiology OR contraindicat* OR cause OR causation OR causing OR causal* OR causality[MeSH] OR predict* OR bleeding OR hemorrhage[MeSH] OR complicat* OR shock* OR (inappropriate AND pacing)
| #13 Search #12 NOT (#6 OR #8)
| #12 Search #3 AND #4 AND #11
| #11 Search safe OR safety OR risk* OR risk[MeSH] OR (adverse AND (effect* OR symptom*)) OR side effect* OR harm OR etiology OR aetiology OR contraindicat* OR cause OR causation OR causing OR causal* OR causality[MeSH] OR predict*
| #10 Search #8 NOT #6
| #8 Search #3 AND #5 AND #7
| #7 Search “Defibrillators, Implantable”[MeSH] OR icd[tiab] OR aicd[tiab] OR (implant* AND (defibrillat* OR defibrilat*))
| #6 Search #3 AND #4 AND #5
| #5 Search #1 OR #2
| #4 Search (resynchronization therapy OR resynchronisation therapy OR biv OR ((biventricular OR dual-chamber OR single-chamber) AND (pacing OR pacer OR stimulat*)) OR ((cardiac OR heart) AND (resynchronization* OR resynchronisation*)) OR medtronic OR insync OR ela medical OR cardiac pacing, artificial[MESH])
| #3 Search “Heart Failure, Congestive”[MeSH] OR “Heart Diseases”[MeSH] OR congestive heart failure* OR congestive cardiac failure* OR chronic cardiac failure* OR chronic heart failure* OR chf
| #2 Search case series OR time series OR efficacy[tiab] OR effectiveness[tiab] OR meta-analysis[pt] OR multicenter study[pt]
| #1 Search (“Clinical Trial”[Publication Type] OR “Clinical Trials”[MeSH] OR “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials”[MeSH] OR “Random Allocation”[MeSH] OR “double-blind method” [MeSH] OR “single-blind method” [MeSH] OR placebos [MeSH] OR research design [MeSH] OR comparative study [MeSH] OR evaluation studies [MeSH] OR follow-up studies [MeSH] OR prospective studies [MeSH] OR (clinical[Title/Abstract] AND trial*[Title/Abstract]) OR control*[Title/Abstract] OR prospectiv* [Title/Abstract] OR volunteer*[Title/Abstract] OR random*[Title/Abstract] OR ((singl*[Title/Abstract] OR doubl* [Title/Abstract] OR trebl* [Title/Abstract]OR tripl* [Title/Abstract]) AND (blind* [Title/Abstract] OR mask*[Title/Abstract])))
OCLC Proceedings First and Papers First | CRT
OCLC FirstSearch | Results: 4
Searched 2005 – November 14, 2006 | biventricular pacing or biventricular pacer* or resynchronization therap* or resynchronisation therap* or biv or dual-chamber pacing or dual-chamber pacer* or dual-chamber stimulat* or single-chamber pacing or single-chamber pacer* or single-chamber stimulat* or cardiac resynchronization or cardiac resynchronisation or heart resynchronization or heart resynchronisation or cardiac pacing or medtronic or insync or ela medical
| AND
| congestive heart failure* or chf or heart disease or congestive cardiac failure* or chronic cardiac failure* or chronic heart failure*
| ICD
| Results: 0
| (implantable and defibrillat*) or (implantable and defibrilat*)
| AND
| congestive heart failure* or chf or heart disease or congestive cardiac failure* or chronic cardiac failure* or chronic heart failure*