# Appendixes

Appendix A: Exact String Searches

Appendix B: Sample Data Extraction Form

Appendix C: Primary Publications and Associated Publications of Included Studies

Appendix D: List of Excluded Studies

Appendix E: Technical Expert Panel and Peer Reviewers