# List of Acronyms/Abbreviations

AHRQ | Agency for Healthcare Research and Quality
ANA | American Nurses Association
AONE | American Organization of Nurse Executives
BSN | Bachelor of Science in Nursing
CDC | Centers for Disease Control and Prevention
CI | Confidence Interval
CPR | Cardiopulmonary Resuscitation
DHHS | Department of Health and Human Services
DRGs | Diagnosis Related Groups
FTE | Full Time Equivalent
HPD | Hours per Patient Day
ICD-9 | International Classification of Diseases (9th revision)
ICU | Intensive Care Unit
IEN | Internationally Educated Nurse
JCAHO | Joint Commission on Accreditation of Healthcare Organizations
LOS | Length of Stay
LPN | Licensed Practical Nurse
LVN | Licensed Vocational Nurse
MOOSE | Meta-analysis Of Observational Studies in Epidemiology
MS | Master of Science
NIOSH | National Institute for Occupational Safety and Health
NQF | National Quality Forum
NS | Not Significant
PhD | Doctor of Philosophy
QOL | Quality of Life
RRT | Rapid Response Team
RN | Registered Nurse
RR | Relative Risk
TEP | Technical Expert Panel
UAP | Unlicensed Assistive Personnel
UTI | Urinary Tract Infection