# References and Included Studies

1 National Center for Health Workforce Analysis. Projected supply, demand, and shortages of registered nurses: 2000-2020. National Center for Health Workforce Analysis (U.S.). Rockville, MD: U.S. Dept. of Health and Human Services, Health Resources and Services Administration, Bureau of Health Professions, National Center for Health Workforce Analysis; 2002.
2 United States Congress Senate Committee on Health Education Labor and Pensions. Addressing direct care staffing shortages: hearing before the Committee on Health, Education, Labor, and Pensions. S. hrg. 107–164 ed. Washington, D.C.: Superintendent of Documents, U.S. Government Printing Office; 2001.
3 Heinz D. Hospital nurse staffing and patient outcomes: a review of current literature. Dimens Crit Care Nurs. Jan–Feb. 2004;23(1):44-50. [pmid: 14734900].
4 Joint Commission on Accreditation of Healthcare Organizations. Joint Commission on Accreditation of Healthcare Organizations setting standard for quality in health care. Oak Brook Terrace, IL: Joint Commission on Accreditation of Healthcare Organizations; 1997.
5 National Quality Forum. National voluntary consensus standards for nursing-sensitive care: an initial performance measure set: a consensus report. Washington, D.C: National Quality Forum; 2004.
6 Needleman J, Buerhaus PI, Stewart M, et al. Nurse staffing in hospitals: is there a business case for quality?. Health Aff (Millwood). Jan–Feb. 2006;25(1):204-11. [pmid: 16403755].
7 Rothberg MB, Abraham I, Lindenauer PK, et al. Improving nurse-to-patient staffing ratios as a cost-effective safety intervention. Med Care. Aug. 2005;43(8):785-91. [pmid: 16034292].
8 Shortell SM, Zimmerman JE, Rousseau DM, et al. The performance of intensive care units: does good management make a difference?. Med Care. May. 1994;32(5):508-25. [pmid: 8182978].
9 Pronovost PJ, Jenckes MW, Dorman T, et al. Organizational characteristics of intensive care units related to outcomes of abdominal aortic surgery. JAMA. Apr 14. 1999;281(14):1310-7. [pmid: 10208147].
10 Aiken LH, Sloane DM, Lake ET, et al. Organization and outcomes of inpatient AIDS care. Med Care. Aug. 1999;37(8):760-72. [pmid: 10448719].
11 Robertson RH, Hassan M. Staffing intensity, skill mix and mortality outcomes: the case of chronic obstructive lung disease. Health Serv Manage Res. Nov. 1999;12(4):258-68. [pmid: 10622804].
12 Silber JH, Kennedy SK, Even-Shoshan O, et al. Anesthesiologist direction and patient outcomes. Anesthesiology. Jul. 2000;93(1):152-63. [pmid: 10861159].
13 Amaravadi RK, Dimick JB, Pronovost PJ, et al. ICU nurse-to-patient ratio is associated with complications and resource use after esophagectomy. Intensive Care Med. Dec. 2000;26(12):1857-62. [pmid: 11271096].
14 Dimick JB, Swoboda SM, Pronovost PJ, et al. Effect of nurse-to-patient ratio in the intensive care unit on pulmonary complications and resource use after hepatectomy. Am J Crit Care. Nov. 2001;10(62):376-82. [pmid: 11688604].
15 Aiken LH, Clarke SP, Sloane DM, et al. Hospital nurse staffing and patient mortality, nurse burnout, and job dissatisfaction. JAMA. Oct 23–30. 2002;288(162):1987-93. [pmid: 12387650].
16 Aiken LH, Clarke SP, Cheung RB, et al. Educational levels of hospital nurses and surgical patient mortality. JAMA. Sep 24. 2003;290(122):1617-23. [pmid: 14506121].
17 Person SD, Allison JJ, Kiefe CI, et al. Nurse staffing and mortality for Medicare patients with acute myocardial infarction. Med Care. Jan. 2004;42(12):4-12. [pmid: 14713734].
18 Mark BA, Harless DW, McCue M, et al. A longitudinal examination of hospital registered nurse staffing and quality of care. Health Serv Res. Apr. 2004;39(22):279-300. [pmid: 15032955]. [pmcid: 1361008].
19 Mark BA, Harless DW, McCue M. The impact of HMO penetration on the relationship between nurse staffing and quality. Health Econ. Jul. 2005;14(72):737-53. [pmid: 15744748].
20 Elting LS, Pettaway C, Bekele BN, et al. Correlation between annual volume of cystectomy, professional staffing, and outcomes: a statewide, population-based study. Cancer. Sep 1. 2005;104(52):975-84. [pmid: 16044400].
21 Halm M, Peterson M, Kandels M, et al. Hospital nurse staffing and patient mortality, emotional exhaustion, and job dissatisfaction. Clin Nurse Spec. Sep–Oct. 2005;19(5):241-51. quiz 52–4. [pmid: 16179855].
22 Hope J. Nosocomial infections and their relationship to nursing workload in an acute care hospital. [PhD]. Ottawa: Dissertation, Queen's University; 2003.
23 Pronovost PJ, Dang D, Dorman T, et al. Intensive care unit nurse staffing and the risk for complications after abdominal aortic surgery. Eff Clin Pract. Sep–Oct. 2001;4(5):199-206. [pmid: 11685977].
24 Dang D, Johantgen ME, Pronovost PJ, et al. Postoperative complications: does intensive care unit staff nursing make a difference?. Heart Lung. May–Jun. 2002;31(3):219-28. [pmid: 12011813].
25 Marcin JP, Rutan E, Rapetti PM, et al. Nurse staffing and unplanned extubation in the pediatric intensive care unit. Pediatr Crit Care Med. May. 2005;6(3):254-7. [pmid: 15857520].
26 Needleman J, Buerhaus P, Mattke S, et al. Nurse-staffing levels and the quality of care in hospitals. N Engl J Med. May 30. 2002;346(22):1715-22. [pmid: 12037152].
27 Needleman J. Nurse staffing and patient outcomes in hospitals. Final Report for Health Resources Services Administration 2001; Contract No. 230990021.
28 Cho S-H. Nurse staffing and adverse patient outcomes. [PhD]: Dissertation, University of Michigan; 2002.
29 Blegen MA, Goode CJ, Reed L. Nurse staffing and patient outcomes. Nurs Res. Jan–Feb. 1998;47(1):43-50. [pmid: 9478183].
30 Berney BL. Use, trends, and impacts of nurse overtime in New York hospitals, 1995-2000. [PhD]: Dissertation, Boston University; 2003.
31 Berney B, Needleman J. Impact of nursing overtime on nurse-sensitive patient outcomes in New York hospitals, 1995-2000. Policy Polit Nurs Pract. May. 2006;7(2):87-100. [pmid: 16864629].
32 Seago JA, Ash M. Registered nurse unions and patient outcomes. J Nurs Adm. Mar. 2002;32(3):143-51. [pmid: 11984245].
33 Unruh LY. The impact of hospital nurse staffing on the quality of patient care. [PhD]: Dissertation, University of Notre Dame; 2000.
34 Bond CA, Raehl CL, Pitterle ME, et al. Health care professional staffing, hospital characteristics, and hospital mortality rates. Pharmacotherapy. Feb. 1999;19(2):130-8. [pmid: 10030762].
35 Houser EP. Nurse staffing levels and patient outcomes. [DNSc]: Dissertation, Johns Hopkins University; 2005.
36 Zidek CK. Assessment of nursing care quality and the judgment of the professional nurse as reflected in nurse-determined patient acuity classification and staffing decisions. [PhD]: Dissertation, Indiana University of Pennsylvania; 2003.
37 Xu Y, Kwak C. Characteristics of internationally educated nurses in the United States. Nurs Econ Sep–Oct 2005;23(5):233–8, 11.
38 Dicicco-Bloom B. The racial and gendered experiences of immigrant nurses from Kerala, India. J Transcult Nurs. Jan. 2004;15(1):26-33. [pmid: 14768413].
39 Yi M, Jezewski MA. Korean nurses' adjustment to hospitals in the United States of America. J Adv Nurs. Sep. 2000;32(3):721-9. [pmid: 11012817].
40 Crawford L. Nurses educated in other countries: coming to America. JONAS Healthc Law Ethics Regul. Jul–Sep. 2004;6(3):66-8. [pmid: 15494629].
41 Flynn L, Aiken LH. Does international nurse recruitment influence practice values in U.S. hospitals?. J Nurs Scholarsh. 2002;34(1):67-73. [pmid: 11901970].
42 Pizer CM, Collard AF, James SM, et al. Nurses' job satisfaction: are there differences between foreign and U.S.-educated nurses?. Image J Nurs Sch. Winter. 1992;24(4):301-6. [pmid: 1452185].
43 Berney B, Needleman J. Trends in nurse overtime, 1995-2002. Policy Polit Nurs Pract. Aug. 2005;6(3):183-90. [pmid: 16443973].
44 Berney B, Needleman J, Kovner C. Factors influencing the use of registered nurse overtime in hospitals, 1995-2000. J Nurs Scholarsh. 2005;37(2):165-72. [pmid: 15960061].
45 Cimiotti JP. Nurse staffing and healthcare-associated infections in the neonatal ICU. [PhD]. Ann Arbor, MI: Dissertation, Columbia University; 2004.
46 Robert J, Fridkin SK, Blumberg HM, et al. The influence of the composition of the nursing staff on primary bloodstream infection rates in a surgical intensive care unit. Infect Control Hosp Epidemiol. Jan. 2000;21(1):12-7. [pmid: 10656348].
47 Alonso-Echanove J, Edwards JR, Richards MJ, et al. Effect of nurse staffing and antimicrobial-impregnated central venous catheters on the risk for bloodstream infections in intensive care units. Infect Control Hosp Epidemiol. Dec. 2003;24(12):916-25. [pmid: 14700407].
48 Oster CAH. The relationships between emergency department staffing and clinical outcomes of the acute myocardial infarction patient. [PhD]: Dissertation, University of Colorado; 2002.
49 Whitman GR, Kim Y, Davidson LJ, et al. The impact of staffing on patient outcomes across specialty units. J Nurs Adm. Dec. 2002;32(1):633-9. [pmid: 12483084].
50 Bloom JR, Alexander JA, Nuchols BA. Nurse staffing patterns and hospital efficiency in the United States. Soc Sci Med. Jan. 1997;44(2):147-55. [pmid: 9015868].
51 United States Agency for Healthcare Research and Quality, University of California San Francisco-Stanford Evidence-Based Practice Center. Hospital Nurse Staffing and Quality of Care. Agency for Healthcare Research and Quality. Available at: http://www.ahrq.gov/research/nursestaffing/nursestaff.htm, 2006.
52 Aiken LH, Smith HL, Lake ET. Lower Medicare mortality among a set of hospitals known for good nursing care. Med Care. Aug. 1994;32(8):771-87. [pmid: 8057694].
53 Buchan J. Lessons from America? US magnet hospitals and their implications for UK nursing. J Adv Nurs. Feb. 1994;19(2):373-84. [pmid: 8188971].
54 Goode CJ, Krugman ME, Smith K, et al. The pull of magnetism: a look at the standards and the experience of a western academic medical center hospital in achieving and sustaining Magnet status. Nurs Adm Q. Jul–Sep. 2005;29(3):202-13. [pmid: 16056154].
55 Lake ET. Development of the practice environment scale of the Nursing Work Index. Res Nurs Health. Jun. 2002;25(3):176-88. [pmid: 12015780].
56 Lake ET, Friese CR. Variations in nursing practice environments: relation to staffing and hospital characteristics. Nurs Res. Jan–Feb. 2006;55(1):1-9. [pmid: 16439923].
57 Laschinger HK, Almost J, Tuer-Hodes D. Workplace empowerment and magnet hospital characteristics: making the link. J Nurs Adm. Jul–Aug. 2003;33(78):410-22. [pmid: 12909793].
58 Taylor NT. The Magnetic pull: does your facility have what it takes to attain Magnet recognition?. Nurs Manage. Sep. 2004;35(9):68-81. [pmid: 15349068].
59 Robinson CA. Magnet nursing services recognition: transforming the critical care environment. AACN Clin Issues. Aug. 2001;12(3):411-23. [pmid: 11759359].
60 Kravitz RL, Sauvé MJ. Hospital Nursing Staff Ratios and Quality of Care. Final Report on Evidence, Administrative Data, an Expert Panel Process, and a Hospital Staffing Survey. Center for Health Services Research in Primary Care. 2006. Available at: http://repositories.cdlib.org/chsrpc/cdhs/Final
61 Bolton LB, Jones D, Aydin CE, et al. A response to California's mandated nursing ratios. J Nurs Scholarsh. 2001;33(2):179-84. [pmid: 11419315].
62 Cho SH, Ketefian S, Barkauskas VH, et al. The effects of nurse staffing on adverse events, morbidity, mortality, and medical costs. Nurs Res. Mar–Apr. 2003;52(2):71-9. [pmid: 12657982].
63 Cheung RB. The relationship between nurse staffing, nursing time, and adverse events in an acute care hospital. [PhD]: Dissertation, University of South Florida; 2002.
64 Donaldson N, Bolton LB, Aydin C, et al. Impact of California's licensed nurse-patient ratios on unit-level nurse staffing and patient outcomes. Policy Polit Nurs Pract. Aug. 2005;6(3):198-210. [pmid: 16443975].
65 Donaldson NE, Brown DS, Bolton LB, et al. Unit Level Nurse Workload Impacts on Patient Safety. The Agency for Healthcare Research and Quality Working Conditions Grant Initiative 2004;Grant R01 # HS11954.
66 Dugan J, Lauer E, Bouquot Z, et al. Stressful nurses: the effect on patient outcomes. J Nurs Care Qual. Apr. 1996;10(3):46-58. [pmid: 8634470].
67 Taunton RL, Kleinbeck SV, Stafford R, et al. Patient outcomes. Are they linked to registered nurse absenteeism, separation, or work load?. J Nurs Adm. Apr. 1994;24(4 Suppl):48-55. [pmid: 8068081].
68 Berger AM, Eilers JG, Pattrin L, et al. Advanced practice roles for nurses in tomorrow's healthcare systems. Clin Nurse Spec. Sep. 1996;10(5):250-5. [pmid: 9069830].
69 Brooten D, Youngblut JM. Nurse dose as a concept. J Nurs Scholarsh. 2006;38(1):94-9. [pmid: 16579330].
70 Gardiner WC. Documenting JCAHO standards in assigning nursing staff. J Healthc Qual. Jul–Aug. 1992;14(4):50-3. [pmid: 10119905].
71 Lookinland S, Crenshaw J. Rewarding clinical competence in the ICU: using outcomes to reward performance. Dimens Crit Care Nurs. Jul–Aug. 1996;15(4):206-15. [pmid: 8717643].
72 Proehl JA. Developing emergency nursing competence. Nurs Clin North Am Mar 2002;37(1):89–96, vii.
73 Cruickshank JF, MacKay RC, Matsuno K, et al. Appraisal of the clinical competence of registered nurses in relation to their designated levels in the Western Australian nursing career structure. Int J Nurs Stud. Jun. 1994;31(3):217-30. [pmid: 8088934].
74 Institute of Medicine, Committee on the Work Environment for Nurses and Patient Safety, NetLibrary Inc. Keeping patients safe: transforming the work environment of nurses. A report of the Committee on the Work Environment for Nurses and Patient Safety Board on Health Care Services. Washington, DC: National Academy Press; 2004.
75 Potter P, Barr N, McSweeney M, et al. Identifying nurse staffing and patient outcome relationships: a guide for change in care delivery. Nurs Econ. Jul–Aug. 2003;21(4):158-66. [pmid: 14509874].
76 Ritter-Teitel J. An exploratory study of a predictive model for nursing-sensitive patient outcomes derived from patient care unit structure and process variables. [PhD]: Dissertation, University of Pennsylvania; 2001.
77 Tallier PC. Nurse staffing ratios and patient outcomes. [PhD]: Dissertation, Columbia University; 2003.
78 Sovie MD, Jawad AF. Hospital restructuring and its impact on outcomes: nursing staff regulations are premature. J Nurs Adm. Dec. 2001;31(1):588-600. [pmid: 11771464].
79 Cimiotti JP, Haas J, Saiman L, et al. Impact of staffing on bloodstream infections in the neonatal intensive care unit. Arch Pediatr Adolesc Med. Aug. 2006;160(8):832-6. [pmid: 16894083].
80 Stegenga J, Bell E, Matlow A. The role of nurse understaffing in nosocomial viral gastrointestinal infections on a general pediatrics ward. Infect Control Hosp Epidemiol. Mar. 2002;23(3):133-6. [pmid: 11918117].
81 American Nurses Association. Implementing Nursing's Report Card. A Study of RN Staffing, Length of Stay and Patient Outcomes. Washington, DC: American Nurses Publishing; 1997.
82 Shamian J, Hagen B, Hu TW, et al. The relationship between length of stay and required nursing care hours. J Nurs Adm. Jul–Aug. 1994;24(78):52-8. [pmid: 8057174].
83 Halpine S, Maloney S. Tracing the missing link between nursing workload and case mix groups: a validation study. Healthc Manage Forum. Fall. 1993;6(3):19-26. [pmid: 10129770].
84 Kohn LT, Corrigan, J, Donaldson, MS,. To err is human: building a safer health system. A report of the Committee on Quality of Health Care in America. Washington, DC: Institute of Medicine, National Academy Press; 2000.
85 Institute of Medicine, Committee on Data Standards for Patient Safety, NetLibrary Inc. Patient Safety: Achieving a New Standard for Care. Washington, DC: Institute of Medicine: National Academy Press; 2004.
86 Unruh LY, Fottler MD, Talbott LL. Improving nurse staffing measures: discharge day measurement in “adjusted patient days of care.”. Inquiry. Fall. 2003;40(3):295-304. [pmid: 14680261].
87 United States Agency for Healthcare Research and Quality. National healthcare quality report. Washington, DC: National Academy Press; 2003.
88 Minnick AF, Roberts MJ, Young WB, et al. What influences patients' reports of three aspects of hospital services?. Med Care. Apr. 1997;35(4):399-409. [pmid: 9107207].
89 Savitz LA, Jones CB, Bernard S. Quality Indicators Sensitive to Nurse Staffing in Acute Care Settings. Agency for Helthcare Research and Quality, Rockville, MD, Advances in Patient Safety: From Research to Implementation 2005;1–4(AHRQ Publication No. 050021):375–85.
90 United States; Agency for Healthcare Research and Quality; University of California SF-SE-BPC. Making health care safer: a critical analysis of patient safety practices. Vol Chapter 39. Nurse Staffing, Models of Care Delivery, and Interventions. Rockville, MD: Agency for Healthcare Research and Quality; 2001.
91 Buerhaus PI, Staiger DO, Auerbach DI. Implications of an aging registered nurse workforce. JAMA. Jun 14. 2000;283(22):2948-54. [pmid: 10865272].
92 Lang TA, Hodge M, Olson V, et al. Nurse-patient ratios: a systematic review on the effects of nurse staffing on patient, nurse employee, and hospital outcomes. J Nurs Adm. Jul–Aug. 2004;34(78):326-37. [pmid: 15303051].
93 Lankshear AJ, Sheldon TA, Maynard A. Nurse staffing and healthcare outcomes: a systematic review of the international research evidence. ANS Adv Nurs Sci. Apr–Jun. 2005;28(2):163-74. [pmid: 15920362].
94 Unruh L. Licensed nurse staffing and adverse events in hospitals. Med Care. Jan. 2003;41(1):142-52. [pmid: 12544551].
95 American Nurses Association. Nursing-sensitive quality indicators for acute care settings and ANA's safety and quality initiative. Washington, D.C: American Nurses Association; 1999.
96 Clark AP. Nurse staffing levels and prevention of adverse events. Clin Nurse Spec. Sep. 2002;16(5):237-8. [pmid: 12394110].
97 Cho SH. Nurse staffing and adverse patient outcomes: a systems approach. Nurs Outlook. Mar–Apr. 2001;49(2):78-85. [pmid: 11309562].
98 Garretson S. Nurse to patient ratios in American health care. Nurs Stand. 2004;19(1416):33-7. [pmid: 15633873].
99 Lewis KK. Nurse-to-patient ratios: research and reality. Issue Brief (Mass Health Policy Forum) Mar 30 2005(25):1–19.
100 Arnow P, Allyn PA, Nichols EM, et al. Control of methicillin-resistant Staphylococcus aureus in a burn unit: role of nurse staffing. J Trauma. Nov. 1982;22(11):954-9. [pmid: 6923938].
101 Estabrooks CA, Midodzi WK, Cummings GG, et al. The impact of hospital nursing characteristics on 30-day mortality. Nurs Res. Mar–Apr. 2005;54(2):74-84. [pmid: 15778649].
102 Kovner CT. State regulation of RN-to-patient ratios. Am J Nurs Nov 2000;100(11):61–3, 5.
103 To amend title XVIII of the Social Security Act to provide for patient protection by establishing minimum nurse staffing ratios at certain Medicare providers, and for other purposes. Registered Nurse Safe Staffing Act of 2005 1. 109th Congress 1st Session ed; 2005.
104 Clarke SP. The policy implications of staffing-outcomes research. J Nurs Adm. Jan. 2005;35(1):17-9. [pmid: 15647663].
105 McCue M, Mark BA, Harless DW. Nurse staffing, quality, and financial performance. J Health Care Finance. Summer. 2003;29(4):54-76. [pmid: 12908654].
106 Sims CE. Increasing clinical, satisfaction, and financial performance through nurse-driven process improvement. J Nurs Adm. Feb. 2003;33(2):68-75. [pmid: 12584458].
107 Sincox AK. Mandatory overtime can hurt a hospital's financial status. Mich Nurse. Nov. 2004;77(9):9.
108 Cavouras CA. Nurse staffing levels in American hospitals: a 2001 report. J Emerg Nurs. Feb. 2002;28(1):40-3. [pmid: 11830733].
109 Hodge MB, Romano PS, Harvey D, et al. Licensed caregiver characteristics and staffing in California acute care hospital units. J Nurs Adm. Mar. 2004;34(3):125-33. [pmid: 15024239].
110 Unruh LY, Fottler MD. Patient turnover and nursing staff adequacy. Health Serv Res. Apr. 2006;41(2):599-612. [pmid: 16584467].
111 Bordoloi SK, Weatherby EJ. Managerial implications of calculating optimal nurse staffing in medical units. Aspens Advis Nurse Exec. Jul. 2000;15(10):1-12. [pmid: 11235456].
112 Urbanowicz JA. An evaluation of an acuity system as it applies to a cardiac catheterization laboratory. Comput Nurs. May–Jun. 1999;17(3):129-34. [pmid: 10341478].
113 Botter ML. The use of information generated by a patient classification system. J Nurs Adm. Nov. 2000;30(11):544-51. [pmid: 11098254].
114 Hall LM, Pink GH, Johnson LM, et al. Development of a nursing management practice atlas. Part 2, Variation in use of nursing and financial resources. J Nurs Adm. Sep. 2000;30(9):440-8. [pmid: 11006786].
115 Rozich JD, Resar RK. Using a unit assessment tool to optimize patient flow and staffing in a community hospital. Jt Comm J Qual Improv. Jan. 2002;28(1):31-41. [pmid: 11787238].
116 The Interagency Collaborative on Nursing Statistics. Nurses, Nursing Education, and Nursing Workforce: Definitions. December 2005. Available at: http://www.iconsdata.org/index.htm, 2006.
117 Silber JH, Williams SV, Krakauer H, et al. Hospital and patient characteristics associated with death after surgery. A study of adverse occurrence and failure to rescue. Med Care. Jul. 1992;30(7):615-29. [pmid: 1614231].
118 Higgins J, Green S. The Cochrane Collaboration. The Cochrane handbook for systematic reviews of interventions. John Wiley & Sons, Ltd. Cochrane Collaboration. Available at: http://www.cochrane.org/resources/handbook/handbook.pdf, 2006.
119 United States Agency for Healthcare Research and Quality; University of California SF-SE-BPC. Systems to Rate the Strength of Scientific Evidence: Rockville, MD; 2002.
120 Hamer S, Collinson G. Achieving evidence-based practice: a handbook for practitioners. Edinburgh: B. Tindall; 1999.
121 Dawson B, Trapp RG. Basic & Clinical Biostatistics (LANGE Basic Science). 3rd ed. New York: Lange Medical Books-McGraw-Hill; 2004.
122 Kahn HA, Sempos CT. Statistical Methods in Epidemiology (Monographs in Epidemiology and Biostatistics). USA: Oxford University Press; 1989.
123 Al-Marzouki S, Evans S, Marshall T, et al. Are these data real? Statistical methods for the detection of data fabrication in clinical trials. BMJ. July 30. 2005;331(7511):267-70. [pmid: 16052019]. [pmcid: 1181267].
124 Buyse M, George SL, Evans S, et al. The role of biostatistics in the prevention, detection and treatment of fraud in clinical trials. Statistics in Medicine. 1999;18(24):3435-51. [pmid: 10611617].
125 Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. Apr 19. 2000;283(15):2008-12. [pmid: 10789670].
126 Duval S, Tweedie R. Trim and fill: A simple funnel-plot-based method of testing and adjusting for publication bias in meta-analysis. Biometrics. Jun. 2000;56(2):455-63. [pmid: 10877304].
127 Vist GE, Hagen KB, Devereaux P, et al. Outcomes of patients who participate in randomised controlled trials compared to similar patients receiving similar interventions who do not participate. The Cochrane Database of Methodology Reviews, John Wiley & Sons, Ltd 2005;3.
128 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
129 American Nurses Association. Nurse Staffing and Patient Outcomes: In the Inpatient Hospital Setting. Washington DC: American Nurses Association; 2000.
130 Spetz J. Minimum nurse staffing ratios in California acute care hospitals. San Francisco: California Workforce Initiative; 2000.
131 Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med Feb 6 2006.
132 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
133 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. Sep 15. 2003;22(17):2693-710. [pmid: 12939780].
134 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London: NetLibrary, Inc. BMJ Books; 2001.
135 Peters JL, Sutton AJ, Jones DR, et al. Comparison of two methods to detect publication bias in meta-analysis. JAMA. Feb 8. 2006;295(6):676-80. [pmid: 16467236].
136 Littell RC, Milliken GA, Stroup WW, et al. SAS System for Mixed Models: SAS Publishing; 1996.
137 Hartemink N, Boshuizen HC, Nagelkerke NJD, et al. Combining Risk Estimates from Observational Studies with Different Exposure Cutpoints: A Meta-analysis on Body Mass Index and Diabetes Type 2. Am J Epidemiol. June 1. 2006;163(11):1042-52. [pmid: 16611666].
138 Kovner C, Jones CB, Gergen PJ. Nurse Staffing in Acute Care Hospitals,1990-1996. Policy, Politics, & Nursing Practice. 2000;1(3):194-204.
139 Blegen MA, Vaughn T. A multisite study of nurse staffing and patient occurrences. Nurs Econ. Jul–Aug. 1998;16(4):196-203. [pmid: 9748985].
140 Tourangeau AE, Giovannetti P, Tu JV, et al. Nursing-related determinants of 30-day mortality for hospitalized patients. Can J Nurs Res. Mar. 2002;33(4):71-88. [pmid: 11998198].
141 Thorson MJ. Hours of nursing care: Relationship to patient outcomes. [PhD]: Dissertation, University of North Carolina at Chapel Hill; 1995.
142 Kahn KL, Brook RH, Draper D, et al. Interpreting hospital mortality data. How can we proceed?. JAMA. Dec 23–30. 1988;260(24):3625-8. [pmid: 3057252].
143 Rosenthal GE, Baker DW, Norris DG, et al. Relationships between in-hospital and 30-day standardized hospital mortality: implications for profiling hospitals. Health Serv Res. Mar. 2000;34(7):1449-68. [pmid: 10737447]. [pmcid: 1975659].
144 United States Health Resources and Services Administration Division of Nursing. The registered nurse population. March 2000, findings from the National Sample Survey of Registered Nurses. Rockville, MD: U.S. Dept. of Health & Human Services, Public Health Service, Health Resources and Services Administration, Bureau of Health Professions, Division of Nursing; 2000.
145 Boyle SM. Nursing unit characteristics and patient outcomes. Nurs Econ May–Jun 2004;22(3):111–9, 23, 07.
146 Flood SD, Diers D. Nurse staffing, patient outcome and cost. Nurs Manage May 1988;19(5):34–5, 8–9, 42–3.
147 Fridkin SK, Pear SM, Williamson TH, et al. The role of understaffing in central venous catheter-associated bloodstream infections. Infect Control Hosp Epidemiol. Mar. 1996;17(3):150-8. [pmid: 8708352].
148 Centers for Disease Control (U.S.). WISQARS Injury Mortality Reports. 1999-2003. Dept. of Health & Human Services, Public Health Service, Centers for Disease Control. Available at: http://www.cdc.gov/ncipc/, 2006.
149 Gandjour A. The effect of managed care penetration on hospital staffing in Tennessee, 1991-1995. Manag Care Interface Sep 2000;13(9):62–6, 70.
150 Shultz Beckman JA. The effectiveness of nursing practice patterns in acute care nursing sub-units. [PhD]. Ann Arbor, MI, University of North Carolina at Chapel Hill; 2003.
151 Lichtig LK, Knauf RA, Milholland DK. Some impacts of nursing on acute care hospital outcomes. J Nurs Adm. Feb. 1999;29(2):25-33. [pmid: 10029799].
152 Upenieks VV. What constitutes effective leadership? Perceptions of magnet and nonmagnet nurse leaders. J Nurs Adm. Sep. 2003;33(9):456-67. [pmid: 14501562].
153 Blegen MA, Vaughn TE, Goode CJ. Nurse experience and education: effect on quality of care. J Nurs Adm. Jan. 2001;31(1):33-9. [pmid: 11198839].
154 Seago JA, Williamson A, Atwood C. Longitudinal analyses of nurse staffing and patient outcomes: more about failure to rescue. J Nurs Adm. Jan. 2006;36(1):13-21. [pmid: 16404195].
155 Langemo DK, Anderson J, Volden CM. Nursing quality outcome indicators. The North Dakota Study. J Nurs Adm. Feb. 2002;32(2):98-105. [pmid: 11984237].
156 Langemo DK, Anderson J, Volden C. Uncovering pressure ulcer incidence. Nurs Manage. Oct. 2003;34(10):54-7. [pmid: 14557784].
157 Kovner C, Gergen PJ. Nurse staffing levels and adverse events following surgery in U.S. hospitals. Image J Nurs Sch. 1998;30(4):315-21. [pmid: 9866290].
158 Kovner C, Jones C, Zhan C, et al. Nurse staffing and postsurgical adverse events: an analysis of administrative data from a sample of U.S. hospitals, 1990-1996. Health Serv Res. Jun. 2002;37(3):611-29. [pmid: 12132597]. [pmcid: 1434654].
159 Needleman J, Buerhaus PI, Mattke S, et al. Measuring hospital quality: can Medicare data substitute for all-payer data?. Health Serv Res. Dec. 2003;38(6 Pt 1):1487-508. [pmid: 14727784]. [pmcid: 1360960].
160 Aiken LH, Sloane DM, Sochalski J. Hospital organisation and outcomes. Qual Health Care. Dec. 1998;7(4):222-6. [pmid: 10339024].
161 Ridge RA. The relationship between patient satisfaction with nursing care and nurse staffing. [PhD]: Dissertation, University of Virginia; 2001.
162 Seago JA, Spetz J, Mitchell S. Nurse staffing and hospital ownership in California. J Nurs Adm. May. 2004;34(5):228-37. [pmid: 15167419].
163 Sochalski J. Is more better?: the relationship between nurse staffing and the quality of nursing care in hospitals. Med Care. Feb. 2004;42(2 Suppl):II67-73. [pmid: 14734944].
164 Vahey DC, Aiken LH, Sloane DM, et al. Nurse burnout and patient satisfaction. Med Care. Feb. 2004;42(2 Suppl):II57-66. [pmid: 14734943].
165 Barkell NP, Killinger KA, Schultz SD. The relationship between nurse staffing models and patient outcomes: a descriptive study. Outcomes Manag. Jan–Mar. 2002;6(1):27-33. [pmid: 12500413].
166 Seago JA. Evaluation of a hospital work redesign: patient-focused care. J Nurs Adm. Nov. 1999;29(11):31-8. [pmid: 10565318].
167 McGillis Hall L, Doran D, Baker GR, et al. Nurse staffing models as predictors of patient outcomes. Med Care. Sep. 2003;41(9):1096-109. [pmid: 12972849].
168 McGillis Hall L, Doran D, Pink GH. Nurse staffing models, nursing hours, and patient safety outcomes. J Nurs Adm. Jan. 2004;34(1):41-5. [pmid: 14737034].
169 Hall LM, Doran D. Nurse staffing, care delivery model, and patient care quality. J Nurs Care Qual. Jan–Mar. 2004;19(1):27-33. [pmid: 14717145].
170 Dunton N, Gajewski B, Taunton RL, et al. Nurse staffing and patient falls on acute care hospital units. Nurs Outlook. Jan–Feb. 2004;52(1):53-9. [pmid: 15014380].
171 Mark BA, Salyer J, Wan TT. Market, hospital, and nursing unit characteristics as predictors of nursing unit skill mix: a contextual analysis. J Nurs Adm. Nov. 2000;30(11):552-60. [pmid: 11098255].
172 Brewer CS, Frazier P. The influence of structure, staff type, and managed-care indicators on registered nurse staffing. J Nurs Adm. Sep. 1998;28(9):28-36. [pmid: 9745659].
173 Rogers AE, Hwang WT, Scott LD, et al. The working hours of hospital staff nurses and patient safety. Health Aff (Millwood). Jul–Aug. 2004;23(4):202-12. [pmid: 15318582].
174 Trinkoff A, Geiger-Brown J, Brady B, et al. How long and how much are nurses now working?. Am J Nurs. Apr. 2006;106(4):60-71. quiz 2. [pmid: 16575241].
175 Gold DR, Rogacz S, Bock N, et al. Rotating shift work, sleep, and accidents related to sleepiness in hospital nurses. Am J Public Health. Jul. 1992;82(7):1011-4. [pmid: 1609900]. [pmcid: 1694075].
176 Ruggiero JS. Correlates of fatigue in critical care nurses. Res Nurs Health. Dec. 2003;26(6):434-44. [pmid: 14689460].
177 Skipper JKJ, Jung FD, Coffey LC. Nurses and shiftwork: effects on physical health and mental depression. J Adv Nurs. Jul. 1990;15(7):835-42. [pmid: 2394892].
178 Hoffman AJ, Scott LD. Role stress and career satisfaction among registered nurses by work shift patterns. J Nurs Adm. Jun. 2003;33(6):337-42. [pmid: 12796631].
179 Hughes KK, Marcantonio RJ. Recruitment, retention, and compensation of agency and hospital nurses. J Nurs Adm. Oct. 1991;21(10):46-52. [pmid: 1919774].
180 Hughes KK, Marcantonio RJ. The clinical practice of supplemental nursing personnel. Nurs Adm Q. Spring. 1993;17(3):83-7. [pmid: 8502426].
181 Warren IB, Rozell BR. Supplemental staffing. Nurse manager views of costs, benefits, and quality of care. J Nurs Adm. Jun. 1995;25(6):51-7. [pmid: 7776008].
182 Strzalka A, Havens DS. Nursing care quality: comparison of unit-hired, hospital float pool, and agency nurses. J Nurs Care Qual. Jul. 1996;10(4):59-65. [pmid: 8783546].
183 Wetzel K, Soloshy DE, Gallagher DG. The work attitudes of full-time and part-time registered nurses. Health Care Manage Rev. Summer. 1990;15(3):79-85. [pmid: 2398005].
184 Burke RJ, Greenglass ER. Effects of hospital restructuring on full time and part time nursing staff in Ontario. Int J Nurs Stud. Apr. 2000;37(2):163-71. [pmid: 10684958].
185 Jolma DJ. Relationship between nursing work load and turnover. Nurs Econ. Mar–Apr. 1990;8(2):110-4. [pmid: 2330060].
186 Porter RT, Porter MJ. Career development: our professional responsibility. J Prof Nurs. Jul–Aug. 1991;7(4):208-12. [pmid: 1894840].
187 Havlovic SJ, Lau DC, Pinfield LT. Repercussions of work schedule congruence among full-time, part-time, and contingent nurses. Health Care Manage Rev. Fall. 2002;27(4):30-41. [pmid: 12433245].
188 Shader K, Broome ME, Broome CD, et al. Factors influencing satisfaction and anticipated turnover for nurses in an academic medical center. J Nurs Adm. Apr. 2001;31(4):210-6. [pmid: 11324334].
189 O'Brien-Pallas L, Shamian J, Thomson D, et al. Work-related disability in Canadian nurses. J Nurs Scholarsh. 2004;36(4):352-7. [pmid: 15636416].
190 Hartz AJ, Krakauer H, Kuhn EM, et al. Hospital characteristics and mortality rates. N Engl J Med. Dec 21. 1989;321(25):1720-5. [pmid: 2594031].
191 Krakauer H, Bailey RC, Skellan KJ, et al. Evaluation of the HCFA model for the analysis of mortality following hospitalization. Health Serv Res. 1992;27(3):317-35. [pmid: 1500289]. [pmcid: 1069881].
192 Simmonds KA. Nursing workload and its relationship to vancomycin-resistant enterococci colonization in chronic dialysis patients. [MSc]. Ottawa: Dissertation, University of Calgary; 2004.
193 Stratton KM. The relationship between pediatric nurse staffing and quality of care in the hospital setting. [PhD]. Denver: Dissertation, University of Colorado; 2005.
194 Grillo-Peck AM, Risner PB. The effect of a partnership model on quality and length of stay. Nurs Econ Nov–Dec 1995;13(6):367–72, 74.
195 Hoover KW. The impact of managed care penetration, hospital organizational variables and nurse staffing on hospital patient outcomes. [PhD]: Dissertation, Clinical Health Sciences, University of Mississippi Medical Center; 2000.
196 Shortell SM, Hughes EF. The effects of regulation, competition, and ownership on mortality rates among hospital inpatients. N Engl J Med. Apr 28. 1988;318(17):1100-7. [pmid: 3127713].
197 Melberg SE. Effects of changing skill mix. Nurs Manage. Nov. 1997;28(11):47-8. [pmid: 9385157].
198 Armstrong KJ, Laschinger H. Structural empowerment, Magnet hospital characteristics, and patient safety culture: making the link. J Nurs Care Qual. Apr–Jun. 2006;21:124-32. quiz 33–4. [pmid: 16540780].
199 Aiken LH, Havens DS, Sloane DM. The Magnet Nursing Services Recognition Program. Am J Nurs. Mar. 2000;100(3):26-35. quiz -6. [pmid: 10738398].
200 Bolton LB, Aydin CE, Donaldson N, et al. Nurse staffing and patient perceptions of nursing care. J Nurs Adm. Nov. 2003;33(11):607-14. [pmid: 14608220].
201 Leiter MP, Harvie P, Frizzell C. The correspondence of patient satisfaction and nurse burnout. Soc Sci Med. Nov. 1998;47(10):1611-7. [pmid: 9823056].
202 Kramer M, Schmalenberg C, Maguire P. Essentials of a magnetic work environment: part 3. Nursing. Aug. 2004;34(8):44-7.
203 Kramer M, Schmalenberg C. Revising the Essentials of Magnetism tool: there is more to adequate staffing than numbers. J Nurs Adm. Apr. 2005;35(4):188-98. [pmid: 15834258].
204 Spence Laschinger HK, Leiter MP. The impact of nursing work environments on patient safety outcomes: the mediating role of burnout/ engagement. J Nurs Adm. May. 2006;36(5):259-67. [pmid: 16705307].
205 Whitman GR, Davidson LJ, Sereika SM, et al. Staffing and pattern of mechanical restraint use across a multiple hospital system. Nurs Res. Nov–Dec. 2001;50(6):356-62. [pmid: 11725937].
206 Clarke SP. Research on nurse staffing and its outcomes: The challenges and risks of grasping at shadows. In: Nelson SG, S, ed. The complexities of care: nursing reconsidered. Ithaca, N.Y: ILR Press; 2006:161–84.
207 Adomat R, Hewison A. Assessing patient category/dependence systems for determining the nurse/patient ratio in ICU and HDU: a review of approaches. J Nurs Manag. Sep. 2004;12(5):299-308. [pmid: 15315485].
208 Calligaro KD, Miller P, Dougherty MJ, et al. Role of nursing personnel in implementing clinical pathways and decreasing hospital costs for major vascular surgery. J Vasc Nurs. Sep. 1996;14(3):57-61. [pmid: 9258016].
209 Discher CL, Klein D, Pierce L, et al. Heart failure disease management: impact on hospital care, length of stay, and reimbursement. Congest Heart Fail. Mar–Apr. 2003;9(2):77-83. [pmid: 12671338].
210 Pitt HA, Murray KP, Bowman HM, et al. Clinical pathway implementation improves outcomes for complex biliary surgery. Surgery. Oct. 1999;126(4):751-6. discussion 6–8. [pmid: 10520925].
211 Smith DM, Gow P. Towards excellence in quality patient care: a clinical pathway for myocardial infarction. J Qual Clin Pract. Jun. 1999;19(2):103-5. [pmid: 10408751].
212 Van Doren ES, Bowman J, Landstrom GL, et al. Structure and process variables affecting outcomes for heart failure clients. Lippincotts Case Manag. Jan–Feb. 2004;9(1):21-6. [pmid: 15076834].
213 Thomas EJ, Sexton JB, Neilands TB, et al. Correction: The effect of executive walk rounds on nurse safety climate attitudes: A randomized trial of clinical units [ISRCTN85147255]. BMC Health Serv Res. Jun 10. 2005;5(1):46. [pmid: 15949037].
214 Thomas EJ, Sexton JB, Neilands TB, et al. The effect of executive walk rounds on nurse safety climate attitudes: a randomized trial of clinical units [ISRCTN85147255] [corrected]. BMC Health Serv Res. Apr 11. 2005;5(1):28. [pmid: 15823204]. [pmcid: 1097728].
215 Cronin-Stubbs D, Swanson B, Dean-Baar S, et al. The effects of a training program on nurses' functional performance assessments. Appl Nurs Res. Feb. 1992;5(1):38-43. [pmid: 1570959].
216 Daghistani D, Horn M, Rodriguez Z, et al. Prevention of indwelling central venous catheter sepsis. Med Pediatr Oncol. Jun. 1996;26(6):405-8. [pmid: 8614377].
217 Danchaivijitr S, Suthisanon L, Jitreecheue L, et al. Effects of education on the prevention of pressure sores. J Med Assoc Thai. Jul. 1995;78(Suppl 1):S1-6. [pmid: 7666018].
218 Ferguson TBJ. Continuous quality improvement in medicine: validation of a potential role for medical specialty societies. Am Heart Hosp J. Fall. 2003;1(4):264-72. [pmid: 15815120].
219 Garcia de Lucio L, Garcia Lopez FJ, Marin Lopez MT, et al. Training programme in techniques of self-control and communication skills to improve nurses' relationships with relatives of seriously ill patients: a randomized controlled study. J Adv Nurs. Aug. 2000;32(2):425-31. [pmid: 10964191].
220 Griffiths P. Clinical outcomes for nurse-led in-patient care. Nurs Times. Feb 28–Mar 5. 1996;92(9):40-3. [pmid: 8700737].
221 Jerant AF, Azari R, Martinez C, et al. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Serv Q. 2003;22(1):1-20. [pmid: 12749524].
222 Tranmer JE, Lochhaus-Gerlach J, Lam M. The effect of staff nurse participation in a clinical nursing research project on attitude towards, access to, support of and use of research in the acute care setting. Can J Nurs Leadersh. Jan–Feb. 2002;15(1):18-26. [pmid: 11908539].
223 Tsai SL, Tsai WW, Chai SK, et al. Evaluation of computer-assisted multimedia instruction in intravenous injection. Int J Nurs Stud. Feb. 2004;41(2):191-8. [pmid: 14725783].
224 Zeler KM, McPharlane TJ, Salamonsen RF. Effectiveness of nursing involvement in bedside monitoring and control of coagulation status after cardiac surgery. Am J Crit Care. Sep. 1992;1(2):70-5. [pmid: 1307893].
225 Spetz J. Public policy and nurse staffing: what approach is best?. J Nurs Adm. Jan. 2005;35(1):14-6. [pmid: 15647662].
226 White KM. Policy spotlight: staffing plans and ratios. Nurs Manage Apr 2006;37(4):18–22, 4.
227 Rainio AK, Ohinmaa AE. Assessment of nursing management and utilization of nursing resources with the RAFAELA patient classification system—case study from the general wards of one central hospital. J Clin Nurs. Jul. 2005;14(6):674-84. [pmid: 15946275].
228 DeGroot HA. Patient classification systems and staffing. Part 2, Practice and process. J Nurs Adm. Oct. 1994;24(10):17-23. [pmid: 7931682].
229 Dunbar LJ, Diehl BC. Developing a patient classification system for the pediatric rehabilitation setting. Rehabil Nurs. Nov–Dec. 1995;20(6):328-32. [pmid: 7494947].
230 Phillips CY, Castorr A, Prescott PA, et al. Nursing intensity. Going beyond patient classification. J Nurs Adm. Apr. 1992;22(4):46-52. [pmid: 1560277].