# Acknowledgments

We would like to thank David Jacobs, Ph.D., for his contribution to conceptualization and methodology of meta-analysis; the librarians Jim Beattie, MLIS, Lisa McGuire, MLIS, Judy Stanke, M.A., and Delbert Reed, Ph.D., for their contributions to the literature search; Kim Belzberg, R.N., B.S.N., and John Nelson, M.S., R.N., for assistance with the literature search and data abstraction; and Marilyn Eells for editing and formatting this report. We would also like to thank Mary Blegen, Ph.D., R.N., F.A.A.N., and Barbara Mark, Ph.D., R.N., F.A.A.N., for their cooperation in sharing their raw data.

We also want to thank Mary Blegen, Ph.D., M.A., B.S.N., R.N.; Peter Buerhaus, Ph.D., R.N., M.S., F.A.A.N.; Sean Clarke, Ph.D., M.S., B.A., B.S., C.R.N..P, R.N.; Linda McGillis-Hall, Ph.D., M.Sc., B.A.S., R.N.; and Linda O'Brien-Pallas, Ph.D., M.Sc.N., B.Sc.N., R.N., for reviewing the draft of this report and providing us with helpful recommendations for revisions and clarifications.