# Discussion

## Association or Cause

The present review and meta-analysis confirm previous contentions that increased nurse staffing in hospitals is associated with better care outcomes.^27,^ ^51,^ ^93^ A persistent question is whether this association reflects a causal relationship. One test of such a causal relationship should be that higher staffing levels should produce stronger effects for nurse sensitive outcomes than for more general outcomes. The evidence across 14 studies consistently suggests that the risk of hospital related mortality was 9 percent lower in ICUs, 6 percent lower for medical patients, and 16 percent lower for surgical patients for each additional RN FTE per patient day (Figure 27). The risk of nurse-sensitive patient outcomes was comparable with those for mortality independent of study design. The relative risk of failure to rescue was reduced by 16 percent in surgical patients and hospital-acquired pneumonia by 30 percent in ICUs, rates substantially higher than those for mortality.

Figure 27. Relative risk of outcomes corresponding to an increase by RN FTE/patient day consistent across the studies

Another test would be the difference in effect size between longitudinal and cross-sectional designs. The former should more directly reflect the effects of changing staffing patterns by holding more constant other hospital variables. Studies that attempted to assess temporality in the association between nurse staffing and failure to rescue had a lower relative risk per RN FTE per patient day ratio (RR 0.84, 95 percent CI 0.75–0.93) than did those using cross-sectional designs (RR 0.92, 95 percent CI 0.91–0.93), supporting the presence of an association rather than a cause.

We also examined the role of the study characteristics on the association between nurse ratios and patient outcomes. We tested the following study characteristics that could modify the association between nurse ratios and patient outcomes: quality scores, assessment of temporality in the association, analytic units, hospital units, patient populations, the adjustment for patient comorbidities, provider characteristic, and clustering of patients and hospitals. The authors adjusted for patient comorbidities at patient and hospital levels and for provider characteristics including hospital teaching and profit status, size and volume, technology index, HMO penetration, and staffing. We examined the association of four aspects of nurse ratios (total, RN, LPN/LVN, UAP) licensed and the same four for nursing hours with 16 outcomes expressed as rates and 19 expressed as relative risks for a total of 280 (eight effect modifiers times 35 outcomes). Only a small proportion of tested models showed a significant influence of study design on the association with nurse staffing and patient outcomes (Appendix G *,Table G30). Among the possible interactions, only the LPN effects were significant more the 30 percent of the time. The proportion of significant interactions was considerably lower for relative risks.

* Appendixes and Evidence Tables for this report are provided electronically at http://www.ahrq.gov/clinic/tp/nursesttp.htm

Hospitals that invest in more nurses may also invest in other actions that improve quality. Empirical evidence suggests that magnet hospitals provide high quality care and report better patient outcomes in relation to nurse staffing.^10,^ ^52,^ ^57,^ ^198,^ ^199^

Several lines of evidence suggest that overall hospital commitment to a high quality of care in combination with effective nurse retention strategies leads to better patient outcomes, patient satisfaction with overall and nursing care, and nurse satisfaction with job and provided care.^10,^ ^52^–^54,^ ^57^–^59^ Hospital volume,^20^ physician practice patterns, and collaboration with nurses^8,^ ^9^ may affect patient outcomes. Professional practice environments in hospitals, which enable nurses to control their practice through governance also contribute to nurses' job satisfaction and positive perceptions of nurse autonomy. These factors are associated with nurse retention and better patient outcomes in several reports.^15,^ ^21,^ ^78,^ ^152,^ ^161,^ ^164,^ ^165,^ ^200,^ ^201^ Hospitals with better professional nurse practice environment had improved RN staffing ratios.^55,^ ^56^ Magnet hospitals had lower patients per RN ratios, better nurse manager ability and support, and collegial nurse-physician relations.^53^–^57,^ ^152,^ ^202,^ ^203^ The quality of the nurse professional practice work environment correlated with patient safety outcomes in several studies.^15,^ ^21,^ ^66,^ ^164,^ ^201,^ ^204^

The outcomes of hospital care are the result of many factors. The studies reviewed here did not, and perhaps could not, address many salient issues. Patient outcomes are affected by patient characteristics. Case mix, when addressed, was usually handled as a mean number averaged across all patients in a unit or hospital. Such averages can hide a lot of different mixtures. Detailed information on comorbidities and disease severity was not included. Likewise, the nature of core medical treatments was not addressed. The absence of these measures can have varied effects depending on whether one believes they represent noise or bias. Case mix differences may hide areas where nurse staffing makes a bigger difference if it is not associated directly with staffing levels, but if it is, it could lead to bias. Such bias should result from more staff going to patients who need more care and hence would decrease the effects seen. These studies best approximate that correction by examining different types of units, which serve patients in varying levels of severity.

The absence of information on medical care is another important shortcoming of these studies, although it would greatly complicate the study designs. Here too, bias needs to be separated from noise. There is no strong basis to assume that the quality of medical care is necessarily correlated with the level of staffing, but it seems unlikely that it would be inversely correlated. With that assumption, any bias would result from hospitals that invested in more staffing also pressing for better medical care, an assumption that seems feasible.

## Marginal Effects

Previous systematic reviews did not estimate the effect size of different nurse staffing measures.^92,^ ^93^ Associations were considered to be clinically important when a 10 percent difference in staffing levels was associated with significant changes in outcomes.^92^ When attempting to find optimal nurse staffing ratio and hours, the effect size could not be estimated reliably because of differences in the studies and possible curvilinear associations.^93^ One study^26^ examined the overall linear trend in adverse events corresponding to a one unit increase in nurse staffing and differences in the rates of patient outcomes among the lowest and highest quartiles of the nurse staffing distribution to find an optimal staffing pattern.^26^

Hospital mortality shows a decline with increasing staffing, but the decline is not linear. The risk increases quickly as the patients per RN per shift ratio rises above four to five. The mean increase of 7 percent for each additional patient per RN per shift can be misleading; the goodness of fit of the linear slope varied across the distribution of nurse to patient ratio. The effect size of this nonlinear association was tested to detect the overall trend and relative and absolute changes in patient outcomes among nurse staffing categories using quartiles of the distribution. Comparing the lowest with the highest quartiles of patients per RN per shift ratio, the observed risk of mortality was 61 percent compared to expected 85 percent (1.61 observed vs. 1.85 expected) if the slope was applied to the differences in the ratio. Moreover, we would expect the risk of mortality to be 19 percent lower when the workload of patients per RN per shift decreased from four to two patients, but in fact it was only 6 percent lower.

We used several ways to analyze strengths and limitations of the individual studies. Applicability of the study was estimated according to a sampling of eligible hospitals and patients with the highest applicability in studies with random population based sampling and random hospital-based sampling and the lowest in the studies with convenient and self-selected sampling. We analyzed the internal validity of the studies by the validation of measured nurse staffing, patient outcomes, and all confounding factors the authors reported. We graded the adjustment for patient characteristics (age, race, comorbidities, socioeconomic status), provider characteristics, and clustering of patients and clinics. We included summarized quality scores and the fact of adjustment for the each of confiding factors in the meta-regression and sensitivity analysis. We compared the direction and the strength of the association from the studies that used different definitions of nurse staffing and patient outcomes (rates and relative risk). We compared the direction and the strength of the association from the studies at patient level analysis that could carefully adjust for patient and nurses characteristics (better internal validity but lower applicability) and large multi-centers studies obtained hospital averages from administrative databases (low internal validity but better applicability). To examine statistically the influence of study quality on tested associations we compared pooled estimates weighted by the sample size and weighted by the quality of the studies and did not detect substantial differences.

Geographical variations in nurse distributions^144^ and rates of fatal adverse events^148^ may impact the effect size of nurse staffing on patient outcomes. Few multi-hospital studies used random effects models to incorporate geographical differences in the estimation;^33,^ ^49,^ ^94^ 37 percent of the included studies reported random sampling and assessments of sampling bias. We compared means of nurse staffing in the studies we included in the meta-analysis with published means^26^ and did not detect substantial differences. However, the report of the Institute of Medicine^74^ suggested that a larger proportion of hospitals have poorer nurse staffing than published in scientific research. Therefore, the effect size of nurse staffing on patient outcomes from the present report can be generalized only to hospitals with similar nurse staffing patterns.

## Nurse Staffing and Patient Outcomes in Hospitals

The majority of the studies found that hospitals with more RNs working with patients had a lower level of patient adverse events related to health care. If these associations were causal, Table 21 estimates the effect size in terms of the number of patient adverse events that could be avoided by adding 8 RN hours a patient receives during 24 hours in a hospital. Table 22 shows the proportion of patient adverse events that could theoretically be avoided by reducing the number of patients assigned to an RN during an 8-hour shift.

Table 21 The number of patient adverse events that could be avoided by additional 8 RN hours a patient receives during 24 hours in a hospital

Patients' Condition Related to Health Care, Not to a Primary Diagnosis | Number of Avoided Events/1,000 Hospitalized Patients (95% CI)
All patients
Mortality, overall | 9 (6–12)
Mortality, hospital level analysis | 3 (2–4)
Mortality, medical patients | 5 (4–5)
Hospital acquired pneumonia | 5 (1–8)
Failure to rescue | 24 (14–34)
CPR | 2 (1–2)
ICUs
Mortality | 5 (2–8)
Hospital acquired pneumonia | 7 (3–10)
Pulmonary failure | 7 (5–9)
Unplanned extubation | 6 (4–8)
CPR | 2 (1–2)
Nosocomial Infection | 10 (6–13)
Surgical patients
Mortality | 6 (4–8)
Failure to rescue | 26 (17–35)
Surgical wound infection | 7 (1–8)
CPR | 1 (1–2)

Table 22 The proportion of patient adverse events (%) that could be avoided by reducing the number of patients assigned to an RN during an 8-hour shift

Patients' Conditions Related to Health Care, Not to a Primary Diagnosis | Number of Patients Assigned to 1 RN During a Shift | Percentage of Patient Adverse Events that Could be Avoided by Reducing the Number of Patients per RN (95% CI)
ICUs
Mortality | <3 vs. 3–4 | 5.6 (3.4; 7.7)
Sepsis | <1.6 vs. 3.3 | 42.7 (8.8; 64.0)
Sepsis | 1 vs. 3.3 | 42.2 (6.0; 64.4)
CPR | <1.6 vs. 3.3 | 34.4 (26.7; 41.4)
CPR | 1 vs. 3.3 | 46.3 (39.2; 52.6)
CPR | 1 vs. >4 | 25.4 (16.7; 33.2)
Medical complications | <1.6 vs. 3.3 | 40.8 (28.6; 50.9)
Medical complications | 1 vs. 3.3 | 46.1 (33.6; 56.3)
Medical complications | 1 vs. >4 | 25.4 (10.1; 38.1)
Pulmonary failure | <1.6 vs. 3.3 | 60.0 (30.9; 76.9)
Pulmonary failure | <1.6 vs. 3 | 63.7 (31.3; 80.8)
Pulmonary failure | 1 vs. >4 | 57.1 (13.8; 78.6)
Unplanned extubation | <1.6 vs. 3.3 | 44.8 (22.2; 60.9)
Unplanned extubation | <1.6 vs. 3 | 68.0 (49.2; 79.8)
Unplanned extubation | 1 vs. 3 | 56.9 (38.2; 69.9)
Unplanned extubation | 3.3 vs. >4 | 42.0 (20.2; 57.9)
Surgical patients
Mortality | ≤2 vs. 4–6 | 24.3 (17.9; 30.3)
Mortality | ≤2 vs. >6 | 38.4 (34.1; 42.4)
Mortality | 2–3.5 vs. 4–6 | 19.8 (13.3;25.9)
Mortality | 2–3.5 vs. >6 | 34.7 (30.4; 38.7)
Mortality | 4–6 vs. >6 | 18.6 (11.8; 24.8)
Hospital acquired pneumonia | 4 vs. >5 | 24.6 (5.2; 40.0)
Nosocomial infection | <2 vs. 3 | 93.6 (65.7; 98.8)
Surgical wound infection | 4 vs. >5 | 20.4 (6.5; 32.3)
Sepsis | <2 vs. 3 | 44.4 (16.4; 63.0)
Sepsis | <2 vs. >5 | 49.4 (8.8; 71.9)
Sepsis | 4 vs. >5 | 28.5 (6.6; 45.3)
CPR | <2 vs. 3 | 30.8 (13.1; 44.9)
CPR | <2 vs. 4 | 25.4 (5.0; 41.4)
Failure to rescue | <2 vs. 4 | 25.5 (17.1; 33.0)
Failure to rescue | <2 vs. >5 | 39.1 (33.6; 44.2)
Failure to rescue | 3 vs. 4 | 20.6 (12.2; 28.3)
Failure to rescue | 3 vs. >5 | 35.2 (29.7; 40.2)
Failure to rescue | 4 vs. >5 | 18.3 (9.1; 26.6)
Pulmonary failure | <2 vs. 3 | 61.9 (28.2; 79.7)
Pulmonary failure | <2 vs. 4 | 75.1 (45.4; 88.6)
Unplanned extubation | <2 vs. 3 | 44.3 (18.4; 62.0)
Unplanned extubation | <2 vs. 4 | 71.5 (53.8; 82.4)
Unplanned extubation | 3 vs. 4 | 48.7 (30.6; 62.1)

## Staffing Measures

Two general measures of nurse staffing were studied. One looks superficially at hours of care provided by different types of nursing staff averaging FTEs of different nurse categories at the hospital level,^11,^ ^18,^ ^19^ including only productive hours worked in direct care.^28,^ ^61,^ ^62^ The other relies on a less precise ratio of total nurse staffing to patient volume derived from administrative databases^63^–^65^ averaging annual nurse-to patient ratios^20^ at the hospital or unit level. The patients per RN per shift ratio was more frequently used and provided greater evidence of the effect, but both showed generally the same trends. Inconsistency in nurse staffing operational definitions and methods to measure with an unknown “gold standard” to assess staffing patterns at the patient levels may bias the results of the studies and consequently, pooled analysis.^206^ Because many of the studies of nurse staffing were based on administrative data, they expressed staffing levels in terms of RN FTEs per patient or similar measures. However, the individuals charged with actually managing staffing are more likely to think in terms of patients per nurse. A simple, back-of-the-envelope transformation would be that 1 RN FTE per patient day would translate to 8 RN hours per patient day or three patients per RN per shift. If the average is 7.8 RN hours per patient day (~3 patients per RN per shift), then increasing staffing by 1 RN FTE per patient day would mean a decrease to 1.5 patients per nurse.

The effect size varied depending on the nurse staffing measure. The reduction in relative risk of hospital related mortality is 16 percent for 1 RN FTE per patient day and 1 percent for an additional RN hour per patient day in surgical patients. Assuming that every additional RN per FTE patient day would provide approximately 8 additional RN hours per patient day, the expected reduction should be more than observed in the studies that examined the risk of mortality in relation to nurse hours (Table 23). The comparison of the effect size on patient outcomes among quartiles of the RN FTE per patient day ratio and nurse hours per patient day detected the same pattern (Table 24); the maximal reduction in relative risk of hospital-related mortality and adverse events occurred when no more than two patients were assigned to an RN in ICUs and in surgical units, and more than 11 nurse hours were spent per one patient day in ICUs and more than 7–8 hours in surgical and medical patients. We did not find consistent evidence that a further increase in RN FTE per patient day ratio can provide better patient safety. Confirming the previous observations,^29,^ ^93,^ ^139^ we detected a curvilinear association between the RN FTE per patient day ratio and hospital related mortality, nosocomial and bloodstream infections, and hospital acquired pneumonia with the optimal association at 2–2.5 patients per RN per shift in ICUs and surgical patients.

Table 23 Relative risk of mortality and nurse sensitive patient outcomes corresponding to one unit increase in nurse staffing ratios and hours (pooled estimates)

Outcome | N | Increment | RR | 95% CI | N | Increment | RR | 95% CI
Mortality | 14 | 1 RN FTE/patient day | 0.92 | 0.90; 0.94 | 1 | 1 nurse hour/patient day
| 4 | 1 patient/LPN/shift | 0.99 | 0.99; 1 | 7* | 1 RN hour/patient day | 1.00 | 0.90; 1.12
| 1 | 1 patient/UAP/shift | 0.99 | 0.99; 1.07 | 3 | 1 LPN hour/patient day | 0.88 | 0.12; 6.47
| | 1 patient/licensed nurse | | | 1 | 1 UAP hour/patient day
| | | | | 1 | 1 licensed hour/patient day
Length of stay | 5 | 1 RN FTE/patient day | 0.92 | 0.80; 1.05 | 4* | 1 nurse hour/patient day
| 1 | 1 patient/LPN/shift | 0.98 | 0.97; 0.99 | 3 | 1 RN hour/patient day | 1.00 | 0.41; 2.42
| | 1 patient/UAP/shift | | | 2 | 1 LPN hour/patient day
| | 1 patient/licensed nurse | | | 1 | 1 UAP hour/patient day
| | | | | 2 | 1 licensed hour/patient day
Patient falls, injuries | 1 | 1 RN FTE/patient day | | | 2 | 1 nurse hour/patient day
| 1 | 1 patient/LPN/shift | | | 1 | 1 RN hour/patient day
| | 1 patient/UAP/shift | | | | 1 LPN hour/patient day
| 1 | 1 patient/licensed nurse | | | | 1 UAP hour/patient day
| | | | | | 1 licensed hour/patient day
Pressure ulcers | | 1 RN FTE/patient day | | | 4 | 1 nurse hour/patient day
| | 1 patient/LPN/shift | | | 1 | 1 RN hour/patient day
| | 1 patient/UAP/shift | | | 1 | 1 LPN hour/patient day
| 1 | 1 patient/licensed nurse | | | 1 | 1 UAP hour/patient day
| | | | | 1 | 1 licensed hour/patient day
Nosocomial infection rate | 3 | 1 RN FTE/patient day | 0.88 | 0.73; 1.06 | 5* | 1 nurse hour/patient day | 0.88 | 0.84; 0.92
| | 1 patient/LPN/shift | | | 2* | 1 RN hour/patient day | 0.76 | 1.05; 0.68
| 1 | 1 patient/UAP/shift | | | 1 | 1 LPN hour/patient day
| | 1 patient/licensed nurse | | | 1 | 1 UAP hour/patient day
| | | | | 2 | 1 licensed hour/patient day
Failure to rescue | 6 | 1 RN FTE/patient day | 0.91 | 0.89; 0.94 | 1 | 1 nurse hour/patient day
| | 1 patient/LPN/shift | | | 3 | 1 RN hour/patient day
| | 1 patient/UAP/shift | | | 1 | 1 LPN hour/patient day
| | 1 patient/licensed nurse | | | 1 | 1 UAP hour/patient day
| | | | | 2 | 1 licensed hour/patient day
Urinary tract infection rate | 2 | 1 RN FTE/patient day | 1.02 | 0.94; 1.11 | 5 | 1 nurse hour/patient day
| 1 | 1 patient/LPN/shift | 0.96 | 0.94; 0.99 | 6 | 1 RN hour/patient day | 1.00 | 0.64; 1.56
| | 1 patient/UAP/shift | | | 4 | 1 LPN hour/patient day | 1.04 | 0.17; 6.26
| 1 | 1 patient/licensed nurse | | | 1 | 1 UAP hour/patient day
| | | | | 2 | 1 licensed hour/patient day
Surgical bleeding | 1 | 1 RN FTE/patient day | 1.02 | 0.78; 1.34 | 4 | 1 nurse hour/patient day
| | 1 patient/LPN/shift | | | 2 | 1 RN hour/patient day | 1.00 | 0.95; 1.05
| | 1 patient/UAP/shift | | | 1 | 1 LPN hour/patient day | 0.93 | 0.00; 233.29
| | 1 patient/licensed nurse | | | 1 | 1 UAP hour/patient day
| | | | | 2 | 1 licensed hour/patient day
Upper gastrointestinal bleeding | | 1 RN FTE/patient day | | | 1 | 1 nurse hour/patient day
| | 1 patient/LPN/shift | | | 3 | 1 RN hour/patient day
| | 1 patient/UAP/shift | | | 1 | 1 LPN hour/patient day
| | 1 patient/licensed nurse | | | 1 | 1 UAP hour/patient day
| | | | | 2 | 1 licensed hour/patient day
Post surgical thrombosis | 1 | 1 RN FTE/patient day | | | 2 | 1 nurse hour/patient day
| | 1 patient/LPN/shift | | | 1 | 1 RN hour/patient day
| | 1 patient/UAP/shift | | | 2 | 1 LPN hour/patient day
| | 1 patient/licensed nurse | | | 1 | 1 UAP hour/patient day
| | | | | 1 | 1 licensed hour/patient day
Atelectasis and pulmonary failure | 5 | 1 RN FTE/patient day | 0.94 | 0.93; 0.94 | 2 | 1 nurse hour/patient day
| 1 | 1 patient/LPN/shift | | | 2 | 1 RN hour/patient day | 1.08 | 0.85; 1.37
| | 1 patient/UAP/shift | | | 2 | 1 LPN hour/patient day
| 1 | 1 patient/licensed nurse | | | 1 | 1 UAP hour/patient day
| | | | | 1 | 1 licensed hour/patient day
Accidental extubation | 5 | 1 RN FTE/patient day | 0.49 | 0.36; 0.67 | | 1 nurse hour/patient day
| | 1 patient/LPN/shift | | | | 1 RN hour/patient day
| | 1 patient/UAP/shift | | | | 1 LPN hour/patient day
| | 1 patient/licensed nurse | | | | 1 UAP hour/patient day
| | | | | | 1 licensed hour/patient day
Hospital acquired pneumonia | 4 | 1 RN FTE/patient day | 0.81 | 0.67; 0.98 | 5 | 1 nurse hour/patient day
| 2 | 1 patient/LPN/shift | | | 4 | 1 RN hour/patient day
| | 1 patient/UAP/shift | | | 3 | 1 LPN hour/patient day
| 1 | 1 patient/licensed nurse | | | | 1 UAP hour/patient day
| | | | | 2 | 1 licensed hour/patient day
Postoperative infection | 1 | 1 RN FTE/patient day | 1.01 | 0.70; 1.45 | 4 | 1 nurse hour/patient day | 1.00 | 0.99; 1.01
| 1 | 1 patient/LPN/shift | | | 2 | 1 RN hour/patient day | 1.00 | 0.95; 1.05
| | 1 patient/UAP/shift | | | 1 | 1 LPN hour/patient day | 0.93 | 0.00; 233.29
| | 1 patient/licensed nurse | | | 1 | 1 UAP hour/patient day
| | | | | 2 | 1 licensed hour/patient day
Cardiac arrest/shock | 3 | 1 RN FTE/patient day | 0.72 | 0.62; 0.84 | | 1 nurse hour/patient day
| | 1 patient/LPN/shift | | | | 1 RN hour/patient day
| | 1 patient/UAP/shift | | | | 1 LPN hour/patient day
| | 1 patient/licensed nurse | | | | 1 UAP hour/patient day
| | | | | 1 | 1 licensed hour/patient day
Complications (medical) | 3 | 1 RN FTE/patient day | 0.72 | 0.60; 0.86 | 2 | 1 nurse hour/patient day
| | 1 patient/LPN/shift | | | | 1 RN hour/patient day
| | 1 patient/UAP/shift | | | | 1 LPN hour/patient day
| | 1 patient/licensed nurse | | | | 1 UAP hour/patient day
| | | | | 1 | 1 licensed hour/patient day

* significant heterogeneity between studies

Table 24 Consistent across the studies, significant association between nurse staffing and patient outcomes (results from pooled analysis), attributable to nurse staffing proportion of events, and number of avoided events per 1,000 hospitalized patients

Outcome | Nurse Staffing | Studies | RR | 95% CI | Attributable to Nurse Staffing Fraction, % | 95%CI | Number of Avoided (excessive) Events/1,000 Hospitalized | 95%CI
All Patients
Mortality | Increase by 1 patient/RN/shift | 6 | 1.08 | 1.08; 1.09 | 7.56 | 7.07; 8.04 | 5 | 4; 5
Mortality, hospital level analysis | Increase by 1 RN FTE/patient day | 5 | 0.96 | 0.94; 0.98 | 4.2 | 6; 2.4 | 3 | 2; 4
Mortality, ICUs | Increase by 1 RN FTE/patient day | 5 | 0.91 | 0.86; 0.96 | 9.2 | 14.4; 3.7 | 5 | 2; 8
Mortality, surgical patients | Increase by 1 RN FTE/patient day | 8 | 0.84 | 0.8; 0.89 | 16 | 20.2; 11.5 | 6 | 4; 8
Mortality, medical patients | Increase by 1 RN FTE/patient day | 6 | 0.94 | 0.94; 0.95 | 5.6 | 6.3; 4.8 | 5 | 4; 5
Mortality, ICUs | Increase by 1 RN hour/patient day | 5 | 0.99 | 0.99; 0.99 | 0.5 | 0.7; 0.3 | 0 | 0.2; 0
Mortality, surgical patients | Increase by 1 RN hour/patient day | 9 | 0.99 | 0.98; 1 | 1.4 | 2.5; 0.3 | 1 | 0; 1
Mortality, medical patients | Increase by 1 RN hour/patient day | 10 | 0.99 | 0.99; 1 | 0.7 | 0.8; 0.5 | 1 | 0; 1
Hospital acquired pneumonia | Increase by 1 patient/RN/shift | 3 | 1.07 | 1.03; 1.11 | 6.5 | 2.9; 9.9 | 2 | 1; 3
Failure to rescue | Increase by 1 patient/RN/shift | 3 | 1.08 | 1.07; 1.09 | 7.4 | 6.5; 8.3 | 12 | 11; 13
Pulmonary failure | Increase by 1 patient/RN/shift | 4 | 1.53 | 1.24; 1.89 | 34.6 | 19.4; 47.1 | 6 | 3; 10
Unplanned extubation | Increase by 1 patient/RN/shift | 5 | 1.45 | 1.27; 1.67 | 31.0 | 21.3; 40.1 | 5 | 3; 8
CPR | Increase by 1 patient/RN/shift | 3 | 1.16 | 1.05; 1.29 | 13.8 | 4.8; 22.5 | 1 | 1; 2
Medical complications | Increase by 1 patient/RN/shift | 3 | 1.17 | 1.04; 1.31 | 14.5 | 3.8; 23.7 | 37 | 9; 64
Hospital acquired pneumonia | Increase by 1 RN FTE/patient day | 4 | 0.81 | 0.67; 0.98 | 19.1 | 33.1; 2.1 | 1 | 0; 2
Pulmonary failure | Increase by 1 RN FTE/patient day | 5 | 0.94 | 0.94; 0.94 | 6 | 6.4; 5.6 | 1 | 1; 1
CPR | Increase by 1 RN FTE/patient day | 5 | 0.72 | 0.62; 0.84 | 27.6 | 37.9; 15.6 | 2 | 1; 2
ICUs
Hospital acquired pneumonia | Increase by 1 RN FTE/patient day | 3 | 0.7 | 0.56; 0.88 | 30.2 | 44.3; 12.4 | 7 | 3; 10
Pulmonary failure | Increase by 1 RN FTE/patient day | 4 | 0.4 | 0.27; 0.59 | 60.3 | 73.4; 40.6 | 7 | 5; 9
Unplanned extubation | Increase by 1 RN FTE/patient day | 5 | 0.49 | 0.36; 0.67 | 50.9 | 63.7; 33.5 | 6 | 4; 8
CPR | Increase by 1 RN FTE/patient day | 3 | 0.72 | 0.62; 0.84 | 27.6 | 37.9; 15.6 | 2 | 1; 2
Nosocomial Infection | Increase by 1 hour in total nurse hours/patient day | 3 | 0.87 | 0.82; 0.92 | 12.9 | 17.6; 8 | 10 | 6; 13
Relative change in LOS | Increase by 1 RN FTE/patient day | 4 | 0.76 | 0.62; 0.94 | 24 | 38; 6 | 7 | 2; 11
Surgical patients
Failure to rescue | Increase by 1 RN FTE/patient day | 5 | 0.84 | 0.79; 0.9 | 16 | 21.4; 10.3 | 26 | 17; 35
Surgical wound infection | Increase by 1 RN FTE/patient day | 1 | 0.15 | 0.03; 0.82 | 84.5 | 97.1; 18.1 | 7 | 1; 8
Sepsis | Increase by 1 RN FTE/patient day | 5 | 0.64 | 0.46; 0.89 | 36 | 54; 11 | 4 | 2; 6
Relative change in LOS | Increase by 1 RN FTE/patient day | 3 | 0.69 | 0.55; 0.86 | 31 | 45; 14 | 14 | 6; 21

The association between patient outcomes and different definitions of nurse staffing suggest several reasons why nurse hours do not always provide a valid estimation of nurse-to-patient ratios. Nurse hours per patient day reflect average staffing across a 24-hour period and do not reflect fluctuations in patient census, scheduling patterns during different shifts,^9,^ ^13^ and periods of the year.^66,^ ^67^ They do not account for the time nurses spend in meetings, educational activities, and administrative work. Therefore, “productive hours per patient day” may underestimate nurse staffing levels when a large proportion of worked hours was not spent on direct patient care.^60,^ ^109^ These reasons may help to explain why the effect size varied across nurse staffing measures.

The majority of studies reviewed in this report focused on registered nurses working in acute care hospital settings. Evidence on the association between LPN/LVN and UAP personnel is limited and controversial. The authors designed the studies to evaluate the effect of nurse staffing on patient outcomes sensitive to RN rather LPN/LVN and UAP work. Skill mix may not directly reflect the hospital' commitment to quality of care and financial strategies. Future research should address the role of skill mix and the contributions of LPNs/LVNs, and UAPs on quality of care.

## Care Setting

Nurse staffing had a different effect in different care settings. The addition of one unit of nursing care may vary depending on the baseline rate. For example, ICUs have higher staffing levels than typical hospital units. The effect of an additional nurse hour might be quite dissimilar in that context. We evaluated differences in the association between nurse staffing variables and patient outcomes by the type of hospital units (ICU, surgical, medical, neonatal) and by the type of patients (medical vs. surgical).^27^ We found a greater reduction in the relative risk of hospital-related mortality (16 percent) in surgical patients for an additional one RN FTE per patient day compared to a reduction of 6 percent in medical patients. Given a higher baseline mortality in surgical patients, the reduction in nurse workload would save six surgical compared to five medical patients per 1,000 hospitalized. Consistent with previous studies,^26,^ ^27^ the present meta-analysis found consistent evidence that surgical patients would demonstrate a greater cost-benefit from improved nurse staffing. Increasing the care of surgical patients by one RN FTE per patient day would eliminate 16 percent of failure to rescue (26 saved lives per 1,000 hospitalized) compared with 9.2 percent in all patients (medical and surgical). Such consistent and large improvements in patient safety from increasing the RN FTE per patient day ratio in surgical patients and in ICUs suggest heath care administrators can improve quality of care in these categories of patients using optimal staffing ratios.^207^

## Other Factors

The primary independent variable examined here is the volume of nursing, tempered by some attention to the education level. But other factors may also be relevant. Numbers alone do not likely explain all that happens. A nurse is not necessarily a nurse.^206^ Skill, organization, and leadership undoubtedly play a role but are much more difficult to assess. Usually we work in just the opposite direction inferring skill from outcomes after other factors have been accounted for. Because these studies rarely include data on case mix and other factors that help to explain outcomes, they cannot be used to infer differences in skill levels. Included studies did not provide the information on the quality of medical and surgical treatment. The importance of nurses' professional competence and performance have been discussed with regard to developing standards of nurse performance to encourage high quality of care.^70^–^73^

There are also questions about the association between nurse experience and patient outcomes. The independent effects of individual nurse competence in interaction with nurse staffing are not well understood and were not the subject of the present review. However, implementing the results of the present review to improve the quality of hospital care, we need to remember that complex interventions in combination with nurse staffing strategies provided better patient benefits. ^208^–^212^ Implementing evidence-based clinical pathways that involve nurse and physician education and collaboration may increase the effectiveness of nursing work and improve patient outcomes.^213,^ ^214^ Several randomized clinical trials reported a significant improvement in nurse performance and patient outcomes as a result of quality improvement initiatives.^215^–^224^

The majority of studies focused on adverse patient events and mortality. However, the estimation of quality of care may include patient satisfaction with nursing and overall medical care and improved quality of life. Future research should address patient positive outcomes, compliance with prescribed treatments, patient functional status, and education in association with provided care including nurse staffing.

## Policy Implications

The case for causation has yet to be made. Nevertheless, if one accepts the results presented as suggesting a causal relationship between nurse staffing and outcomes, the next question is one of practicality. Possible staffing decisions to improve quality of care would involve comparing existing staffing with changes in staffing needed to achieve desirable patient outcomes. The effect sizes depend on rich staffing ratios, which are not feasible in most hospitals. Moreover, defining the best level of nurse staffing requires addressing cost-effectiveness analysis^225^ that was beyond the present report. Because hospitals are paid a fixed rate under diagnosis related groups (DRGs) that does not reflect the quality of care they provide, they are not in a position to assume substantial cost burdens. The estimation of the threshold in terms of marginal costs and benefits depends on value placed on survival, patient satisfaction, and quality of life (QOL).^6^

Policymakers can consider several approaches to regulate nurse staffing. Our calculations suggest that it is difficult to set fixed nursing standards. Indeed, fixed minimum nurse-to patient ratios implemented in several states did not provide the expected patient safety benefits.^226^ To maintain a reasonable staffing level, the increasing nurse shortage may force hospitals to reduce capacity rather than increase staffing. Mandatory nurse to patient ratios without legislative agreement to increase reimbursement may result in administrative decisions to reduce support staff positions and investments to other quality initiatives.^225^ Patient acuity-based staffing requirements adjust staffing for patient diagnosis and comorbidities but do not regulate shift-to shift fluctuations in nurse staffing that have an important influence on quality of care. ^175,^ ^205^ Moreover, no consensus exists about patient classification systems, which are different among hospitals and states.^113,^ ^227^–^230^ Public disclosure of nurse staffing was introduced in one state,^227^ but its effect on quality of care is not known.^226^ Pay-for performance has been proposed to provide incentives for quality of care, but its effect on cost effectiveness is not well understood.^226^ Ideally we should monitor every hospital in the United States to see how differences in policies and financial performance affect the cost effectiveness of staffing and its effect on quality of health care.^225,^ ^226^

Finally, the number of patients a nurse cares for is not a true measure of the “work” of the nurse. The patient flow (admissions, discharges, return from surgeries, transfers to other units, transfers from other units) can result in nurses providing care for many more patients in a day than what is reflected in the RN hour per patient day or nurse to patient ratio. This significant factor was not addressed in any of the studies reviewed and should be considered as a nurse staffing measure for future studies. Another factor not considered in the studies is the number and type of support personnel available to nurses to assist them with care of patients. A recent trend in hospitals is having Rapid Response Teams (RRTs). This team is usually comprised of an experienced critical care nurse, respiratory therapist, and a physician. The team can be called by any nurse in the hospital if the nurse assesses that the patient's condition is changing such that it could potentially result in a negative outcome. Nurses also have access to consultation from advanced practice nurses, unit-based nurse educators, charge nurses, assistant nurse managers, and nurse managers. These types of nursing hours are not included in the studies or considered as nurse staffing measures.

In conclusion, the present review found consistent statistically and clinically significant associations between nurse staffing and adjusted relative risk of hospital related mortality, failure to rescue, and other patient outcomes sensitive to nursing care, but we cannot conclude these relationships are causal. Hence, they cannot be interpreted as a basis for recommending specific staffing levels. The effect size is greater in surgical patients and in ICUs. The associations may include other structure and process factors in causal pathway to patient effective and safe care. A commitment to a high quality care at hospital level may provide better patient outcomes in relation to nurse staffing.

## Strength of the Evidence

Taken as a whole, there is consistent evidence of an association between the level of nurse staffing and patient outcomes but no clear case for causation. The nature of the study designs precludes any efforts to establish a causal relationship. There are no interventions, let alone controlled trials. The effect on quality of other salient input, such as medical care, is not tested. Adjustments for case mix rely on averages across units or hospitals. The quality of the studies is modest by standard measures, and the coverage of salient variables that could affect quality is weak. The distinction is still far from clear. The association was somewhat stronger with nurse-sensitive outcomes than with more generic ones like mortality, but it was also stronger with cross-sectional rather than longitudinal designs.

## Recommendations for Future Research

While it is not feasible to think about research designs that might be more interventional, it may be possible to take advantage of natural experiments where nurse staffing levels are changed holding other factors constant. Future observational studies will need to take cognizance of the many other factors that can affect the outcomes of interest, especially medical care, patient characteristics, and the organization of nursing units and staffs. Larger multi-center studies will be needed. Nonetheless, it is unlikely that all the salient variables can be addressed in any one study. Future work will need to target specific questions and collect and analyze enough information to isolate the effects of nurse staffing levels.