# Results

Figure 4 traces the flow of our literature search for questions 1, 2, and 4. Of the 2,858 potentially relevant references from eight databases identified, we excluded 97 percent of the studies; 2 percent were case reports; 20 percent - comments and success stories; 2 percent - legal cases; 2 percent - editorials and expert opinions; 5 percent - letters, guidelines, interview, and news that reprinted the results of the original reports; and 4 percent - reviews and secondary data analyses, and one web survey. We excluded 21 percent of the studies that lacked relevant components; 6 percent without eligible outcomes, 30 percent without eligible target populations, and 21 percent that did not test associative hypotheses between nurse staffing and patient outcomes. Among 101 potentially relevant randomized controlled clinical trials, none was eligible; 56 tested ineligible interventions; five reported ineligible outcomes; 38 were conducted in European countries or included nurses in long-term nursing facilities.

Figure 4. Flow of study selection for questions 1, 2, and 4

We identified 94 eligible studies presented in 96 reports; 7 percent were case control studies; 3 percent were case series; 44 percent were cross sectional studies; 46 percent assessed temporality in the association between nurse staffing and patient outcomes.

The overall quality of the studies averaged 38 (where the maximum possible score was 50) (Table 2). Three studies received <50 percent of the maximum quality score; 24 studies had <66 percent, and 21 studies had >88 percent of the maximum quality score. Within this score, the mean external validity was 3.5 ± 1 (70 percent of the maximum score) with 67 percent for the sampling of the study populations; random sampling was reported in 16 studies (17 percent), and sampling bias was assessed in 15 studies (16 percent). More than 9 percent of the sampled analytic units were excluded from 27 studies. Single hospital studies constituted 25 percent of all eligible studies (23 reports). Geographical locations of eligible hospitals were reported in 49 studies (52 percent). The investigators generally obtained national and state administrative databases to identify eligible populations.

Table 2 Distribution of the studies' quality* (94 studies)

Quality Measures | Mean | Standard Deviation | Median
Study question clearly focused and appropriate | 4.69 | 0.73 | 5
Clear definition of exposure | 3.96 | 0.65 | 4
Clear definition of the primary and secondary outcomes | 4.41 | 0.65 | 4.5
Sampling of study population | 3.34 | 0.81 | 3
Statistical analysis: assessment of confounding attempted | 3.61 | 1.11 | 4
Adjustment for the effects of various factors | 2.89 | 1.62 | 3.5
Statistical methods | 3.70 | 0.94 | 4
Measure of effect for outcomes | 3.66 | 1.11 | 4
External validity | 3.48 | 0.97 | 4
Conclusions | 4.01 | 0.68 | 4
Total scores | 37.76 | 6.40 | 38

* Maximum possible score of 5; total of 50 for each study

The mean score for adjustment for assessed confounding factors as a characteristic of internal validity was 2.9 ± 1.6 (only 58 percent of the possible maximum score); 17 studies did not provide information on adjustment for confounding factors. Few studies reported the validation to measure nurse staffing variables (11 studies, 12 percent) and patient outcomes (22 studies, 23 percent). Medical records were obtained to measure patient outcomes in 27 studies (29 percent); 58 studies (62 percent) used administrative databases. Thirty-two studies used hospitals as analytic units (34 percent); 43 studies (46 percent) used patients; and 13 studies (17 percent) used hospital units. Medicare populations were used in 11 studies (12 percent).

The majority of the studies were conducted in the United States (84 studies) with no significant differences in quality (80 percent in Canadian studies vs. 76 percent in American, p = 0.44). The studies supported by national grants had higher quality (80 percent of maximum) compared with unknown sponsorship (73 percent, p = 0.02). The quality scores of the studies did not change over the decades (p = 0.15). The test for publication bias was not valid due to a small number of studies for each association and heterogeneity in the results.

## Association Between Nursing Hours and Ratios and Patient Outcomes

### Distribution of Nurse Staffing Hours and Ratios

Many investigators obtained administrative databases on national, state, and hospital levels. Some relied on surveys of nurse managers to measure nurse staffing variables (Appendix G *, Table G1). The means and distribution of nursing hours and ratios are presented in Table 3. Total nursing hours per patient day were measured in 36 studies (38 percent), RN hours in 27 studies (29 percent), LPN/LVN hours in 12 studies (13 percent), licensed nurse hours in three studies, and UAP hours in three studies. Ratios of patients per RN and RN FTE per patient day were examined in 36 studies (38 percent), LPN/LVN ratios in eight studies (9 percent), licensed nurse ratios in three studies, and UAP ratios in nine studies (10 percent). The distribution of nurse staffing variables in eligible published studies was comparable with that published in literature with higher LPN/LVN hours per patient days in medical patients.^27,^ ^138^

* Appendixes and Evidence Tables for this report are provided electronically at http://www.ahrq.gov/clinic/tp/nursesttp.htm

Table 3 Distribution of nurse hours and ratios (94 studies)

Nurse Staffing | Number of Studies | Mean | Standard Deviation
ICUs
RN FTE/patient day | 15 | 1.3 | 0.7
Patients/RN/shift | 15 | 3.1 | 1.8
Total nursing hours/patient day | 15 | 13.0 | 5.2
RN hours/patient day | 10 | 12.6 | 5.3
LPN/LVN hours/patient day | 3 | 0.3 | 0.6
UAP hours/patient day | 4 | 2.3 | 1.2
Licensed nurse hours/patient day | 1 | 7.3 | 0.4
Surgical patients
RN FTE/patient day | 13 | 1.1 | 0.8
Patients/RN/shift | 13 | 4.0 | 2.3
Patients/LPN/shift | 2 | 3.1 | 2.2
Total nursing hours/patient day | 12 | 8.7 | 4.3
RN hours/patient day | 11 | 8.1 | 5.1
LPN/LVN hours/patient day | 7 | 1.3 | 1.1
UAP hours/patient day | 5 | 2.1 | 0.6
Medical patients
RN FTE/patient day | 20 | 1.1 | 1.0
Patients/RN/shift | 20 | 4.4 | 2.9
Patients/LPN/shift | 6 | 13.3 | 8.5
Patients/UAP/shift | 4 | 12.0 | 8.9
Patients/licensed nurse/shift | 2 | 4.1 | 1.1
Total nursing hours/patient day | 27 | 8.2 | 4.4
RN hours/patient day | 23 | 6.1 | 3.6
LPN/LVN hours/patient day | 13 | 2.3 | 2.0
UAP hours/patient day | 12 | 2.5 | 2.1
Licensed nurse hours/patient day | 4 | 3.3 | 2.9

## Question 1. Association Between Nurse to Patient Ratios and Hospital-Related Mortality

We identified 26 studies that examined the association between hospital related mortality and nursing hours or ratios (Appendix G, Table G2).^8^–^21,^ ^23,^ ^26^–^28,^ ^30,^ ^32^–^34,^ ^139^–^141^ The authors defined hospital related mortality as in-hospital mortality^8,^ ^9,^ ^13,^ ^14,^ ^18^–^20,^ ^26,^ ^27,^ ^30,^ ^33,^ ^34^ or death within 30 days after hospital admission.^10,^ ^11,^ ^15^–^17,^ ^21,^ ^32,^ ^140^ For analysis purposes we combined in-hospital mortality and 30-day mortality. Estimating hospital-related mortality based only on in-hospital deaths may be influenced by hospital discharge practices^142^ and could result in lower in-hospital mortality rates that are independent of the quality or effectiveness of hospital care.

One study^143^ compared the relationship of in-hospital and 30-day mortality rates in 13,834 patients with congestive heart failure who were admitted to 30 hospitals and found a significant correlation in standardized mortality ratios sensitive to individual hospital characteristics. The association with nurse ratios or hours was presented as changes in crude death rates and adjusted relative risk of death corresponding to one unit increase in nurse staffing or in nurse staffing categories defined by authors.

### Nurses Ratios and Mortality

The pooled results, overall and within ICUs and surgical units, weighted by the sample size (number of hospitals and patients) showed a reduction in the crude death rate in association with increase RN staffing. An additional RN FTE per patient day was associated with a 1.24 percent reduction in death rate.^12,^ ^17,^ ^34^ The same tendency was shown corresponding to one additional RN per 1,000 patient days.^33^ In contrast, one additional patient per RN per shift was associated with an increase in hospital-related mortality by 0.1 percent^13,^ ^16,^ ^23^ (Table 4).

Table 4 Hospital-related mortality rates corresponding to changes in patients/RN ratio (pooled weighted estimates from published studies)

Level of Analysis | Number of Studies | Change in Death Rate, % | Standard Error | p Value for the Association | p Value for Heterogeneity
Authors' definition of nurse to patient ratio
Increase by 1 patient/RN/shift | 3 | 0.095 | 0.03 | 0.003 | 0.33
Increase by 1 RN FTE/patient day | 3 | -1.24 | 1.13 | 0.311 | 0.041
Increase by 1 RN FTE/1,000 patient days | 1 | -1.29 | 0.54 | 0.076
Estimated Increase by 1 RN FTE/patient day
All studies | 8 | -1.18 | 0.49 | 0.02 | <0.001
ICUs | 3 | -0.97 | 0.28 | <0.001 | 0.23
Surgical patients | 5 | -0.89 | 0.49 | 0.08 | <0.001
Medical patients | 3 | -1.18 | 0.78 | 0.15 | <0.001
Hospital level analysis | 3 | -3.48 | 2.68 | 0.25 | 0.67
Patient level analysis | 5 | -1.18 | 0.55 | 0.04 | <0.001

A pooled analysis showed that an increase by one RN FTE per patient day was associated with a 1.2 percent reduction in mortality rates in all studies.^12,^ ^13,^ ^16,^ ^17,^ ^20,^ ^23,^ ^34^ The association was consistent in ICUs.^13,^ ^16,^ ^23^

A nonlinear quadratic association between patients per RN per shift and the death rate was noted. The rates increased from 1 to 5 patients per RN per shift (p for heterogeneity <0.001). The nadir for the relative risk of death was 1.5 RN FTE per patient day (p for heterogeneity 0.002). Table 5 shows both the effects of increasing staff with the authors' definitions of nurse to patient ratios by one RN FTE per patient day and the relative effects in quartiles of patients per RN per shift distribution in different clinical settings. More RN staffing was consistently associated with a reduction in adjusted relative risk of hospital-related mortality. An increase by one RN FTE per patient day was associated with a smaller but consistent across the studies' reduction in mortality by 6 percent (RR 0.94, 95 percent CI 0.93–0.95).^8,^ ^10^–^12,^ ^17,^ ^20^

Table 5 RN to patient ratios and relative risk* of hospital-related mortality (pooled adjusted estimates from published studies)

Level of Analysis | Number of Studies | Relative Risk | 95% CI | p Value for the Association | Consistency
Authors' definition of nurse to patient ratio
Increase by patient/RN/shift | 6 | 1.08 | 1.07; 1.09 | <.0001 | No
Increase by 1 RN FTE/patient day | 6 | 0.943 | 0.93; 0.953 | <.0001 | Yes
Increase by 1 RN FTE/1,000 patient days | 3 | 0.995 | 0.95; 1.04 | 0.8273 | Yes
Estimated Increase by 1 RN FTE/patient day
All studies | 14 | 0.92 | 0.90; 0.94 | <.0001 | No
Patient level analysis | 8 | 0.919 | 0.89; 0.95 | 0.0002 | No
Hospital level analysis | 5 | 0.958 | 0.94; 0.98 | 0.0001 | Yes
ICUs | 5 | 0.908 | 0.86; 0.96 | 0.0321 | Yes
Surgical patients | 8 | 0.84 | 0.80; 0.89 | <.0001 | Yes
Medical patients | 6 | 0.944 | 0.94; 0.95 | <.0001 | Yes
Quartiles of patients/RN/shift ratio
<2 vs. 2–4 | 14 | 0.94 | 0.92; 0.95 | <.0001 | Yes
<2 vs. 4–5.5 | | 0.76 | 0.71; 0.81 | <.0001 | Yes
<2 vs. >6 | | 0.62 | 0.59; 0.66 | <.0001 | Yes
2–4 vs. 4–5.5 | | 0.81 | 0.76; 0.87 | <.0001 | Yes
2–4 vs.>6 | | 0.66 | 0.63; 0.70 | <.0001 | Yes
4–5.5 vs. >6 | | 0.82 | 0.76; 0.88 | <.0001 | Yes
ICUs | 5
<3 vs. 3–4 | | 0.94 | 0.92; 0.97 | 0.016 | Yes
Medical patients | 6
<2 vs. 2–4 | | 0.94 | 0.92; 0.96 | <.0001 | Yes
Surgical patients | 8
<2 vs. 4–6 | | 0.76 | 0.70; 0.82 | 0.000 | Yes
<2 vs. >6 | | 0.62 | 0.58; 0.66 | <.0001 | Yes
2–3.5 vs. 4–6 | | 0.80 | 0.74; 0.87 | 0.001 | Yes
2–3.5 vs. >6 | | 0.65 | 0.61; 0.70 | <.0001 | Yes
4–6 vs. >6 | | 0.81 | 0.75; 0.88 | 0.001 | Yes

* Relative risk of outcomes - the ratio of the incidence rate of outcomes corresponding to different nurse staffing levels (relative risk =1 means no association, <1 - protective effect of increased nurse staffing, >1 - increased probability of patient outcomes). 95% CI - ranges of relative risk with 95% confidence that we will have the same results repeating the study many times in the same population.

The relative risk of hospital related death was associated with a decrease by 8 percent corresponding to an additional one RN FTE per patient day in pooled analysis.^8^–^21^ For studies analyzed at the hospital level, the associated decrease in relative risk was 4 percent (95 percent CI 0.94–0.98).^11,^ ^12,^ ^18^–^20^ For those analyzed at the patient level, it was 8 percent (95 percent CI 0.89–0.95).^9,^ ^10,^ ^13^–^17,^ ^21^ Among medical patients it was 6 percent (95 percent CI 0.94–0.95)^8,^ ^10,^ ^11,^ ^17^–^19^ and among surgical patients, 16 percent (95 percent CI 0.8–0.89)^9,^ ^12^–^16,^ ^20,^ ^21^ (Figure 5). In contrast, an additional patient per RN per shift was associated with an 8 percent increase in mortality risk (RR 1.08; 95 percent CI 1.07–1.09).^9,^ ^13^–^16,^ ^21^

Figure 5. Relative risk of patient hospital-related mortality corresponding to change in registered nurse to patient ratio (pooled estimation from the studies)

We calculated the relative risk of death in quartiles of patients per RN per shift and found a consistently significant reduction in the relative risk of hospital-related mortality corresponding to a reduced number of patients assigned to an RN (Table 5 and Figure 6). The effect was larger in surgical patients. The pooled relative risk was 0.76 times less when one RN was assigned to less than two patients compared with four to six patients, and 0.62 times less compared with more than six patients per RN. The reduction was 6 percent in ICUs when one RN was assigned to less than three patients vs. three to four patients.

Figure 6. Relative risk of death among different categories of patients/RN/shift (pooled analysis)

If the relationship between staffing and outcomes was causal, we estimate that an increase by one RN FTE per patient day would save five lives per 1,000 hospitalized patients, five lives per 1,000 medical patients, and six per 1,000 surgical patients (Table 6). Reducing the workload from more than six to two to four patients per RN per shift would save 23 lives per 1,000 hospitalized patients. A reduction from three to four to less than three patients per RN per shift in ICUs would save three lives per 1,000 hospitalized patients. The decrease from more than six to 2–3.5 surgical patients per RN per shift would save 13 lives, and a further reduction to less than two patients per RN would result in 15 avoided deaths per 1,000 hospitalized surgical patients.

Table 6 Number of avoided deaths/1,000 hospitalized patients attributable to RN FTE/patient day ratio (pooled adjusted estimates from published studies)

Level of Analysis | Studies | RR | 95% CI | Attributable to Nurse Staffing, Percentage of Death, 95% CI | NNT* | Number of Avoided deaths/1,000 Hospitalized, 95% CI
Authors' definitions of nurse staffing ratio
Increase by patient/RN/shift | 6 | 1.08 | 1.07; 1.09 | 7.6 (7.07; 8.04) | 198 | 5 (4; 5)
Increase by 1 RN FTE/patient day | 6 | 0.94 | 0.93; 0.95 | 6 (7; 5) | 162 | 6 (5; 7)
Estimated increase by 1 RN FTE/patient day
All studies | 14 | 0.92 | 0.90; 0.94 | 8 (10; 6) | 191 | 5 (4; 6)
Patient level analysis | 8 | 0.92 | 0.89; 0.95 | 8 (11; 5) | 154 | 7 (4l 9)
Hospital level analysis | 5 | 0.96 | 0.94; 0.98 | 4 (6; 2) | 342 | 3 (2; 4
Intensive care units | 5 | 0.91 | 0.86; 0.96 | 9 (14; 4) | 187 | 5 ( 2; 8)
Surgical patients | 8 | 0.84 | 0.80; 0.89 | 16 ( 20; 12) | 164 | 6 (4; 8)
Medical patients | 6 | 0.94 | 0.94; 0.95 | 6 (6; 5) | 211 | 5 (4; 5)
Quartiles of patients/RN/shift ratio
<2 vs. 2–4 | 14 | 0.94 | 0.92; 0.95 | 6 (8; 5) | 247 | 4 (3; 5)
<2 vs. 4–5.5 | | 0.76 | 0.71; 0.81 | 24 (29; 19) | 63 | 16 (12; 19)
<2 vs. >6 | | 0.62 | 0.59; 0.66 | 38 (41; 35) | 40 | 25 (23; 28)
2–4 vs. 4–5.5 | | 0.81 | 0.76; 0.87 | 19 (24; 13) | 80 | 12 (9; 16)
2–4 vs. >6 | | 0.66 | 0.63; 0.70 | 34 (37; 30) | 45 | 23 (20; 25)
4–5.5 vs. >6 | | 0.82 | 0.76; 0.88 | 18 (24; 12) | 83 | 12 (8; 16)
ICUs | 5
<3 vs. 3–4 | | 0.94 | 0.92; 0.97 | 6 (8; 3) | 308 | 3 (2; 5)
Medical patients | 6
<2 vs. 2–4 | | 0.94 | 0.92; 0.96 | 6 (8; 5) | 187 | 5 (4; 7)
Surgical patients | 8
≤2 vs. 4–6 | | 0.76 | 0.70; 0.82 | 24 (30; 18) | 107 | 9 (7; 12)
≤2 vs. >6 | | 0.62 | 0.58; 0.66 | 38 (42; 34) | 68 | 15 (13; 16)
2–3.5 vs. 4–6 | | 0.80 | 0.74; 0.87 | 20 (26; 13) | 132 | 8 (5; 10)
2–3.5 vs. >6 | | 0.65 | 0.61; 0.70 | 35 (39; 30) | 75 | 13 (12; 15)
4–6 vs. >6 | | 0.81 | 0.75; 0.88 | 19 (25; 12) | 141 | 7 (5; 10)

* Number needed to treat to generate benefit (saved life)

Extrapolating these relationships even further to examine the public health impact of RNs per patient ratio, we found that an increase of one RN FTE per patient day would reduce hospital mortality by 8 percent. The effect varies from 4 percent at a hospital level analysis to 8 percent at a patient level analysis. The reduction in a workload from 3 to 4 to less than three patients per RN would eliminate 6 percent of deaths in ICUs. The proportion of deaths attributable to patients per RN per shift ratio is larger in surgical patients; 38 percent of deaths were linked to poorer nurse staffing in hospitals with more than six patients per RN compared to less than two patients in surgical units.

To compare the results from individual studies, we calculated changes in death rates and relative risk of death corresponding to an increase by one unit in nurse staffing (Appendix G Table G2 and Table 7). The majority of the studies (57 percent) reported a significant reduction in risk of death corresponding to an increase in RN staffing, but the effect size differed in studies that used medical records in contrast to administrative databases to measure mortality among hospital units and patient populations (Appendix G Tables G3 and G4). We calculated from the individual studies^10,^ ^15,^ ^16^ that about 6–7 percent of deaths were attributable to an increase in patients per RN per shift (Table 8). The observed death rate could be reduced by 9–10 percent when increasing by one RN FTE per 1,000 patient days.^18,^ ^19^ A decrease in the nurse to patient ratio in the evening was associated with a 90 percent increase in mortality; 47 percent of deaths in patients after abdominal aortic surgery was attributable to nurse staffing in these hospitals.^9^ Ten percent of avoided deaths in patients with acute myocardial infarction was attributable to an increase from 1.06 to 2.7 RN FTE per patient day.^17^ In patients hospitalized with bladder carcinoma, 51 percent of deaths was associated with a reduction from 3.1 to 1.4 RNs per occupied bed ratio.^20^

Table 7 Calculated relative risk of hospital-related mortality corresponding to increased RN staffing (results from individual studies)

Study, Analytic Unit | RR | 95% CI | Data, Definition of RN Ratio | Units | Patients | Diagnosis
Hospital
Mark, 2004^18^ | 1.02 | 0.9; 1.1 | Administrative, RN FTE/1,000 patient days | Combined | Combined | Combined
Mark, 2005^19^ | 1.005 | 0.98;1.03 | Administrative, RN FTE/1,000 patient days | Combined | Combined | Combined
Robertson, 1999^11^ | 0.97 | 0.957; 0.98 | Administrative, RN FTE/patient day | Combined | Medical | Chronic obstructive pulmonary disease
Silber, 2000^12^ | 0.93* | p <0.05 | Administrative, RN FTE/patient day | Surgical | Surgical | Combined
Elting, 2005^20^ | 0.61* | p <0.05 | Administrative, RN FTE/patient day | Surgical | Surgical | Bladder carcinoma (ICD-9 codes 188.0 – 188.9 and 236.7) after total cystectomy
Patient
Aiken, 1999^10^ | 0.28 | 0.2; 0.5 | Medical records, RN FTE/patient day | Combined | Medical | AIDS
Aiken, 2002^15^ | 0.58 | 0.4; 0.8 | Administrative, RN FTE/patient day | Combined | Surgical | General surgical, orthopedic, or vascular operation
Aiken. 2003^16^ | 0.89 | 0.848; 0.934 | Administrative, RN FTE/patient day | ICU | Surgical | General surgical, orthopedic, vascular operation
Person, 2004^17^ | 0.94 | 0.9; 1 | Administrative, RN FTE/patient day | Combined | Medical | Acute myocardial infarction
Pronovost, 1999^9^ | 0.02* | p <0.05 | Administrative, patients/RN/shift | ICU | Medical | Abdominal aortic surgery
Amaravadi, 2000^13^ | 0.39* | NS | Administrative, patients/RN/shift | ICU | Surgical | Esophageal resection
Dimick, 2001^14^ | 6.5* | NS | Administrative, patients/RN/shift | ICU | Surgical | Hepatic resection
Halm, 2005^21^ | 1.02* | NS | Administrative, patients/RN/shift | Surgical | Surgical | General, orthopedic, and vascular surgery
Hospital unit
Shortell, 1994^8^ | 1.13* | NS | Administrative, RN FTE/patient day | ICU | Medical | Combined

* 95% CI were not reported, significance reported by authors

Table 8 Association between RN staffing ratio and mortality and proportion of mortality attributable to nurse staffing (results from individual studies)

Author | Analytic Unit | Hospital Unit | Patients | RN Ratio | Relative Risk of Death (95% CI) | Attributable Proportion, (95% CI)
Pronovost^9^ | P | ICU | S, Abdominal aortic surgery | Nurse to patient ratio <1:2 vs. >1:2 in evening | 1.9 (1.2; 3) | 0.47 (0.17; 0.23)
Aiken^10^ | P | C | M, AIDS | Increase by 1 patient/RN/shift | 2.3 (1.3; 4.2) | 0.57 (0.76; 0.22)
Aiken^15^ | P | ICU | S, general surgical, orthopedic, or vascular operation | Increase in workload of 1 patient/RN/shift | 1.06 (1.01; 1.1) | 0.06 (0.01; 0.09)
Aiken^16^ | P | ICU | S, general surgical, orthopedic, or vascular operation | Increase by 6 patients/RN/shift | 1.5 (1.19; 1.97) | 0.33 (0.16; 0.49)
| | | | Increase by 1 patient/RN/shift | 1.07 (1.03; 1.12) | 0.07 (0.03; 0.11)
Person^17^ | P | C | M, acute, myocardial, infarction | 4^th^ quartile vs.1 quartile of RN staffing (~2.7 RN FTE/patient day vs. ~1.6 RN FTE/patient day) | 0.91 (0.86; 0.97 | 0.10 (0.16; 0.03)
Elting^20^ | H | S | S, bladder carcinoma after total cystectomy | Hospitals with few RN FTE/occupied bed (median 1.4) vs. many (median 3.1) | 2.04 (1.03; 5.3) | 0.51 (0.81; 0.03)
Mark^19^ | H | C | C | Increase by 1 RN FTE/1,000 patient days in hospitals with high HMO penetration | 0.91 (0.86; 0.95) | 0.10 (0.16; 0.05
Robertson^11^ | H | C | M | Increase by 1 RN in RN FTE/patient day ratio in
| | | | 1989 | 0.988 | 0.01
| | | | 1990 | 0.987 | 0.01
| | | | 1991 | 0.978 | 0.02
Mark^18^ | H | C | C | 75^th^ quartile of RN FTE/1,000 patient-days | 0.96 (0.95; 0.98) | 0.04 (0.05; 0.02)
| | | | 7.24 RN hours/patient day
| | | | 50^th^ quartile of RN FTEs/1,000 patient days | 0.97 (0.96; 0.98) | 0.03 (0.04; 0.02)
| | | | 6.01 RN hours/patient day
| | | | 25^th^ quartile of RN FTEs/1,000 patient days | 0.98 (0.96; 0.99) | 0.02 (0.04; 0.01)
| | | | 4.79 RN hours/patient day
| | | | Increase by 1 RN FTE/1,000 patient days | 0.92 (0.87; 0.96) | 0.09 (0.15; 0.04)
Silber^12^ | H | S | S | Hospitals with 1.6 vs. 2.7 patients/RN/shift | 0.95 (0.93; 0.96) | 0.05 (0.08; 0.04)

P = patient; H = hospital; C = combined; S = surgical; M = medical; Attributable Proportion = proportion of deaths attributable to nurse staffing

Three studies that examined the effect of the LPN/LVN per patient day ratio^17,^ ^34,^ ^94^ reported inconsistent changes in the death rate. A nonlinear association between patients per LPN/LVN per shift ratio and relative risk of hospital-related mortality was observed in medical patients with the lowest risk corresponding to 9–12 patients per LPN/LVN (p for quadratic association 0.0003). The death rate was lowest when one UAP was assigned to 7–12 medical patients (p for quadratic association 0.0029). One study reported a significant increase in the death rate of 1.9 percent (95 percent CI 1.5–2.5 percent) for every additional patient per UAP (p = <.0001).^94^

We found some evidence that nurse education and experience are associated with hospital-related mortality. Using state level administrative reports on nurse distribution in the United States^1,^ ^144^ and the CDC data^148^ on fatal injuries related to health care, we found a significant negative correlation between the percentage of nurses with BSN degrees and the incidence of deaths related to health care (r = -0.46, p = 0.02) (Table 9). One study in surgical patients^16^ reported a 5 percent reduction in mortality with each 10 percent increase in nurses with BSN degrees (Table 10). Hospitals with a higher proportion of nurses with BSN degrees (36 percent vs.11 percent) had 19–34 percent less mortality.^101^ Nursing experience did not impact hospital-related mortality.^16,^ ^140^ Nurse job satisfaction was associated with a significant reduction in the risk of death;^101^ an increase by 17 percent in nurses reporting they were satisfied or very satisfied with their job was associated with a 15 percent decrease in mortality. Hospitals where nurses had the freedom to make important patient care and work decisions experienced 21 percent lower mortality.^101^ Nurse manager support was negatively correlated with mortality (r = 0.3) in one single hospital study in 21 hospital units.^145^

Table 9 Correlation between nurse staffing and age adjusted fatal adverse events related to medical care at the state level^1,^ ^144,^ ^148^

| r | p Value
Excess or shortage | 0.08 | 0.58
Percent of shortage | -0.10 | 0.50
Total number of nurses | -0.11 | 0.62
Employed in nursing | -0.11 | 0.59
Percent employed in nursing | -0.12 | 0.56
RN/100,000 population | -0.24 | 0.26
Full-time employed | -0.09 | 0.66
Percent full-time employed | 0.13 | 0.55
Part-time employed | -0.13 | 0.55
Percent part-time employed | -0.10 | 0.62
RN FTE | -0.04 | 0.84
Number of nurses with diploma | -0.04 | 0.86
Percent of nurses with diploma | -0.10 | 0.64
Number of nurses with associate degree | 0.33 | 0.11
Percent of nurses with associate degree | 0.33 | 0.11
Number of nurses with BSN | -0.15 | 0.48
Percent of nurses with BSN | -0.46* | 0.02
Number of nurses with MS and PhD | -0.14 | 0.52
Percent of nurses with MS and PhD | 0.16 | 0.46

* significant at 95% level

r = correlation coefficient

Table 10 Association between nurse education, experience, and mortality

Author, Unit, Patients | Nurse Education and Experience | Death Rate, % | Relative Risk, 95% CI
Aiken^16^ | 40% of hospital workforce with BSN or higher | 2.17
ICU | 10% increase in nurses with BSN degree* | -0.10 | 0.95 (0.9; 0.99)
Surgical | Increase by 1 year in nurse experience | 0.23 | 0.09
| Interactions:
| 60% of hospital workforce with BSN or higher, 8 patients/day | 1.98
| 40% of hospital workforce with BSN or higher, 4 patient/nurse | 1.80
| 20% of hospital workforce with BSN or higher, 4 patients/nurse | 1.97
| 60% of hospital workforce with BSN or higher, 6 patients/nurse | 1.80
| 40% of hospital workforce with BSN or higher, 6 patients/nurse | 1.98
| 20% of hospital workforce with BSN or higher, 6 patients/nurse | 2.16
| 60% of hospital workforce with BSN or higher, 4 patients/nurse | 1.64
| 20–29% of hospital workforce with BSN or higher, 14 years of nurse experience | 2.20
| <20% of hospital workforce with BSN or higher, 15 years of nurse experience | 2.30
| 20% of hospital workforce with BSN or higher, 8 patients/nurse | 2.38
| >50% of hospital workforce with BSN or higher, 12.5 years of nurse experience | 1.70
| 40–49% of hospital workforce with BSN or higher, 14.3 years of nurse experience | 1.90
| 30–39% of hospital workforce with BSN or higher, 14 years of nurse experience | 1.80
Estabrooks^101^ | Hospitals with higher proportion of nurses with BSN 36% vs. low (11%) | | 0.81 (0.68; 96)
Combined | Hospitals with higher proportion of nurses with BSN, 36% vs. low (11%) (random effects model) | | 0.65 (0.6; 0.71)
Medical
Tourangeau^140^ | Increase by 1 year in nursing experience in teaching hospitals | | 0.99
Combined | Increase by 1 year in nurse experience | | 0.99
Medical | Increase by 1 year in nursing experience in nonurban hospitals | | 1
| 30 days mortality in teaching hospitals, 7.85 years of nurse experience | 14.02
| 30 days mortality in nonurban community hospitals, 9.47 years of nurse experience | 15.27
| 30 days mortality in urban community hospitals, 8.9 years of nurse experience | 15.05

* We calculated death rate corresponding to 10% increase in nurses with BSN and to 1 year increase in nurse experience, significant at 95% level.

### Association Between Nurse to Patient Ratios and Nurse Sensitive Patient Outcomes

Authors used different definitions of nurse sensitive patient outcomes, including a combination of medical^13,^ ^14,^ ^23^ and surgical^13,^ ^23^ complications related to health care, failure to rescue,^15,^ ^16,^ ^20,^ ^21,^ ^35^ and secondary diagnoses of patient nosocomial infections, falls, pressure ulcers, pulmonary and cardiac failure, and thrombo-embolic complications related to health care (Appendix G, Table G5). The associations were presented as differences in the rates or relative risk of outcomes by various categories of nurse staffing.

Patient outcomes corresponding to an increase in registered nurse per patient ratio. Pooled analysis of crude rates (Table 11) showed inconsistent results on patient outcomes. An increase by one patient per RN per shift was associated with a significant increase in failure to rescue by 0.35 percent,^16^ and pulmonary failure by 6.54 percent.^13,^ ^14,^ ^23^ An increase by one RN FTE per patient day was association with 0.03 percent decrease in atelectasis and pulmonary failure.^13,^ ^14,^ ^23,^ ^33,^ ^35^ The effect was larger in surgical patients in ICUs with a 12 percent reduction in pulmonary failure.^13,^ ^14,^ ^23^ However, a 0.71 percent reduction in urinary tract infection was associated with one additional patient per RN per shift^22,^ ^146^ and a 5 percent increase corresponded to one RN FTE per patient day.^22,^ ^23,^ ^146^ Studies that defined RN FTE per patient day ratio did not show significant changes in outcomes. One unpublished dissertation^33^ reported an increase in falls, nosocomial infections, and pressure ulcers corresponding to an increase of one RN FTE per 1,000 patient days (Appendix G, Table G6).

Table 11 Patient outcomes rates (%) corresponding to an increase in RN staffing ratios (pooled estimation from the published studies)

Outcomes | Studies | Difference in Rate, % | Standard Error | p Value for the Association | Consistency
Authors' definition of nurse staffing ratio
Increase by 1 patient/RN/shift
Failure to rescue | 1 | 0.35 | 0.12 | 0.01
CPR | 3 | 0.45 | 0.06 | 0.001 | No
Falls | 2 | 3.88 | 1.26 | 0.05 | Yes
Urinary tract infection | 2 | -0.71 | 0.41 | 0.10 | Yes
Pneumonia | 2 | 2.04 | 1.62 | 0.43 | Yes
Nosocomial Infection | 5 | -0.03 | 0.08 | 0.68 | No
Pressure ulcers | 2 | -1.26 | 0.41 | 0.06 | No
Pulmonary failure | 3 | 6.54 | 1.04 | 0.001 | Yes
Unplanned extubation | 3 | 4.20 | 0.31 | 0.001 | No
Estimated increase by 1 RN FTE/patient day
Failure to rescue | 3 | -0.67 | 0.20 | 0.001 | No
Falls | 3 | -13.43 | 1.55 | 0.001 | No
Urinary tract infection | 3 | 5.18 | 1.94 | 0.02 | Yes
Pneumonia | 2 | -3.57 | 2.84 | 0.43 | Yes
Nosocomial Infection | 6 | 0.23 | 0.40 | 0.57 | No
Pressure ulcers | 2 | 3.94 | 1.11 | 0.04 | No
Pulmonary failure | 4 | -0.03 | 0.02 | 0.11 | Yes
Unplanned extubation | 3 | -7.35 | 0.55 | 0.001 | No
Thrombosis | 1 | -0.05 | 0.04 | 0.29
Estimated increase by 1 RN FTE/patient day in ICUs
Failure to rescue | 1 | -3.69 | 1.26 | 0.01
CPR | 3 | -0.78 | 0.10 | 0.002 | No
Pulmonary failure | 3 | -11.45 | 1.82 | 0.003 | Yes
Unplanned extubation | 3 | -7.35 | 0.55 | 0.001 | No
Estimated increase by 1 RN FTE/patient day in surgical patients
Failure to rescue | 2 | -3.32 | 1.25 | 0.02 | Yes
CPR | 3 | -0.78 | 0.10 | 0.002 | No
Sepsis | 5 | -1.15 | 0.42 | 0.02 | No

In contrast with the analyses of outcomes rates, pooled analysis of adjusted relative risks (Table 12) detected a significant, generally consistent reduction in patient outcomes corresponding to an increase in RN staffing. An additional patient per RN per shift was associated with a 1.07 times higher risk of hospital acquired pneumonia (95 percent CI 1.03–1.11),^13,^ ^14,^ ^22^ a 1.08 times higher risk of failure to rescue (95 percent CI 1.07–1.09),^15,^ ^16,^ ^21^ and a 1.16 times higher risk of cardiac arrest (95 percent CI 1.05–1.29).^13,^ ^23,^ ^24^ The risk of pulmonary failure was greater by 53 percent and the risk of unplanned extubation by 45 percent corresponding to an additional patient per RN per shift.^13,^ ^14,^ ^23^–^25^ We estimated that an increase by one RN FTE per patient day in ICUs was associated with a consistent reduction in the relative risk of hospital acquired pneumonia by 30 percent,^13,^ ^14,^ ^22^ pulmonary failure by 60 percent,^13,^ ^14,^ ^23,^ ^24^ unplanned extubation by 51 percent,^13,^ ^14,^ ^23^–^25^ and cardiac arrest by 28 percent.^13,^ ^14,^ ^24^ An increase by one RN FTE per patient day in surgical patients was associated with 0.84 times less risk of failure to rescue^12,^ ^15,^ ^16,^ ^20,^ ^21^ and 0.64 times less risk of nosocomial bloodstream infections.^13,^ ^22^–^24,^ ^147^

Table 12 Relative risk of patient outcomes corresponding to an increase in RN staffing ratios (pooled estimation from the studies)

Outcomes | Studies | Relative Risk | 95% CI | p Value for the Association | Consistency
Authors' definition of nurse staffing ratio
Increase by 1 patient/RN/shift
Hospital acquired pneumonia | 3 | 1.07 | 1.03; 1.11 | 0.001 | Yes
Failure to rescue | 3 | 1.08 | 1.07; 1.09 | <.0001 | No
Pulmonary failure | 4 | 1.53 | 1.24; 1.89 | 0.001 | Yes
Unplanned extubation | 5 | 1.45 | 1.27; 1.67 | <.0001 | Yes
Nosocomial infection | 3 | 1.03 | 0.98; 1.07 | 0.24 | No
CPR | 3 | 1.16 | 1.05; 1.29 | 0.008 | Yes
Medical complications | 3 | 1.17 | 1.04; 1.31 | 0.01 | Yes
Increase by 1 RN FTE/patient day
Failure to rescue | 2 | 0.92 | 0.92; 0.92 | 0.002 | No
Estimated increase by 1 RN FTE/patient day
ICU
Hospital acquired pneumonia | 3 | 0.7 | 0.56; 0.88 | 0.02 | Yes
Pulmonary failure | 4 | 0.4 | 0.27; 0.59 | 0.001 | Yes
Unplanned extubation | 5 | 0.49 | 0.36; 0.67 | 0.001 | Yes
CPR | 3 | 0.72 | 0.62; 0.84 | 0.002 | Yes
Medical complications | 3 | 0.72 | 0.6; 0.86 | 0.005 | Yes
Surgical patients
Urinary tract infection | 1 | 1.68 | 1.06; 2.67 | 0.05
Failure to rescue | 5 | 0.84 | 0.79; 0.9 | 0.001 | Yes
Nosocomial infection | 2 | 0.08 | 0.04; 0.18 | <.0001 | No
Surgical wound infection | 1 | 0.15 | 0.03; 0.82 | 0.051
Sepsis | 5 | 0.64 | 0.46; 0.89 | 0.015 | Yes
Patient level analysis
Failure to rescue | 4 | 0.91 | 0.89; 0.94 | 0.002 | Yes
Pulmonary failure | 5 | 0.94 | 0.94; 0.94 | <.0001 | Yes

In individual studies, the largest decrease in the relative risk of central line associated bloodstream infection was seen in surgical patients in ICUs corresponding to increased nurse to patient ratio.^147^ Surgical patients also experienced greater increase in the risk of failure to rescue (p for interaction 0.04) in a multi-hospital study^15^ by 7 percent corresponding to every additional patient per RN (RR 1.07, 95 percent CI 1.02–1.11).

We found nonlinear quadratic associations between the RN FTE per patient day ratio and unplanned extubation in ICUs with the nadir at 1.9 RN FTE per patient day (p for quadratic association 0.04). In surgical patients, the ranges of RN FTE per patient day at 0.9–2.2 were associated with the lowest relative risk of hospital acquired pneumonia (p for quadratic association 0.02) and the ranges of 1.5–2 RN FTE per patient day were associated with the lowest risk of failure to rescue (p for quadratic association 0.005).

Patient outcomes corresponding to an increase by one patient per LPN/LVN per shift (Appendix G, Table G7). The data on LPNs/LVNs is varied and inconclusive. One large study in 1,477 hospitals^94^ examined the association between LPN/LVN per patient ratios and patient outcomes (Figure 7) and reported that one additional patient per LPN/LVN per shift increased the rates of surgical wound infection by 0.02 percent (95 percent CI 0.01–0. 05), pulmonary failure by 0.04 percent (95 percent CI 0.02–0.05), pneumonia by 0.06 percent (95 percent CI 0.04–0.07), patient falls by 0.03 percent (95 percent CI 0.02–0.04), and cardiac arrest by 0.03 percent (95 percent CI 0.02–0.04). One study^18^ reported a nonsignificant risk of pneumonia and urinary tract infections (UTI) corresponding to an increase by one LPN/LVN FTE per patient day.

Figure 7. Patient outcomes rates (%) corresponding to an increase by patient per LPN/LVN per shift (calculated from one study)

Few studies examined the association between patient outcomes and licensed nurse ratio defining licensed nurses as RN or LPN/LVN. Nonsignificant changes in the rates of pressure ulcers were reported in one study^64^ and in patient falls in two studies^64,^ ^65^ corresponding to an additional patient per licensed nurse.

Patient outcomes corresponding to an increase by one patient per UAP per shift. An examination of the association between UAP per patient ratio and patient outcomes (Figure 8) showed that one additional patient per UAP was associated with an increase in the rate of surgical wound infection by 0.01 percent (95 percent CI 0.009–0.03), cardiac arrest by 0.04 percent (95 percent CI 0.02–0.05), and pressure and decubitus ulcers by 0.5 percent (95 percent CI 0.2–0.8). Consistently across three studies^33,^ ^61,^ ^75^ an increase in the rate of patient falls by 0.03 percent (95 percent CI 0.02–0.04) (heterogeneity not significant [NS]) was detected corresponding to an increase by one patient per UAP per shift (Appendix G, Table G8).

Figure 8. Patient outcomes rates (%) corresponding to an increase by patient/UAP/shift (estimates from individual studies and pooled analysis)

Length of stay corresponding to an increase in nurse staffing ratios. The associations between nurse staffing ratios and LOS in hospitals and in hospital units were reported in days and in relative changes in days adjusted for patients and provider characteristics (Appendix G, Table G9). Pooled analysis^9,^ ^13,^ ^14,^ ^23,^ ^33,^ ^35,^ ^146,^ ^147,^ ^150^ (Table 13) detected a reduction in length of stay by 0.25 days corresponding to an additional RN FTE per patient day (p value for heterogeneity <0.05). The reduction by 0.25 days per one RN FTE per patient day was significant but not consistent in medical patients. One study^94^ reported that every additional LPN/LVN FTE per 1,000 patient days increased the length of stay by 1.8 days (95 percent CI 1.35–2.25). Random changes in LOS in relation to UAP workload were reported in one study.^33^

Table 13 Length of stay corresponding to an increase in RN staffing ratios (pooled analysis)

Nurse Staffing | Studies | Change in Length of Stay, Days | Standard Errors | p Value for the Association | Consistency
Authors' definitions
Increase by 1 patient/RN/shift | 6 | 0.7 | 0.8 | 0.4 | Yes
Increase by 1 RN FTE/patient day | 2 | -0.25 | 0.03 | <.0001 | Yes
Estimated increase by 1 RN FTE/patient day
All studies | 10 | -0.25 | 0.02 | <.0001 | No
ICUs | 5 | -0.70 | 1.64 | 0.68 | Yes
Surgical patients | 5 | -0.63 | 1.50 | 0.68 | Yes
Medical patients | 5 | -0.25 | 0.02 | <.0001 | No

Pooled analysis of adjusted relative changes in LOS (Figure 9) detected a 20 percent increase in LOS corresponding to one additional patient per RN per shift (95 percent CI 1.08–1.35, heterogeneity NS). The significant reduction in LOS was 31 percent in surgical patients (95 percent CI 0.55–0.86)^9,^ ^13,^ ^14^ and 24 percent in ICUs (95 percent CI 0.62–0.94)^8,^ ^9,^ ^13,^ ^14^ corresponding to an increase by one RN FTE per patient day. In contrast, one study^19^ reported that every patient per LPN/LVN reduced LOS by 22 percent (95 percent CI 0.71–0.86).

Figure 9. Relative changes in LOS corresponding to an increase in RN staffing ratios (pooled estimation from the studies)

Patient outcomes in quartiles of nurse to patient distribution. We analyzed the relative risk of patient outcomes among different quartiles of patients per RN per shift distribution (Figures 10–12). Relative risk of hospital acquired pneumonia was 0.75 times less in surgical patients when an RN was assigned to 4.9 patients compared to more than five patients per shift (Figure 10). In medical patients, the reduction in ratio from more than six to two or less patients per RN per shift was associated with a 41 percent reduction in hospital acquired pneumonia. Relative risk of nosocomial infection was 94 percent less in surgical patients corresponding to a reduction from 2.8 to two or less patients per RN per shift. A significant consistent across the studies reduction in relative risk of nosocomial infection in medical patients was observed by 33–38 percent when one RN was assigned to less than two patients. In contrast, the relative risk of urinary tract infection was higher in medical patients corresponding to an increase in RN staffing.

Figure 10. Relative risk of hospital acquired infections in quartiles of patients/RN/shift distribution (pooled analysis)

*The following table shows how the patients/RN/shift quartiles were established.

Quartiles | ICU | Surgical Patients | Medical Patients
0 | <1.6 | <2 | <2
1 | 2.0 | 2.8 | 3.0
2 | 3.3 | 4.9 | 4.8
3 | >4 | >5 | >6

Figure 12. Relative risk of patient outcomes in quartiles of patients/RN/shift distribution (pooled analysis)

*The following table shows how the patients/RN/shift quartiles were established.

Quartiles | ICU | Surgical Patients
0 | <1.6 | <2
1 | 2.0 | 2.8
2 | 3.3 | 4.9
3 | >4 | >5

The effect of reduction in patients per RN per shift on patient outcomes was greater in ICUs and in surgical patients (Figure 11). The relative risk of cardiopulmonary resuscitation was 0.54 and 0.75 times less when one RN was assigned to 3.3 and more than four patients, respectively compared with two patients per RN per shift. Surgical patients experienced cardiac arrest 0.69–0.75 times less often with less than two patients per RN vs. 2.8 and 4.9 patients per RN respectively. The reduction in RN workload was consistently associated with a decrease in relative risk of failure to rescue in surgical patients by 25–39 percent when one RN was assigned to less than two patients vs.4.9 and more than five patients, respectively. The same direction of association in ICUs and in surgical patients was shown with the reduction in relative risk of pulmonary failure, and unplanned extubation across quartiles of patients per RN per shift distribution (Figure 12). A nonlinear association between patients per RN ratio and medical complications was observed in ICUs. The reduction from 3–3.6 patients per RN to less than 1.5 patients was associated with a relative decrease by 17 percent (p = 0.03, heterogeneity NS) in LOS in ICUs. The LOS was 22 percent shorter with a ratio of 1.6–2.5 patients per RN compared with 3–3.6 patients per RN in ICUs (p = 0.03, heterogeneity NS).

Figure 11. Relative risk of patient outcomes in quartiles of patients/RN/shift distribution (pooled analysis)

*The following table shows how the patients/RN/shift quartiles were established.

Quartiles | ICU | Surgical Patients
0 | <1.6 | <2
1 | 2.0 | 2.8
2 | 3.3 | 4.9
3 | >4 | >5

In conclusion, despite the substantial heterogeneity in the studies, some consistent evidence from observational studies suggests that increased RN to patient ratio is associated with a reduction in hospital-related mortality, failure to rescue, unplanned extubation, pulmonary failure, and bloodstream infections after adjustment for patient and provider characteristics and reduced LOS of surgical patients. While the effect size is greater in surgical patients and ICUs, the optimal ratio seems to be within the first quartiles of distribution of patients per RN per shift in ICU and in surgical patients. The evidence in medical patients is less consistent and needs further investigation.

## Question 2. Association Between Nurse Hours per Patient Day and Patient Outcomes

### Total Nurse Hours per Patient Day and Hospital Related Mortality

Four studies examined the association between total nurse hours per patient day and hospital related mortality, three at the hospital level^26^–^28^ and one at the unit level.^139^ A consistent and significant reduction in death rate by 1.98 percent for every additional nurse hour per patient (95 percent CI 0.96–3 percent) was observed (p = 0.0005, heterogeneity NS). The rate was slightly higher (2.1 percent) in three studies analyzed at the hospital level (95 per cent CI 1–3.1 percent, p = 0.0004). Every additional nurse hour per patient day reduced the death rate by 1.4 percent (95 percent CI 0.5–2.3) in medical patients^26^–^28^ and by 2.3 percent (95 percent CI 1.2–3.3) in surgical patients^26,^ ^27^ (heterogeneity NS). One large study reported non-significant changes in the relative risk of death corresponding to an increase by one hour in total nursing hours per patient day.^27^

RN hours per patient day and hospital related mortality. The association with RN hours per patient day did not show significant changes in mortality rates in four studies.^26^–^28,^ ^139^ Pooled analysis that examined the relative risk of death in relation to RN hours per patient day did not detect significant association.^18,^ ^19,^ ^26,^ ^27,^ ^30,^ ^141^ Random changes in the risk of death were observed by pooling three studies at hospital level analysis^18,^ ^19,^ ^26,^ ^27,^ ^30^ in medical units,^27^ in surgical patients,^26,^ ^27^ and in medical patients.^26^–^28^ One multi-hospital study reported a 2 percent reduction in mortality (RR 0.98, 95 percent CI 0.97–0.99) in medical patients.^150^ Another study demonstrated a small but significant increase in the relative risk of death corresponding to one additional RN hour per patient day.^141^

We conducted combined pooled analysis with RN hours per patient day reported by the authors and estimated from RN to patient ratios. An increase of one RN hour per patient day was associated with a small but consistent reduction in the relative risk of hospital-related mortality. A reduction of 1 percent was observed in ICUs (RR 0.96, 95 percent CI 0.99–1.0),^8,^ ^9,^ ^13,^ ^14,^ ^16^ in surgical patients (RR 0.90, 95 percent CI 0.98–1.0),^12^–^16^ and in medical patients (RR 0.99, 95 percent CI 0.99–1.0).^8,^ ^10,^ ^11,^ ^17^–^19^

LPN/LVN and UAP hours per patient day and hospital related mortality. Two studies examined the association between death rates and LPN/LVN hours per patient day^26,^ ^27^ and three^18,^ ^19,^ ^27^ reported the relative risk of death corresponding to increased LPN/LVN hours. After pooling all three studies, every additional LPN/LVN hour per patient day was associated with an increase in the crude death rate of 3.4 percent (95 percent CI 2.1–4.8). One study reported an additional LPN/LVN hour was associated with a 2.5 percent increase in the crude death rate in medical units (95 percent CI 1.8–3.2),^27^ with a greater increase in surgical patients by 3.3 percent (95 percent CI 2.4–4.2)^26,^ ^27^ (heterogeneity NS). Combined analysis of reported and estimated LPN/LVN hours detected inconsistent increases in death rate. The relative risk of hospital-related mortality was not significant in individual studies (Appendix G, Table G10) and pooled analysis. One study examined the association between mortality and UAP hours per patient day reporting random changes in crude death rates and adjusted risk of mortality.^27^

Patient outcomes corresponding to an increase of 1 total nurse hour per patient day. (Appendix G, Tables G11–G13). The results of pooled analysis of changes in patient outcomes corresponding to one additional nurse hour per patient day are presented in Table 14. The pooled analysis showed a significant consistent reduction in sepsis among surgical patients by 1.33 ± 0.27 percent,^26,^ ^27,^ ^46^ failure to rescue by 3.53 ± 0.48 percent,^26,^ ^27^ urinary tract infection by 4.23 ± 0.97 percent,^26,^ ^27,^ ^76,^ ^78^ hospital acquired pneumonia by 2.2 ± 0.52 percent,^26,^ ^27,^ ^151^ surgical wound infection by 0.31 ± 0.05 percent,^26,^ ^27^ pressure ulcers by 2.26 ± 0.34 percent,^26,^ ^27,^ ^76,^ ^78,^ ^151^ shock by 0.77 ± 0.14 percent,^26,^ ^27^ pulmonary failure by 2.39 ± 0.49 percent,^26,^ ^27^ and deep venous thrombosis by 0.45 ± 0.11 percent.^26,^ ^27^ In medical patients an additional nurse hour per patient day was associated with a consistent reduction in failure to rescue by 1.39 ± 0.5 percent,^26,^ ^27^ urinary tract infection by 1.88 ± 0.36 percent,^26^–^28,^ ^76^–^78,^ ^81^ hospital acquired pneumonia by 0.89 ± 0.27 percent,^26^–^28,^ ^45,^ ^79,^ ^81^ shock by 0.34 ± 0.05 percent,^26,^ ^27^ and deep venous thrombosis by 0.15 ± 0.05 percent.^26,^ ^27^

Table 14 Patient outcomes rates (%) corresponding to an increase by 1 hour in total nursing hours/patient day (pooled analysis)

Outcomes | Studies | Difference in Outcome Rate, % | Standard Error | p Value for the Association | Consistency
ICUs
Falls | 5 | -0.08 | 0.01 | <0.001 | Yes
Nosocomial infection | 4 | -0.83 | 0.31 | 0.03 | No
Sepsis | 3 | -0.24 | 0.47 | 0.63 | Yes
Pressure ulcers | 5 | -0.90 | 0.65 | 0.30 | Yes
Surgical patients
Failure to rescue | 2 | -3.53 | 0.48 | <.0001 | Yes
Falls | 3 | 0.12 | 0.07 | 0.16 | Yes
Urinary tract infection | 4 | -4.23 | 0.97 | 0.001 | Yes
Hospital acquired pneumonia | 3 | -2.20 | 0.52 | 0.002 | Yes
Nosocomial infection | 2 | 0.44 | 0.27 | 0.19 | Yes
Sepsis | 3 | -1.33 | 0.27 | 0.001 | Yes
Surgical wound infection | 2 | -0.31 | 0.05 | 0.000 | Yes
Pressure ulcers | 5 | -2.26 | 0.34 | <.0001 | Yes
Gastrointestinal bleeding | 2 | -0.89 | 0.18 | 0.001 | Yes
Shock | 2 | -0.77 | 0.14 | 0.000 | Yes
Pulmonary failure | 2 | -2.39 | 0.49 | 0.001 | Yes
Thrombosis | 2 | -0.45 | 0.11 | 0.002 | Yes
Medical patients
Failure to rescue | 2 | -1.39 | 0.50 | 0.02 | Yes
Falls | 11 | -0.17 | 0.13 | 0.18 | Yes
Urinary tract infection | 7 | -1.88 | 0.36 | <.0001 | Yes
Hospital acquired pneumonia | 5 | -0.89 | 0.27 | 0.004 | Yes
Nosocomial infection | 5 | 0.11 | 0.04 | 0.01 | No
Sepsis | 5 | -0.06 | 0.05 | 0.25 | Yes
Pressure ulcers | 13 | 0.33 | 0.20 | 0.10 | Yes
Gastrointestinal bleeding | 2 | -0.44 | 0.10 | 0.002 | Yes
Shock | 2 | -0.34 | 0.05 | <.0001 | Yes
Thrombosis | 2 | -0.15 | 0.05 | 0.008 | Yes

An observed increase in nosocomial infection was not consistent across the studies. Differences in patient falls was significant in ICUs only^49,^ ^61,^ ^64,^ ^75,^ ^139^ with a reduction by 0.08 ± 0.01 percent corresponding to additional nurse hour per patient day.

Pooled analysis of the adjusted relative risk (Figure 13) detected a significant 12 percent reduction in nosocomial infection corresponding to an increase of one nurse hour per patient day (95 percent CI 0.84–0.92), but the heterogeneity was significant (p for heterogeneity = 0.001).^33,^ ^45,^ ^46,^ ^63,^ ^80^ However, a consistent nonlinear quadratic association was detected (p = 0.02) whereby an increase of more than nine total nurse hours per patient day was associated with a 13 percent reduction in the relative risk of nosocomial infection. One study reported a reduction in the risk of shock by 16 percent (95 percent CI 0.71–0.99) and in gastrointestinal bleeding by 1 percent (95 percent CI 0.98–0.99) per one total nurse hour per patient day. Two studies that assessed the relative risk of thrombo-embolic complications reported random changes in risk.^27,^ ^129^ Three studies that examined the risk of sepsis found only random changes in relation to nurse hours.^27,^ ^46,^ ^62^ Four studies that assessed the risk of pressure ulcers and total nurse hours did not detect significant changes.^27,^ ^62,^ ^129,^ ^151^ Two studies that assessed relative risk of pulmonary failure also showed random change in risk of the outcomes.^27,^ ^62^ The relative risk of hospital acquired pneumonia was not associated with total nurse hours.^27,^ ^62,^ ^81,^ ^129,^ ^151^ Nursing hours were not associated with failure to rescue in one study.^27^

Figure 13. Relative risk of patient outcomes corresponding to an increase by 1 hour in total nursing hours/patient day

Patient characteristics can influence the association between outcomes and nurse hours. (We rely here largely on broad definitions like surgical vs. medical patients.) The adjustment for comorbidities^28,^ ^29,^ ^36,^ ^65,^ ^75,^ ^76,^ ^139,^ ^153,^ ^154^ attenuated the effect of nursing hours on patient falls (p for interaction <.0001) and the risk of nosocomial infections and nurse hours per patient day (p for interaction = 0.001).^45,^ ^46,^ ^81^

Patient outcomes corresponding to an increase by 1 RN hour per patient day. The results of a pooled analysis of the rates of various patient outcomes (Appendix G, Tables G14–G15) corresponding to one additional RN hour per patient day (reported by the authors and estimated from RN FTE per patient day ratios) are presented in Table 15. The associations varied in different clinical settings. In ICUs, an additional RN hour per patient day was associated with a consistent reduction in patient falls by 0.06 ± 0.01 percent^61,^ ^64,^ ^75,^ ^139^and pulmonary failure by 1.43 ± 0.23 percent.^13,^ ^14,^ ^23^ In medical patients, a consistent reduction in bloodstream infection by 0.22 ± 0.09 percent was seen^22,^ ^26^–^28,^ ^45,^ ^47,^ ^79^ with a significant but not consistent decrease in pressure ulcers by 1.06 ± 0.32 percent.^26^–^28,^ ^33,^ ^36,^ ^61,^ ^63,^ ^64,^ ^76,^ ^77,^ ^154^–^156^

Table 15 Patient outcomes rates (%) corresponding to an increase by 1 hour in RN hours/patient day (pooled analysis reported by the authors and estimated RN hours/patient day)

Outcomes | Studies | Difference in Outcome Rate, % | Standard Error | p Value for the Association | Consistency
ICUs
Failure to rescue | 1 | -0.46 | 0.16 | 0.013
CPR | 4 | -0.10 | 0.01 | 0.001 | No
Falls | 4 | -0.06 | 0.01 | 0.001 | Yes
Urinary tract infection | 1 | 1.55 | 1.12 | 0.397 | Yes
Hospital acquired pneumonia | 3 | -0.46 | 0.25 | 0.210 | Yes
Nosocomial infection | 7 | 0.01 | 0.18 | 0.964 | Yes
Sepsis | 7 | -0.10 | 0.07 | 0.168 | Yes
Pressure ulcers | 4 | -0.19 | 0.48 | 0.760 | Yes
Pulmonary failure | 3 | -1.43 | 0.23 | 0.003 | Yes
Unplanned extubation | 3 | -0.92 | 0.07 | 0.000 | No
Surgical patients
Failure to rescue | 4 | -0.73 | 0.77 | 0.353 | No
CPR | 5 | -0.10 | 0.01 | 0.001 | No
Urinary tract infection | 7 | 3.22 | 1.47 | 0.039 | No
Hospital acquired pneumonia | 6 | 1.15 | 0.70 | 0.114 | No
Nosocomial infection | 3 | 0.60 | 0.08 | <.0001 | Yes
Sepsis | 7 | 0.73 | 0.45 | 0.120 | No
Surgical wound infection | 2 | 0.10 | 0.16 | 0.528 | No
Pressure ulcers | 4 | -0.04 | 1.02 | 0.966 | No
Gastrointestinal bleeding | 2 | 0.53 | 0.48 | 0.303 | No
Shock | 2 | 0.43 | 0.40 | 0.312 | No
Pulmonary failure | 7 | 1.14 | 0.63 | 0.081 | No
Unplanned extubation | 3 | -0.92 | 0.07 | 0.000 | No
Thrombosis | 4 | 0.20 | 0.15 | 0.203 | No
Medical patients
Failure to rescue | 3 | 0.05 | 0.10 | 0.612 | No
CPR | 3 | 0.44 | 0.03 | <.0001 | No
Falls | 11 | 0.33 | 0.05 | <.0001 | Yes
Urinary tract infection | 9 | 1.61 | 0.34 | <.0001 | No
Hospital acquired pneumonia | 6 | 0.66 | 0.17 | 0.000 | No
Nosocomial infection | 7 | 0.04 | 0.05 | 0.461 | No
Sepsis | 6 | -0.22 | 0.09 | 0.023 | Yes
Pressure ulcers | 12 | -1.06 | 0.32 | 0.002 | No
Gastrointestinal bleeding | 2 | 0.18 | 0.23 | 0.458 | No
Shock | 2 | 0.05 | 0.16 | 0.746 | No
Pulmonary failure | 2 | 0.01 | 0.01 | 0.280 | Yes
Thrombosis | 3 | 0.01 | 0.01 | 0.105 | No

Additional RN hours were associated with an increase in rates of urinary tract infection in surgical and medical patients and hospital acquired pneumonia in medical patients (heterogeneity significant for all these associations).

Pooled analysis of the adjusted relative risk is presented in Figure 14 with a significant but not consistent reduction in nosocomial infection by 24 percent (95 percent CI 0.69–0.83) corresponding to one additional RN hour per patient day (p for heterogeneity <0.01).^45,^ ^147^ One study reported a significant 21 percent reduction in the relative risk of central line associated bloodstream infections by (p <.0001) corresponding to an increase of one RN hour per patient day in surgical patients in ICUs.^147^ The large multi-center study showed a significant reduction by 1 percent in urinary tract infection in medical patients (RR 0.99, 95 percent CI 0.98–1) corresponding to one additional RN hour per patient day and absolute reduction by 3.6 percent in rates of urinary tract infection comparing 25^th^ and 75^th^ percentiles of RN hours. The same study also reported a relative reduction by 2 percent (RR 0.98, 95 percent CI 0.97–0.99) in upper gastrointestinal bleeding in medical patients per additional RN hour per patient day and a 5.2 percent absolute reduction in the rate of this outcome between the 25^th^ and 75^th^ quartiles of RN hours. We conducted a combined pooled analysis using measures reported by the authors and estimated from ratios of RN hours per patient day (Figure 15). Additional RN hours per patient day in ICUs were associated with a reduction in relative risk of hospital acquired pneumonia,^13,^ ^14,^ ^22^ pulmonary failure,^13,^ ^14,^ ^23,^ ^24^ unplanned extubation,^13,^ ^14,^ ^23^–^25^ and nosocomial infection.^22,^ ^45,^ ^47,^ ^79,^ ^147^ In surgical patients, the relative risk of failure to rescue was lower by 1 percent,^12,^ ^15,^ ^16,^ ^20,^ ^26,^ ^27,^ ^30,^ ^31^ unplanned extubation by nine percent,^13,^ ^23,^ ^24^ and cardiac arrest by four percent^13,^ ^23,^ ^24^ for every additional RN hour per patient day. Small reductions by 1 percent in relative risk of pulmonary failure^35,^ ^62^ and deep venous thrombosis^27,^ ^35^ was detected in medical patients.

Figure 14. Relative risk of patient outcomes corresponding to an increase by 1 hour in RN hours/patient day (pooled analysis)

Figure 15. Relative risk of outcomes corresponding to an increase by 1 hour in RN hours/patient day (pooled analysis combined from reported and estimated hours)

Patient outcomes corresponding to an increase by one LPN/LVN hour per patient day. Patient outcome rates from pooled analysis corresponding to one additional LPN/LVN hour per patient day are presented in Table 16. The crude rates of most outcomes increased corresponding to an additional one LPN/LVN hour per patient day; this raise was consistent across the studies (heterogeneity NS for all outcomes). However, additional LPN/LVN hours were associated with lower rates of several outcome in medical patients. Patient falls were lower by 0.21 ± 0.03 and sepsis was lower by 0.29 ± 0.12 percent per 1 LPN hour per patient day (heterogeneity NS).

Table 16 Patient outcomes rates (%) corresponding to an increase by 1 hour in LPN/LVN hours/patient day (pooled analysis)

Outcomes | Studies | Difference in Outcome Rate,% | Standard Error | p Value for the Association | Consistency
Surgical patients
Failure to rescue | 2 | 2.68 | 1.22 | 0.05 | Yes
Urinary tract infection | 3 | 6.63 | 0.60 | <.0001 | Yes
Hospital acquired pneumonia | 3 | 3.48 | 0.26 | <.0001 | Yes
Nosocomial infection | 1 | -2.70 | 4.61 | 0.62
Sepsis | 2 | 1.81 | 0.27 | <.0001 | Yes
Surgical wound infection | 2 | 0.35 | 0.08 | 0.001 | Yes
Pressure ulcers | 2 | 2.60 | 0.60 | 0.002 | Yes
Gastrointestinal bleeding | 2 | 1.28 | 0.15 | <.0001 | Yes
Shock | 2 | 1.04 | 0.15 | <.0001 | Yes
Pulmonary failure | 3 | 3.31 | 0.31 | <.0001 | Yes
Thrombosis | 3 | 0.67 | 0.06 | <.0001 | Yes
Medical patients
Failure to rescue | 2 | 1.25 | 0.89 | 0.19 | Yes
CPR | 2 | -0.26 | 0.02 | <.0001 | Yes
Falls | 3 | -0.21 | 0.03 | <.0001 | Yes
Urinary tract infection | 3 | 0.78 | 0.40 | 0.06 | No
Hospital acquired pneumonia | 3 | 0.81 | 0.28 | 0.01 | No
Sepsis | 2 | -0.29 | 0.12 | 0.04 | Yes
Pressure ulcers | 7 | -2.53 | 0.28 | <.0001 | No
Gastrointestinal bleeding | 2 | 0.56 | 0.11 | 0.001 | No
Shock | 2 | 0.35 | 0.10 | 0.01 | Yes
Pulmonary failure | 1 | -0.26 | 0.06 | 0.002
Thrombosis | 2 | 0.24 | 0.04 | 0.000 | Yes

Pooled analysis of the studies that analyzed relative risk of hospital acquired pneumonia^26,^ ^27,^ ^33,^ ^157^ and studies that assessed the risk of urinary tract infections^26,^ ^27,^ ^33,^ ^77,^ ^157^ did not find significant associations with LPN/LVN hours.

One study^158^ reported a reduction in the rate of thrombo-embolic complications by -0.3 ± 0.1 percent (p = 0.01), of pulmonary failure by -1.2 ± 0.2 percent (p = 0.002), and pneumonia by -1.7 ± 0.3 percent (p = 0.002) corresponding to one additional LPN/LVN hour per patient day (Appendix G, Table G16). One study detected a significant reduction by 87 percent in the relative risk of hospital acquired pneumonia (p = 0.004) for one LPN/LVN hour per patient day.^18^

Patient outcomes corresponding to an increase of one licensed hour per patient day. The rate of pressure ulcers,^64^ failure to rescue,^27,^ ^159^ falls,^64,^ ^65^ and CPR^159^ was not associated with licensed hours per patient day. One large study reported a reduction by 11 percent in risk of urinary tract infections (RR 0.89, 95 percent CI 0.8–0.99), by 1 percent in gastrointestinal bleeding (RR 0.987, 95 percent CI 0.98–1.00) and hospital-acquired pneumonia (RR 0.99 95 percent CI 0.98–1.00), and by 3–4 percent in pressure ulcers (RR 0.97, 95 percent CI 0.94–0.99) and bloodstream infections (RR 0.96 95 percent CI 0.95–0.97) corresponding to an additional licensed hour per patient day in surgical patient at hospital level analysis.^27^ The relative risk of shock,^27,^ ^159^ thrombosis,^27^ combined complications,^27^ and hospital-acquired pneumonia was not associated with licensed hours per patient day^27,^ ^159^

Patient outcomes corresponding to an increase by 1 UAP hour per patient day. The results of the pooled analysis of patient outcomes corresponding to 1 additional UAP hour per patient day are presented in Figure 16. An increase of 1 UAP hour per patient day was associated with a significant consistent reduction in pressure ulcers by 2.07 percent (0.88–3.26) (heterogeneity NS),^27,^ ^36,^ ^76^–^78^ patient falls by 0.2 percent (95 percent CI 0.14–0.26),^33,^ ^36,^ ^61,^ ^75,^ ^76,^ ^78^ and urinary tract infection by 1.26 percent (95 percent CI 0.16–2.36).^27,^ ^33,^ ^76^–^78^ We could find no studies that examined the relative risk of patient outcomes corresponding to UAP hours (Appendix G, Table G17).

Figure 16. Patient outcomes rates (%) corresponding to an increase by 1 hour in UAP hours/patient day (pooled analysis)

Length of stay corresponding to an increase by 1 nurse hour per patient day. The results from a pooled analysis of changes in the length of stay corresponding to 1 additional total nurse hour per patient day are presented in Figure 17. An additional total nurse hour per patient day was associated with a decreased LOS by 1.43 days (95 percent CI 0.31–2.25) in eight studies (heterogeneity NS),^26^–^28,^ ^36,^ ^45,^ ^48,^ ^82,^ ^83^ by 0.45 days in medical patients (95 percent CI 0.19–0.72, heterogeneity NS),^26^–^28,^ ^36,^ ^45,^ ^48,^ ^82,^ ^83^ and by 2.36 days in surgical patients (95 percent CI 1.34–3.39, heterogeneity NS).^26,^ ^27,^ ^48,^ ^82,^ ^83^ The association between RN hours per patient day and LOS was not consistent across the studies with random changes in the pooled estimate and significant heterogeneity in the results (p for heterogeneity = 0.05).^26^–^28,^ ^36,^ ^45^ The relationship between nurse staffing and LOS in medical patients showed conflicting results (p for heterogeneity = 0.0008).^26^–^28,^ ^36,^ ^45^ The studies in surgical patients did not find a significant association with RN hours (p for heterogeneity = 0.013).^26,^ ^27^

Figure 17. Changes in LOS corresponding to an increase by 1 nursing hour/patient day (pooled analysis)

The following table shows how quartiles of nurse hours were established.

Quartiles | ICU | Surgical Patients | Medical Patients
0 | <6.32 | <5.1 | <5.6
1 | 8.3 | 6.2 | 7.0
2 | 12.1 | 9.5 | 9.6
3 | >14.6 | >11.37 | >10.75

The studies that examined the association between LPN/LVN hours and LOS reported a significant increase by 3.21 days (95 percent CI 1.88–4.3) corresponding to an additional LPN/LVN hour.^26,^ ^27^ The effect was larger in surgical patients with an increase by 4.6 days for every LPN/LVN hour per patient day.^26,^ ^27^ An increase by 1.53 days (95 percent CI 0.93–2.13) in LOS corresponded to 1 additional UAP hour per patient day (heterogeneity NS).^27,^ ^36,^ ^45^ The increase in medical patients was 1.6 days (heterogeneity NS)^27,^ ^36,^ ^45^

Patient outcomes in quartiles of the distribution of nurse hours per patient day. We analyzed rates of patient outcomes among different quartiles of nurse hours per patient day distribution (Table 17). A decrease in nurse hours per patient day from 12.1 hours to 8.3 hours in ICUs was associated with an increase in the rate of patient falls by 0.76 ± 0.22 percent. A decrease in nurse hours per patient day from more than 11 vs. 9.5 hours in surgical patients was associated with an increase in the rate of failure to rescue by 3.22 ± 0.6 percent, surgical wound infection by 0.29 ± 0.05 percent, upper gastrointestinal bleeding by 0.81 ± 0.19 percent, shock by 0.68 ± 0.16 percent, pulmonary failure by 2.17 ± 0.5 percent, deep venous thrombosis by 0.42 ± 0.1 percent, urinary tract infection by 4.1 ± 0.85 percent, sepsis by 1.3 ± 0.24 percent, and pressure ulcers by 2.31 ± 0.31 percent. A reduction in the total nurse hours from more than 9.6 hours per patient day in medical patients was associated with a 0.36 ± 0.04 percent increase in the rate of shock, 2.49 ± 0.19 percent in urinary tract infection, and 1.35 ± 0.15 percent in hospital acquired pneumonia. The relative risk of failure to rescue was 8 percent higher in medical (RR 1.08, 95 percent CI 1.07–1.1) and 49 percent higher in surgical patients (RR 1.49, 95 percent CI 1.32–1.69). When we compared the highest and the lowest quartiles of RN hours per patient day (Figure 18), the relative risk of cardiopulmonary resuscitation was 1.52 times higher corresponding to a decrease from more than 16 to 8.2 RN hours per patient day in ICUs. In surgical patients, a reduction from more than 10 to 8.4 RN hours per patient day was associated with a 66 percent increase in the relative risk of cardiac arrest (RR 1.66, 95 percent CI 1.49–1.85). The relative risk of unplanned extubation was three times higher in ICUs (RR 3.12, 95 percent CI 1.97–4.96) corresponding to a decrease in RN hours per patient day from more than 16 to less than six.

Table 17 Differences in outcomes rates (%) in quartiles of total nursing hours/patient day distribution (pooled analysis)

Quartiles | Outcomes | Difference in Rate, % | Standard Error | p Value for the Association | Consistency
ICUs
1 vs. 2 | Falls | 0.76 | 0.22 | 0.02 | Yes
1 vs. 3 | Falls | 0.59 | 0.10 | 0.002
1 vs. 2 | Nosocomial infection | 7.24 | 1.97 | 0.01 | No
2 vs. 3 | Pressure ulcers | 1.13 | 7.33 | 0.89 | No
Surgical patients
2 vs. 3 | Failure to rescue | 3.22 | 0.68 | 0.001 | Yes
2 vs. 3 | Surgical wound infection | 0.29 | 0.05 | 0.00 | Yes
2 vs. 3 | Gastrointestinal bleeding | 0.81 | 0.19 | 0.002 | Yes
2 vs. 3 | Shock | 0.68 | 0.16 | 0.001 | Yes
2 vs. 3 | Pulmonary failure | 2.17 | 0.50 | 0.001 | Yes
2 vs. 3 | Thrombosis | 0.42 | 0.10 | 0.002 | Yes
2 vs. 3 | Falls | 0.36 | 1.51 | 0.83 | Yes
2 vs. 3 | Urinary tract infection | 4.10 | 0.85 | 0.000 | Yes
0 vs. 2 | Hospital acquired pneumonia | 4.39 | 97.60 | 0.97 | Yes
2 vs. 3 | Hospital acquired pneumonia | 2.01 | 0.53 | 0.003
2 vs. 3 | Sepsis | 1.30 | 0.24 | 0.000 | Yes
2 vs. 3 | Pressure ulcers | 2.31 | 0.31 | <.0001 | Yes
Medical patients
2 vs. 3 | Gastrointestinal bleeding | 0.51 | 0.06 | <.0001 | Yes
2 vs. 3 | Shock | 0.36 | 0.04 | <.0001 | Yes
2 vs. 3 | Thrombosis | 0.17 | 0.03 | 0.000 | Yes
1 vs. 3 | Falls | 7.62 | 1.55 | <.0001 | No
2 vs. 3 | Falls | 5.90 | 1.63 | 0.001
2 vs. 3 | Urinary tract infection | 2.49 | 0.19 | <.0001 | Yes
2 vs. 3 | Hospital acquired pneumonia | 1.35 | 0.15 | <.0001 | Yes

Figure 18. Relative risk of patient outcomes in quartiles of RN hours/patient day (pooled analysis of RN hours reported by the authors and estimated from RN ratios)

The following table shows how quartiles of nurse hours were established.

Quartiles | ICU | Surgical Patients | Medical Patients
0 | <6 | <4.2 | <4
1 | 8.2 | 5.4 | 4.9
2 | 12.9 | 8.4 | 6.9
3 | >16 | >10.1 | >8.1

In conclusion, the evidence from observational studies suggests that an increase in total nurse hours per patient day was associated with reduced hospital mortality, failure to rescue, nosocomial bloodstream and urinary tract infections, and other adverse events. The effects of RN hours substantially differ among the studies and patient population. A few studies suggest that LPN/LVN hours may increase the rates of sepsis, shock, urinary tract infections, and hospital inquired pneumonia in surgical patients. Additional UAP hours reduced the rate of pressure ulcers, patient falls, and urinary tract infection but not other outcomes. Increasing to more than 16 RN hours per patient day may reduce the risk of cardiopulmonary resuscitation, pulmonary failure, and unplanned extubation in ICUs. Increasing to more than 10 RN hours per patient day in surgical patients is associated with reduced risk of CPR, failure to rescue, and unplanned extubation. The LOS in hospitals is lower along with additional total nursing, but not LPN/LVN and UAP hours.

Evidence of the association between nurse characteristics and patient outcomes. Some evidence (Appendix G, Table G18) suggests that nurse experience and education can influence patient outcomes (Figure 19). The crude rates of complications were reduced by 1.13 percent (95 percent CI 1.9–0.36) for each additional year of nurse experience in surgical patients in the ICU.^16^ In the same study, an increase by 1 percent in the proportion of nurses with BSN degrees reduced the rate of failure to rescue by 0.04 percent (95 percent CI 0.06–0.02). The same study reported that an increase in the crude rate of failure to rescue corresponding to 1 year of nurse experience was not significant after adjustment for confounding factors (RR1.01, 95 percent CI 0.96–1.03). The authors reported a 5 percent reduction in failure to rescue corresponding to a 10 percent increase in the proportion of nurses with BSN degrees (RR 0.95, 95 percent CI 0.91–0.99).^16^ The adjusted relative risk of unplanned extubation in neonatal ICUs was not associated with nurse experience (relative risk 1.02, 95 percent CI 0.96–1.08 for an additional year of experience).^25^ Other studies did not show significant changes in pressure ulcers, patient falls, or urinary tract infections in relation to nurse experience and education.

Figure 19. Patient outcome rates corresponding to an increase in nurses' education and experience (results from individual studies)

Several nurse surveys assessed perceived nurses' satisfaction about patient outcomes^21,^ ^36,^ ^66,^ ^78,^ ^88,^ ^101,^ ^160^–^164^ (Appendix G, Table G19.) One large survey (8,760 nurses)^163^ examined the relative risk of adverse events among Medicare patients in relation to perceived quality of care. Nurses responded to the survey question, “In general, how would you describe the quality of nursing care delivered to patients in your unit on your last shift?” A reduction by 16 percent in the relative risk of patient falls and medication errors corresponded to a 30 percent increase in nurses satisfied with the care provided.^163^ An increase in the proportion of nurses' perceived work related stress by 40 percent increased the rates of patient falls by 1.1 percent.^66^ A 2 percent increase in nurse autonomy accompanied a 0.5 percent reduction in pressure ulcer rates.^162^ An increase in nurse turnover by approximately 2 percent increased the rate of patient falls by 0.2 percent.^36^

There is limited evidence suggesting better nurse staffing is associated with patient satisfaction with nursing care and pain management (Appendix G, Table G-20). In an early study of this phenomenon, larger proportions of patients treated in magnet-designated hospitals were satisfied with provided care compared with conventional (nonmagnet designated) general medical units (85 percent vs. 74 percent).^160^ Surgical patients in units using a total patient care model (larger proportion of RNs) were more satisfied with pain management compared with a team nursing model (84.6 ± 13 vs. 83.4 ± 13 scores on the Parkside Patient Satisfaction Survey).^165^ Medical patients in units with higher proportions of RNs with BSN degrees (54 percent) expressed satisfaction with care 1.5 times more often.^88^ An increase by 1 hour in total nurse hours per patient day was associated with an increase by 2.44 ± 0.62 patient satisfaction scores with pain management, an increase by 1 percent in the proportion of nurses with BSN degrees was associated with greater satisfaction by 13.6 ± 3.6 patient satisfaction scores.^154^ Some studies, however, did not detect a significant improvement in patient satisfaction in relation to nurse staffing.^77,^ ^78,^ ^166^

In conclusion, some evidence from a few observational studies suggests that an increase in nurses with BSN degrees may reduce the risk of hospital-related mortality and failure to rescue. Hospitals with higher proportions of nurses with BSN degrees (36 percent vs.11 percent) have lower mortality. States with larger proportions of BSN degrees report lower rates of fatal injuries related to health care. Nurses' perceived satisfaction may reflect the quality of care.

## Question 3. What Factors Influence Nurse Staffing Policies?

Policies related to nurse staffing in hospitals can vary. There may be policies related to the shift length, scheduling nurses to rotate to different shifts, mandatory overtime, weekend staffing, use of agency or temporary nurses, assigning nurses to nursing units other than those they are regularly assigned to work (floating), use of full-time, part-time, and internationally educated nurses, the nurse-to-patient ratio or nursing hours per patient day for nursing units, and the skill mix (licensed vs. unlicensed staff) of nursing units (Figure 2). Staffing policies can be influenced by patient and patient care unit factors. For example, the fluctuation of patient flow on a nursing unit may determine policies for the length of the shift for nurses. Nurse staffing policies can also be influenced in hospitals in which nurses are unionized or in which nurses have a strong governance structure. The age and/or tenure of nurses in a hospital may have an impact on policies regarding rotating shifts or frequency of working weekends.

Review of the literature to determine factors that can influence nurse staffing policies did not reveal any studies that empirically examined influences on nurse staffing policy. Rather, all studies found for this review examined one or more of the staffing policy variables. Thirty-six studies were identified as eligible and relating to one or more of the staffing policy variables. One hundred forty-seven studies were identified as eligible and relating to one or more of the staffing policy variables (Appendix G, Tables G21–G26). One hundred seventeen studies were excluded for the following reasons: not related to the variable of interest (87); from conference proceedings (2); an integrative review not related to the variables of interest (1); relevant to nursing homes (3); not in peer reviewed journals (17); inadequate presentation of data (6); not research (1). A review of 30 studies for each of the staffing policy variables is provided. For the staffing policy variable staffing ratio/mix/hours, the findings from the studies analyzed for questions 1, 2, and 4 are applied. The factors identified in Figure 2 were included in a few of the studies reviewed and will be described in the review for each of the staffing policy variables. Some studies addressed more than one staffing policy variable and are included in more than one evidence table.

### Staffing Ratios/Mix/Hours

The research literature related to nurse staffing ratios or hours and staff mix was comprehensively reviewed in the first two questions examined for this review using meta-analytic approaches. None of the studies empirically examined the effect or impact of a staffing policy related to staffing ratios/hours or staff mix. However, several studies examined the impact of the California mandated staffing ratios—an externally imposed staffing policy^64,^ ^109,^ ^162^ (Appendix G, Table G21). These findings should be cautiously used to inform staffing policies because these studies have limitations in their design and data sources.

Licensed nurses working in California acute care hospitals and nurse staffing in those hospitals were characterized prior to the implementation of mandated nurse staffing ratios.^109^ A low percentage of RNs (39 percent) have baccalaureate degrees and the mix of RNs ranged from 30 percent (sub-acute/transitional) to 84 percent (postpartum/labor/delivery) by different types of nursing care units. RN-to-patient ratios varied by type of hospital ownership in California (1:3.2 to 1:7.4)^162^ as well as RN skill mix (56.9 percent to 66.6 percent). Following the implementation of the mandated staffing ratios, total RN hours of care per patient day increased by 20.8 percent and the number of patients per RN decreased by 17.5 percent. There was no change in the use of contract staff. However, despite the increased exposure of patients to RN time, there was no reduction in falls, the prevalence of pressure ulcers, or restraint use.^64^

Two recent systematic reviews of nurse staffing and patient, nurse, and hospital outcomes reached basically similar conclusions.^92,^ ^93^ Both concluded that the studies reviewed had a number of limitations which implies caution in interpretation of the findings and translating findings to staffing policies (e.g., data from one unit or hospital, no control for case mix variations, variations in staffing and outcome measures, hospital level data, or data presented as regression coefficients which are difficult to interpret clinically). Other variables likely associated with quality of care should be considered for hospital staffing policies or legislated staffing ratios.^92^ These included acuity of the patients, skill mix, competence of nurses, technological support, and institutional support of nursing. This research supports probable relationships between richer nurse staffing and several patient and nurse outcomes; whereas another study showed strong support for the positive relationship between higher RN skill mix and improved outcomes.^93^

Studies with implications for staffing policies that were related to nurse-patient ratios or RN skill mix, but found to be ineligible for meta-analysis, are summarized in Appendix G, Table G21. A study conducted in 19 teaching hospitals in Ontario, Canada, supported the relationship between RN skill mix for patient, nurse, and hospital outcomes. The proportion of Regulated Nursing Staff (Canadian equivalent of RNs in the United States) was associated with better patient outcomes in regard to function, pain, satisfaction^167^ infections, nurses' perceptions of the quality of care, and fewer medication errors.^168,^ ^169^

Several studies found marginal, and in some cases diminishing effects, of increased RN staffing and patient outcomes. Greater than 15 nursing hours per patient day on medical and medical-surgical units no longer improved the patient fall rate; however, on surgical units, fall rates improved when nursing hours exceeded 15 hours.^170^ Diminishing effects of increased RN staffing on reducing the mortality ratio were also found.^18^

The findings from the meta-analyses in this report related to nurse-patient ratios/hours and RN skill mix and specifically examined the relationship between nurse staffing and patient and nurse outcomes. These studies did not examine relationships between hospital factors, patient factors, or nursing characteristics on nurse staffing policy variables. However, the findings from the meta-analyses conducted with these studies may have implications for nurse staffing policies regarding RN skill mix or nurse-to-patient ratios. The largest proportion of studies for the meta-analysis was associated with nurse to patient ratios and hospital related mortality. The findings indicate that a higher RN to patient ratio is associated with a decrease in hospital-related mortality. Nurses with baccalaureate degrees in nursing were associated with a reduction in mortality. Negative patient outcomes are also reduced by increasing the RN to patient ratio. There is less evidence for how LPNs/LVNs and UAPs reduce negative patient outcomes; in fact, there is a trend indicating that an increased LPN/LVN and UAP to patient ratio increases negative outcomes. The studies examining the relationship between RN hours per patient day differed substantially; however, there was stronger evidence that total nurse hours per patient day were associated with reduced mortality and negative patient outcomes. Again, there was a trend indicating that LPN/LVN and UAP hours per patient day were associated with increased negative patient outcomes. The findings from the meta-analysis examining nurse staffing ratios suggest hospital staffing policies that provide for a higher RN skill mix. If staffing ratios become part of a hospital staffing policy, they need to consider the type of patient as well as other factors that may impact desired patient and nurse outcomes (e.g., education of nurse, care delivery models, patient factors). Staffing policies that require regular evaluation of staffing effectiveness on patient care units serving different types of patients would seem essential.

Figure 2 suggests that nursing organizational factors have an intervening effect on the relationship between hospital factors and nurse staffing policies. None of the studies reviewed for question 3 supported this relationship, although several studies examined the direct relationship between hospital factors and nurse staffing policy variables. The technological sophistication of hospitals (technology level) was associated with a higher proportion of RNs on the unit.^171^ More sophisticated use of technology predicted increased RN hours.^162^ For-profit hospitals and for-profit systems had fewer RN productive hours for medical-surgical nursing units; however, this finding seemed to be driven by two large for-profit health systems in the sample.^162^ Another study did not find that ownership was related to nurse staffing variables.^172^ The two studies were conducted in two different states. They did find that the type of unit (patient care unit factors) affected hospital RN staffing. Intensive care, pediatric, and maternity units had significantly higher RN staffing than medical/surgical or gynecologic units. Controlling for size, rural hospitals also had higher RN staffing. Primary nursing, a nursing care delivery model, explained more than half of the variability in nurse staffing, using about one-third more RNs per occupied bed.^172^ While nursing care delivery models were not hypothesized in Figure 2 to be a factor influencing nurse staffing policies, it makes sense that it would be a factor because the primary nursing care delivery model relies on a higher proportion of RNs to be successfully implemented.

Shift work of nurses. Seven studies specifically focused on the length of shift nurses work (8, 10, and 12 hours) and the types of shifts nurses were scheduled to work (days, evenings, nights, or a combination) (Appendix G, Table G22). Two recent survey design studies examined the work patterns of hospital staff nurses. A survey of nurses who were members of the ANA (n=393)^173^ and a randomly selected sample of nurses who participated in the National Institute for Occupational Safety and Health (NIOSH) Nurse Worklife Survey (n = 2,273)^174^ both found that nurses were working long hours. Nurses worked, on average, 55 minutes longer than scheduled each day.^173^ Of the 5,317 shifts worked by the respondents during a 28 day period, 38.7 percent of the shifts were 12.5 hours or more. One quarter of the respondents worked 50 hours per week for two or more weeks of the 28-day period. More than half of hospital nurses were working 12 or more hours per day but half as likely to work 6–7 days a week, suggesting that more hospital nurses are working 12 hour shifts. Older nurses (≥50 years) were less likely to work long shifts.^174^

The likelihood of making medication and procedural errors (actual and near miss errors) increased with longer work hours and was three times higher when nurses worked shifts lasting 12.5 hours or longer.^173^ Age of the nurse (nurse factor), hospital size (hospital factor), or type of unit (unit factor) did not have any affect on errors or near errors. Among 687 RNs and LPNs surveyed in one hospital medication and procedural errors were associated with nurses that rotated shifts.^175^ In addition, nurses who rotated shifts had a higher risk of having an automobile accident or other injuries. Among nurses from across the country who worked in critical care units on the day (n = 67) and night shifts (n = 75) the ones who worked permanently on the night shift had significantly more depression and poorer global sleep quality than nurses on the day shift.^176^ There was no significant difference between night and day shift nurses in regards to chronic fatigue or anxiety. However, 46 percent of the variance in chronic fatigue was explained by depression and global sleep quality. There was no relationship between physical health and mental depression of nurses working the day, evening, night, and rotating shifts from five hospitals (n = 463).^177^ Nurses working 12-hour shifts experienced significantly higher levels of stress than nurses working 8-hour shifts, but the stress levels were similar when controlling for experience.^178^ Nurses working rotating shifts experienced higher stress and lower perception of job performance. Nurses working the night shift reported receiving the least amount of sleep and had the most trouble sleeping.^177^

The findings from these seven descriptive studies that used survey methodologies indicate that nurses are working long hours. Because more nurses are working 12-hour shifts (by preference), the risk of working more than 12 hours is high, given that nurses are often not able to finish their work by the end of their scheduled shift. There is beginning evidence that working more than 12 hours and rotating shifts can lead to errors that compromise patient safety as well as accidents, injuries, and higher stress levels of nurses. Implications for staffing policies indicate that the length of nurses' shifts should be no more than 12 hours and strategies should be implemented to limit work hours exceeding 12 hours. Requiring nurses to work rotating shifts should be curtailed.

Contract (agency) nurses. There is little research on the use of agency staff (Appendix G, Table G23). One descriptive study indicates that nurses choosing to work for a staffing agency are not necessarily motivated by nonsalary benefits and hospital nurses are not motivated by the higher salary paid to agency nurses.^179^ In that same survey, agency nurses were more likely to work evening and night shifts and weekends. The clinical activities differed by agency and hospital nurses reported having less opportunity to use their clinical skill.^180^ Nurse managers do not view agency nurses as cost effective but believe that using agency nurses reduces overtime and provides coverage for weekends, vacations, and absenteeism. Managers' perceptions of quality care of supplemental staff did not differ for hospital pool supplemental staff versus agency staff.^181^ Float pool nurses had the highest rate of documentation on two clinical aspects of patient care;^182^ however, there were significant limitations to the study, including being conducted on only one unit of a hospital and using medical record documentation as a measure of evaluating nursing care quality of agency staff. From a hospital efficiency perspective, agency nurses were associated with higher hospital operating cost.^50^

These studies provide limited insight to guide implications for staffing policies regarding agency nurses. It should be noted that a number of studies were found on the use of agency nurses, but these studies were conducted in countries other than the United States and Canada. Research is needed to evaluate the effectiveness and effective use of agency staff in hospitals as a means to provide adequate staffing for quality patient care.

Full- and part-time nurses. Few studies addressed the full or part time status of nurses (Appendix G, Table G24). There were discrepancies in the demographics reported for full- and part-time nurses. Two large surveys of Canadian nurses demonstrated these differences. In one, part-time nurses were reported to be older,^183^ whereas full-time nurses were older.^184^ This difference may be related to a 10-year difference in the time these studies were done. A trend in the studies was that full-time nurses experienced higher role overload,^185^ heavier workloads, higher levels of stress, and poorer physical wellbeing.^184^ Full-time nurses were statistically more involved in their job^183^ and more likely to be confident, independent, functioning as a leader and professional.^186^ Nurses who worked part time reported liking their work schedules more and experienced less interference between their work and nonwork activities. From an organizational perspective,^187^ Part-time nurses were associated with lower personnel and hospital costs.^50^

Internationally educated nurses. A strategy to address the nursing shortage and the growing demands of staffing in hospitals has been the utilization of IENs (Appendix G, Table G25). There is a paucity of research on the use and effectiveness of IENs in U.S. hospitals.^37^ The limited research available includes qualitative exploratory studies^38,^ ^39^ and descriptive studies^40^–^42^ that examined IEN use in healthcare. No studies empirically evaluated the interaction of IEN staffing policies with organizational, nurse, or patient care unit factors. Lack of research becomes more notable when it is recognized that IENs represent approximately 3.7 percent of the RN population within the United States.^37^ Understanding this demographic group may facilitate more effective integration and use of nurses who are educated in and emigrate from other countries.

IENs experience moderate to high levels of stress for up to 10 years after coming to the United States to practice nursing.^39^ IENs from India experienced racism within the work setting with recommendations for interventions to assist with acculturation.^38^ Other idiosyncrasies noted about IENs include the tendency to gravitate to critical care,^40,^ ^42^ younger in age,^37,^ ^42^ the majority from the Philippines,^37^ more likely to work full-time, night, and evening shifts and more overtime,^37^ baccalaureate educated,^37,^ ^42^ and half as likely to leave the organization.^37^ No differences were found between IENs and U.S. nurses when comparing perceptions of their control over practice or relationship with the physician,^41^ job satisfaction as it relates to time to do the job or quality of care,^42^ or general job satisfaction.^37,^ ^42^ Despite the lack of empirical evidence that articulates the relationship of IENs within the organization, the accumulation of these exploratory and descriptive data may assist in understanding human resource demographics more clearly. Further studies are warranted to understand healthful integration of IENs into the acute care system of the United States for the purpose of formulating organization policy.

Nurse overtime. Another staff policy to secure adequate staffing for increasing patient demands and scarce resources is the use of overtime (Appendix G, Table G26). Again, few studies were found in regards to this staffing variable. The prevalence of overtime has been documented in a recent national survey. Seventeen percent of randomly selected nurses reported required mandatory overtime and those whose jobs included mandatory overtime worked significantly longer work hours.^174^ Almost two-thirds of nurses, in a survey of RNs who were members of the ANA, worked overtime ten or more times during a 28-day period and more than 25 percent reported working mandatory overtime.^173^

Unionization does not seem to be effective in minimizing overtime. A review of overtime use in New York State hospitals for 5 years found that overtime was 22 percent higher for unionized nurses.^43^ Occupancy, average hourly wage, and hours in the average work week were not associated with RN overtime within hospitals. When controlling for year-to-year variations in overtime for each hospital, higher RN straight hours was significantly associated with higher RN overtime. Each 1 hour increase in straight time was associated with an 8.7 percent increase in overtime.^43,^ ^44^

RN overtime does not seem to be associated with the location of the hospital, teaching status of the hospital, average hours in a nurse's work week, acute bed occupancy, acute average daily census, or financial margin of the hospital^44^ however, an analysis of nurse overtime over 7 years in New York State hospitals found that overtime increased more in nongovernment unionized hospitals and nonteaching hospitals.^43^ Working overtime increased the odds of making at least one medication-related error and the risk of making errors increases when nurses work overtime after longer shifts.^173^ Weekend overtime is associated with anticipated turnover.^188^ Lost time claim rates were associated with increasing overtime worked by nurses.^189^ A few studies suggest that mandatory overtime and overtime in general is prevalent for nurses in U.S. hospitals. There is evidence that overtime and excessively long working hours can compromise patient safety and impact turnover of nurses. These findings suggest that practices related to nurse overtime and associated policies are important.

## Question 4. Association Between Nurse Staffing Strategies and Patient Outcomes

We defined eligible nurse staffing strategies as skill mix (proportion of productive [i.e., direct patient care related] hours worked by registered and licensed nurses), the proportion of overtime hours, contract hours, and the proportion of full-time nurses employed in patient care. The distribution of nurse staffing strategies is presented in Table 18. We identified 48 studies that assessed the proportion of RNs; eight studies addressed licensed nurses; 12 studies examined the effects of contract nurse hours on patient outcomes; and only a few studies evaluated overtime hours and the proportion of full-time nurses. The details on the sources used to measure nurse staffing strategies and on study design are presented in Appendix G, Tables G27–G28.

Table 18 The distribution of nurse skill and experience mix, nurse education, and proportion of temporary and full-time nurse hours

| Number of Studies | Mean | Standard Deviation | Median
% RN | 48 | 69.4 | 17.1 | 71.0
% licensed nurses | 8 | 81.1 | 7.5 | 86.0
% of nurses with BSN | 9 | 39.7 | 17.9 | 41.1
Experience in years | 12 | 10.1 | 2.8 | 10.0
% overtime hours | 2 | 11.7 | 6.5 | 15.8
% temporary nurses | 12 | 16.2 | 12.6 | 13.0
% full-time nurses | 3 | 78.0 | 11.3 | 78.0

### Patient Outcomes Corresponding to an Increase by 1 Percent in the Proportion of RNs

Studies examined the effects of changes in categories of nurse staffing patterns including not only the proportion of RNs, but nurse hours and ratios on a number of outcomes. Pooling these results with random effects models to examine the main effect of the nursing skill mix on patient outcomes detected substantial heterogeneity between studies. For instance, heterogeneity was significant when pooling eight studies that examined the rates of in-hospital mortality (p for heterogeneity = 0.04),^26,^ ^28,^ ^33,^ ^52,^ ^139,^ ^140,^ ^146,^ ^190,^ ^191,^ eight studies that measured the rates of nosocomial infections (p <0.001),^22,^ ^45,^ ^81,^ ^139,^ ^192^–^194^ and 11 studies that evaluated the rates of pressure ulcers in relation to nursing skill mix (p for heterogeneity <0.001).^26,^ ^28,^ ^33,^ ^36,^ ^61,^ ^64,^ ^76,^ ^77,^ ^81,^ ^151,^ ^162^

To estimate whether the direction or strength of the associations can explain the massive differences in the results, we calculated and compared the rates of outcomes in individual studies (Appendix G, Table G28) when possible (Table 19). Three studies reported significant reductions in mortality^140,^ ^190,^ ^191^ by 0.1–0.4 percent; one unpublished dissertation showed a small but significant increase in mortality^86^ by 0.04 percent; the rest did not find significant associations. The same unpublished study reported a small increase in pulmonary failure and other patient outcomes corresponding to an increase in RNs.^33^ Random changes in the rates of nosocomial infections were shown in the majority of the studies. One study detected a reduction in hospital-acquired pneumonia by 0.02 percent (95 percent CI 0.01–0.02).^28^ A seemingly paradoxical finding was the increase in the rates of urinary tract infections in four studies, with a significant increase by 0.05–0.11 percent for each increase in the percent of RNs in two reports.^28,^ ^33^ One study^139^ reported nonlinear association in patient falls and pressure ulcers: the rates increased when more than 87.5 percent of RNs worked in units. Pooled analysis (Figure 20) detected a significant reduction in patient falls by 0.03 percent (95 percent CI 0.03–0.04) corresponding to one additional percent of RNs in ICUs. Rates of patient outcomes were increased in medical and surgical patients per additional percent of RNs.

Table 19 Calculated changes in rates of patient outcomes corresponding to an increase by 1% in the proportion of RNs

Author, Analytic Unit | Hospital Unit | Patients | Outcome | Difference in Rate, % | 95% CI
Hospital
Krakauer^191^ | Combined | Medical | Mortality | -0.095 | -0.13; -0.06
Hartz^190^ | Combined | Medical | Mortality | -0.387 | -0.58; -0.19
Hospital and Patient
Cho^28^ | Combined | Medical | Mortality | 0.085 | -0.03; 0.20
Aiken^52^ | Combined | Medical | Mortality | -0.001 | -0.001; -0.001
Tourangeau^140^ | Combined | Medical | Mortality | -0.086 | -0.16; -0.01
Cho^28^ | Combined | Surgical | Surgical wound infection | 0.057 | -0.01; 0.13
Cho^28^ | Combined | Medical | Urinary tract infection | 0.107 | 0.09; 0.12
Cho^28^ | Combined | Medical | Pneumonia | -0.017 | -0.02; -0.02
Cho^28^ | Combined | Medical | Pressure ulcers | -0.024 | -0.04; -0.004
Cho^28^ | Combined | Medical | Falls | -0.001 | -0.02; 0.02
Hospital and unit
Needleman^26^ | Combined | Medical and surgical | Sepsis | 0.065 | -0.22; 0.35
Patient
Unruh^33^ | Combined | Combined | Mortality | 0.039 | 0.04; 0.04
Unruh^33^ | Combined | Combined | Pulmonary failure | 0.009 | 0.007; 0.01
Unruh^33^ | Combined | Combined | Cardiopulmonary resuscitation | 0.008 | 0.01; 0.01
Hope^22^ | Medical and surgical | Medical and surgical | Nosocomial infection | 0.000 | -0.01; 0.01
Hope^22^ | Medical and surgical | Medical and surgical | Urinary tract infection | 0.082 | -0.06; 0.22
Simmonds^192^ | Specialized | Medical | Nosocomial infection | -0.546 | -1.28; 0.20
Unruh^33^ | Combined | Surgical | Surgical wound infection | 0.004 | 0.004; 0.004
Unruh^33^ | Combined | Combined | Pneumonia | 0.019 | 0.02; 0.02
Unruh^33^ | Combined | Combined | Urinary tract infection | 0.051 | 0.02; 0.08
Zidek^36^ | Combined | Medical | Pressure ulcers | 0.015 | -0.03; 0.06
Zidek^36^ | Combined | Medical | Falls | 0.002 | -0.08; 0.08
Unruh^33^ | Combined | Combined | Falls | 0.007 | 0.001; 0.01
Seago^166^ | Combined | Medical | Pressure ulcers | 0.027 | -0.10; 0.16
Seago^166^ | Combined | Medical | Falls | 0.020 | -0.05; 0.09
Seago^154^ | Combined | Medical | Falls | -0.047 | -0.07; -0.02
Unit
Blegen^29^ | Combined, ICU, specialized | Medical and surgical | Mortality | -1.449 | -3.4; 0.5
Ritter-Teitel^76^ | Medical and surgical | Medical and surgical | Urinary tract infection | 0.124 | -0.83; 1.07
Stratton^193^ | Combined, ICU, specialized | Medical and surgical | Nosocomial infection | 0.033 | 0.02; 0.05
Blegen^29^ | Combined, ICU, specialized | Medical and surgical | Nosocomial infection | -6.302 | -8.16; -4.44
Ritter-Teitel^76^ | Medical and surgical | Medical and surgical | Pressure ulcers | -0.111 | -0.94; 0.72
Ritter-Teitel^76^ | Medical and surgical | Medical and surgical | Falls | 0.006 | -0.24; 0.25
Blegen^29^ | Combined, ICU, specialized | Medical and surgical | Pressure ulcers | -5.308 | -6.32; -4.29
Blegen^29^ | Combined, ICU, specialized | Medical and surgical | Falls | -0.015 | -0.51; 0.48
Potter^75^ | ICU | Medical | Falls | -0.048 | -0.12; 0.06
Donaldson^64^ | Step-down, Medical and surgical units | Medical and surgical | Pressure ulcers | 0.121 | -0.13; 0.37
Donaldson^64^ | Step-down, Medical and surgical units | Medical and surgical | Falls | -0.059 | -0.17; 0.01

Figure 20. Calculated changes in rates of patient outcomes corresponding to an increase by 1% in the proportion of RNs (pooled analysis)

The analysis of the adjusted relative risks of patient outcomes corresponding to an increase by 1 percent in RN composition is presented in Figure 21. Random changes in the relative risk of all patient outcomes were observed corresponding to each additional percent of RN time. One large study^27^ contributed the most to the analysis. One study reported a 16 percent reduction in hospital-related mortality in hospitals with 83 percent of RNs compared with 63 percent (RR 0.84 percent CI 0.78–0.92).^195^ Three studies reported a tendency to reduce mortality,^8,^ ^26,^ ^101^ and one large study^27^ found substantial differences in the association with mortality in different levels of analysis and patient populations, which resulted in significant statistical heterogeneity in the results (p for heterogeneity <0.001) (Figure 22). The same study,^27^ however, reported a consistent reduction in failure to rescue by 27 percent (RR 0.73, 95 percent CI 0.65–0.83) for an additional percent of RN staffing. Pulmonary failure (Figure 23) was not associated with the proportion of RNs in one study.^27^ Another study reported a nonsignificant reduction by 25 percent (RR 0.11–4.98) in relative risk of pulmonary failure corresponding to doubling the proportion of RNs.^62^ The relative risk of shock was reduced by 41 percent for each additional percent of RN staffing in a large multi-hospital study.^27^ The studies did not show significant associations with nosocomial infections, surgical wounds infections, and bloodstream infections. One study reported a significant reduction in the risk of urinary tract infections in surgical patients.^27^ Overall complications and thrombo-embolic complications increased with the increase in the proportion of RNs.^27^ An increase by 1 percent in the proportion of RN staffing was associated with a reduction in the risk of upper gastrointestinal bleeding by 42 percent (RR 0.58, 95 percent CI 0.4–0.84) and in pressure ulcers by 76 percent (RR 0.24, 95 percent CI 0.09–0.62) across different settings and patient populations in one study (Figure 24).^27^ The same study reported a reduction in the relative risk of urinary tract infection in medical (RR 0.48, 95 percent CI 0.38–0.91) and in surgical patients (RR 0.67, 95 percent CI 0.46–0.98), upper gastrointestinal bleeding (RR 0.66, 95 percent CI 0.45–0.96), hospital acquired pneumonia (RR 0.59, 95 percent CI 0.44–0.8), and shock (RR 0.46, 95 percent CI 0.27–0.81) corresponding to an increase by 1 percent in the proportion of RN hours among licensed hours per patient day.^27^

Figure 21. Relative risk of patient outcomes corresponding to an increase by 1% in the proportion of RNs (pooled analysis)

Figure 22. Relative risk of hospital related mortality and failure to rescue corresponding to an increase by 1% in the proportion of RNs (results from individual studies and pooled estimates)

Figure 23. Relative risk of patient outcomes corresponding to an increase by 1% in the proportion of RNs (results from individual studies and pooled estimates)

Figure 24. Relative risk of treatment complications corresponding to an increase by 1% in the proportion of RNs (results from individual studies and pooled estimates)

A higher proportion of RNs was associated with shorter lengths of stay by 0.17 days (95 percent CI 0.03–0.3) but the association was not consistent across studies (p for heterogeneity <0.001). The effect was significant in medical patients only with a decrease by 0.19 days for each 1 percent of RN staffing (95 percent CI 0.1–0.28) but still not consistent (p for heterogeneity <0.05).^26,^ ^28,^ ^33,^ ^36,^ ^45,^ ^48,^ ^146,^ ^150,^ ^194^

### Patient Outcomes Corresponding to an Increase by 1 Percent in the Proportion of Licensed Nurses

Eight studies attempted to assess the proportion of licensed nurses in relation to patient outcomes^26,^ ^27,^ ^30,^ ^31,^ ^35,^ ^63^–^65,^ ^159^ (Table 20 and Figures 25–26) but one study^27^ contributed most of the data for the overall estimates. An increase by 1 percent in the proportion of licensed nurses was associated with a 17 percent reduction in the risk of failure to rescue (RR 0.83, 95 percent CI 0.78–0.87) (Figure 25). Hospital-related mortality was reduced by 3 percent (RR 0.97, 95 percent CI .95–0.98) for every additional percent of licensed nurses. Cardiac arrest occurred 0.59 times less often in association with a 1 percent increase in the proportion of licensed nurses in medical and surgical patients (RR 0.59, 95 percent CI 0.49–0.71) (Figure 26). Pulmonary failure demonstrated random changes in relation to nurse skill mix. Every additional percent of licensed nurses was associated with a 47 percent reduction in the relative risk of shock (RR 0.53, 95 percent CI 0.46–0.61). The risk of hospital acquired pneumonia was reduced by 29 percent (RR 0.71, 95 percent CI 0.63–0.8) in relation to every additional percent of licensed nurses, but the strength of the association differed across patient populations (p for heterogeneity = 0.02). Among other nosocomial infections, the risk of urinary tract infections was reduced by 13 percent (RR 0.87, 95 percent CI 0.83–0.9), while the risk of surgical wound infection and bloodstream infections was increased by 60 percent as reported in one study.^27^ The same negative tendency was observed in the risk of thrombo-embolic complications, where a 29 percent increase corresponded to an additional percent of licensed staff (RR 1.29, 95 percent CI 1.08–1.54). One study reported a significant increase in the length of stay by 0.05 days (95 percent CI 0.04–0.05) for each additional 1 percent of licensed nurses.^35^

Table 20 Relative risk of patient outcomes corresponding to an increase by 1% in licensed nurse hours

Outcomes | Relative Risk | 95% CI
Author (patients)
Failure to rescue
Needleman^27^ (medical) | 0.81 | 0.66; 1.00
Needleman^27^ (surgical) | 0.73 | 0.49; 1.09
Needleman^27^ (medical) | 0.90 | 0.80; 1.01
Needleman^27^ (surgical) | 0.82 | 0.70; 0.96
Needleman^27^ (medical) | 0.58 | 0.40; 0.86
Needleman^27^ (medical) | 0.69 | 0.50; 0.95
Needleman^27^ (surgical) | 0.45 | 0.22; 0.92
Needleman^27^ (surgical) | 0.54 | 0.30; 0.99
Needleman^27^ (medical) | 0.80 | 0.64; 0.97
Needleman^27^ (surgical) | 0.81 | 0.68; 0.94
Needleman^27^ (surgical) | 0.70 | 0.37; 1.03
Needleman^27^ (surgical) | 0.72 | 0.42; 1.01
Needleman^7^ (medical) | 0.90 | 0.80; 1.00
Needleman^27^ (medical) | 0.81 | 0.64; 0.99
Needleman^27^ (medical) | 0.81 | 0.66; 1.00
Cheung^63^ (medical) | 1.00 | 1.00; 1.00
Mortality
Berney^30^ (surgical) | 0.97 | 0.95; 0.98
Needleman^27^ (medical) | 0.90 | 0.74; 1.09
Needleman^27^ (surgical) | 0.99 | 0.67; 1.47
Needleman^27^ (medical) | 0.98 | 0.90; 1.08
Needleman^27^ (surgical) | 0.88 | 0.75; 1.03
Needleman^27^ (medical) | 0.91 | 0.65; 1.27
Needleman^27^ (medical) | 0.89 | 0.68; 1.16
Needleman^27^ (surgical) | 0.76 | 0.34; 1.69
Needleman^27^ (surgical) | 0.87 | 0.47; 1.61
Needleman^27^ (medical) | 0.90 | 0.74; 1.09
CPR
Needleman^27^ (surgical) | 0.59 | 0.42; 0.76
Needleman^27^ (surgical) | 0.42 | 0.10; 0.74
Needleman^27^ (surgical) | 0.60 | 0.19; 1.00
Needleman^27^ (medical) | 0.66 | 0.48; 0.85
Needleman^27^ (medical) | 0.40 | 0.18; 0.63
Pulmonary failure
Needleman^27^ (surgical) | 1.10 | 0.63; 1.92
Needleman^27^ (surgical) | 1.21 | 0.99; 1.47
Needleman^27^ (surgical) | 1.00 | 0.39; 2.60
Needleman^27^ (surgical) | 1.02 | 0.45; 2.32
Shock
Needleman^27^ (medical) | 0.46 | 0.27; 0.81
Needleman^27^ (surgical) | 0.54 | 0.28; 1.04
Needleman^27^ (medical) | 0.66 | 0.50; 0.87
Needleman^27^ (surgical) | 0.59 | 0.44; 0.78
Needleman^27^ (medical) | 0.20 | 0.08; 0.53
Needleman^27^ (medical) | 0.40 | 0.19; 0.86
Needleman^27^ (surgical) | 0.22 | 0.09; 0.57
Needleman^27^ (surgical) | 0.27 | 0.12; 0.61
Needleman^27^ (medical) | 0.49 | 0.21; 0.77
Needleman^27^ (surgical) | 0.59 | 0.42; 0.76
Needleman^27^ (surgical) | 0.42 | 0.10; 0.74
Needleman^27^ (surgical) | 0.60 | 0.19; 1.00
Needleman^27^ (medical) | 0.66 | 0.48; 0.85
Needleman^27^ (medical) | 0.40 | 0.18; 0.63
Needleman^27^ (medical) | 0.46 | 0.27; 0.81
Nosocomial Infection
Cheung^63^ (medical) | 1.00 | 1.00; 1.00
Pneumonia
Needleman^27^ (medical) | 0.60 | 0.44; 0.80
Needleman^27^ (surgical) | 0.56 | 0.31; 1.01
Needleman^27^ (medical) | 0.83 | 0.71; 0.98
Needleman^27^ (surgical) | 0.94 | 0.76; 1.16
Needleman^27^ (medical) | 0.52 | 0.32; 0.87
Needleman^27^ (medical) | 0.69 | 0.47; 1.03
Needleman^27^ (surgical) | 0.66 | 0.26; 1.69
Needleman^27^ (surgical) | 0.79 | 0.37; 1.71
Needleman^27^ (medical) | 0.61 | 0.42; 0.79
Needleman^27^ (surgical) | 0.94 | 0.74; 1.13
Needleman^27^ (surgical) | 0.36 | 0.12; 0.59
Needleman^27^ (surgical) | 0.52 | 0.20; 0.84
Needleman^27^ (medical) | 0.83 | 0.70; 0.96
Needleman^27^ (medical) | 0.59 | 0.39; 0.78
Needleman^27^ (medical) | 0.59 | 0.44; 0.80
Surgical wound infection
Needleman^27^ (surgical) | 1.91 | 1.34; 2.48
Needleman^27^ (surgical) | 0.93 | 0.24; 1.62
Needleman^27^ (surgical) | 1.33 | 0.53; 2.13
Sepsis
Needleman^27^ (medical) | 1.39 | 0.85; 1.94
Needleman^27^ (surgical) | 1.10 | 0.85; 1.35
Needleman^27^ (surgical) | 0.86 | 0.30; 1.42
Needleman^27^ (surgical) | 1.11 | 0.47; 1.74
Needleman^27^ (medical) | 1.24 | 0.97; 1.51
Needleman^27^ (medical) | 1.11 | 0.65; 1.56
Needleman^27^ (medical) | 1.01 | 1.00; 1.01
Berney^30^ (surgical) | 1.01 | 1.00; 1.01
Urinary tract infection
Needleman^27^ (medical) | 0.48 | 0.38; 0.61
Needleman^27^ (surgical) | 0.67 | 0.46; 0.98
Needleman^27^ (medical) | 0.77 | 0.68; 0.86
Needleman^27^ (surgical) | 0.89 | 0.75; 1.07
Needleman^27^ (medical) | 0.44 | 0.28; 0.70
Needleman^27^ (medical) | 0.60 | 0.41; 0.87
Needleman^27^ (surgical) | 0.64 | 0.30; 1.37
Needleman^27^ (medical) | 0.49 | 0.37 0.61
Needleman^27^ (surgical) | 0.88 | 0.71; 1.04
Needleman^27^ (surgical) | 0.68 | 0.40; 0.95
Needleman^27^ (surgical) | 0.59 | 0.36; 0.82
Needleman^27^ (medical) | 0.76 | 0.67; 0.85
Needleman^27^ (medical) | 0.54 | 0.41; 0.66
Needleman^27^ (medical) | 0.48 | 0.38; 0.61
Berney^30^ (medical) | 1.00 | 0.99; 1.00
Berney^30^ (surgical) | 1.00 | 0.99; 1.00
Complications
Needleman^27^ (surgical) | 2.43 | 1.00; 5.93
Needleman^27^ (medical) | 1.86 | 1.32; 2.62
Needleman^27^ (surgical) | 1.62 | 1.02; 2.56
Needleman^27^ (medical) | 1.44 | 0.39; 5.32
Needleman^27^ (medical) | 1.04 | 0.32; 3.35
Needleman^27^ (surgical) | 4.13 | 0.53; 32.25
Needleman^27^ (surgical) | 1.83 | 0.32; 10.49
Gastrointestinal bleeding
Needleman^27^ (medical) | 0.66 | 0.46; 0.96
Needleman^27^ (surgical) | 0.57 | 0.28; 1.15
Needleman^27^ (medical) | 0.96 | 0.79; 1.16
Needleman^27^ (surgical) | 0.78 | 0.59; 1.03
Needleman^27^ (medical) | 0.83 | 0.40; 1.72
Needleman^27^ (medical) | 0.87 | 0.48; 1.58
Needleman^27^ (surgical) | 0.72 | 0.22; 2.37
Needleman^27^ (surgical) | 0.63 | 0.23; 1.71
Needleman^27^ (surgical) | 0.77 | 0.56; 0.98
Needleman^27^ (surgical) | 0.40 | 0.07; 0.74
Needleman^27^ (surgical) | 0.53 | 0.15; 0.90
Needleman^27^ (medical) | 0.96 | 0.77; 1.15
Needleman^27^ (medical) | 0.68 | 0.42; 0.95
Needleman^27^ (medical) | 0.66 | 0.45; 0.96
Berney^30^ (medical) | 1.00 | 1.00; 1.01
Berney^30^ (surgical) | 1.01 | 1.00; 1.01
Pressure ulcers
Cheung^63^ (medical) | 1.00 | 1.00; 1.00
Needleman^27^ (medical) | 0.73 | 0.49; 1.08
Needleman^27^ (surgical) | 1.38 | 0.69; 2.78
Needleman^27^ (surgical) | 0.94 | 0.74; 1.19
Needleman^27^ (medical) | 0.35 | 0.15; 0.79
Needleman^27^ (medical) | 0.55 | 0.28; 1.06
Needleman^27^ (surgical) | 0.68 | 0.18; 2.52
Needleman^27^ (surgical) | 0.71 | 0.26; 1.94
Needleman^27^ (medical) | 0.77 | 0.46; 1.07
Needleman^27^ (surgical) | 0.90 | 0.68; 1.12
Needleman^27^ (surgical) | 0.81 | 0.14; 1.49
Needleman^27^ (surgical) | 0.83 | 0.24; 1.41
Needleman^27^ (medical) | 0.89 | 0.70; 1.09
Needleman^27^ (medical) | 0.71 | 0.40; 1.02
Thrombosis
Needleman^27^ (medical) | 1.39 | 0.92; 2.11
Needleman^27^ (surgical) | 1.29 | 0.66; 2.54
Needleman^27^ (medical) | 1.28 | 1.02; 1.60
Needleman^27^ (surgical) | 1.52 | 1.12; 2.07
Needleman^27^ (medical) | 1.97 | 0.84; 4.58
Needleman^27^ (Medical) | 1.55 | 0.78; 3.07
Needleman^27^ (surgical) | 0.03 | 0.00; 0.66
Needleman^27^ (surgical) | 1.11 | 1.04; 1.18

Figure 25. Relative risk of hospital related mortality and failure to rescue corresponding to an increase by 1% in the proportion of licensed nurses

Figure 26. Relative risk of patient outcomes corresponding to an increase by 1% in the proportion of licensed nurses

### Patient Outcomes Corresponding to an Increase by 1 Percent in Overtime Hours

Two studies^30,^ ^193^ examined the association between overtime hours and patient outcomes (Appendix G, Table G29). Every additional 10 percent of overtime hours was associated with a 1.3 percent increase in hospital related mortality (RR 1.013, 95 percent CI 1.0001–1.65).^30^ The association was nonlinear (p = 0.006) with an increase in hospital-related mortality by 32 percent corresponding to an increase in overtime hours by 10 percent from nadir (7 percent) to 17 percent.

The rate of nosocomial infections increased by 1.9 percent (95 percent CI 0.3–3.5 percent) with each additional percent of overtime hours.^193^ The relative risk of shock increased by 12 percent in medical but not surgical patients (RR 1.12, 95 percent CI 1.001–1.24) corresponding to a 5 percent increase in overtime hours.^31^ The relative risk for bloodstream infections increased by 11.5 percent in surgical (RR 1.12, 95 percent CI 1.021–1.22) and by 14 percent in medical patients (RR 1.14, 95 percent CI 1.05–1.24).^31^ That study did not find an association between overtime hours and urinary tract infections, failure to rescue, or gastrointestinal bleeding.

### Patient Outcomes Corresponding to an Increase by 1 Percent in Contract Hours

The majority of the studies that reported the proportion of contract hours did not examine the main effect of temporary nurses; rather they reported patient outcomes in units and hospitals with different staffing patterns including nursing ratios and hours. Some authors distinguished contract hours from hours worked by float nurses;^28,^ ^46,^ ^64,^ ^193^ others included the hours worked by float nurses as temporary hours.^45,^ ^47^ One study showed no association between contract hours and the rates of urinary tract infections, pneumonia, pressure ulcers, surgical wound infections, or bloodstream infections.^28^ Two studies reported an increase in rates of patient falls corresponding to additional contract hours.^28,^ ^64^ A small increase in the rate of nosocomial infections corresponded to an increase in contract hours,^193^ but another study did not find a significant association after adjustment for other factors.^46^ In contrast with contract hours, the proportion of float nurses was positively associated with the risk of nosocomial infection. The risk was 2.61–2.71 times higher in patients cared for in units with more than 60 percent of float nurses.^47^ Another study reported an increase in the rate of bloodstream infection by 5 percent corresponding to a 23 percent increase in the proportion of float nurses.^45^ Summarizing the results from two studies^46,^ ^47^ that examined the risk of sepsis in relation to float nurses, the risk was 2.79 time higher for every percent increase in float hours (RR 2.8, 95 percent CI 2.8–2.79). An increase in the proportion of temporary nurses by 1 percent of contract hours increased the length of stay by 0.1 day (RR 0.11, 95 percent CI 0.03–0.18, heterogeneity NS).^28,^ ^45,^ ^48,^ ^50^

In conclusion, some evidence from a few multi-hospital studies suggests that a higher proportion of RNs may reduce the risk of failure to rescue, shock, pressure ulcers, and gastrointestinal bleeding. A significant but not consistent reduction on LOS in medical patients was observed pooling the results from 12 studies.

Overtime hours may increase the risk of hospital-related mortality and bloodstream infections. An increase in contract hours may increase in-hospital LOS. A small amount of evidence suggests that an increase in hours worked by float nurses is associated with a large increase in the risk of bloodstream infections.