# Methods

## Literature Search Strategy and Eligibility Criteria

### Search Strategy

Studies were sought from a wide variety of sources, including MEDLINE^®^, PubMed^®^, CINAHL, Cochrane databases, EBSCO research database, BioMed Central, federal reports, National Database of Nursing Quality Indicators, National Center for Health Workforce Analysis, American Nurses Association, American Academy of Nurse Practitioners, and Digital Dissertations. The search strategies for the four research questions are described in Appendix A *. The same eligibility criteria, selection of studies, and analysis of studies were used to examine the association between nurse staffing and strategies and patient outcomes. The approach was different to identify studies that examined factors that influence nurse staffing policies. As noted earlier, the question about policies was not appropriate for meta-analysis. Excluded references are shown in Appendix B. All work was conducted under the guidance of a Technical Expert Panel (TEP). Members are identified in Appendix C. The data abstraction forms are shown in Appendix D.

* Appendixes and Evidence Tables for this report are provided electronically at http://www.ahrq.gov/clinic/tp/nursesttp.htm

### Eligibility

Two investigators independently decided on the eligibility of the studies.^118^ We reviewed abstracts to exclude studies with ineligible target populations conducted in countries other than the United States and Canada and in long-term nursing facilities. Then we confirmed the eligibility status of the study designs, excluding secondary data analysis, reviews, letters, comments, legal cases, and editorials. The full texts of the original epidemiologic studies were examined to define eligible independent variables (nurse staffing and strategies) and eligible outcomes. Then we excluded studies that did not test the associative hypotheses and did not provide adequate information on tested hypotheses (e.g., least square means, relative risk).

Inclusion criteria were applied to select articles for full review. Studies needed to meet one of the following criteria for questions 1, 2, and 4:

- Retrospective observational cohort studies and retrospective cross sectional comparisons
- Administrative cross-sectional survey and analyses;
- Randomized controlled trials with random allocation of subjects to intervention and control groups
- Controlled not randomized clinical trials^2^
  2 The literature in this area contained no randomized controlled trials or even non-randomized trials.
- The studies must evaluate the associations between nurse staffing and patient outcomes/nurse quality measures among eligible target populations (patients hospitalized in acute care hospitals in the United States and Canada) and published after 1990 except conducted in 1982-1989 but frequently cited in recent publications
- Ecologic studies on correlations between nurse staffing and patients outcomes
- Cost-effectiveness analysis of nurse staffing

Studies were selected for question 3 if the study provided implications for nurse staffing policies. No studies had as a primary purpose to empirically examine a specific nurse staffing policy.

The exclusion criteria included the following:

- Studies published before 1990
- Studies conducted in countries other than United States and Canada and not published in the English language
- Studies with target population as outpatients and patients in long-term care facilities
- Studies with no information relevant to nurse staffing policies and strategies
- Studies that examined the contributions of advance practice nurses (nurse practitioners, nurse clinicians, certified nurse midwives, nurse anesthetists)
- Studies that evaluated the association between nurse staffing and ineligible outcomes (questions 1, 2, and 4)
- Administrative reports and single hospital studies with no control comparisons that do not test an associative hypothesis (questions 1, 2, and 4)

The assessment of the studies' quality was based on “Systems to Rate the Strength of Scientific Evidence.”^119^ For questions 1, 2, and 4 we grouped all criteria into ten dimensions with scores for each aspect assigned a value from 0 to 5 (highest) for a total possible score of 50 for the statistical analysis of the studies' quality (Appendix E).

Given the absence of RCTs, the level of evidence for all studies was estimated using a subset of the U.S. Preventive Services Task Force^120^ criteria noted below:

II-2A: Well-designed cohort (prospective) study with concurrent controls

II-2B: Well-designed cohort (prospective) study with historical controls

II-2C: Well-designed cohort (retrospective) study with concurrent controls

II-3: Well-designed case controlled (retrospective) study

III: Large differences from comparisons between times and/or places with or without interventions (cross-sectional comparisons).

For question 3, an evidence table was developed for each of the nurse staffing variables identifying the purpose of the study, sample, design, independent and dependent variables, and findings.

For questions 1, 2, and 4, descriptive statistics, correlation and regression coefficients, and F and T tests for treatment differences were used to assess reported outliers, variances, and skewness in the data.^121,^ ^122^ Baseline data were compared in different studies to test the differences in the target population and unusual patterns in the data.^123,^ ^124^ Standard errors, regression coefficients, and 95 percent CI were calculated from reported means, standard deviations, and sample size.^121,^ ^122^ The protocol for the meta-analyses was created according to the recommendations for Meta-analysis Of Observational Studies in Epidemiology (MOOSE).^125^

We used the Trim and Fill method^126^ to detect publication bias defined as the tendency to publish positive results and to predict the association when all conducted (published and unpublished) studies are analyzed. Time trends in positive results were assessed with interaction models with time of the events as continuous variables.

The evaluations of the studies and the data extraction were performed manually and independently by two researchers. The principal investigators of some studies were contacted to assess the additional and missing information when necessary. Errors in the data extractions were assessed by a comparison with the established ranges for each variable and by a comparison of the data charts with the original articles. Any discrepancies were detected and discussed.

Patient populations were classified as surgical, medical, and combined samples.^26,^ ^27^ Adjustments for patient age, race, gender, comorbidities, socioeconomic status, provider characteristics, and clustering of patients and providers were extracted from the studies.^127^

### Data Synthesis

For questions 1, 2, and 4, the results of individual studies were summarized in an evidence table with relation to the sample size and 95 percent CI in outcomes. Weighted by the number of patients and hospitals, odds ratios and 95 percent CIs were calculated with fixed and random effects models.^128^

We report the nurse to patient ratios as they were used by individual authors; but we have also created two standardized rates for purposes of comparison:

1 The number of patients cared by one nurse per shift^3^
  3 We assume an 8-hour shift.
2 RN FTE per patient day

FTE per occupied bed ratios were calculated based on FTE per mean annual number of occupied bed days (patient days). Therefore, we conducted separated analyses and report the results:

- With definitions the authors used
- Corresponding to an increase by one RN FTE per patient day
- In categories of patients per RN per shift in ICUs, and with surgical and medical patients.^27^

Different methods have been used to estimate nurse hours per patient day from FTEs. Some investigators assume a 40 hour week and 52 working weeks per year (2,080 hours per year). Others use more conservative estimates (e.g., 37.5 hours per week for 48 weeks = 1,800 hours per year).^129^ In our conversions, we used the latter estimate (Appendix F).

We estimated that:

- Nurse hours per patient day = (FTE * 40)/patient days^130^
- One nurse per patient day = 8 working hours per patient day^129^
- Then the patient per nurse ratio = 24 hours/nurse hours per patient day^130^

We made the following assumptions:

- 37.5 hour work week on average
- 48 working weeks per year (4 weeks vacation, holidays, sick time);
- All FTEs are full-time nurses with the same shift distribution (assume three 8-hour shifts)
- The length of shift does not modify the association between nurse staffing and patient outcomes
- Patient density is the same over the year

The same estimation was used for each nurse job category—RN, LPN/LVN, and UAP.

Meta-analysis was used to assess the consistency of the association between nurse staffing and patient outcomes and improvement in economic outcomes including LOS. The analyses were conducted separately for classes of patient and hospital characteristics. Assumptions underlying meta-analysis included valid measurements of nurse staffing and patient outcomes, similarity in target populations, and similarity in reported and not reported variance.

Sub-analyses were conducted to test whether the direction and strength of the association was independent of study design and financial support.^127^ Consistency in the results was tested comparing the direction and strength of the association in models with nurse staffing variables as continuous (overall trend) and categorical, in studies reporting outcome rates and adjusted relative risk, and with goodness of fit tests. Chi squared tests were used to assess heterogeneity in study results.^131,^ ^132^ Significant heterogeneity means the effects of nurse staffing on patient outcomes were not consistent in the studies (not replicable results). The hypotheses of the associations between outcomes and nurse staffing variables were tested with random effects models (random intercept for each study) to incorporate between variability in the studies and to provide valid pooled estimates weighted by sample size. Individual studies were analyzed with simple linear regression to find slopes for each study when possible. Meta-analysis was used to estimate pooled regression coefficients: changes in outcomes corresponding to incremental changes by one unit in nurse staffing. The analytic framework and algorithms for the meta-analysis are shown in Appendix F.

Meta-regression models analyzed possible interactions with the year of publication, analytic units, hospital units, adjustment for confounding factors, and patient population.^132,^ ^133^ The calculations were performed using the following software: STATA,^134,^ ^135^ and SAS 9.2 Proc Mixed.^136^ To ascertain whether the relationships were linear, two different forms of staffing variables were tested: continuous and categorical, where the latter was arranged in quartiles. When authors reported outcome rates and relative risks grouped by different exposure cut points and reference, we assigned exposure levels as the mean or median of nurse staffing variables, assuming a normal distribution. We also transformed nurse staffing levels into a risk estimate per unit of exposure and assigned an exposure value to each categorical group, assuming a specific parametric distribution for the exposure in the population.^137^ This method can test a linear dose-response relation and assess the nonlinearity of the dose-response relation.

The research question examining factors that influence nurse staffing policies (question 3) involved the identification of studies that included one or more of the nurse staffing variables. The studies were summarized in evidence tables followed by a synthesis of the studies for each staffing policy.