# Introduction

## Overview

Reports from the Institute of Medicine addressing quality of health care provided in the United States call for significant improvements at a system level to guarantee effective, efficient, evidence-based, patient-oriented, and equitable care.^74,^ ^84,^ ^85^ Patient safety from injuries caused by the health care system is critical to improving quality of care and reducing health care costs.^84^ Estimates suggest that 1 percent of health expenditures, or $8.8 billion, is attributable to preventable adverse events.^84^ Patient safety is included in certification process of health care organizations by the Joint Commission on Accreditation of Healthcare Organizations (JCAHO)^4^ and monitored by the voluntary National Quality Forum (NQF).^5,^ ^87^ The health care workforce is crucial to providing patients with high-quality care.^74^ Nurses constitute 54 percent of all health care workers in the United States.^74^ Because of the key role nurses play in patient safety and quality of care, the U.S. Department of Health and Human Services (DHHS) and the Agency for Healthcare Research and Quality (AHRQ) conducted several studies^51,^ ^65,^ ^89,^ ^90^ to examine the association between nurse staffing and patient outcomes which showed that the work environment was a major threat to safe nursing practice in hospitals.^27^ Hospital restructuring in the last two decades, in response to the advent of managed care, resulted in shorter hospitalizations of acutely ill patients to increase hospitals' efficiency and financial performance.^19^ Increased patient turnover placed new stresses on nurses to provide safe patient care.^3,^ ^74^ The increased workload, when 23 percent of hospitals reported 7–12 patients per nurse in most medical-surgical units, reduced nurses' trust in hospital and nursing administration as well as reducing nurse autonomy.^74^ At least part of the growing nurse shortage from 6 percent in 2000 to a projected 20 percent in 2020 can be traced to nurse job dissatisfaction.^1,^ ^91^

A nurse shortage, in combination with increased workload, has the potential to threaten quality of care.^74,^ ^51^ Hospitals with inadequate nurse staffing have higher rates of adverse events such as hospital acquired infection, shock, and failure to rescue.^26,^ ^27,^ ^51^ Systematic reviews of the published literature show that better nurse staffing is associated with less hospital mortality and failure to rescue, and shorter lengths of stay.^51,^ ^92,^ ^93^ A simulation model based on extensive research on nurse staffing estimates the need for additional nurses to achieve the quality goals set for hospital care.^6,^ ^26,^ ^27^

The design of nurse staffing studies varies. Some look specifically at individual units or nurses, while others use administrative data bases that address data at the hospital level and do not permit statistical adjustment for many potentially relevant factors. The latter designs allow for only crude associations.

Quality indicators directly related to nurse staffing have been developed.^89,^ ^95^ AHRQ, the American Nurses Association (ANA), and the NQF considered failure to rescue and pressure ulcers as patient outcomes that are sensitive to nursing care, but there is less consensus on other quality measures such as hospital acquired pneumonia (AHRQ, NQF), urinary tract infection (NQF, ANA), patient falls (NQF, ANA), patient satisfaction with nursing care (ANA), ventilator associated pneumonia, and catheter associated bloodstream infections (NQF).^5,^ ^89,^ ^95^

Few studies have evaluated optimal nurse staffing ratios and hours in different clinical settings; instead, they reported the overall correlation with selected patient outcomes.^35,^ ^92,^ ^94,^ ^96^–^99^ The effect size varied widely using different definitions of RN to patient ratio. An additional patient per RN per shift was associated with increased relative risk of mortality by 6–7 percent in surgical patients.^15,^ ^16^ An increased patient/RN ratio in the evening was associated with a 90 percent increase in relative risk of death in ICUs.^9^ An increase from 1.06 to 2.66 RN FTE per patient day was associated with a relative reduction in hospital-related mortality by 9 percent.^17^ Failure to rescue was reduced by 4–6 percent in surgical patients^26^ when the proportion of RNs increased by 13 percent.^27^ Each additional patient per RN was associated with a 5 percent increase in failure to rescue.^16^ Few studies examined the effect on patient outcomes of nurse staffing strategies, such as overtime hours^100^ and contract or agency nurses.^28,^ ^30,^ ^64,^ ^101^

Increasing the nurse-to-patient ratios and hours has been recommended as a means to improve patient safety.^74^ Mandatory nurse-to-patient ratios and staffing plans have been established in several states^102^ and proposed for all Medicare participating hospitals.^103^ However, most legislative efforts related to mandatory staffing regulations cannot be supported by research that has yielded evidence-based optimal nurse-to-patient ratios or hours.^104^ Moreover, the cost effectiveness of increasing the number of RN hours or RN patient ratios is controversial.^105^–^107^ A national estimation of the cost of increasing RN staffing and the concomitant benefits from avoided deaths, reduced length of stay, and patient adverse events (urinary tract infections, hospital acquired pneumonia, shock, upper gastrointestinal bleeding, and failure to rescue) concluded that increased RN hours per patient day without increased total nursing hours could yield a net reduction in cost of care.^6^ Comparing the results of different studies is complicated by the way both staffing and outcomes are measured.

The aim of this systematic review is to analyze associations between hospital nurse staffing and patient outcomes with consideration of variables that could influence the primary association. The idea for this systematic review was supported by the American Organization of Nurse Executives (AONE). AONE had representation on the Technical Expert Panel. A series of research questions was developed by AONE in conjunction with AHRQ staff as follows:

1 How is a specific nurse-to-patient ratio associated with patient outcomes?
  a Patient outcomes: mortality; adverse drug events, nurse quality outcomes, length of stay; patient satisfaction with nurse care
  b How does this association vary by:
    i patient characteristics such as acuity/severity of illness, stage of treatment process; functional capacity
    ii nurse characteristics such as nurse level of education, nursing years in practice, contract nurses, foreign-trained nurses
    iii organizational characteristics such as type of clinical unit, duration of shift, shift rotation
    iv nursing outcomes such as nurse satisfaction, nurse vacancy rate, nurse turnover rate, nurse retention rate
2 How is a measure of nurse work hours (hours per patient or patient day) associated with patient outcomes?
  a Patient outcomes: mortality; adverse drug events, nurse quality outcomes, length of stay; patient satisfaction with nurse care
  b How does this association vary by:
    i patient characteristics such as acuity/severity of illness, stage of treatment process; functional capacity
    ii nurse characteristics such as nurse level of education, nursing years in practice, contract nurses, foreign-trained nurses
    iii organizational characteristics such as type of clinical unit, duration of shift; shift rotation
    iv nursing outcomes such as nurse satisfaction, nurse vacancy rate, nurse turnover rate, nurse retention rate
3 What factors influence nurse staffing policies (staffing ratios, hours per patient day, skill mix, shift rotations, shift durations, overtime (mandatory and voluntary), weekend staffing, temporary nurses, full-time/part-time mix, floating to nursing units, foreign graduate nurses)?
4 What nurse staffing strategies (use of temporary nursing agencies, part-time nurses, proportion of RNs, experience mix of nursing staff, continuing nurse education, use of ancillary personnel) are effective for improving the patient outcomes listed in question 1?
5 What gaps in the body of research of nurse staffing and patient outcomes can be identified to address in future studies?

Questions 1, 2, and 4 are addressed in the systematic review using meta-analytic approaches. The literature associated with question 3 does not lend itself to meta-analysis. Rather, the third question is approached by a review of the literature. The fifth question is addressed from the results of the overall review and analysis of the studies on nurse staffing and quality.

Questions about nurse ratios and hours are basically similar and examine the same conceptual association between nurse staffing and patient outcomes but employ two different measures of nurse staffing.^108^ The nurse to patient ratio relies on a general ratio, which may include all nurses assigned to a unit, including nonclinical time, whereas nurse work hours look specifically at nurses involved in patient care. Ideally, worked hours should not include other time (e.g., vacation, sick leave, conferences) that is included in the ratio. It is important to distinguish wherever possible paid hours from those actually worked.

Even within this distinction, a number of important differences exist in the way staffing ratios are calculated. Various authors used different operational definitions for the nurse to patient ratio, including:

- Number of patients cared for by one nurse per shift.
- FTE per 1,000 patient days.
- Nurse per patient day or FTE per occupied bed.

These differences provide challenges to pool data across studies.

Hours per patient day (HPD) cannot readily be used to accurately determine nurse-to-patient ratios. HPD reflect average staffing across a 24-hour period and do not reflect fluctuations in census, scheduling patterns, or absenteeism. Not all productive nursing hours are spent at the bedside. Nurses may be engaged in activities such as education, administration, and quality assurance. Thus, HPD are likely to overestimate the actual amount of bedside care, and the magnitude of the discrepancy may vary from hospital to hospital.^60,^ ^109^

Other challenges are associated with the type of nursing staff included in the nursing hours or nurse ratios. Some studies include only RNs and other studies include both RNs and LPNs/LVNs.

Outcomes research attempts to isolate the relationship between any type of treatment and outcomes by adjusting for the effects of other salient variables, such as the nature of the disease and patient characteristics. In the case of nurse staffing, the situation is somewhat different. Nurse staffing is only one component of treatment. The ideal study design would simultaneously adjust for the effects of other treatment elements, such as the specific medications and procedures given and the skills of the medical staff. Instead, most nursing studies emphasize the effect of nursing resources, assuming that all other variables are constant and use average comorbidity scores across hospitals instead of more patient-specific measures. Indeed, individual level patient characteristics are not usually directly addressed, at least not in any detail. Some studies may be conducted on specific units that treat certain types of patients, but the disease mix and severity are generally not addressed specifically.^86^ Whereas a typical medical outcomes study would include variables on patients' disease severity and comorbidities, these can best be addressed in the nurse staffing analyses conducted at patient levels, but most studies were conducted at the unit and hospital level where average values may result from various mixes of patient types.^110,^ ^111^

Given this reality, the conceptual model for the relationship between nurse staffing and outcomes (questions 1 and 2) (shown in Figure 1) focuses on those aspects of care that are generally addressed in such studies.^112^–^115^ Two types of outcomes are proposed to be related to nurse staffing: nurse outcomes and patient outcomes. While patient outcomes are the ultimate concern, nurse outcomes can interact with nurse staffing to affect patient outcomes. Nurse characteristics can influence nurse staffing. The model includes patient factors and hospital organizational factors that may influence the effect of nurse staffing on patient outcomes. Patient outcomes will, in turn, affect LOS; greater complication rates will increase LOS. Table 1 provides definitions for the variables included in Figure 1.

Table 1 Operational definitions

Variable | Definition
Questions 1 and 2: How is a specific nurse to patient ratio or a measure of nurse work hours associated with patient outcomes and how does this association vary by patient, nurse, and organizational characteristics?
Nurse Workforce ^116^
Registered Nurse (RN) | An individual who holds a current license to practice within the scope of professional nursing in at least one jurisdiction of the United States.
Licensed Practical/Vocational Nurse (LPN/LVN) | An individual who holds a current license to practice as a practical or vocational nurse in at least one jurisdiction of the United States.
UAP Assistive Nursing Personnel | Unlicensed individuals who assist nursing staff in the provision of basic care to clients and who work under the supervision of licensed nursing personnel. Included in, but not limited to, this category are nurses aides, nursing assistants, orderlies, attendants, personal care aides, medication technicians, and home health aides.
Nursing personnel | This term refers to the full range of nursing personnel including RNs, LPNs/LVNs and UAPs.
Nurse Staffing Measures
Patient to nurse ratios | Number of patients cared for by one nurse, specified by job category
RN to patient ratio | Number of patients cared for by one RN
LPN to patient ratio | Number of patients cared for by one LPN
UAP to patient ratio | Number of patients cared for by one UAP
Nurse hours per patient day | Total number of productive hours worked by all nursing staff with direct care responsibilities per patient day (a patient day is the number of days any one patient stays in the hospital)
RN hours per patient day | Number of productive hours worked by RN with direct care responsibilities per patient day (a patient day is the number of days any one patient stays in the hospital)
LPN/LVN hours per patient day | Number of productive hours worked by LPN/LVN with direct care responsibilities per patient day (a patient day is the number of days any one patient stays in the hospital)
UAP hours per patient day | Number of productive hours worked by UAP with direct care responsibilities per patient day (a patient day is the number of days any one patient stays in the hospital)
RN/LPN/UAP FTEs per patient day | Number of RN/LPN/UAP FTEs per patient day (FTEs can be composed of multiple part-time or one full-time individual) This ratio has been calculated in several different ways: number of patients cared for by one nurse per shift; FTE/1,000 patient-days; nurse/patient day or FTE/occupied bed. For analytic purposes we operationalized the nurse to patient ratio as the number of patients cared by one nurse per shift and FTE/patient day (see Appendix F for calculations)
FTE | A full-time employee, or a combination of part-time employees whose combined hours are the equivalent of a full-time position, as defined by the employer
Skill mix | Proportion of productive (i.e., direct patient care related) hours worked by each skill mix category (RN, LP/VN, UAP)
Licensed nurse | RN and LP/VN
Patient Outcomes
Mortality
Mortality | Death from all causes (intra hospital, 30 days after discharge)
Death in low mortality Diagnosis Related Groups (DRGs) | In-hospital deaths in DRGs with less than 0.5% mortality
Adverse Drug Event
Adverse Drug Events | An injury related to drugs caused by medical management rather than by the underlying disease or condition of the patient
Length of Stay
Length of stay | Average length of stay: the number of patient days divided by the number of discharges for a time period
Patient Satisfaction
Patient satisfaction with nursing care | Measure of patient perception of the hospital experience related to satisfaction with nursing care
Patient satisfaction with pain management | Patient opinion of how well nursing staff managed their pain as determined by scaled responses to a uniform series of questions designed to elicit patient views regarding specific aspects of pain management
Patient satisfaction with educational information | Patient opinion of nursing staff efforts to educate them regarding their conditions and care requirements as determined by scaled responses to a uniform series of questions designed to elicit patient views regarding specific aspects of patient education activities
Patient satisfaction with overall care | Patient opinion of care received during the hospital stay as determined by scaled responses to a uniform series of questions designed to elicit patient views regarding global aspects of care
Nurse Quality Outcomes
Patient falls, injuries | Unplanned descent to the floor during the course of a hospital stay
Maintenance of skin integrity/pressure ulcers | Stage I–IV ulcers
Nosocomial infection rate | An infection occurring in a patient in a hospital or other healthcare facility in whom it was not present or incubating at the time of admission
Failure to rescue | The number of deaths in patients who developed an adverse occurrence; the number of patients who developed an adverse occurrence ^117^
Urinary tract infection rate | Disorder involving repeated or prolonged bacterial infection of the bladder or lower urinary tract (urethra)
Surgical bleeding | Post-surgical hematoma or hemorrhage
Upper gastrointestinal bleeding | Gastrointestinal hemorrhage
Post surgical thrombosis | Deep vein thrombosis or pulmonary embolism among surgical patients
Atelectasis and pulmonary failure | Iatrogenic atelectasis and acute respiratory failure in hospitalized patients
Accidental extubation | Iatrogenic accidental extubation
Hospital-acquired pneumonia | An infection of the lungs contracted during a hospital stay
Postoperative infection | Any infection of post-surgical wounds
Cardiac arrest/shock | Cessation of cardiac mechanical activity as confirmed by the absence of signs of circulation
*Restraint prevalence (vest and limb only) | Restricting free movement of another person
Urinary catheter associated infections | Iatrogenic infection of urinary tract associated with a catheterization
Nurse Outcomes
Staff vacancy rate | Open positions divided by total positions
Nurse satisfaction | Opinion of nurses about their job in terms of pay, reward, administration style, professional status, and interaction with colleagues
Staff turnover rate | Departures from the staff (or hires) divided by total positions
Retention rate | Proportion of nurses employed at the beginning of the year who are still employed there at the end in each participating unit
Burnout rate | Proportion of nurses who reported an excessive stress reaction to professional environment manifested by feelings of emotional and physical exhaustion coupled with a sense of frustration and failure
Patient Characteristics
Age | Mean age in years
Primary diagnosis | Diagnosis which was a cause for hospitalization (ICD-9 codes)
Comorbidity | Coexistence of two or more disease-processes measured with weighted scales. This data can be collected on the individual patient level or an average figure can be calculated for an entire hospital.
Severity | Severity of illness classified as none or minor, moderate, or major, based on expected impact on length of stay. For surgical patients, a fourth class is added for patients having catastrophic comorbidities or complications; including chronically, critically, or terminally ill.
Stage of treatment | This applies largely to surgical patients and would be pre-op/post-op; could apply to persons undergoing some other defined intervention; could also be used to distinguish rehabilitative phase from acute treatment.
Functional capacity | Individual's maximum capacity to perform daily activities in the physical, psychological, social, and spiritual domains of life
Nurse Characteristics
Demographics | Age and gender
Level of education | Proportion of nurses with nursing degree: Associate degree; Diploma; BSN; Master of Science (MS); Doctor of Philosophy (PhD)
Nursing experience | Experience in nursing practice in years
UAP | Unlicensed assistive personnel (not RNs or LPNs)
International Educated Nurse (IEN) | Nurses who graduated from schools of nursing in foreign countries
Contract/temporary/agency nurses | Any licensed nurse who is providing service at the facility as an employee of another entity
Organizational Characteristics
Type of clinical units | Types of patients and services provided on a nursing unit (e.g., telemetry, medical, surgical, critical care)
Duration of shift | Length of working shift (8, 10, or 12 hour shift)
Nursing unions | Organizations that represent nurses for the purposes of collective bargaining
Hospital Factors
Teaching status | Affiliation with a medical school
Size | Number of beds
Volume | Annual number of procedures performed in a hospital
Technology index | Weighted sum of the number of technologies for direct patient care and services available in a hospital. Availability and saturation in use of computerized physician orders entry systems, computerized nursing, and patient medical records
Question 3: What factors influence nurse staffing policies?
Nurse Staffing Policies
Staffing ratios | Policies regarding the number of patients cared for by one nurse specified by job category (RN, LPN/LVN, UAP)
Staffing hours per patient day | Policies regarding the total number of productive hours worked by nursing staff with direct care responsibilities on acute care units per patient day (total nursing hours, RN hours, LPN/LVN hours, UAP hours)
Staff mix | Policies regarding the proportion of productive hours worked by each skill mix category (RN, LPN/LVN, UAP)
Shift rotations | Policies regarding scheduling nursing staff to work different work shifts (days, evenings, nights) during a defined period of time (e.g., pay period; schedule period)
Shift durations | Policies regarding the length of shifts (e.g., 8 hours; 10 hours; 12 hours)
Overtime (mandatory and voluntary) | Policies requiring or permitting additional worked hours over 40 hours/week or more than 8 hours in a day or more than 80 hours in a pay period
Weekend staffing | Policies regarding the frequency of weekends worked
Temporary nurses | Policies regarding the use of temporary/agency nurses
Full-time/part-time mix | Policies regarding the number and type of nursing staff that are full time and part time
Floating to nursing units | Policies regarding when nurses can be assigned to work on nursing units other than their regularly assigned nursing unit
International Educated Nurses (IEN) | Policies regarding the hiring and use of nurses that have graduated from schools of nursing in foreign countries
Patient Care Unit Factors
Patient classification system | Systems that classify patients according to the intensity of nursing care required
Patient flow/census fluctuations | Frequency of admissions, discharges, transfers of patients in a nursing unit or a hospital
Type of nursing unit | Types of patients and services provided in a nursing unit (e.g., telemetry, medical, surgical, pediatric, critical care)
Nursing Organization Factors
Governance | Organizational models through which nurses control their practice as well as influence administrative areas
Management/leadership style | Degree to which nurses in management and leadership positions make themselves visible and accessible to nursing staff, seek, value, and incorporate feedback from nursing staff, and communicate with nursing staff
Hospital Factors
Type | Teaching, non teaching, rural, urban
Ownership | Proprietary, government/public, and not-for-profit
Technology use | Electronic medical record
Risk management | Degree to which the organization addresses the prevention of adverse events
Unionization | Percent or proportion of nurses who are members of a collective bargaining unit
Nurse Factors
Experience in nursing | Years working as a licensed nurse or UAP
Age | Age in years
Education | Proportion of nurses by highest level of education in nursing: practical nursing, associate degree, diploma, baccalaureate, masters, doctorate
Question 4: What nurse staffing strategies are effective for improving outcomes?
Nurse Staffing Models
Patient focused care | RNs serve as care managers managing unlicensed assistive personnel in expanded roles (drawing blood, performing EKGs, and performing certain assessment activities)
Primary nursing | RN accountable for care of patient from admission to discharge; coordinates all care; provides direct care for patient
Total patient care | RN assumes total responsibility for care of the patient during the time the nurse is on duty
Team nursing | RN is a team leader and LPNs and UAPs provide patient care as directed by the RN team leader
Functional nursing | Nursing staff are assigned specific tasks (e.g., treatments, medications, patient hygiene care) according to their skill and education
Staffing Strategies
Use of temporary nursing agencies | Use of nursing personnel that are employed by an organization that supplies nursing staff
Use of part-time nurses | Proportion of nurses (RN and LPN) working part time (less than 8 hours per shift or less than 40 hours per week)
Proportion of RNs | Proportion of RNs among total hospital and total nursing personnel
Experience mix of nursing staff | Proportion of nursing staff (by type) according to their years of experience
Continuing nurse education | Professional development process after the completion of the pre-registration nurse education program. It consists of planned learning experiences which are designed to augment the knowledge, skills, and attitudes of registered nurses to improve quality of care and patient outcomes.
Use of ancillary personnel | Aides, clerical staff, phlebotomists

* Nurse process measures

Patient outcome measures used for questions 1 and 2 will be used for question 4 as well.

Figure 1. Conceptual framework of nurse staffing and patient outcomes

The conceptual model for question 3 (Figure 2) focuses on nurse staffing policies and illustrates factors that might affect such policies, including patient care unit factors. The composition of the nursing staff, such as the extent of experience or extent of contract nursing staff, may also play a role in determining nurse staffing policies and vice versa. Hospital factors will influence nurse staffing policies; however, it is proposed that nursing organizational factors are an intervening factor. The definitions for the variables are provided in Table 1.

Figure 2. Factors affecting nurse staffing policies

The conceptual model for question 4 (Figure 3) emphasizes the relationship between nurse staffing strategies and patient outcomes. Although these strategies may be influenced by nurse staffing models, this variable is not overtly considered in this analysis, and hence is shown in a dotted box. Hospital factors and patient factors can directly affect patient outcomes, as can medical care and nurse staffing levels (not shown in the model).

Figure 3. Nurse staffing strategies and patient outcomes