# Appendix G: Evidence Tables

Table G1 Design, external, and internal validity of the studies that examined the associations between nurse staffing and strategies and patient outcomes

Author, Year, Publication Type | Aim of the Study | Hospital Eligibility Criteria, Database, % of Teaching Hospitals, % of Hospitals for Profit, % of HMO | Time, Analytic Units, Sample Size, % Excluded from Analysis, Sampling, Assessment of Sampling Bias | Patient Eligibility Criteria: Database, Population, Age, Diagnosis, Medical Care | Adjustment for Confounding Factors | Outcomes
Case control studies
Fridkin, 1966^1^ Article | Examine the associations between nurse staffing and central venous catheter-associated bloodstream infections | Single hospital study: university-affiliated Veterans Affairs medical center | 1992-1993, Patient, Random sample of 1,760 patients | Medical records, Adults, Catheter-associated bloodstream infections, Veterans Affairs | Patient age, gender, length of stay, primary diagnosis, severity of illness | Bloodstream infections
Arnow, 1982^2^ Article | Examine association between staffing by overtime or temporary nurses and nosocomial infection in a burn unit | Single unit study, Medical records | 1975, Patient, 147 patients, 27.21% | Medical records, Adults | Not reported | Nosocomial infection
Marcin, 2005^3^ Article | Examine the association between unplanned extubation and years of nurse experience and nurse-to-patient ratio in the pediatric intensive care unit | Single hospital study | 1999-2002, Patient, 220 patients | Medical records, Children | Matching: a) weaning status and duration of intubation; b) patient age; and c) severity of illness as defined by PRISM III. Adjustment: patient age, physical restraints, sedation, patient agitation | Unplanned extubation
Aiken, 1998^4^ Article | Examine association between hospital organization, nurse burnout, an patient satisfaction | American Hospital Association Annual Hospital Survey | 1990-1991, Patient, 1,393 patients, 13.50% | Medical records, Adults, AIDS | Patient sex, age, race, type of insurance, HIV risk categories, illness severity; admitting physician as a part of an AIDS specialty service; the extent of nurse control over practice environment | Patient satisfaction
Aiken, 1999^5^ Article | Compare differences in AIDS patients' 30-day mortality and satisfaction with care in dedicated AIDS units, scattered-bed units in hospitals with and without dedicated AIDS units, and in magnet hospitals known to provide good nursing care | American Hospital Association Annual Hospital Survey | 1990-1991, Patient, 1,393 patients, 13.50% | Medical records, Adults, AIDS | Patient sex, age, race, type of insurance, HIV risk categories, illness severity; admitting physician as a part of an AIDS specialty service; the extent of nurse control over practice environment | Mortality. patient satisfaction
Robert, 2000^6^ Article | Examine the association between nosocomial primary bloodstream infections (BSIs) and nursing-staff levels in surgical intensive care unit (SICU) patients | Single hospital study - 20-bed SICU in a 1,000-bed inner-city public hospital, 100, South | 1994-1995, Patient, Random sample of 127 patients | Medical records, Adults, Nosocomial primary bloodstream infections | Patient age, diagnosis, comorbidity, length of stay | Bloodstream infection
Aiken, 1994^7^ Article | Examine the association between Medicare mortality and hospitals with different nursing care | 39 magnet hospitals and 195 control hospitals, selected using a multivariate matched sampling procedure that controls for hospital characteristics, 28.2%, 7.7% | 1988, Hospital, Random sample of 234 hospitals | Administrative, Adults, 65, Medicare | Patient age, sex, comorbidities, type and source of admission, propensity scores for 12 hospital characteristics census, size occupancy rate, location, technology index) | Mortality
Case-series
Seago, 1999^8^ Article | Examine the association of patient-focused care at one tertiary care university teaching hospital on patient outcomes | Single tertiary care hospital study before and after implementation of patient-focused care | 1996-1997, Patient, 89,256 patients | Medical records, Adults | Not reported | Patient satisfaction, pressure ulcers, falls
Donaldson, 2005^9^ Article | Examine patients' outcomes before and after legislations for mandatory nurse/patient ratios in California hospitals | Convenience sample of 68 acute hospitals participating in the California Nursing Outcomes Coalition project | 2004-2005, Unit, 268, 39.55% | Administrative, Adults | Not reported; before-after comparison were conducted in the same units | Pressure ulcers. falls
Grillo-Peck, 1995^10^ Article | Examine the impact of implementation of a new nursing partnership model with a reduction of RN from 80% to 60% on patient outcomes in neuroscience unit | Single hospital study | 1995-1993, Patient, 156 patients | Medical records, Adults, Cerebro vascular diseases | Not reported. The authors reported that patients had similar demographic characteristics | Length of stay, nosocomial infection, falls
Cross-sectional studies
Hartz, 1989^11^ Article | Examine the association between nurse staffing and mortality in Medicare population | 3,100 hospitals from the 1986 HCFA mortality study and the American Hospital Association's 1986 annual survey of hospitals, 8.1%, 11.9% | 1986, Hospital, 5,781 patients 46.38% | Administrative, Adults >65years, Medicare | Severity of illness | Mortality
Krakauer, 1992^12^ Article | Examine the association of nurse staffing on mortality in Medicare population | 84 statistically selected hospitals from 1986 American Hospital Association (AHA) survey, Single hospital study | 1986, Hospital, 42,773 patients, Random sampling, bias assessed | Medical records | Patient one principal discharge diagnosis, up to four secondary diagnoses, age, sex, race, comorbidities, transfer status; hospital size, location, finances, technical capability of the hospital, cluster patients and hospitals | Mortality
| | | | Adults, >65 years, Medicare
McDaniel, 1992^13^ Article | Examine relationship between nurse turnover and patient and nurse satisfaction | Single hospital study | Patient, 300 patients | Medical records, Adults | Not reported | Patient satisfaction
Halpine, 1993^14^ Article | Examine the association between nurse staffing and length of stay in Ontario hospitals | The Hospital Medical Records Institute, 75% | 1989-1990, Hospital, 40,000 patients, 22.36% | Administrative | Nursing intensity index | Length of stay
Shamian, 1994^15^ Article | Examine relationship between length of stay and hours per patient day in 11 clinical specialty areas | 58 hospitals in the U.S., 33% | Unit, 1,733 patients | Administrative | Patient age, primary and secondary diagnosis; hospital unionization, unit computerization, hospital ownership | Length of stay
Taunton, 1994^16^ Article | Examine associations between patient outcomes and staff registered nurse absenteeism | Taunton, 25% | 1989-1990, Unit, 65 units | Administrative, Adults | Not reported | Urinary tract infection, falls, bloodstream infection
Dugan, 1996^17^ Article | Examine the association between nurses' perceived stress and patient incidents, including falls | Single hospital study | 1996, Nurse, 600 nurses, 51.17% | Survey | Not reported | Falls
Bloom, 1997^18^ Article | Examine association between registered nurses (RNs) from temporary agencies; part-time career RNs; RN rich skill mix; and organizationally experienced RNs on operational and total hospital cost | 1981 AHA annual survey of hospitals; A 20% random sample (1,222 hospitals) | Hospital, 732 hospitals, 20.36%, Random sampling, sample bias assessed | Administrative, Adults | Hospital size, ownership/control, teaching status, operating capacity, geographic region, urban/rural status, local economic climate, hospital wage rates, supply of nursing labor within the community | Length of stay
Minnick, 1997^19^ Article | Examine association between nurse staffing and patient satisfaction | 117 no intensive medical-surgical inpatient units in 17 hospitals selected from a pool of 69 institutions within a metropolitan area by a stratified random sample | 1991-1992, Unit, 2,595 patients, 20.96% | Survey, Adults | Patient age, gender, marital status, race, education, diagnosis | Patient satisfaction
Melberg, 1997^20^ Book | Examine the association between nurse staffing and length of stay | Single system in California, 100%, Pacific | 1994-1995, Hospital, 5% | Administrative, Adults | Not reported | Length of stay
Leiter, 1998^21^ Article | Examine the relationships of nurse burnout, intention to quit, and meaningfulness of work as assessed on a staff survey with patient satisfaction with nursing care | Single hospital study | 1998, Patient Random sample of 605 patients | Survey | Not reported | Patient satisfaction
Kovner, 1998^22^ Article | Examine the relationship between nurse staffing and adverse events controlling for related hospital characteristics | Stratified probability sample of U.S. community hospitals - 589 acute-care hospitals in 10 states, 21%, 11.8% | 1993, Hospital, 900 hospitals, 34.56% | Administrative, Adults, >18years | Case mix (patient age, sex, and comorbidity); hospital teaching status, ownership, bed size, region | Urinary tract infection, gastrointestinal bleeding, pneumonia, pulmonary failure. thrombosis, acute myocardial infarction as a secondary diagnosis after surgery
Hoover, 2000^23^ Dissertation | Examine the association between managed care penetration, nurse staffing, and hospital outcomes in three southern states | American Hospital Association Annual Survey, Health Care Financing Administration, Mississippi State Department of Public Health Office of Rural Health, U.S. Census Bureau | 1995-1997, Hospital, 271 hospitals, 35.06% | Administrative, Adults, >65 years, Chronic obstructive pulmonary disease, viral pneumonia, heart attack, shock, stroke, and hip procedures, Medicare | Patient age, sex, race, procedure, comorbidity; hospital size, location, and teaching status | Mortality, length of stay
Gandjour, 2000^24^ Article | Determine the effect of managed health care plans on hospital staffing | Tennessee Department of Health, 17%, 25.97%, 29–60% | 1995, Hospital, 151 hospitals, 49.01% | Administrative, Adults | Medicare case-mix, number of patient days, hospital beds, average salary, hospital status, occupancy rate | Length of stay
Ridge, 2001^25^ Dissertation | Examine the association between nurse staffing and patient satisfaction | Single hospital study- JCAHO-accredited tertiary care hospital, 100% | 1997-1999, Patient, 5,509 patients, 80.47% | Survey, Adults | Patient age, gender, race, and acuity, Medicare case mix, primary and secondary diagnoses | Length of stay, patient satisfaction
Bolton, 2001^26^ Article | Examine association between nurse staffing and patient safety outcomes | Voluntary sample of California acute care hospitals; 257 medical, surgical, medical-surgical combined, step-down, 24-hour observation units, and critical care patient care units, 9% of all general acute care hospitals in California | 1998-1999, Unit, 257 units, Sampling bias, Assessed | Administrative, Adults, >16 years | Not reported | Pressure ulcers, falls
Aiken, 2001^27^ Article | Examine the association between nurse staffing and mortality | Hospital Association Annual Survey | 1997-1998, Hospital, 22 hospitals | Administrative, Adults, Medicare | Not reported | Mortality
Needleman, 2001^28,29^ Report | Examine the relationship between patient outcomes potentially sensitive to nursing and nurse staffing in inpatient units in acute care hospitals | American Hospital Association Annual Survey of hospitals; hospital patient discharge data and state hospital financial reports or hospital staffing surveys; 11 states across the U.S. | 1997, Hospital, 3,173,705 patients | Administrative | Patient diagnosis, age, sex, comorbidities, health care, emergency admission, hospital location, number of beds, occupancy rate, teaching status, patient acuity in each hospital's mix of patients | Gastrointestinal bleeding, pneumonia, shock, failure to rescue, pressure ulcers, pulmonary failure. surgical wound infection, thrombosis, cardiac arrest and CPR, CNS complications (coma and stupor, acute delirium, reactive confusion, reactive depression), physiologic/ metabolic complications bloodstream infection
Cho, 2002^30^ Dissertation | Examine the association between nurse staffing and adverse patient outcomes | Hospital Financial Data and HCUP State Inpatient Database, 5.6%, 29.7% | 1997, Hospital, 124,204 patients | Administrative, Adults, >18 years | Patient age, sex, race, primary payer, DRG, number of diagnoses at admission, and type of admission (scheduled or unscheduled); hospital location, size, teaching status, ownership; clustering patients in hospitals (two levels model) | Urinary tract infection, pressure ulcers, falls, surgical wound infection, bloodstream infection
Oster, 2002^31^ Dissertation | Examine the association between nurse staffing and patient outcomes in patient with acute myocardial infarction in urban emergency department | Single hospital study in an academic medical center | 2000-2001, Patient, 543 patients | Medical records, Adults, Acute myocardial infarction | Patient age, sex, ethnicity, payer type | Length of stay
Cheung, 2002^32^ Dissertation | Examine the association between nurse staffing, time spent on direct and indirect care, and adverse events in five inpatient units in acute care hospital | Single hospital study | Nurse, 1,007 nurses | Medical records, Adults, >17 years | Unit acuity, skill mix, total number of nursing personnel, events, and nursing characteristics | Pressure ulcers, falls, nosocomial infection, unexpected injury not due to underlying condition of the patients that occurs during the care: falls, decubitus ulcers, medication errors, and blood stream infections
Langemo, 2002^33^ Article | Examine nursing quality outcome indicators (falls and pressure ulcers) after implementation of ANA Nursing Care Report Card | North Dakota Nurses Association (NDNA) Research Council | 2003, Patient, 942 patients | Administrative, Adults | Not reported | Patient satisfaction, pressure ulcers, falls
Seago, 2002^34^ Article | Examine the relationship between the presence of a bargaining unit for registered nurses and the acute myocardial infarction mortality rate for acute care hospitals in California | California Office of Statewide Health Planning and Development (OSHPD) Hospital Disclosure Report database | 1991-1993, Hospital, 385 hospitals, 10.91%, Sampling bias assessed | Medical records, Adults, Acute myocardial infarction | Patient age, sex, severity of illness; hospital services, patient volume, teaching status, number of MDs per acute myocardial infarction-related discharges, the cardiac technology index, rural status and the Hospital Service Area (HSA) wage index | Mortality
Needleman, 2002^29^ Article based on the report | Examine the relationship between the amount of care provided by nurses at the hospital and patients' outcomes | American Hospital Association's Annual Survey of Hospitals | 1997, Hospital, 6,180,628 patients | Administrative, Adults | Rate of the outcome in the patient's diagnosis-related group, state of residence, age, sex, primary health insurer, emergency admission, and comorbidities, hospital number of beds, teaching status, state, and metropolitan or non metropolitan location | Mortality, urinary tract infection, gastrointestinal bleeding, pneumonia, shock, failure to rescue
Kovner, 2002^35^ Article | Examine the association between nurse staffing and patient adverse events after controlling for hospital characteristics | National Inpatient Sample, 80.5% | 1990-1996, Hospital, Random sample of 570 hospitals | Administrative, Adults, >18 years | Medicare Case Mix Index, hospital bed size, location, region, ownership, teaching status, HMO penetration | Urinary tract infection, pneumonia, pulmonary failure, thrombosis
Whitman, 2002^36^ Article | Determine the relationships between nursing staffing and specific nurse-sensitive outcomes (central line blood-associated infection, pressure ulcer, fall, medication error, and restraint application duration rates) across specialty units | Secondary analysis of prospective, observational data from 10 adult acute care hospitals | 1999, Unit, 95 units | Administrative, Adults | Not reported | Pressure ulcers, falls, bloodstream infection
Beckman, 2003^37^ Dissertation | Examine association between nurse management and patient outcomes | Single hospital study, 100%, 17% | 1999-2000, Patient, 429 patients, 74.36% | Survey, Adults | Patient age, sex, race | Random, length of stay
Cho, 2003^38^ Article | Examine the effects of nurse staffing on adverse events, morbidity, mortality, and medical costs | Hospital financial data, state Inpatient databases, 5%, 20% | 1996-1999, Patient, 124,204 patients | Administrative, Adults, >18 years | Patient age, sex, race, primary payer, DRG, number of diagnoses at admission, and type of admission (scheduled or unscheduled); hospital location, size, teaching status, ownership; clustering patients in hospitals (two levels model) | Urinary tract infection, pressure ulcers, falls, surgical wound infection, bloodstream infection, ICD-9-CM for adverse drug event
Aiken, 2003^39^ Article | Examine whether the proportion of hospital RNs educated at the baccalaureate level or higher is associated with risk-adjusted mortality and failure to rescue (deaths in surgical patients with serious complications | Pennsylvania Health Care Cost Containment Council, 36% | 1998-1999, Patient, 232,342 patients | Administrative, Adults, >20 years, general surgical, orthopedic, vascular operation | Patient age, sex, referral from another hospital, comorbidities; hospital size, teaching status, and technology; having a board-certified surgeon | Mortality, failure to rescue
Potter, 2003^40^ Article | Examine the association between nurse staffing and patient outcomes at the unit level in the acute care adjusting for patient acuity and proportion of floating nurses | Single hospital study, 100% | 1999-2001, Unit, 32 units | Medical records, Adults | Not reported | Patient satisfaction, falls
Langemo, 2003^41^ Article | Examine the association between pressure ulcer incidence, staff mix, and nursing care hours | Midwest Research Institute/National Database of Nursing Quality Indicators | 2003, Hospital, 942 hospitals | Administrative | Not reported | Pressure ulcers
Bolton, 2003^42^ Article | Examine the relationship between nurse staffing and patient perceptions of nursing care in a convenience sample of 40 California hospitals | Hospitals participating in both the ongoing California Nursing Outcomes Coalition statewide database project and the statewide Patients' Evaluation of Performance in California project | 1998-2000, Hospital, 113 hospitals | Administrative, Adults | Not reported | Patient satisfaction
Needleman, 2003^43^ Article | Assess whether adverse outcomes in Medicare patients can be used as a surrogate for measures from all patients in quality of care research using administrative datasets | National MedPAR discharge data for Medicare patients from 3,357 hospitals, state hospital staffing surveys or financial reports, American Hospital Association Annual Survey, present sample is 26% of all discharges in the U.S. in 1997 | 1997-1998, Hospital, 6,180,628 patients | Administrative, Adults | Patient age, sex, primary DRG, health insurance, emergency admission, and comorbidities, hospital teaching, metropolitan status, and bed size | Length of stay, urinary tract infection, gastrointestinal bleeding, pneumonia, shock, failure to rescue, pressure ulcers, surgical wound infection, cardiac arrest and CPR, bloodstream infection
Vahey, 2004^44^ Article | Examine the effects of the nurse work environment and nurse burnout on patients' satisfaction with their nursing care | 40 units in 20 urban hospitals across the U.S. (sample from the study of quality of care in AIDS patients) | 1991, Patient, 722 patients, 13.99% | Survey, Adults, AIDS | Patient age, sex, and race, severity of illness, nurse sex, race, age, experience in nursing and in the unit; clustering nurses and patients within hospitals | Patient satisfaction
Sochalski, 2004^45^ Article | Examine the effects of nurse staffing and process of nursing care indicators on assessments of the quality of nursing care | Hospitals where responding licensed RNs in Pennsylvania worked in 1999 | 1999, Nurse, 8,500 nurses, 7.70%, Random sample, Bias assessed | Survey | Nurses clustered within hospitals, nurses perceived quality of care and patient safety | Falls
Van Doren, 2004^46^ Article | Examine the relationships between congestive heart failure patient outcomes and RN hours | Single hospital study, 75% | 1998, 0.57%, Random of 175 patients | Medical records, Adults, Heart failure | Not reported | Length of stay
Boyle, 2004^47^ Article | Examine the association between nurse autonomy and collaboration and patient outcomes | Single hospital study, 100% | 2001, Unit, 11,496 patients | Survey, Adults | Case mix index | Mortality, length of stay, urinary tract infection, pneumonia, failure to rescue, pressure ulcers, falls, cardiac arrest, and CPR
Donaldson, 2005^9^ Report | Test associations between daily nurse staffing in adult medical-surgical units and hospital acquired pressure ulcers, patient falls | 25 acute care, not-for-profit California hospitals, the part of the California Nursing Outcomes Coalition (CalNOC) | 2002-2003, Unit, 77 units | Administrative, Adults | Hospital rural/urban designation; ownership; no. licensed acute care beds; average daily census | Pressure ulcers, falls, adverse events, unexpected clinical events not related to the patient's illness or underlying condition resulting in unanticipated death or major permanent loss of function, or adversely affects the patient care quality or outcomes
Tschannen, 2005^48^ Dissertation | Examine association between patient length of stay and nurse staffing and nurse-physician collaboration | Single hospital study | 2005, Patient, 406 patients, 23.65% | Medical records | Patient DRG, age, gender, acuity scores, unit of admission, admission type and source, and comorbidities; nursing characteristics | Length of stay
Houser, 2005^49^ Dissertation | Examine the association between nurse staffing and nurse-sensitive patient outcomes | American Hospital Association Annual Survey (685 hospitals); 20% random sample of U.S. hospitals | 2001, Patient, 7,452,727 patients, 24.37%, Random sample | Administrative, Adults | Patient age, race, sex, health insurance, comorbidity; hospital size, teaching status, location, ownership | Length of stay, failure to rescue, pressure ulcers, pulmonary failure, thrombosis
Estabrooks, 2005^50^ Article | Examine the association between nurse education and skill mix, and 30-day mortality after adjusting for institutional factors and individual patients characteristic | International Hospital Outcome Study, 8.2% | 1998-1999, Patient, 18,142 patients | Administrative, Adults, >18 years, acute myocardial infarction, stroke, congestive heart failure, chronic obstructive pulmonary disease, pneumonia | Comorbidity scores, patient age, and gender | Mortality
Halm, 2005^51^ Article | Examine the association between nurse-to-patient ratio and patient mortality, failure to rescue, emotional exhaustion and job satisfaction of nurse | Single hospital study, 100%, 0% | 2002, Patient, 6,216 patients, 56.42% | Administrative, Adults, General, orthopedic, and vascular surgery | Patients demographics, emergency department admission, comorbidity and complications | Mortality, failure to rescue
Studies that assessed temporality in association between patient outcomes and nurse staffing patterns
Wan, 1987^52^ Article, Retrospective | Examine association between nurse staffing and patient adverse events in 45 community acute care hospitals across the U.S. | Health area resources file, hospital survey | 1985, Hospital, 60 hospitals, 25.0% | Administrative, Adults | Severity of adverse event | Falls
Flood, 1988^53^ Article, Prospective | Examine association between nurse shortage and length of stay | Single hospital study | 1986, Patient, 497 patients | Medical records, Adults | Not reported, subgroup analysis by patient acuity | Length of stay, adverse events, infections including urinary tract infection and gangrene; congestive heart failure, and arrhythmias, gastrointestinal bleeding
Shortell, 1994^15^ Article, Retrospective | Examine staffing factors associated with risk-adjusted mortality, risk-adjusted average length of stay, and nurse turnover | 1,691 non federal U.S. hospitals with >200 beds, 53%, 12% | 1988-1990, Unit, 17,440 patients, Random sample, bias assessed | Administrative, Adults, >16 years | Patient demographic characteristics, primary DRG and comorbidity (APACHE III scores) | Mortality
Shortell, 1988^54^ Article, Retrospective | Examine the association between the proportion of RNs on mortality rates in Medicare patients for 16 selected clinical conditions | 981 hospitals in 45 states, 46% | 1983-1984, Hospital, 214,839 patients, Sample bias Assessed | Administrative, Adults, >65 years, >16 years, Selected clinical conditions, Medicare | Patient age, sex, comorbidity, length of stay, Medicare case mix; hospital's size, location, ownership | Mortality, length of stay
Thorson, 1995^55^ Dissertation, Retrospective | Relationship between the available hours of RN care and patient outcomes, defined as discharge disposition and death | Acute care short term hospitals in North Carolina, 19% | 1988-1993, Patient, 146,000 patients | Medical records, Adults | Patient age, gender, length of stay, major diagnostic category; hospital ownership, occupancy, size, location, teaching status, and technology | Mortality, length of stay
ANA, 1997^56^ Report, Retrospective | Examine association between nurse staffing and patient outcomes | 502 hospitals from California, Massachusetts, and New York | 1992-1994, Hospital, 502 hospitals, Sample bias assessed | Administrative | Nursing Intensity weights, hospital teaching status, location | Length of stay, urinary tract infection, pneumonia, pressure ulcers, nosocomial infection
Archibald, 1997^57^ Article, Retrospective | Examine the effect of fluctuations in cardiac intensive care unit nurse staffing levels and patient census on cardiac care unit nosocomial infection rate | Single hospital study | 1994-1995, Patient, 782 patients | Medical records, Children | Not reported | Nosocomial infection
Blegen, 1998^58^ Article, Retrospective | Describe, at the level of the nursing care unit, the relationships among total hours of nursing care, registered nurse skill mix, and adverse patient outcomes | Consortium of hospitals members of Information and Quality Healthcare | 1993, Unit, 42 units | Administrative, Adults | Patient severity, nursing acuity system | Mortality, patient satisfaction, pressure ulcers, falls, nosocomial infection
Blegen, 1998^59^ Article, Retrospective | Determine the relationship between different levels of nurse staffing (total hours/patient day and proportion of RNs) and patient falls and cardiovascular arrests | Consortium of hospitals members of Information and Quality Healthcare | 1993-1995, Unit, 39 | Administrative, Adults | Medicare case mix scores | Falls, cardiac arrest, and CPR
Bond, 1999^60^ Article, Retrospective | Examine associations between nurse staffing levels and mortality rates in 3,763 U.S. hospitals | American Hospital Association's Abridged Guide to the Health Care Field, 8.3%, 14.2% | 1992, Hospital, 4,822 hospitals, 21.96% | Administrative, Adults, Medicare | Severity of illness: % of ICU days, annual number of emergency room visits/average daily census, and % of Medicaid patients | Mortality
Pronovost, 1999^61^ Article, Retrospective | Determine whether nurse to patient ratio in ICUs is associated with length of stay in abdominal aortic surgery patients who typically receive care in an ICU | Maryland Health Services Cost Review Commission | 1994-1996, Patient, 2,996 patients, 0.30%, Sample bias assessed | Medical records, Adults, >30 years, Abdominal aortic surgery | Patients' age, sex, race, nature of admission, type of aneurism, comorbidity, surgeon and hospital volumes | Mortality, length of stay
Robertson, 1999^62^ Article, Retrospective | Examine the association between staffing intensity, skill mix, and mortality in patients with chronic obstructive lung disease | American Hospital Association | 1989-1991, Hospital, 5,708 patients, Sample bias assessed | Administrative, Adults, chronic obstructive pulmonary disease, Medicare | Severity of illness and comorbidity (Medicare case mix index); hospital's financial status, ownership, technology index, size, staffing variables (nursing, physicians, technologists) | Mortality
Lichtig, 1999^63^ Article, Retrospective | Examine the relationships between patient outcome indicators and nurse staffing | Hospital cost reports from New York and California | 1992,1994, Hospital, 691, 33.00% | Administrative, Adults | Nursing intensity weights based on patients' characteristics, teaching status, and location | Length of stay, urinary tract infection, pneumonia, pressure ulcers, surgical wound infection
Amaravadi, 2000^64^ Article, Retrospective | Determine if a night-time nurse-to-patient ratio in the intensive care unit is associated with clinical and economic outcomes following esophageal resection | Maryland Health Service Cost Review Commission | 1994-1996, Patient, 366 patients in 32 hospitals | Adults, >18 years, Esophageal resection | Patient age, sex, nature of admission, type of operation, comorbid disease and hospital and surgeon volume; clustering of outcomes within a hospital | Mortality, length of stay, pneumonia, pulmonary failure, unplanned extubation, cardiac arrest and CPR, septicemia postoperative infection, myocardial infarction, surgical complications, acute renal failure
ANA, 2000^65^ Report, Retrospective | Examine the association between nurse staffing and patient outcomes in the inpatient hospital settings | HCFA | 1992-1996, Hospital, 14,251,921 patients, 9.32% | Administrative, Adults, >75 years, Medicare | Large urban location (Y/N); rural location (Y/N); teaching status; nursing intensity weights | Length of stay, urinary tract infection, pneumonia, pressure ulcers, surgical wound infection, thrombosis, anoxic brain damage; communicable conditions; complications in post-partum period; diabetic complications, joint effusion, metabolic imbalances, personal care complications, psychiatric secondary diagnosis, transfusion reactions, trauma in non-trauma patients, adverse drug reactions
Unruh, 2000^66^ Dissertation, Retrospective | Examine the association between nurse staffing and quality of patient care | 211 hospitals yearly, 1,477 during 7 years acute care hospitals in Pennsylvania, State Department of health with unique information on nurse staffing and patients discharge, 0.4% | 1991-1997, Patient, 83,924 patients | Administrative | Patient age, gender, race, acuity (Mediqual, hospital location, size, ratio of board certified physicians/ adjusted patients days of care; hospital restructuring including capacity utilization, merger status, ownership, number of administrators/ adjusted patients days of care | Mortality, length of stay, urinary tract infection, pneumonia, pressure ulcers, falls, pulmonary failure, surgical wound infection, cardiac arrest and CPR, complications: secondary diagnosis of misadventures to patients during surgical and medical care
Silber, 2000^67^ Article, Retrospective | Examine the association between nurse staffing and patient outcomes in surgical Medicare patients | Medicare patients in 245 hospitals | 1991-1994, Hospital, 217,440 patients | Administrative, Adults, >65 years, Medicare | 27 patient characteristics including age, sex, race, diagnosis and comorbidities, hospital size, location, technology, % of certified physicians and anesthesiologists | Mortality, failure to rescue, in-hospital complication rate, cardiac event, congestive heart failure, shock, deep vein thrombosis and pulmonary embolus, stroke, transient ischemic attack, coma, nosocomial infections, pneumonia, pulmonary failure, pressure ulcers, wound infections, sepsis, bleeding
Whitman, 2001^68^ Article, Prospective | Examine the relationship between restraint use and staffing | A secondary analysis of prospective, observational data from 10 adult acute care hospitals with bed capacity ranging from 59–861 beds, in an integrated healthcare system in the east, 50% | 1999, Unit, 370,574 patients | Medical records, Adults | Not reported; however, the authors obtained hierarchical longitudinal linear models (random coefficient regression models) | Restraint use
Ritter-Teitel, 2001^69^ Dissertation, Retrospective | Examine the association between nurse staffing and patient outcomes | Sample from HRIO study (“Hospital Restructuring's Impact on Outcomes”) of 42 teaching hospitals, 100% | 1997-1998, Unit, 56, Sample bias assessed | Administrative | Age, primary diagnosis and case-mix index, random effects of hospitals | Patient satisfaction, transient ischemic attack, pressure ulcers, falls
Dimick, 2001^70^ Article, Retrospective | Determine if nurse-to-patient ratio in the intensive care unit at night is associated with differences in clinical and economic outcomes after hepatectomy | Maryland Health Services Cost Review Commission | 1994-1998, Patient, 569 patients, 2.28% | Administrative, Adults, >18 years, hepatic resection | Patient age, sex, nature of admission, type of operation, comorbidity; hospital and surgeon volumes | Mortality, length of stay, pneumonia, pulmonary failure, unplanned extubation, cardiac arrest and CPR, postoperative myocardial infarction, acute renal failure, bloodstream infection
Sovie, 2001^71^ Article, Retrospective | Examine the association between nurse staffing and patient outcomes | 29 university teaching hospitals based on the MECON-PEERx Operations Benchmarking Database Reports, 100% | Hospital, 29 hospitals | Administrative, Adults | Year of submission and type of unit | Patient satisfaction, urinary tract infection, pressure ulcers, falls
Pronovost, 2001^72^ Article, Retrospective | Evaluate the association between nurse-to-patient ratio in the ICU and risk for medical and surgical complications after abdominal aortic surgery | Health Services Cost Review Commission | 1994-1996, Patient, 2,615 patients, 0.34%, Sampling bias assessed | Administrative, Adults, >30 years, Abdominal aortic surgery | Number of hospital beds and the volume of aortic surgery performed during the study period by each hospital and each surgeon in the database; patient age (in years), sex, race, and comorbidities | Mortality, length of stay, pulmonary failure, unplanned extubation, cardiac arrest and CPR, medical complications acute renal failure, septicemia, acute myocardial infarction, surgical complications, reoperation for bleeding, bloodstream infection
Blegen, 2001^73^ Article, Retrospective | Describe the relationships between the quality of patient care and the education and experience of the nurses providing that care | | 1993-1995, Unit, 81 units | Administrative, Adults | Hospital Medicare case mix index | Falls
Aiken, 2002^74^ Article, Retrospective | Determine the association between the patient-to-nurse ratio and patient mortality, failure to rescue (deaths following complications) among surgical patients, and factors related to nurse retention | American Hospital Association (AHA) annual survey and 1999 Pennsylvania Department of Health Hospital Survey, 36.2% | 1998-1999, Patient, 232,342 patients | Administrative, Adults, >20 years, General surgical, orthopedic, or vascular operation | Patient age, sex, surgery types, comorbidity; hospital size, teaching status, and technology; nurse's sex, years of experience in nursing, education | Mortality, failure to rescue
Dang, 2002^75^ Article, Retrospective | Examine the association between ICU nurse staffing and the likelihood of complications for patients undergoing abdominal aortic surgery | Maryland Health Services Cost Review Commission | 1994-1996, Patient, 2,987 patients, 12.76% | Administrative, Adults, 30, Abdominal aortic surgery | Patient age, sex, race, comorbidity, severity of illness, nature of admission, hospital and ICU bed size; hospital and surgeon volume, type of unit, full-time medical director and nurse manager, RN attendance at daily rounds, use of clinical pathways | Pulmonary failure, unplanned extubation, cardiac arrest and CPR, complications: acute myocardial infarction, cardiac complications after a procedure, acute renal failure, platelet transfusion, bloodstream infection
Tourangeau, 2002^76^ Article, Retrospective | Examine the association between nursing-related hospital variables and 30-day mortality rates for hospitalized patients | Ontario Hospital Reporting system, 13.3% | 1998-1999, Hospital, 46,941 hospitals | Administrative, Adults, >21 years, Acute myocardial infarction, stroke, pneumonia, or septicemia | Patient age, sex, comorbidities, socio-economic status; hospital teaching status, and location | Mortality
Barkell, 2002^77^ Article, Retrospective | Examine the effects of a change in the staffing model on length of stay, variable cost, patient satisfaction, incidence of urinary tract infection and pneumonia, and pain management in bowel resection patients | Single hospital study: 508-bed full service community-based teaching hospital | 1999-2000, Patient, 96 patients | Medical records, Adults, >18 years, Postoperative bowel procedure | Not reported | Length of stay, patient satisfaction, urinary tract infection, pneumonia
Stegenga, 2002^78^ Article, Retrospective | Examine the relationship between nurse staffing levels and the rate of nosocomial viral gastrointestinal infections (NVGIs) in a general pediatrics population | Single hospital study, general pediatrics ward at The Hospital for Sick Children in Toronto, Ontario, Canada, a 320-bed, tertiary-care pediatric institution | 1997-1999, Patient, 2,929 patients | Medical records, Children | Not reported | Nosocomial infection
Alonso-Echanove, 2003^79^ Article, Prospective | Examine the association between nurse staffing and bloodstream infections in intensive care units | Part of Detailed ICU Surveillance Component (DISC) Study (prospective, multi center cohort study). 6 hospitals, 8 ICU units | 1997-1999, Patient, 8,593 patients | Medical records, Adults, Central venous catheter | Patient age, gender, weight, height, diagnosis, comorbidity | Bloodstream infection
Mark, 2003^80^ Article, Prospective | Examine the association between nurse practice and patient outcomes (patient satisfaction, rate of reported medication errors, and falls) | 68 randomly selected non-federal, no psychiatric, not-for-profit, accredited acute care hospitals with more than 150 beds in 10 southeastern states, 34% | 1995-2000, Patient, 1,326 patients, Random sampling | Survey, Adults | Case mix index, hospital size, technology | Length of stay, patient satisfaction, falls
Unruh, 2003^81^ Article, Retrospective | Examine the changes in licensed nursing staff in Pennsylvania hospitals from 1991 to 1997, and to assess the relationship of licensed nursing staff with patient adverse events in hospitals | Pennsylvania Department of Health | 1991-1997, Hospital, 83,924 patients, Sampling bias assessed | Administrative, Adults | Patient age, gender, race, ethnic status, and level of severity, ownership status, hospital mergers, number of board-certified physicians, and capacity utilization | Urinary tract infection, pneumonia, pressure ulcers, falls, pulmonary failure, nosocomial infection
Simmonds, 2003^82^ Dissertation, Retrospective | Examine the association between nurse staffing and colonization vancomycin-resistant enterococci colonization in chronic dialysis patients | Single hospital study | 2000-2002, Patient, 1,084 patients, 26.11% | Medical records, Chronic renal diseases that requires hemodialysis | Nursing workload index, patient age, and acuity | Nosocomial infection
Tallier, 2003^83^ Dissertation, Retrospective | Examine the relationship between nurse staffing and patient outcomes | Single hospital study including 7 nursing units with patients at high risk of acquiring events | 2000-2001, Patient, 2,897 patients | Medical records, Adults, >18 years | Not reported | Patient satisfaction, urinary tract infection, pressure ulcers, nosocomial infection
Berney, 2003^84^ Dissertation, Retrospective | Examine association between nurse overtime and patient mortality and 6 nurse-sensitive patient outcomes | Hospitals in New York state completed Institutional Cost Reports, 41.2% | 1995-2000, Hospital, 10,210,556 patients | Administrative, Adults | Patient age's, race, primary payer, emergency admission, primary diagnosis and comorbidities (DRGs), hospital variables (location, teaching status, unionization, size, margins), clustering patient within hospitals | Mortality, urinary tract infection, gastrointestinal bleeding, pneumonia, shock, failure to rescue, cardiac arrest and CPR, bloodstream infection
Zidek, 2003^85^ Dissertation, Retrospective | Examine the association between changes in nurse staffing determined based on a new patient classification system and patient outcomes | Single hospital study: rural acute tertiary care facility | 1999-2001, Patient, 5,067 patients | Medical records | Patient age, sex, primary diagnosis, acuity; unit size, organizational leadership | Length of stay, pressure ulcers, falls
Hope, 2003^86^ Dissertation, Retrospective | Examine the relationship between nursing workload and nosocomial infections in acute care hospital | Single hospital study | 1998-2000, Patient, 39,481 patients, 37.23% | Administrative | Patient age, gender, and primary diagnosis, severity of illness; ward type, national risk of infection; resource intensity weight | Urinary tract infections, pneumonia, nosocomial infection, surgical wound infection, bloodstream infection
Cimiotti, 2004^87^ Dissertation, Prospective | Examined the association between nurse staffing, healthcare-associated infection, and length of stay among infants in the neonatal ICU | Two Level III-IY neonatal ICU units in New York City participated in a clinical trial to test hygiene regimens | 2001-2003, Patient, 2,675 patients | Medical records, Children | Patient acuity based on DRG and nursing Intensity weight; use of surgery and invasive medical devices, birth weight, differences in practices in study's sites | Length of stay, nosocomial infection
Person, 2004^88^ Article, Retrospective | Assess the association of nurse staffing with in-hospital mortality for patients with acute myocardial infarction | Cooperative Cardiovascular Project (CCP) dataset, 39.2% | 1994-1995, Patient, 234,754 patients, 49.33%, Random | Administrative, Adults, >65 years, Acute myocardial infarction, Medicare | Patient age, gender, ethnicity, and severity of illness, hospital volume, rural/urban location, and teaching status | Mortality
Mark, 2004^89^ Article, Retrospective | Examine the effects of change in registered nurse staffing on change in quality of care | American Hospital Association | 1990-1995, Hospital, 422 patients, Random | Administrative | Patient's age, gender, admission type, admission source, and type of treatment (medical vs. surgical); hospital size, case mix, and the availability of high technology services | Mortality, urinary tract infection, pneumonia, pressure ulcers
Mark, 2005^90^ Article, Retrospective | Examine structural differences in the relationship between nurse staffing and quality of care in different levels of managed care penetration | Longitudinal cohort of the Healthcare Cost and Utilization Project (HCUP) National Inpatient Sample (NIS); a 20% probability sample of U.S. community hospitals from 11 states, 0.122%, 3.26% | 1990-1995, Hospital, 422 hospitals, Random sampling, Sampling bias assessed | Administrative | Patient's age, gender, admission type, admission source, and type of treatment (medical vs. surgical), hospital size, case mix, and the availability of high technology services | Mortality, length of stay
Stratton, 2005^91^ Dissertation, Retrospective | Relationships between pediatric nurse staffing and 5 indicators of quality care (measured as adverse occurrence rates) in 17 medical/surgical, 5 oncology, and 12 intensive care units | Seven, academic, not-for-profit children's hospitals from the National Association of Children's Hospitals and Related Institutions (NACHRI), 100%, 0%, Different % HMO penetration | 2002, Unit, 6,011 patients | Administrative, Children, >1year | Patient age, sex, race, socio economic status, unit/hospital type, size, and occupancy, transfers, technological complexity, organizational factors including care model, length of shift, flexible staffing, self-governance, paid continuing nursing education, relationships with physicians | Length of stay, patient satisfaction, nosocomial infection
Elting, 2005^92^ Article, Retrospective | Examine the association between nurse staffing (RN/patient ratio) and patient mortality and complication after cystectomy | Texas Hospital Discharge Public Use Data | 1999-2001, Hospital, 1,302 hospitals | Administrative, Adults, Bladder carcinoma (ICD-9 codes 188.0–188.9 and 236.7) after total cystectomy | Age, gender, race, ethnicity, comorbidities, and distance from the closest high-volume hospital | Mortality, bacteremia, wound infections, pulmonary compromise, pneumonia, deep venous thrombosis, pulmonary embolus, reoperation, postoperative coma or shock, acute myocardial infarction, arrhythmia, and cardiac arrest or shock
Seago, 2006^93^ Article, Retrospective | Examine the association between nurse staffing and patient outcomes for 3 adult medical-surgical nursing units in one university teaching hospital across 4 years (16 fiscal quarters) | Single hospital study, 100% | 1999-2002, Patient, 1,012 patients | Administrative, Adults | Case-mix | Patient satisfaction, failure to rescue, pressure ulcers, falls

CNS = Central Nervous System; CPR = Cardio-pulmonary Resuscitation; DRG = Diagnosis Related Group; HMO = Health Maintenance Organization; ICU = Intensive Care Unit; MedPAR = Medicare Provider Analysis Review; RN = Registered Nurse

Table G2 Calculated change in hospital-related mortality corresponding to an increase by one patient/RN, LPN/shift (results from individual studies)

Definition of Nurse to Patient Ratio | Source to Measure Ratio | Author | Increase by One Patient/RN/Shift | | | | Increase by One Patient/LPN/Shift
| | | Death Rate | p Value | RR | p Value | Death Rate | p Value | RR | p Value
RN/patient day | Survey of RNs | Aiken^5^ | | | 1.83 | NS
Patients/RN/shift | Survey of RNs | Aiken^39^ | 0.11 | <0.05 | 1.06 | <0.05
Patients/RN/shift | Survey of RNs | Aiken^74^ | | | 1.08 | <0.05
Patients/RN/shift | Survey of ICU directors | Amaravadi^64^ | 4.7 | NS | 1.2 | NS
Nurse/patient day | AHA and HCFA data bases | Bond^60^ | | | | | | NS
Patients/RN/shift | Survey of ICU directors | Dimick^70^ | | | | NS
RN, LPN FTE/ number of occupied beds | Hospital Cost Report Information System, Provider of Services files, and the American Hospital Association Survey | Elting^92^ | 0.42 | NS | 1.18 | <0.05 | 1.12 | <0.05
Patients/RN/shift | Survey of staff nurses; daily staffing plans and unit census records | Halm^51^ | | | 0.99 | NS
RN, LPN FTE/1,000 patient days | Area Resource Files, American Hospital Association Annual Survey, CMS Wage Rate File, CMS Online Survey | Mark^90^ | | | 1.001 | NS | | | | NS
RN, LPN FTE/1,000 patient days | Area Resource Files, American Hospital Association Annual Survey, CMS Wage Rate File, CMS Online Survey | Mark^89^ | | | 1 | NS | | | | NS
RN, LPN FTE/ patient day | CCP and AHA datasets | Person^88^ | 1.41 | NS | 1.1 | <0.05 | | NS | | NS
Patients/RN/shift | Survey of ICU directors | Pronovost^72^ | 0.5 | NS
Patients/RN/shift | Survey of ICU directors | Pronovost^61^ | | | 1.9 | <0.05
RN FTE/patient day | AHA database | Robertson^62^ | | | 1.02 | <0.05
Patients/RN/shift | Hospital administrative databases; survey of nursing directors in each unit | Shortell^94^ | | | | NS
Patients/RN/shift | AHA Annual Surveys for 1991-1993, and the Pennsylvania Health Care Cost Containment Council Data Base for years 1991-1994 | Silber^67^ | | | 1.05 | <0.05
RN, LPN FTE/ 1,000 patient days | State Department of Health, AHA database | Unruh^66^ | -1.4 | <0.05 | | | 0.14 | <0.05

LPN = Licensed Practical Nurse; NS = Not Significant; RN = Registered Nurse; RR = Relative Risk

Table G3 Evidence of the association between nurse staffing and mortality

Author, Source to Measure Mortality, Definition of Mortality | Source to Measure Nurse Staffing, Definition of Nurse Staffing | Number of Hospitals, Units, Patient Age, % of Whites, % of Males, % of Emergency Admissions | | | Nurse Staffing Categories | | | Mortality
Pronovost, 2001^72^ | Survey to the ICU directors, An average ICU nurse-to-patient ratio during the day and evening | Mean age 68 years, 89% whites, 66% males, 11–13% emergency admissions, | | | | | | Crude rate % ± SD
The Uniform Health Discharge Data Set | | Units: ICU | | | More nurses: RN/patient 1:1 or 1:2 (7 hospitals) | | | 7 ± 26
In-hospital mortality from all causes | | Patients: surgical | | | Fewer nurses: RN/patient 1:3 or 1:4 (31 hospitals) | | | 8 ± 36
Pronovost, 1999^61^ | Survey of intensive care unit directors, | Mean age 68 years, 89% whites, 66% males, 11–13% emergency admissions, | | | | | | Relative risk (95% CI)
The Uniform Hospital Health Discharge Data Set | An average nurse to patient ratio in day and in evening; decreased nurse to patient ratio in evening | Units: ICU | | | Decreased nurse to patient ratio in evening (7 hospitals) | | | 1.9 (1.2; 3)
In-hospital mortality | | Patients: surgical | | | Nurse to patient ratio >1:2 in evening (31 hospitals) | | | Reference
Amaravadi, 2000^64^ | Survey of ICU directors, | 32 hospitals
The Uniform Health Discharge Data Set | An average nurse-to-patient ratio during the day and at night | Units: ICU
In-hospital mortality | | Patients: surgical
| | Age | % Whites | Males | | | | Relative Risk (95% CI)
| | 63 | 77 | 70 | Night time nurse to patient ratio >1:2 | | | 0.7 (0.3;2)
| | 60 | 83 | 79 | Night time nurse to patient ratio <1:2 | | | Reference
| | | | | | | | Crude rate %
| | 60 | 83 | 79 | Night time nurse to patient ratio >1:2 | | | 5.6
| | 63 | 77 | 7 | Night time nurse to patient ratio <1:2 | | | 15
Dimick, 2001^70^ | Survey of ICU directors, | Units: ICU
The Uniform Health Discharge Data Se | An average nurse-to-patient ratio in the ICU during the day and evening and at night | Patients: surgical
In-hospital mortality | | Age | % Whites | Males | | | | Relative risk (95% CI)
| | 56 | 82 | 51 | More nurses: RN/patient 1:1–1:2 (8 hospitals) | | | Reference
| | 57 | 67 | 55 | Fewer nurses: RN/patient 1:3–1:4 (25 hospitals) | | | 0.49 (0.18;1.29)
Blegen, 1998^59^ | A record of hours worked for each individual employee was completed by the staffing clerk and approved by the employee and nurse manager before being entered into the computerized payroll database. The hours of care per patient day from all nursing personnel: Hours of direct patient care by RNs, LPNs, and nursing assistants each month divided by the patient days of care on the unit for the month. The hours of direct patient care from RNs divided by patient days excluding hours for non patient care (meetings, vacation, sick leave, and holidays) | Single hospital study, 42 units | | | | | | Changes in death rate/100 patient days
Hospital records | | | | | Increase by 1% in proportion of RN nurses | | | -0.36 ± 1.64
Death rates per 1,000 patient days. All deaths, whether expected, unexpected, procedure-related, or do not resuscitate, were included | | | | | Proportion of RN >87.5% | | | 0.14 ± 0.53
| | | | | Increase by 1 hour in total nursing hours | | | 0.02 ± 0.07
| | | | | Mean nurse staffing | | | Death Rate
| | | | | Total nursing hours 10.7, RN hours 7.7 | | | 0.06
Aiken, 1999^5^ | Survey of all registered and licensed practical nurses who worked at least 16 hours per week | Hospitals | | Units | | | | Relative risk (95% CI)
Medical charts of consecutively admitted patients | The average number of nurses per patient day (self-reported) | 20 | | 40 | Increase by 1 RN/patient | | | 0.43 | 0.24 | 0.78
Mortality within 30 days from admission | Nurse autonomy: nurse control over the practice environment across hospital units (Clinical Environment Index) | 5 | | 8 | Dedicated AIDS units | | | 1.06 | 0.59 | 1.9
| | 5 | | 8 | AIDS hospital-scattered bed units | | | 0.69 | 0.34 | 1.41
| | 5 | | 8 | Conventional scattered bed units | | | 1 | 1 | 1
| | 20 | | 40 | Nurse control over practice setting | | | 1.03 | 0.94 | 1.13
| | Age | % Whites | Males
| | 37 | 47 | 88 | Increase by 1 RN/patient
| | 39 | 29 | 77 | Dedicated AIDS units
| | 37 | 45 | 87 | AIDS hospital-scattered bed units
Aiken, 2003^39^ | Surveys of hospital nurses (the Pennsylvania Board of Nursing) | Units: ICU | | | | | | Relative risk (95% CI)
Discharge abstracts | The mean number of patients assigned to all staff nurses who reported caring for at least 1 but fewer than 20 patients on the last shift they worked; highest credential in nursing: a hospital school diploma, an associate degree, a bachelor's degree, a master's degree, or another degree; the mean number of years of experience working as an RN for nurses from each hospital | Patients: surgical | | | Increase by 1 year in nurse experience | | | 1 | 0.98 | 1.02
Deaths within 30 days of hospital admission | | Hospitals | | | Increase in workload of 1 patient | | | 1.06 | 1.01 | 1.1
| | 53 | | | 10% increase in nurses with BSN degree | | | 0.95 | 0.91 | 0.99
| | 34 | | | | | | Mortality rate/100 patients
| | 168 | | | 40% of hospital workforce with BSN or higher, 4 patients/nurse | | | 1.8
| | 19 | | | 20% of hospital workforce with BSN or higher, 4 patients/nurse | | | 1.97
| | 26 | | | 60% of hospital workforce with BSN or higher, 6 patients/nurse | | | 1.8
| | 36 | | | 40% of hospital workforce with BSN or higher, 6 patients/nurse | | | 1.98
| | | | | 20% of hospital workforce with BSN or higher, 6 patients/nurse | | | 2.16
| | | | | 60% of hospital workforce with BSN or higher, 4 patients/nurse | | | 1.64
| | | | | 20–29% of hospital workforce with BSN or higher | | | 2.2
| | | | | <20% of hospital workforce with BSN or higher | | | 2.3
| | | | | 20% of hospital workforce with BSN or higher, 8 patients/nurse | | | 2.38
| | | | | >50% of hospital workforce with BSN or higher | | | 1.7
| | | | | 40–49% of hospital workforce with BSN or higher | | | 1.9
| | | | | 30–39% of hospital workforce with BSN or higher | | | 1.8
| | | | | 40% of hospital workforce with BSN or higher | | | 2.17
| | | | | 60% of hospital workforce with BSN or higher, 8 patients/day | | | 1.98
Aiken, 2002^74^ | Survey of 50% random sample of registered nurses who were on the Pennsylvania Board of Nursing rolls; | Patients | | Surgical | | | | Relative risk (95% CI)
Hospital data (Health Care Cost Containment Council | Burnout: the Emotional Exhaustion scale of the Maslach Burnout Inventory Scale | Hospitals | | 168 | Increase by 6 patients/nurse | | | 1.5 | 1.19 | 1.97
Death within 30 days of hospital admission | Nurse' job satisfaction: 4-point scale from very dissatisfied to very satisfied | % males | | 44 | Increase by 1 patient/nurse | | | 1.07 | 1.03 | 1.12
| | Mean age | | 44 years | Increase by 8 patients/nurse | | | 1.72 | 1.27 | 2.48
| | | | | Increase by 4 patients/nurse | | | 1.31 | 1.13 | 1.57
Person, 2004^88^ | AHA Survey | Hospitals | | 4,401 | | | | Mortality Rate
Medicare database | The ratio of full-time equivalent RNs to average daily census (ADC) categorized by their respective quartiles of nurse to ADC ratio; the ratio of full-time equivalent licensed practical nurses (LPNs) to ADC categorized by their respective quartiles of nurse to ADC ratio; ratio of RNs to LPNs | Age | % Whites | Males | Skill Mix: % of RN
In-hospital mortality and within 30 days of hospital admission | | 77 | 90 | 50 | 1 quartile of LPN staffing | | | 23.9
| | | | | 1 quartile of LPN staffing | | | 20
| | | | | 1 quartile of RN staffing | | | 20.1
| | | | | 1 quartile of RN staffing | | | 23.3
| | | | | 2 quartiles of LPN staffing | | | 17.9
| | | | | 2 quartiles of LPN staffing | | | 20.9
| | | | | 2 quartiles of RN staffing | | | 21.6
| | | | | 2 quartiles of RN staffing | | | 18.6
| | | | | 3 quartiles of LPN staffing | | | 20.1
| | | | | 3 quartiles of LPN staffing | | | 22.1
| | | | | 3 quartiles of RN staffing | | | 17.4
| | | | | 3 quartiles of RN staffing | | | 20.5
| | | | | 4 quartiles of LPN staffing | | | 17.2
| | | | | 4 quartiles of LPN staffing | | | 18.7
| | | | | 4 quartiles of RN staffing | | | 21.5
| | | | | 4 quartiles of RN staffing | | | 17.8
| | | | | | | | Relative Risk (95% CI)
| | | | | 1 quartile of LPN staffing | | | 1 | 1 | 1
| | | | | 1 quartile of RN staffing | | | 1 | 1 | 1
| | | | | 2 quartiles of LPN staffing | | | 1 | 0.94 | 1.07
| | | | | 2 quartiles of RN staffing | | | 0.96 | 0.9 | 1
| | | | | 3 quartiles of LPN staffing | | | 1.02 | 0.96 | 1.09
| | | | | 3 quartiles of RN staffing | | | 0.94 | 0.88 | 1
| | | | | 4 quartiles of LPN staffing | | | 1.07 | 1 | 1.15
| | | | | 4 quartiles of RN staffing | | | 0.91 | 0.86 | 0.97
Berney, 2003^84^ | The New York State Institutional Cost Reports | Hospitals: 161 | | | | | | Relative risk (95% CI)
The New York Statewide Planning and Research Cooperative System | RN total hours in inpatient cost units/patient-days in units adjusted for nursing acuity, RN acute hours/ (RN+LPN acute hours); % of total RN hours paid as overtime hours; Union: RN are represented by unions as reported in ICR | Surgical | | | 1% increase in RN overtime work | | | 0.99 | 0.98 | 1.01
In-hospital mortality | | Medical | | | 1 hour increase in RN hours/acute patient day | | | 0.98 | 0.97 | 0.99
| | Surgical | | | 1% increase in RN hours/total licensed hours | | | 0.97 | 0.95 | 0.98
| | Medical | | | 1st (low overtime) quartile | | | 0.99 | 0.98 | 1.00
| | Medical | | | 4th (high overtime) quartile | | | 1.00 | 1.00 | 1.00
| | Medical | | | 1% increase in RN overtime work | | | 1.00 | 0.99 | 1.00
| | Surgical | | | 1st (low overtime) quartile | | | 0.99 | 0.98 | 1.00
| | Surgical | | | 4th (high overtime) quartile | | | 1.00 | 1.00 | 1.00
Needleman, 2001^28^ | State hospital financial reports or hospital staffing surveys; the American Hospital Association Annual Survey of hospitals (2,080 hours * each FTE category) + (1,040 hours * number of part-time employees). Total nursing hours/patient-day NIW adjusted; RNs, clinical nurse specialists, general duty nurses, nurse practitioner excluding nursing directors, managers, administrators, supervisors, instructors, anesthetists, and midwifes. | 4,156 hospitals | | | | | | Relative risk (95% CI)
799 hospitals (11 states, all-patients + Medicare patients) | RN hours/patient day NIW adjusted. Licensed hours/patient-day NIW adjusted | | | | Increase by 1 hour of RN hours in medical patients | | | 1.00 | 0.99 | 1.01
-hospital level analysis; 256 California hospitals (part of the 11 state sample) | LPN/LVN, excluding the director of nursing. | | | | Increase by 1 hour in RN hours in surgical patients | | | 1.00 | 0.99 | 1.01
- unit level analysis; National sample of 3,357 hospitals (Medicare patients) | LPN/LVN hours/patient-day NIW adjusted | | | | Increase by 1 hour in LPN hours in medical patients | | | 1.01 | 0.99 | 1.03
-hospital level analysis; | Nursing aides, orderlies and attendants, excluding ward clerks. Total aide hours/patient day NIW adjusted | | | | Increase by 1 hour in LPN hours in surgical patients | | | 1.00 | 0.96 | 1.04
in-hospital mortality | RN hours per day/total hours per day; | | | | Increase by 1 hour in aide hours in medical patients | | | 1.01 | 1.00 | 1.02
| RN hours/licensed hours = RN hours per day/licensed hours per day (RN + LPN) | | | | Increase by 1 hour in aide hours in surgical patients | | | 1.07 | 1.04 | 1.09
| | | | | Increase by 1 hour in total nursing hours in medical patients | | | 1.00 | 1.00 | 1.01
| | | | | Increase by 1 hour in total nursing hours in surgical patients | | | 1.00 | 0.99 | 1.01
| | | | | Increase by 1% in RN/total nursing hours in medical patients | | | 0.87 | 0.71 | 1.05
| | | | | Increase by 1% in RN/total nursing hours in surgical patients | | | 0.96 | 0.68 | 1.35
| | | | | Increase by 1 hour in licensed hours/patient-day in medical patients | | | 1.00 | 0.99 | 1.01
| | | | | Increase by 1% of RN hours/total licensed hours per patient day in medical patients | | | 0.90 | 0.74 | 1.09
| | | | | Increase by 1 hour in licensed hours/patient-day in surgical patients | | | 1.00 | 0.99 | 1.01
| | | | | Increase by 1% in RN hours/total licensed hours per patient-day in surgical patients | | | 0.99 | 0.67 | 1.47
| | | | | Increase by 1 hour in RN hours in medical patients | | | 1.00 | 1.00 | 1.01
| | | | | Increase by 1 hour in LPN hours in medical patients | | | 1.00 | 0.99 | 1.01
| | | | | Increase by 1 hour in licensed hours in medical patients | | | 1.00 | 1.00 | 1.00
| | | | | Increase by 1% in RN hours/total licensed hours in medical patients | | | 0.98 | 0.89 | 1.08
| | | | | Increase in total nurse hours in medical patients | | | 1.00 | 1.00 | 1.01
| | | | | Increase by 1% in RN hours/total nurse hours in medical patients | | | 0.84 | 0.71 | 1.01
| | | | | Increase by 1 hour in aide hours in medical patients | | | 1.01 | 1.00 | 1.02
| | | | | Increase by 1 hour in RN hours in surgical patients | | | 0.98 | 0.95 | 1.00
| | | | | Increase by 1 hour in LPN in surgical patients | | | 1.01 | 1.00 | 1.02
| | | | | Increase by 1 hour in licensed hours in surgical patients | | | 1.00 | 0.99 | 1.00
| | | | | Increase by 1% in RN hours/licensed hours in surgical patients | | | 0.88 | 0.75 | 1.03
| | | | | Increase by 1 hour in aide hours in surgical patients | | | 1.00 | 0.98 | 1.03
| | | | | Increase by 1 hour in total nursing hours | | | 1.00 | 0.99 | 1.01
| | | | | Increase by 1% in RN hours/total nursing hours | | | 1.02 | 0.70 | 1.48
| | | | | Increase by 1 hour in RN hours in medical patients, hospital level analysis, California hospitals | | | 0.98 | 0.97 | 0.99
| | | | | Increase by 1 hour in LPN hours in medical patients, hospital level analysis, California hospitals | | | 0.98 | 0.94 | 1.02
| | | | | Increase by 1 hour in aide hours in medical patients, hospital level analysis, California hospitals | | | 1.02 | 1.00 | 1.04
| | | | | Increase by 1 hour in total nursing hours in medical patients, hospital level analysis, California hospitals | | | 0.87 | 0.81 | 0.94
| | | | | Increase by 1% in RN hours/total nursing hours in medical patients, hospital level analysis, California hospitals | | | 0.59 | 0.45 | 0.78
| | | | | Increase by 1 hour of licensed nursing hours in medical patients, hospital level analysis, California hospitals | | | 0.98 | 0.97 | 1.00
| | | | | Increase by 1% of RN hours/total licensed hours in medical patients, hospital level analysis, California hospitals | | | 0.91 | 0.65 | 1.27
| | | | | Increase by 1 hour of RN hours in medical patients, unit level analysis, California hospitals | | | 0.98 | 0.96 | 1.00
| | | | | Increase by 1 hour in LPN hours in medical patients, unit level analysis, California hospitals | | | 0.98 | 0.94 | 1.02
| | | | | Increase by 1 hour in aide hours/patient day in medical patients, unit level analysis, California hospitals | | | 1.28 | 1.06 | 1.54
| | | | | Increase by 1 hour in total nursing hours in medical patients, unit level analysis, California hospitals. | | | 0.81 | 0.72 | 0.90
| | | | | Increase by 1% in RN hours/total nursing hours in medical patients, unit level analysis, California hospitals | | | 0.60 | 0.46 | 0.78
| | | | | Increase by 1 hour of total licensed hours in medical patients, unit level analysis, California hospitals | | | 0.98 | 0.96 | 1.00
| | | | | Increase by 1% of RN hours/licensed hours in medical patients, unit level analysis, California hospitals | | | 0.89 | 0.68 | 1.16
| | | | | Increase by 1 hour of RN hours in surgical patients, hospital level analysis, California hospitals | | | 1.02 | 1.00 | 1.04
| | | | | Increase by 1 hour in LPN hours in surgical patients, hospital level analysis, California hospitals | | | 1.07 | 0.97 | 1.17
| | | | | Increase by 1 hour in aide hours in surgical patients, hospital level analysis, California hospitals | | | 1.01 | 0.96 | 1.06
| | | | | Increase by 1 hour in total nursing hours in surgical patients, hospital level analysis, California hospitals | | | 1.02 | 1.00 | 1.04
| | | | | Increase by 1% in RN hours/total nursing hours in surgical patients, hospital level analysis, California hospitals | | | 1.29 | 0.74 | 2.26
| | | | | Increase by 1 hour in licensed hours in surgical patients, hospital level analysis, California hospitals | | | 1.03 | 1.00 | 1.05
| | | | | Increase by 1% in RN hours/licensed hours in surgical patients, hospital level analysis, California hospitals | | | 0.76 | 0.34 | 1.69
| | | | | Increase by 1 hour of RN hours in surgical patients, unit level analysis, California hospitals | | | 1.04 | 1.01 | 1.07
| | | | | Increase by 1 hour in LPN hours in surgical patients, unit level analysis, California hospitals | | | 1.06 | 0.96 | 1.16
| | | | | Increase by 1 hour in aide hours in surgical patients, unit level analysis, California hospitals | | | 0.98 | 0.92 | 1.03
| | | | | Increase by 1 hour in total nursing hours in surgical patients, unit level analysis, California hospitals | | | 1.02 | 1.00 | 1.05
| | | | | Increase by 1% in RN hours/total nursing hours in surgical patients, unit level analysis, California hospitals | | | 1.69 | 1.02 | 2.81
| | | | | Increase by 1 hour in licensed hours in surgical patients, unit level analysis, California hospitals | | | 1.04 | 1.01 | 1.07
| | | | | Increase by 1% in RN hours/ licensed hours in surgical patients, unit level analysis, California hospitals | | | 0.86 | 0.46 | 1.61
Seago, 2002^34^ | The California Office of Statewide Health Planning and Development (OSHPD) Hospital Disclosure Report database; the National Labor Relations Board, number of RN hours/acute myocardial infarction (AMI) related discharge; the presence of a bargaining unit for registered nurses | Hospitals | | | | | | Mortality Rate ± SD
The California Office of Statewide Health Planning and Development (OSHPD) Hospital Disclosure Report database; the California Vital Statistics data set from the California Department of Human Services (DHS), mortality within 30 days of hospital admission | | 106 | | | Union hospitals | | | 14.4 ± 3
| | 238 | | | Not union hospitals | | | 15.2 ± 3.5
| | | | | | | | Relative risk
| | 343 | | | Union vs. not union | | | 0.43
| | 343 | | | 5 RN hour/AMI discharge | | | 0.89
| | 343 | | | 1 RN hour/AMI discharge | | | 0.97
| | 343 | | | 8 RN hour/AMI discharge | | | 0.834
Estabrooks, 2005^50^ | Survey of RN (Alberta Association of Registered Nurses registry) working in acute care hospitals | 49 hospitals | | | | | | Relative risk (95% CI)
Hospital Inpatient Database; Alberta Health Care Insurance Plan Registry (AHCIPR) was linked to identify persons who died within 30 days of admission | Self-reported % of RNs to total nursing staff, | | | | Hospitals with lower proportion of temporary nurses | | | 1 | 1 | 1
Mortality within 30 days of hospital admission | Self reported highest RN credential: Diploma; Baccalaureate; Masters; Otherwise; | | | | Hospitals with higher proportion of nurses with BSN | | | 0.81 | 0.68 | 0.96
| % of BSN in hospital level derived from the question regarding the highest degree; | | | | Hospitals with lower proportion of nurses with BSN | | | 1 | 1 | 1
| Nurse job satisfaction: responses for the question: “On the whole, how satisfied are you with your job?” | | | | Hospitals with higher proportion of temporary nurses | | | 1.47 | 1.21 | 1.79
| 1 Very dissatisfied; 2 A little dissatisfied; 3 Moderately satisfied; 4 Very satisfied) | | | | Hospitals with lower proportion of RN | | | 1 | 1 | 1
| Nurse autonomy: freedom to make important patient care and work decisions | | | | Hospitals with lower proportion of RN | | | 1 | 1 | 1
| | | | | Hospitals with higher proportion of RN | | | 0.76 | 0.66 | 0.87
| | | | | Hospitals with lower proportion of temporary nurses | | | 1 | 1 | 1
| | | | | Hospitals with higher proportion of temporary nurses | | | 1.26 | 1.09 | 1.47
| | | | | Hospitals with higher proportion of RN | | | 0.83 | 0.73 | 0.96
| | | | | Hospitals with lower proportion of nurses with BSN | | | 1 | 1 | 1
| | | | | Hospitals with higher proportion of nurses with BSN | | | 0.65 | 0.6 | 0.71
Cho, 2003^38^ | The State Inpatient Databases, the total productive hours worked by all nursing personnel per patient day, the total productive hours by registered nurses per patient day | Mean age 68 years | | | | | | Death Rate ± SD
Hospital Financial Data, in hospital mortality | | % Whites 79.3
| | Males 48.9%
| | Hospitals
| | 12 | | | Large non-profit teaching hospitals, 76.5% RN | | | 5.13 ± 2.73
| | 79 | | | Medium, non-profit, non-teaching, non-rural, 68.1% RN | | | 4.4 ± 2.18
| | 48 | | | Large, non-profit, non-teaching, non-rural 72.4% RN | | | 4.22 ± 1.5
| | 48 | | | Medium, investor-owned non-teaching non-rural hospitals, 72.7% RN | | | 4.45 ± 2.31
Elting, 2005^92^ | Hospital Cost Report Information System, Provider of Services files, and the American Hospital Association Survey, number of LPN/mean annual number of occupied bed days, number of RN/mean annual number of occupied bed days | Patients Surgical | | | | | | Death rate
The Texas Hospital Discharge Public Use Data File linked to the 2000 U.S. Census, | | 58 | | | Hospitals with few LPNs/occupied bed (median 0.7) | | | 2.3
In-hospital mortality | | 75 | | | Hospitals with many LPNs/occupied bed (median 3.1) | | | 3.1
| | 75 | | | Hospitals with many RNs/occupied bed (median 3.1) | | | 0.7
| | 58 | | | Hospitals with few RNs/occupied bed (median 1.4) | | | 1.9
| | 75 | | | Hospitals with many RNs/occupied bed (median 3.1) | | | 1.9
| | 58 | | | Hospitals with few RNs/occupied bed (median 1.4) | | | 4.5
| | 58 | | | Hospitals with few RNs/occupied bed (median 1.4) | | | 4.41
| | 75 | | | Hospitals with many RNs/occupied bed (median 3.1) | | | 1.6
| | | | | | | | Relative risk (95% CI)
| | | | | | | | 1 | 1 | 1
| | | | | | | | 0.43 | 0.19 | 0.97
Tourangeau, 2002^76^ | The Ontario Registered Nurse Survey of Hospital Characteristics and Ontario Hospital Reporting System | 75 hospitals | | | | | | Relative risk
Discharge abstract database linked to the Ontario Registered Persons Database, mortality within 30 days of hospital admission | Total nursing staff worked hours per Ontario case weight | | | | Increase by 1 year in nursing experience in teaching hospitals | | | 0.99
| RN inpatient hours/other nursing staff earned hours (RN + LPN + aide); | | | | Increase by 10% proportion of RN/total nursing personnel | | | 0.95
| number of years employed in the current clinical unit | | | | Increase by 1 year in nursing experience in non-urban hospitals | | | 1.00
| | | | | Increase by 1 year in experience | | | 0.99
| | | | | 30 days mortality in teaching hospitals (85% RN) | | | 14.02
| | | | | 30 days mortality in non-urban community hospitals (71% RN) | | | 15.27
| | | | | 30 days mortality in urban community hospitals (79% RN) | | | 15.05
Mark, 2005^90^ | The Area Resource Files, American Hospital Association Annual Survey, CMS | Hospitals | | | | | | Relative risk (95% CI)
Centers for Medicare and Medicaid Services Minimum Cost and Capital File, CMS Provider of Services File, CMS Case Mix Index File, CMS Online Survey; Certification and Reporting system (OSCAR) files, and HCUP files | Wage Rate File, CMS Online Survey | 353 | | | Lowest quartile of HMO penetration | | | 0.99 | 0.97 | 1.02
In-hospital mortality | Certification and Reporting system (OSCAR) files | 362 | | | Second quartile of HMO penetration | | | 1.03 | 1.00 | 1.05
| RN FTEs/1,000 in-patient days | 362 | | | Third quartile of HMO penetration | | | 0.99 | 0.96 | 1.01
| RN hours/patient * day = (FTE RN/1,000 patient * days * 37.5 * 48)/1,000; 37.5 hour work week on average | 360 | | | Highest quartile of HMO penetration | | | 1.01 | 0.99 | 1.04
| 48 working weeks/year | 422 | | | Increase by 1 RN FTE/1,000 patient days in hospitals with high HMO penetration | | | 0.91 | 0.86 | 0.95
| LPN FTEs/1,000 in-patient days | | | | Increase by 1 LPN FTE/1,000 patient days in hospitals with high HMO penetration | | | 1.02 | 0.90 | 1.16
| LPN hours/patient * day = (FTE LPN /1,000 patient * days * 37.5 * 48)/1,000; 37.5 hour work week on average | | | | Increase by 1 RN FTE/1,000 patient days in hospitals with low HMO penetration | | | 1.01 | 0.86 | 1.18
| 48 working weeks/year | | | | Increase by 1 LPN FTE/1,000 patient days in hospitals with low HMO penetration | | | 0.82 | 0.55 | 1.23
| | | | | 25th Quartile of RN FTE/1,000 patient days with high HMO penetration | | | 0.97 | 0.96 | 0.99
| | | | | 50th Quartile of RN FTE/1,000 patient days with high HMO penetration | | | 0.99 | 0.97 | 1.00
| | | | | 75th Quartile of RN FTE/1,000 patient days with high HMO penetration | | | 1.00 | 0.99 | 1.02
| | | | | 25th Quartile of RN FTE/1,000 patient days with low HMO penetration | | | 0.97 | 0.93 | 1.01
| | | | | 50th Quartile of RN FTE/1,000 patient days with high HMO penetration | | | 0.97 | 0.93 | 1.01
| | | | | 75th Quartile of RN FTE/1,000 patient days with low HMO penetration | | | 0.97 | 0.91 | 1.03
| | | | | Reference 1 patient/FTE nurse | | | 1.00 | 1.00 | 1.00
Robertson, 1999^62^ | The American Hospital Association database, hospital average of RN FTE/100 adjusted submissions, hospital average of LPN FTE/100 adjusted submissions, hospital average of aide FTE/100 adjusted submissions | Hospitals | | | | | | Relative risk
HCFA database and Hospitals Information Reports, | | 1,791 | | | Increase by 1 aide in aide/patient ratio in 1989 | | | 0.98
mortality within 30 days of hospital admission | | 2,133 | | | Increase by 1 aide in aide/patient ratio in 1991 | | | 1.02
| | 1,791 | | | Increase by 1 LPN in LPN/patient ratio in 1990 | | | 0.92
| | 1,784 | | | Increase by 1 LPN in LPN/patient ratio in 1989 | | | 0.92
| | 2,133 | | | Increase by 1 RN in RN/patient ratio in 1990 | | | 0.99
| | 2,133 | | | Increase by 1 RN in RN/patient ratio in 1989 | | | 0.99
| | 2,133 | | | Increase by 1 RN in RN/patient ratio in 1991 | | | 0.98
| | 2,133 | | | Increase by 1 UAP aide/patient ratio in 1990 | | | 1.04
| | 2,133 | | | Increase by 1 LPN in LPN/patient ratio in 1991 | | | 1.01
Needleman, 2003^43^ | The American Hospital Association's Annual Survey of Hospitals, | 799 hospitals | | | | | | Relative risk (95% CI)
Hospital discharge data | Total licensed hours (RN + LPN) / adjusted patient day; RN hours / adjusted patient day calculated from FTE in hospital (2,080 hours, 52 weeks at 40 hours/ week) | Units
In-hospital mortality | LPN hours / adjusted patient day calculated from FTE in hospital (2,080 hours, 52 weeks at 40/week). | Medical | | | 1% increase in RN hours/total licensed hours (RN + LPN) | | | 0.9 | 0.74 | 1.09
| UPA hours/adjusted patient day calculated from FTE in hospital (2,080 hours, 52 weeks at 40/week). | Surgical | | | Increase in 1 hour of RN in surgical patients | | | 1 | 0.99 | 1.01
| the proportion of hours of care by RN/licensed nurses (RN + LPN) | Medical | | | Increase in 1 hour of RN in medical patients | | | 1 | 0.99 | 1.01
| | Surgical | | | 1% increase in proportion of RN/total nursing personnel | | | 0.99 | 0.67 | 1.47
| | | | | | | | Death rate
| | Surgical | | | Surgical patients in 799 hospitals (68% RN) | | | 1.6
| | Medical | | | Medical patients in 799 hospitals 68% RN) | | | 3.2
Hartz, 1989^11^ | The American Hospital Association's 1986 annual survey of hospitals | 3,100 hospitals | | | | | | Death rate
Hospital discharges data from The Health Care Financing Administration (HCFA) | Proportion of RN/total nursing personnel in hospital | | | | Hospitals with high proportion of RNs (upper quartile, 61%) | | | 11.31 adjusted for severity
Mortality within 30 days of hospital admission | | | | | Hospitals with high proportion of RNs (upper quartile, 61%) | | | 11.1 crude
| | | | | Hospitals with lower proportion of RNs (lower quartile, 59%) | | | 11.94 adjusted for severity
| | | | | Hospitals with lower proportion of RNs (lower quartile, 59%) | | | 12.16 crude
| | | | | Hospitals with 59% of RNs | | | 11.75 fully adjusted
| | | | | Hospitals with 61% of RNs | | | 11.5 fully adjusted
Krakauer, 1992^12^ | 1986 American Hospital Association (AHA) survey, the proportion of registered nurses/total nursing personnel | 84 hospitals | | | | | | Death rate
Medical records for all Medicare discharges, a random sample of 700 discharges were abstracted from the stratum that included hospitals with 700 or more discharges | | Age 72.3 years, Whites 84%, Males 46% | | | Lower quartile of % of RN, claims model | | | 15.7
Mortality within 30 days of hospital admission | | | | | Upper quartile of % RN, claims model | | | 12.1
| | | | | Lower quartile of % RN, clinical model | | | 14.9
| | | | | Upper quartile of % RN, clinical model | | | 12.8
Aiken, 1994^7^ | 1988 AHA annual survey of hospitals | 79 hospitals | | | | | | Death rate
HCFA database | % of RN/total nursing personnel | | | | Control hospitals, 70.8 % RN | | | 0.111
Mortality within 30 days of hospital admission | | | | | Control hospitals, 67.1% RN | | | 0.116
| | | | | Magnet hospitals, 76% RN | | | 0.105
| | | | | Control hospitals, 69.2% RN | | | 0.117
| | | | | Control hospitals, 69% RN | | | 0.109
| | | | | Control hospitals, 68.2% RN | | | 0.117
Shortell, 1988^54^ | Database of the larger study of 8 multi-hospital systems | 981 hospitals | | | | | | Relative risk (95% CI)
MedPAR dataset of hospital discharges | Proportion of RN/total hospital employee | | | | Increase by 1% in RN/total hospital staff | | | 0.73 (0.48;1.1)
In-hospital mortality
Mark, 2004^89^ | American Hospital Association Annual Survey, Online Survey Certification and Reporting System [OSCAR] | Hospitals | | | | RN hours/patient day | | Relative Risk (95% CI)
The Healthcare Cost and Utilization Project (HCUP) National Inpatient Sample (NIS) | RN FTEs/1000 inpatient days | 357 | | | Year 1993 | 6.05 | | 1.05 | 1.02 | 1.08
In-hospital mortality | RN hours/patient * day = (FTE RN/1,000 patient*days * 37.5 * 48)/1000 | 361 | | | Year 1994 | 6.30 | | 0.97 | 0.94 | 1.00
| LPN FTEs/1,000 inpatient days | 361 | | | Year 1992 | 5.76 | | 1.09 | 1.06 | 1.12
| LPN hours/patient * day = (FTE LPN/1000 patient * days * 37.5 * 48)/1,000 | 366 | | | Year 1992 | 5.65 | | 1.15 | 1.12 | 1.18
| | 373 | | | Year 1990 | 5.44 | | 1.20 | 1.17 | 1.23
| | 357 | | | 75th quartile of RN FTE/1,000 patient days, 7.24 RN hours/patient day | | | 0.96 | 0.95 | 0.98
| | 357 | | | 50th quartile of RN FTE/1,000 patient days, 6.01 RN hours/patient day | | | 0.97 | 0.96 | 0.98
| | 357 | | | 25th quartile of RN FTE/1,000 patient days, 4.79 RN hours/patient day | | | 0.98 | 0.96 | 0.99
| | 357 | | | Year 1995 | 6.48 RN hours | | 0.90 | 0.87 | 0.93
| | 422 | | | Increase by 1 RN FTE/patient day | | | 0.92 | 0.87 | 0.96
| | 422 | | | Increase by 1 LPN FTE/patient day | | | 1.01 | 0.97 | 1.06
| | 422 | | | Reference 1 RN and LPN FTE/patient day | | | 1.00 | 1.00 | 1.00
Silber, 2000^67^ | The American Hospital Association Annual Surveys for 1991-1993, and the Pennsylvania Health Care Cost Containment Council Data Base for years 1991-1994 | Hospitals | | Units | | | | Relative risk (95% CI)
Pennsylvania Medicare claims records; the Medicare Standard Analytic Files; random sample of 50% of Medicare patients who underwent general surgical or orthopedic procedures | RN/bed ratio at hospital level | 245 | | Surgical | Hospitals with lower RN/bed ratio | | | 1 | 1 | 1
Mortality within 30 days of hospital admission | | 258 | | Surgical | Hospitals with higher RN/bed ratio | | | 0.95 | 0.93 | 0.96
| | | | | | | | Death rate
| | 258 | | Surgical | Indirect patients, RN/patient ratio 1.38 | | | 4.53
| | 258 | | Surgical | Directed patients, RN/patient ratio 1.4 | | | 3.41
Hoover, 2000^23^ | The AHA and HCFA databases | Hospitals | | Units | | | | Relative risk
The Health Care Financing Agency, HealthCareReportCards.com; MEDPAR database | RN/LPN ratio = total number RN FTE/LPN FTE reported by the hospital and RN/total nursing staff | 176 | | Medical | Lowest quartile of RN proportion | | | 1 | 1 | 1
Mortality index = [(P -A) / P] * 100 where P = predicted mortality for each hospital according to patients characteristics, and A = actual mortality; | | | | | Highest quartile of RN proportion | | | 0.84 | 0.78 | 0.92
In hospital mortality, and 6 months after submission mortality
Aiken, 2001^27^ | American Hospital Association Annual survey | 22 hospitals | | | Nurse staffing - RN FTE/average daily census in units | | | Correlation with mortality
MedPar Mortality Data file for 1997 | RN FTE/daily average units census | | | | | | | -0.49
In hospital mortality
Bond, 1999^60^ | Data from the AHA and HCFA data bases were matched for 3,763 hospitals | 3,763 hospitals | | | | | | Change in Death rate ± SD
Hospital Medicare mortality rates from the Health Care Financing Administration | FTE RN/the mean number of occupied beds for each hospital | | | | Increase by 1 RN/patient | | | -0.0003 ± 0.0061
In hospital mortality/1,000 admissions and number of deaths/hospital/year | FTE LPN/the mean number of occupied beds for each hospital | | | | Increase by 1 LPN/patient | | | 0.0005 ± 0.0092
Shortell, 1994^94^ | Hospital administrative databases; survey of nursing directors in each unit | 40 hospitals, 42 ICU units; Patients Medical | | | | | | Relative risk
Hospitals discharge data | An average RN/patient ratio in unit during the study period, number of nurses who left ICU in the year of the study/number of nurses employed that year | | | | Increase by 1 RN/patient ratio | | | 1.14
In hospital mortality, standardized morality ratio (actual mortality in each unit/predicted mortality)
Boyle, 2004^47^ | Nurses NWI-R survey (N=390) of nurses working >1 month in the unit | Single hospitals study, 21 units | | | | | | Correlation with mortality
Patient discharges | NWI-R 57 items questionnaire to report nurse autonomy and collaboration; | | | | Nurse manager support | | | -0.3
In-hospital mortality | NWI-R 57 items questionnaire to report nurse manager support
Halm, 2005^51^ | Survey of 140 staff nurses (42% response rate); daily variable staffing plans and unit census records | Single hospital study, age 55.6 years, | | | | | | Relative risk
The hospital's data warehouse with patients discharges | Average RN/patient ratio was calculated for each nursing unit across all 3 shifts for every week; | 37.4% Males | | | Increase by 1 unit in RN/patient ratio | | | 1.01
Mortality within 30 days of hospital admission | % of RN with BSN and higher; years of total nursing experience; Burnout: Maslach Burnout Inventory Manual (max 6 scores) with 3 subscales of burnout: emotional exhaustion; depersonalization; personal accomplishment (feelings of competence and successful achievement in one's work). Overall rating on a simple 4-point Likert scale, ranging from 1 (very dissatisfied) to 4 (very satisfied) and the likelihood to leave current position within the next 12 months | 22.7% emergency admission
| | Patients Surgical
Thorson, 1995^55^ | The archives of the NC Board of Nursing for 100 hospitals, an average of total nursing hours/patient day in surgical and medical units, an average RN hours/patient day in surgical and medical units | 100 hospitals | | | | | | Relative risk (95% CI)
Administrative data on patient discharges from the North Carolina Medical Database Commission | | | | | Increase by 1 RN hour, crude odds of death | | | 1.004 | 1.003 | 1.004
In-hospital mortality | | | | | Increase by 1 RN hour, adjusted for patient characteristics odds ratio | | | 1.009 | 1.008 | 1.010
| | | | | Increase by 1 RN hour, adjusted for patient and hospital characteristics odds ratio | | | 1.008 | 1.007 | 1.010
Unruh, 2000^66^ | State Department of Health, American Hospital Association | 1,477 hospitals, | | | Year | RN/patient ratio | % RN | Death rate
State Health Care Cost Containment Council | Total nurses FTE/1,000 APDC | Whites: 45.4% | | | 1991 | 2.9 | 69 | 3.10
In-hospital mortality | RN FTE/1,000 APDC | Males: 42.43% | | | 1992 | 2.7 | 69 | 2.85
| LPN FTE/1,000 APDC | | | | 1993 | 2.7 | 70 | 2.81
| UAP FTE/1,000 APDC | | | | 1994 | 2.7 | 71 | 2.67
| % of RN FTE /total nurses FTE | | | | 1995 | 2.6 | 72 | 2.60
| | | | | 1996 | 2.8 | 71 | 2.47
| | | | | 1997 | 2.7 | 72 | 2.33
| | | | | | | | Change in death rate
| | | | | Increase by 1 unit in RN/patient ratio | | | 0.02
| | | | | Increase by 1 unit in RN/patient ratio in small hospitals | | | 0.32
| | | | | Increase by 1 unit in RN/patient ratio in medium hospitals | | | -0.13
| | | | | Increase by 1 unit in RN/patient ratio in large hospitals | | | -0.03
| | | | | Increase by 1 unit in LPN/patient ratio | | | -0.09
| | | | | Increase by 1 unit in LPN/patient ratio in small hospitals | | | -0.21
| | | | | Increase by 1 unit in LPN/patient ratio in medium hospitals | | | -0.31
| | | | | Increase by 1 unit in LPN/patient ratio in large hospitals | | | -0.19
| | | | | Increase by 1 unit in UAP/patient ratio | | | 0.04
| | | | | Increase by 1 unit in UAP/patient ratio in small hospitals | | | 0.38
| | | | | Increase by 1 unit in UAP/patient ratio in medium hospitals | | | -0.07
| | | | | Increase by 1 unit in UAP/patient ratio in large hospitals | | | 0.005
| | | | | Increase by 1% in RN proportion | | | 0.00
| | | | | Increase by 1% in RN proportion in small hospitals | | | -0.00
| | | | | Increase by 1% in RN proportion in medium hospitals | | | 0.00
| | | | | Increase by 1% in RN proportion in large hospitals | | | 0.00

AHA = American Hospital Association; AMI = Acute Myocardial Infarction; BSN = Bachelor or Science in Nursing; CI = Confidence Interval; CMS = Centers for Medicare and Medicaid Services; FTE = Full Time Equivalent; HMO = Health Maintenance Organization; ICU = Intensive Care Unit; LPN = Licensed Practical Nurse; LVN = Licensed Vocational Nurse; MedPAR = Medicare Provider Analysis Review; NIW = nursing intensity weights; RN = Registered Nurse; SD = Standard Deviation; UAP = Unlicensed Assistive Personnel

Table G4 The relative risk of hospital related mortality among estimated categories of patients/nurse/shift ratio

Author (Patients/RN/Shift) | RR | 95% CI
Pronovost^61^ (2 vs. 3) | 0.53 | 0.33; 0.83
Amaravadi^64^ (1.5 vs. 3) | 0.70 | 0.30; 2.00
Dimick^70^ (1.5 vs. 3.5) | 2.04 | 0.78; 5.56
Aiken^5^ (1.5 vs. 5) | 0.19 | 0.06; 0.61
Aiken^5^ (1.9 vs. 5) | 0.08 | 0.01; 0.47
Aiken^5^ (2 vs. 3) | 0.94 | 0.91; 0.99
Aiken^39^ (1 vs. 6) | 0.67 | 0.51; 0.84
Aiken^39^ (1 vs. 4) | 0.76 | 0.64; 0.89
Person^88^ (1.1 vs. 2.8) | 0.91 | 0.86; 0.97
Person^88^ (1.6 vs. 2.8) | 0.94 | 0.88; 1.00
Person^88^ (1.9 vs. 2.8) | 0.96 | 0.90; 1.00
Elting^92^(4.3 vs. 9.5) | 0.43 | 0.19; 0.97
Mark^90^ (4.2 vs. 13.3) | 0.99 | 0.97; 1.02
Mark^90^ (4.1 vs. 13.3) | 1.03 | 1.00; 1.05
Mark^90^ (3.8 vs. 13.3) | 0.99 | 0.97; 1.01
Mark^90^ (3.6 vs. 13.3) | 1.01 | 0.99; 1.04
Mark^90^ (6.7 vs. 13.3) | 0.82 | 0.74; 0.91
Mark^90^ (6.7 vs. 13.3) | 1.01 | 0.74; 1.39
Mark^90^ (5 vs. 13.3) | 0.97 | 0.96; 0.99
Mark^90^ (4 vs. 13.3) | 0.99 | 0.98; 1.00
Mark^90^ (3.3 vs. 13.3) | 1.00 | 0.99; 1.02
Mark^90^ (5 vs. 13.3) | 0.97 | 0.93; 1.01
Mark^90^ (4 vs. 13.3) | 0.97 | 0.93; 1.01
Mark^90^ (3.3 vs. 13.3) | 0.97 | 0.91; 1.03
Mark^89^ (4 vs. 13.3) | 1.05 | 1.02; 1.08
Mark^89^ (3.8 vs. 13.3) | 0.97 | 0.94; 1.00
Mark^89^ (4.2 vs. 13.3) | 1.09 | 1.06; 1.12
Mark^89^ (4.2 vs. 13.3) | 1.15 | 1.12; 1.18
Mark^89^ (4.4 vs. 13.3) | 1.20 | 1.17; 1.23
Mark^89^ (3.3 vs. 13.3) | 0.96 | 0.95; 0.98
Mark^89^ (4 vs. 13.3) | 0.97 | 0.96; 0.98
Mark^89^ (5 vs. 13.3) | 0.98 | 0.97; 0.99
Mark^89^ (3.7 vs. 13.3) | 0.90 | 0.87; 0.93
Mark^89^ (6.7 vs. 13.3) | 0.84 | 0.76; 0.93
Silber^67^ (1.6 vs. 2.7) | 0.95 | 0.93; 0.96
Shortell^54^ (1.5 vs. 3) | 1.13 | 0.86; 1.13
Robertson^62^ (1.5 vs. 3) | 0.97 | NR
Robertson^62^ (1.5 vs. 3) | 0.98 | NR
Robertson^62^ (1.5 vs. 3) | 0.96 | NR
Halm^51^ (0.8 vs. 4) | 1.02 | NR
Author (Patients/LPN/Shift)
Person^88^ (8 vs.11) | 1.07 | 1.00; 1.15
Person^88^ (10 vs. 11) | 1.00 | 0.94; 1.07
Mark^90^ (18 vs. 13) | 0.99 | 0.97; 1.02
Mark^90^ (21 vs. 13) | 1.03 | 1.00; 1.05
Mark^90^ (24 vs. 13) | 0.99 | 0.96; 1.01
Mark^90^ (25 vs. 13) | 1.01 | 0.99; 1.04
Mark^90^ (7 vs. 13) | 1.05 | 0.82; 1.34
Mark^90^ (7 vs. 13) | 0.68 | 0.30; 1.52
Robertson^62^ (3 vs. 20) | 0.92 | NR
Mark^89^ (21 vs. 13) | 1.05 | 1.02; 1.08
Mark^89^ (23 vs. 13) | 0.97 | 0.94; 1.00
Mark^89^ (20 vs. 13) | 1.09 | 1.06; 1.12
Mark^89^ (19 vs. 13) | 1.15 | 1.12; 1.18
Mark^89^ (20 vs. 13) | 1.20 | 1.17; 1.23
Mark^89^ (23 vs. 13) | 0.90 | 0.87; 0.93
Mark^89^ (7 vs. 13) | 1.01 | 0.97; 1.06

NR- not reported

Table G5 Evidence of the association between nurse/patient ratio and patient outcomes

Author, Source to Measure Patient Outcomes, Definition of Patient Outcomes, Source to Measure Nurse Staffing, Definition of Nurse/Patient Ratios | Number of Hospitals, Units, Patient Age, % of Whites, % of Males, % of Emergency Admissions | | | Nurse Staffing Categories | | | | Patient Outcomes
Aiken^39^ | 168 | | | | | | | Failure to rescue %
Discharge abstracts, | ICU | | | 60% of hospital workforce with BSN or higher, 8 patients/day | | | | 8.47
Failure to rescue: deaths within 30 days of admission among patients who experienced complications; | Surgical | | | 40% of hospital workforce with BSN or higher, 4 patients/nurse | | | | 7.84
Complications: the secondary diagnosis distinguished from preexisting comorbidities | Age | 60.8 | 61.3 | 20% of hospital workforce with BSN or higher, 4 patients/nurse | | | | 8.54
Surveys of hospital nurses (the Pennsylvania Board of Nursing) | Sex | 42.9 | 41.8 | 60% of hospital workforce with BSN or higher, 6 patients/nurse | | | | 7.80
The mean number of patients assigned to all staff nurses who reported caring for at least 1 but fewer than 20 patients on the last shift they worked | Severity | 28.5 | 18.9 | 40% of hospital workforce with BSN or higher, 6 patients/nurse | | | | 8.50
| | | | 20% of hospital workforce with BSN or higher, 6 patients/nurse | | | | 9.26
| | | | 60% of hospital workforce with BSN or higher, 4 patients/nurse | | | | 7.18
| | | | 20–29% of hospital workforce with BSN or higher | | | | 9.40
| | | | <20% of hospital workforce with BSN or higher | | | | 10.20
| | | | 20% of hospital workforce with BSN or higher, 8 patients/nurse | | | | 10.02
| | | | >50% of hospital workforce with BSN or higher | | | | 6.90
| | | | 40–49% of hospital workforce with BSN or higher | | | | 8.60
| | | | 30–39% of hospital workforce with BSN or higher | | | | 8.00
| | | | 40% of hospital workforce with BSN or higher | | | | 9.22
| | | | | | | | Relative Risk
| | | | Increase in workload of 1 patient | | | | 1.05 | 1.01 | 1.10
| | | | Reference 1 RN/patient | | | | 1
| | | | | | | | Complications, %
| | | | 20–29% of hospital workforce with BSN or higher | | | | 22.90
| | | | <20% of hospital workforce with BSN or higher | | | | 22.90
| | | | >50% of hospital workforce with BSN or higher | | | | 25.20
| | | | 40–49% of hospital workforce with BSN or higher | | | | 22.00
| | | | 30–39% of hospital workforce with BSN or higher | | | | 22.80
Aiken^74^ | 168 | | | | | | | Failure to rescue, Relative risk
Hospital data (Health Care Cost Containment Council; | Combined | | | Increase by 6 patients/nurse | | | | 1.50 | 1.13 | 1.87
Failure to rescue: deaths within 30 days of admission among patients who experienced complications; | Surgical | | | Increase by 1 patient/nurse | | | | 1.07 | 1.02 | 1.11
Survey of 50% random sample of registered nurses who were on the Pennsylvania Board of Nursing rolls; | Age | 59.3 | | Increase by 8 patients/nurse | | | | 1.72 | 1.17 | 2.30
The mean patient load across all staff registered nurses who reported having responsibility for at least 1 but fewer than 20 patients on the last shift they worked, regardless of the specialty or shift (day, evening, night) worked | Sex | 43.7 | | Increase by 4 patients/nurse | | | | 1.31 | 1.08 | 1.52
| Severity | 27.3 | | Reference 1 RN/patient | | | | 1.00 | 1.00 | 1.00
Alonso-Echanove^79^ | ICU | | | | | | | Bloodstream infections, rate %
All adult patients admitted to the ICU for at least 48 hours; | Medical | | | All ICU from 1997-1999 | | | | 2.80
Bloodstream infections as secondary diagnosis after CVC. Duration of CVC- number of days from the placement date to the day when bloodstream infection occurred or to the day of CVC removal; | Race | 61 | | RN/patient ratio: 0.5
Unit administrative records; | Sex | 54 | | Patient/UAP: 14.3
Number of RN nurses for each patient each day; | | | | | | | | Relative risk
Number of patient care assistants/100 patients | | | | Increase by 1 RN and UAP/patient | | | | Not significant
Amaravadi^64^ | ICU | | | | | | | Pneumonia %
The Uniform Health Discharge Data Set; | Surgical | | | Night time nurse to patient ratio <1:2 | | | | 16.00
Postoperative pneumonia; aspiration, pulmonary failure; reintubation after unplanned extubation; cardiac arrest; | Age | 63 | | Night time nurse to patient ratio >1:2 | | | | 8.00
Complications: respiratory, Pneumonia, reintubation, aspiration, infectious, septicemia, postoperative infection, myocardial infarction, cardiac arrest, surgical complications, acute renal failure, septicemia; | Race | 77 | | | | | | Relative risk
Survey of ICU directors; | Sex | 70 | | Night time nurse to patient ratio <1:2 | | | | 2.40 | 1.20 | 4.70
An average nurse-to-patient ratio of greater than or equal to 1:2 versus less than 1:2 both during the day and at night | Severity | 12 | | Night time nurse to patient ratio >1:2 | | | | 1.00 | 1.00 | 1.00
| | | | | | | | Pulmonary failure %
| | | | Night time nurse to patient ratio <1:2 | | | | 25.00
| | | | Night time nurse to patient ratio >1:2 | | | | 22.00
| | | | | | | | Relative risk
| | | | Night time nurse to patient ratio <1:2 | | | | 1.20 | 0.70 | 2.00
| | | | Night time nurse to patient ratio >1:2 | | | | 1.00 | 1.00 | 1.00
| | | | | | | | Reintubation %
| | | | Night time nurse to patient ratio <1:2 | | | | 25.00
| | | | Night time nurse to patient ratio >1:2 | | | | 12.00
| | | | | | | | Relative risk
| | | | Night time nurse to patient ratio <1:2 | | | | 2.50 | 1.40 | 4.50
| | | | Night time nurse to patient ratio >1:2 | | | | 1.00 | 1.00 | 1.00
| | | | | | | | CPR %
| | | | Night time nurse to patient ratio <1:2 | | | | 0.80
| | | | Night time nurse to patient ratio >1:2 | | | | 0.00
| | | | | | | | Relative risk
| | | | Night time nurse to patient ratio <1:2 | | | | 1.20 | 0.60 | 2.20
| | | | Night time nurse to patient ratio >1:2 | | | | 1.00 | 1.00 | 1.00
| | | | | | | | Medical complications %
| | | | Night time nurse to patient ratio <1:2 | | | | 0.80
| | | | Night time nurse to patient ratio >1:2 | | | | 0.90
| | | | | | | | Relative risk
| | | | Night time nurse to patient ratio <1:2 | | | | 0.90 | 0.08 | 9.70
| | | | Night time nurse to patient ratio >1:2 | | | | 1.00 | 1.00 | 1.00
| | | | | | | | Surgical complications %
| | | | Night time nurse to patient ratio <1:2 | | | | 17.00
| | | | Night time nurse to patient ratio >1:2 | | | | 8.00
| | | | | | | | Relative risk
| | | | Night time nurse to patient ratio <1:2 | | | | 1.90 | 0.90 | 3.80
| | | | Night time nurse to patient ratio >1:2 | | | | 2.10 | 0.70 | 6.40
| | | | | | | | Sepsis, %
| | | | Night time nurse to patient ratio <1:2 | | | | 6.20
| | | | Night time nurse to patient ratio >1:2 | | | | 1.80
| | | | | | | | Relative risk
| | | | Night time nurse to patient ratio <1:2 | | | | 3.70 | 1.10 | 12.50
| | | | Night time nurse to patient ratio>1:2 | | | | 1.00 | 1.00 | 1.00
Bolton^26^ | Unit | Patients | | | | | | Falls /100 patient days
California Nursing Outcomes Coalition database; the California Department of Health Services; 1,253,892 inpatient days; | Medical | Medical | | Medical-surgical units: 5 patients/RN, 2.4 patient/UAP | | | | 3.70
Hospital acquired pressure ulcers: the monthly rate per 1,000 patient days for each nursing unit and each hospital. Falls: unplanned descent to the floor in adult patients; the monthly fall rate per 1,000 patient days for each nursing unit and each hospital. Data were collected at the patient level and aggregated by CalNOC staff to the unit level. | ICU | Medical | | Critical Care units: 1.6 patients/RN | | | | 0.10
California Nursing Outcomes Coalition database; the California Department of Health Services | | | | | | | | Pressure ulcers/100 patient days
RN/patient day | | | | Medical-surgical units: 5 patients/RN, 2.4 patient/UAP | | | | 8.00
| | | | Critical Care units: 1.6 patients/RN | | | | 13.00
Cheung^32^ | Unit | Combined | | | | | | Pressure ulcers
Incidence reports, quality referrals, and medical record coding stores in the database Excalibur system | Patients | Medical | | Increase by one increment in nurse staffing variables: | | | | Relative risk
Pressure ulcers coded as secondary diagnosis; patients falls coded as secondary diagnosis; primary bloodstream infections after admitting the unit; | | | | RN/patient ratio | | | | NS
Automated Nurse staffing Office system and direct observation of nursing activities with Hill_Rom COMposer@nurse locator system; | | | | LPN/patient ratio | | | | NS
Number of patients assigned to RN during a shift; number of patients assigned to LPN during the shift; ratio of RN and LPN to unlicensed nursing personnel | | | | Increase by one increment in nurse staffing variables: | | | | Falls, Relative risk
| | | | RN/patient ratio | | | | NS
| | | | LPN/patient ratio | | | | NS
| | | | Increase by one increment in nurse staffing variables: | | | | Primary bloodstream infection
| | | | | | | | Relative risk
| | | | RN/patient ratio | | | | NS
| | | | LNPNpatient ratio | | | | NS
Dang^75^ | Unit | ICU | | | | | | Relative risk
The Uniform Health Discharge Data Set | Patients | Surgical | | | | | | Pulmonary failure
Aspiration, atelectasis or pulmonary failure; pneumonia; pulmonary insufficiency after a procedure; tracheal reintubation; cardiac arrest; | Race | 89 | | High Intensity | 4 patients/RN | | | 2.33 | 1.50 | 3.60
Cardiac complications: acute myocardial infarction | Sex | 68 | | Mixed Intensity | 3 patients/RN | | | 5.11 | 2.89 | 9.04
Cardiac complications after a procedure | Severity | 13 | | Low Intensity | 2 patients/RN | | | 1.00 | 1.00 | 1.00
Other: acute renal failure, platelet transfusion | | | | | | | | Extubation
Any other complication | | | | High Intensity | 4 patients/RN | | | 2.33 | 1.50 | 3.60
Any complication; septicemia; | | | | Mixed Intensity | 3 patients/RN | | | 2.09 | 1.47 | 3.03
Survey of ICU directors; | | | | Low Intensity | 2 patients/RN | | | 1.00 | 1.00 | 1.00
An average nurse-to-patient ratio in the ICU during the daytime; low-intensity staffing (1:3 or greater on the day and night shifts); medium intensity (1:3 or greater on either the day or night shift, but not both);high-intensity staffing <1:2 | | | | | | | | CPR
| | | | High Intensity | 4 patients/RN | | | 1.34 | 0.82 | 2.17
| | | | Mixed Intensity | 3 patients/RN | | | 2.10 | 1.26 | 3.50
| | | | Low Intensity | 2 patients/RN | | | 1.00 | 1.00 | 1.00
| | | | | | | | Complication
| | | | High Intensity | 4 patients/RN | | | 1.34 | 0.82 | 2.17
| | | | Mixed Intensity | 3 patients/RN | | | 2.10 | 1.26 | 3.50
| | | | Low Intensity | 2 patients/RN | | | 1.00 | 1.00 | 1.00
| | | | | | | | Sepsis
| | | | High Intensity | 4 patients/RN | | | 1.13 | 0.73 | 1.75
| | | | Low Intensity | 2 patients/RN | | | 1.00 | 1.00 | 1.00
Dimick^70^ | Unit: | ICU | | | | | | Pneumonia, %
The Uniform Health Discharge Data Set | Patients: | Surgical | | More nurses: RN/patient 1:1–1:2 | | | | 2.80
Postoperative pneumonia, pulmonary failure, aspiration, reintubation, cardiac arrest, myocardial infarction, acute renal failure; septicemia; | Group | 316 | | Fewer nurses: RN/patient 1:3–1:4 | | | | 4.20
Survey of ICU directors; | Age | 56 | | | | | | Relative risk
An average nurse-to-patient ratio in the ICU during the day and evening and at night; "more ICU nurses: nurse/ patient ratio 1:1 or 1:2; “fewer ICU nurses”: nurse/patient ratio 1:3 or 1:4 | Race | 82 | | More nurses: RN/patient 1:1–1:2 | | | | 1.00 | 1.00 | 1.00
| Severity | 15 | | Fewer nurses: RN/patient 1:3–1:4 | | | | 1.40 | 0.60 | 3.50
| | | | | | | | Pulmonary Failure %
| | | | More nurses: RN/patient 1:1–1:2 | | | | 1.60
| | | | Fewer nurses: RN/patient 1:3–1:4 | | | | 5.80
| | | | | | | | Relative risk
| | | | More nurses: RN/patient 1:1–1:2 | | | | 1.00 | 1.00 | 1.00
| | | | Fewer nurses: RN/patient 1:3–1:4 | | | | 3.60 | 1.30 | 10.10
| | | | | | | | Extubation %
| | | | More nurses: RN/patient 1:1–1:2 | | | | 1.90
| | | | Fewer nurses: RN/patient 1:3–1:4 | | | | 10.80
| | | | | | | | Relative risk
| | | | More nurses: RN/patient 1:1–1:2 | | | | 5.70 | 2.40 | 13.70
| | | | Fewer nurses: RN/patient 1:3–1:4 | | | | CPR %
| | | | More nurses: RN/patient 1:1–1:2 | | | | 0.60
| | | | Fewer nurses: RN/patient 1:3–1:4 | | | | 0.80
| | | | | | | | Complications %
| | | | More nurses: RN/patient 1:1–1:2 | | | | 6.60
| | | | Fewer nurses: RN/patient 1:3–1:4 | | | | 1.20
| | | | | | | | Sepsis %
| | | | More nurses: RN/patient 1:1–1:2 | | | | 2.70
| | | | Fewer nurses: RN/patient 1:3–1:4 | | | | 5.40
Donaldson^9^ | Hospitals | 68 | | | | | | Falls /100 patient days ± SD
CalNOC database | Unit | Combined | | Medical surgical units, before mandatory ratios: 5.43 patients/RN | | | | 0.31 ± 0.20
Total number of patients with Stage I–IV pressure ulcers regardless of whether ulcer was acquired during hospitalization or present on admission; %/total number of surveyed patients, unplanned descent to the floor; rate/1,000 patient days. | Patients | Medical | | Medical and surgical units after mandatory ratios: 4.48 patients/RN | | | | 0.32 ± 0.17
CalNOC database in 2004 and 2005 (after legislation); number of patients/RN | | | | Step-down units before mandatory ratios: 4.02 patients/RN | | | | 0.30 ± 0.22
| | | | Step-down units after mandatory ratios: 3.56 patients/RN | | | | 0.26 ± 0.16
| | | | | | | | Pressure ulcers/100 patient days ± SD
| | | | Medical surgical units, before mandatory ratios: 5.43 patients/RN | | | | 14.07 ± 11.07
| | | | Medical and surgical units after mandatory ratios: 4.48 patients/RN | | | | 14.48 ± 10.39
| | | | Step-down units before mandatory ratios: 4.02 patients/RN | | | | 13.52 ± 10.78
| | | | Step-down units after mandatory ratios: 3.56 patients/RN | | | | 16.29 ± 10.27
Donaldson^95^ | Hospitals | 25 | | | | | | Change in falls rate/100 patient days ± SD
California Nursing Outcomes Coalition (CalNOC) | Unit | Combined | | Increase by 1 patient/RN | | | | 0.02 ± 0.05
Hospital acquired pressure related skin injury controlling for date of admission, % of all patients on the day of prevalence study; patient's unplanned descent to the hospital floor; were analyzed as 7 day aggregate per unit; also actually number per unit; the number of falls/1000 patient days. | Patient | Medical | | Increase by 1 patient/licensed staff | | | | 0.02 ± 0.09
The California Nursing Outcomes Coalition (CalNOC)
Elting^92^ | Hospitals | 75 | | | | | | Failure to rescue
The Texas Hospital Discharge Public Use Data File linked to the 2000 U.S. Census | Unit | Surgical | | | | | | Relative risk
Bacteremia, wound infection, pulmonary compromise, pneumonia, deep venous thrombosis, pulmonary embolus, reoperation, postoperative coma or shock, acute myocardial infarction, arrhythmia, and cardiac arrest or shock. | Patients | Surgical | | Hospitals with many RNs/occupied bed | 3.1 RNs/patient | | | 1.00 | 1.00 | 1.00
Hospital Cost Report Information System, Provider of Services files, and the American Hospital Association Survey; number of LPN/mean annual number of occupied bed days, number of RN/mean annual number of occupied bed days | | | | Hospitals with few RNs/occupied bed | 1.4 RNs/patient | | | 0.39 | 0.10 | 0.80
| | | | | | | | Complication rate %
| | | | Hospitals with many RNs/occupied bed | 3.1 RNs/patient | | | 12.60
| | | | Hospitals with few RNs/occupied bed | 1.4 RNs/patient | | | 16.20
| | | | Hospitals with many LPNs/occupied bed | 0.32 patients/LPN | | | 14.20
| | | | Hospitals with few LPNs/occupied bed | 1.40 patients/LPN | | | 14.00
Flood^53^ | Hospitals | 1 | | | | | | Urinary tract infection %
Patient medical records; nosocomial infections including urinary tract infections and gangrene; congestive heart failure and arrhythmias, gastrointestinal bleeding. | Unit | Combined | | Understaffed unit | 3.8 patient/s RN | | | 0.12
Staffing workload index; RN FTE/patient/shift/unit | Patients | Medical | | Normally staffed unit | 4.94 patients/RN | | | 0.14
| | | | | | | | Nosocomial infection %
| | | | Understaffed unit | 3.8 patients/RN | | | 0.16
| | | | Normally staffed unit | 4.94 patients/RN | | | 0.19
| | | | | | | | Complication %
| | | | Understaffed unit | 3.8 patients/RN | | | 64.00
| | | | Normally staffed unit | 4.94 patients/RN | | | 71.00
Fridkin^1^ | Hospitals | 1 | | | | | | Nosocomial infection
Medical records of surgical patient in ICU. Cases were defined as any patient hospitalized >48 hours, in the SICU >24 hours who developed a laboratory confirmed CVC-BSI during outbreak periods. Controls were randomly selected from all SICU patients; | Unit | ICU | | | | | | Relative risk
laboratory confirmed catheter-associated bloodstream infections or clinical sepsis; rates were compared in pre- and outbreak periods. | Patients | Surgical | | Month's patient/nurse ratio = 1.2 | | | | 3.95 | 1.07 | 14.54
Hospital administrative records; | | | | Month's patient/nurse ratio = 1.5 | | | | 15.60 | 1.15 | 211.40
average monthly SICU patient-to-nurse ratio; ratio in pre- and outbreak periods | | | | Month's patient/nurse ratio = 2 | | | | 61.50 | 1.23 | 3,074
| | | | Month's patient/nurse ratio = 1 | | | | 1.00 | 1.00 | 1.00
| | | | | | | | Rate/100 patient days
| | | | Pre-outbreak period | | | | 1.95
| | | | Outbreak period | | | | 4.96
| | | | | | | | Sepsis, rate/100 patient days
| | | | Pre-outbreak period | | | | 0.53
| | | | Outbreak period | | | | 1.31
Halm^51^ | Hospitals | 1 | | | | | | Failure to rescue
The hospital's data warehouse with patient's discharges; failure to rescue: death following complications within 30 days. | Unit | Surgical | | Increase by 1 unit in RN/patient ratio | | | | Relative risk NS
Survey of 140 staff nurses (42% response rate); daily variable staffing plans and unit census records | Patients | Surgical
Average RN/patient ratio was calculated for each nursing unit across all 3 shifts for every week
Hope^86^ | Unit | Patients | | | Patients/RN | | | Rate/100 patient days
Medical Microbiology Laboratory and Infection Control Services; Discharge Abstract Database incidence rate of urinary tract infection, incidence rate of ventilator associated pneumonia, incidence rate of infections that occurred after 72 hours of hospitalization, incidence rate of surgical site infections, incidence rate of positive culture with known pathogen or two or more positive cultures with pathogens one can be considered as contaminant. | Surgical | Surgical | | | | | | Urinary tract infection,
The Grace Reynolds Application of the Study of Peto; Nursing Workload Office | Surgical | Surgical | | Surgery ward 1 | 5.64 | | | 0.65
Calculated from RN utilization as (national US standard * Utilization) / 100 | Surgical | Surgical | | Surgery ward 2 | 6.97 | | | 0.88
| Surgical | Surgical | | Surgery ward 3 | 5.16 | | | 0.91
| Medical | Medical | | Surgery ward 4 | 6.64 | | | 0.66
| Medical | Medical | | Medicine ward 1 | 6.79 | | | 0.00
| Medical | Medical | | Medicine ward 2 | 4.07 | | | 0.65
| Medical | Medical | | Medicine ward 3 | 6.11 | | | 0.50
| Medical | Medical | | Medicine ward 4 | 6.09 | | | 0.64
| Medical | Medical | | medicine ward 4 | 6.19 | | | 1.27
| Medical | Medical | | Medicine ward 5 | 6 | | | 0.68
| Medical | Medical | | Medicine ward 6 | 5.39 | | | 0.72
| Specialty | Medical | | Medicine ward 7 | 5.54 | | | 0.74
| ICU | Medical | | Coronary Care Unit | 4.62 | | | 0.42
| ICU | Medical | | ICU unit | 2.45 | | | 1.13
| Surgical | Medical | | Neonatal ICU | 2.14 | | | 4.03
| Neonatal | Medical | | Neurosurgical critical care unit | 6.79 | | | 1.33
| | | | Pediatrics unit | 4.39 | | | 0.27
| | | | | | | | Relative risk NS
| | | | | | | | Nosocomial infection
| | | | Surgery ward 1 | 5.64 | | | 0.01
| | | | Surgery ward 2 | 6.97 | | | 0.06
| | | | Surgery ward 3 | 5.16 | | | 0.02
| | | | Surgery ward 4 | 6.64 | | | 0.03
| | | | Medicine ward 1 | 6.79 | | | 0.03
| | | | Medicine ward 2 | 4.07 | | | 0.02
| | | | Medicine ward 3 | 6.11 | | | 0.01
| | | | Medicine ward 4 | 6.09 | | | 0.01
| | | | Medicine ward 4 | 6.19 | | | 0.001
| | | | Medicine ward 5 | 6 | | | 0.001
| | | | Medicine ward 6 | 5.39 | | | 0.01
| | | | Medicine ward 7 | 5.54 | | | 0.04
| | | | Coronary Care Unit | 4.62 | | | 0.001
| | | | ICU unit | 2.45 | | | 0.20
| | | | Neonatal ICU | 2.14 | | | 0.01
| | | | Neurosurgical critical care unit | 6.79 | | | 0.01
| | | | Pediatrics unit | 4.39 | | | 0.001
| | | | | | | | Relative Risk NS
| | | | Surgery ward 1 | 5.64 | | | Sepsis, %
| | | | Surgery ward 2 | 6.97 | | | 7.54
| | | | Surgery ward 3 | 5.16 | | | 11.80
| | | | Surgery ward 4 | 6.64 | | | 0.33
| | | | Medicine ward 1 | 6.79 | | | 4.59
| | | | Medicine ward 2 | 4.07 | | | 0.00
| | | | Medicine ward 3 | 6.11 | | | 7.21
| | | | Medicine ward 4 | 6.09 | | | 2.95
| | | | medicine ward 4 | 6.19 | | | 1.31
| | | | Medicine ward 5 | 6
| | | | Medicine ward 6 | 5.39 | | | 7.87
| | | | Medicine ward 7 | 5.54 | | | 8.20
| | | | Coronary Care Unit | 4.62 | | | 6.56
| | | | ICU unit | 2.45 | | | 1.97
| | | | Neonatal ICU | 2.14 | | | 23.28
| | | | Neurosurgical critical care unit | 6.79 | | | 9.51
| | | | Pediatrics unit | 4.39 | | | 4.59
| | | | | | | | 2.30
| | | | | Patients/RN | | | UTI relative risk
| | | | Higher RN Utilization (111%) | 5.34 | | | 1.14 | 1.02 | 1.26
| | | | | | | | Pneumonia relative risk
| | | | 1% increase in RN utilization | 5.94 | | | 0.97 | 0.94 | 1.01
| | | | Higher RN Utilization (111%), | 5.34 | | | 0.66 | 0.43 | 1.01
| | | | Higher RN utilization (>89%) | 7.14 | | | 1.59 | 2.43 | 1.04
| | | | | | | | Nosocomial infection relative risk
| | | | 1% increase in RN utilization | 5.94 | | | 0.97 | 0.96 | 0.99
| | | | Higher RN Utilization (111%) | 5.34 | | | 0.62 | 0.31 | 1.23
| | | | 1% increase in RN utilization | 5.94 | | | 1.01 | 0.99 | 1.03
| | | | | | | | Sepsis relative risk
| | | | 1% increase in RN utilization, surgery wards | 5.94 | | | 0.98 | 0.97 | 0.98
| | | | Higher RN Utilization (111%), surgery wards | 5.34 | | | 0.66 | 0.50 | 0.87
| | | | 1% increase in RN utilization, surgery wards | 5.94 | | | 0.99 | 0.98 | 1.00
| | | | Higher RN utilization (>114%) in surgical units | 5.16 | | | 0.53 | 0.34 | 0.83
Houser^49^ | Hospitals | 170 | | | | | | Failure to rescue % ± SD
Nationwide Inpatient Sample of 2001 with hospital discharge records; | Unit Combined | | | RN/patient ratio 0.15–1.29 | | | | 11.61 ± 8.41
Failure to rescue: death/1,000 patients who developed complications of care during hospitalization; cases of decubitus ulcer/1,000 discharges identified as secondary diagnosis, cases of acute respiratory failure/1,000 surgical discharges, cases of deep vein thrombosis or PE/1,000 surgical discharges. | Patients | Medical | | RN/patient ratio 1.3–1.89 | | | | 13.82 ± 5.80
American Hospital Association Annual Survey for 2001; Hospital reported RN FTE/average daily census | Age | 55.08 | | RN/patient ratio 1.9–2.49 | | | | 12.40 ± 9.11
| Race | 51 | | RN/patient ratio 2.5–6.5 | | | | 10.51 ± 6.82
| Sex | 42 | | RN/patient ratio 3.5–4.41 | | | | 9.01 ± 6.26
| | | | RN/patient ratio 4.57–5.5 | | | | 9.42 ± 10.16
| | | | RN/patient ratio 5.67–7.67 | | | | 5.43 ± 8.89
| | | | | | | | Relative risk
| | | | Increase by 1 unit in nurse staffing levels | | | | 0.92 | 0.88 | 0.96
| | | | Reference (RN/patient=1) | | | | 1.00
| | | | | | | | Decubitus ulcers % ± SD
| | | | RN/patient ratio 0.15–1.29 | | | | 2.21 ± 1.78
| | | | RN/patient ratio 1.3–1.89 | | | | 2.57 ± 1.62
| | | | RN/patient ratio 1.9–2.49 | | | | 2.14 ± 1.45
| | | | RN/patient ratio 2.5–6.5 | | | | 1.90 ± 1.70
| | | | RN/patient ratio 3.5–4.41 | | | | 1.70 ± 1.39
| | | | RN/patient ratio 4.57–5.5 | | | | 1.44 ± 1.48
| | | | RN/patient ratio 5.67–7.67 | | | | 2.24 ± 4.21
| | | | | | | | Pulmonary failure % ± SD
| | | | RN/patient ratio 0.15–1.29 | | | | 0.26 ± 0.65
| | | | RN/patient ratio 1.3–1.89 | | | | 0.33 ± 0.37
| | | | RN/patient ratio 1.9–2.49 | | | | 0.32 ± 0.37
| | | | RN/patient ratio 2.5–6.5 | | | | 0.19 ± 0.42
| | | | RN/patient ratio 3.5–4.41 | | | | 0.15 ± 0.36
| | | | RN/patient ratio 4.57–5.5 | | | | 0.34 ± 0.79
| | | | RN/patient ratio 5.67–7.67 | | | | 0.00
| | | | | | | | Relative risk
| | | | Increase by 1 unit in nurse staffing levels | | | | 0.94 | 0.77 | 1.15
| | | | Reference (RN/patient = 1) | | | | 1.00 | 1.00 | 1.00
| | | | | | | | Thrombosis % ± SD
| | | | RN/patient ratio 0.15–1.29 | | | | 0.52 ± 0.71
| | | | RN/patient ratio 1.3–1.89 | | | | 0.75 ± 0.63
| | | | RN/patient ratio 1.9–2.49 | | | | 0.68 ± 0.65
| | | | RN/patient ratio 2.5–6.5 | | | | 0.44 ± 0.78
| | | | RN/patient ratio 3.5–4.41 | | | | 0.38 ± 1.06
| | | | RN/patient ratio 4.57–5.5 | | | | 0.52 ± 1.28
| | | | RN/patient ratio 5.67–7.67 | | | | 0.06 ± 0.13
| | | | Increase by 1 unit in nurse staffing levels | | | | 0.84 | 0.75 | 0.93
| | | | Reference (RN/patient = 1) | | | | 1.00 | 1.00 | 1.00
Kovner^35^ | Hospitals | 5,708 | | | | | | Urinary tract infection relative risk
The National Inpatient Sample (NIS) | Unit | Surgical | | Increase by 1 patient/LPN | | | | 1.01
Post operative discharges with UTI, pneumonia, pulmonary congestion, lung edema, or respiratory failure, and DVT in any secondary diagnosis. | Patient | Surgical | | | | | | Pneumonia, relative risk
American Hospital Association Annual Survey of Hospitals, the part of the Health Care Utilization Project | | | | Increase by 1 patient/LPN | | | | 0.99
| | | | | | | | Pulmonary failure, relative risk
| | | | Increase by 1 patient/LPN | | | | 1
| | | | | | | | Thrombosis, relative risk
| | | | Increase by 1 patient/LPN | | | | 0.96
Marcin^3^ | Hospitals | 1 | | | | | | Extubation relative risk
ICU Evaluation Database (controls), incidence reports (cases) | Size | 220 | | 1:2 nurse/patient ratio | | | | 4.24 | 1.00 | 19.10
Extubation where the endotracheal tube was displaced or removed from the trachea by either the patient (self-extubation) or unplanned by medical personnel (e.g., when positioning a patient for a radiograph or procedure). | Unit | ICU | | 1:1 nurse/patient ratio | | | | 1.00 | 1.00 | 1.00
Archived nursing assignments, self-reported years in ICU; nurse-to-patient ratio at the time of the unplanned extubation or matching time for the control patients. Standard ratio 1:1 or 1:2 | Patients | Combined
| Age | 3 years
Mark^89^ | Hospitals | 357 | | | RN/patient | Patients/LPN | | Urinary tract infection relative risk
The Healthcare Cost and Utilization Project (HCUP) National Inpatient Sample (NIS) | Unit | Combined | | Year 1993 | 3.36 | 1.56 | | 1.14 | 1.08 | 1.20
Risk-adjusted observed/ expected urinary tract infections, risk-adjusted observed/expected pneumonias, risk-adjusted observed/expected decubitus ulcers | Patients | Combined | | Year 1994 | 3.5 | 1.69 | | 1.11 | 1.05 | 1.17
American Hospital Association Annual Survey, Online Survey Certification and Reporting System [OSCAR] | | | | Year 1992 | 3.2 | 1.52 | | 1.17 | 1.11 | 1.23
RN FTEs/1,000 inpatient days | | | | Year 1992 | 3.14 | 1.45 | | 1.17 | .12 | 1.22
| | | | Year 1990 | 3.02 | 1.47 | | 1.18 | 1.13 | 1.23
| | | | 75th quartile of RN FTE/1,000 patient-days | 4.02 | | | 0.93 | 0.90 | 0.95
| | | | 50th quartile of RN FTE/1,000 patient-days | 3.34 | | | 0.94 | 0.91 | 0.96
| | | | 25th quartile of RN FTE/1,000 patient-days | 2.66 | | | 0.95 | 0.92 | 0.97
| | | | Year 1995 | 3.6 | 1.69 | | 0.98 | 0.93 | 1.03
| | | | Increase by 1 RN FTE/patient day | 2 | | | 1.05 | .92 | 1.21
| | | | Reference 1 RN FTE/patient day | 1 | | | 1.00
| | | | | | | | Pneumonia relative risk
| | | | Year 1993 | 3.36 | 1.56 | | 0.84 | 0.79 | 0.89
| | | | Year 1994 | 3.5 | 1.69 | | 0.90 | 0.85 | 0.95
| | | | Year 1992 | 3.2 | 1.52 | | 0.72 | 0.67 | 0.77
| | | | Year 1992 | 3.14 | 1.45 | | 0.65 | 0.60 | 0.70
| | | | Year 1990 | 3.02 | 1.47 | | 0.61 | 0.56 | 0.66
| | | | 75th quartile of RN FTE/1,000patient-days | 4.02 | | | 0.98 | 0.95 | 1.01
| | | | 50th quartile of RN FTE/1,000patient-days | 3.34 | | | 0.96 | 0.93 | 0.99
| | | | 25th quartile of RN FTE/1,000patient-days | 2.66 | | | 0.94 | 0.91 | 0.97
| | | | Year 1995 | 3.6 | 1.69 | | 0.97 | 0.91 | 1.03
| | | | Increase by 1 RN FTE/patient day | 2 | | | 1.03 | 0.92 | 1.16
| | | | Reference 1 RN FTE/patient day | 1 | | | Reference 1
| | | | | | | | Decubitus ulcers relative risk
| | | | Year 1993 | 3.36 | 1.56 | | 0.62 | 0.57 | 0.67
| | | | Year 1994 | 3.5 | 1.69 | | 0.69 | 0.63 | 0.75
| | | | Year 1992 | 3.2 | 1.52 | | 0.58 | 0.53 | 0.63
| | | | Year 1992 | 3.14 | 1.45 | | 0.51 | 0.46 | 0.56
| | | | Year 1990 | 3.02 | 1.47 | | 0.48 | 0.44 | 0.52
| | | | 75th quartile of RN FTE/1,000patient-days | 4.02 | | | 0.96 | 0.93 | 0.99
| | | | 50th quartile of RN FTE/1,000patient-days | 3.34 | | | 0.96 | 0.93 | 0.98
| | | | 25th quartile of RN FTE/1,000patient-days | 2.66 | | | 0.95 | 0.92 | 0.98
| | | | Year 1995 | 3.6 | 1.69 | | 0.74 | 0.69 | 0.79
| | | | Increase by 1 RN FTE/patient day | 2 | | | 1.10 | 0.99 | 1.22
| | | | Reference 1 RN FTE/patient day | 1 | | | 1.00 | 1.00 | 1.00
Potter^40^ | Hospitals | 1 | | | Patients/UAP | | | Falls/100 patient days
Medical records (number of falls on a unit/number of patient days * 1,000 | Size | 32 | | Means in time period 2–4/2000 | 1.1501 | | | 0.30
Administrative hospital data | Unit | ICU | | Means in time period 5–7/2000 | 1.1078 | | | 0.29
Proportion of UAP hours of direct patient care | Patients | Medical | | Means in time period 8–10/2000 | 1.134 | | | 0.30
| | | | Means in time period 11–1/2001 | 1.1532 | | | 0.23
Pronovost^72^ | Unit | ICU | | | | | | Pulmonary failure %
The Uniform Health Discharge Data Set | Patients | Surgical | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 24.00
Acute lung edema, pulmonary insufficiency after surgery, respiratory failure not otherwise specified, reinsertion of endotracheal tube, cardio respiratory arrest | Age | 68 | | More nurses | RNs/patient 1:1 or 1:2 | | | 9.00
Medical complications: acute renal failure, septicemia, acute myocardial infarction, cardiac arrest | Race | 89 | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 24.00
Surgical complications: surgical complications after a procedure, surgical E codes, reoperation for bleeding, bloodstream infection, hemorrhage or hematoma complicating surgery. | Sex | 66 | | More nurses | RNs/patient 1:1 or 1:2 | | | 9.00
Survey to the ICU directors; | Severity | 11 | | | | | | Pulmonary failure relative risk
An average ICU nurse-to-patient ratio during the day and evening | Hospitals | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 2.60 | 2.10 | 3.20
| 7 | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| 31 | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 4.50 | 2.90 | 6.90
| 7 | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| 31 | | | | | | | Extubation %
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 21
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 13
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 21
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 13
| | | | | | | | Extubation relative risk
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 1.50 | 1.30 | 1.80
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 1.60 | 1.10 | 2.50
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| | | | | | | | CPR %
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 2
| | | | More nurses | RN/patient 1:1 or 1:2 | | | 1
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 2
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1
| | | | | | | | CPR relative risk
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 1.40 | 0.60 | 3.00
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 1.70 | 0.70 | 4.70
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| | | | | | | | Surgical complications %
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 47
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 34
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 47
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 34
| | | | | | | | Relative risk
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 1.40 | 1.20 | 1.50
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 1.70 | 1.30 | 2.40
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| | | | | | | | Medical complications %
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 43
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 28
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 43
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 28
| | | | | | | | Relative risk
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 1.50 | 1.40 | 1.70
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 2.10 | 1.50 | 2.90
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| | | | | | | | Sepsis %
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 4
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 3
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 4
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 3
| | | | | | | | Relative risk
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 1.40 | 0.80 | 2.10
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 1.90 | 0.90 | 3.90
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| | | | | | | | Bleeding %
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 2
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 3
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 2
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 3
| | | | | | | | Relative risk
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 0.80 | 0.40 | 1.60
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
| | | | Fewer nurses | RNs/patient 1:3 or 1:4 | | | 1.20 | 0.40 | 3.50
| | | | More nurses | RNs/patient 1:1 or 1:2 | | | 1.00 | 1.00 | 1.00
Silber^67^ | Hospitals | 245 | | | | | | Failure to rescue relative risk
Pennsylvania Medicare claims records; the Medicare Standard Analytic Files; random sample of 50% of Medicare patients who underwent general surgical or orthopedic procedures; | Size | 217,440 | | Hospitals with lower RN/bed ratio | 1.1 | | | 1.00 | 1.00 | 1.00
Failure to rescue: 30-day death rate after complications, in-hospital complication rate: Cardiac event, CHF, Shock, DVT and PE, Stroke, TIA, Coma, Nosocomial infections, pneumonia, pulmonary failure, pressure ulcers, wound infections, sepsis, and bleeding. | Unit | Surgical | | Hospitals with higher RN/bed ratio | 1.87 | | | 0.94 | 0.92 | 0.96
The American Hospital Association Annual Surveys for 1991-1993, and the Pennsylvania Health Care Cost Containment Council Data Base for years 1991-1994; | Patients | Surgical | | | | | | %
RN/bed ratio at hospital level | | | | Indirect patients | 1.38 RNs/patient | | | 9.32
| | | | Directed patients | 1.4 RNs/patient | | | 8.18
| | | | | | | | Complications relative risk
| | | | Hospitals with lower RN/bed ratio | 1.1 | | | 1.00 | 1.00 | 1.00
| | | | Hospitals with higher RN/bed ratio | 1.87 | | | 1.04 | 1.03 | 1.04
| | | | | | | | %
| | | | Indirect patients | 1.38 RNs/patient | | | 47.87
| | | | Directed patients | 1.4 RNs/patient | | | 41.15
Simmonds^82^ | Hospitals | 1 | | | Patient/RN | | | Nosocomial infection, %
Active microbiological surveillance of all chronic patients admitted for >30 days of hemodialysis; volunteering patient participation in other units, % of patients with positive colonization of vancomycin-resistant enterococci 48 hours after admission to the hospital and after surgery; | Unit | Spec | | Means at the beginning of the study | 1.64 | | | 1.61
Administrative reports of Patient Care Manager and Nursing Workload Specialist; Integrated Nursing System database, | Patients | Medical | | Means after 1 year | 1.62 | | | 3.29
FTE RNs/number of beds | Age | 68.75 | | Means after 2 year | 1.60 | | | 4.97
| Sex | 55.8 | | Means after 3 year | 1.58 | | | 6.65
| | | | RN/patient ratio at the beginning of the study | 1.64 | | | 1.92
| | | | RN/patient ratio after 1 year | 1.62 | | | 1.75
| | | | RN/patient ratio after 2 years | 1.60 | | | 1.58
| | | | RN/patient ratio after 3 years | 1.58 | | | 1.41
Stegenga^78^ | Hospitals | 1 | | | RN/patient ratio | | | Nosocomial infection /100 patient days
Patients and laboratory records | Unit | ICU | | Pre infection night shifts | 3.16 | | | 1.3
Nosocomial viral gastrointestinal infections (NVGIs) (CDC definition). Rate = number of NVGIs/1,000 patient days. | Patients | Medical | | Post infection night shifts | 3.26 | | | 0
Administrative hospital records
Number of nurses/patient in each shift according to actual work schedule. Ratio was calculated 72 hours before and after infection event
Unruh^66^ | Hospitals | 1,477 | | | RN/patient | Patients/LPN | Patients/ UAP | UTI %, | Decubitus ulcer %
State Health Care Cost Containment Council | Unit | Combined | | State data in 1991 | 2.9 | 1.5 | 1.6 | 5.18 | 0.55
Secondary diagnosis of nosocomial UTI, hospital acquired pneumonia, decubitus ulcer, adult atelectasis, and cardiac arrest | Patients | Combined | | State data in 1992 | 2.7 | 1.7 | 1.7 | 4.48 | 0.49
| Race | 45.37 | | State data in 1993 | 2.7 | 1.8 | 1.8 | 4.44 | 0.53
| Sex | 42.43 | | State data in 1994 | 2.7 | 2.0 | 1.8 | 4.91 | 0.69
| | | | State data in 1995 | 2.6 | 2.0 | 1.8 | 4.80 | 0.67
| | | | State data in 1996 | 2.8 | 2.1 | 1.8 | 5.14 | 0.73
| | | | State data in 1997 | 2.7 | 2.4 | 1.7 | 4.70 | 0.73
| | | | Mean RN/patient levels in medium size hospitals: 2.67 | | | | 0.50 | 0.68
| | | | Reduction by 10% in LPN/patient ratio, medium size hospitals: 2.4 | | | | 0.51 | 0.72
| | | | Mean LPN/patient levels in medium size hospitals: 1.9 | | | | 0.50 | 0.68
| | | | Reduction by 10% in LPN/patient ratio, medium size hospitals: 2.1 | | | | 0.50 | 0.69
| | | | Mean RN/patient levels: 2.81 | | | | 0.51 | 0.69
| | | | Reduction by 10% in LPN/patient ratio: 2.53 | | | | 0.52 | 0.71
| | | | Mean LPN/patient levels: 1.9 | | | | 0.51 | 0.69
| | | | Reduction by 10% in LPN/patient ratio: 2.0 | | | | 0.51 | 0.69
| | | | | | | | SWI %, | Complications %
| | | | State data in 1991 | 2.9 | 1.5 | 1.6 | 0.29 | 2.58
| | | | State data in 1992 | 2.7 | 1.7 | 1.7 | 0.26 | 2.40
| | | | State data in 1993 | 2.77 | 1.8 | 1.8 | 0.24 | 2.47
| | | | State data in 1994 | 2.7 | 2.0 | 1.8 | 0.28 | 2.67
| | | | State data in 1995 | 2.6 | 2.0 | 1.8 | 0.28 | 2.49
| | | | State data in 1996 | 2.8 | 2.1 | 1.8 | 0.31 | 2.79
| | | | State data in 1997 | 2.7 | 2.4 | 1.7 | 0.30 | 2.71
| | | | Mean RN/patient levels in medium size hospitals: 2.67 | | | | 0.27 | 2.34
| | | | Reduction by 10% in LPN/patient, medium size hospitals: 2.4 | | | | 0.27 | 2.37
| | | | Mean LPN/patient levels in medium size hospitals: 1.9 | | | | 0.27 | 2.34
| | | | Reduction by 10% in LPN/patient, medium size hospitals: 2.1 | | | | 0.27 | 2.35
| | | | Mean RN/patient levels: 2.81 | | | | 0.30 | 2.69
| | | | Reduction by 10% in RPN/patient ratio: 2.53 | | | | 0.31 | 2.70
| | | | Mean LPN/patient levels: 1.9 | | | | 0.30 | 2.69
| | | | Reduction by 10% in LPN/patient ratio 2.0 | | | | 0.32 | 2.70
| | | | | | | | Pnm | Falls | PulmF | CPR
| | | | State data in 1991 | 2.9 | 1.5 | 1.6 | 0.98 | 0.04 | 0.52 | 0.54
| | | | State data in 1992 | 2.7 | 1.7 | 1.7 | 0.91 | 0.04 | 0.46 | 0.48
| | | | State data in 1993 | 2.7 | 1.8 | 1.8 | 0.96 | 0.16 | 0.47 | 0.50
| | | | State data in 1994 | 2.7 | 2.0 | 1.8 | 1.54 | 0.91 | 0.63 | 0.61
| | | | State data in 1995 | 2.6 | 2.0 | 1.8 | 1.55 | 0.86 | 0.68 | 0.64
| | | | State data in 1996 | 2.8 | 2.1 | 1.8 | 1.63 | 0.74 | 0.70 | 0.63
| | | | State data in 1997 | 2.7 | 2.4 | 1.7 | 1.64 | 0.72 | 0.69 | 0.60
| | | | | | | | UTI | Pnm | Dec Ul %
| | | | Increase by 1 unit in RN/patient ratio | | | | -0.15 | 0.04 | -0.07
| | | | Increase by 1 unit in RN/patient ratio in small hospitals | | | | 0.31 | 0.30 | 0.06
| | | | Increase by 1 unit in RN/patient ratio in medium hospitals | | | | -0.34 | -0.30 | -0.15
| | | | Increase by 1 unit in RN/patient ratio in large hospitals | | | | -0.07 | 0.00 | -0.04
| | | | Increase by 1 unit in LPN/patient ratio | | | | -0.10 | 0.21 | 0.04
| | | | Increase by 1 unit in LPN/patient ratio in small hospitals | | | | 0.24 | 0.58 | 0.13
| | | | Increase by 1 unit in LPN/patient ratio in medium hospitals | | | | -0.37 | -0.04 | -0.12
| | | | Increase by 1 unit in LPN/patient ratio in large hospitals | | | | 0.77 | 0.35 | -0.12
| | | | Increase by 1 unit in UAP/patient ratio | | | | -0.09 | 0.12 | 0.06
| | | | Increase by 1 unit in UAP/patient ratio in small hospitals | | | | 0.00 | 0.48 | 0.05
| | | | Increase by 1 unit in UAP/patient ratio in medium hospitals | | | | -0.14 | 0.14 | 0.17
| | | | Increase by 1 unit in UAP/patient ratio in large hospitals | | | | 0.05 | 0.01 | -0.04
| | | | | | | | Falls | PulmF | Pressure ulcer
| | | | Increase by 1 unit in RN/patient ratio | | | | -0.01 | -0.02 | -0.01
| | | | Increase by 1 unit in RN/patient ratio in small hospitals | | | | 0.05 | 0.12 | 0.09
| | | | Increase by 1 unit in RN/patient ratio in medium hospitals | | | | -0.02 | -0.05 | -0.04
| | | | Increase by 1 unit in RN/patient ratio in large hospitals | | | | 0.00 | -0.12 | -0.01
| | | | Increase by 1 unit in LPN/patient ratio | | | | -0.09 | 0.09 | 0.03
| | | | Increase by 1 unit in LPN/patient ratio in small hospitals | | | | -0.12 | -0.03 | 0.10
| | | | Increase by 1 unit in LPN/patient ratio in medium hospitals | | | | 0.01 | 0.02 | -0.07
| | | | Increase by 1 unit in LPN/patient ratio in large hospitals | | | | 0.01 | -0.46 | 0.16
| | | | Increase by 1 unit in UAP/patient ratio | | | | -0.03 | 0.03 | 0.00
| | | | Increase by 1 unit in UAP/patient ratio in small hospitals | | | | -0.08 | 0.19 | 0.12
| | | | Increase by 1 unit in UAP/patient ratio in medium hospitals | | | | 0.05 | 0.05 | -0.03
| | | | Increase by 1 unit in UAP/patient ratio in large hospitals | | | | -0.02 | -0.15 | -0.01
| | | | | | | | SWI | CPR | Complication
| | | | Increase by 1 unit in RN/patient ratio | | | | -0.02 | 0.00 | -0.03
| | | | Increase by 1 unit in RN/patient ratio in small hospitals | | | | -0.09 | -0.04 | -0.05
| | | | Increase by 1 unit in RN/patient ratio in medium hospitals | | | | 0.00 | 0.00 | -0.12
| | | | Increase by 1 unit in RN/patient ratio in large hospitals | | | | -0.02 | -0.03 | 0.00
| | | | Increase by 1 unit in LPN/patient ratio | | | | -0.04 | 0.02 | -0.18
| | | | Increase by 1 unit in LPN/patient ratio in small hospitals | | | | -0.03 | -0.05 | -0.10
| | | | Increase by 1 unit in LPN/patient ratio in medium hospitals | | | | 0.00 | 0.06 | -0.21
| | | | Increase by 1 unit in LPN/patient ratio in large hospitals | | | | 0.01 | -0.24 | -0.52
| | | | Increase by 1 unit in UAP/patient ratio | | | | 0.02 | 0.05 | 0.18
| | | | Increase by 1 unit in UAP/patient ratio in small hospitals | | | | -0.06 | -0.24 | -0.23
| | | | Increase by 1 unit in UAP/patient ratio in medium hospitals | | | | 0.05 | 0.06 | 0.15
| | | | Increase by 1 unit in UAP/patient ratio in large hospitals | | | | 0.01 | 0.05 | 0.09
Unruh^81^ | Hospitals | 1,477 | | | | | | Relative risk
Health Care Cost Containment Council | Unit | Combined | | Reference, 3.3 licensed nurses/patient | | | | Reference
Yearly number of occurrences of adverse events per hospital: secondary diagnosis of diseases and disorders of the kidney and urinary tract, male reproductive system, or female reproductive system, decubitus ulcer, fall, atelectasis, infection or sepsis or septicemia following infusion, injection, transfusion, or vaccination, and complications of obstetrical surgical wounds. | Patients | Medical | | | | | | Urinary tract infection
The Pennsylvania Department of Health (PDH) and the American Hospital Association (AHA) | | | | 10% increase in number of licensed nurses | | | | 0.99
Number of FTE RNs + LPNs on hospital payroll as of June 30th yearly. No. FTE RNs + LPNs + NA on hospital payroll as of June 30th yearly. | | | | | | | | Pneumonia
| | | | 10% increase in number of licensed nurses | | | | 1.01
| | | | | | | | Decubitus ulcer
| | | | 10% increase in number of licensed nurses | | | | 0.98
| | | | | | | | Falls
| | | | 10% increase in number of licensed nurses | | | | 0.97
| | | | | | | | Pulmonary failure
| | | | 10% increase in number of licensed nurses | | | | 0.985

BSI = Bloodstream Infection; BSN = Bachelor of Science in Nursing; CPR = Cardiopulmonary Resuscitation; Dec Ul = Decubitus Ulcer; FTE = Full Time Equivalent; ICU = Intensive Care Unit; LPN = Licensed Practical Nurse; NA = Nursing Assistants; NS = Not Significant; Pnm = Pneumonia; PulmF = Pulmonary Failure; RN = Registered Nurse; SD = Standard Deviation; SICU = Surgical Intensive Care Unit; SWI = Surgical Wound Infection; UAP = Unlicensed Assistive Personnel; UTI = Urinary Tract Infection

Table G6 Patient outcomes corresponding to an increase by one patient/RN/shift (effects reported by authors and calculated from published results, more studies contributed to pooled analysis)

Author | Outcome | Measure | Effect | Standard Error | Significance
Pronovost^72^ | Pulmonary failure | Relative risk | 0.61 | 0.14 | 0.05
Pronovost^72^ | Unplanned extubation | Relative risk | 0.22 | 0.02 | 0.01
Pronovost^72^ | CPR | Relative risk | 0.22 | 0.05 | 0.05
Pronovost^72^ | Complications | Relative risk | 0.22 | 0.05 | 0.05
Pronovost^72^ | Medical complications | Relative risk | 0.29 | 0.08 | 0.08
Pronovost^72^ | Surgical complications | Relative risk | -0.12 | 0.06 | 0.21
Pronovost^72^ | Sepsis | Relative risk | 0.24 | 0.08 | 0.09
Pronovost^72^ | Bleeding | Relative risk | -0.01 | 0.10 | 0.93
Dang^75^ | Pulmonary failure | Relative risk | 0.43 | 0.24 | 0.13
Dang^75^ | Unplanned extubation | Relative risk | 0.41 | 0.11 | 0.01
Dang^75^ | CPR | Relative risk | 0.18 | 0.12 | 0.19
Dang^75^ | Complications | Relative risk | 0.06 | 0.14 | 0.69
Dang^75^ | Medical Complications | Relative risk | 0.18 | 0.12 | 0.19
Dang^75^ | Sepsis | Relative risk | 0.06 | 0.14 | 0.69
Amaravadi^64^ | CPR | Rate | 0.40
Amaravadi^64^ | Hospital acquired pneumonia | Rate | 4.00
Amaravadi^64^ | Sepsis | Rate | 2.20
Amaravadi^64^ | Pulmonary failure | Rate | 1.50
Amaravadi^64^ | Unplanned extubation | Rate | 6.50
Amaravadi^64^ | Hospital acquired pneumonia | Relative risk | 0.44
Amaravadi^64^ | Pulmonary failure | Relative risk | 0.09
Amaravadi^64^ | Unplanned extubation | Relative risk | 0.46
Amaravadi^64^ | CPR | Relative risk | 0.09
Amaravadi^64^ | Medical complications | Relative risk | -0.05
Amaravadi^64^ | Surgical complications | Relative risk | -0.05
Amaravadi^64^ | Sepsis | Relative risk | 0.65
Dimick^70^ | CPR | Rate | 0.10
Dimick^70^ | Hospital acquired pneumonia | Rate | 0.70
Dimick^70^ | Sepsis | Rate | 1.35
Dimick^70^ | Pulmonary failure | Rate | 2.10
Dimick^70^ | Unplanned extubation | Rate | 4.45
Dimick^70^ | Hospital acquired pneumonia | Relative risk | 0.17
Dimick^70^ | Pulmonary failure | Relative risk | 0.64
Dimick^70^ | Unplanned extubation | Relative risk | 0.87
Aiken^39^ | Failure to rescue | Rate | 0.41 | 0.16 | 0.03
Aiken^39^ | Failure to rescue | Relative risk | 0.05
Aiken^39^ | Failure to rescue | Relative risk | 0.08 | 0.00 | 0.00
Marcin^3^ | Unplanned extubation | Relative risk | 1.44
Elting^92^ | Failure to rescue | Relative risk | -0.18
Flood^53^ | Urinary tract infection | Rate | 0.02
Flood^53^ | Nosocomial infection | Rate | 0.03
Fridkin^1^ | Nosocomial infection | Rate | 41.06
Fridkin^1^ | Sepsis | Rate | 10.64
Fridkin^1^ | Sepsis | Relative risk | 3.99 | 0.58 | 0.02
Mark^89^ | Urinary tract infection | Relative risk | 0.00 | 0.01 | 0.69
Mark^89^ | Hospital acquired pneumonia | Relative risk | 0.02 | 0.02 | 0.36
Donaldson^9^ | Falls | Rate | 0.43 | 0.21 | 0.17
Donaldson^9^ | Pressure ulcers | Rate | -0.82 | 0.89 | 0.46
Bolton^26^ | Falls | Rate | 5.35
Bolton^26^ | Pressure ulcers | Rate | -1.47
Silber^67^ | Failure to rescue | Rate | 36.71
Silber^67^ | Failure to rescue | Relative risk | 0.06
Silber^67^ | Complications | Relative risk | -0.03
Hope^86^ | Urinary tract infection | Rate | -0.71 | 0.43 | 0.12
Hope^86^ | Nosocomial infection | Rate | -0.03 | 0.03 | 0.31
Hope^86^ | Sepsis | Rate | -0.10 | 0.10 | 0.34
Hope^86^ | Urinary tract infection | Relative risk | -0.01 | 0.00 | 0.18
Hope^86^ | Hospital acquired pneumonia | Relative risk | 0.07 | 0.02 | 0.00
Hope^86^ | Nosocomial infection | Relative risk | 0.02 | 0.02 | 0.17
Hope^86^ | Surgical wound infection | Relative risk | 0.02 | 0.04 | 0.67
Hope^86^ | Sepsis | Relative risk | 0.02 | 0.03 | 0.42
Houser^49^ | Failure to rescue | Rate | 0.23 | 0.30 | 0.48
Houser^49^ | Pulmonary failure | Rate | 0.01 | 0.01 | 0.65
Houser^49^ | Deep venous thrombosis | Rate | 0.01 | 0.03 | 0.69
Houser^49^ | Failure to rescue | Relative risk | 0.03
Houser^49^ | Pulmonary failure | Relative risk | 0.02
Houser^49^ | Deep venous thrombosis | Relative risk | 0.06
Halm^51^ | Failure to rescue | Relative risk | 0.00 | 0.00 | 0.00
Simmonds^82^ | Nosocomial infection | Rate | -13.35 | 10.40 | 0.25
Unruh^66^ | CPR | Rate | -0.32 | 0.03 | <.0001
Unruh^66^ | Falls | Rate | -0.24 | 0.12 | 0.08
Unruh^66^ | Urinary tract infection | Rate | -2.13 | 0.58 | 0.00
Unruh^66^ | Hospital acquired pneumonia | Rate | -0.71 | 0.13 | 0.00
Unruh^66^ | Surgical wound infection | Rate | -0.17 | 0.02 | <.0001
Unruh^66^ | Pulmonary failure | Rate | -0.33 | 0.04 | <.0001

Table G7 Patient outcomes corresponding to an increase by one patient/LPN (effects reported by authors and calculated from published results, more studies contributed to pooled analysis)

Author | Outcome | Measure | Effect | Standard Error | Significance
Needleman^28^ | Failure to rescue | Rate | -0.07 | 0.07 | 0.36
Needleman^28^ | Urinary tract infection | Rate | -0.07 | 0.04 | 0.10
Needleman^28^ | Hospital acquired pneumonia | Rate | -0.06 | 0.03 | 0.03
Needleman^28^ | Sepsis | Rate | 0.00 | 0.01 | 0.86
Needleman^28^ | Surgical wound infection | Rate | 0.01 | 0.01 | 0.42
Needleman^28^ | Pressure ulcers | Rate | -0.04 | 0.04 | 0.34
Needleman^28^ | Upper gastrointestinal bleeding | Rate | -0.01 | 0.01 | 0.33
Needleman^28^ | Shock | Rate | -0.01 | 0.01 | 0.14
Needleman^28^ | Pulmonary failure | Rate | -0.05 | 0.04 | 0.21
Needleman^28^ | Deep venous thrombosis | Rate | 0.00 | 0.00 | 0.27
Kovner^35^ | Urinary tract infection | Rate | -0.02 | 0.02 | 0.31
Kovner^35^ | Hospital acquired pneumonia | Rate | 0.02 | 0.01 | 0.32
Kovner^35^ | Pulmonary failure | Rate | 0.00 | 0.01 | 0.93
Kovner^35^ | Deep venous thrombosis | Rate | -0.04 | 0.02 | 0.12
Langemo^41^ | Pressure ulcers | Rate | 0.49 | 0.33 | 0.37
Mark^89^ | Urinary tract infection | Relative risk | -0.04 | 0.01 | 0.05
Mark^89^ | Hospital acquired pneumonia | Relative risk | 0.12 | 0.02 | 0.00
Bolton^26^ | Falls | Rate | 1.60
Bolton^26^ | Pressure ulcers | Rate | -0.44
Unruh^66^ | CPR | Rate | 0.03 | 0.00 | <.0001
Unruh^66^ | Falls | Rate | 0.03 | 0.01 | 0.00
Unruh^66^ | Urinary tract infection | Rate | 0.14 | 0.06 | 0.03
Unruh^66^ | Hospital acquired pneumonia | Rate | 0.06 | 0.01 | <.0001
Unruh^66^ | Surgical wound infection | Rate | 0.01 | 0.00 | <.0001
Unruh^66^ | Pulmonary failure | Rate | 0.04 | 0.01 | <.0001
Zidek^85^ | Falls | Rate | 0.02 | 0.08 | 0.77
Zidek^85^ | Pressure ulcers | Rate | -0.01 | 0.04 | 0.82
Tallier^83^ | Urinary tract infection | Rate | 0.81 | 0.32 | 0.07
Tallier^83^ | Pressure ulcers | Rate | -0.38 | 0.33 | 0.31

Table G8 Patient outcomes corresponding to an increase by one patient/UAP (effects reported by authors and calculated from published results, more studies contributed to pooled analysis)

Author | Outcome | Measure | Effect | Standard error | Significance
Needleman^28^ | Failure to rescue | Rate | 0.14 | 0.41 | 0.73
Needleman^28^ | Urinary tract infection | Rate | -0.19 | 0.22 | 0.39
Needleman^28^ | Hospital acquired pneumonia | Rate | -0.15 | 0.15 | 0.33
Needleman^28^ | Sepsis | Rate | 0.04 | 0.06 | 0.48
Needleman^28^ | Surgical wound infection | Rate | 0.02 | 0.03 | 0.57
Needleman^28^ | Pressure ulcers | Rate | 0.06 | 0.25 | 0.81
Needleman^28^ | Gastrointestinal bleeding | Rate | -0.04 | 0.05 | 0.36
Needleman^28^ | Shock | Rate | -0.02 | 0.04 | 0.60
Needleman^28^ | Pulmonary failure | Rate | 0.01 | 0.19 | 0.97
Needleman^28^ | Deep venous thrombosis | Rate | -0.03 | 0.02 | 0.11
Potter^40^ | Falls | Rate | 0.28 | 0.50 | 0.64
Sovie^71^ | Falls | Rate | -0.08 | 0.34 | 0.82
Sovie^71^ | Urinary tract infection | Rate | -0.17 | 0.13 | 0.26
Sovie^71^ | Pressure ulcers | Rate | -0.25 | 0.26 | 0.41
Ritter-Teitel^69^ | Falls | Rate | -0.07 | 0.04 | 0.18
Ritter-Teitel^69^ | Urinary tract infection | Rate | -0.41 | 0.02 | <.0001
Ritter-Teitel^69^ | Pressure ulcers | Rate | 0.25 | 0.13 | 0.12
Unruh^66^ | CPR | Rate | 0.03 | 0.00 | <.0001
Unruh^66^ | Falls | Rate | 0.03 | 0.01 | 0.02
Unruh^66^ | Urinary tract infection | Rate | 0.28 | 0.02 | <.0001
Unruh^66^ | Hospital acquired pneumonia | Rate | 0.07 | 0.01 | 0.00
Unruh^66^ | Surgical wound infection | Rate | 0.02 | 0.00 | <.0001
Unruh^66^ | Pulmonary failure | Rate | 0.03 | 0.00 | <.0001
Zidek^85^ | Falls | Rate | 0.00 | 0.01 | 0.97
Zidek^85^ | Pressure ulcers | Rate | 0.00 | 0.01 | 0.44
Stratton^91^ | Nosocomial infection | Rate | 0.04 | 0.11 | 0.70
Tallier^83^ | Urinary tract infection | Rate | 0.21 | 3.58 | 0.96
Tallier^83^ | Pressure ulcers | Rate | -1.23 | 2.57 | 0.66

Table G9 The association between nurse staffing and length of stay

Author, Definition of Length of Stay, Definition of Nurse Staffing | Number of Hospitals, Units, Patient Age, % of Whites, % of Males, % of Emergency Admissions | | | Nurse Staffing Categories | | | | Length of Stay
Amaravadi^64^ | Hospitals | 1 | | Night time nurse to patient ratio <1:2 | | | | 15
The Uniform Health Discharge Data Set; hospital length of stay, survey of ICU directors; average nurse-to-patient ratio of ≥1:2 versus <1:2 both during the day and at night | Unit | ICU | | Night time nurse to patient ratio >1:2 | | | | 9
| Patients | Surgical | | | | | | Relative increase in length of stay
| | | | Night time nurse to patient ratio <1:2 | | | | 1.39 | 1.19 | 1.61
| | | | Night time nurse to patient ratio >1:2 | | | | 1 | 1 | 1
ANA^65^ | | | | Increase by 1 hour in total nursing hours in | | | | Relative increase in length of stay
Uniform Hospital Discharge Data Set; an average length of stay in hospital, American Hospital Association survey, hospitals cost reports; total nursing hours per Nursing Intensity Weight, % RN Hours/total nursing hours | | | | Massachusetts, 1992 | | | | 0.903
| | | | Massachusetts, 1994 | | | | 1
| | | | New York, 1992 | | | | 0.9354
| | | | New York, 1994 | | | | 0.956
| | | | California, 1992 | | | | 0.9518
| | | | California, 1994 | | | | 0.946
| | | | Increase by 1% in RN in
| | | | Massachusetts, 1992 | | | | 0.9973
| | | | Massachusetts, 1994 | | | | 0.9981
| | | | New York, 1992 | | | | 0.9981
| | | | New York, 1994 | | | | 0.9989
| | | | California, 1992 | | | | 0.9993
| | | | California, 1994 | | | | 0.9984
Barkell^77^ | Hospitals | 1 | | | | | | Length of stay, days ± SD
Medical records; length of stay in the unit: the number of midnights a patient was on the unit as an inpatient, hospital administrative database, proportion of RN/total nursing staff | Unit | Surgical | | Team nursing model with patient care associate assisting RNs in delivery of patient care (66% of RN) | | | | 6.8 ± 3.1
| Patients | Surgical | | Total patient care model, 79% RN | | | | 7.1 ± 2.9
Beckman^37^ | Hospital | 1 | | | | | | Length of stay, days ± SD
Medical records, length of stay in unit, unit administrators and nurses survey, hospital administrative data; scheduled RNs/patients in unit, % of RN/total nursing personnel | Unit | ICU | | RN + Case manager | | | | 29 ± 32.6
| | | | RN + MSW | | | | 35 ± 42
| | | | RN + Clinical nurse specialist | | | | 11 ± 2.1
| | | | RN + mixed support (rehabilitation nurse) | | | | 17 ± 8.5
| | | | Advanced practice nurse + clinical nurse specialist | | | | 11 ± 6
| | | | Advanced practice nurse + social worker | | | | 7 ± 0
| | | | Advanced practice nurse + mixed support | | | | 14 ± 0
| | | | RN staff with no support | | | | 9 ± 7.4
| Unit | | | Patient/RN | % RN
| Surgical | | | 0.86 | 60 | | | 13.25 ± 5.73
| Surgical | | | 0.85 | 66 | | | 7.92 ± 6.64
| Specialty | | | 0.63 | 69 | | | 28.53 ± 33.72
| Medical | | | 1.04 | 61.5 | | | 10.50 ± 5.87
| Medical | | | 1.16 | 58.5 | | | 9.77 ± 8.17
| Surgical | | | 0.91 | 69 | | | 12.29 ± 9.42
| Surgical | | | 1.39 | 57 | | | 4.23 ± 3.00
Cho^30^ | Unit | Combined | | RN hours | % RN | % contract hours | | Length of stay, days ± SD
The State Inpatient Databases in hospital length of stay, Hospital Financial Data; the total productive hours worked by RN per patient day; contracted hours = productive nursing hours (direct care to patient) worked by nursing personnel contracted on a temporary basis. Contract hours * % of RN; RN hours divided by all hours | Patients | Combined | | 7.2 | 76.5 | 3.60 | | 8.6 ± 1.5
| | | | 6 | 68.1 | 3.30 | | 7.2 ± 1.3
| | | | 6.6 | 72.4 | 3.20 | | 7.6 ± 9
| | | | 6.2 | 72.7 | 5.00 | | 7.8 ± 1.5
Cimiotti^87^ | Hospitals | 1 | | Nurse hours | RN hours | % RN | | Length of stay, days ± SD
Patients discharges and medical records review by study's nurse epidemiologist; the length of stay as the 1 day of admission and all succeeding days except the day of discharge, nurse staffing office and sign-in/out sheet from each supplemental nursing agency; total nursing hours worked by direct care providers adjusted for Nursing Intensity Weights categorized as below and above median; RN hours/patient day adjusted for Nursing Intensity Weights categorized as below and above median; % of RN hours among total nursing hours adjusted for Nursing Intensity Weights; hours/patient day worked by float pool and agency RN not regularly assigned to the NICU | Unit | Neonatal | | 10.68 | 10.68 | 100 | | 17.23 ± 24.39
| Patients | Medical | | 10.97 | 10.56 | 96 | | 19.6 ± 28.28
| | | | 8.705 | | | | 10.01 ± 13.45
| | | | 12.95 | | | | 21.3 ± 29.03
| | | | | 8.5 | | | 15.75 ± 24.47
| | | | | 12.74 | | | 18.05 ± 24.69
| | | | % of contract nurses
| | | | 0.19 | | | | 17.23 ± 24.39
| | | | 24.07 | | | | 19.6 ± 28.28
| | | | 14.19 | | | | 12.52 ± 16.09
| | | | 12.13 | | | | 17.1 ± 30.75
Dimick^70^ | Hospitals | 32 | | | | | | Relative increase in length of stay
The Uniform Health Discharge Data Set; In-hospital length of stay; survey of ICU directors; average nurse-to-patient ratio in the ICU during the day and evening and at night. | Unit | ICU | | More nurses: | RNs/patient | 1:1–1:2 | | 1 | 1 | 1
| Patients | Surgical | | Fewer nurses: | RNs/patient | 1:1-3-1:4 | | 1.09 | 0.89 | 1.12
Flood^53^ | Hospitals | 1 | | Nurse hours | % RN | | | Length of stay, days ± SD
Patient medical records; length of stay in unit, staffing workload index; RN FTE/patient per shift per unit | Unit | Combined | | 6.9 | 60.45 | | | 8.56 ± 7.81
| Patients | Medical | | 6.7 | 42.32 | | | 9.49 ± 8.74
Gandjour^24^ | Hospitals | 77 | | Nurse hours | Patients/nurse | | | Length of stay, days
Health Care Financing Administration database; average hospital length of stay; Joint Annual Report of Hospital Data; number of administrative full time employees RN (FTE)/1,000 patient days | Unit | Combined | | 19 | 2.86 | | | 5.49
| Patients | Combined | | 19 | 2.85 | | | 5.54
| | | | 8.9 | 3.22 | | | 5.43
| | | | 8.4 | 3.44 | | | 5.13
| | | | 4 | 3.2 | | | 5.29
Grillo-Peck^10^ | Hospitals | 1 | | % RN | | | | Length of stay, days
Review of risk management records and medication records 6 months before and after implementation of nursing model; length of stay in unit; hospital administrative records; decrease in % of RN in the unit within new partnership model with increase patient care technicians and service associates; RN spent more time on direct patient care | Unit | Specialized | | 80 | | | | 9.46
| Patients | Medical | | 60 | | | | 8.76
Halpine^14^ | Hospitals | 5 | | | | | | Length of stay, days
The Hospital Medical Records Institute database; in average length of stay in units; The Hospital Medical Records Institute; GRASP workload system; total nursing hours/patient day | Unit | Patients | | Hour
| Spec | Medical | | 8.64 | | | | 39.25
| Surgical | Surgical | | 8.51 | | | | 1.86
| Surgical | Surgical | | 7.57 | | | | 13.33
| Surgical | Surgical | | 6.92 | | | | 15
| Surgical | Surgical | | 6.64 | | | | 9.24
| Surgical | Surgical | | 6.56 | | | | 12.2
| Neonatal | Medical | | 6.32 | | | | 7.58
| Surgical | Surgical | | 6.14 | | | | 21.79
| Specialty | Surgical | | 6.07 | | | | 19.79
| Surgical | Surgical | | 5.87 | | | | 16.71
| Surgical | Surgical | | 5.78 | | | | 14.31
| Surgical | Surgical | | 5.78 | | | | 26.5
| Surgical | Surgical | | 5.47 | | | | 2.19
| Neonatal | Medical | | 4.67 | | | | 4.74
| ICU | Medical | | 4.66 | | | | 12.34
| Surgical | Surgical | | 4.58 | | | | 6.72
| ICU | Medical | | 4.52 | | | | 10.1
| Specialty | Medical | | 4.51 | | | | 12.49
| Specialty | Medical | | 4.41 | | | | 17.86
| Medical | Medical | | 4.38 | | | | 6.67
| Surgical | Surgical | | 9.28 | | | | 9.75
| Surgical | Surgical | | 9.19 | | | | 10.76
| Medical | Medical | | 7.51 | | | | 2.56
| Medical | Medical | | 7.32 | | | | 1.32
| Neonatal | Medical | | 6.49 | | | | 3.06
| Surgical | Surgical | | 6.33 | | | | 1.52
| Medical | Medical | | 6.32 | | | | 3.34
| Surgical | Surgical | | 6.15 | | | | 2.1
| Neonatal | Medical | | 6.01 | | | | 2.52
| Medical | Medical | | 5.78 | | | | 4.42
| Medical | Surgical | | 5.59 | | | | 2.17
| Medical | Medical | | 5.58 | | | | 4.33
| Surgical | Surgical | | 5.53 | | | | 9
| Neonatal | Medical | | 5.49 | | | | 2.26
| Neonatal | Medical | | 5.45 | | | | 2.86
| ICU | Medical | | 5.41 | | | | 9.42
| Medical | Medical | | 5.34 | | | | 2.75
| Surgical | Surgical | | 5.13 | | | | 17.11
| Specialty | Medical | | 5.1 | | | | 2.6
| Surgical | Surgical | | 5.06 | | | | 3.23
Hoover^23^ | Unit | Combined | | | | | | Length of stay, days ± SD
The Health Care Financing Agency, HealthCareReportCards.com; MEDPAR database, the Medicare Average Length of Stay (ALOS) = total number of Medicare discharge days/total number of Medicare discharges for each hospital. The AHA and HCFA databases; RN/LPN ratio = total number RN FTE/LPN FTE reported by the hospital and RN/total nursing staff | Patients | Medical | | % RN
| Hospitals | 54 | | 79.6 | | | | 5.67 ± 0.36
| | 52 | | 69.8 | | | | 5.69 ± 0.67
| | 70 | | 72.83 | | | | 6.31 ± 0.47
| | 176 | | 81.8 | | | | 5.82 ± 0.09
| | 176 | | 62.9 | | | | 6.18 ± 0.09
Houser^49^ | Unit | Combined
Nationwide Inpatient Sample of 2001 with hospital discharge records; average length of stay in the hospital in days; American Hospital Association Annual Survey for 2001; hospital reported RN FTE/RN + LPN | Patients | Medical | | | | | | LOS, days ± SD
| Hospitals | 170 | | RN/patient ratio | 0.15–1.29 | | | 4.64 ± 2.68
| | 172 | | RN/patient ratio | 1.3–1.89 | | | 4.54 ± 0.97
| | 174 | | RN/patient ratio | 1.9–2.49 | | | 4.38 ± 2.59
| | 171 | | RN/patient ratio | 2.5–6.5 | | | 3.84 ± 2.19
| | 39 | | RN/patient ratio | 3.5–4.41 | | | 4.08 ± 4
| | 14 | | RN/patient ratio | 4.57–5.5 | | | 3.47 ± 1.25
| | 8 | | RN/patient ratio | 5.67–7.67 | | | 2.76 ± 0.88
Lichtig^63^ | Unit | Surgical | | Increase by 1 hour in total nursing hours in | | | | Relative change in length of stay
The Uniform Hospital Discharge Data Set; The California Office of Statewide Health Planning and Development; the Statewide Planning and Research Cooperative System Administratively Releasable file; a relative length of stay (LOS) index was calculated as the ratio of the actual-to-expected geometric mean LOS; The Annual Hospital Disclosure Report, Institutional Cost Reports; total nursing hours per NIW-adjusted patient day; RN hours as a percentage of total nursing hours per NIW-adjusted patient day. | Patients | Surgical | | New York, 1992 | 12.50 | | | 0.94
| Hospitals | 126 | | New York, 1994 | 13.00 | | | 0.96
| | 131 | | California, 1992 | 12.00 | | | 0.95
| | 352 | | California, 1994 | 6.50 | | | 0.95
| | 295 | | New York,1992 | 13.50 | | | 1.00
| | 126 | | New York, 1994 | 12.80 | | | 1.00
| | 131 | | Increase by 1% in proportion of RNs, California, 1992 | | | | Not significant
| | 352 | | Increase by 1% in proportion of RNs, California, 1994 | | | | Not significant
| | 295
Mark^90^ | Unit | Patients | | Pt/RN | RN hours | Pt/LPN | LPN hours | Relative change in length of stay
Centers for Medicare Services, Minimum Cost and Capital File, CMS Provider of Services File, CMS Case Mix Index File, CMS Online Survey; Certification and Reporting system (OSCAR) files, and HCUP files. risk-adjusted ratio of observed/expected length of stay; Area Resource Files, American Hospital Association Annual Survey, CMS Wage Rate File, CMS Online Survey; Certification and Reporting system (OSCAR) files; RN FTEs/1,000 in-patient days, RN hours/patient * day = (FTE RN/1,000 patient * days * 37.5 * 48)/1,000; 37.5 hours work week in average 48 working weeks/year, LPN FTEs/1,000 in-patient days, LPN hours/patient * day = (FTE LPN/1,000 patients * days * 37.5 * 48)/1,000; 37.5 hours work week in average 48 working weeks/year | Combined | Medical | | 0.31 | 5.74 | 1.32 | 1.36 | 0.78 | 0.76 | 0.78
| | | | 0.31 | 5.88 | 1.57 | 1.15 | 0.83 | 0.82 | 0.83
| | | | 0.28 | 6.36 | 1.81 | 0.99 | 0.81 | 0.79 | 0.81
| | | | 0.27 | 6.59 | 1.87 | 0.96 | 0.80 | 0.79 | 0.80
| | | | Increase by 1 RN FTE/1,000 patient days in hospitals with high HMO penetration | | | | 0.97 | 0.95 | 0.99
| | | | Increase by 1 LPN FTE/1,000 patient days in hospitals with high HMO penetration | | | | 1.03 | 0.98 | 1.09
| | | | Increase by 1 RN FTE/1,000 patient days in hospitals with low HMO penetration | | | | 0.99 | 0.97 | 1.01
| | | | Increase by 1 LPN FTE/1,000 patient days in hospitals with low HMO penetration | | | | 1.04 | 0.99 | 1.09
| | | | Nurse hours | Patient/RN | RN hours
| | | | 14.60 | 0.38 | 4.79 | | 0.99 | 0.99 | 1.00
| | | | 9.60 | 0.30 | 6.01 | | 0.99 | 0.99 | 1.00
| | | | 17.60 | 0.25 | 7.24 | | 1.00 | 0.99 | 1.00
| | | | 7.80 | 0.38 | 4.79 | | 1.00 | 0.99 | 1.01
| | | | 10.90 | 0.30 | 6.01 | | 1.00 | 0.99 | 1.00
| | | | | 0.25 | 7.24 | | 1.00 | 0.99 | 1.00
Mark^80^ | Hospitals | 64 | | Nurse hours | % RN | % BSN | | Length of stay, days ± SD
The hospital's incident reporting system and patient survey; total patient days divided by the number of discharges, administrative hospital data, nursing survey; proportion of RNs to the total complement of nursing staff, as a ratio of the number of nurses who left during the period divided by the number of nurses employed at the end of the year; availability of support services was evaluated with a 27-item, 3-point checklist 24 in which staff nurses (n = 1,682) indicated whether a variety of support services was available, not available, or inconsistently available (alpha =.85) | Unit | Combined | | 10.00 | 58.00 | 21.00 | | 5.31 ± 1.47
| Patients | Medical
Melberg^20^ | Hospitals | 1 | | Patient/RN | % RN | | | Length of stay, days
Hospital discharge data; average length of stay in hospital; hospital administrative data; FTE RN/100 occupied bed in acute units; % of RN/total nursing personnel | Unit | ICU | | 0.41 | 96 | | | 5.97
| Patients | Medical | | 0.44 | 73.00 | | | 6.70
| | | | 0.36 | 64.00 | | | 6.15
| | | | 0.42 | 76.00 | | | 5.20
| | | | 0.42 | 82.00 | | | 6.30
Needleman^28^ | Hospitals | Patient | | | | | | Length of stay, days ± SD
799 hospitals (11 states, all-patients + Medicare patients) - hospital level analysis; 256 California hospitals (part of the 11 state sample) – unit level analysis; national sample of 3,357 hospitals (Medicare patients) - hospital level analysis; length of stay in hospital; nurse hours calculation: (2,080 hours * each FTE category) + (1,040 hours * number of part-time employees). Total nursing hours/patient-day NIW adjusted including RNs, clinical nurse specialists, general duty nurses, nurse practitioner excluding nursing directors, managers, administrators, supervisors, instructors, anesthetists, and midwifes; RN hours/patient day NIW adjusted; licensed hours/patient-day NIW adjusted including LPN/LVN, excluding the director of nursing. LPN/LVN hours/patient day NIW adjusted; RN hours per day/total hours per day; RN hours/licensed hours = RN hours per day/licensed hours per day (RN + LPN) | 32 | Medical | | Nevada | | | | 4.5 ± 1.26
| 280 | Medical | | New York | | | | 6.31 ± 1.42
| 83 | Medical | | Maryland | | | | 4.34 ± 0.70
| 128 | Medical | | Virginia | | | | 4.62 ± 1.16
| 68 | Medical | | West Virginia | | | | 5.72 ± 1.57
| 86 | Medical | | South Carolina | | | | 4.71 ± 0.72
| 145 | Medical | | Wisconsin | | | | 4.03 ± 0.84
| 154 | Medical | | Missouri | | | | 5.38 ± 1.67
| 25 | Medical | | Arizona | | | | 3.63 ± 0.92
| 127 | Medical | | Massachusetts | | | | 4.79 ± 1.10
| 488 | Medical | | California | | | | 4.81 ± 2.71
| 3,357 | Medical | | Medicare patients | | | | 5.79 ± 2.92
| 3,296 | Surgical | | Medicare patients | | | | 7.68 ± 2.90
| 127 | Surgical | | Massachusetts | | | | 4.15 ± 0.59
| 280 | Surgical | | New York | | | | 5.35 ± 0.97
| 83 | Surgical | | Maryland | | | | 4.25 ± 0.92
| 128 | Surgical | | Virginia | | | | 4.32 ± 0.92
| 68 | Surgical | | West Virginia | | | | 8.09 ± 3.15
| 86 | Surgical | | South Carolina | | | | 4.62 ± 1.10
| 145 | Surgical | | Wisconsin | | | | 4.38 ± 0.74
| 154 | Surgical | | Missouri | | | | 4.52 ± 0.76
| 25 | Surgical | | Arizona | | | | 3.91 ± 0.50
| 32 | Surgical | | Nevada | | | | 5.35 ± 0.79
| 488 | Surgical | | California | | | | 4.27 ± 1.19
| | | | | | | | Relative change in length of stay
| 4,156 | Medical | | Increase by 1 hour of RN hours | | | | 0.90 | 0.86 | 0.93
| 4,156 | Surgical | | Increase by 1 hour in RN hours | | | | 0.97 | 0.95 | 1.00
| 4,156 | Medical | | Increase by 1 hour in LPN hours | | | | 0.98 | 0.91 | 1.05
| 4,156 | Surgical | | Increase by 1 hour in LPN hours | | | | 1.05 | 0.94 | 1.18
| 4,156 | Medical | | Increase by 1 hour in aide hours | | | | 1.07 | 1.02 | 1.13
| 4,156 | Surgical | | Increase by 1 hour in aide hours | | | | 1.00 | 0.95 | 1.06
| 4,156 | Medical | | Increase by 1 hour in total nursing hrs | | | | 0.95 | 0.92 | 0.98
| 4,156 | Surgical | | Increase by 1 hour in total nursing hrs | | | | 0.99 | 0.96 | 1.02
| 4,156 | Medical | | Increase by 1% in RNs | | | | 0.12 | 0.05 | 0.29
| 4,156 | Surgical | | Increase by 1% in RNs | | | | 0.84 | 0.39 | 1.78
| 4,156 | Medical | | Increase by 1 hour in licensed hour | | | | 0.91 | 0.88 | 0.94
| 4,156 | Medical | | increase by 1% of RN/licensed hour | | | | 0.28 | 0.12 | 0.65
| 4,156 | Surgical | | Increase by 1 hour in licensed hour | | | | 0.99 | 0.96 | 1.02
| 4,156 | Surgical | | Increase by 1% in RN/licensed hour | | | | 0.48 | 0.20 | 1.17
| 3,357 | Medical | | Increase by 1 hour in RN hours | | | | 0.94 | 0.92 | 0.96
| 3,357 | Medical | | Increase by 1 hour in LPN hours | | | | 0.99 | 0.97 | 1.02
| 3,357 | Medical | | Increase by 1 hour in licensed hours | | | | 0.95 | 0.93 | 0.97
| 3,357 | Medical | | Increase by 1% in RN/licensed hours | | | | 0.45 | 0.28 | 0.73
| 3,357 | Medical | | Increase in total nurse hours | | | | 0.94 | 0.90 | 0.98
| 3,357 | Medical | | Increase by 1% in RNs | | | | 0.07 | 0.03 | 0.19
| 3,357 | Medical | | Increase by 1 hours in aide hours | | | | 1.09 | 1.02 | 1.17
| 3,357 | Surgical | | Increase by 1 hour in RN hours | | | | 0.98 | 0.95 | 1.00
| 3,357 | Surgical | | Increase by 1 hour in LPN hours | | | | 0.97 | 0.93 | 1.02
| 3,357 | Surgical | | Increase by 1 hour in licensed hours | | | | 0.98 | 0.95 | 1.00
| 3,357 | Surgical | | Increase by 1% in RN/licensed hours | | | | 0.93 | 0.51 | 1.72
| 3,357 | Surgical | | Increase by hour in aide hours | | | | 0.99 | 0.92 | 1.07
| 3,357 | Surgical | | Increase by 1 hour in total nursing hrs | | | | 0.64 | 0.41 | 0.99
| 3,357 | Surgical | | Increase by 1% in RNs | | | | 0.73 | 0.17 | 3.11
| | | | California hospitals
| 256 | Medical | | Increase by hour in RN hours | | | | 0.80 | 0.64 | 1.00
| 256 | Medical | | Increase by 1 hour in LPN hours | | | | 1.54 | 0.60 | 3.92
| 256 | Medical | | Increase by 1 hour in aide hours | | | | 0.99 | 0.78 | 1.25
| 256 | Medical | | Increase by 1 hour in nursing hours | | | | 0.92 | 0.76 | 1.11
| 256 | Medical | | Increase by 1% in RNs | | | | 0.00 | 0.00 | 0.89
| 256 | Medical | | Increase by 1 hour of licensed hours | | | | 0.47 | 0.24 | 0.96
| 256 | Medical | | Increase by 1% of RNs/licensed hour | | | | 0.00 | 0.00 | 0.11
| 256 | Medical | | Increase by 1 hour of RN hours | | | | 0.71 | 0.56 | 0.90
| 256 | Medical | | Increase by 1 hour in LPN hours | | | | 1.14 | 0.57 | 2.29
| 256 | Medical | | Increase by 1 hour in aide hours | | | | 0.93 | 0.65 | 1.33
| 256 | Medical | | Increase by 1 hour nursing hours | | | | 0.82 | 0.70 | 0.96
| 256 | Medical | | Increase by 1% in RNs | | | | 0.00 | 0.00 | 0.70
| 256 | Medical | | Increase by 1 hour/licensed hour | | | | 0.19 | 0.04 | 0.83
| 256 | Medical | | Increase by 1% of RN hours/licensed hr | | | | 0.01 | 0.00 | 0.16
| 256 | Surgical | | Increase by 1 hour of RNs | | | | 1.00 | 0.97 | 1.03
| 256 | Surgical | | Increase by 1 hour in LPN hours | | | | 1.20 | 1.00 | 1.44
| 256 | Surgical | | Increase by 1 hour in aide hours | | | | 0.92 | 0.80 | 1.05
| 256 | Surgical | | Increase by 1 hour in total nursing hours | | | | 1.00 | 0.97 | 1.02
| 256 | Surgical | | Increase by 1% in RNs | | | | 0.16 | 0.03 | 1.04
| 256 | Surgical | | Increase by 1 hour in licensed hours | | | | 1.03 | 0.99 | 1.07
| 256 | Surgical | | Increase by 1% in RNs | | | | 0.31 | 0.08 | 1.22
| | | | Unit level analysis:
| 256 | Surgical | | Increase by 1 hour of RN hours | | | | 1.00 | 0.95 | 1.04
| 256 | Surgical | | Increase by 1 hour in LPN hours | | | | 3.12 | 1.14 | 8.52
| 256 | Surgical | | Increase by 1 hour in aide hours | | | | 0.89 | 0.78 | 1.02
| 256 | Surgical | | Increase by 1 hour in total nursing hours | | | | 0.98 | 0.93 | 1.03
| 256 | Surgical | | Increase by 1% in RNs | | | | 2.47 | 0.86 | 7.12
| 256 | Surgical | | Increase by 1 hour in licensed hours | | | | 1.02 | 0.97 | 1.06
| 256 | Surgical | | Increase by 1% in RNs | | | | 0.48 | 0.18 | 1.26
Needleman^43^ | Hospitals | 799 | | | | | | Relative change in length of stay
Hospital discharge data from 11 states (all patients and Medicare sample) and MedPAR national database (all Medicare patients); adjusted length of stay; state hospital staffing surveys or financial reports. American Hospital Association Annual Survey; Licensed hours (RN + LPN)/patient days adjusted for nursing case-mix index for each hospital, proportion of RN hours/licensed hours (RN + LPN) adjusted for nursing case-mix index for each hospital | Unit | Combined | | 1% increase in RN hours/licensed hour | | | | 0.24 | 0.10 | 0.57
| Patients | Medical | | Increase in 1 licensed hour | | | | 0.99 | 0.96 | 1.01
| | | | Increase in 1 licensed hour | | | | 0.97 | 0.94 | 1.00
| | | | 1% increase in RN hours/licensed hour | | | | 0.94 | 0.51 | 1.73
| | | | Increase in 1 licensed hour | | | | 0.99 | 0.93 | 1.05
| | | | 1% increase in RN hours/licensed hour | | | | 0.46 | 0.15 | 1.38
| | | | 1% increase in RN hours/licensed hour | | | | 0.58 | 0.25 | 1.35
| | | | Increase in 1 licensed hour | | | | 0.95 | 0.93 | 0.97
| | | | 1% increase in RN hours/licensed hour | | | | 0.44 | 0.33 | 0.59
| | | | Increase in 1 licensed hour | | | | 0.87 | 0.83 | 0.91
| | | | Increase in 1 licensed hour | | | | 0.91 | 0.88 | 0.94
| | | | 1% increase in RN hours/licensed hour | | | | 0.11 | 0.04 | 0.36
| | | | 1% increase in RN hours/licensed hour | | | | 0.33 | 0.14 | 0.79
| | | | Increase in 1 licensed hour | | | | 0.91 | 0.88 | 0.95
Oster^31^ | Hospitals | 1 | | % RN | % contract hrs | % full-time hrs | | Length of stay, Days ± SD
Electronic medical records system; length of stay in the hospital for each patient; hospital administrative daily statistic reports; total productive nursing hours/patient day; total number of productive hours worked by nursing personnel with direct patient care/number of patients; % of RN hours/total nursing hours per patient day; % of contract agencies nurses; % of full time nurses | Unit | Patients | | 67.00 | 18.30 | 70.00
| Emergency | Medical | | | | | | 5.24 ± 3.95
| Surgical | Surgical | | | | | | 0.03
| Surgical | Surgical | | | | | | -0.02
| Intensive Care Unit | Medical | | | | | | -0.02
| Intensive Care Unit | Medical | | | | | | 0.01
| Specialty | Medical | | | | | | -0.19
| Specialty | Medical | | | | | | -0.11
Pronovost^72^ | Unit | ICU | | | | | | Length of stay, days
The Uniform Health Discharge Data Set; Hospital length of stay, survey to the ICU directors, average ICU nurse-to-patient ratio during the day and evening | Patients | Surgical | | | | | | Unit | Hospital
| Hospitals | 7 | | More nurses: RNs/patient 1:1 or 1:2, adjusted | | | | 3.00 | 8.00
| | 31 | | Fewer nurses: RNs/patient 1:3 or 1:4, adjusted | | | | 3.00 | 8.00
| | 7
| | 31
Pronovost^61^ | Unit | ICU | | | | | | Relative change in length of stay in unit
The Uniform Hospital Health discharge Data Set; in-hospital length of stay; in ICU length of stay; survey of ICU directors; average nurse to patient ratio in day, in evening. decreased nurse to patient ratio in evening | Patients | Surgical | | Nurse to patient ratio <1:2 during the day
| Hospitals | 8 | | Nurse to patient ratio >1:2 during the day | | | | 1.49 | 1.17 | 1.91
| | 31 | | Nurse to patient ratio <1:2 in evening | | | | 1.00 | 1.00 | 1.00
| | 14 | | Nurse to patient ratio >1:2 in evening | | | | Relative change in LOS in hospital
| | 25 | | | | | | 9.60 | 1.20 | 1.07
| | | | | | | | 8.00 | 1.00 | 1.00
Ridge^25^ | Hospitals | 1 | | % BSN | Experience | % full time | | Length of stay, Days ± SD
Patient survey 2 weeks after discharge with computerized phone interview system; length of stay in hospital; hospital administrative database, finance reports, Health Care Information Access database, unit nurse manager reports; educational level by degree learned: AD, BSN; number of individual staff hired annually/total number of staff, staffing adequacy - RN worked hours/RN target hours | Unit | Surgical | | 44.00 | 8.70 | 86.00 | | 4.10 ± 3.90
| Patients | Surgical
Shamian^15^ | Hospitals | 58 | | | | | | Length of stay, days
The National Comparative Database for Nursing Resource Consumption; average length of stay in unit. GRASP work Load Measurement System, The National Comparative Database for Nursing Resource Consumption; the amount of nursing services for each patient during 24 hours | | | | Rehabilitation units | | | | 24.8
| | | | Psychiatric units | | | | 12.5
| | | | Neonatal units | | | | 14.0
| | | | Pediatric units | | | | 3.7
| | | | Obstetrics | | | | 3.0
| | | | Oncology | | | | 7.9
| | | | Neurological | | | | 6.6
| | | | Intensive Care Unit | | | | 3.8
| | | | Medical surgical | | | | 6.6
| | | | Orthopedics | | | | 6.1
| | | | Cardiac step-down | | | | 6.0
Shortell^94^ | Hospitals | 40 | | | | | | Relative change in length of stay
Hospitals discharge data; length of stay in unit for survivors (observed length of stay/expected length of stay) hospital administrative databases; survey of nursing directors in each unit | Unit | ICU | | Increase by 1 RN/patient ratio | | | | 1.06
| Patients | Medical
Stratton^91^ | Hospitals | Unit | Patients | | | Experience | | Length of stay, Days ± SD
Medical records, hospital incidence and infection control records, surveys; average length of stay in units; payroll records from the National Association of Children's Hospitals and Related Institutions (NACHRI); average in each quarter 2002 of total hours of productive nursing care/patient day adjusted for short-stay patients; average in each quarter 2002 of % of RN productive hours/total nursing hours/patient day; % of RN productive hours worked by supplemental nurse staffing (total nursing overtime hours and percentages of hours from float/agency/traveler RN hours) | 7 | Combined | Combined | Medical/Surgical units | | 7.6 years | | 3.58 ± 0.94
| 7 | Specialty | Surgical | Oncology units | | 6.6 years | | 4.47 ± 0.77
| 7 | ICU | Medical | ICU units | | 8.3 years | | 6.48 ± 4.80
Tschannen^48^ | Hospitals | 2 | | Experience in years | | | | Length of stay, Days ± SD
Patients medical records; patient's episode of care on the study unit; actual patients days were calculated as the time from admission to the time of discharge from the unit; nursing surveys, daily staff assignment sheets, census logs, and payroll records; proportion of RNs working in the unit; self reported years working in the present job category | Unit | ICU | | 15.91 | | | | 2.67 ± 2.20
| Patients | Medical | | 12.58 | | | | 2.83 ± 2.10
| | | | 7.42 | | | | 2.86 ± 2.20
| | | | 10.31 | | | | 3.11 ± 2.60
| | | | | | | | Relative change in length of stay
| | | | Increase by 1 hour in total nursing hours | | | | 1.18
| | | | Increase by 1% in RNs | | | | 0.97
Unruh^66^ | Hospitals | 211 | | Patient/RN | | % RNs | | Length of stay, days
State Health Care Cost Containment Council; average length of stay in hospital. State Department of Health, American Hospital Association; total nurses FTE/1,000 APDC, RN FTE/ 1,000 APDC, LPN FTE/1,000 APDC | Unit | Combined | | 0.34 | | 68.50 | | 6.70
| Patients | Medical | | 0.37 | | 69.20 | | 6.90
| | | | 0.37 | | 70.20 | | 6.50
| | | | 0.37 | | 71.20 | | 6.10
| | | | 0.38 | | 71.50 | | 5.80
| | | | 0.36 | | 71.40 | | 5.40
| | | | 0.38 | | 71.80 | | 5.50
Zidek^85^ | Hospitals | 1 | | Nurse hours | RN hours | % RN
Patient records and chart audits, individuals length of stay in the hospital, administrative records; total nursing hours/patient day; RN hours calculated from % of RN FTE/total FTE | Unit | Combined | | 6.60 | 2.05 | 31.00
| Patients | Medical | | 8.40 | 2.62 | 31.00
| | | | 7.30 | 2.03 | 28.00
| | | | 8.20 | 2.63 | 32.00
| | | | 6.90 | 2.07 | 30.00
| | | | 10.20 | 3.05 | 30.00
| | | | 8.30 | 2.58 | 31.00
| | | | 9.00 | 2.97 | 33.00
| | | | 7.30 | 2.32 | 32.00
| | | | 8.80 | 2.72 | 31.00
| | | | 11.20 | 3.70 | 33.00
| | | | 8.50 | 2.54 | 30.00

APDC = Adjusted Patient Day Care; FTE = Full Time Equivalent; hrs = hours; ICU = Intensive Care Unit; LPN = Licensed Practical Nurse; LOS = Length of Stay; LVN = Licensed Vocational Nurse; MSW = Master of Social Work; NICU = Neonatal Intensive Care Unit; NIW = Nursing Intensity Weight; RN = Registered Nurse; SD = Standard Deviation

Table G10 Calculated change in hospital related mortality corresponding to an increase by 1 nursing hour/patient day (results from individual studies)

Author | Increase by 1 Nurse Hour | | Increase by 1 RN Hour | | | | Increase by 1 LPN Hour | | Increase by 1 UAP Hour
| Death rate | p value | Death rate | p value | RR | p value | Death rate | p value | Death rate | p value
Berney^84^ | | | | | 0.98 | <0.05
Blegen^59^ | | NS | | NS
Cho^38^ | | NS | | NS
Mark^90^ | | | | | 1.01 | NS
Mark^89^ | | | | | 0.94 | NS
Needleman^28^ | | NS | | NS | 1.00 | NS | | NS | | NS
Needleman^29^ | | NS | | NS | 1.00 | NS | | NS
Seago^34^ | | | | | 0.98 | <0.05
Thorson^55^ | | | | | 1.01 | <0.05

LPN = Licensed Practical Nurse; NS = Not Significant; RN = Registered Nurse; RR = Relative Risk; UAP = Unlicensed Assistive Personnel

Table G11 Evidence of the association between nurse hours/patient day and patient outcomes

Author, Source to Measure Patient Outcomes, Definition of Patient Outcomes, Source to Measure Nurse Staffing, Definition of Nurse Hours | Number of Hospitals, Units, Patient Age, % of Whites, % of Males, % of Emergency Admissions | | Nurse Staffing Categories | | | | | Patient Outcomes
ANA^65^ | Hospitals | 1384 | | | | | | Relative Risk
HCFA and MEDPAR national data sets; | Unit | Combined | | | | | | UTI | Nosocomial infection
Urinary tract infections, bacterial unspecified pneumonia, pressure ulcers, postoperative infections, vascular complications, anoxic brain damage; communicable conditions; complications in post-partum period; diabetic complications; joint effusion; metabolic imbalances, personal care complications; psychiatric secondary diagnosis; transfusion reactions; trauma in non-trauma patients | Patients | Combined | Increase by 1 hour in total nursing hours in New York, 1992 | | | | | NS | NS
RN % of licensed hours | | | Increase by 1 hour in total nursing hours in New York, 1994 | | | | | NS | NS
| | | Increase by 1 hour in total nursing hours in California, 1992 | | | | | NS | NS
| | | Increase by 1 hour in total nursing hours in California, 1994 | | | | | NS | NS
| | | | | | | | Pneumonia | Pressure ulcers
| | | Increase by 1 hour in total nursing hours in New York, 1992 | | | | | 1.00 | 0.82
| | | Increase by 1 hour in total nursing hours in New York, 1994 | | | | | 1.00 | 1.00
| | | Increase by 1 hour in total nursing hours in California, 1992 | | | | | 1.00 | 1.00
| | | Increase by 1 hour in total nursing hours in California, 1994 | | | | | 1.08 | 0.84
Archibald^57^ | Hospitals | 1 | | | | | | Nosocomial Infection, rate/100 patient days
Retrospective review of patient and microbiology records from December 1994 through December 1995. The total number of nosocomial infections caused by Serratia marcescens; number of infections per 1,000 patient days. | Unit | ICU | Median RN hours/patient day, 15.2 | | | | | 0.69
Retrospective review of administrative records from December 1994 through December 1995 | Patients | Combined | Increase by 1 hour in RNs/patient day, 16.2 | | | | | 0.67
RN hours worked by the registered nursing staff of this unit; monthly nursing hours/patient day ratio
Berney^84^ | Hospitals | 161 | | | | | | Relative risk
The New York Statewide Planning and Research Cooperative System | Unit | Medical | | | | | | Urinary tract infection
Actual number of events identified as secondary DRG: Death among patients with shock, sepsis, pneumonia, deep vein thrombosis/ pulmonary embolism, or gastrointestinal bleeding | Patients | Medical | 1 hour increase in RN hours/patient day | | | | | 0.99 | 0.98 | 1.01
The New York State Institutional Cost Reports | Patients | Surgical | 1 hour increase in RN hours/patient day | | | | | 0.98 | 0.96 | 1.00
RN total hours in inpatient cost units/patients days in units adjusted for nursing acuity | | | | | | | | Gastro-intestinal bleeding
| Patients | Medical | 1 hour increase in RN hours/patient day | | | | | - | - | -
| Patients | Surgical | 1 hour increase in RN hours/patient day | | | | | 0.95 | 0.92 | 0.99
| | | | | | | | Failure to rescue
| Patients | Medical | 1 hour increase in RN hours/patient day | | | | | 0.98 | 0.97 | 0.99
| Patients | Surgical | 1 hour increase in RN hours/patient day | | | | | 0.98 | 0.97 | 0.99
| | | | | | | | Sepsis
| Patients | Medical | 1 hour increase in RN hours/patient day | | | | | 0.96 | 0.94 | 0.98
| Patients | Medical | 1 hour increase in RN hours/patient day | | | | | 0.97 | 0.95 | 0.99
Blegen^58^ | Hospitals | 11 | | Hours | RN hours | | | Rate per 100 patient days
Comparative occurrence reporting service (CORS) | Unit | Patients | | | | | | Falls | CPR
The number of patient falls on the unit in quarter/1,000 patient days, the number of arrests on the unit in quarter/1,000 patient days | Combined | Combined | Mean of outcome in units | 8.6 | 6.0 | | | 0.27 | 0.04
Hospital reports (Institute for Quality Healthcare database) | | | Increase by 1% in proportion of RN | | 1.1 | | | -0.05 | -0.01
Hours of patient care for each unit provided by all personnel were added for each quarter and divided by patient days for that unit in that quarter | | | Increase by 1 hour in total nursing care | 1.0 | | | | 0.00 | -0.01
| Combined | Combined | Mean of outcome in units | 5.7 | 2.1 | | | 0.4 | 0.03
| Neonatal | Surgical | Mean of outcome in units | 11.3 | 9.9 | | | 0.04 | 0.00
| ICU | Surgical | Mean of outcome in units | 18.0 | 16.2 | | | 0.14 | 0.58
| Combined | Medical | Mean of outcome in units | 10.8 | 7.8 | | | 0.22 | 0.16
Blegen^73^ | Hospitals | 11 | | | | | | Falls rate per 100 patient days
Discharge databases of participating hospitals The number of patient falls on the unit in quarter/1,000 patient days. Hospitals were members of the Institute for Quality Healthcare | Unit | Combined | Total hours -11, RN hours -7.8 | | | | | 0.220
| Patients | Combined | Increase by 1% of RN hours/total nursing hours | | | | | -0.028
| | | Increase by 1 nurse hour/patient day | | | | | -0.005
| | | Increase by 1% of RN hours/total nursing hours | | | | | -0.019
| | | Total hours -11, RN hours -7.7 | | | | | 0.270
Blegen^59^ | Hospitals | 1 | | | | | | Rate per 100 patient days
Hospital records; | Unit | Combined | | | | | | UTI | Pneumonia | Dec ulcer
The number of patient complaints standardized as a rate per 1,000 patient days, new incidences of skin breakdown secondary to pressure or exposure to urine or feces, suddenly and involuntarily leaving a position and coming to rest on the floor or some object. All reported falls were included whether or not injuries resulted, nosocomial infections that express themselves in hospitalized patients in whom the infection was not present or incubating at the time of admission. A record of hours worked for each individual employee was completed by the staffing clerk and approved by the employee and nurse manager before being entered into the computerized payroll database | Patients | Combined | Increase by 1 hour in total nursing hours | | | | | 0.34 | 0.26 | 0.03
The hours of care per patient day from all nursing personnel: hours of direct patient care by RNs, LPNs, and nursing assistants each month divided by the patient days of care on the unit for the month | Acuity | 4.19 | Total hours: 10.74, RN hours: 7.7
The hours of direct patient care from RNs divided by patient days excluding hours for non patient care (meetings, vacation, sick leave, and holidays) | | | | | | | | Falls | Nosocomial infection
| | | Increase by 1 hour in total nursing hours | | | | | 0.01 | 0.05
| | | Total hours: 10.74, RN hours: 7.7 | | | | | 0.27 | 0.60
Bolton^26^ | Medical-surgical units | | | | | | | Rate/100 patient days
California Nursing Outcomes Coalition database; the California Department of Health Services. Hospital-acquired pressure ulcers, unplanned descent to the floor in adult patients; the monthly fall rate per 1,000 patient days for each nursing unit and each hospital. Data are collected at the patient level and aggregated by CalNOC staff to the unit level. | ICU | | Hours | RN hours | LPN hours | | | Falls | Pressure ulcer
California Nursing Outcomes Coalition database; the California Department of Health Services | | | 8 | 4.7 | 0.88 | | | 3.70 | 8
Productive hours worked by the nursing staff who provide direct patient care on the defined unit | | | 16.8 | 15.3 | 1.51 | | | 0.10 | 13
RN hours/patient day
% of UAP hours/total nursing hours
Cheung^32^ | Hospitals | 1 | | | | | | Relative risk
Incidence reports, quality referrals, and medical record coding stores in the database Excalibur system | Unit | Combined | Increase by 1 hour in total nursing hours | | | | | Decubitus ulcer | NS
Pressure ulcers, falls, primary bloodstream infections after admitting the unit as secondary diagnosis. | Patients | Medical | Increase by 1 hour in total nursing hours | | | | | Falls | NS
Automated Nurse staffing Office system and direct observation of nursing activities with Hill_RomCOMposer@nurse locator system | | | Increase by 1 hour in total nursing hours | | | | | Nosocomial Infections | NS
Total nursing personnel on the unit for each shift including the number of RN, LPN, aides, and unit secretaries
RN hours/patient day
LPN hours/patient day
Aide hours/patient day
Cho^30,38^ | Hospitals-232 | | RN hours/patient day | | | | | Pneumonia
The State Inpatient Databases | Unit | Combined | Large, nonprofit, non-teaching, non-rural, 4 | | | | | 2.06
ICD-9-CM for UTI, pressure ulcers, falls and injury, surgical wound infection, sepsis, adverse drug event. | Patients | Combined | Large, nonprofit, non-teaching, non-rural, 5 | | | | | 1.88
Hospital Financial Data | Age | 67.9 | Large, nonprofit, non-teaching, non-rural, 6 | | | | | 1.72
The total productive hours worked by all nursing personnel per patient day; the total productive hours by registered nurses per patient day | Race | 79.3 | Large, nonprofit, non-teaching, non-rural, 8 | | | | | 1.43
| Sex | 48.9 | Large, nonprofit, non-teaching, non-rural, 7 | | | | | 1.57
| Severity | 49.7 | Medium, nonprofit, non-teaching, non-rural, 8 | | | | | 1.33
| | | Medium, investor-owned, non-teaching, non-rural, 4 | | | | | 2.09
| | | Medium, investor-owned, non-teaching, non-rural, 5 | | | | | 1.91
| | | Medium, investor-owned, non-teaching, non-rural, 6 | | | | | 1.74
| | | Medium, investor-owned, non-teaching, non-rural, 7 | | | | | 1.59
| | | Medium, investor-owned, non-teaching, non-rural, 8 | | | | | 1.45
| | | Medium, investor-owned, non-teaching, non-rural, 8 | | | | | 2.16
| | | Large, nonprofit, teaching, non-rural, 5 | | | | | 1.98
| | | Large, nonprofit, teaching, non-rural, 6 | | | | | 1.81
| | | Large, nonprofit, teaching, non-rural, 8 | | | | | 1.51
| | | Medium, nonprofit, non-teaching, non-rural, 4 | | | | | 1.91
| | | Medium, nonprofit, non-teaching, non-rural, 5 | | | | | 1.75
| | | Medium, nonprofit, non-teaching, non-rural, 6 | | | | | 1.59
| | | Medium, nonprofit, non-teaching, non-rural, 7 | | | | | 1.45
| | | Large, nonprofit, teaching, non-rural, 4 | | | | | 2.17
| | | Large, nonprofit, teaching, non-rural, 7 | | | | | 1.65
| | | | Total hours | RN hours | | | UTI % | SWI %
| | | Increase in 1 hour of total nurse hours
| | | large nonprofit teaching hospitals | 10 | 7.2 | | | 2.50 | 1.60
| | | Medium, nonprofit, non-teaching, non-rural | 9 | 6 | | | 1.60 | 1.10
| | | Large, nonprofit, non-teaching, non-rural | 9 | 6.6 | | | 2.00 | 1.50
| | | Medium, investor-owned non-teaching
| | | non-rural hospitals | 9 | 6.2 | | | 2.10 | 1.10
| | | | | | | | Falls % | Sepsis %
| | | Large nonprofit teaching hospitals | 10 | 7.2 | | | 0.20 | 1.20
| | | Medium, nonprofit, non-teaching, non-rural | 9 | 6 | | | 0.20 | 0.80
| | | Large, nonprofit, non-teaching, non-rural | 9 | 6.6 | | | 0.20 | 1.10
| | | Medium, investor-owned non-teaching
| | | non-rural hospitals | 9 | 6.2 | | | 0 | 1.00
| | | | | | | | Pneumonia | Pressure ulcer
| | | Large nonprofit teaching hospitals | 10 | 7.2 | | | 3.10 | 0.10
| | | Medium, nonprofit, non-teaching, non-rural | 9 | 6 | | | 2.70 | 0.30
| | | Large, nonprofit, non-teaching, non-rural | 9 | 6.6 | | | 2.80 | 0.30
| | | Medium, investor-owned non-teaching
| | | non-rural hospitals | 9 | 6.2 | | | 2.80 | 0.20
| | | | | | | | Relative risk
| | | | | | | | Urinary tract infection
| | | Increase in 1 hour of total nurse hours | | | | | 1.02 | 0.95 | 1.08
| | | Increase in 1 hour of RN hours | | | | | 1.01 | 0.93 | 1.08
| | | | | | | | Pneumonia
| | | Increase in 1 hour of total nurse hours | | | | | 0.96 | 0.91 | 1.01
| | | Increase in 1 hour of RN hours | | | | | 0.91 | 0.85 | 0.97
| | | | | | | | Falls
| | | Increase in 1 hour of total nurse hours | | | | | 1.08 | 0.99 | 1.18
| | | Increase in 1 hour of RN hours | | | | | 1.07 | 0.96 | 1.19
| | | | | | | | Pulmonary Failure
| | | Increase in 1 hour of total nurse hours | | | | | 1.13 | 1.01 | 1.27
| | | Increase in 1 hour of RN hours | | | | | 1.11 | 0.97 | 1.27
| | | | | | | | SWI
| | | Increase in 1 hour of total nurse hours | | | | | 1.00 | 0.95 | 1.06
| | | Increase in 1 hour of RN hours | | | | | 0.97 | 0.91 | 1.04
| | | | | | | | Sepsis
| | | Increase in 1 hour of total nurse hours | | | | | 1.01 | 0.95 | 1.08
| | | Increase in 1 hour of RN hours | | | | | 1.02 | 0.95 | 1.09
Cimiotti^87^ | Hospitals | 1 | | | | | | Sepsis
Patient discharges and medical records review by study's nurse epidemiologist | Unit | Neonatal ICU | NICU A, 10.7 nursing hours/patient day | | | | | 10.50
Infections occurring in an infant 48 hours or longer after admission to the NICU including bloodstream infections, device associated pneumonia, CNS and skininfections, conjunctivitis; | Patients | Medical | NICU B, 11 nursing hours/patient day | | | | | 5.50
Nurse staffing office and sign-in/out sheet from each supplemental nursing agency; | | | Mean staffing levels, 10.8 nursing hours/patient day | | | | | 1.00
Total nursing hours worked by direct care providers adjusted for Nursing Intensity Weights categorized as below and above median | | | Low nursing hours, 8.7/patient day | | | | | 2.56
RN hours/patient day adjusted for Nursing Intensity Weights categorized as below and above median | | | High nursing hours,12.9/patient day | | | | | 1.38
| | | Low RN hours, 8.5 hours/patient day | | | | | 3.71
| | | High RN hours, 12.7 hours/patient day | | | | | 1.74
| | | | | | | | % Pneumonia | Nosocomial infection
| | | NICU A, 10.7 nursing hours/patient day | | | | | 0.50 | 18.30
| | | NICU B, 11 nursing hours/patient day | | | | | 0.90 | 15.10
| | | | | | | | Relative risk
| | | | | | | | Nosocomial infection, relative risk
| | | Mean staffing levels, 10.8 nursing hours/patient day | | | | | 1.00
| | | Low nursing hours, 8.7/patient day | | | | | 1.25
| | | High nursing hours, 12.9/patient day | | | | | 0.84
| | | Low RN hours, 8.5 hours/patient day | | | | | 1.75
| | | High RN hours, 12.7 hours/patient day | | | | | 1.08
Donaldson^9^ | Hospitals | 68 | | | | | | Rate/100 patient days SD
CalNOC database; | Unit | Combined | | | | | | Falls
Total number of patients with Stage I-IV pressure ulcers regardless of whether ulcer was acquired during hospitalization or present on admission;%/total number of surveyed patients, unplanned descent to the floor; rate/1,000 patient days. | Patients | Medical | Medical surgical units, before mandatory ratios
CalNOC database in 2004 and 2005 (after legislation); | | | Hour | RN hours | licensed hours
Productive hours worked by total nursing staff who have direct patient care responsibilities on the defined units and are included in the staffing matrix, total number of productive RN hours worked by all RNs (including contracted staff) with direct patient care responsibilities, total number of productive LPN hours worked by all LPNs (including contracted staff) with direct patient care responsibilities | | | 8.08 | 4.76 | 5.44 | | | 0.31 ± 0.20
| | | Medical and surgical units after mandatory ratios
| | | Hour | RN hours | licensed hours
| | | 8.68 | 5.75 | 6.41 | | | 0.32 ± 0.17
| | | Step-down units before mandatory ratios
| | | Hour | RN hours | licensed hours
| | | 9.59 | 6.59 | 6.98 | | | 0.30 ± 0.22
| | | Step-down units after mandatory ratios
| | | Hour | RN hours | licensed hours
| | | 10.11 | 7.28 | 7.59 | | | 0.26 ± 0.16
| | | | | | | | Pressure ulcers
| | | Medical surgical units before mandatory ratios
| | | Hour | RN hours | licensed hours
| | | 8.08 | 4.76 | 5.44 | | | 14.07 ± 11.07
| | | Medical and surgical units after mandatory ratios
| | | Hour | RN hours | licensed hours
| | | 8.68 | 5.75 | 6.41 | | | 14.48 ± 10.39
| | | Step-down units before mandatory ratios
| | | Hour | RN hours | licensed hours
| | | 9.59 | 6.59 | 6.98 | | | 13.52 ± 10.78
| | | Step-down units after mandatory ratios
| | | Hour | RN hours | licensed hours
| | | 10.11 | 7.28 | 7.59 | | | 16.29 ± 10.27
Donaldson^95^ | Hospitals | 25 | | | | | | Rate/100 patient days ± SD
California Nursing Outcomes Coalition (CalNOC) | Unit | Combined | Increase by 1 hour in total RN hours/patient day | | | | | -0.02 ± 0.05
Hospital acquired pressure related skin injury controlling for date of admission, % of all patients on the day of prevalence study | Patients | Medical | Increase by 1 hour in total licensed hours of care/patient day | | | | | -0.02 ± 0.05
Patient's unplanned descent to the hospital floor; were analyzed as 7 day aggregate per unit; also actual number per unit; the number of falls/1,000 patient days. | | | Increase by 1 hour in total nursing hours patient day | | | | | -0.01 ± 0.07
The California Nursing Outcomes Coalition (CalNOC); hours worked by RNs, LPNs, and others (aides and other direct care providers) that have direct patient care responsibilities/ assignments on the defined unit and are included in the staffing matrix.
Fridkin^1^ | Hospitals | 1 | | | | | | Rate/100 patient days
Medical records of the patients in surgical intensive care unit. Cases were defined as any patient hospitalized >48 hours, in the SICU >24 hours who developed a laboratory confirmed CVC-BSI during outbreak periods. Controls were randomly selected from all SICU patients; | Unit | ICU | | | | | | Nosocomial infection | | Sepsis
Laboratory confirmed catheter-associated bloodstream infections or clinical sepsis; rates were compared in pre- and outbreak periods. | Patients | Surgical | Pre-outbreak period, 20 RN hours/patient day | | | | | 1.95 | | 0.53
Hospital administrative records; | | | Outbreak period, 17 RN hours/patient day | | | | | 4.96 | | 1.31
RN hours/patient day | | | | | | RN hours | | Relative risk
| | | Month's patient/nurse ratio = 1.2 | | | 20 | | 3.95 | 1.07 | 14.54
| | | Month's patient/nurse ratio = 1.5 | | | 16 | | 15.60 | 1.15 | 211.4
| | | Month's patient/nurse ratio = 2 | | | 12 | | 61.50 | 1.23 | 3,074
| | | Month's patient/nurse ratio = 1 | | | 24 | | 1.00 | 1.00 | 1.00
Kovner^35^ | Hospitals | 5,708 | Increase by 1 hour in LPN hours/patient day | | | | | UTI, relative risk | | | 1.01
The National Inpatient Sample (NIS) | Unit | Surgical | Increase by 1 hour in LPN hours/patient day | | | | | Pneumonia, relative risk | | | 0.99
Post operative discharges with urinary tract infection, pneumonia, pulmonary congestion, lung edema, or respiratory failure, and DVT in any secondary diagnosis. | Patient | Surgical | Increase by 1 hour in LPN hours/patient day | | | | | Pulmonary failure, RR | | | 1
American Hospital Association Annual Survey of Hospitals, the part of the Health Care Utilization Project | | | Increase by 1 hour in LPN hours/patient day | | | | | Thrombosis, relative risk | | | 0.96
| | | Year | RN hours | LPN hours | | | Rate, %
| | | | | | | | UTI | | Pneumonia
| | | 1990 | 5.84 | 1.24 | | | 3.77 | | 0.75
| | | 1991 | 6.01 | 1.23 | | | 3.75 | | 0.77
| | | 1992 | 5.9 | 1.13 | | | 3.84 | | 0.78
| | | 1993 | 6.13 | 1.09 | | | 3.72 | | 0.95
| | | 1994 | 6.13 | 1.01 | | | 3.81 | | 1.05
| | | 1995 | 6.39 | 1.01 | | | 3.57 | | 1.13
| | | 1996 | 6.56 | 0.97 | | | 3.68 | | 1.24
| | | | | | | | Pulmonary failure | | | DVT
| | | 1990 | 5.84 | 1.24 | | | 0.62 | | | 0.32
| | | 1991 | 6.01 | 1.23 | | | 0.65 | | | 0.33
| | | 1992 | 5.9 | 1.13 | | | 0.72 | | | 0.35
| | | 1993 | 6.13 | 1.09 | | | 0.81 | | | 0.35
| | | 1994 | 6.13 | 1.01 | | | 0.80 | | | 0.37
| | | 1995 | 6.39 | 1.01 | | | 0.95 | | | 0.40
| | | 1996 | 6.56 | 0.97 | | | 1.00 | | | 0.42
Kovner^22^ | Hospitals | 589 | | | | | | Rate ± SD
The Nationwide Inpatient Sample of hospital discharges; | Unit | Surgical | | | | | | Urinary tract infection
UTI, gastrointestinal hemorrhage or ulceration, pneumonia, invasive vascular procedure, pulmonary congestion, lung edema, respiratory insufficiency or failure, DVT or PE, | Patients | Surgical | Reference 5.8 RN hours/adjusted patient day | | | | | 3.58 ± 4.91
AMI as secondary diagnoses after surgery. | | | Increase by 0.5 RN hour/adjusted patient day | | | | | 3.42 ± 4.91
American Hospital Association data | | | | | | | | Pneumonia
RN FTE working in the hospital and outpatient departments/adjusted patient day, LPN FTE working in the hospital and outpatient departments/ adjusted patient day. | | | Reference 5.8 RN hours/adjusted patient day | | | | | 0.95 ± 1.91
| | | Increase by 0.5 RN hour/adjusted patient day | | | | | 0.91 ± 1.91
| | | | | | | | Pulmonary failure
| | | Reference 5.8 RN hours/adjusted patient day | | | | | 0.82 ± 1.40
| | | Increase by 0.5 RN hour/adjusted patient day | | | | | 0.81 ± 1.40
| | | | | | | | Deep vein thrombosis
| | | Reference 5.8 RN hours/adjusted patient day | | | | | 0.32 ± 0.59
| | | Increase by 0.5 RN hour/adjusted patient day | | | | | 0.31 ± 0.59
| | | Increase by 1 LPN hour/patient day | | | | | All outcomes NS
Langemo^41^ | Hospital | 1 | Medical-surgical units in hospitals with <100 bed | | | | | Pressure ulcers, rate,%
The Midwest Research Institute/National Database of Nursing Quality Indicators; | Patients | Medical | Hours | RN hours | LPN hours
% of patients who had a pressure ulcer on a given day to all patients assessed for a pressure ulcer; pressure ulcers that occurred post admission were documented as hospital-acquired. | Unit | ICU | 9.6 | 5 | 1.7 | | | 4.10
The Midwest Research Institute/National Database of Nursing Quality Indicators; | | | ICU in hospitals with 200–299 beds
Total nursing hours/patient day | | | Hours | RN hours | LPN hours
| | | 18 | 17.6 | 0.1 | | | 0.00
| | | ICU units in hospitals <100 beds
| | | Hours | RN hours | LPN hours
| | | 15 | 8.7 | 0.7 | | | 13.10
| | | Medical-surgical units in hospitals with 200–299 beds
| | | Hours | RN hours | LPN hours
| | | 7.8 | 4.8 | 1.2 | | | 0.00
Langemo^33^ | Hospitals | 6 | Acute care units | | | | | Pressure ulcers, rate, %
The North Dakota Nurses Association (NDNA) Research Council; | Unit | ICU | 11 total nursing hours and 5.42 RN hours/patient day | | | | | 8.60
Any lesion which is caused by unrelieved pressure that results in damage to underlying tissues; | Patients | Medical | The authors compared the rate with published studies
unplanned descent to the floor recorded in incidence reports. | Age | 61.9
The North Dakota Nurses Association (NDNA) Research Council; | Sex | 41
Total number of productive hours worked by nursing staff with direct patient care responsibilities
Lichtig^63^ | Unit | Surgical | | | | | | Relative risk,
The Uniform Hospital Discharge Data Set; The California Office of Statewide Health Planning and Development; the Statewide Planning and Research Cooperative System Administratively Releasable file | Patients | Surgical | | | | | | Urinary tract infection, pneumonia, surgical wound infections, and pressure ulcers
Urinary tract infection as the likely adverse patient outcomes of the hospital stay (secondary diagnosis), pneumonia as the likely adverse patient outcomes of the hospital stay (secondary diagnosis), pressure ulcers as the likely adverse patient outcomes of the hospital stay (secondary diagnosis), any secondary diagnosis of infection in surgical patients as the likely adverse patient outcomes of the hospital stay. | Hospitals | | Increase by 1 hour in total nursing hours in New York, 1992 | | | | | NS
The Annual Hospital Disclosure Report Institutional Cost Reports; | 126 | | Increase by 1 hour in total nursing hours in New York, 1994 | | | | | NS
Total RN hours per NIW-adjusted patient day | 131 | | Increase by 1 hour in total nursing hours in California, 1992 | | | | | NS
| 352 | | Increase by 1 hour in total nursing hours in California, 1994 | | | | | NS
| 295 | | | | | | | Rate, %
| | | | | | | | Pressure ulcer | Pneumonia
| | | Increase by 1 hour in total nursing hours in New York, 1992 | | | | | -17.89
| | | Increase by 1 hour in total nursing hours in California, 1994 | | | | | -15.59 | 7.65
Mark^89^ | Hospitals | 357 | Year | RN hours | LPN hours | | | Relative risk, 95% CI
The Healthcare Cost and Utilization Project (HCUP) National Inpatient Sample (NIS); | Unit | Combined | | | | | | Urinary tract infection
Risk-adjusted observed/expected urinary tract infections, pneumonias, decubitus ulcers. | Patients | Combined | 1990 | 5.4 | 1.2 | | | 1.18 | 1.13 | 1.23
American Hospital Association Annual Survey, Online Survey Certification and Reporting System [OSCAR]; | | | 1992 | 5.8 | 1.2 | | | 1.17 | 1.11 | 1.23
RN hours/patient * day = (FTE RN/1,000 patient * days * 37.5 * 48) / 1,000 | | | 1992 | 5.7 | 1.2 | | | 1.17 | 1.12 | 1.22
LPN hours/patient * day = (FTE LPN/1,000 patient * days * 37.5 * 48) / 1,000 | | | 1993 | 6.0 | 1.1 | | | 1.14 | 1.08 | 1.20
| | | 1994 | 6.3 | 1.1 | | | 1.11 | 1.05 | 1.17
| | | 1995 | 6.5 | 1.1 | | | 0.98 | 0.93 | 1.03
| | | | | | | | Pneumonia
| | | 1990 | 5.4 | 1.2 | | | 0.61 | 0.56 | 0.66
| | | 1992 | 5.8 | 1.2 | | | 0.72 | 0.67 | 0.77
| | | 1992 | 5.7 | 1.2 | | | 0.65 | 0.60 | 0.70
| | | 1993 | 6.0 | 1.1 | | | 0.84 | 0.79 | 0.89
| | | 1994 | 6.3 | 1.1 | | | 0.90 | 0.85 | 0.95
| | | 1995 | 6.5 | 1.1 | | | 0.97 | 0.91 | 1.03
| | | | | | | | Decubitus ulcers
| | | 1990 | 5.4 | 1.2 | | | 0.48 | 0.44 | 0.52
| | | 1992 | 5.8 | 1.2 | | | 0.58 | 0.53 | 0.63
| | | 1992 | 5.7 | 1.2 | | | 0.51 | 0.46 | 0.56
| | | 1993 | 6.0 | 1.1 | | | 0.62 | 0.57 | 0.67
| | | 1994 | 6.3 | 1.1 | | | 0.69 | 0.63 | 0.75
| | | 1995 | 6.5 | 1.1 | | | 0.74 | 0.69 | 0.79
Needleman^28^ | Hospitals Patients | | Sample | Hours | RN hours | LPN hours | UAP hours | Rate % ± SD
799 hospitals (11 states, all-patients + Medicare patients) - hospital level analysis; | | | | | | | | Urinary tract infection
256 California hospitals (part of the 11 state sample) - unit level analysis; | 32 | Medical | Nevada | 12.8 | 9.6 | 1.1 | 2.3 | 4.92 ± 0.99
National sample of 3,357 hospitals (Medicare patients) - hospital level analysis. | 280 | Medical | New York | 11.3 | 7.2 | 1.2 | 2.8 | 5.67 ± 1.87
Urinary tract infection coded in discharge abstract as secondary diagnosis, acute gastric ulcer, duodenal ulcer, peptic ulcer, gastrojejunal ulcer, hemorrhagic gastritis, erosive gastritis, unspecified GI-hemorrhage, esophageal hemorrhage coded in discharge abstract as secondary diagnosis, aspiration pneumonia 507.0, post-operative pneumonia 997.3, hypostatic pneumonia 514, bacterial pneumonia 482, bronchopneumonia 485, unspecified pneumonia 486 coded in discharge abstract as secondary diagnosis, cardiac arrest, shock without mention of trauma, shock, unspecified, cardiogenic shock. shock, other, respiratory arrest, nonmechanical methods of resuscitation, cardiopulmonary resuscitation, closed chest massage, death in patients with sepsis, pneumonia, GI bleeding, shock or DVT coded in discharge abstract as secondary diagnosis, pressure ulcers coded with ICD 682 and 707.0 in discharge abstract as secondary diagnosis, pulmonary congestion/ hypostasis, acute edema of lung, unspecified pulmonary insufficiency following trauma and surgery, respiratory failure, posttraumatic (958.3), postoperative (998.5), V. illiaca-451.81, V. fem-451.11, V. pop.-451.19, post-op PE-415.11, PE-415.1, DVT NEC-453.8 coded in discharge abstract as secondary diagnosis, cardiac arrest, shock without mention of trauma, shock, unspecified cardiogenic shock, shock, other respiratory arrest, nonmechanical methods of resuscitation, cardiopulmonary resuscitation, closed chest massage, CNS complications (coma and stupor, acute delirium, reactive confusion, reactive depression); physiologic/metabolic derangement | 83 | Medical | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 6.10 ± 1.72
| 128 | Medical | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 6.14 ± 1.88
| 68 | Medical | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 5.85 ± 2.18
| 86 | Medical | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 6.27 ± 2.30
| 145 | Medical | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 5.89 ± 1.78
| 154 | Medical | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 7.46 ± 2.28
| 25 | Medical | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 4.99 ± 1.25
| 127 | Medical | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 5.52 ± 1.76
| 488 | Medical | California | 10.7 | 7.5 | 1 | 2.2 | 6.92 ± 2.83
| | | Medicare, medical patients
| 3,357 | Medical | | 10.6 | 7.8 | 1.7 | | 8.81 ± 3.01
| | | Medicare, surgical patients
| 3,296 | Surgical | | 10.6 | 7.8 | 1.7 | | 7.75 ± 5.94
| 127 | Surgical | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 3.31 ± 1.72
| 280 | Surgical | New York | 11.3 | 7.2 | 1.2 | 2.8 | 3.01 ± 1.31
| 83 | Surgical | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 2.87 ± 1.63
| 128 | Surgical | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 3.49 ± 2.28
| 68 | Surgical | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 6.95 ± 3.55
| 86 | Surgical | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 3.62 ± 3.30
| 145 | Surgical | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 2.73 ± 1.63
| 154 | Surgical | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 4.05 ± 2.33
| 25 | Surgical | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 2.89 ± 1.44
| 32 | Surgical | Nevada | 12.8 | 9 | 1.1 | 2.3 | 2.80 ± 0.84
| 488 | Surgical | California | 10.7 | 7.5 | 1 | 2.2 | 2.95 ± 1.72
| | | | | | | | Gastrointestinal bleeding
| | | Nevada | 12.8 | 9.6 | 1.1 | 2.3 | 0.70 ± 0.34
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 1.05 ± 0.54
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 1.22 ± 0.43
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 0.96 ± 0.41
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 0.52 ± 0.26
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 0.89 ± 0.51
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 0.84 ± 0.44
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 1.21 ± 0.58
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 0.81 ± 0.41
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.83 ± 0.41
| | | California | 10.7 | 7.5 | 1 | 2.2 | 1.18 ± 0.81
| | | Medicare, medical patients
| | | | 10.6 | 7.8 | 1.7 | | 1.53 ± 0.85
| | | Medicare, surgical patients
| | | | 10.6 | 7.8 | 1.7 | | 1.37 ± 1.78
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.35 ± 0.27
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 0.49 ± 0.42
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 0.58 ± 0.50
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 0.38 ± 0.35
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 1.56 ± 1.09
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 0.44 ± 0.63
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 0.36 ± 0.25
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 0.49 ± 0.50
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 0.32 ± 0.26
| | | Nevada | 12.8 | 9 | 1.1 | 2.3 | 0.59 ± 0.29
| | | California | 10.7 | 7.5 | 1 | 2.2 | 0.48 ± 0.40
| | | | | | | | Pneumonia
| | | Nevada | 12.8 | 9.6 | 1.1 | 2.3 | 2.61 ± 0.85
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 2.36 ± 0.94
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 2.38 ± 0.75
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 2.58 ± 1.04
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 1.89 ± 0.84
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 2.19 ± 0.99
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 1.89 ± 0.65
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 3.57 ± 1.56
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 2.01 ± 0.64
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.56 ± 0.40
| | | California | 10.7 | 7.5 | 1 | 2.2 | 2.54 ± 0.98
| | | Medicare, medical patients
| | | | 10.6 | 7.8 | 1.7 | | 3.72 ± 1.79
| | | Medicare, surgical patients
| | | | 10.6 | 7.8 | 1.7 | | 3.42 ± 3.84
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.12 ± 0.16
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 0.98 ± 0.68
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 1.18 ± 0.91
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 1.32 ± 0.91
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 5.35 ± 2.92
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 2.00 ± 7.81
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 0.74 ± 0.54
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 1.56 ± 1.48
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 0.84 ± 0.52
| | | Nevada | 12.8 | 9 | 1.1 | 2.3 | 1.68 ± 0.67
| | | California | 10.7 | 7.5 | 1 | 2.2 | 1.00 ± 0.68
| | | | | | | | Shock
| | | Nevada | 12.8 | 9.6 | 1.1 | 2.3 | 0.59 ± 0.30
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 0.57 ± 0.32
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 0.56 ± 0.27
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 0.52 ± 0.42
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 0.18 ± 0.16
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 0.49 ± 0.30
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 0.41 ± 0.23
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 0.48 ± 0.31
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 0.55 ± 0.24
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.08 ± 0.08
| | | California | 10.7 | 7.5 | 1 | 2.2 | 0.80 ± 1.32
| | | Medicare, medical patients
| | | | 10.6 | 7.8 | 1.7 | | 0.94 ± 0.72
| | | Medicare, surgical patients
| | | | 10.6 | 7.8 | 1.7 | | 1.23 ± 1.97
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.06 ± 0.09
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 0.39 ± 0.33
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 0.45 ± 0.40
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 0.35 ± 0.43
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 1.56 ± 1.15
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 0.27 ± 0.33
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 0.38 ± 0.62
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 0.50 ± 0.63
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 0.42 ± 0.34
| | | Nevada | 12.8 | 9 | 1.1 | 2.3 | 0.83 ± 0.34
| | | California | 10.7 | 7.5 | 1 | 2.2 | 0.59 ± 0.42
| | | | | | | | Failure to rescue
| | | Nevada | 12.8 | 9.6 | 1.1 | 2.3 | 18.68 ± 2.11
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 22.62 ± 5.92
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 18.83 ± 3.46
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 16.54 ± 5.42
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 13.63 ± 6.21
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 19.05 ± 6.10
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 16.15 ± 5.80
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 16.10 ± 5.28
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 16.76 ± 4.56
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 14.74 ± 4.59
| | | California | 10.7 | 7.5 | 1 | 2.2 | 18.98 ± 5.37
| | | Medicare, medical patients
| | | | 10.6 | 7.8 | 1.7 | | 19.97 ± 7.57
| | | Medicare, surgical patients
| | | | 10.6 | 7.8 | 1.7 | | 22.75 ± 13.65
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 13.02 ± 19.01
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 20.88 ± 14.58
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 20.72 ± 12.24
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 19.51 ± 13.80
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 22.48 ± 12.19
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 16.59 ± 12.53
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 13.00 ± 10.24
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 17.36 ± 11.19
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 18.39 ± 9.31
| | | Nevada | 12.8 | 9 | 1.1 | 2.3 | 21.58 ± 9.25
| | | California | 10.7 | 7.5 | 1 | 2.2 | 22.57 ± 11.85
| | | | | | | | Decubitus ulcer
| | | Nevada | 12.8 | 9.6 | 1.1 | 2.3 | 6.31 ± 3.80
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 7.52 ± 4.13
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 9.01 ± 3.62
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 6.61 ± 2.58
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 5.22 ± 2.90
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 6.57 ± 4.44
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 4.57 ± 2.86
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 6.37 ± 2.94
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 4.43 ± 2.56
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 3.08 ± 1.63
| | | California | 10.7 | 7.5 | 1 | 2.2 | 9.20 ± 5.21
| | | Medicare, surgical patients | | | | | Pulmonary failure
| | | | 10.6 | 7.8 | 1.7 | | 3.53 ± 3.20
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.18 ± 0.23
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 1.09 ± 0.82
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 1.57 ± 1.15
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 1.17 ± 0.95
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 2.19 ± 2.09
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 2.04 ± 7.81
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 0.72 ± 0.51
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 1.23 ± 0.85
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 1.09 ± 0.62
| | | Nevada | 12.8 | 9 | 1.1 | 2.3 | 3.90 ± 1.44
| | | California | 10.7 | 7.5 | 1 | 2.2 | 1.24 ± 0.84
| | | | | | | | Pressure ulcers
| | | Nevada | 12.8 | 9.6 | 1.1 | 2.3 | 6.31 ± 3.80
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 7.52 ± 4.13
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 9.01 ± 3.62
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 6.61 ± 2.58
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 5.22 ± 2.90
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 6.57 ± 4.44
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 4.75 ± 2.86
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 6.37 ± 2.94
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 4.43 ± 2.56
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 3.08 ± 1.63
| | | California | 10.7 | 7.5 | 1 | 2.2 | 9.20 ± 5.21
| | | Medicare, medical patients
| | | | 10.6 | 7.8 | 1.7 | | 6.78 ± 5.34
| | | Medicare, surgical patients
| | | | 10.6 | 7.8 | 1.7 | | 8.13 ± 8.31
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 2.99 ± 4.10
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 6.55 ± 5.01
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 7.07 ± 6.35
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 6.47 ± 9.22
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 6.97 ± 6.19
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 4.63 ± 4.31
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 2.87 ± 3.18
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 3.89 ± 4.87
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 4.11 ± 3.25
| | | Nevada | 12.8 | 9 | 1.1 | 2.3 | 6.24 ± 6.06
| | | California | 10.7 | 7.5 | 1 | 2.2 | 6.93 ± 7.98
| | | | | | | | Deep vein thrombosis, pulmonary embolism
| | | Nevada | 12.8 | 9.6 | 1.1 | 2.3 | 0.57 ± 0.31
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 0.48 ± 0.24
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 0.59 ± 0.34
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 0.50 ± 0.22
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 0.43 ± 0.23
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 0.40 ± 0.17
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 0.52 ± 0.39
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 0.64 ± 0.44
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 0.45 ± 0.19
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.34 ± 0.19
| | | California | 10.7 | 7.5 | 1 | 2.2 | 0.51 ± 0.32
| | | Medicare, medical patients
| | | | 10.6 | 7.8 | 1.7 | | 0.68 ± 0.47
| | | Medicare, surgical patients
| | | | 10.6 | 7.8 | 1.7 | | 0.85 ± 1.10
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.19 ± 0.20
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 0.44 ± 0.30
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 0.49 ± 0.39
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 0.36 ± 0.37
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 0.77 ± 0.86
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 0.36 ± 0.30
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 0.46 ± 0.47
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 0.41 ± 0.36
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 0.27 ± 0.24
| | | Nevada | 12.8 | 9 | 1.1 | 2.3 | 0.77 ± 0.42
| | | California | 10.7 | 7.5 | 1 | 2.2 | 0.35 ± 0.39
| | | | | | | | Surgical wounds infection
| | | Medicare, surgical patients
| | | | 10.6 | 7.8 | 1.7 | | 1.09 ± 1.30
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.85 ± 0.46
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 0.91 ± 0.58
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 0.91 ± 0.52
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 0.70 ± 0.53
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 0.38 ± 0.52
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 0.69 ± 0.52
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 0.73 ± 0.45
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 0.67 ± 0.56
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 0.72 ± 0.39
| | | Nevada | 12.8 | 9 | 1.1 | 2.3 | 0.85 ± 0.40
| | | California | 10.7 | 7.5 | 1 | 2.2 | 0.83 ± 0.58
| | | | | | | | Sepsis
| | | Nevada | 12.8 | 9.6 | 1.1 | 2.3 | 1.47 ± 0.49
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 1.30 ± 0.56
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 1.53 ± 0.63
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 1.04 ± 0.78
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 0.49 ± 0.35
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 1.12 ± 0.54
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 1.00 ± 0.73
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 1.10 ± 0.60
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 1.58 ± 0.78
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.35 ± 0.19
| | | California | 10.7 | 7.5 | 1 | 2.2 | 1.71 ± 1.04
| | | Medicare, medical patients
| | | | 10.6 | 7.8 | 1.7 | | 1.33 ± 0.98
| | | Medicare, surgical patients
| | | | 10.6 | 7.8 | 1.7 | | 2.37 ± 2.35
| | | Massachusetts | 10.9 | 7.6 | 0.8 | 2.3 | 0.15 ± 0.23
| | | New York | 11.3 | 7.2 | 1.2 | 2.8 | 1.06 ± 0.80
| | | Maryland | 11.2 | 8.2 | 0.6 | 2.4 | 1.35 ± 0.85
| | | Virginia | 12.2 | 8.6 | 1.9 | 1.9 | 0.91 ± 0.98
| | | West Virginia | 11.8 | 7.1 | 2.2 | 2.9 | 1.30 ± 1.07
| | | South Carolina | 11.7 | 7.7 | 2 | 2.2 | 0.79 ± 0.62
| | | Wisconsin | 12.7 | 8.9 | 0.9 | 3 | 0.65 ± 0.47
| | | Missouri | 12.7 | 8.9 | 0.9 | 2.9 | 0.85 ± 0.83
| | | Arizona | 12.4 | 9.9 | 0.7 | 1.9 | 0.94 ± 0.60
| | | Nevada | 12.8 | 9 | 1.1 | 2.3 | 1.84 ± 0.80
| | | California | 10.7 | 7.5 | 1 | 2.2 | 1.19 ± 0.82
| | | | | | | | Relative risk, 95% CI
| | | Increase by 1 hour of RN hours in medical patients | | | | | 0.99 | 0.98 | 0.99
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 1.00 | 0.98 | 1.02
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 1.06 | 1.04 | 1.09
| | | Increase by 1 hour in LPN hours in surgical patients | | | | | 1.04 | 1.01 | 1.08
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 1.00 | 0.98 | 1.01
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 1.00 | 0.98 | 1.02
| | | Increase by 1 hour in total nursing hours in medical patients | | | | | 1.00 | 1.00 | 1.01
| | | Increase by 1 hour in total nursing hours in surgical patients | | | | | 1.01 | 1.00 | 1.02
| | | Increase by 1 hour in licensed hours/patient-day in medical patients | | | | | 1.00 | 0.99 | 1.01
| | | increase by 1% of RN hours/total licensed hours per patient day in medical patients | | | | | 0.48 | 0.38 | 0.61
| | | Increase by 1 hour in licensed hours/patient-day in surgical patients | | | | | 1.01 | 0.99 | 1.02
| | | Increase by 1 hour in RN hours in medical patients | | | | | 0.99 | 0.99 | 1.00
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 1.01 | 1.00 | 1.02
| | | Increase by 1 hour in licensed hours in medical patients | | | | | 1.00 | 0.99 | 1.00
| | | Increase in total nurse hours in medical patients | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 0.99 | 0.98 | 1.01
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 0.99 | 0.98 | 1.00
| | | Increase by 1 hour in LPN in surgical patients | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 hour in licensed hours in surgical patients | | | | | 0.99 | 0.99 | 1.00
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 1.00 | 0.98 | 1.02
| | | Increase by 1 hour in total nursing hours | | | | | 1.00 | 0.99 | 1.02
| | | Increase by 1 hour in RN hours in medical patients, hospital level analysis, California hospitals | | | | | 0.99 | 0.97 | 1.00
| | | Increase by 1 hour in LPN hours in medical patients, hospital level analysis, California hospitals | | | | | 1.10 | 1.03 | 1.17
| | | Increase by 1 hour in UAP hours in medical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.97 | 1.03
| | | Increase by 1 hour in total nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.98 | 1.01
| | | Increase by 1 hour of licensed nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.99 | 1.02
| | | Increase by 1 hour of RN hours in medical patients, unit level analysis, California hospitals | | | | | 0.98 | 0.96 | 1.00
| | | Increase by 1 hour in LPN hours in medical patients, unit level analysis, California hospitals | | | | | 1.05 | 0.99 | 1.12
| | | Increase by 1 hour in UAP hours/patient-day in medical patients, unit level analysis, California hospitals | | | | | 0.99 | 0.95 | 1.02
| | | Increase by 1 hour in total nursing hours in medical patients, unit level analysis, California hospitals. | | | | | 0.99 | 0.97 | 1.01
| | | Increase by 1 hour of total licensed hours in medical patients, unit level analysis, California hospitals | | | | | 0.99 | 0.97 | 1.01
| | | Increase by 1 hour of RN hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.87 | 0.77 | 0.99
| | | Increase by 1 hour in LPN hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.02 | 0.93 | 1.11
| | | Increase by 1 hour in UAP hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.95 | 1.05
| | | Increase by 1 hour in total nursing hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.98 | 1.03
| | | Increase by 1 hour in licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.89 | 0.80 | 0.99
| | | Increase by 1% in RN hours/licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.64 | 0.30 | 1.37
| | | Increase by 1 hour of RN hours in surgical patients, unit level analysis, California hospitals | | | | | 0.77 | 0.59 | 0.99
| | | Increase by 1 hour in LPN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.03 | 0.94 | 1.13
| | | Increase by 1 hour in UAP hours in surgical patients, unit level analysis, California hospitals | | | | | 1.01 | 0.95 | 1.08
| | | Increase by 1 hour in total nursing hours in surgical patients, unit level analysis, California hospitals | | | | | 0.81 | 0.66 | 0.98
| | | Increase by 1 hour in licensed hours in surgical patients, unit level analysis, California hospitals | | | | | 0.70 | 0.48 | 1.04
| | | 1% increase in RN hours/total licensed hours (RN + LPN) | | | | | 0.49 | 0.37 | 0.61
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.01 | 0.99 | 1.02
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.99 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.99 | 1.02
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.99 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 hour of RN in surgical patients | | | | | 1.00 | 0.98 | 1.02
| | | Increase by 1 hour of RN in medical patients | | | | | 0.99 | 0.98 | 1.00
| | | | | | | | Gastrointestinal bleeding
| | | Increase by 1 hour of RN hours in medical patients | | | | | 0.98 | 0.97 | 0.99
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 0.98 | 0.96 | 1.01
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 1.02 | 0.98 | 1.06
| | | Increase by 1 hour in LPN hours in surgical patients | | | | | 1.03 | 0.96 | 1.10
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 1.00 | 0.98 | 1.02
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 1.00 | 0.97 | 1.04
| | | Increase by 1 hour in total nursing hours in medical patients | | | | | 0.99 | 0.98 | 1.01
| | | Increase by 1 hour in total nursing hours in surgical patients | | | | | 0.99 | 0.97 | 1.01
| | | Increase by 1 hour in licensed hours/patient-day in medical patients | | | | | 0.99 | 0.97 | 1.00
| | | increase by 1% of RN hours/total licensed hours per patient day in medical patients | | | | | 0.66 | 0.45 | 0.96
| | | Increase by 1 hour in licensed hours/patient day in surgical patients | | | | | 0.99 | 0.96 | 1.01
| | | Increase by 1 hour in RN hours in medical patients | | | | | 0.99 | 0.99 | 1.00
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 0.99 | 0.98 | 1.01
| | | Increase by 1 hour in licensed hours in medical patients | | | | | 0.99 | 0.99 | 1.00
| | | Increase in total nurse hours in medical patients | | | | | 0.99 | 0.97 | 1.00
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 1.00 | 0.97 | 1.02
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 0.98 | 0.98 | 0.99
| | | Increase by 1 hour in LPN in surgical patients | | | | | 1.00 | 0.98 | 1.02
| | | Increase by 1 hour in licensed hours in surgical patients | | | | | 0.99 | 0.98 | 0.99
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 1.00 | 0.95 | 1.04
| | | Increase by 1 hour in total nursing hours | | | | | 0.99 | 0.97 | 1.02
| | | Increase by 1 hour in RN hours in medical patients, hospital level analysis, California hospitals | | | | | 0.98 | 0.96 | 1.00
| | | Increase by 1 hour in LPN hours in medical patients, hospital level analysis, California hospitals | | | | | 1.02 | 0.93 | 1.11
| | | Increase by 1 hour in UAP hours in medical patients, hospital level analysis, California hospitals | | | | | 0.99 | 0.95 | 1.04
| | | Increase by 1 hour in total nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 0.99 | 0.97 | 1.01
| | | Increase by 1 hour of licensed nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 0.98 | 0.96 | 1.01
| | | Increase by 1hour of RN hours in medical patients, unit level analysis, California hospitals | | | | | 0.98 | 0.95 | 1.01
| | | Increase by 1 hour in LPN hours in medical patients, unit level analysis, California hospitals | | | | | 1.01 | 0.92 | 1.10
| | | Increase by 1 hour in UAP hours/patient-day in medical patients, unit level analysis, California hospitals | | | | | 0.99 | 0.93 | 1.04
| | | Increase by 1 hour in total nursing hours in medical patients, unit level analysis, California hospitals. | | | | | 0.99 | 0.96 | 1.01
| | | Increase by 1 hour of total licensed hours in medical patients, unit level analysis, California hospitals | | | | | 0.98 | 0.95 | 1.02
| | | Increase by 1 hour of RN hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.01 | 0.98 | 1.05
| | | Increase by 1 hour in LPN hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.05 | 0.91 | 1.20
| | | Increase by 1 hour in UAP hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.93 | 1.08
| | | Increase by 1 hour in total nursing hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.85 | 0.67 | 1.09
| | | Increase by 1 hour in licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.02 | 0.98 | 1.06
| | | Increase by 1% in RN hours/licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.72 | 0.22 | 2.37
| | | Increase by 1 hour of RN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.03 | 0.98 | 1.08
| | | Increase by 1 hour in LPN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.09 | 0.94 | 1.26
| | | Increase by 1 hour in UAP hours in surgical patients, unit level analysis, California hospitals | | | | | 0.96 | 0.88 | 1.06
| | | Increase by 1 hour in total nursing hours in surgical patients, unit level analysis, California hospitals | | | | | 0.74 | 0.57 | 0.96
| | | Increase by 1 hour in licensed hours in surgical patients, unit level analysis, California hospitals | | | | | 1.04 | 0.99 | 1.09
| | | 1% increase in RN hours/total licensed hours (RN + LPN) | | | | | 0.66 | 0.41 | 0.90
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.96 | 1.01
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.98 | 0.99
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.96 | 1.02
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.99 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.97 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.97 | 1.00
| | | Increase by 1 hour of RN in medical patients | | | | | 0.98 | 0.97 | 0.99
| | | | | | | | Pneumonia
| | | Increase by 1 hour of RN hours in medical patients | | | | | 0.99 | 0.98 | 1.00
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 1.00 | 0.98 | 1.03
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 1.05 | 1.01 | 1.08
| | | Increase by 1 hour in LPN hours in surgical patients | | | | | 1.07 | 1.01 | 1.14
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 1.00 | 0.99 | 1.02
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 1.00 | 0.97 | 1.04
| | | Increase by 1 hour in total nursing hours in medical patients | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 hour in total nursing hours in surgical patients | | | | | 1.02 | 1.00 | 1.05
| | | Increase by 1 hour in licensed hours/patient-day in medical patients | | | | | 1.00 | 0.99 | 1.01
| | | increase by 1% of RN hours/total licensed hours per patient day in medical patients | | | | | 0.59 | 0.44 | 0.80
| | | Increase by 1 hour in licensed hours/patient day in surgical patients | | | | | 1.02 | 0.99 | 1.04
| | | Increase by 1 hour in RN hours in medical patients | | | | | 1.00 | 0.99 | 1.00
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 1.01 | 1.00 | 1.02
| | | Increase by 1 hour in licensed hours in medical patients | | | | | 1.00 | 0.99 | 1.00
| | | Increase in total nurse hours in medical patients | | | | | 1.10 | 1.01 | 1.19
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 1.00 | 1.10 | 0.91
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 0.99 | 0.98 | 1.00
| | | Increase by 1 hour in LPN in surgical patients | | | | | 0.99 | 0.98 | 1.01
| | | Increase by 1 hour in licensed hours in surgical patients | | | | | 0.99 | 0.98 | 1.00
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 1.01 | 0.97 | 1.05
| | | Increase by 1 hour in total nursing hours | | | | | 1.03 | 1.00 | 1.05
| | | Increase by 1 hour in RN hours in medical patients, hospital level analysis, California hospitals | | | | | 0.99 | 0.97 | 1.01
| | | Increase by 1 hour in LPN hours in medical patients, hospital level analysis, California hospitals | | | | | 1.08 | 1.01 | 1.15
| | | Increase by 1 hour in UAP hours in medical patients, hospital level analysis, California hospitals | | | | | 0.99 | 0.96 | 1.02
| | | Increase by 1 hour in total nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 hour of licensed nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.99 | 1.02
| | | Increase by 1 hour of RN hours in medical patients, unit level analysis, California hospitals | | | | | 0.98 | 0.96 | 1.00
| | | Increase by1 hour in LPN hours in medical patients, unit level analysis, California hospitals | | | | | 1.04 | 0.97 | 1.10
| | | Increase by 1 hour in UAP hours/patient day in medical patients, unit level analysis, California hospitals | | | | | 0.98 | 0.95 | 1.02
| | | Increase by 1 hour in total nursing hours in medical patients, unit level analysis, California hospitals. | | | | | 0.99 | 0.97 | 1.01
| | | Increase by 1 hour of total licensed hours in medical patients, unit level analysis, California hospitals | | | | | 0.99 | 0.97 | 1.01
| | | Increase by 1 hour of RN hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.02 | 0.99 | 1.04
| | | Increase by 1 hour in LPN hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.06 | 0.95 | 1.19
| | | Increase by 1 hour in UAP hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.07 | 1.01 | 1.14
| | | Increase by 1 hour in total nursing hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.03 | 1.01 | 1.06
| | | Increase by 1 hour in licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.02 | 0.99 | 1.05
| | | Increase by 1% in RN hours/licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.66 | 0.26 | 1.69
| | | Increase by 1 hour of RN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.02 | 0.98 | 1.07
| | | Increase by 1 hour in LPN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.06 | 0.95 | 1.19
| | | Increase by 1 hour in UAP hours in surgical patients, unit level analysis, California hospitals | | | | | 1.06 | 0.98 | 1.14
| | | Increase by 1 hour in total nursing hours in surgical patients, unit level analysis, California hospitals | | | | | 1.03 | 0.99 | 1.08
| | | Increase by 1 hour in licensed hours in surgical patients, unit level analysis, California hospitals | | | | | 1.03 | 0.99 | 1.07
| | | 1% increase in RN hours/total licensed hours (RN + LPN) | | | | | 0.61 | 0.42 | 0.79
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.02 | 0.99 | 1.04
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.98 | 0.99
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.02 | 0.99 | 1.04
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.99 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 hour of RN in medical patients | | | | | 0.99 | 0.98 | 1.00
| | | | | | | | Shock
| | | Increase by 1 hour of RN hours in medical patients | | | | | 0.98 | 0.96 | 1.00
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 0.99 | 0.96 | 1.02
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 1.07 | 1.01 | 1.12
| | | Increase by 1 hour in LPN hours in surgical patients | | | | | 1.04 | 0.98 | 1.11
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 1.02 | 0.98 | 1.05
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 0.98 | 0.94 | 1.03
| | | Increase by 1 hour in total nursing hours in medical patients | | | | | 0.84 | 0.71 | 0.99
| | | Increase by 1 hour in total nursing hours in surgical patients | | | | | 0.99 | 0.97 | 1.01
| | | Increase by 1 hour in licensed hours/patient-day in medical patients | | | | | 1.00 | 0.97 | 1.02
| | | Increase by 1% of RN hours/total licensed hours per patient day in medical patients | | | | | 0.46 | 0.27 | 0.81
| | | Increase by 1 hour in licensed hours/patient day in surgical patients | | | | | 1.00 | 0.97 | 1.02
| | | Increase by 1 hour in RN hours in medical patients | | | | | 0.99 | 0.98 | 1.00
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 1.03 | 1.01 | 1.05
| | | Increase by 1 hour in licensed hours in medical patients | | | | | 1.00 | 0.99 | 1.01
| | | Increase in total nurse hours in medical patients | | | | | 1.00 | 0.99 | 1.02
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 1.03 | 0.99 | 1.06
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 0.99 | 0.98 | 1.00
| | | Increase by 1 hour in LPN in surgical patients | | | | | 1.03 | 1.01 | 1.04
| | | Increase by 1 hour in licensed hours in surgical patients | | | | | 1.00 | 0.99 | 1.00
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 1.01 | 0.96 | 1.06
| | | Increase by 1 hour in total nursing hours | | | | | 1.00 | 0.98 | 1.03
| | | Increase by 1 hour in RN hours in medical patients, hospital level analysis, California hospitals | | | | | 0.97 | 0.94 | 1.00
| | | Increase by 1 hour in LPN hours in medical patients, hospital level analysis, California hospitals | | | | | 1.17 | 1.04 | 1.31
| | | Increase by 1 hour in UAP hours in medical patients, hospital level analysis, California hospitals | | | | | 1.08 | 1.01 | 1.16
| | | Increase by 1 hour in total nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 1.02 | 0.99 | 1.04
| | | Increase by 1 hour of licensed nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.97 | 1.03
| | | Increase by 1 hour of RN hour in medical patients, unit level analysis, California hospitals | | | | | 0.97 | 0.92 | 1.01
| | | Increase by 1 hour in LPN hours in medical patients, unit level analysis, California hospitals | | | | | 1.08 | 0.95 | 1.21
| | | Increase by 1 hour in UAP hours/patient day in medical patients, unit level analysis, California hospitals | | | | | 1.08 | 1.00 | 1.17
| | | Increase by 1 hour in total nursing hours in medical patients, unit level analysis, California hospitals. | | | | | 1.01 | 0.97 | 1.05
| | | Increase by 1 hour of total licensed hours in medical patients, unit level analysis, California hospitals | | | | | 0.99 | 0.27 | 3.62
| | | Increase by 1 hour of RN hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.97 | 0.94 | 1.00
| | | Increase by 1 hour in LPN hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.18 | 1.06 | 1.32
| | | Increase by 1 hour in UAP hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.01 | 0.94 | 1.08
| | | Increase by 1 hour in total nursing hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.97 | 1.03
| | | Increase by 1 hour in licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.99 | 0.96 | 1.03
| | | Increase by 1% in RN hours/licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.22 | 0.09 | 0.57
| | | Increase by 1 hour of RN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.55 | 1.12 | 2.15
| | | Increase by 1 hour in LPN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.21 | 1.07 | 1.36
| | | Increase by 1 hour in UAP hours in surgical patients, unit level analysis, California hospitals | | | | | 1.94 | 1.11 | 3.40
| | | Increase by 1 hour in total nursing hours in surgical patients, unit level analysis, California hospitals | | | | | 1.01 | 0.97 | 1.06
| | | Increase by 1 hour in licensed hours in surgical patients, unit level analysis, California hospitals | | | | | 1.68 | 1.05 | 2.69
| | | 1% increase in RN hours/total licensed hours (RN + LPN) | | | | | 0.49 | 0.21 | 0.77
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.97 | 1.02
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.99 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.97 | 1.03
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.97 | 1.02
| | | Increase by 1 licensed hour (RN +LPN)/patient day | | | | | 1.00 | 0.97 | 1.02
| | | Increase by 1 hour of RN in medical patients | | | | | 0.98 | 0.96 | 1.01
| | | | | | | | Failure to rescue
| | | Increase by 1 hour of RN hours in medical patients | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 0.98 | 0.96 | 0.99
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 1.02 | 1.00 | 1.04
| | | Increase by 1 hour in LPN hours in surgical patients | | | | | 1.01 | 0.97 | 1.06
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 1.01 | 1.00 | 1.03
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 1.02 | 0.99 | 1.04
| | | Increase by 1 hour in total nursing hours in medical patients | | | | | 1.01 | 1.00 | 1.01
| | | Increase by 1 hour in total nursing hours in surgical patients | | | | | 0.99 | 0.98 | 1.01
| | | Increase by 1 hour in licensed hours/patient-day in medical patients | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1% of RN hours/total licensed hours per patient day in medical patients | | | | | 0.81 | 0.66 | 1.00
| | | Increase by 1 hour in licensed hours/patient day in surgical patients | | | | | 0.98 | 0.97 | 1.00
| | | Increase by 1 hour in RN hours in medical patients | | | | | 1.00 | 0.99 | 1.00
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 1.01 | 1.00 | 1.01
| | | Increase by 1 hour in licensed hours in medical patients | | | | | 1.00 | 1.00 | 1.00
| | | Increase in total nurse hours in medical patients | | | | | 1.01 | 1.00 | 1.01
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 1.01 | 1.00 | 1.03
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 0.97 | 0.95 | 1.00
| | | Increase by 1 hour in LPN in surgical patients | | | | | 1.01 | 1.00 | 1.02
| | | Increase by 1 hour in licensed hours in surgical patients | | | | | 1.00 | 0.99 | 1.00
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 1.01 | 0.98 | 1.04
| | | Increase by 1 hour in total nursing hours | | | | | 0.99 | 0.97 | 1.00
| | | Increase by 1 hour in RN hours in medical patients, hospital level analysis, California hospitals | | | | | 0.99 | 0.98 | 1.00
| | | Increase by 1 hour in LPN hours in medical patients, hospital level analysis, California hospitals | | | | | 1.05 | 1.00 | 1.11
| | | Increase by 1 hour in UAP hours in medical patients, hospital level analysis, California hospitals | | | | | 1.03 | 1.01 | 1.06
| | | Increase by 1 hour in total nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 1.01 | 0.99 | 1.02
| | | Increase by 1 hour of licensed nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.98 | 1.01
| | | Increase by 1 hour of RN hours in medical patients, unit level analysis, California hospitals | | | | | 0.99 | 0.97 | 1.01
| | | Increase by1 hour in LPN hours in medical patients, unit level analysis, California hospitals | | | | | 1.04 | 0.99 | 1.09
| | | Increase by 1 hour in UAP hours/patient day in medical patients, unit level analysis, California hospitals | | | | | 1.03 | 1.00 | 1.06
| | | Increase by 1 hour in total nursing hours in medical patients, unit level analysis, California hospitals. | | | | | 1.00 | 0.99 | 1.02
| | | Increase by 1 hour of total licensed hours in medical patients, unit level analysis, California hospitals | | | | | 1.00 | 0.98 | 1.02
| | | Increase by 1 hour of RN hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.96 | 0.94 | 0.99
| | | Increase by 1 hour in LPN hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.09 | 1.00 | 1.19
| | | Increase by 1 hour in UAP hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.96 | 1.05
| | | Increase by 1 hour in total nursing hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.90 | 1.29 | 2.79
| | | Increase by 1 hour in licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.12 | 1.03 | 1.22
| | | Increase by 1% in RN hours/licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.45 | 0.22 | 0.92
| | | Increase by 1 hour of RN hours in surgical patients, unit level analysis, California hospitals | | | | | 0.96 | 0.92 | 0.99
| | | Increase by 1 hour in LPN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.07 | 0.97 | 1.17
| | | Increase by 1 hour in UAP hours in surgical patients, unit level analysis, California hospitals | | | | | 1.01 | 0.95 | 1.06
| | | Increase by 1 hour in total nursing hours in surgical patients, unit level analysis, California hospitals | | | | | 0.98 | 0.95 | 1.01
| | | Increase by 1 hour in licensed hours in surgical patients, unit level analysis, California hospitals | | | | | 1.41 | 1.00 | 1.99
| | | 1% increase in RN hours/total licensed hours (RN + LPN) | | | | | 0.80 | 0.64 | 0.97
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.98 | 0.97 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.99 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.98 | 0.96 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 1.00 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 1.00 | 1.00 | 1.01
| | | Increase by 1 hour of RN in surgical patients | | | | | 0.98 | 0.96 | 0.99
| | | Increase by 1 hour of RN in medical patients | | | | | 1.00 | 0.99 | 1.01
| | | | | | | | Deep vein thrombosis, pulmonary embolism
| | | Increase by 1 hour of RN hours in medical patients | | | | | 1.01 | 0.99 | 1.03
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 1.03 | 1.00 | 1.06
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 0.97 | 0.93 | 1.01
| | | Increase by 1 hour in LPN hours in surgical patients | | | | | 1.01 | 0.94 | 1.08
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 1.01 | 0.98 | 1.03
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 1.01 | 0.96 | 1.05
| | | Increase by 1 hour in total nursing hours in medical patients | | | | | 1.00 | 0.98 | 1.02
| | | Increase by 1 hour in total nursing hours in surgical patients | | | | | 1.02 | 1.00 | 1.05
| | | Increase by 1 hour in licensed hours/patient-day in medical patients | | | | | 1.01 | 0.99 | 1.02
| | | Increase by 1% of RN hours/total licensed hours per patient day in medical patients | | | | | 1.39 | 0.92 | 2.11
| | | Increase by 1 hour in licensed hours/patient day in surgical patients | | | | | 1.03 | 1.00 | 1.05
| | | Increase by 1 hour in RN hours in medical patients | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 0.99 | 0.97 | 1.00
| | | Increase by 1 hour in licensed hours in medical patients | | | | | 1.00 | 0.99 | 1.01
| | | Increase in total nurse hours in medical patients | | | | | 1.00 | 0.99 | 1.02
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 1.00 | 0.97 | 1.04
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 hour in LPN in surgical patients | | | | | 0.97 | 0.95 | 0.99
| | | Increase by 1 hour in licensed hours in surgical patients | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 0.99 | 0.95 | 1.04
| | | Increase by 1 hour in total nursing hours in surgical patients | | | | | 1.01 | 0.99 | 1.04
| | | Increase by 1 hour in RN hours in medical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.98 | 1.03
| | | Increase by 1 hour in LPN hours in medical patients, hospital level analysis, California hospitals | | | | | 0.91 | 0.83 | 1.01
| | | Increase by 1 hour in UAP hours in medical patients, hospital level analysis, California hospitals | | | | | 1.01 | 0.95 | 1.07
| | | Increase by 1 hour in total nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.97 | 1.02
| | | Increase by 1 hour of licensed nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 0.99 | 0.96 | 1.02
| | | Increase by 1 hour of RN hours in medical patients, unit level analysis, California hospitals | | | | | 1.02 | 0.98 | 1.06
| | | Increase by1 hour in LPN hours in medical patients, unit level analysis, California hospitals | | | | | 0.50 | 0.27 | 0.95
| | | Increase by 1 hour in UAP hours/patient day in medical patients, unit level analysis, California hospitals | | | | | 1.04 | 0.96 | 1.12
| | | Increase by 1 hour in total nursing hours in medical patients, unit level analysis, California hospitals. | | | | | 1.02 | 0.98 | 1.06
| | | Increase by 1 hour of total licensed hours in medical patients, unit level analysis, California hospitals | | | | | 1.01 | 0.97 | 1.05
| | | Increase by 1 hour of RN hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.07 | 1.03 | 1.11
| | | Increase by 1 hour in LPN hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.05 | 0.85 | 1.29
| | | Increase by 1 hour in UAP hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.02 | 0.93 | 1.12
| | | Increase by 1 hour in total nursing hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.06 | 1.02 | 1.10
| | | Increase by 1 hour in licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.07 | 1.02 | 1.12
| | | Increase by 1% in RN hours/licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.03 | 0.00 | 0.66
| | | Increase by 1 hour of RN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.11 | 1.05 | 1.17
| | | Increase by 1 hour in LPN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.09 | 0.89 | 1.33
| | | Increase by 1 hour in UAP hours in surgical patients, unit level analysis, California hospitals | | | | | 1.03 | 0.92 | 1.14
| | | Increase by 1 hour in total nursing hours in surgical patients, unit level analysis, California hospitals | | | | | 1.09 | 1.03 | 1.15
| | | Increase by 1 hour in licensed hours in surgical patients, unit level analysis, California hospitals | | | | | 1.55 | 0.18 | 13.15
| | | | | | | | Sepsis
| | | 1% increase in RN hours/total licensed hours (RN + LPN) | | | | | 1.04 | 1.01 | 1.08
| | | Increase by 1 hour of RN hours in medical patients | | | | | 1.01 | 0.98 | 1.03
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 0.96 | 0.93 | 1.00
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 1.00 | 0.95 | 1.05
| | | Increase by 1 hour in LPN hours in surgical patients | | | | | 1.01 | 0.98 | 1.03
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 0.99 | 0.96 | 1.03
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 1.00 | 0.98 | 1.01
| | | Increase by 1 hour in total nursing hours in medical patients | | | | | 1.00 | 0.98 | 1.02
| | | Increase by 1 hour in total nursing hours in surgical patients | | | | | 0.99 | 0.98 | 1.00
| | | Increase by 1 hour in licensed hours/patient day in medical patients | | | | | 1.34 | 0.91 | 1.97
| | | Increase by 1% of RN hours/total licensed hours per patient day in medical patients | | | | | 1.01 | 0.99 | 1.03
| | | Increase by 1 hour in licensed hours/patient day in surgical patients | | | | | 1.00 | 0.99 | 1.01
| | | Increase by 1 hour in RN hours in medical patients | | | | | 0.98 | 0.97 | 0.99
| | | Increase by 1 hour in LPN hours in medical patients | | | | | 0.99 | 0.99 | 1.00
| | | Increase by 1 hour in licensed hours in medical patients | | | | | 0.99 | 0.98 | 1.01
| | | Increase in total nurse hours in medical patients | | | | | 1.01 | 0.99 | 1.04
| | | Increase by 1 hour in UAP hours in medical patients | | | | | 0.99 | 0.98 | 0.99
| | | Increase by 1 hour in RN hours in surgical patients | | | | | 0.98 | 0.96 | 0.99
| | | Increase by 1 hour in LPN in surgical patients | | | | | 0.96 | 0.95 | 0.97
| | | Increase by 1 hour in licensed hours in surgical patients | | | | | 1.01 | 0.97 | 1.04
| | | Increase by 1 hour in UAP hours in surgical patients | | | | | 0.99 | 0.97 | 1.01
| | | Increase by 1 hour in total nursing hours | | | | | 1.01 | 0.99 | 1.04
| | | Increase by 1 hour in RN hours in medical patients, hospital level analysis, California hospitals | | | | | 0.96 | 0.88 | 1.06
| | | Increase by 1 hour in LPN hours in medical patients, hospital level analysis, California hospitals | | | | | 1.02 | 0.97 | 1.07
| | | Increase by 1 hour in UAP hours in medical patients, hospital level analysis, California hospitals | | | | | 1.01 | 0.99 | 1.03
| | | Increase by 1 hour in total nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.98 | 1.03
| | | Increase by 1 hour of licensed nursing hours in medical patients, hospital level analysis, California hospitals | | | | | 1.02 | 0.98 | 1.05
| | | Increase by 1 hour of RN hours in medical patients, unit level analysis, California hospitals | | | | | 0.96 | 0.88 | 1.05
| | | Increase by 1 hour in LPN hours in medical patients, unit level analysis, California hospitals | | | | | 1.02 | 0.96 | 1.08
| | | Increase by 1 hour in UAP hours/patient day in medical patients, unit level analysis, California hospitals | | | | | 1.01 | 0.98 | 1.04
| | | Increase by 1 hour in total nursing hours in medical patients, unit level analysis, California hospitals | | | | | 1.01 | 0.97 | 1.04
| | | Increase by 1 hour of total licensed hours in medical patients, unit level analysis, California hospitals | | | | | 1.01 | 0.98 | 1.04
| | | Increase by 1 hour of RN hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.00 | 0.89 | 1.13
| | | Increase by 1 hour in LPN hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.02 | 0.96 | 1.08
| | | Increase by 1 hour in UAP hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.59 | 0.31 | 1.14
| | | Increase by 1 hour in total nursing hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.01 | 0.98 | 1.04
| | | Increase by 1 hour in licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 0.12 | 0.01 | 1.01
| | | Increase by 1% in RN hours/licensed hours in surgical patients, hospital level analysis, California hospitals | | | | | 1.03 | 0.98 | 1.08
| | | Increase by 1 hour of RN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.06 | 0.94 | 1.19
| | | Increase by 1 hour in LPN hours in surgical patients, unit level analysis, California hospitals | | | | | 1.02 | 0.95 | 1.08
| | | Increase by 1 hour in UAP hours in surgical patients, unit level analysis, California hospitals | | | | | 1.03 | 0.99 | 1.07
| | | Increase by 1 hour in total nursing hours in surgical patients, unit level analysis, California hospitals | | | | | 1.04 | 1.00 | 1.09
| | | Increase by 1 hour in licensed hours in surgical patients, unit level analysis, California hospitals | | | | | 1.39 | 0.85 | 1.94
| | | 1% increase in RN hours/total licensed hours (RN + LPN) | | | | | 1.01 | 0.98 | 1.03
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.98 | 0.99
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.96 | 1.01
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.99 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.97 | 1.00
| | | Increase by 1 licensed hour (RN + LPN)/patient day | | | | | 0.99 | 0.98 | 1.01
Potter^40^ | Hospitals | 1 | Period | | | Hour | RN hour | Falls, rate/100 patient days
Medical records; (number of falls on a unit/number of patient days) * 1,000. | Unit | ICU | Means in time period Feb-Apr 2000 | | | 3 | 1.67 | 0.30
Administrative hospital data; an average number of nursing care per patient day on the day shift, proportion of UAP hours of direct patient care | Patients | Medical | Means in time period May-Jul 2000 | | | 3 | 1.61 | 0.29
| | | Means in time period Aug-Oct 2000 | | | 3 | 1.69 | 0.30
| | | Means in time period Nov 2000-Jan 2001 | | | 3 | 1.77 | 0.23
Ritter-Teitel^69^ | Hospitals | 28 | Time, Place | Hour | RN hours | UAP hours | | Rate, % ± SD
Hospital Incidence reports; | | | | | | | | Urinary tract infection
% of patients with urinary tract infections not presented at admission among total discharged or sampled patients, % of patients with pressure ulcers, number of events/1,000 patient days. | | | 1997 | 9.3 | 5.1 | 2.4 | | 2.09 ± 2.25
Labor Productivity Program Database and nurse survey; | | | 1998 | 9.6 | 5.3 | 2.6 | | 2.53 ± 2.29
Total nursing hours worked/ patient-day, RN hours worked/patient day, UAP hours worked/patient day | | | Medical Units 1997 | 9.2 | 5.0 | 2.5 | | 2.25 ± 2.36
| | | Medical Units 1998 | 9.8 | 5.5 | 2.7 | | 2.61 ± 2.46
| | | Surgical Units 1997 | 9.4 | 5.2 | 2.3 | | 1.93 ± 2.18
| | | Surgical Units 1998 | 9.4 | 5.1 | 2.6 | | 2.45 ± 2.16
| | | | | | | | Falls
| | | 1997 | 9.3 | 5.1 | 2.4 | | 0.32 ± 0.20
| | | 1998 | 9.6 | 5.3 | 2.6 | | 0.34 ± 0.16
| | | Medical Units 1997 | 9.2 | 5.0 | 2.5 | | 0.40 ± 0.21
| | | Medical Units 1998 | 9.8 | 5.5 | 2.7 | | 0.41 ± 0.17
| | | Surgical Units 1997 | 9.4 | 5.2 | 2.3 | | 0.24 ± 0.14
| | | Surgical Units 1998 | 9.4 | 5.1 | 2.6 | | 0.27 ± 0.12
| | | | | | | | Pressure ulcers
| | | 1997 | 9.3 | 5.1 | 2.4 | | 2.42 ± 2.10
| | | 1998 | 9.6 | 5.3 | 2.6 | | 2.06 ± 1.66
| | | Medical Units 1997 | 9.2 | 5.0 | 2.5 | | 2.33 ± 2.12
| | | Medical Units 1998 | 9.8 | 5.5 | 2.7 | | 2.23 ± 1.94
| | | Surgical Units 1997 | 9.4 | 5.2 | 2.3 | | 2.50 ± 2.11
| | | Surgical Units 1998 | 9.4 | 5.1 | 2.6 | | 1.88 ± 1.33
| | | | | | | | Urinary tract infection
| | | Increase by 1 hour in RN hours | | | | | -0.18 ± 1.24
| | | | | | | | Falls
| | | Increase by 1 hour in RN hours | | | | | -0.42 ± 0.90
| | | Increase by 1 hour in RN hours | | | | | -0.24 ± 1.18
| | | | | | | | Falls
| | | Increase by 1hour in RN hours in medical units | | | | | -0.49 ± 0.87
| | | Increase by 1hour in RN hours in surgical units | | | | | -0.15 ± 0.96
Robert^6^ | Hospitals | 1 | | | Hour/patient day | | | Nosocomial infection
Case-all patients hospitalized in ICU >3 days with a primary BSI during the study period. Controls-randomly selected patients hospitalized ≥3 days in the same unit; primary bloodstream infections (BSIs) (CDC), Index date for cases- the day of 1 positive blood culture; for controls = (cases LOS before BSI/total cases LOS) * control total LOS. | Unit | ICU | | | | | | Rate/100 patient days
Administrative hospital data; | Patients | Surgical | Lower % of temporary nurses | | 13.5 | | | 1.00
total nursing hours-patient day | | | High proportion of temporary nurses | | 12.8 | | | 3.20
| | | | | | | | Relative risk
| | | Lower % of temporary nurses | | 13.5 | | | 1.00 | 1.00 | 1.00
| | | High proportion of temporary nurses | | 12.8 | | | 3.20 | 1.20 | 8.20
Seago^93^ | Hospitals | 1 | | Nursing hours | RN hours | | | Rate per 100 patient days ± SD
Incident reporting system; | Unit | Combined | | | | | | Decubitus ulcer
Decubitus ulcers, rate/1,000 patient days. | Patients | Medical | Medical surgical unit A | 8 | 6 | | | 0.78 ± 0.09
ANSOS/TSI database; | | | Medical surgical unit B | 8 | 8 | | | 0.02 ± 0.05
Both RN and non-RN hours divided by total patient day, RN hours divided by total patient days | | | Medical surgical unit C | 7 | 5 | | | 0.05 ± 0.08
| | | | | | | | Falls
| | | Medical surgical unit A | 8 | 6 | | | 0.35 ± 0.20
| | | Medical surgical unit B | 8 | 8 | | | 0.19 ± 0.19
| | | Medical surgical unit C | 7 | 5 | | | 0.45 ± 0.25
Simmonds^82^ | Hospitals | 1 | Nursing hours | RN hours | | | | Rate %
Active microbiological surveillance of all chronic patients admitted for >30 days of hemodialysis; volunteering patient participation in other units | Unit | Specialized | 5.5 | 4.2 | | | | 1.61
% of patients with positive colonization of vancomycin-resistant enterococci 48 hours after admission to the hospital and after surgery. | Patients | Medical | 5.7 | 4.3 | | | | 3.29
Administrative reports of Patient Care Manager and Nursing Workload Specialist; Integrated Nursing System database; | Age | 68.75 | 5.9 | 4.3 | | | | 4.97
Total nursing FTE per shift * 8 hours/beds in the units | Sex | 55.8 | 6.0 | 4.4 | | | | 6.65
| | | 5.5 | | | | | 1.56
| | | 5.7 | | | | | 1.33
| | | 5.9 | | | | | 1.11
| | | 6.0 | | | | | 1.11
Sovie^71^ | Hospitals | 29 | | | | | | Rate, % ± SD
Incident reports; nosocomial infection (not present at admission or within 72 hours after); the number of infections / number of patients discharged * 100 at hospital level, any lesions caused by unrelieved pressure not presented in admission; annual rate (%) at hospital level, any fall or slip in which a patient came to rest unintentionally on the floor; the ratio of the number of falls in a unit (or area) to the number of patient days * 1000. | Unit | Combined | Hospital nursing department, 1997 | | | | | UTI
The MECON-PEERx Operations Benchmarking Database Reports; the office of the chief nurse executives; nursing survey; | Patients | Combined | Nurse hours | RN hours | UAP hours
Hours Worked per patient day, RN hours worked per patient day, UAP hours worked per patient day | | | 14 | 8.45 | 3 | | | 2.64 ± 1.67
| | | Hospital nursing department, 1998
| | | Nurse hours | RN hours | UAP hours
| | | 13 | 8.09 | 3 | | | 2.02 ± 1.43
| | | Medical units, 1997
| | | Nurse hours | RN hours | UAP hours
| | | 9.1 | 5.1 | 2 | | | 2.17 ± 2.49
| | | Medical units 1998
| | | Nurse hours | RN hours | UAP hours
| | | 9.8 | 5.52 | 3 | | | 2.61 ± 2.56
| | | Surgical units, 1997
| | | Nurse hours | RN hours | UAP hours
| | | 9.3 | 5.18 | 2 | | | 1.87 ± 2.29
| | | Surgical units, 1998
| | | Nurse hours | RN hours | UAP hours
| | | 9.4 | 5.15 | 3 | | | 2.45 ± 2.24
| | | | | | | | Falls
| | | Hospital nursing department, 1997
| | | Nurse hours | RN hours | UAP hours | | | 2.88 ± 1.20
| | | 14 | 8.45 | 3
| | | Hospital nursing department, 1998
| | | Nurse hours | RN hours | UAP hours
| | | 13 | 8.09 | 3 | | | 2.95 ± 0.91
| | | Medical units, 1997
| | | Nurse hours | RN hours | UAP hours
| | | 9.1 | 5.1 | 2 | | | 3.97 ± 2.10
| | | Medical units 1998
| | | Nurse hours | RN hours | UAP hours
| | | 9.8 | 5.52 | 3 | | | 4.11 ± 1.68
| | | Surgical units, 1997
| | | Nurse hours | RN hours | UAP hours
| | | 9.3 | 5.18 | 2 | | | 2.42 ± 1.41
| | | Surgical units, 1998
| | | Nurse hours | RN hours | UAP hours
| | | 9.4 | 5.15 | 3 | | | 2.69 ± 1.19
| | | | | | | | Pressure Ulcers
| | | Hospital nursing department, 1997
| | | Nurse hours | RN hours | UAP hours
| | | 14 | 8.45 | 3 | | | 3.53 ± 1.82
| | | Hospital nursing department, 1998
| | | Nurse hours | RN hours | UAP hours
| | | 13 | 8.09 | 3 | | | 3.14 ± 2.63
| | | Medical units, 1997
| | | Nurse hours | RN hours | UAP hours
| | | 9.1 | 5.1 | 2 | | | 2.61 ± 2.56
| | | Medical units 1998
| | | Nurse hours | RN hours | UAP hours
| | | 9.8 | 5.52 | 3 | | | 2.23 ± 1.94
| | | Surgical units, 1997
| | | Nurse hours | RN hours | UAP hours | | | 2.68 ± 2.22
| | | 9.3 | 5.18 | 2
| | | Surgical units, 1998
| | | Nurse hours | RN hours | UAP hours
| | | 9.4 | 5.15 | 3 | | | 1.88 ± 1.33
| | | | | | | | Falls
| | | Increase by 1 hour in RN hours | | | | | -0.43 ± 0.18
| | | | | | | | UTI
| | | Increase by 1 hour in total nursing hours | | | | | -0.65 ± 0.23
| | | | | | | | Falls
| | | Increase by 1 hour in total nursing hours | | | | | -0.33 ± 0.14
| | | | | | | | Pressure ulcers
| | | Increase by 1 hour in total nursing hours | | | | | -0.32 ± 0.15
Stegenga^78^ | Hospitals | 1 | | Nursing hours | | | | Nosocomial infection/100 patient days
Patients and laboratory records | Unit | ICU | Preinfection night shifts | 12.5 | | | | 1.30
Nosocomial viral gastrointestinal infections (NVGIs) (CDC definition). Rate = number of NVGIs / 1,000 patient days. | Patients | Medical | Postinfection night shifts | 13 | | | | 0.00
Administrative hospital records; | | | Nursing hours/patient days >10.5 | 12 | | | | 1.01
Total nursing hours/patient day. Total hours included educational and overtime hours but not vacation. Total hours were calculated 72 hours before and after infection event | | | Nursing hours/patient days <10.5 | 6.5 | | | | 3.21
| | | | | | | | Relative risk, 95% CI
| | | Nursing hours/patient days >10.5 | 12 | | | | 1.00 | 1.00 | 1.00
| | | Nursing hours/patient days <10.5 | 6.5 | | | | 2.94 | 2.16 | 4.01
Stratton^91^ | Hospitals = 7 | | Nursing hours | RN hours | LPN hours | Aide hours | | Nosocomial infection
Medical records, hospital incidence and infection control records, surveys Â rate/1,000 patient days of respiratory, gastrointestinal, bloodstream and central line infections in hospitalized patients not present at time of admission; rate/1,000 patient days of bloodstream and central line infections in hospitalized patients not present at time of admission. | Units | | | | | | | Rate/100 patient days ± SD
Payroll records from the National Association of Children's Hospitals and Related Institutions (NACHRI); | Medical/surgical units, quarter 1 | | 9.54 | 7.04 | 0.22 | 2.28 | | 0. 75 ± 0.69
Average in each quarter 2002 of total hours of productive nursing care/patient day adjusted for short-stay patients | Medical/surgical units, quarter 2 | | 9.98 | 7.26 | 0.21 | 2.51 | | 0. 53 ± 0.67
| Medical/surgical units, quarter 3 | | 10.5 | 7.65 | 0.22 | 2.63 | | 0. 71 ± 0.77
| Medical/surgical units, quarter 4 | | 9.97 | 7.46 | 0.19 | 2.33 | | 0. 64 ± 0.43
| Oncology units, quarter 1 | | 11.33 | 9.4 | 0.33 | 1.55 | | 0. 65 ± 0.23
| Oncology units, quarter 2 | | 11.37 | 8.93 | 0.47 | 1.92 | | 0. 62 ± 0.39
| Oncology units, quarter 3 | | 12.77 | 10.1 | 0.46 | 2.16 | | 0. 71 ± 0.59
| Oncology units, quarter 4 | | 12.41 | 9.9 | 0.36 | 2.06 | | 0. 85 ± 0.50
| ICU units, quarter 1 | | 18.86 | 16.8 | 0.02 | 2.02 | | 0. 73 ± 0.56
| ICU units, quarter 2 | | 19.37 | 17.1 | 0.03 | 2.3 | | 1. 03 ± 0.96
| ICU units, quarter 3 | | 20.2 | 17.6 | 0.03 | 2.55 | | 0. 80 ± 0.69
| ICU units, quarter 4 | | 19.59 | 17.3 | 0.02 | 2.32 | | 0. 95 ± 0.71
| All units, quarter 1 | | 13.1 | | | | | 0. 51 ± 0.08
| All units, quarter 2 | | 13.5 | | | | | 0. 79 ± 0.17
| All units, quarter 3 | | 14.25 | | | | | 0. 66 ± 0.12
| All units, quarter 4 | | 13.72 | | | | | 0. 56 ± 0.17
| | | Increase by 1 hour in total nursing hours | | | | | 0. 01 ± 0.03
Tallier^83^ | Hospitals | 1 | Time | Nurse hours | RN hours | LPN hours | UAP hours | Rate/100 patient days
Hospital acquired retrospective data; | Unit | Combined | 2000, 4^th^ quarter | 5.84 | | | | UTI
Nosocomial urinary tract infection, incidence rate/1,000 patient day developed 72 hours after admission | Patients | Medical | 2001, 1^st^ quarter | 5.67 | | | | 0.78
Pressure ulcers-Incidence rate/1,000 patient days developed more than 72 hours after admission. | | | October 2000 | 6.2 | 5.85 | 0.87 | 3.58 | 0.24
Nursing Care hours reports, Nursing Daily Staffing Sheets; total productive nursing hours/patient day | | | November 2000 | 5.77 | 5.87 | 1 | 3.31 | 1.10
| | | December 2000 | 5.76 | 5.5 | 0.93 | 3.29 | 0.90
| | | January 2001 | 5.69 | 6.88 | 1.08 | 3.67 | 1.50
| | | February 2001 | 5.27 | 6.64 | 1.04 | 3.29 | 0.70
| | | March 2001 | 6.05 | 6.83 | 1.11 | 3.41 | 0.30
| | | | | | | | 0.30
| | | | | | | | Pressure ulcers
| | | 2000, 4th quarter | 5.84 | | | | 0.17
| | | 2001, 1st quarter | 5.67 | | | | 0.29
| | | October 2000 | 6.2 | 5.85 | 0.87 | 3.58 | 0.10
| | | November 2000 | 5.77 | 5.87 | 1 | 3.31 | 0.60
| | | December 2000 | 5.76 | 5.5 | 0.93 | 3.29 | 0.10
| | | January 2001 | 5.69 | 6.88 | 1.08 | 3.67 | 0.90
| | | February 2001 | 5.27 | 6.64 | 1.04 | 3.29 | 0.60
| | | March 2001 | 6.05 | 6.83 | 1.11 | 3.41 | 0.10
Wan^52^ | Hospitals | 45 | | | | | | Falls, rate/100 patient days
Hospital records; | Unit | Combined | Increase by 1 hour in total nursing hours | | | | | 0.03
Falls, incidence/1,000 patient days adjusted for severity of incident | Patients | Combined | Nurse hours | RN hours | LPN hours
Hospital staffing records; | | | 4.93 | 2.56 | 1.63 | | | 0.31 ± 0.05
Nursing hours/patient day, LPN hours/total nursing hours
Whitman^36^ | Hospitals: 10 | | | | Nurse hours | | | Rate/100 patient days ± SD
Hospital discharge data; | | | | | | | | Falls
The number of hospital-acquired pressure ulcers (≥grade II) divided by the number of patients visually assessed by the nursing staff for skin breakdown; number of unplanned descents to the floor with or without injury times 1,000 divided by the total number of patient days on each unit; number of nosocomial CLI times 1,000 divided by the number of central catheter line days (the number of days central intravenous catheters were in place in patients). | | | Mean in noncardiac ICU | | 18.8 | | | 0.01 ± 0.12
Hospitals system's finance department; | | | Mean in noncardiac ICU | | 18.9 | | | 0.07 ± 0.06
Total worked hours (paid hours minus sick, vacation, and holiday hours) for all personnel (RN, licensed practical nurses, nursing aides, secretaries): total worked hours/the monthly patient days for each unit | | | Mean in noncardiac IMC | | 8.9 | | | 0.31 ± 0.17
| | | Mean in cardiac IMC | | 8.4 | | | 0.35 ± 0.13
| | | Mean in medical/surgical | | 4 | | | 0.49 ± 0.48
| | | | | | | | Pressure ulcers
| | | Mean in noncardiac ICU | | 18.8 | | | 0.07 ± 0.05
| | | Mean in noncardiac ICU | | 18.9 | | | 0.11 ± 0.09
| | | Mean in noncardiac IMC | | 8.9 | | | 0.05 ± 0.05
| | | Mean in cardiac IMC | | 8.4 | | | 0.03 ± 0.03
| | | Mean in medical/surgical | | 4 | | | 0.03 ± 0.03
Zidek^85^ | Hospitals | 1 | | Nurse hours | RN hours | LPN hours | UAP hours | Rate, %
Patient records and chart audits | Unit | Combined | | | | | | Falls | Pressure ulcers
New incidence of skin breakdown acquired over the course of the hospital stay, number of reported unplanned descent to the floor during the course of the hospital stay. | Patients | Medical and surgical | 1999, 1^st^ quarter | 6.6 | 2.1 | 3.84 | 0.73 | 0.59 | 0.18
Administrative records; | | | 1999, 2^nd^ quarter | 8.4 | 2.6 | 4.73 | 1.1 | 0.45 | 0.05
total nursing hours/patient day | | | 1999, 3^rd^ quarter | 7.3 | 2 | 4.06 | 1.16 | 0.83 | 0.26
calculated from % of RN FTE/ total FTE calculated from % of LPN FTE/total FTE calculated from % of UAP FTE/total FTE | | | 1999, 4^th^ quarter | 8.2 | 2.6 | 4.85 | 0.74 | 0.52 | 0.09
| | | 2000, 1^st^ quarter | 6.9 | 2.1 | 4.14 | 0.69 | 0.28 | 0.00
| | | 2000, 2^nd^ quarter | 10.2 | 3.1 | 5.90 | 1.22 | 0.25 | 0.06
| | | 2000, 3^rd^ quarter | 8.3 | 2.6 | 4.45 | 1.25 | 0.23 | 0.17
| | | 2000, 4^th^ quarter | 9 | 3 | 5.13 | 0.9 | 0.63 | 0.37
| | | 2001, 1^st^ quarter | 7.3 | 2.3 | 4.21 | 0.73 | 0.61 | 0.09
| | | 2001, 2^nd^ quarter | 8.8 | 2.7 | 5.09 | 0.96 | 0.62 | 0.24
| | | 2001, 3^rd^ quarter | 11.2 | 3.7 | 6.17 | 1.35 | 0.66 | 0.18
| | | 2001, 4^th^ quarter | 8.5 | 2.5 | 4.91 | 1.02 | 0.66 | 0.11

Dec Ulcer = Decubitus Ulcer; DRG = Diagnosis Related Group; DVT = Deep Vein Thrombosis; ICU = Intensive Care Unit; IMC = Intermediate Care; LPN = Licensed Practical Nurse; NICU = Neonatal Intensive Care Unit; NS = Not Significant; RN = Registered Nurse; RR = Relative Risk; SD = Standard Deviation; SWI = Surgical Wound Infection; UAP = Unlicensed Assistive Personnel; UTI = Urinary Tract Infection

Table G12 Patient outcomes corresponding to an increase by 1 nursing hour/patient day (calculated from published results, more studies contributed to pooled analysis)

Studies | Outcomes | Measure | Effect | Significance
Simmonds^82^ | Nosocomial infection | Rate | | NS
Ritter-Teitel^69^ | Pressure ulcers | Rate | 0.29 | <.0001
Ritter-Teitel^69^ | Urinary tract infection | Rate | 0.30 | <.0001
Ritter-Teitel^69^ | Falls | Rate | 0.08 | <.0001
Cho^30^ | Sepsis | Rate | | NS
Cho^30^ | Pressure ulcers | Rate | | NS
Cho^30^ | Pneumonia | Rate | | NS
Cho^30^ | Urinary tract infection | Rate | | NS
Cho^30^ | Falls | Rate | | NS
Zidek^85^ | Pressure ulcers | Rate | | NS
Zidek^85^ | Falls | Rate | | NS
Tallier^83^ | Pressure ulcers | Rate* | | NS
Tallier^83^ | Urinary tract infection | Rate* | | NS
Cimiotti^87^ | Sepsis | Rate | | NS
Cimiotti^87^ | Nosocomial infection | Rate | | NS
Cimiotti^87^ | Nosocomial infection | Relative risk | 0.92 | 0.001
Cimiotti^87^ | Pneumonia | Rate | | NS
Stratton^91^ | Nosocomial infection | Rate* | 0.04 | <.0001
Blegen^59^ | Nosocomial infection | Rate* | | NS
Blegen^59^ | Urinary tract infection | Rate* | 0.24 | 0.010
Blegen^58^ | Falls | Rate* | | NS
Blegen^58^ | CPR | Rate* | | NS
Robert^6^ | Sepsis | Rate* | | NS
Robert^6^ | Sepsis | Relative risk | | NS
Robert^6^ | Nosocomial infection | Rate* | | NS
Robert^6^ | Nosocomial infection | Relative risk | | NS
Blegen^73^ | Falls | Rate* | 0.03 | 0.010
Bolton^26^ | Pressure ulcers | Rate* | | NS
Bolton^26^ | Falls | Rate* | | NS
Sovie^71^ | Pressure ulcers | Rate | 0.29 | <.0001
Sovie^71^ | Urinary tract infection | Rate | 0.24 | 0.010
Sovie^71^ | Falls | Rate | | NS
Stegenga^78^ | Nosocomial infection | Rate* | | NS
Stegenga^78^ | Nosocomial infection | Relative risk | | NS
Whitman^36^ | Pressure ulcers | Rate* | | NS
Whitman^36^ | Falls | Rate* | -0.03 | 0.001
Potter^40^ | Falls | Rate* | | NS
Langemo^41^ | Pressure ulcers | Rate | | NS
Seago^93^ | Falls | Rate* | | NS
Donaldson^9^ | Pressure ulcers | Rate* | | NS
Donaldson^9^ | Falls | Rate* | -0.02 | 0.031
Needleman^28^ | Sepsis | Rate | | NS
Needleman^28^ | Shock | Rate | | NS
Needleman^28^ | Gastrointestinal bleeding | Rate | | NS
Needleman^28^ | Pressure ulcers | Rate | | NS
Needleman^28^ | Surgical wound infection | Relative risk | | NS
Needleman^28^ | Deep vein thrombosis | Rate | | NS
Needleman^28^ | Pulmonary Failure | Rate | | NS
Needleman^28^ | Pneumonia | Rate | | NS
Needleman^28^ | Urinary tract infection | Rate | | NS
Needleman^28^ | Failure to rescue | Rate | | NS

CPR = Cardiopulmonary Resuscitation; NS = Not Significant

* Rate per 100 patient days

Table G13 Relative risk of patient outcomes corresponding to an increase by 1 nurse hour/patient day as reported by authors

Author | Data | Analytic unit | Hospitals | Unit | Patients | Outcome | Relative Risk | 95% CI
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | UTI | 1.00 | 1.00; 1.01
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | UTI | 1.01 | 1.00; 1.02
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | UTI | 1.00 | 0.99; 1.01
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | UTI | 1.00 | 0.99; 1.02
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | UTI | 1.00 | 0.98; 1.01
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | UTI | 0.99 | 0.97; 1.01
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | UTI | 1.00 | 0.98; 1.03
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | UTI | 0.81 | 0.66; 0.98
Cho^38^ | Administrative | Patient | 232 | Combined | Combined | UTI | 1.02 | 0.95; 1.08
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | GIB | 0.99 | 0.98; 1.01
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | GIB | 0.99 | 0.97; 1.01
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | GIB | 0.99 | 0.97; 1.00
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | GIB | 0.99 | 0.97; 1.02
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | GIB | 0.99 | 0.97; 1.01
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | GIB | 0.99 | 0.96; 1.01
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | GIB | 0.85 | 0.67; 1.09
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | GIB | 0.74 | 0.57; 0.96
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Pneumonia | 1.00 | 0.99; 1.01
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Pneumonia | 1.02 | 1.00; 1.05
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Pneumonia | 1.10 | 1.01; 1.19
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Pneumonia | 1.03 | 1.00; 1.05
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Pneumonia | 1.00 | 0.99; 1.01
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Pneumonia | 0.99 | 0.97; 1.01
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Pneumonia | 1.03 | 1.01; 1.06
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Pneumonia | 1.03 | 0.99; 1.08
Cho^38^ | Administrative | Patient | 232 | Combined | Combined | Pneumonia | 0.96 | 0.91; 1.01
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Shock | 0.84 | 0.71; 0.99
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Shock | 0.99 | 0.97; 1.01
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Shock | 1.00 | 0.99; 1.02
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Shock | 1.00 | 0.98; 1.03
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Shock | 1.02 | 0.99; 1.04
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Shock | 1.01 | 0.97; 1.05
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Shock | 1.00 | 0.97; 1.03
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Shock | 1.01 | 0.97; 1.06
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Failure to rescue | 1.01 | 1.00; 1.01
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Failure to rescue | 0.99 | 0.98; 1.01
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Failure to rescue | 1.01 | 1.00; 1.01
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Failure to rescue | 0.99 | 0.97; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Failure to rescue | 1.01 | 0.99; 1.02
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Failure to rescue | 1.00 | 0.99; 1.02
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Failure to rescue | 1.90 | 1.29; 2.79
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Failure to rescue | 0.98 | 0.95; 1.01
Cho^38^ | Administrative | Patient | 232 | Combined | Combined | Falls | 1.08 | 0.99; 1.18
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Falls | 1.00 | 0.99; 1.02
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Pressure ulcers | 0.99 | 0.97; 1.02
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Pressure ulcers | 0.99 | 0.97; 1.01
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Pressure ulcers | 1.02 | 1.00; 1.04
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Pressure ulcers | 1.02 | 0.99; 1.05
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Pressure ulcers | 0.82 | 0.64; 1.05
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Pressure ulcers | 0.64 | 0.46; 0.88
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | SWI | 1.00 | 0.99; 1.02
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | SWI | 1.01 | 0.99; 1.03
Cho^38^ | Administrative | Patient | 232 | Combined | Surgical | SWI | 1.00 | 0.95; 1.06
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | DVT | 1.00 | 0.98; 1.02
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | DVT | 1.02 | 1.00; 1.05
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | DVT | 1.00 | 0.99; 1.02
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | DVT | 1.01 | 0.99; 1.04
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | DVT | 1.00 | 0.97; 1.02
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | DVT | 1.02 | 0.98; 1.06
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | DVT | 1.06 | 1.02; 1.10
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | DVT | 1.09 | 1.03; 1.15
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Complications | 1.03 | 1.01; 1.06
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Complications | 1.25 | 1.05; 1.50
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Complications | 1.03 | 1.00; 1.06
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Complications | 1.02 | 0.99; 1.05
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Complications | 1.06 | 1.01; 1.10
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Complications | 0.39 | 0.14; 1.13
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Complications | 1.10 | 1.03; 1.18
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Sepsis | 1.00 | 0.98; 1.01
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Sepsis | 1.00 | 0.98; 1.02
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Sepsis | 0.99 | 0.98; 1.01
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Sepsis | 0.99 | 0.97; 1.01
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Sepsis | 1.01 | 0.99; 1.03
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Sepsis | 1.01 | 0.98; 1.04
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Sepsis | 0.59 | 0.31; 1.14
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Sepsis | 1.03 | 0.99; 1.07
Cho^38^ | Administrative | Patient | 232 | Combined | Medical | Sepsis | 1.01 | 0.95; 1.08

DVT = Deep vein thrombosis; GIB = Gastrointestinal bleeding; SWI = Surgical wound infection; UTI = Urinary tract infection

Table G14 Patient outcomes corresponding to an increase by 1 RN hour/patient day (calculated from published results, more studies contributed to pooled analysis)

Studies | Outcomes | Measure | Effect | Significance
Simmonds^82^ | Nosocomial infection | Rate | | NS
Ritter-Teitel^69^ | Pressure ulcers | Rate | | NS
Ritter-Teitel^69^ | Urinary tract infection | Rate | | NS
Ritter-Teitel^69^ | Falls | Rate | | NS
Cho^30^ | Sepsis | Rate | | NS
Cho^30^ | Pressure ulcers | Rate | | NS
Cho^30^ | Surgical wound infection | Rate | | NS
Cho^30^ | Pneumonia | Rate | | NS
Cho^30^ | Urinary tract infection | Rate | | NS
Cho^30^ | Falls | Rate | | NS
Zidek^85^ | Pressure ulcers | Rate | | NS
Zidek^85^ | Falls | Rate | | NS
Tallier^83^ | Pressure ulcers | Rate* | | NS
Tallier^83^ | Urinary tract infection | Rate* | -0.70 | 0.019
Cimiotti^87^ | Sepsis | Rate | | NS
Cimiotti^87^ | Nosocomial infection | Rate | | NS
Cimiotti^87^ | Nosocomial infection | Relative risk | | NS
Cimiotti^87^ | Pneumonia | Rate | | NS
Stratton^91^ | Nosocomial infection | Rate* | 0.02 | 0.012
Fridkin^1^ | Sepsis | Rate* | | NS
Fridkin^1^ | Sepsis | Relative risk | 0.71 | <.0001
Fridkin^1^ | Nosocomial infection | Rate* | | NS
Fridkin^1^ | Nosocomial infection | Relative risk | 0.71 | <.0001
Archibald^57^ | Nosocomial infection | Rate* | | NS
Blegen^58^ | Falls | Rate* | | NS
Blegen^58^ | CPR | Rate* | 0.03 | 0.042
Kovner^22^ | Pulmonary failure | Rate | | NS
Kovner^22^ | Pneumonia | Rate | | NS
Blegen^73^ | Falls | Rate* | 0.04 | 0.010
Bolton^26^ | Pressure ulcers | Rate* | | NS
Bolton^26^ | Falls | Rate* | | NS
Sovie^71^ | Pressure ulcers | Rate | 0.32 | 0.032
Sovie^71^ | Urinary tract infection | Rate | | NS
Sovie^71^ | Falls | Rate | | NS
Kovner^35^ | Deep vein thrombosis | Rate | -0.11 | <.0001
Kovner^35^ | Pulmonary failure | Rate | | NS
Kovner^35^ | Pneumonia | Rate | | NS
Kovner^35^ | Urinary tract infection | Rate | | NS
Kovner^35^ | Urinary tract infection | Relative risk | | NS
Cho^38^ | Sepsis | Relative risk | | NS
Cho^38^ | Surgical wound infection | Relative risk | | NS
Cho^38^ | Pulmonary failure | Relative risk | | NS
Cho^38^ | Pneumonia | Rate | -0.16 | <.0001
Cho^38^ | Pneumonia | Relative risk | | NS
Cho^38^ | Urinary tract infection | Relative risk | | NS
Cho^38^ | Falls | Relative risk | | NS
Potter^40^ | Falls | Rate* | | NS
Langemo^41^ | Pressure ulcers | Rate | | NS
Mark^89^ | Pneumonia | Relative risk | | NS
Mark^89^ | Urinary tract infection | Relative risk | | NS
Seago^93^ | Falls | Rate* | | NS
Donaldson^9^ | Pressure ulcers | Rate* | | NS
Donaldson^9^ | Falls | Rate* | | NS
Needleman^28^ | Sepsis | Rate | | NS
Needleman^28^ | Shock | Rate | | NS
Needleman^28^ | Gastrointestinal bleeding | Rate | | NS
Needleman^28^ | Pressure ulcers | Rate | | NS
Needleman^28^ | Surgical wound infection | Rate | | NS
Needleman^28^ | Surgical wound infection | Relative risk | | NS
Needleman^28^ | Deep vein thrombosis | Rate | | NS
Needleman^28^ | Pulmonary failure | Rate | | NS
Needleman^28^ | Pneumonia | Rate | | NS
Needleman^28^ | Urinary tract infection | Rate | | NS
Needleman^28^ | Failure to rescue | Rate | | NS

NS = Not significant

* Rate per 100 patient days

Table G15 Relative risk of patient outcomes corresponding to an increase by 1 RN hour/patient day as reported by authors

Author | Data | Analytic Unit | Hospitals | Units | Patients | Outcomes | Relative Risk | 95% CI
Berney^84^ | Administrative | Hospital | 161 | Medical | Medical | UTI | 0.99 | 0.98; 1.01
Berney^84^ | Administrative | Hospital | 161 | Surgical | Surgical | UTI | 0.98 | 0.96; 1.00
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | UTI | 0.99 | 0.98; 0.99
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | UTI | 1.00 | 0.98; 1.02
Needleman^28^ | Administrative | Hospital | 3,,357 | Medical | Medical | UTI | 0.99 | 0.99; 1.00
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | UTI | 0.99 | 0.98; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | UTI | 0.99 | 0.97; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | UTI | 0.98 | 0.96; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | UTI | 0.87 | 0.77; 0.99
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | UTI | 0.77 | 0.59; 0.99
Cho^38^ | Administrative | Hospital | 232 | Combined | Medical | UTI | 1.01 | 0.93; 1.08
Needleman^28^ | Administrative | Hospital | 799 | Combined | Surgical | UTI | 1.00 | 0.98; 1.02
Needleman^28^ | Administrative | Hospital | 799 | Combined | Medical | UTI | 0.99 | 0.98; 1.00
Berney^84^ | Administrative | Hospital | 161 | Surgical | Surgical | GIB | 0.95 | 0.92; 0.99
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | GIB | 0.98 | 0.97; 0.99
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | GIB | 0.98 | 0.96; 1.01
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | GIB | 0.99 | 0.99; 1.00
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | GIB | 0.98 | 0.98; 0.99
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | GIB | 0.98 | 0.96; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | GIB | 0.98 | 0.95; 1.01
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | GIB | 1.01 | 0.98; 1.05
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | GIB | 1.03 | 0.98; 1.08
Needleman^29^ | Administrative | Hospital | 799 | Combined | Medical | GIB | 0.98 | 0.97; 0.99
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Pneumonia | 0.99 | 0.98; 1.00
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Pneumonia | 1.00 | 0.98; 1.03
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Pneumonia | 1.00 | 0.99; 1.00
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Pneumonia | 0.99 | 0.98; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Pneumonia | 0.99 | 0.97; 1.01
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Pneumonia | 0.98 | 0.96; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Pneumonia | 1.02 | 0.99; 1.04
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Pneumonia | 1.02 | 0.98; 1.07
Cho^38^ | Administrative | Hospital | 232 | Combined | Medical | Pneumonia | 0.91 | 0.85; 0.97
Needleman^29^ | Administrative | Hospital | 799 | Combined | Medical | Pneumonia | 0.99 | 0.98; 1.00
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Shock | 0.98 | 0.96; 1.00
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Shock | 0.99 | 0.96; 1.02
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Shock | 0.99 | 0.98; 1.00
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Shock | 0.99 | 0.98; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Shock | 0.97 | 0.94; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Shock | 0.97 | 0.92; 1.01
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Shock | 0.97 | 0.94; 1.00
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Shock | 1.55 | 1.12; 2.15
Needleman^29^ | Administrative | Hospital | 799 | Combined | Medical | Shock | 0.98 | 0.96; 1.01
Berney^84^ | Administrative | Hospital | 161 | Medical | Medical | Failure to rescue | 0.98 | 0.97; 0.99
Berney^84^ | Administrative | Hospital | 161 | Surgical | Surgical | Failure to rescue | 0.98 | 0.97; 0.99
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Failure to rescue | 1.00 | 0.99; 1.01
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Failure to rescue | 0.98 | 0.96; 0.99
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Failure to rescue | 1.00 | 0.99; 1.00
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Failure to rescue | 0.97 | 0.95; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Failure to rescue | 0.99 | 0.98; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Failure to rescue | 0.99 | 0.97; 1.01
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Failure to rescue | 0.96 | 0.94; 0.99
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Failure to rescue | 0.96 | 0.92; 0.99
Needleman^29^ | Administrative | Hospital | 799 | Combined | Surgical | Failure to rescue | 0.98 | 0.96; 0.99
Needleman^29^ | Administrative | Hospital | 799 | Combined | Medical | Failure to rescue | 1.00 | 0.99; 1.01
Cho^38^ | Administrative | Hospital | 232 | Combined | Medical | Falls | 1.07 | 0.96; 1.19
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Pulmonary failure | 1.00 | 0.98; 1.02
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Pulmonary failure | 1.00 | 0.99; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Pulmonary failure | 0.99 | 0.96; 1.02
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Pulmonary failure | 0.99 | 0.94; 1.04
Cho^38^ | Administrative | Hospital | 232 | Combined | Combined | Pulmonary failure | 1.11 | 0.97; 1.27
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Pressure ulcers | 0.99 | 0.97; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Pressure ulcers | 0.98 | 0.96; 1.01
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Pressure ulcers | 0.99 | 0.98; 1.00
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Pressure ulcers | 0.98 | 0.98; 0.99
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Pressure ulcers | 0.99 | 0.97; 1.02
Cho^38^ | Administrative | Hospital | 232 | Combined | Medical | Pressure ulcers | 1.00 | 0.96; 1.03
Kovner^35^ | Administrative | Hospital | 5,708 | Surgical | Surgical | Pressure ulcers | 0.87 | 0.75; 1.02
Needleman^29^ | Administrative | Hospital | 799 | Combined | Surgical | Pressure ulcers | 1.04 | 0.99; 1.10
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | SWI | 1.00 | 0.99; 1.02
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | SWI | 1.02 | 1.01; 1.03
Cho^38^ | Administrative | Hospital | 232 | Combined | Surgical | SWI | 0.97 | 0.91; 1.04
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | DVT | 1.01 | 0.99; 1.03
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | DVT | 1.03 | 1.00; 1.06
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | DVT | 1.00 | 0.99; 1.01
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | DVT | 1.00 | 0.99; 1.01
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | DVT | 1.00 | 0.98; 1.03
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | DVT | 1.02 | 0.98; 1.06
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | DVT | 1.07 | 1.03; 1.11
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | DVT | 1.11 | 1.05; 1.17
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Complications | 0.96 | 0.68; 1.35
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Complications | 1.01 | 1.00; 1.02
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Complications | 1.10 | 1.03; 1.19
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Complications | 1.02 | 0.98; 1.05
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Complications | 1.05 | 1.00; 1.10
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Complications | 1.04 | 0.98; 1.10
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Complications | 1.10 | 1.02; 1.19
Berney^84^ | Administrative | Hospital | 161 | Medical | Medical | Sepsis | 0.96 | 0.94; 0.98
Berney^84^ | Administrative | Hospital | 161 | Surgical | Surgical | Sepsis | 0.97 | 0.95; 0.99
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Sepsis | 1.04 | 1.01; 1.08
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Sepsis | 1.01 | 0.98; 1.03
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Sepsis | 1.00 | 0.99; 1.01
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Sepsis | 0.99 | 0.98; 0.99
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Sepsis | 1.01 | 0.99; 1.04
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Sepsis | 1.02 | 0.98; 1.05
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Sepsis | 1.01 | 0.98; 1.04
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Sepsis | 1.03 | 0.98; 1.08
Cho^38^ | Administrative | Hospital | 232 | Combined | Medical | Sepsis | 1.02 | 0.95; 1.09

DVT = Deep vein thrombosis; GIB = Gastrointestinal bleeding; SWI = Surgical wound infection; UTI = Urinary tract infection

Table G16 Patient outcomes corresponding to an increase by 1 LPN hour/patient day (effects reported by authors and calculated from published results, more studies contributed to pooled analysis)

Studies | Outcomes | Measure | Effect | Significance
Zidek^85^ | Pressure ulcers | Rate | | NS
Zidek^85^ | Falls | Rate | | NS
Tallier^83^ | Pressure ulcers | Rate* | | NS
Tallier^83^ | Urinary tract infection | Rate* | | NS
Stratton^91^ | Nosocomial Infection | Rate* | | NS
Bolton^26^ | Pressure ulcers | Rate* | | NS
Bolton^26^ | Falls | Rate* | | NS
Kovner^35^ | Deep vein thrombosis | Rate | -0.31 | 0.003
Kovner^35^ | Pulmonary failure | Rate | -1.23 | 0.002
Kovner^35^ | Pneumonia | Rate | -1.69 | 0.002
Kovner^35^ | Urinary tract infection | Rate | | NS
Langemo^41^ | Pressure ulcers | Rate | | NS
Mark^89^ | Pneumonia | Relative risk | 0.13 | 0.004
Mark^89^ | Urinary tract infection | Relative risk | | NS
Needleman^28^ | Sepsis | Rate | | NS
Needleman^28^ | Gastrointestinal bleeding | Rate | | NS
Needleman^28^ | Pressure ulcers | Rate | | NS
Needleman^28^ | Surgical wound infection | Rate | | NS
Needleman^28^ | Surgical wound infection | Relative risk | | NS
Needleman^28^ | Deep vein thrombosis | Rate | | NS
Needleman^28^ | Pulmonary failure | Rate | | NS
Needleman^28^ | Pneumonia | Rate | 1.07 | 0.015
Needleman^28^ | Urinary tract infection | Rate | | NS
Needleman^28^ | Failure to rescue | Rate | | NS

NS = Not significant

* Rate per 100 patient days

Table G17 Patient outcomes corresponding to an increase by 1 unlicensed assistive personnel hour/patient day (effects reported by authors and calculated from published results, more studies contributed to pooled analysis)

Studies | Outcomes | Measure | Effect | Significance
Needleman^28^ | Shock | Rate | | NS
Needleman^28^ | Gastrointestinal bleeding | Rate | | NS
Ritter-Teitel^69^ | Pressure ulcers | Rate | | NS
Zidek^85^ | Pressure ulcers | Rate | | NS
Tallier^83^ | Pressure ulcers | Rate* | | NS
Sovie^71^ | Pressure ulcers | Rate | | NS
Needleman^28^ | Pressure ulcers | Rate | | NS
Needleman^28^ | Surgical wound infection | Rate | | NS
Needleman^28^ | Surgical wound infection | Relative risk | | NS
Cimiotti^87^ | Nosocomial infection | rate | | NS
Stratton^91^ | Nosocomial infection | Rate* | | NS
Needleman^28^ | Deep vein thrombosis | Rate | | NS
Needleman^28^ | Pulmonary failure | Rate | | NS
Needleman^28^ | Pneumonia | Rate | | NS
Cimiotti^87^ | Pneumonia | Rate | | NS
Ritter-Teitel^69^ | Urinary tract infection | Rate | 1.58 | 0.0001
Tallier^83^ | Urinary tract infection | Rate* | | NS
Sovie^71^ | Urinary tract infection | Rate | | NS
Needleman^28^ | Urinary tract infection | Rate | | NS
Needleman^28^ | Failure to rescue | Rate | | NS
Ritter-Teitel^69^ | Falls | Rate | | NS
Zidek^85^ | Falls | Rate | | NS
Sovie^71^ | Falls | Rate | | NS

NS = Not significant

* Rate per 100 patient days

Table G18 Evidence of the association between nurse education and experience and patient outcomes

Author, Definition of Patient Outcomes, Definition of Nurse Education and Experience | Number of hospitals, Units, Patient Age, % of Whites, % of Males, % of Emergency Admissions | | Nurse Education and Experience Categories | | | | Patient Outcomes
Aiken^39^ | Hospitals | 168 | | | | | Falls, rate %
Failure to rescue: deaths within 30 days of admission among patients who experienced complications, Complications: the secondary diagnosis distinguished from preexisting co morbidities, Highest credential in nursing: a hospital school diploma, an associate degree, a bachelor's degree, a master's degree, or another degree; the mean number of years of experience working as an RN for nurses from each hospital | Unit | ICU | 60% of hospital workforce with BSN or higher, 8 patients/day | | | | 8.47
| Patients | Surgical | 40% of hospital workforce with BSN or higher, 4 patient/nurse | | | | 7.84
| | | 20% of hospital workforce with BSN or higher, 4 patients/nurse | | | | 8.54
| | | 60% of hospital workforce with BSN or higher, 6 patients/nurse | | | | 7.80
| | | 40% of hospital workforce with BSN or higher, 6 patients/nurse | | | | 8.50
| | | 20% of hospital workforce with BSN or higher, 6 patients/nurse | | | | 9.26
| | | 60% of hospital workforce with BSN or higher, 4 patients/nurse | | | | 7.18
| | | 20–29% of hospital workforce with BSN or higher, experience 14.4 years | | | | 9.40
| | | <20% of hospital workforce with BSN or higher, 14.9 years | | | | 10.20
| | | 20% of hospital workforce with BSN or higher, 8 patients/nurse | | | | 10.02
| | | >50% of hospital workforce with BSN or higher, experience 12.5 years | | | | 6.90
| | | 40–49% of hospital workforce with BSN or higher, experience 14.3 years | | | | 8.60
| | | 30–39% of hospital workforce with BSN or higher, experience 14.0 years | | | | 8.00
| | | 40% of hospital workforce with BSN or higher | | | | 9.22
| | | | | | | Complications
| | | 20–29% of hospital workforce with BSN or higher, experience 14.4 years | | | | 22.90
| | | <20% of hospital workforce with BSN or higher, 14.9 years | | | | 22.90
| | | >50% of hospital workforce with BSN or higher, experience 12.5 years | | | | 25.20
| | | 40–49% of hospital workforce with BSN or higher, experience 14.3 years | | | | 22.00
| | | 30–39% of hospital workforce with BSN or higher, experience 14.0 years | | | | 22.80
| | | | | | | Failure to rescue
| | | Increase by 1 year in nurse experience | | | | 1.01 | 0.96 | 1.03
| | | 10% increase in nurses with BSN degree | | | | 0.95 | 0.91 | 0.99
Blegen^73^ | Hospitals | 11 | | | | | Falls, rate per 100 patien days
The number of patient falls on the unit in quarter/1,000patient days, The proportion of RNs on the unit with BSN education, the proportion of RNs on the unit with more than 5 years experience or the average years of nursing experience of RNs on the unit | Unit | Combined | Increase by 1 year in RN experience in unit | | | | -0.04
| Patients | Combined | Increase by 1% in proportion of RN with BSN | | | | 0.01
| | | Increase by 1% in proportion of RN with BSN | | | | -0.01
| | | Increase by 1% in proportion of RN with experience >5 years | | | | -0.01
| | | Nurse hours | RN hours | % BSN
| | | 10.7 | 7.704 | 47.00 | | 0.27 ± 0.28
Langemo^33^ | Hospitals | 6 | Nurse hours | RN hours | % BSN | Experience | Pressure ulcers, rate %
Any lesion which is caused by unrelieved pressure that results in damage to underlying tissues, unplanned descent to the floor recorded in incidence reports | Unit | ICU | 10.9 | 5.42 | 59.5 | 11.0 | 8.6
| Patients | Medical
| Age | 61.9
| Sex | 41
Marcin^3^ | Hospitals | 1 | | | | | Relative risk
Extubation - displacement of the endotracheal tube from the trachea by either the patient (self-extubation) or unplanned by medical personnel (e.g., when positioning a patient for a radiograph or procedure), The number of years of clinical experience in the PICU calculated from the time of starting work in the PICU to the middle of the study period | Unit | ICU | 1:2 nurse/patient ratio, experience 7.8 years | | | | 4.24 | 1.00 | 19.10
| Patients | Combined | 1:1 nurse/patient ratio, experience 7.0 years | | | | 1.00 | 1.00 | 1.00
| Age | 3.3 | 7.8 years of nurse experience in ICU | | | | 1.02 | 0.96 | 1.08
| | | 7 years of nurse experience in ICU | | | | 1.00 | 1.00 | 1.00
Mark^80^ | Hospitals | 64 | % RN | % BSN | | | Falls, rate % ± SD
Number of incidents per 1,000 acuity-adjusted patient days; average highest educational level attained by nurses on the unit; the average years of experience in nursing for nurses on the unit | Unit | Combined | 58 | 21.00 | | | 0.75 ± 0.09
| Patients | Medical
Sovie^71^ | Hospitals | 29 | | BS | Years | | UTI, rate % ± SD
Nosocomial urinary tract infection (not present at admission or within 72 hours after); the number of infections / number of patients discharged * 100 at hospital level; any fall or slip in which a patient came to rest unintentionally on the floor; the ratio of the number of falls in a unit (or area) to the number of patient days * 1,000; % of nurses with BSN; nursing experience in years | Unit | Combined | 1997 | 53.00 | 10.9 | | 2.64 ± 1.67
| Patients | Combined | 1998 | 52.70 | 11.2 | | 2.02 ± 1.43
| Medical units | | 1997 | 53.00 | 10.9 | | 2.17 ± 2.49
| Medical units | | 1998 | 52.70 | 11.2 | | 2.61 ± 2.56
| Surgical units | | 1997 | 53.00 | 10.9 | | 1.87 ± 2.29
| Surgical units | | 1998 | 52.70 | 11.2 | | 2.45 ± 2.24
| | | | BS | Years | | Falls, rate % ± SD
| Medical units | | 1997 | 53.00 | 10.9 | | 2.88 ± 1.20
| Medical units | | 1998 | 52.70 | 11.2 | | 2.95 ± 0.91
| Surgical units | | 1997 | 53.00 | 10.9 | | 3.97 ± 2.10
| Surgical units | | 1998 | 52.70 | 11.2 | | 4.11 ± 1.68
| | | | 53.00 | 10.9 | | 2.42 ± 1.41
| | | | 52.70 | 11.2 | | 2.69 ± 1.19
| | | | BS | Years | | Pressure ulcers, rate % ± SD
| | | 1997 | 53.00 | 10.9 | | 3.53 ± 1.82
| | | 1998 | 52.70 | 11.2 | | 3.14 ± 2.63
| Medical units | | 1997 | 53.00 | 10.9 | | 2.61 ± 2.56
| Medical units | | 1998 | 52.70 | 11.2 | | 2.23 ± 1.94
| Surgical units | | 1997 | 53.00 | 10.9 | | 2.68 ± 2.22
| Surgical units | | 1998 | 52.70 | 11.2 | | 1.88 ± 1.33

BSN = Bachelor of Science in Nursing' ICU = Intensive Care Unit; PICU = Pediatric Intensive Car Unit; RN = Registered Nurse; SD = Standard Deviation

Table G19 The association between nurse characteristics and patient outcomes

Author, Definition of Nurse Characteristics and Patient Outcomes | Unit, Number of Nurses, % of Whites, % of Females | | | | | Nurse Categories | | | Patient Outcomes
Aiken^4^ | | | | | | % of reported | | | Patient satisfaction with nursing care
Patient survey; patients satisfaction with nurse care in unit, nurses survey; burnout scale not reported on the article, nurses autonomy subscale | | | | | | Burnout | Adequate autonomy | | Scores ± SD
| | | | | | 26.73 | 70.8 | | 60.06 ± 8.09
| | | | | | 21.48 | 75.45 | | 64.41 ± 8.18
| | | | | | 21.9 | 84.8 | | 67.85 ± 9.08
Dugan^17^ | Unit | Nurses | | | | % reported stress | | | Falls, rate %
Incident reports; the number of reported patient falls occurred monthly during the study period; nurses survey to measure stress: a manifestation, evidences by behavioral, physical, and personal changes that were perceived by staff nurses and measured by the Stress Contunuum Scale (10 max stress) and Stress Survey Scores (max 268) | Combined | 293 | | | | 20 | | | 0.6
| | | | | | 45.5 | | | 1
| | | | | | 53 | | | 1.1
| | | | | | 58 | | | 1.6
| | | | | | 63 | | | 1.8
| | | | | | 68 | | | 2.1
| | | | | | 85.5 | | | 2.2
Estabrooks^50^ | Unit | Combined | | | | % satisfied | % adequate autonomy | | Relative risk of death, 95% CI
Hospital Inpatient Database, Alberta Health Care Insurance Plan Registry (AHCIPR) was linked to identify persons who died within 30 days of admission. Survey of RN (Alberta Association of Registered Nurses registry) working in acute care hospitals. Reponses for the Q “On the whole, how satisfied are you with your job?”: 1. very dissatisfied; 2. a little dissatisfied; 3. moderately satisfied; 4. very satisfied); Q.“ Freedom to make important patient care and work decisions”. Responses:1. Strongly disagree; 2. Somewhat disagree; 3. Somewhat agree; 4. strongly agree | Nurses | 4,799 | | | | 60.125 | | | 1 | 1 | 1
| | | | | | 77.5 | | | 0.85 | 0.47 | 1.55
| | | | | | | 55.375 | | 1 | 1 | 1
| | | | | | | 69.25 | | 0.79 | 0.37 | 1.66
Halm^51^ | Unit | Surgical | | | | % Burnout | % Satisfied | % Stress | Death rate %
The hospital's data warehouse with patient's discharges; deaths within 30 days of admission, death following complications within 30 days). Survey of 140 staff nurses (42% response rate); Maslach Burnout Inventory Manual (max 6 scores) with 3 subscales of burnout: emotional exhaustion; depersonalization; personal accomplishment (feelings of competence and successful achievement in one's work), overall rating on a simple 4-point Likert scale, ranging from 1 (very dissatisfied) to 4 (very satisfied) and the likelihood to leave current position within the next 12 months, the 22-item Human Services Survey from the Maslach Burnout Inventory Manual to measure emotional exhaustion | Nurses | 140 | | | | 25 | 70 | 25 | 1.2
| % females | 96.4
Mark^80^ | Unit | Medical | | | | Turnover | Satisfaction | Adequacy | Length of stay, days ± SD
The hospital's incident reporting system and patient survey; total patient days divided by the number of discharges. Patients' satisfaction with nursing care; perceptions of the courtesy of the nursing staff; the ability of the doctors, nurses, and other staff to work together; their satisfaction with pain relief; and their level of comfort sharing concerns with nurses. Number of falls per 1,000 acuity-adjusted patient days. Administrative hospital data, nursing survey. Turnover as a ratio of the number of nurses who left during the period divided by the number of nurses employed at the end of the year; global satisfaction in the job (alpha = .84, a single factor explained 68% of the variance). Adequacy - the extent to which nurses on the unit felt free to engage in activities such as consulting with others about complex care problems, influencing standards of care, and acting on their own decisions related to caregiving. Availability of support services was evaluated with a 27-item, 3-point checklist 24 in which staff nurses (n = 1,682) indicated whether a variety of support services was available, not available, or inconsistently available (alpha =.85) | Nurses | 1,682 | | | | 17 | 54.25 | 47 | 5.31 ± 1.47
| | | | | | | | | % if satisfied with nurse care ± SD
| | | | | | Support | Coordination | Autonomy | 78.33 ± 7.5
| | | | | | 50 | 50.33 | 73.2 | Falls, rate/100 patient days ± SD
| | | | | | | | | 0.12 ± 0.09
Minnick^19^ | | | | | | Increase in nurse job satisfaction by 10 scores | | | Patient satisfaction with pain management
Patient survey with interviews within 26 days of hospital discharge using the Computer-Assisted Telephone Interview (CATI) system, reports about assistance with pain management. Unit labor quantity data and nurses survey: Manager's Ability to Involve Staff in Practice Self-Governance. This variable is the average of the unit's RNs' rating (on a 5 point scale with 5 as most favorable) of the manager's ability to involve staff in setting patient care standards; the pay (score range 6–42), professional status (score 7–49), and task requirement attitude (score 6–42) scales (Stamps and Piedmonte) and the benefit (3 score 3–21) and schedule (score 4–28) scales (Minnick and Roberts); Central Hospital Support Systems Adequacy-the average of a RNs' ratings (on a 1 to 5 scale with 1 as least favorable) of hospital-wide support systems | | | | | | | | | Relative risk
| | | | | | | | | 1.22
Ridge^25^ | Unit | Surgical | | | | | | | Length of stay, days ± SD
Patient survey 2 weeks after discharge with computerized phone interview system; length of stay in hospital; patient satisfaction measured with Likert-type 5 points scale from strongly disagree to agree for overall nursing care, pain management, overall hospital care. Hospital administrative database, finance reports, HCIA database, unit nurse manager reports; turnover - number of individual staff hired annually/total number of staff; staffing adequacy - RN worked hours/RN target hours | Nurses | 22 | | | | % Turnover | 23.2 | | 4.1 ± 3.9
| % Females | 92 | | | | | | | % satisfied with nurse care
| | | | | | % Turnover | 23.2 | | 88
| | | | | | % Vacancy | 9 | | 87.2
| | | | | | | | | % satisfied with pain management
| | | | | | % Turnover | 23.2 | | 83.6 ± 16.6
| | | | | | % Vacancy | 9 | | 83.2 ± 3.828
Seago^8^ | | | | | | % satisfied | Coordination | Autonomy | Relative risk of pressure ulcer
Hospital incidence reports database at three time periods: time 1-third quarter fiscal year 1996 (FY96); time 2-second quarter fiscal year 1997 (FY97); and time 3-third quarter fiscal year 1997 (FY97) in three different cross-sections of patients, Patient satisfaction measured with Likert scale; the proportion of pressure ulcers per patient day; the proportion of falls per patient day. The nursing staffing system (ANSOS) and nursing survey at three time periods: time 1-third quarter fiscal year 1996 (FY96); time 2-second quarter fiscal year 1997 (FY97); and time 3-third quarter fiscal year 1997 (FY97). | | | | | | 71 | | 94.40 | Not significant
| | | | | | 69 | 62.13 | 93.60
| | | | | | 59 | 62.13 | 92.20
| | | | | | % satisfied | Coordination | Autonomy | Falls | Pressure ulcer
| | | | | | 71 | | 94.40 | 0.29 | 0.24
| | | | | | 69 | 62.13 | 93.60 | 0.27 | 0.18
| | | | | | 59 | 62.13 | 92.20 | 0.23 | 0.29
Sochalski^45^ | Unit | Combined | | | | Perceived quality of care, % satisfied | | | Adverse events
MedPAR dataset of hospital discharges; reported by RN frequency of medication errors and patients falls from “never in the past year” (score 1) to “occur frequently” (score 10). survey of RNs, the survey question “In general, how would you describe the quality of nursing care delivered to patients your unit on your last shift?,” and for which a 4-category response was available (poor, fair, good, excellent) | Nurses | 8,670 | | | | | | | Relative risk, 95%
| | | | | | 10 | | | 1.00 | 1.00 | 1.00
| | | | | | 20 | | | 0.92 | 0.91 | 0.92
| | | | | | 30 | | | 0.88 | 0.87 | 0.88
| | | | | | 40 | | | 0.84 | 0.84 | 0.85
Sovie^71^ | Unit | Nurses | Age | Sex | Race | Management | Quality | Autonomy | % satisfied with nurse care ± SD
Incident reports, patient survey 4 years after restructuring and reengineering in hospitals. The Picker Institute Patient Satisfaction Survey; the Press, Ganey Patient Satisfaction Survey. Dimensions: Pain management; Education; Attention to needs; Nursing care; Preparation for discharge. Nosocomial (not present at admission or within 72 hours after); the number of infections / number of patients discharged * 100 at hospital level; any fall or slip in which a patient came to rest unintentionally on the floor; the ratio of the number of falls in a unit (or area) to the number of patient days * 1,000. the MECON-PEERx Operations Benchmarking Database Reports; the office of the chief nurse executives; nursing survey; achieving quality patient outcomes; ranged from 1 = strongly disagree to 5 = strongly agree | Medical | 347 | 36.9 | 92.8 | 79.6 | 66.8 | 74.4 | 47 | 83.6 ± 5.89
| Medical | 298 | 36.7 | 92.3 | 82.4 | 66.8 | 72 | 47.25 | 83.32 ± 5.67
| Surgical | 289 | 36.9 | 92.8 | 79.6 | 65.6 | 74 | 49 | 82.82 ± 6.54
| Surgical | 239 | 36.7 | 92.3 | 82.4 | 65.6 | 72.2 | 49.25 | 84.9 ± 6.99
| | | | | | Management | Quality | Autonomy | % satisfied with pain management ± SD
| | | | | | 66.8 | 74.4 | 47 | 83.04 ± 9.92
| | | | | | 66.8 | 72 | 47.25 | 83.31 ± 7.82
| | | | | | 65.6 | 74 | 49 | 85.55 ± 6.77
| | | | | | 65.6 | 72.2 | 49.25 | 85.92 ± 4.63
Vahey^44^ | Unit | Specialized | | | | Burnout | Support | Stress | Patient satisfaction, relative risk
Conducted cross-sectional surveys of patients (621) satisfaction with nursing care using the La Monica-Oberst Patient Satisfaction Scale (LOPSS), 4 points scale. Conducted cross-sectional surveys of nurses (N=820) with the Maslach Burnout Inventory (MBI);7 point scales, staffing adequacy, administrative support, 4 scores, emotional exhaustion, 7 point scales | Nurses | 621 | | | | 80 | 20 | 20
| Age | 34.6 | | | | | | | Reference
| Sex | 7.4 | | | | Support | 80 | | 1.49 | 1.06 | 2.09
| Race | 48.8 | | | | Burnout | 20 | | 2.37 | 1.37 | 4.12
| | | | | | Stress | 80 | | 0.51 | 0.3 | 0.87
Zidek^85^ | Unit | Combined | | | | Turnover % | | | Rate, %
Patient records and chart audits, individuals length of stay in the hospital, new incidence of skin breakdown acquired over the course of the hospital stay, number of reported unplanned descent to the floor during the course of the hospital stay, administrative records, quarterly turnover rate in % | Nurses | 1,759 | | | | | | | Falls | Pressure ulcers
| | | | | | 10.67 | | | 2.79 | 0.68
| | | | | | 12.04 | | | 1.58 | 0.67
| | | | | | 13.16 | | | 2.95 | 0.72

CI = Confidence Interval; RN = Registered Nurse; SD = Standard Deviation

Table G20 The evidence of the association between nurse staffing and patient satisfaction

Author, Measure of Patient Satisfaction | Sample Size, Unit, Patients | | Nurse Categories | | | Patient Satisfaction
Aiken^5^ | Size | 1,205 | | | | Relative risk of being satisfied
Twenty-one item scale based in part on the LaMonica/Oberst Patient Satisfaction Scale (LOPSS) | Unit | Combined | Increase by 1 RN | | | 3.0 | 0.0 | 343.8
| Patients | Medical | Nurse control over practice setting | | | 1.4 | 1.4 | 2.5
| | | Dedicated AIDS units | | | 3.6 | 0.3 | 41.3
| | | AIDS hosp-scattered bed units | | | 0.1 | 0.0 | 2.0
| | | Conventional scattered bed units | | | 1.0 | 1.0 | 1.0
Aiken^4^ | Size | 1,205 | Conventional general medical unit, | | | % satisfied | Scores ± SD
Patients satisfaction | Unit | Spec | Non-magnet hospital | | | 74% | 7.42 ± 2.3
with nurse care in unit | Patients | Medical | Specialized AIDS unit, non-magnet hospital | | | 83% | 8.29 ± 1.7
| | | General medical unit, magnet hospital | | | 85% | 8.53 ± 1.9
Barkell^77^ | Size | 96 | | | | % Satisfied ± SD
Patient satisfaction: the patient's perception of pain, and the frequency of documentation of pain scores measured by scores on the Parkside Patient Satisfaction Survey | Unit | Surgical | Team nursing model with UAP assisting RNs in delivery of patient care (lower proportion of RN = 65.7%) | | | 83.4 ± 13
| Patients | Surgical | Total patient care model (higher proportion of RNs = 78.5%) | | | 84.6± 13
Blegen^59^ | Size | 42 | | | | Rate of complains/100 patient days ± SD
| Unit | Combined | Increase by 1% in proportion of RNs | | | 0.46 ± 1.85
The number of patient complaints standardized as a rate per 1,000 patient days. | Patients | Combined | Proportion of RNs >87.5% | | | 0.04 ± 0.07
| | | Increase by 1 hour in total nursing hours | | | 0.02 ± 0.60
| | | 10.74 nurse hours/patient day | | | 0.22
Bolton^42^ | Size | 113 | Nurse hours/patient day | 7.9 hours | | % Satisfied with nurse care ± SD
The standardized Picker Institute inpatient questionnaire including respect patients' values and preferences, coordination of care; information and education; pain management; emotional support, and transition and continuity to the home or community | Unit | Combined | RN hours/patient day | 4.4 hours | | 86 ± 5%
| Patients | Combined | % RN | 56%
Langemo^33^ | Size | 942 | Nurse Hours/patient day | 10.9 | | Score for satisfaction with pain management
Patient's satisfaction with nursing care and opinions of overall hospital care, pain management, and education from 42-item Patient Opinions of Nursing Care Survey | Unit | ICU | RN hours/patient day | 5.42 | | 0.913
| Patients | Medical | % BSN | 59.5
Mark^80^ | Size | 1,326 | % RN | 58 | | % Satisfied with care
Patients' satisfaction with nursing care; perceptions of the courtesy of the nursing staff; ability of the doctors, nurses, and other staff to work together; their satisfaction with pain relief; and their level of comfort sharing concerns with nurses | Unit | Combined | % BSN | 21.00 | | 78.33%
| Patients | Medical | | | | Score of satisfaction with nurse care ± SD
| | | | | | 4.7 ± 0.45
Minnick^19^ | Size | 2,051 | | | | Relative risk of being satisfied with care -
Reports about assistance with pain management; patient teaching was defined as reports of instruction that patients received about signs and symptoms that needed attention after hospital discharge | Unit | Medical | Patient satisfaction in units with >54% of RN with BSN | | | 1.48
| Patients | Medical | vs. lower % of RN with BSN | | | Relative risk of being satisfied with pain management - Not significant
Potter^40^ | Size | 32 | Nurse hours/patient day | % RN | | % Satisfied with nurse care
Eight Visual Analog Scale and post discharge (48 hour) satisfaction with seven satisfaction measures including communication, respect, coordination of care, nursing care, discharge process, advocating, and patient compassionate care (5 point Likert scale) | Unit | ICU | 3.1 | 53.8 | | 75.4
| Patients | Medical | 2.9 | 55.4 | | 74.2
| | | 3 | 56.2 | | 77.3
| | | 3.1 | 57.1 | | 75.6
Ridge^25^ | Size | 1,076 | % BSN | Experience | | Satisfaction with nurse are ± SD
Likert-type 5-point scale from strongly disagree to agree for overall nursing care, pain management, and overall hospital care | Unit | Surgical | 44 | 8.70 | | 4.3 ± 0.76
| Patients | Surgical | Nurse hours/patient day | % RN
| | | 6.9 | 67 | | 4.29 ± 0.14
| | | Increase by
| | | 1 hour in LPN hours | | | 0.65
| | | Increase by
| | | 1% in RN | | | 0.893
| | | | | | % satisfied
| | | % BSN | Experience
| | | 44 | 8.70 | | 88%
| | | Nurse hours/patient day | % RN
| | | 6.9 | 67 | | 87.2%
| | | | | | % satisfied with pain management
| | | % BSN | Experience
| | | 44 | 8.70 | | 84 ± 7
| | | Nurse hours/patient day | % RN
| | | 6.9 | 67 | | 83 ± 3.8
Ritter-Teitel^69^ | Size | 56 | | | | % satisfied with nurse care ± SD
satisfaction with nursing care and pain management during hospital stay (max 100 scores) | Unit | Combined | Nurse hours/patient day | % RN
| Patients | Combined | 9.3 | 56.15 | | 82.68 ± 6.08%
| | | 9.58 | 56.4 | | 84.38 ± 6.31%
| | | 9.19 | 56.79 | | 83.29 ± 6.08%
| | | 9.79 | 56.77 | | 83.82 ± 5.67%
| | | 9.41 | 56.79 | | 82.08 ± 6.31%
| | | 9.36 | 56.77 | | 84.9 ± 6.99%
| | | Increase by 1 hour in RN hours | | | 1.18 ± 4.17%
| | | Nurse hours/patient day | % RN | | % satisfied with pain management
| | | 9.3 | 56.15 | | 84.1 ± 8.73%
| | | 9.58 | 56.4 | | 84.6 ± 6.46%
| | | 9.19 | 56.79 | | 83.1 ± 10.2%
| | | 9.79 | 56.77 | | 83.3 ± 7.82%
| | | 9.41 | 56.79 | | 85.3 ± 6.87%
| | | 9.36 | 56.77 | | 85.9 ± 4.63%
| | | Increase by 1 hour in RN hours | | | 1.50 ± 4.08%
Seago^8^ | Size | 89,256 | Patient focused care | % RN | | Relative risk of being satisfied with nurse care
Patient satisfaction measured with Likert scale | Unit | Combined | Before | 63 | | Not significant
| Patients | Medical | After | 61.5 | | Not significant
| | | After | 62 | | Not significant
Seago^93^ | Size | 1,012 | Nurse hour | %RN | | % satisfied with pain management ± SD
Patient satisfaction measured with Likert scale | Unit | Combined | 8.1 | 75 | | 84.2 ± 3.5%
| Patients | Medical | 8.3 | 96 | | 89.3 ± 6.4%
| | | 7.49 | 72 | | 80.5 ± 6.7%
| | | Increase by 1 nurse hour | | | 2.44 ± 0.62
| | | Increase by 1% in RN | | | 13.6 ± 3.6
| | | Increase by 1 RN hour | | | 2 ± 2
Sovie^71^ | Size | 29 | Nurse hour | UAP hour | % BSN | % satisfied with nurse care ± SD
The Picker Institute Patient Satisfaction Survey; the Press, Ganey Patient Satisfaction Survey. Dimensions: pain management, education, Attention to needs, nursing care, preparation for discharge | Unit | Combined | 9.14 | 2.39 | 53.00 | 84 ± 5.9%
| Patients | Medical | 9.79 | 2.7 | 52.70 | 84 ± 5.7%
| | | 9.34 | 2.22 | 53.00 | 83 ± 6.5%
| | | 9.36 | 2.56 | 52.70 | 85 ± 7%
| | | Increase by 1 RN hour | | | 2.87
| | | Nurse hour | UAP hour | % BSN | % satisfied with pain management
| | | 9.14 | 2.39 | 53.00 | 83.04 ± 9.962
| | | 9.79 | 2.7 | 52.70 | 83.31 ± 7.862
| | | 9.34 | 2.22 | 53.00 | 85.55 ± 6.862
| Medical | | 9.36 | 2.56 | 52.70 | 85.92 ± 4.662
| Surgical | | Increase by 1 nurse hour | | | -2.3 ± 1
| | | Increase by 1 nurse hour | | | -1.4 ± 0.3
Tallier^83^ | Size | 2,897 | Nurse hours | % RN | | % satisfied
Patient opinion of care in hospital measured with Patient Satisfaction Survey (max 27 scores) | Unit | Combined | 5.8 | 57 | | 72%
| Patients | Medical | 5.7 | 60 | | 72%
| | | Nurse hours | RN hours
| | | 6.2 | 5.9 | | 72%
| | | 5.8 | 5.9 | | 72%
| | | 5.8 | 5.5 | | 72%
| | | 5.7 | 6.9 | | 77%
| | | 5.3 | 6.6 | | 77%
| | | 6.1 | 6.8 | | 77%

RN = registered nurse; UAP = unlicensed assistive personnel; BSN = Bachelor of Science in Nursing; SD = Standard deviation

Table G21 Research studies related to staffing ratios/hours/skill mix in acute care hospitals (not included in questions 1, 2, and 4)

Author, Year, Publication Type | Aim of the Study | Sample | Study Design and Method | Variables | Results
Systematic reviews
Lankshear ^96^ | Assesses the evidence for a relationship between the nursing workforce and patient outcomes in acute hospitals through a systematic review of the literature | 22 international studies between 1990 and 2004 | Systematic review of literature | Nurse staffing Patient outcomes | 22 studies relating nurse staffing to mortality, failure to rescue, and 7 common complications. Concluded that there is support that higher nurse staffing and RN skill mix are associated with improved patient outcomes. Noted that the effect size could not be estimated reliably. The association between nurse staffing and patient outcomes appears to show diminishing marginal returns.
Lang^97^ | Determine if peer-reviewed literature supports minimum nurse-patient ratios for acute care hospitals and whether nurse staffing is associated with patient, nurse employee, and hospital outcomes | 43 studies between 1980 and 2003 | Systematic review of literature | Nurse staffing Patient, nurse employee, and hospital outcomes | 43 studies relating nurse staffing to in-hospital adverse events (failure to rescue, inpatient mortality, pneumonia, urinary tract infection, pressure ulcers, shock); nurse outcomes (needle stick injuries, nurse burnout, nurse documentation, nurse satisfaction, absenteeism, assaults, and nurse professionalism), hospital outcomes (length of stay, financial outcomes, staffing models).
| | | | | Concluded there is probable relationships between nurse staffing and failure to rescue among surgical patients, inpatient mortality; limited evidence between nurse staffing and burnout, needle stick injuries, nurse documentation, hospital financial outcomes; statistically and clinically significant relationship between nurse staffing and length of stay. No support in the literature for specific, minimum nurse-patient ratios, especially in the absence of adjustments for skill and patient mix.
Externally imposed staffing policies (mandated patient ratios)
Seago^98^ | Examine the relationship between nurse staffing and owner type or specific corporate entity | Short-term general hospitals that reported in the California Office of Statewide Health Planning and Development's (OSHPD) Hospital Disclosure report from 1997-1999 | Descriptive cross-sectional design. | RN hours/patient day, RN-to-patient ratio, RN skill mix. | For profit hospitals and system had fewer RN productive hours for medical-surgical nursing, but when distinguished by rural or urban location, the relationship is no longer significant. The lower use of RNs in for profit systems is likely driven by one health system. More RN productive hours is predicted by more patient days, higher case mix index and higher technology scores.
| | | Secondary data analysis using data from the California OSHPD Hospital Disclosure report (1997-1998). | LVN, aide, and total hours/patient day, patient days, discharges, RN/LPN/NA wages, percent Medicaid, Medicare case mix, length of stay, technology index, rural/urban location, proprietary status for hospital and system
Donaldson^9^ | Examine the impact of mandated nurse-to-patient ratios on unit-level nurse staffing, the incidence and patient outcomes | California hospitals participating in the California Nursing Outcomes Coalition (CalNOC) | Descriptive, pre-post design | Nursing-care hours (RN, LVN, unlicensed productive hours); RN nursing care hours; LVN nursing care hours; non-RN and LVN caregiver care hours; contracted hours; skill mix; total patient days; patient falls incidence; hospital acquired pressure ulcer prevalence. | Mean total RN hours of care per patient day increased by 20.85 on medical-surgical units after implementation of mandated staffing ratios; total nursing hours increased by 7.4%. Number of patients per licensed nurse decreased post-implementation by 16% and the number of patients per RN decreased by 17.5%. No changes noted to step-down units; no changes in use of contract nurses. Changes were consistent across hospital size and hospital systems. There was no statistically significant change in the incidence of falls or the prevalence of hospital acquired pressure ulcers following implementation of the nurse-patient mandated ratios.
| | N = 68 hospitals and 268 patient care units | CalNOC data collected at the point of service in real time by hospitals using current staffing data as well as the three patient outcomes.
| | | Pre-ratio baseline: first 6 months (2 quarters) of 2002
| | | Post-ratio period: first 6 months (2 quarters) of 2004 following implementation of the licensed nurse-to-patient ratios
Hodge^99^ | Develop baseline data on the characteristics, number, and distribution of licensed caregivers in specific units of acute care hospitals in California and determine how staffing varies across different types of acute care hospitals. | Stratified random sample of general acute care hospitals in California. | Cross-sectional descriptive design. | Unit-related data: Duration of shifts, type of shifts, number of patients, nurses, unlicensed staff, admissions, discharges, patient care assignments, services provided by licensed nurses; experience, education, employment status and patient load of each nurse on duty on day of survey; staffing and skill mix data for all shift. | Diverse nursing staffs are present in California hospitals (e.g. education, experience, employment status). 50% of RNs on day shift have a baccalaureate degree. The proportion of RNs varied by type of unit ranging from 30% (subacute) to 84% (postpartum/delivery). Per diem and agency staff comprise more than 20% of the day shift staff for emergency departments and post-partum units. Nurses in academic medical centers and rural hospitals generally had fewer patients than did nurses in other hospital types.
| | N = 80 hospitals; | Investigator developed survey instrument which was administered by RN surveyors. Data collected from hospital administrators, nurse managers, direct care staff nurses.
| | 2,298 nurses
Studies with implications for staffing policies that were ineligible for meta-analysis
McGillis Hall^100^ | Evaluate the impact of different nurse staffing models selected patient outcomes. | 19 teaching hospitals in Ontario, Canada using adult medical-surgical and obstetric inpatients. | Repeated measure design | Functional health outcomes (Functional Independence Measure; SF-36); | A higher proportion of regulated nursing staff (Canadian term for RN) was associated with better FIM scores and better social function scores at hospital discharge. Nursing staff mix (higher proportion of RN/RPNs) was a significant predictor of functional independence, pain, social functioning, and patient satisfaction with obstetric care, after other potential determinants of health outcomes were controlled.
| | N at admission: = 2,046 | Data collected from patients using a variety of instruments and data also collected by data collectors. Staffing data provided by nurse managers. Patient data collected at admission, discharge, and 6 weeks after discharge. | Pain (Brief Pain Inventory Short Form);
| | N at discharge = 1,811 | | Patient perception of nursing care (Patient Judgment of Hospital Quality Questionnaire);
| | N at 6 weeks post discharge = 1,483 | | Mix of staff on patient care units
| | | | Continuity of patient care assignments
McGillis Hall^101^ | Determine if nurse staffing models and nursing demographic variables explain variation in quality outcomes. Determine if the influence of the nurse staffing model on the quality outcomes varies by type of care delivery model. | 77 adult medical, surgical and obstetrical patient care units in 19 urban teaching hospitals in Ontario, Canada. | Descriptive correlational design | Nurse staff mix; | There was a significant positive relationship between all nursing staff models with an all-RN staff and nurses' perceptions of quality of care. A staff mix of RNs and RPNs had a statistically significant negative influence on the use of individualized approaches for the coordination of care and overall unit communication, whereas the opposite was true for staff models that had both regulated and unregulated workers (RNs, RPNs, and URWs).
| | 1,116 nurses | Nurse staffing data collected through questionnaires to unit managers; | Nursing care delivery models (total patient care, team nursing, primary nursing);
| | | Surveys distributed to RNs | Nurses' perceptions of quality of care;
| | | | Unit communication and coordination
McGillis Hall^101^ | Examine the effect of different nurse staffing models on costs and patient outcomes. | 77 adult medical, surgical and obstetrical patient care units in 19 urban teaching hospitals in Ontario, Canada. | Descriptive correlational design | Four types of nursing staff mix (RN and RPN; all RN; proportion of URW to regulated workers (RNs and RPNs); RN/RPN//URW staff mix. | Lower proportions of professional nursing staff (RNs/RPNs) was related to higher number of medication errors and wound infections.
| | | | Patient safety outcomes (patient falls, medication errors, wound infections, urinary tract infections);
| | | | Case nursing hours (measure of nursing resource use);
| | | | Patient complexity.

FIM = Functional independence measure; RN = Registered Nurse; RPN = Registered Practical Nurse; URW = unregulated workers

Table G22 Research studies related to shift work of nurses (types of shifts; length of shifts)

Author, Year, Publication Type | Aim of the Study | Sample | Study Design and Method | Variables | Results
Skipper^102^ | Examine the relationship between the physical health and mental depression of nurse shift workers and relevant social and work related variables | 482 RNs working shifts in five hospitals in the southeastern region of the U.S. | Descriptive survey | Physical health scale (e.g. quantity and quality of sleep; physical related problems); | When controlling for the background variables, there was no relationship between difficulty in family relations and shift work or informal social participation and shift work. Shift work was associated with voluntary organization participation (most prevalent in the day shift nurses), hours spent in solitary activities (most prevalent in the evening shift nurses), and job performance (lowest perception of job performance by nurses working rotating shifts). Job related stress and shift work were significantly related (nurses working rotating shifts experienced the highest stress). No association was found between shift work and physical health or depression. There was an association with shift type and quality and quantity of sleep. Night shift nurses received the least amount of sleep and had the most trouble sleeping.
| | | Distributed questionnaires through the nurses' hospital | Depression measured by the CES-D scale;
| | | | Family relation;
| | | | Informal social participation (e.g. frequency visiting friends, relatives);
| | | | Job performance measured by the Six-Dimension Scale of Nursing Performance;
| | | | Job related stress scale.
| | | | Covariates: age, marital status, number of children under age 6, education, work experiences, shift preferences, etc.
Gold^103^ | Examine the impact of work schedule on the sleep schedule, sleepiness, and accident rates of female nurses in a Massachusetts hospital based on a self-administered questionnaire administered in 1986. | 687 RNs and LPNs employed in one hospital | Cross-sectional | Nurses' record of shifts worked for two weeks and sleep and wake times for the same two weeks. Nurses' self-assessments of quality of sleep, sleepiness, automobile accidents or other injuries, medication, and procedural errors. | Night nurses and nurses that rotated shifts (rotators) had the highest odds of poorer quality of sleep and using sleeping medications. The odds of reporting any accidents or errors were higher for rotators than nurses working days or evenings.
| | | Self-administered questionnaire in which nurses kept records for two weeks regarding their work schedules and sleep patterns
Ruggiero^104^ | To determine variables contributing to chronic fatigue in critical care nurses and to determine if there are differences between critical care nurses working day and night shifts in regards to fatigue, depression anxiety, and quality of sleep. | Subjects were members of the American Association of Critical Care Nurses. | Descriptive, survey; two-group comparison | Chronic shift worker fatigue measured by the Standard Shiftwork Index Chronic Fatigue Scale; | Permanent night nurses had significantly more depression and poorer global sleep quality; no significant differences between day and night shift nurses in chronic fatigue or anxiety. 46% of the variance in chronic fatigue was explained by depression and global sleep quality.
| | 67 worked the day shift and 75 worked the night shift. | Mailed survey | Global sleep quality measured by the Pittsburgh Sleep Quality Index; Depression measured with the Beck Depresssion Inventory-II; Anxiety measured with the Beck Anxiety Inventory. Demographic data obtained regarding age, gender, shift, and schedule details.
Rogers^105^ | To examine the work patterns of hospital staff nurses and determine if there is a relationship between hours worked and frequency of errors. | 393 RNs who were members of the American Nurses Association. Unit of analysis was number of shifts worked (5,317) over a 28-day reporting period. | Descriptive; survey | Nurse-reported data regarding hours worked (scheduled and actual), time of day worked, overtime, days off, sleep/wake patterns, mood, caffeine intake, errors and near errors. | Participants worked, on average, 55 minutes longer than scheduled each day. Almost 2/3 of the nurses worked overtime 10 or more times during the 28-day period. One quarter of the respondents worked more than 50 hours per week for two or more weeks of the 2-day period. More than 25% of nurses reported working mandatory overtime at least once during the 28 days. There were 199 reported errors and 213 reported near errors. More than half of the errors and near errors were medication related. The likelihood of making an error increased with longer work hours and was three times higher when nurses worked shifts lasting 12.5 hours or more (OR = 3.29). Working overtime increased the odds of making at least one error, regardless of how long the shift was originally scheduled (OR = 2.06). The risk of making errors increases when nurses work overtime after longer shifts. Age, hospital size, or type of unit did not have an effect on errors or near errors.
| | | Mailed log book
Trinkoff^106^ | To describe the nature and prevalence of extended work schedules of nurses | 2,273 randomly selected RNs who participated in the NIOSH Nurses Worklife and Health Study | Cross-sectional survey | Work-schedule variables derived from the Standard Shiftwork Index hours worked per day and week; weekends worked/ month; days worked in a row; work more than one job; how off shifts are organized). | When compared to the entire sample, hospital staff nurses were most likely to work 12 or more hours/day, but half as likely to work 6–7 days/week. They were more likely to work off-shifts.
| | | Mailed survey | Mandatory overtime requirement. Demographic characteristics. | Similarly, nurses with more than one job worked more hours per week as well as more consecutive days. Nurses 50 years old and older were less likely to work long days and were the group that tended to work days only. 17% of the sample were required to work mandatory overtime. On call requirements were more prevalent among hospital staff nurses.
Havlovic^107^ | Examine the impact of work schedule congruence on personal life interference and service to patients; examine the combined effects of the rotating shift and the compressed work week | 520 randomly selected nurses in British Columbia that returned the mailed survey. Nurses were members of the nurses' union. | Descriptive correlational | Subscales from the Comprehensive Work-Schedule Survey (CWSS): Current Schedule Interference with Activities with Family & Friends; General Affect Toward Current Schedule; Service to External Constituents; Interference with Rest and Sleep. | Over 40% of nurses worked a rotating compressed work week schedule and 47% were working both their preferred shift and work week. Nurses that worked their preferred shift, but not their preferred week reported lower interference with family and friends, a positive general affect toward their schedule and less interference with sleep and rest. Work week congruence was not significant for any of the dependent variables. Nurses with a rotating compressed work week schedule experienced more interference with their personal lives, including rest patterns as well as family and social activities, and most were dissatisfied with their schedules and reported lower quality service to their patients.
| | | Mailed survey | Nurse characteristics included full/part time status, shift and schedule currently working and preferred. | Nurses who worked in larger hospitals (hospital factor) experienced greater interference of their work schedules with rest and sleep.
| | | | | Nurses that worked a longer time in a hospital (nurse factors) were less likely to report negative consequences of their work schedule.
Hoffman^108^ | Examine the variation in role stress and career satisfaction among hospital-based RNs by work shift length | Probability sample of 208 nurses who were members of the Michigan Nurses Association (50.4% response rate). | Descriptive comparative study | Role stress (Nursing Stress Scale) | No significant demographic differences between groups. RNs working 12 hour shifts experienced significantly higher levels of stress than those working 8-hour shifts; however, when controlling for nursing experience, similar levels of stress were found in both groups. Both groups were similar in regards to work satisfaction and the only differences in career satisfaction was that 8-hour RNs were significantly more satisfied with their current salary and 12-hour RNs derived more satisfaction from professional status.
| | N = 99 working predominantly 8-hour shift pattern; | Mailed questionnaires | Career satisfaction (Index of Work Satisfaction)
| | N = 105 working 12 hours shifts or a combination of 8, 10, and 12 hour shifts.

Table G23 Research studies related to use of agency/contract nursing staff in hospitals

Author, Year, Publication Type | Aim of the Study | Sample | Study Design and Method | Variables | Results
Hughes^109^ | Examine differences between agency and hospital nurses as related to recruitment, retention, and compensation. | 6,895 staff nurses responding to a survey sent by a state's Board of Nursing. | Descriptive; survey | Items from the survey regarding nurses' non-salary compensation package; issues related to recruitment and retention; conditions for willingness or need to increase current work hours. | Hospital nurses were more likely to receive pension plans, health and dental insurance, reimbursement for continuing education and tuition; child care services, and parking. Agency nurses received significantly higher hourly wages. Agency nurses were more likely to indicate that improved benefits would be an incentive to change jobs whereas hospital nurses were more likely to change jobs for increased autonomy. There was no difference between the groups in terms of changing jobs for improved scheduling, specialty practice, or salary. Half of all nurses in the study indicated they would leave their job for increased salary, but there was no difference between agency and hospital nurses. While most nurses were willing to increase their work hours for incentives such as salary increases, child care services, improve relations at work, improved scheduling, promotion opportunities, and improved patient care, hospital nurses were more likely to increase their workload for those incentives.
| | Primary employer a staffing agency: n=3,360 | Survey sent out with nurses' renewal of their license.
| | Primary employer a hospital: n=3,535 (randomly selected)
Hughes^110^ | Examine the sociodemographic characteristics of agency and hospital staff nurses and determine if there are differences in their work schedules and clinical practice. | 6,895 staff nurses responding to a survey sent by a state's Board of Nursing. | Descriptive; survey | Items from the survey regarding nurses' work schedules, practice activities/use of clinical skills, and perception of nurses regarding opportunities in their jobs to use the clinical skills. | Agency nurses were more likely to be male, unmarried, and members of minority groups, and have a master's degree, whereas hospital nurses were more likely to be enrolled in an education program at least part time. Agency nurses were more likely to work evening and night shifts as well as weekend shifts and fewer hours per week than hospital employed nurses. There were significant differences in the clinical practice of both groups. Hospital nurses reported performing more physical and psychological examinations on a greater percentage of their patients. Agency nurses evaluated clinical outcomes, developed nursing diagnoses and therapeutic plans for more patients. Agency nurses differed significantly from hospital nurses in regard to reporting they had a very or fairly good chance to use their skills; whereas hospital nurses felt they had little or no chance. Agency nurses used computers to a significantly lesser extent than hospital nurses.
| | Primary employer a staffing agency: n=3,360 | Survey sent out with nurses' renewal of their license.
| | Primary employer a hospital: n=3,535 (randomly selected)
Warren^111^ | To examine nurse managers' use, perceptions of costs, benefits and quality of care of supplemental nursing staff. | 89 nurses in management positions in two urban and two rural hospitals randomly selected from 32 hospitals in a southeastern state. | Descriptive; survey | Investigator developed questionnaire that queried the use of supplemental staffing and perceptions of the quality of care provided by supplemental staff nurses. | While the majority of nurse managers believed that the use of supplemental nurses would increase in the future, they did not believe it was a cost effective practice. 59 of the 89 respondents had used supplemental staffing. The primary reason for non-use was perception of poor quality care. Those that had used supplemental staff indicated that it resulted in reduction of overtime and workload for nursing staff as well as covering for weekends, night shifts, absenteeism, and vacations.
| | | Mailed questionnaire | Supplemental staff could be either agency-based or hospital-pool. | Managers' perceptions of quality care of supplemental staff did not differ for hospital pool supplemental staff versus agency staff.
Strzalka^112^ | To compare float pool nurses (FPN), agency nurses (AN), and unit-hired nurses (UHN) on selected clinical indicators. | Over the course of 8 months, medical records associated with nurses on one nursing unit from each of the three groups were reviewed. 150 records were reviewed—50 from each group. | Descriptive comparative design | Two clinical aspects of care were monitored: patient safety measures to prevent falls and assessment and management of bowel function. | Float pool nurses had the highest rate of documentation, followed by agency nurses and then unit-hired nurses. There were statistically significant differences between FPNs and UHNs for 3 of 5 indicators to prevent falls and a statistically significant difference between ANs and FPNs on 1 of 3 indicators for bowel management and between UHNs and ANs and FPNs on 1 of 3 indicators for bowel management.
| | Study was conducted in a large teaching hospital in the southeastern U.S. | | Patient flow sheets in the patients' medical records were reviewed.
Bloom^18^ | Assess the effect of four nurse staffing patterns on the efficiency of patient care delivery: RNs from temporary agencies; part-time career RNs; RN rich skill mix; and organizationally experienced RNs | Random sample of 1,222 hospitals selected; 583 hospitals in sample | Descriptive correlational | Nursing Personnel Survey which includes information about full and part time staff, use of agency staff, RN mix and experience. Merged data from the American Hospital Association's annual survey of hospitals and the Area Resource File. | Use of part-time staff was related to lower personnel and hospital costs; skill mix was unrelated to personnel and hospital costs; use of temporary RNs was not related to personnel costs but was related to higher hospital operating costs.
| | | | Hospital efficiency was the dependent variable and measured as personnel costs per adjusted admission and total non-personnel operating costs per adjusted hospital admission. Control variables: hospital size, ownership/control; teaching status; occupancy rate; length of stay; geographic region; urban/rural status; regulatory intensity by state; local economic climate; hospital wage rates; hospital competition within a service area; supply of nursing labor within the community.

Table G24 Research studies related to full- and part-time nursing staff

Author, Year, Publication Type | Aim of the Study | Sample | Study Design and Method | Variables | Results
Jolma^113^ | Examine the relationship between nursing workload and turnover. | Randomly selected sample of medical-surgical staff nurses employed in Arizona (n=270). 123 respondents with usable questionnaires. | Descriptive correlational | Nursing workload was measured by the Role Overload subscale and intent to turnover was measured by the Intention to Turnover subscale, both part of the Michigan Organizational Assessment Questionnaire. | Full-time status, large hospital size, and large unit size were associated with higher role overload and turnover intent.
| | | Mailed questionnaire | Demographic questionnaire including information on full- and part-time status.
Wetzel^114^ | Comparison of personal and job characteristics and work-related attitudes of full-time and part-time registered nurses. | Full and part time RNs employed in three large urban hospitals in a Canadian province. Stratified sampling technique to ensure representation of full- and part-time RNs. Questionnaire sent to 930 nurses with 634 responding. Eliminated nurses with less than a year of employment resulting in a final sample of 595. | Descriptive comparative design | Job characteristics and work related attitude measures: organizational commitment; professionalism; job involvement; extrinsic and intrinsic job satisfaction, satisfaction with supervisor; difficulty leaving job; influence on decision making. No description provided of the questionnaire, reliability and validity. | Part-time nurses were older, married, had greater tenure in the organization, and more experience.
| | | Mailed questionnaires | | Statistically significant difference in job involvement between full- and part-time nurses. Full-time nurses were significantly more job involved. There was no difference between full- and part-time nurses on the other work-related attitude items.
Porter^115^ | Determine if there were self-image differences between beginning and expert nurses, caregivers and non-caregivers, educational levels of nursing and full-time and part-time staff. | 363 nurses in a midwestern hospital responding to a survey. | Descriptive; comparative | Self image measured by Porter Nursing Image Scale (3 factors: interpersonal power; interpersonal relations; interpersonal ability) and demographic questionnaire | More positive scores on the three factors were found for full-time versus part-time nurses; there was a statistically significant difference for the interpersonal power factor (e.g. leader; functioning in an independent manner).
| | | Method for distributing questionnaires not provided.
Bloom^18^ | Assess the effect of four nurse staffing patterns on the efficiency of patient care delivery: RNs from temporary agencies; part-time career RNs; RN rich skill mix; and organizationally experience RNs | Random sample of 1,222 hospitals selected; 583 hospitals in sample | Descriptive correlational | Nursing Personnel Survey which includes information about full- and part-time staff, use of agency staff, RN mix and experience. | Use of part-time staff was related to lower personnel and hospital costs; skill mix was unrelated to personnel and hospital costs; use of temporary RNs was not related to personnel costs but was related to higher hospital operating costs.
| | | Secondary data | Merged data from the American Hospital Association's annual survey of hospitals and the Area Resource File.
| | | | Hospital efficiency was the dependent variable and measured as personnel costs per adjusted admission and total non-personnel operating costs per adjusted hospital admission. Control variables: hospital size, ownership/control; teaching status; occupancy rate; length of stay; geographic region; urban/rural status; regulatory intensity by state; local economic climate; hospital wage rates; hospital competition within a service area; supply of nursing labor within the community.
Burke^116^ | Examine the effects of hospital restructuring and downsizing on full- and part-time nursing staff. | Randomly selected nurses employed in Ontario hospitals and members of a nurses union. | Descriptive, correlational | Personnel and situational characteristics which included whether the respondent worked full or part time. | Full- and part-time nurses differed significantly on the majority of demographic and situational characteristics (e.g. full-time nurses more experience in nursing, worked more hours per week, older, higher levels of education, less likely to be married). They responded to the effects of downsizing and restructuring quite similarly, but full-time nurses reported significantly heavier workloads. They were also similar in regards to job satisfaction, but full-time nurses were more likely to be absent and less likely to quit. Full-time nurses reported significantly higher levels of exhaustion, cynicism, and professional efficacy (psychological burnout). They were also more likely to report poorer physical health, greater medication use, and poorer lifestyles (physical wellbeing).
| | N=1,362 | Mailed questionnaire | Restructuring and downsizing measures (extent of restructuring; workload; staff bumping; impact of generic workers).
| | Part time: 700 | | Threats to security (e.g. layoff, change of employment status to part time).
| | Full time: 645 | | Impact on staff and institutions (job insecurity feelings; impact of restructuring on hospital functioning; impact on hospital facilities).
| | | | Implementation and management measures (fairness, communication, vision, staff participation, revitalization).
| | | | Organizational support.
| | | | Work outcomes (job satisfaction, intent to quit and absenteeism).
| | | | Psychological well-being indicators (emotional exhaustion, cynicism, professional efficacy, psychosomatic symptoms, physical health, medication use, lifestyle habits)
Havlovic^107^ | Examine the impact of work schedule congruence on personal life interference and service to patients; examine the combined effects of the rotating shift and the compressed work week. | 520 randomly selected nurses in British Columbia that returned the mailed survey. Nurses were members of the nurses' union. | Descriptive correlational | Subscales from the Comprehensive Work-Schedule Survey (CWSS): Current schedule Interference with activities with family & friends; general affect toward current schedule; Service to external constituents; interference with rest and sleep. | Specific to full- and part-time status of nurses, nurse who worked part-time reported providing higher quality service to patients, liked their present work schedules more, and experienced less interference between their work and non-work activities. Nurses who worked part time on a contingent basis did not have these positive experiences.
| | | Mailed survey | Nurse characteristics including full- and part-time status, shift and schedule currently working and preferred

Table G25 Research studies related to internationally educated nurses (IEN)

Author, Year, Publication Type | Aim of the Study | Sample | Study Design and Method | Variables | Results
Crawford^117^ | Compare processes of U.S. and IEN nurses' experience to acquire licensure, and compare practice settings of U.S. nurses and IENs. | Stratified random sample of 1,000 RNs educated in the U.S. and 1,000 RNs educated in targeted foreign countries (10% Philippines, 20% India, 10% Canada, 10% South Korea, 10% Nigeria, 10% England, 10% USSR, and 10% China) and who had successfully completed the NCLEX-RN examination. | Descriptive survey | Demographic data; description of process experienced by nurses to complete the application for U.S. RN licensure and secure a job; work settings, geographic locations. | 35% of IENs worked with a recruiter when completing the steps for U.S. nursing licensure. The average amount of time to complete the process to receive a U.S. RN licensed for IENs was 23 months, but 19 months for those using a recruiter. 34% of IEN RNs secured a nursing position in the U.S. before moving to the U.S. from their home country. U.S. nurses were more likely to report working in critical care (29.8 %) and medical surgical units (42.7%). IENs were more likely to work in medical surgical units (41.4%) and nursing homes (21.6%).
| | U.S. response rate = 570 (58.7%) | Potential responders were selected from the nurses who had successfully completed the NCLEX-RN examination between September 1 and November 30, 2002. A 4-stage mailing process was used to engage participants.
| | IEN response rate = 401 (45.5%) | Selected potential responders were sent the Practice and Professional Issues Survey (PPI) which is routinely used by the National Council of State Boards of Nurses to collect information from entry-level nurses of practice activities.
DiCicco-Bloom^118^ | To describe the experiences of a group of immigrant women nurses regarding their life and work in a culture other than their own. | Snowball sample initiated with the South Asian Nurses Association in New York state. | Descriptive, qualitative design. | Descriptive experiences of nurses educated in India and living and working in the U.S. as RNs | The themes emerging from the interviews were related to the challenges of living between two cultures and countries, racism experienced by the participants and their experience of marginalization as female nurses of color.
| | 10 participants educated in India between the ages of 40–50, married, and lived in either Pennsylvania (n=3) or New Jersey (n=7). All were educated in India. | Semi structured interviews with open-ended questions were used to evaluate for themes of life and work as reported by the female immigrants from India.
Flynn^119^ | Examine differences, between cultures of the U.S. and international nurses regarding core values of nursing (autonomy, control over practice, and relationship with physicians); job satisfaction; and levels of burnout | 820 nurses who worked at least 16 hours per week on one of the 40 study units. | Comparative descriptive study using secondary data collected in 1991 from 40 inpatient care units in 20 hospitals located in 11 U.S. cities with a high incidence of AIDS. | Country of origin (IV); values related to the professional nursing practice environment (Nursing Work Index-6 subscales); emotional exhaustion (Maslach Burnout Inventory) | 124 of the international nurses received their nursing education outside of the U.S.
| | N=252 international in origin | | | No differences were found between country of origin and three of the subscales of the Nursing Work Index (control over practice, relationships with physicians, and importance of hierarchy). Significant differences were found for three of the subscales (autonomy, ambiguity reduction, and collectivism). The absence of a professional practice environment was a significant predictor of emotional exhaustions among both U.S. and international nurses.
| | N=547 U.S. in origin
Pizer^120^ | Compare job satisfaction and demographics for U.S. and IEN in six New York City pubic hospitals. | 857 direct care nurses from six public hospitals in New York City. | Comparaitive study design. | Demographics (e.g. education, shift worked, overtime, age, experience, unit type). | Internationally educated nurses were younger and held a baccalaureate degree. They were more likely to be male, have less children, work off shifts and more overtime, work in specialty units, and had less experience as an RN that U.S. nurses.
| | N=857 IEN nurses | A two-part survey was developed for study by the Institute for Health Policy distributed to nurses. | Job satisfaction (Nurse Job Satisfaction Survey) | No differences between the two groups were found in job satisfaction for time to do the job and satisfaction with quality of care they were able to provide. There was a small significant difference for enjoyment of job with U.S. nurses reporting slightly more job enjoyment. This difference disappeared however when nurses who had positions that required both administrative responsibilities and direct care were omitted.
| | N=535 U.S. nurses | | | Being a IEN did not provide any explanation of variance for the three subscales of the NJSS.
Xu^121^ | Describe the demographic, educational, and employment characteristics of Internationally Educated Nurses (IENs) with comparison to U.S. trained nurses. | 35,579 nurses from the 2000 National Sample Survey of Registered Nurses; 3.7% of sample (1,300) were IENs. | Descriptive study using secondary data from the 2000 National Sample Survey of Registered Nurses (NSSRN), | Age, gender, education, employment (full time vs. part time; work hours) work setting and unit; position; income; job satisfaction, reasons for not working. | IENs were generally younger than U.S. nurses. Most were from the Philippines (38.9%), followed by Canada (17.5%), India (10.9%) and the UK (8.9%). IENs are more likely to be baccalaureate prepared over USNs (38.3% and 30% respectively) and more likely to work full time (73.7% vs. 59.1%). Many of the IENs were on contract to work full time and thus did not have an option to work part time. There was no difference in job satisfaction between the two groups. The rate of IENs who left nursing was only half that of U.S. nurses (2.3% vs. 4.6%).
Yi^122^ | Investigate how Korean nurses adjust to the U.S. hospital settings, the processes by which they adjust, and how their cultural background affects their adjustment process. | Purposive sample of 12 Korean nurses working in the U.S. | Exploratory study using a grounded theory method using semi-structured, indepth interviews. | Experience of Korean nurses' adjustment to U.S. hospitals. | Adjustment to U.S. hospitals involves two stages. Initial stage of adjustment is 2–3 years involving three stages: 1) relieving psychological stresses; 2) overcoming the language barriers; 3) accepting U.S. nursing practice. 5–10 years for two later stages: 1) adopting U.S. styles of problem-solving strategies; 2) adopting styles of U.S. interpersonal relationships.

USNs = U.S. trained nurses

Table G26 Research related to nursing staff overtime

Author, Year, Publication Type | Aim of the Study | Sample | Study Design and Method | Variables | Results
Shader^123^ | Examine the relations between work satisfaction, stress, age, cohesion, work schedule, and anticipated turnover | Staff nurses and nurse managers from 12 units in a 908-bed university hospital in the southeastern U.S. | Descriptive study using a cross-sectional survey design. | Nurse work satisfaction (Index of Work Satisfaction) | Specific to overtime, work satisfaction, weekend overtime, job stress, and group cohesion predicted anticipated turnover rate and explained 31% of the variance
| | N = 241 | Questionnaire distributed directly to nurses during work hours. | Job stress (modified version of the Job Stress Scale).
| | | | Group cohesion (Bryne Group Cohesion Scale).
| | | | Anticipated turnover (Anticipated Turnover Scale). Actual turnover (calculated as a ratio of the number of people who resigned to the average number of staff working for one year)
| | | | Unit demographics (e.g., size of the unit, turnover data, patient satisfaction scores, overtime, acuity, ADC, staffing mix, and reallocation).
| | | | Nurse demographics (e.g., age, gender, position, years of experience, tenure, education, shift worked).
Berney^124^ | To determine factors that influence overtime use among various hospitals and within the same hospitals from year to year | General acute care hospitals in New York state that filed Institutional Cost Reports (ICR) 1995 to 2000. Over the five years, hospitals included in analysis ranged from 167 to 174 hospitals. | Secondary data from cost reports | Straight time and overtime hours; proportion of RN hours for acute inpatients that were overtime hours; ownership; location; teaching; unionization. | RNs, on average, worked 4.5%, of their total hours as overtime (under 2 hours/week; range 0 to 8 hours/ week. Multivariate analysis results found that within hospitals, an increase of 1 hour of RN straight time per patient day was associated with a 10% decrease in overtime.
| | Observations represented hospital years and varied from 1,008 to 1,028. | | | Occupancy, average hourly wage and hours in the average work week were not associated with RN overtime within hospitals. When controlling for year to year variations in overtime for each hospital, higher RN straight hours were significantly associated with higher RN overtime. Each 1 hour increase in straight time was associated with an 8.7% increase in overtime. Government hospitals used 44% less overtime than did for-profit and nonprofit hospitals.
| | | | | Having unionized RNs was associated with a 22% higher rate of overtime use.
Rogers^105^ | To examine the work patterns of hospital staff nurses and determine if there is a relationship between hours worked and frequency of errors. | 393 RNs who were members of the American Nurses Association. Unit of analysis was number of shifts worked (5,317) over a 28 day reporting period. | Descriptive; survey | Nurse-reported data regarding hours worked (scheduled and actual), time of day worked, overtime, days off, sleep/wake patterns, mood, caffeine intake, errors and near errors. | Participants worked, on average, 55 minutes longer than scheduled each day. Almost 2/3 of the nurses worked overtime 10 or more times during the 28-day period. One quarter of the respondents worked more than 50 hours per week for two or more weeks of the 28-day period. More than 25% of nurses reported working mandatory overtime at least once during the 28 days. There were 199 reported errors and 213 reported near errors.
| | | Mailed log book | | More than half of the errors and near errors were medication related. The likelihood of making an error increased with longer work hours and was three times higher when nurses worked shifts lasting 12.5 hours or more (OR-3.29).
| | | | | Working overtime increased the odds of making at least one error, regardless of how long the shift was originally scheduled (OR=2.06). The risk of making errors increases when nurse work overtime after longer shifts. Age, hospital size or type of unit did not have an effect on errors or near errors.
Trinkoff^106^ | To describe the nature and prevalence of extended work schedules of nurses. | 2,273 randomly-selected RNs who participated in the NIOSH Nurses Worklife and Health Study. | Cross-sectional survey | Work-schedule variables derived from the Standard Shiftwork Index hours worked per day and week; weekends worked/month; days worked in a row; work more than one job; how off shifts are organized). | When compared to the entire sample, hospital staff nurses were most likely to work 12 or more hours/day, but half as likely to work 6–7 days/week and off-shifts.
| | | Mailed survey | Mandatory overtime requirement. Demographic characteristics. | Similarly, nurses with more than one job worked more hours per week as well as more consecutive days. Nurses 50 and older were less likely to work long days and were the group that tended to work days only. 17% of the sample was required to work mandatory overtime and 2/3 were required to do so with less than a 2 hour notice.
| | | | | There were no differences in the prevalence of mandatory overtime among hospital staff RNs compared with the overall sample, those working more than one job and those 50 years and older. Single parents were more likely to work jobs with mandatory overtime.
| | | | | Those whose jobs included mandatory overtime worked significantly longer hours. On call requirements were more prevalent among hospital staff nurses.
O"Brien-Pallas^125^ | Determine factors contributing to high RN injury claim rates in Canadian hospitals. | 127 hospitals in Ontario, Canada | Cross-sectional study | Workload and staffing data (mandatory annual Ontario Ministry of Health and Long Term Care hospital submissions; | High hospital RN lost-time claim rates were increased by 70% for each quartile increase in the percentage of RNs reporting more than one hour of overtime per week.
| | N = 8,044 RNs | Secondary data (1998-99) | Nursing lost-time injury claims data (Ontario Workplace Safety and Insurance Board database);
| | | | Organizational (job dissatisfaction), nurse characteristics (age, health, missed shifts, emotional exhaustion, autonomy in practice, control over practice, nurse-physician relationships).
Berney^126^ | Examine trends in the use of overtime by hospitals to determine whether overtime has been increasing more rapidly in some kinds of hospitals than in others. | 150 hospitals in New York State | Secondary data from cost reports | Straight time and overtime hours; proportion of RN hours for acute inpatients that were overtime hours; ownership; location; teaching; unionization. | Overtime increased 51% from 1995-2002. Overtime increased more in nongovernment, unionized hospitals and non teaching hospitals.

Table G27 Evidence of the association between nurse skill mix (proportion of registered nurses) and patient outcomes

Author, Source to Measure Patient Outcomes, Definition of Patient Outcomes | Number of Hospitals, Units, Patient Age, % of Whites, % of Males, % of Emergency Admissions | | Nurse Staffing Categories | | Patient Outcomes
Source to Measure Nurse Skill Mix, Definition of Nurse Skill Mix
ANA^56^ | Hospitals | 131 | | | Relative risk
An average hospital rate of nosocomial pneumonia, urinary tract infections, postoperative infections as secondary diagnoses in surgical patients; % RN Hours/total nursing hours | Unit | Combined | | | Urinary tract infection
| Patients | Combined | Increase by 1% in RNs in New York, 1992 | | 1.00
| | | Increase by 1% in RNs in New York, 1994 | | 0.99
| | | Increase by 1% in RNs in California, 1992 | | 0.99
| | | Increase by 1% in RNs in California, 1994 | | 0.99
| | | | | Pneumonia
| | | | | Rate, % | Relative risk
| | | Increase by 1% in RNs in New York, 1992 | | 0.00 | 1.00
| | | Increase by 1% in RNs in New York, 1994 | | 0.00 | 1.00
| | | Increase by 1% in RNs in California, 1992 | | -0.56 | 0.99
| | | Increase by 1% in RNs in California, 1994 | | -0.39 | 1.00
| | | | | Pressure ulcers
| | | | | Rate, % | Relative risk
| | | Increase by 1% in RNs in New York, 1992 | | -1.77 | 0.98
| | | Increase by 1% in RNs in New York, 1994 | | -1.23 | 0.99
| | | Increase by 1% in RNs in California, 1992 | | -0.79 | 0.99
| | | Increase by 1% in RNs in California, 1994 | | -1.23 | 0.99
| | | | | Nosocomial infections
| | | | | Rate, % | Relative risk
| | | Increase by 1% in RNs in New York, 1992 | | 0.00 | 1.00
| | | Increase by 1% in RNs in New York, 1994 | | 0.00 | 1.00
| | | Increase by 1% in RNs in California, 1992 | | -0.53 | 0.99
| | | Increase by 1% in RNs in California, 1994 | | -0.47 | 1.00
Barkell^77^ | Hospitals | 1 | | | Pneumonia, rate %
The incidence of urinary tract infection: a) presence of white blood cells >100/high-powered field (HPF) on urinalysis, b) bacteria 3+/ high-powered field F or 4+/ high-powered field on urinalysis, and c) urine culture showing >100,000 colonies of one or two (not three or more) organisms; the incidence of pneumonia; proportion of RN/ total nursing staff. | Unit | Surgical | Team nursing model with patient care associate assisting RNs in delivery of patient care (lower proportion of RN: 65.8%) | | 5.1
| Patients | Surgical | Total patient care model, higher proportion of RN: 78.6%) | | 0
| Race | 88.1
| Sex | 40.7
Berney^84^ | Hospitals | 161 | | | Relative risk
Actual number of urinary tract infections, gastrointestinal bleeding, and sepsis events identified as secondary DRG; RN acute hours/(RN + LPN acute hours) | | | | | Urinary tract infection
| | | 1% increase in RN hours/total licensed hours, medical patients | | 1.00 | 0.99 | 1.00
| | | 1% increase in RN hours/total licensed hours, surgical patients | | 1.00 | 0.99 | 1.00
| | | | | Gastrointestinal bleeding
| | | 1% increase in RN hours/total licensed hours, medical patients | | 1.00 | 1.00 | 1.01
| | | 1% increase in RN hours/total licensed hours, surgical patients | | 1.01 | 1.00 | 1.01
| | | | | Sepsis
| | | 1% increase in RN hours/total licensed hours, medical patients | | 1.01 | 1.00 | 1.01
| | | 1% increase in RN hours/total licensed hours, surgical patients | | 1.01 | 1.00 | 1.01
Blegen^58^ | Hospitals | 11 | | | Rate per 100 patient days ± SD
The number of patient falls on the unit in quarter/1,000 patient days; the number of CPR on the unit in quarte/1,000 patient days; RN hours per patient day divided by all hours per patient day | Unit | Combined | | | Falls
| Patients | Combined | Increase by 1% in proportion of RN | | -0.05 ± 1.63
| | | | | CPR
| | | Increase by 1% in proportion of RN | | -0.01 ± 0.55
Blegen^73^ | | | Proportion of BSN | | Rate/100 patient days ± SD
The number of patient falls on the unit in quarter/1,000patient days; RN hours per patient day divided by all hours per patient day | | | | | Falls
| | | 73% | | 0.22 ± 0.18
| | | 72% | | 0.27 ± 0.28
Blegen^59^ | Hospitals | 1 | | | Rate/100 patient days ± SD
New incidences of skin breakdown secondary to pressure or exposure to urine or feces; suddenly and involuntarily leaving a position and coming to rest on the floor or some object. All reported falls were included whether or not injuries resulted. RN hours per patient day divided by all hours per patient day | Unit | Combined | | | Decubitus ulcer
| Patients | Combined | Increase by 1% in proportion of RN nurses | | -1.06 ± 3.36
| | | Proportion of RN >87.5% | | 0.25 ± 0.12
| | | | | Falls
| | | Increase by 1% in proportion of RN nurses | | 0.04 ± 3.01
| | | Proportion of RN >87.5% | | -0.22 ± 0.10
| | | | | Nosocomial infection
| | | Increase by 1% in proportion of RN nurses | | -1.26 ± 6.15
| | | Proportion of RN >87.5% | | 0.13 ± 0.22
Bolton^26^ | Hospitals | 38 | | % RN | Rate/100 patient days
Hospital-acquired pressure ulcers; the monthly rate per 1,000 patient days for each nursing unit and each hospital. Data are collected at the patient level and aggregated by CalNOC staff to the unit level. | | | | | Falls | Pressure ulcers
Unplanned descent to the floor in adult patients; the monthly fall rate per 1,000 patient days for each nursing unit and each hospital; % of RN hours/total nursing hours. | | | Medical-surgical units | 59 | 3.70 | 8.00
| | | Critical care units | 91 | 0.10 | 13.00
Cheung^32^ | Hospitals | 1 | Increase by 1% of licensed nurses | | Relative risk of decubitus ulcers, failure to rescue, and nosocomial infection
Pressure ulcers, patient falls coded as secondary diagnosis, primary bloodstream infections after admitting the unit, ratio of RN and LPN among to unlicensed nursing personnel | Unit | Combined | | | Not significant
| Patients | Medical
Cho^38^ | Unit | Combined
ICD-9-CM for urinary tract infections | Patients | Combined
ICD-9-CM for pressure ulcers | Hospitals | | % RN | | Pneumonia, rate %
ICD-9-CM for falls and injury | 48 | | 70 | | 1.67
ICD-9-CM for surgical wound infection | 48 | | 50 | | 2.03
ICD-9-CM for sepsis | 79 | | 60 | | 1.72
ICD-9-CM for adverse drug event. | 79 | | 90 | | 1.28
RN Hours divided by all hours | 48 | | 60 | | 1.96
| 48 | | 60 | | 1.84
| 48 | | 80 | | 1.51
| 48 | | 90 | | 1.37
| 48 | | 50 | | 2.16
| 79 | | 70 | | 1.56
| 12 | | 50 | | 2.08
| 12 | | 80 | | 1.42
| 12 | | 50 | | 1.90
| 79 | | 60 | | 1.89
| 12 | | 70 | | 1.71
| 12 | | 80 | | 1.55
| 12 | | 90 | | 1.41
| 48 | | 80 | | 1.61
| 48 | | 90 | | 1.46
| 48 | | 70 | | 1.78
| | | | | Relative risk, 95% CI
| | | | | Urinary tract infection
| 232 | | 100% increase in RN hours | | 0.92 | 0.31 | 2.64
| | | | | Pneumonia
| | | 100% increase in RN hours | | 0.37 | 0.15 | 0.91
| | | | | Falls
| | | 100% increase in RN hours | | 0.96 | 0.21 | 4.49
| | | | | Pulmonary failure
| | | 100% increase in RN hours | | 0.75 | 0.11 | 4.98
| | | | | Surgical wound infection
| | | 100% increase in RN hours | | 0.52 | 0.21 | 1.3
| | | | | Sepsis
| | | 100% increase in RN hours | | 1.20 | 0.43 | 3.33
Cho^30^ | Unit | Combined | % RN | | Rate, % ± SD
The same study | Patients | Combined | 76.5 | | 2.50 ± 1.30
| Age | 67.9 | 68.1 | | 1.60 ± 1.40
| Race | 79.3 | 72.4 | | 2.00 ± 1.00
| Sex | 48.9 | 72.7 | | 2.10 ± 1.80
| Severity | 49.7 | | | Pneumonia
| | | 76.5 | | 3.10 ± 1.90
| | | 68.1 | | 2.70 ± 2.20
| | | 72.4 | | 2.80 ± 1.30
| | | 72.7 | | 2.80 ± 2.00
| | | | | Falls
| | | 76.5 | | 0.20 ± 0.20
| | | 68.1 | | 0.20 ± 0.30
| | | 72.4 | | 0.20 ± 0.20
| | | 72.7 | | 0.10 ± 0.20
| | | | | Pressure ulcers
| | | 76.5 | | 0.10 ± 0.30
| | | 68.1 | | 0.30 ± 0.60
| | | 72.4 | | 0.30 ± 0.50
| | | 72.7 | | 0.20 ± 0.40
| | | | | Surgical wound infection
| | | 76.5 | | 1.60 ± 1.00
| | | 68.1 | | 1.10 ± 1.10
| | | 72.4 | | 1.50 ± 0.70
| | | 72.7 | | 1.10 ± 1.00
| | | | | Sepsis
| | | 76.5 | | 1.20 ± 0.70
| | | 68.1 | | 0.80 ± 0.80
| | | 72.4 | | 1.10 ± 0.60
| | | 72.7 | | 1.00 ± 1.10
Cimiotti^87^ | Hospitals | 1 | % RN | | Rate, %
Infections occurring in an infant 48 hours or longer after admission to the Neonatal Intensive Care Unit including bloodstream infections, device associated pneumonia, Central nervous System and skin infections, conjunctivitis. | Unit | Neonatal | | | Pneumonia | Nosocomial infection
% of RN hours among total nursing hours adjusted for nursing intensity weights | Patients | Medical | 100 | | 0.50 | 18.30
| | | 96 | | 0.90 | 15.10
| | | | | Sepsis
| | | 100 | | 10.50
| | | 96 | | 5.50
Donaldson^9^ | Hospitals | 68 | % RN | % licensed nurses | Rate/100 patient days ± SD
Total number of patients with Stage I–IV pressure ulcers regardless of whether ulcer was acquired during hospitalization or present on admission; %/total number of surveyed patients; unplanned descent to the floor; rate/1,000 patient days; % of RN hours/total nursing care hours; % of licensed hours/total nursing care hours. | Patients | Medical | | | Falls
| Unit | Combined | 59.2 | 67.52 | 0.31 ± 0.20
| | Combined | 66.67 | 74.29 | 0.32 ± 0.17
| | ICU | 68.79 | 72.99 | 0.30 ± 0.22
| | ICU | 72.19 | 75.54 | 0.26 ± 0.16
| | | | | Pressure ulcers
| | | 59.2 | 67.52 | 14.07 ± 11.07
| | | 66.67 | 74.29 | 14.48 ± 10.39
| | | 68.79 | 72.99 | 13.52 ± 10.78
| | | 72.19 | 75.54 | 16.29 ± 10.27
Donaldson^95^ | Hospitals | 25 | | | Rate/100 patient days ± SD
Patients' unplanned descent to the hospital floor; were analyzed as 7 day aggregate per unit; also actually number per unit; the number of falls/1,000 patient days, the % of RN hours / total care hours per day, per unit. | Unit | Combined | | | Falls
| Patients | Medical | Increase by 1% in RN hours of care | | -0.0020 ± 0.00
| | | Increase by 1% licensed hours of care | | -0.0010 ± 0.01
Flood^53^ | Hospitals | 1 | | % RN | Rate, %
infections including urinary tract infection and gangrene; Complications: congestive heart failure and arrhythmias, gastrointestinal bleeding | Unit | Combined | | | Nosocomial infections
| Patients | Medical | Understaffed unit | 60.45 | 0.16
| Sex | 60 | Normally staffed unit | 42.32 | 0.19
| | | | | Complications
| | | Understaffed unit | 60.45 | 64
| | | Normally staffed unit | 42.32 | 71
Grillo-Peck^10^ | Hospitals | 1 | % RN | | Rate, % ± SD
The number of reported monthly incidents in the unit, total number of infected patients per month of the entire unit census. Decrease in % of RNs in the unit within new partnership model with increase patient care technicians and service associates. RN spent more time on direct patient care. | Unit | Specialty | | | Falls
| Patients | Medical | 80 | | 8.69 ± 3.93
| Sex | 43.7 | 60 | | 3.53 ± 1.66
| | | | | Nosocomial infection
| | | 80 | | 16.48 ± 32.87
| | | 60 | | 10.39 ± 32.92
Halm^51^ | Hospitals | 1 | Increase by 1 unit in RN/patient ratio | | Failure to rescue, relative risk
Failure to rescue: death following complications within 30 days | Unit | Surgical | | | NS
| Patients | Surgical
| Age | 55.6
| Sex | 37.4
| Severity | 22.7
Hope^86^ | Hospitals | 1 | | | Rate/100 patient days
Incidence rate of urinary tract infection, ventilator associated pneumonia, surgical site infections, and infections that occurred after 72 hours of hospitalization; incidence rate of positive culture with known pathogen or two or more positive cultures with pathogens (one can be considered as contaminant); proportion of RN hours/total nursing hours/patient day 4–10 days before the event occurred | Sex | 44.99 | % RN | | Nosocomial Infection
| Units | | 83.65 | | 3.08
| Surgical | | 84.26 | | 20.00
| Surgical | | 81.73 | | 4.62
| Surgical | | 85.09 | | 10.77
| Surgical | | 98.81 | | 0.00
| Medical | | 77.28 | | 6.15
| Medical | | 76.48 | | 1.54
| Medical | | 89.7 | | 1.54
| Medical | | 98.6 | | 0.00
| Medical | | 80.4 | | 0.00
| Medical | | 78.12 | | 3.08
| Medical | | 76.23 | | 10.77
| Medical | | 98.75 | | 0.00
| Specialty | | 94.48 | | 33.85
| ICU | | 99.56 | | 1.54
| ICU | | 99.11 | | 3.08
| Surgical | | 92.11 | | 0.00
| Neonatal | | | | Sepsis
| | | 83.65 | | 7.54
| Surgical | | 84.26 | | 11.8
| Surgical | | 81.73 | | 0.33
| Surgical | | 85.09 | | 4.59
| Surgical | | 98.81 | | 0.00
| Medical | | 77.28 | | 7.21
| Medical | | 76.48 | | 2.95
| Medical | | 89.7 | | 1.31
| Medical | | 80.4 | | 7.87
| Medical | | 78.12 | | 8.20
| Medical | | 76.23 | | 6.56
| Medical | | 98.75 | | 1.97
| Spec | | 94.48 | | 23.28
| ICU | | 99.56 | | 9.51
| ICU | | 99.11 | | 4.59
| Surgical | | 92.11 | | 2.30
| Neonatal | | | | Relative risk, 95% CI
| | | | | Urinary tract infection
| | | Increase by 1% in proportion of RN | | 1.01 | 1.00 | 1.01
| | | | | Pneumonia
| | | Increase by 1% in proportion of RN | | 1.06 | 0.93 | 1.21
| | | | | Nosocomial infection
| | | Increase by 1% in proportion of RN | | 1.06 | 1.03 | 1.09
| | | | | Surgical wound infection
| | | Increase by 1% in proportion of RN | | 1.03 | 0.99 | 1.08
| | | | | Sepsis
| | | Increase by 1% in proportion of RN | | 1.05 | 1.04 | 1.07
Houser^49^ | Unit | Combined | | | Rate, % ± SD
Failure to rescue: death/1,000 patients who developed complications of care during hospitalization; cases of decubitus ulcer/1,000 discharges identified as secondary diagnosis; cases of acute respiratory failure/1,000 surgical discharges; cases of deep vein thrombosis or pulmonary embolism/1,000 surgical discharges. Reported by hospitals ratio reported RN FTE/RN+LPN | Patients | Medical | % RN | | Failure to rescue
| Age | 55.08 | 79 | | 11.61 ± 8.41
| Race | 51 | 86 | | 13.82 ± 5.80
| Sex | 42 | 87 | | 12.40 ± 9.11
| Hospitals | | 88 | | 10.51 ± 6.82
| 170 | | 88 | | 9.01 ± 6.26
| 172 | | 88 | | 9.42 ± 10.16
| 174 | | 86 | | 5.43 ± 8.89
| 171 | | | | Decubitus ulcer
| 39 | | 79 | | 2.21 ± 1.78
| 14 | | 86 | | 2.57 ± 1.62
| 8 | | 87 | | 2.14 ± 1.45
| | | 88 | | 1.90 ± 1.70
| | | 88 | | 1.70 ± 1.39
| | | 88 | | 1.44 ± 1.48
| | | 86 | | 2.24 ± 4.21
| | | | | Pulmonary failure
| | | 79 | | 0.26 ± 0.65
| | | 86 | | 0.33 ± 0.37
| | | 87 | | 0.32 ± 0.37
| | | 88 | | 0.19 ± 0.42
| | | 88 | | 0.15 ± 0.36
| | | 88 | | 0.34 ± 0.79
| | | 86 | | 0.00
| | | | | Deep vein thrombosis
| | | 79 | | 0.52 ± 0.71
| | | 86 | | 0.75 ± 0.63
| | | 87 | | 0.68 ± 0.65
| | | 88 | | 0.44 ± 0.78
| | | 88 | | 0.38 ± 1.06
| | | 88 | | 0.52 ± 1.28
| | | 86 | | 0.06 ± 0.13
Langemo^41^ | Hospitals | 1 | | % RN | Rate, %
% of patients who had a pressure ulcer on a given day to all patients assessed for a pressure ulcer, pressure ulcers that occurred post admission were documented as hospital-acquired. Number of productive hours worked by RN divided by total staff hours. | | | Medical-surgical units in hospitals with <100 beds | 53.4 | 4.10
| | | ICU in hospitals with 200–299 beds | 99.4 | 0.00
| | | ICU units in hospitals <100 beds | 60.6 | 13.10
| | | Medical-surgical units in hospitals with 200–299 beds | 61.5 | 0.00
Lichtig^63^ | Hospitals | Unit | Increase by 1% in proportion of RNs: | | Rate, %
Likely adverse patient outcomes of the hospital stay, secondary diagnoses of urinary tract infection, pneumonia, pressure ulcers, infection in surgical patients. RN hours as a percentage of total nursing hours per nursing intensity weight-adjusted patient day | 352 | Surgical | | | Pressure ulcers
| 295 | Surgical | California, 1992 | | -0.79
| 126 | Surgical | California, 1994 | | -1.23
| 131 | Surgical | New York,1992 | | -1.77
| | | New York, 1994 | | -1.23
| | | | | Pneumonia
| | | California, 1992 | | -0.56
| | | California, 1994 | | -0.39
| | | | | Surgical wound infections
| | | California, 1992 | | -0.53
| | | California, 1994 | | -0.47
| | | | | Relative risk of UTI,
| | | New York,1992 | | pneumonia, pressure ulcers, and SWI: Not significant
| | | New York, 1994
Needleman^28^ | Hospitals | Patients | | | Relative risk
Urinary tract infection in discharge abstract as secondary diagnosis; acute gastric ulcer, duodenal ulcer, peptic ulcer, gastrojejunal ulcer, hemorrhagic gastritis, erosive gastritis, unspecified GI-hemorrhage, esophageal hemorrhage coded in discharge abstract as secondary diagnosis; aspiration pneumonia, postoperative pneumonia, hypostatic pneumonia, bacterial pneumonia, bronchopneumonia coded in discharge abstract as secondary diagnosis; cardiac arrest; shock without mention of trauma; cardiogenic shock; respiratory arrest, nonmechanical methods of resuscitation, cardiopulmonary resuscitation, failure to rescue: death in patients with sepsis, pneumonia, gastrointestinal bleeding, shock or deep vein thrombosis coded in discharge abstract as secondary diagnosis; pressure ulcers, posttraumatic surgical wound infection and postoperative surgical wound infection; % of RN hours/total nursing hours; % of licensed hours/total nursing hours | | | | | Urinary tract infection
| 4,156 | Medical | Increase by 1% in RNs/total nursing hours | | 0.40 | 0.29 | 0.55
| 4,156 | Surgical | Increase by 1% in RNs/total nursing hours | | 0.58 | 0.36 | 0.96
| 4,156 | Medical | increase by 1% of RN hours/total licensed hours | | 0.48 | 0.38 | 0.61
| 4,156 | Surgical | Increase by 1% in RN hours/total licensed hours | | 0.67 | 0.46 | 0.98
| 3,357 | Medical | Increase by 1% in RN hours/total licensed hours | | 0.77 | 0.68 | 0.86
| 3,357 | Medical | Increase by 1% in RN hours/total nurse hours | | 0.46 | 0.34 | 0.63
| 3,357 | Surgical | Increase by 1% in RN hours/licensed hours | | 0.89 | 0.74 | 1.07
| 3,357 | Surgical | Increase by 1% in RN hours/total nursing hours | | 1.02 | 0.73 | 1.44
| 256 | Medical | Increase by 1% in RN hours/total nursing hours, hospital level analysis, California hospitals | | 0.33 | 0.18 | 0.61
| 256 | Medical | Increase by 1% of RN hours/total licensed hours, hospital level analysis, California hospitals | | 0.44 | 0.28 | 0.70
| 256 | Medical | Increase by 1% in RN hours/total nursing hours, unit level analysis, California hospitals | | 0.50 | 0.30 | 0.84
| 256 | Medical | Increase by 1% of RN hours/licensed hours, unit level analysis, California hospitals | | 0.60 | 0.41 | 0.87
| 256 | Surgical | Increase by 1% in RN hours/total nursing hours, hospital level analysis, California hospitals | | 0.82 | 0.47 | 1.44
| 256 | Surgical | Increase by 1% in RN hours/licensed hours, hospital level analysis, California hospitals | | 0.64 | 0.30 | 1.37
| 256 | Surgical | Increase by 1% in RN hours/total nursing hours, California hospitals | | 0.09 | 0.01 | 0.91
| 256 | Surgical | Increase by 1% in RN hours/licensed hours, unit level analysis, California hospitals | | 0.05 | 0.00 | 1.54
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.49 | 0.37 | 0.61
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.88 | 0.71 | 1.04
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.68 | 0.40 | 0.95
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.59 | 0.36 | 0.82
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.76 | 0.67 | 0.85
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.54 | 0.41 | 0.66
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.48 | 0.38 | 0.61
| 799 | Surgical | 1% increase in proportion of RN/total nursing personnel | | 0.67 | 0.46 | 0.98
| | | | | Gastrointestinal bleeding
| 4156 | Medical | Increase by 1% in RN/total nursing hours | | 0.52 | 0.35 | 0.77
| 4156 | Surgical | Increase by 1% in RN/total nursing hours | | 0.41 | 0.19 | 0.86
| 4156 | Medical | increase by 1% of RN hours/total licensed hours | | 0.59 | 0.44 | 0.80
| 4156 | Surgical | Increase by 1% in RN hours/total licensed hours | | 0.56 | 0.31 | 1.01
| 3,357 | Medical | Increase by 1% in RN hours/total licensed hours | | 0.83 | 0.71 | 0.98
| 3,357 | Medical | Increase by 1% in RN hours/total nurse hours | | 0.49 | 0.32 | 0.76
| 3357 | Surgical | Increase by 1% in RN hours/licensed hours | | 0.94 | 0.76 | 1.16
| 3357 | Surgical | Increase by 1% in RN hours/total nursing hours | | 0.23 | 0.10 | 0.53
| 256 | Medical | Increase by 1% in RN hours/total nursing, hospital level analysis, California hospitals | | 0.44 | 0.22 | 0.86
| 256 | Medical | Increase by 1% of RN hours/total licensed hours, hospital level analysis, California hospitals | | 0.52 | 0.32 | 0.87
| 256 | Medical | Increase by 1% in RN hours/total nursing hours, unit level analysis, California hospitals | | 1.02 | 0.72 | 1.44
| 256 | Medical | Increase by 1% of RN h/licensed hours, unit level analysis, California hospitals | | 0.69 | 0.47 | 1.03
| 256 | Surgical | Increase by 1% in RN h/total nursing hours, hospital level analysis, California hospitals | | 0.61 | 0.30 | 1.23
| 256 | Surgical | Increase by 1% in RN hours/licensed hours, hospital level analysis, California hospitals | | 0.66 | 0.26 | 1.69
| 256 | Surgical | Increase by 1% in RN hours/total nursing hours, California hospitals | | 0.78 | 0.40 | 1.52
| 256 | Surgical | Increase by 1% in RN hours/licensed hours, unit level analysis, California hospitals | | 0.79 | 0.37 | 1.71
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.61 | 0.42 | 0.79
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.94 | 0.74 | 1.13
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.36 | 0.12 | 0.59
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.52 | 0.20 | 0.84
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.83 | 0.70 | 0.96
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.59 | 0.39 | 0.78
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.59 | 0.44 | 0.80
| | | | | Pneumonia
| 4156 | Medical | Increase by 1% in RN/total nursing hours | | 0.52 | 0.35 | 0.77
| 4156 | Surgical | Increase by 1% in RN/total nursing hours | | 0.41 | 0.19 | 0.86
| 4156 | Medical | increase by 1% of RN hours/total licensed hours | | 0.59 | 0.44 | 0.80
| 4156 | Surgical | Increase by 1% in RN hours/total licensed hours | | 0.56 | 0.31 | 1.01
| 3,357 | Medical | Increase by 1% in RN hours/total licensed hours | | 0.83 | 0.71 | 0.98
| 3,357 | Medical | Increase by 1% in RN hours/total nurse hours | | 0.49 | 0.32 | 0.76
| 3357 | Surgical | Increase by 1% in RN hours/licensed hours | | 0.94 | 0.76 | 1.16
| 3357 | Surgical | Increase by 1% in RN hours/total nursing hours | | 0.23 | 0.10 | 0.53
| 256 | Medical | Increase by 1% in RN hours/total nursing, hospital level analysis, California hospitals | | 0.44 | 0.22 | 0.86
| 256 | Medical | Increase by 1% of RN h/total licensed hours, hospital level analysis, California hospitals | | 0.52 | 0.32 | 0.87
| 256 | Medical | Increase by 1% in RN hours/total nursing hours, unit level analysis, California hospitals | | 1.02 | 0.72 | 1.44
| 256 | Medical | Increase by 1% of RN hours/licensed hours, unit level analysis, California hospitals | | 0.69 | 0.47 | 1.03
| 256 | Surgical | Increase by 1% in RN h/total nursing hours, hospital level analysis, California hospitals | | 0.61 | 0.30 | 1.23
| 256 | Surgical | Increase by 1% in RN hours/licensed hours, hospital level analysis, California hospitals | | 0.66 | 0.26 | 1.69
| 256 | Surgical | Increase by 1% in RN hours/total nursing hours, California hospitals | | 0.78 | 0.40 | 1.52
| 256 | Surgical | Increase by 1% in RN hours/licensed hours, unit level analysis, California hospitals | | 0.79 | 0.37 | 1.71
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.94 | 0.74 | 1.13
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.36 | 0.12 | 0.59
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.52 | 0.20 | 0.84
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.83 | 0.70 | 0.96
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 1.00 | 0.99 | 1.01
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.59 | 0.39 | 0.78
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.59 | 0.44 | 0.80
| | | | | Shock
| 4156 | Medical | Increase by 1% in RN/total nursing hours | | 0.84 | 0.71 | 0.99
| 4156 | Surgical | Increase by 1% in RN/total nursing hours | | 1.08 | 0.60 | 1.96
| 4156 | Medical | increase by 1% of RN hours/total licensed hours | | 0.46 | 0.27 | 0.81
| 4156 | Surgical | Increase by 1% in RN hours/total licensed hours | | 0.54 | 0.28 | 1.04
| 3,357 | Medical | Increase by 1% in RN hours/total licensed hours | | 0.66 | 0.50 | 0.87
| 3,357 | Medical | Increase by 1% in RN hours/total nurse hours | | 0.52 | 0.31 | 0.89
| 3357 | Surgical | Increase by 1% in RN hours/licensed hours | | 0.59 | 0.44 | 0.78
| 3357 | Surgical | Increase by 1% in RN hours/total nursing hours | | 0.36 | 0.14 | 0.93
| 256 | Medical | Increase by 1% in RN hours/total nursing, hospital level analysis, California hospitals | | 0.30 | 0.12 | 0.72
| 256 | Medical | Increase by 1% of RN hours/total licensed hours, hospital level analysis, California hospitals | | 0.20 | 0.08 | 0.53
| 256 | Medical | Increase by 1% in RN hours/total nursing hours, unit level analysis, California hospitals | | 0.34 | 0.16 | 0.75
| 256 | Medical | Increase by 1% of RN hours/licensed hours, unit level analysis, California hospitals | | 0.40 | 0.19 | 0.86
| 256 | Surgical | Increase by 1% in RN hours/total nursing hours, hospital level analysis, California hospitals | | 0.14 | 0.05 | 0.43
| 256 | Surgical | Increase by 1% in RN hours/licensed hours, hospital level analysis, California hospitals | | 0.22 | 0.09 | 0.57
| 256 | Surgical | Increase by 1% in RN hours/total nursing hours, California hospitals | | 0.17 | 0.06 | 0.47
| 256 | Surgical | Increase by 1% in RN hours/licensed hours, unit level analysis, California hospitals | | 0.27 | 0.12 | 0.61
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.59 | 0.42 | 0.76
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.42 | 0.10 | 0.74
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.60 | 0.19 | 1.00
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.66 | 0.48 | 0.85
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 1.00 | 0.97 | 1.02
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.40 | 0.18 | 0.63
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.46 | 0.27 | 0.81
| | | | | Failure to rescue
| 4156 | Medical | Increase by 1% in RN/total nursing hours | | 0.85 | 0.70 | 1.03
| 4156 | Surgical | Increase by 1% in RN/total nursing hours | | 0.64 | 0.44 | 0.92
| 4156 | Medical | increase by 1% of RN hours/total licensed hours | | 0.81 | 0.66 | 1.00
| 4156 | Surgical | Increase by 1% in RN hours/total licensed hours | | 0.73 | 0.49 | 1.09
| 3,357 | Medical | Increase by 1% in RN hours/total licensed hours | | 0.90 | 0.80 | 1.01
| 3,357 | Medical | Increase by 1% in RN hours/total nurse hours | | 0.85 | 0.70 | 1.04
| 3357 | Surgical | Increase by 1% in RN hours/licensed hours | | 0.82 | 0.70 | 0.96
| 3357 | Surgical | Increase by 1% in RN hours/total nursing hours | | 0.69 | 0.45 | 1.06
| 256 | Medical | Increase by 1% in RN hours/total nursing, hospital level analysis, California hospitals | | 0.63 | 0.47 | 0.84
| 256 | Medical | Increase by 1% of RN hours/total licensed hours, hospital level analysis, California hospitals | | 0.58 | 0.40 | 0.86
| 256 | Medical | Increase by 1% in RN hours/total nursing hours, unit level analysis, California hospitals | | 0.70 | 0.54 | 0.90
| 256 | Medical | Increase by 1% of RN hours/licensed hours, unit level analysis, California hospitals | | 0.69 | 0.50 | 0.95
| 256 | Surgical | Increase by 1% in RN hours/total nursing hours, hospital level analysis, California hospitals | | 0.36 | 0.14 | 0.89
| 256 | Surgical | Increase by 1% in RN hours/licensed hours, hospital level analysis, California hospitals | | 0.45 | 0.22 | 0.92
| 256 | Surgical | Increase by 1% in RN hours/total nursing hours, California hospitals | | 0.44 | 0.20 | 0.96
| 256 | Surgical | Increase by 1% in RN hours/licensed hours, unit level analysis, California hospitals | | 0.54 | 0.30 | 0.99
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.80 | 0.64 | 0.97
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.81 | 0.68 | 0.94
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.70 | 0.37 | 1.03
| 799 | Surgical | 1% increase in RN hours/total licensed hours | | 0.72 | 0.42 | 1.01
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.90 | 0.80 | 1.00
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 1.00 | 1.00 | 1.01
| 799 | Medical | 1% increase in RN hours/total licensed hours | | 0.81 | 0.64 | 0.99
| 799 | Surgical | 1% increase in proportion of RN/total nursing personnel | | 0.81 | 0.66 | 1.00
Potter^40^ | Hospitals | 1 | % RN | | Falls, rate/100 patient days
(Number of falls on a unit/number of patient days) * 1,000 | Unit | ICU | 53.8 | | 0.30
| Patients | Medical | 55.4 | | 0.29
| | | 56.2 | | 0.30
| | | 57.1 | | 0.23
Ritter-Teitel^69^ | Hospitals | 28 | % RN | | Rate %, ± SD
Hospital Incidence reports; | | | 56.15 | | 2.09 ± 2.25
% of patients with urinary tract infection not presented at admission among total discharged or sampled patients; % of patients with pressure ulcers, number of events/1,000 patient days, % of RNs among total nursing personnel | | | 56.4 | | 2.53 ± 2.29
| | | 56.79 | | 2.25 ± 2.36
| | | 56.77 | | 2.61 ± 2.46
| | | 56.79 | | 1.93 ± 2.18
| | | 56.77 | | 2.45 ± 2.16
| | | Increase by 1 hour in RN hours | | -0.18 ± 1.24
| | | % RN | | Pressure ulcers
| | | 56.15 | | 2.42 ± 2.10
| | | 56.4 | | 2.06 ± 1.66
| | | 56.79 | | 2.33 ± 2.12
| | | 56.77 | | 2.23 ± 1.94
| | | 56.79 | | 2.50 ± 2.11
| | | 56.77 | | 1.88 ± 1.33
| | | Increase by 1 hour in RN hours | | -0.24 ± 1.18
| | | % RN | | Falls
| | | 56.15 | | 0.32 ± 0.20
| | | 56.4 | | 0.34 ± 0.16
| | | 56.79 | | 0.40 ± 0.21
| | | 56.77 | | 0.41 ± 0.17
| | | 56.79 | | 0.24 ± 0.14
| | | 56.77 | | 0.27 ± 0.12
| | | Increase by 1 hour in RN hours | | -0.42 ± 0.90
| | | Increase by 1 hour in RN hours in medical units | | -0.49 ± 0.87
| | | Increase by 1 hour in RN hours in surgical units | | -0.15 ± 0.96
Seago^8^ | Hospitals | 1 | % RN | | Rate, %
The proportion of pressure ulcers per patient day; the proportion of falls per patient day; RN hours/total hours. | Unit | Combined | | | Falls | Pressure ulcers
| Patients | Medical | 63 | | 0.29 | 0.24
| | | 61.5 | | 0.27 | 0.18
| | | 62 | | 0.23 | 0.29
Seago^93^ | Hospitals | 1 | | | Rate/100patient days ± SD
The proportion of pressure ulcers per patient day, the proportion of falls per patient day, RN hours/total hours | Unit | Combined | % RN | | Decubitus ulcers
| Patients | Medical | 75 | | 0.78 ± 0.09
| | | 96 | | 0.02 ± 0.05
| | | 72 | | 0.05 ± 0.08
| | | | | Falls
| | | 75 | | 0.35 ± 0.20
| | | 96 | | 0.19 ± 0.19
| | | 72 | | 0.45 ± 0.25
Simmonds^82^ | Hospitals | 1 | % RN | | Rate, %
% of patients with positive colonization of vancomycin-resistant enterococci 48 hours after admission to the hospital and after surgery; 100% of nursing care provided by a licensed practical nurse | Unit | Specialty | | | Nosocomial infection
| Patients | Medical | 76.83 | | 1.61
| Age | 68.75 | 75.51 | | 3.29
| Sex | 55.8 | 74.19 | | 4.97
| | | 72.87 | | 6.65
| | | 76.83 | | 2.87
| | | 75.51 | | 3.73
| | | 74.19 | | 4.59
| | | 72.87 | | 1.79
Stratton^91^ | Hospitals | 7 | % RN | | Rate/100 patient days ± SD
Rate/1,000 patient days of respiratory, gastrointestinal, bloodstream and central line infections in hospitalized patients not present at time of admission; rate/1,000 patient days of bloodstream and central line infections in hospitalized patients not present at time of admission. average % of RN productive hours/total nursing hours/ patient day | Unit | Patients | | | Nosocomial infections
| Combined | Combined | 73.41 | | 0.75 ± 0.69
| Combined | Combined | 72.06 | | 0.53 ± 0.67
| Combined | Combined | 72.41 | | 0.71 ± 0.77
| Combined | Combined | 74 | | 0.64 ± 0.43
| Spec | Surgical | 83.2 | | 0.65 ± 0.23
| Spec | Surgical | 79 | | 0.62 ± 0.39
| Spec | Surgical | 79.6 | | 0.71 ± 0.59
| Spec | Surgical | 80.2 | | 0.85 ± 0.50
| ICU | Medical | 89 | | 0.73 ± 0.56
| ICU | Medical | 88.17 | | 1.03 ± 0.96
| ICU | Medical | 87.5 | | 0.80 ± 0.69
| ICU | Medical | 88.5 | | 0.95 ± 0.71
| Combined | Medical | 80.35 | | 0.51 ± 0.08
| Combined | Medical | 78.76 | | 0.79 ± 0.17
| Combined | Medical | 78.79 | | 0.66 ± 0.12
| Combined | Medical | 80.03 | | 0.56 ± 0.17
| Combined | Medical | Increase by 1 hour in total nursing hours | | 0.01 ± 0.03
| Combined | Medical | Increase by 1% in RN hours | | 0.00 ± 0.01
| Combined | Medical | increase by 1% in overtime RN hours | | -0.01 ± 0.02
| Combined | Medical | Increase by 1% in temporary nurses | | 0.00 ± 0.01
Tallier^83^ | Hospitals | 1 | % RN | | Rate/100 patient days
Incidence rate/1,000 patient days of pressure ulcers developed 72 hours after admission, % of productive hours in direct patient care worked by RN | Unit | Combined | | | Pressure ulcers
| Patients | Medical | 57 | | 0.17
| | | 60 | | 0.29
Unruh^81^ | Hospitals | 1477 | | | Relative risk
Yearly number of occurrences of pneumonia, falls, and decubitus ulcers per hospital | Unit | Combined | | | Pneumonia
| Patients | Medical | 1% increase in proportion of licensed nurses/total nursing personnel | | 0.99
| | | | | Decubitus ulcers
| | | 1% increase in proportion of licensed nurses/total nursing personnel | | 0.98
| | | | | Falls
| | | 1% increase in proportion of licensed nurses/total nursing personnel | | 1.03
Unruh^66^ | Hospitals | 211 | % RN | | Decubitus ulcer, rate %
Nosocomial urinary tract infection as secondary diagnosis when primary diagnosis is not disorders of kidneys, urinary and reproductive tracts and systems; hospital acquired pneumonia as secondary diagnosis when primary diagnosis is not respiratory disorders and adult atelectasis; secondary diagnosis of decubitus ulcer in patients not transferred from another hospital; falls in hospital when a primary diagnosis was not fracture or injury; adult atelectasis as secondary diagnosis when primary diagnosis is not respiratory disorders, secondary diagnosis of post surgical infections; cardiac arrest as secondary diagnosis when primary diagnosis is not circulatory disorder, % of RN FTE/total nurses FTE | Unit | Combined | 68.5 | | 0.55
| Patients | Combined | 69.2 | | 0.49
| Race | 45.37 | 70.2 | | 0.53
| Sex | 42.43 | 71.2 | | 0.69
| | | 71.5 | | 0.67
| | | 71.4 | | 0.73
| | | 71.8 | | 0.73
| | | 70 | | 0.68
| | | 63 | | 0.78
| | | 70 | | 0.69
| | | 63 | | 0.75
| | | Increase by 1% in RN proportion | | -0.00090
| | | Increase by 1% in RN proportion in small hospitals | | -0.00070
| | | Increase by 1% in RN proportion in medium hospitals | | -0.00120
| | | Increase by 1% in RN proportion in large hospitals | | 0.00010
| | | | | Surgical wound infections
| | | 68.5 | | 0.29
| | | 69.2 | | 0.26
| | | 70.2 | | 0.24
| | | 71.2 | | 0.28
| | | 71.5 | | 0.28
| | | 71.4 | | 0.31
| | | 71.8 | | 0.30
| | | 70 | | 0.27
| | | 63 | | 0.28
| | | 70 | | 0.30
| | | 63 | | 0.31
| | | Increase by 1% in RN proportion | | 0.00
| | | Increase by 1% in RN proportion in small hospitals | | 0.00
| | | Increase by 1% in RN proportion in medium hospitals | | 0.00
| | | Increase by 1% in RN proportion in large hospitals | | 0.00
| | | | | Pneumonia
| | | 68.5 | | 0.98
| | | 69.2 | | 0.91
| | | 70.2 | | 0.96
| | | 71.2 | | 1.54
| | | 71.5 | | 1.55
| | | 71.4 | | 1.63
| | | 71.8 | | 1.64
| | | Increase by 1% in RN proportion | | -0.00090
| | | Increase by 1% in RN proportion in small hospitals | | -0.00220
| | | Increase by 1% in RN proportion in medium hospitals | | -0.00050
| | | Increase by 1% in RN proportion in large hospitals | | -0.00030
| | | | | Falls
| | | 68.5 | | 0.04
| | | 69.2 | | 0.04
| | | 70.2 | | 0.16
| | | 71.2 | | 0.91
| | | 71.5 | | 0.86
| | | 71.4 | | 0.74
| | | 71.8 | | 0.72
| | | Increase by 1% in RN proportion | | 0.00010
| | | Increase by 1% in RN proportion in small hospitals | | 0.00050
| | | Increase by 1% in RN proportion in medium hospitals | | -0.00030
| | | Increase by 1% in RN proportion in large hospitals | | 0.00010
| | | | | Pulmonary failure
| | | 68.5 | | 0.52
| | | 69.2 | | 0.46
| | | 70.2 | | 0.47
| | | 71.2 | | 0.63
| | | 71.5 | | 0.68
| | | 71.4 | | 0.70
| | | 71.8 | | 0.69
| | | Increase by 1% in RN proportion | | -0.00030
| | | Increase by 1% in RN proportion in small hospitals | | 0.00010
| | | Increase by 1% in RN proportion in medium hospitals | | -0.00060
| | | Increase by 1% in RN proportion in large hospitals | | 0.00070
| | | | | CPR
| | | 68.5 | | 0.54
| | | 69.2 | | 0.48
| | | 70.2 | | 0.50
| | | 71.2 | | 0.61
| | | 71.5 | | 0.64
| | | 71.4 | | 0.63
| | | 71.8 | | 0.60
| | | Increase by 1% in RN proportion | | 0.00
| | | Increase by 1% in RN proportion in small hospitals | | 0.00
| | | Increase by 1% in RN proportion in medium hospitals | | 0.00
| | | Increase by 1% in RN proportion in large hospitals | | 0.00
| | | | | Pressure ulcers
| | | Increase by 1% in RN proportion | | -0.00010
| | | Increase by 1% in RN proportion in small hospitals | | -0.00020
| | | Increase by 1% in RN proportion in medium hospitals | | 0.00001
| | | Increase by 1% in RN proportion in large hospitals | | -0.00010
Wan^52^ | Hospitals | 45 | | | Falls, rate/100 patient days
Incidence/1,000 patient days of falls adjusted for severity of incident, RN hours/total nursing hours | Unit | Combined | Increase by 1% of RNs/total nursing hours | | -0.05
| Patients | Combined | 52% of RNs | | 0.31 ± 0.05
Zidek^85^ | Hospitals | 1 | % RN | | Rate, %
New incidence of skin breakdown acquired over the course of the hospital stay; number of reported unplanned descents to the floor during the course of the hospital stay. % of RN FTE/total nursing FTE | Unit | Combined | | | Falls | Pressure ulcer
| Patients | Medical-surgical | 31 | | 0.59 | 0.18
| | | 31 | | 0.45 | 0.05
| | | 28 | | 0.83 | 0.26
| | | 32 | | 0.52 | 0.09
| | | 30 | | 0.28 | 0.00
| | | 30 | | 0.25 | 0.06
| | | 31 | | 0.23 | 0.17
| | | 33 | | 0.63 | 0.37
| | | 32 | | 0.61 | 0.09
| | | 31 | | 0.62 | 0.24
| | | 33 | | 0.66 | 0.18
| | | 30 | | 0.66 | 0.11

BSN = Bachelor of Science in Nursing; CPR = Cardio Pulmonary Resuscitation; DRG = Diagnosis Related Group; HPF = high-powered field; ICU = Intensive Care Unit; LPN = Licensed Practical Nurse; NS = Not Significant; RN = Registered Nurse; SD = Standard Deviation; SWI = Surgical Wound Infection; UTI = Urinary Tract Infection

Table G28 Relative risk of patient outcomes corresponding to an increase by 1% of RNs in nurse skill mix as reported by authors

Author | Data | Analytic Unit | Hospitals | Unit | Patients | Outcomes | Relative Risk | 95% CI
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Urinary tract infection | 0.40 | 0.29; 0.55
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Urinary tract infection | 0.58 | 0.36; 0.96
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Urinary tract infection | 0.46 | 0.34; 0.63
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Urinary tract infection | 1.02 | 0.73; 1.44
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Urinary tract infection | 0.33 | 0.18; 0.61
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Urinary tract infection | 0.50 | 0.30; 0.84
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Urinary tract infection | 0.82 | 0.47; 1.44
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Urinary tract infection | 0.09 | 0.01; 0.91
Needleman^29^ | Administrative | Hospital | 799 | Combined | Surgical | Urinary tract infection | 0.67 | 0.46; 0.98
Hope^86^ | Administrative | Patient | 1 | Combined | Medical | Urinary tract infection | 1.01 | 1.00; 1.01
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Gastrointestinal bleeding | 0.60 | 0.36; 0.97
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Gastrointestinal bleeding | 0.45 | 0.18; 1.11
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Gastrointestinal bleeding | 0.81 | 0.58; 1.12
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Gastrointestinal bleeding | 0.27 | 0.09; 0.78
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Gastrointestinal bleeding | 0.89 | 0.52; 1.53
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Gastrointestinal bleeding | 0.93 | 0.56; 1.55
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Gastrointestinal bleeding | 0.02 | 0.00; 0.51
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Gastrointestinal bleeding | 0.04 | 0.00; 0.64
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Pneumonia | 0.52 | 0.35; 0.77
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Pneumonia | 0.41 | 0.19; 0.86
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Pneumonia | 0.49 | 0.32; 0.76
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Pneumonia | 0.23 | 0.10; 0.53
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Pneumonia | 0.44 | 0.22; 0.86
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Pneumonia | 1.02 | 0.72; 1.44
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Pneumonia | 0.61 | 0.30; 1.23
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Pneumonia | 0.78 | 0.40; 1.52
Hope^86^ | Administrative | Patient | 1 | Combined | Medical | Pneumonia | 1.06 | 0.93; 1.21
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Shock | 0.84 | 0.71; 0.99
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Shock | 1.08 | 0.60; 1.96
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Shock | 0.52 | 0.31; 0.89
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Shock | 0.36 | 0.14; 0.93
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Shock | 0.30 | 0.12; 0.72
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Shock | 0.34 | 0.16; 0.75
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Shock | 0.14 | 0.05; 0.43
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Shock | 0.17 | 0.06; 0.47
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Failure to rescue | 0.85 | 0.70; 1.03
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Failure to rescue | 0.64 | 0.44; 0.92
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Failure to rescue | 0.85 | 0.70; 1.04
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Failure to rescue | 0.69 | 0.45; 1.06
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Failure to rescue | 0.63 | 0.47; 0.84
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Failure to rescue | 0.70 | 0.54; 0.90
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Failure to rescue | 0.36 | 0.14; 0.89
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Failure to rescue | 0.44 | 0.20; 0.96
Needleman^29^ | Administrative | Hospital | 799 | Combined | Surgical | Failure to rescue | 0.73 | 0.49; 1.09
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Pulmonary failure | 0.94 | 0.56; 1.56
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Pulmonary failure | 0.76 | 0.43; 1.34
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Pulmonary failure | 0.81 | 0.41; 1.60
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Pulmonary failure | 0.86 | 0.46; 1.59
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Pressure ulcers | 0.44 | 0.23; 0.86
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Pressure ulcers | 0.27 | 0.09; 0.83
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Pressure ulcers | 0.65 | 0.36; 1.17
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Pressure ulcers | 0.01 | 0.00; 0.29
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Pressure ulcers | 0.00 | 0.00; 0.11
Hope^86^ | Administrative | Patient | 1 | Combined | Combined | Nosocomial infections | 1.06 | 1.03; 1.09
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Surgical wound infection | 1.03 | 0.66; 1.60
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Surgical wound infection | 1.31 | 0.73; 2.38
Hope^86^ | Administrative | Patient | 1 | Combined | Surgical | Surgical wound infection | 1.03 | 0.99; 1.08
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Deep vein thrombosis | 1.05 | 0.64; 1.71
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Deep vein thrombosis | 1.39 | 0.66; 2.91
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Deep vein thrombosis | 0.78 | 0.39; 1.57
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Deep vein thrombosis | 0.75 | 0.40; 1.40
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Deep vein thrombosis | 1.55 | 0.51; 4.76
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Deep vein thrombosis | 1.87 | 0.69; 5.04
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Complications | 3.06 | 0.94; 10.03
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Complications | 18.55 | 1.22; 281.24
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Complications | 1.68 | 0.66; 4.27
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Complications | 0.68 | 0.29; 1.58
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Complications | 0.74 | 0.32; 1.68
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Complications | 0.57 | 0.17; 1.91
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Complications | 0.71 | 0.20; 2.48
Needleman^28^ | Administrative | Hospital | 4,156 | Medical | Medical | Sepsis | 1.55 | 0.93; 2.61
Needleman^28^ | Administrative | Hospital | 4,156 | Surgical | Surgical | Sepsis | 1.15 | 0.72; 1.84
Needleman^28^ | Administrative | Hospital | 3,357 | Medical | Medical | Sepsis | 0.83 | 0.56; 1.22
Needleman^28^ | Administrative | Hospital | 3,357 | Surgical | Surgical | Sepsis | 0.74 | 0.43; 1.28
Needleman^28^ | Administrative | Hospital | 256 | Medical | Medical | Sepsis | 1.08 | 0.61; 1.91
Needleman^28^ | Administrative | Unit | 256 | Medical | Medical | Sepsis | 1.03 | 0.61; 1.75
Needleman^28^ | Administrative | Hospital | 256 | Surgical | Surgical | Sepsis | 0.00 | 0.00; 0.85
Needleman^28^ | Administrative | Unit | 256 | Surgical | Surgical | Sepsis | 0.99 | 0.51; 1.92
Hope^86^ | Administrative | Patient | 1 | Combined | Medical | Sepsis | 1.05 | 1.04; 1.07

Table G29 Evidence of the association between nurse strategies (overtime hours, temporary nurse hours, full-time hours) and patient outcomes

Author, Definition of Patient Outcomes, Definition of Nurse Strategies | Number of Hospitals, Units, Patient Age, % of Whites, % of Males, % of Emergency Admissions | | Nurse Staffing Categories | | | Patient Outcomes
Alonso-Echanove^79^ | Hospitals | 6 | | | | Relative risk
Bloodstream infections as secondary diagnosis after CVC, duration of CVC, number of days from the placement date to the day when bloodstream infection occurred or to the day of CVC removal, % of temporary nurses/ float nurses in unit each day; float nurse = a nurse not permanently assigned to the participating ICU, agency nurses, and nurses from other units or hospital areas who had been working in the participating ICU less than a year | Unit | ICU | | | | Nosocomial infection
| Patients | Medical | Patients cared for by float nurse, days >60% | | | 2.75 | 1.45 | 5.22
| Race | 61 | Patients cared by float nurse, days >60% | | | 2.61 | 1.21 | 5.59
| Sex | 54 | Patients cared for by float nurse, days <60% | | | 1.00 | 1.00 | 1.00
Berney^84^ | Hospitals | 161 | | | | Relative risk
Actual number of events identified as secondary DRG: urinary tract infection, gastrointestinal bleeding, pneumonia, shock, failure to rescue, sepsis | Unit | Patients | | | | Urinary tract infection
| Surgical | Surgical | 1% increase in RN overtime hours | | | 1.01 | 0.99 | 1.02
| Medical | Medical | 1st (low overtime) quartile | | 1.6% | 1.00 | 0.99 | 1.01
| Medical | Medical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
| Medical | Medical | 1% increase in RN overtime hours | | .00% | 1.01 | 1.00 | 1.02
| Surgical | Surgical | 1st (low overtime) quartile | | 1.6% | 1.01 | 0.99 | 1.02
| Surgical | Surgical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
| | | | | | Gastrointestinal bleeding
| Surgical | Surgical | 1% increase in RN overtime hours | | | 1.02 | 0.99 | 1.05
| Medical | Medical | 1st (low overtime) quartile | | 1.6% | 0.98 | 0.96 | 1.01
| Medical | Medical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
| Medical | Medical | 1% increase in RN overtime hours | | .00% | 1.01 | 0.98 | 1.03
| Surgical | Surgical | 1st (low overtime) quartile | | 1.6% | 1.00 | 0.96 | 1.03
| Surgical | Surgical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
| | | | | | Pneumonia
| Surgical | Surgical | 1% increase in RN overtime hours | | | 1.02 | 1.00 | 1.04
| Medical | Medical | 1st (low overtime) quartile | | 1.6% | 1.01 | 0.99 | 1.02
| Medical | Medical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
| Medical | Medical | 1% increase in RN overtime hours | | .00% | 1.01 | 1.00 | 1.02
| Surgical | Surgical | 1st (low overtime) quartile | | 1.6% | 1.01 | 0.99 | 1.04
| Surgical | Surgical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
| | | | | | Shock
| Surgical | Surgical | 1% increase in RN overtime hours | | | 1.01 | 0.98 | 1.03
| Medical | Medical | 1st (low overtime) quartile | | 1.6% | 1.01 | 0.99 | 1.03
| Medical | Medical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
| Medical | Medical | 1% increase in RN overtime hours | | 00% | 1.02 | 1.00 | 1.04
| Surgical | Surgical | 1st (low overtime) quartile | | 1.6% | 1.00 | 0.98 | 1.02
| Surgical | Surgical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
| | | | | | Failure to rescue
| Surgical | Surgical | 1% increase in RN overtime hours | | | 1.00 | 0.99 | 1.01
| Medical | Medical | 1st (low overtime) quartile | | 1.6% | 1.00 | 0.99 | 1.00
| Medical | Medical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
| Medical | Medical | 1% increase in RN overtime hours | | .00% | 1.00 | 1.00 | 1.01
| Surgical | Surgical | 1st (low overtime) quartile | | 1.6% | 1.00 | 0.99 | 1.01
| Surgical | Surgical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
| | | | | | Sepsis
| Surgical | Surgical | 1% increase in RN overtime hours | | | 1.02 | 1.00 | 1.04
| Medical | Medical | 1st (low overtime) quartile | | 1.6% | 1.01 | 0.99 | 1.02
| Medical | Medical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
| Medical | Medical | 1% increase in RN overtime hours | | .00% | 1.03 | 1.01 | 1.04
| Surgical | Surgical | 1st (low overtime) quartile | | 1.6% | 1.02 | 1.00 | 1.03
| Surgical | Surgical | 4th (high overtime) quartile | | 7.4% | 1.00 | 1.00 | 1.00
Cho^30^ | Unit | Combined | % Contract hours | | % of RN | Rate, % ± SD
ICD-9-CM for urinary tract infection, pressure ulcers, falls and injury, surgical wound infection, and sepsis; | Patients | Combined | | | | Urinary tract infection
Contracted hours = productive nursing hours (direct care to patient) worked by nursing personnel contracted on a temporary basis. Contract hours * % of RN | Age | 67.9 | 3.60 | | 76.5 | 2.50 ± 1.30
| Race | 79.3 | 3.30 | | 68.1 | 1.60 ± 1.40
| Sex | 48.9 | 3.20 | | 72.4 | 2.00 ± 1.00
| Severity | 49.7 | 5.00 | | 72.7 | 2.10 ± 1.80
| | | | | | Pneumonia
| | | 3.60 | 76.5 | | 3.10 ± 1.90
| | | 3.30 | 68.1 | | 2.70 ± 2.20
| | | 3.20 | 72.4 | | 2.80 ± 1.30
| | | 5.00 | 72.7 | | 2.80 ± 2.00
| | | | | | Falls
| | | 3.60 | 76.5 | | 0.20 ± 0.20
| | | 3.30 | 68.1 | | 0.20 ± 0.30
| | | 3.20 | 72.4 | | 0.20 ± 0.20
| | | 5.00 | 72.7 | | 0.10 ± 0.20
| | | | | | Pressure ulcers
| | | 3.60 | 76.5 | | 0.10 ± 0.30
| | | 3.30 | 68.1 | | 0.30 ± 0.60
| | | 3.20 | 72.4 | | 0.30 ± 0.50
| | | 5.00 | 72.7 | | 0.20 ± 0.40
| | | | | | Surgical wound infections
| | | 3.60 | 76.5 | | 1.60 ± 1.00
| | | 3.30 | 68.1 | | 1.10 ± 1.10
| | | 3.20 | 72.4 | | 1.50 ± 0.70
| | | 5.00 | 72.7 | | 1.10 ± 1.00
| | | | | | Sepsis
| | | 3.60 | 76.5 | | 1.20 ± 0.70
| | | 3.30 | 68.1 | | 0.80 ± 0.80
| | | 3.20 | 72.4 | | 1.10 ± 0.60
| | | 5.00 | 72.7 | | 1.00 ± 1.10
Cimiotti^87^ | Hospitals | 1 | | | | Rate, %
Infections occurring in an infant 48 hours or longer after admission to the NICU including bloodstream infections, device associated pneumonia, CNS and skin infections, conjunctivitis; hours/patient day worked by float pool and agency RN not regularly assigned to the NICU | Unit | Neonatal | | | | Pneumonia | Nosocomial infection
| Patients | Medical | 0.19% of float nurses | | | 0.50 | 18.30
| | | 24.07% of float nurse | | | 0.90 | 15.10
| | | | | | Sepsis
| | | 0.19% of float nurses | | | 10.50
| | | 24.07% of float nurse | | | 5.50
| | | | | | Relative risk
| | | | | | Nosocomial infection
| | | Mean staffing levels | 12.13% | | Reference
| | | Low % of pooled nurses | 14.19% | | 1.30
| | | High % of pooled nurses | 12.13% | | 1.30
| | | | | | Sepsis rate%
| | | Mean staffing levels | 12.13% | | 1.00
| | | Low % of pooled nurses | 14.19% | | 2.01
| | | High % of pooled nurses | 12.13% | | 2.06
Donaldson^9^ | Hospitals | 68 | % contract hours | % RN | | Rate/100 patient days ± SD
Total number of patients with Stage I–IV pressure ulcers regardless of whether ulcer was acquired during hospitalization or present on admission; % total number of surveyed patients; unplanned descent to the floor; rate/1,000 patient days, total number of productive hours worked only by those with direct patient care responsibilities who are contract staff (registry, travelers). It does not include internal float staff | | | 8.43 | 59.2 | | 0.31 ± 0.20
| | | 8.04 | 66.67 | | 0.32 ± 0.17
| | | 9.22 | 68.79 | | 0.30 ± 0.22
| | | 10.74 | 72.19 | | 0.26 ± 0.16
Donaldson^95^ | Hospitals | 25 | | | | Rate/100 patient days ± SD
Hospital acquired pressure related skin injury controlling for date of admission, % of all patients on the day of prevalence study, patient's unplanned descent to the hospital floor; were analyzed as 7 day aggregate per unit; also actually number per unit; the number of falls/1,000 patient days, percent of contacted or agency staff. | Unit | Combined | | | | Falls
| Patients | Medical | Increase by 1% contracted hours of care | | | -0.001 ± 0.01
Potter^40^ | Hospitals | 1 | % float hours | % RN | | Rate/100 patient days
(Number of falls on a unit/number of patient days) * 1,000, an average % of float nurses in day shift provided by nurses from other units or outside the hospital | Unit | ICU | | | | Falls
| Patients | Medical | 7.30 | 53.8 | | 0.30
| | | 11.00 | 55.4 | | 0.29
| | | 8.80 | 56.2 | | 0.30
| | | 10.10 | 57.1 | | 0.23
Robert^6^ | Hospitals | 1 | % of contract hours | | | Nosocomial infection, rate/100 patient days
Primary bloodstream infections (BSIs) (CDC). Index date for cases, the day of 1 positive blood culture; for controls = (cases LOS before BSI/total cases LOS) * control total LOS, % of pool staff - not regular full-time employees of the hospital assigned to SICU. | Unit | ICU
| Patients | Surgical | 17.19 | | | 0.28
| | | 32.59 | | | 0.76
| | | | | | Relative risk
| | | 17.19 | | | 1.00 | 1.00 | 1.00
| | | 32.59 | | | 3.20 | 1.20 | 8.20
Stratton^91^ | Hospitals | 7 | % hours | | | Rate/100 patient days ± SD
Rate/1,000 patient days of respiratory, gastrointestinal, bloodstream and central line infections in hospitalized patients not present at time of admission, rate/1,000 patient days of bloodstream and central line infections in hospitalized patients not present at time of admission, % of total productive overtime nursing hours worked by RN, LPN, and UAP in each quarter 2002, % of RN productive hours worked by supplemental nurse staffing (total nursing overtime hours and percentages of hours from float/agency/traveler RN hours) | | | overtime | contract | RN | Nosocomial infection
| | | 18.06 | 14.05 | 73.41 | 0.75 ± 0.69
| | | 17.59 | 13.91 | 72.06 | 0.53 ± 0.67
| | | 17.59 | 14.03 | 72.41 | 0.71 ± 0.77
| | | 14.71 | 11.53 | 74 | 0.64 ± 0.43
| | | 17.20 | 17.95 | 83.2 | 0.65 ± 0.23
| | | 16.20 | 17.53 | 79 | 0.62 ± 0.39
| | | 17.20 | 17.93 | 79.6 | 0.71 ± 0.59
| | | 16.80 | 18.08 | 80.2 | 0.85 ± 0.50
| | | 16.92 | 12.72 | 89 | 0.73 ± 0.56
| | | 15.67 | 12.03 | 88.17 | 1.03 ± 0.96
| | | 15.92 | 11.67 | 87.5 | 0.80 ± 0.69
| | | 16.58 | 12.52 | 88.5 | 0.95 ± 0.71
| | | 4.08 | 14.04 | 80.35 | 0.51 ± 0.08
| | | 3.84 | 13.67 | 78.76 | 0.79 ± 0.17
| | | 4.00 | 13.64 | 78.79 | 0.66 ± 0.12
| | | 3.52 | 12.68 | 80.03 | 0.56 ± 0.17
| | | Increase by 1% in overtime RN hours | | | -0.01 ± 0.02
| | | Increase by 1% in temporary nurses | | | 0.00380 ± 0.01
Tourangeau^76^ | Hospitals | 75 | % fulltime | % RN | | Rate, %
30 day mortality, % of full time nurses | Unit | Combined | 0.67 | 85 | | 14.02
| Patients | Medical | 0.55 | 71 | | 15.27
| | | 0.62 | 79 | | 15.05

BSI = Bloodstream infection; CNS = Central nervous system; CVC = Central venous catheter DRG = Diagnosis related group; ICU = Intensive care unit; LOS = Length of stay; NISU = Neonatal intensive care unit; RN = Registered Nurse; SD = Standard deviation; SICU = Surgical intensive care unit

Table G30 The significant effect modification by the study design of the association between nurse staffing and patient outcomes

| Outcomes Rates (N=16) | Outcomes Relative Risk (N=19)
Quality scores | % Significant interactions | % Significant interactions
Patients/RN/shift | 12.5 | 21.1
RN FTE/patient day | 12.5 | 15.8
Patients/LPN | 31.3 | 5.3
Total nurse hours | 6.3 | 0
RN hours/patient day | 12.5 | 21.1
LPN hours | 31.3 | 0
UAP hours | 6.3 | 0

## References for Evidence Tables

1 Fridkin SK, Pear SM, Williamson TH, et al. The role of understaffing in central venous catheter-associated bloodstream infections. Infect Control Hosp Epidemiol. Mar. 1996;17(3):150-8. [pmid: 8708352].
2 Arnow P, Allyn PA, Nichols EM, et al. Control of methicillin-resistant Staphylococcus aureus in a burn unit: role of nurse staffing. J Trauma. Nov. 1982;22(11):954-9. [pmid: 6923938].
3 Marcin JP, Rutan E, Rapetti PM, et al. Nurse staffing and unplanned extubation in the pediatric intensive care unit. Pediatr Crit Care Med. Apr. 2005;6(3):254-7. [pmid: 15857520].
4 Aiken LH, Sloane DM, Sochalski J. Hospital organisation and outcomes. Qual Health Care. Dec. 1998;7(4):222-6. [pmid: 10339024].
5 Aiken LH, Sloane DM, Lake ET, et al. Organization and outcomes of inpatient AIDS care. Med Care. Aug. 1999;37(8):760-72. [pmid: 10448719].
6 Robert J, Fridkin SK, Blumberg HM, et al. The influence of the composition of the nursing staff on primary bloodstream infection rates in a surgical intensive care unit. Infect Control Hosp Epidemiol. Jan. 2000;21(1):12-7. [pmid: 10656348].
7 Aiken LH, Smith HL, Lake ET. Lower Medicare mortality among a set of hospitals known for good nursing care. Med Care. Aug. 1994;32(8):771-87. [pmid: 8057694].
8 Seago JA. Evaluation of a hospital work redesign: patient-focused care. J Nurs Adm. Nov. 1999;29(11):31-8. [pmid: 10565318].
9 Donaldson N, Bolton LB, Aydin C, et al. Impact of California's licensed nurse-patient ratios on unit-level nurse staffing and patient outcomes. Policy Polit Nurs Pract. Aug. 2005;6(3):198-210. [pmid: 16443975].
10 Grillo-Peck AM, Risner PB. The effect of a partnership model on quality and length of stay. Nurs Econ Nov–Dec 1995;13(6):367–72, 74.
11 Hartz AJ, Krakauer H, Kuhn EM, et al. Hospital characteristics and mortality rates. N Engl J Med. Dec 21. 1989;321(25):1720-5. [pmid: 2594031].
12 Krakauer H, Bailey RC, Skellan KJ, et al. Evaluation of the HCFA model for the analysis of mortality following hospitalization. Health Serv Res. Aug. 1992;27(3):317-35. [pmid: 1500289]. [pmcid: 1069881].
13 McDaniel C, Patrick T. Leadership, nurses, and patient satisfaction: a pilot study. Nurs Adm Q. Spring. 1992;16(3):72-4. [pmid: 1584481].
14 Halpine S, Maloney S. Tracing the missing link between nursing workload and case mix groups: a validation study. Healthc Manage Forum. Fall. 1993;6(3):19-26. [pmid: 10129770].
15 Shamian J, Hagen B, Hu TW, et al. The relationship between length of stay and required nursing care hours. J Nurs Adm. Jul–Aug. 1994;24(78):52-8. [pmid: 8057174].
16 Taunton RL, Kleinbeck SV, Stafford R, et al. Patient outcomes. Are they linked to registered nurse absenteeism, separation, or work load?. J Nurs Adm. Apr. 1994;24(4 Suppl):48-55. [pmid: 8068081].
17 Dugan J, Lauer E, Bouquot Z, et al. Stressful nurses: the effect on patient outcomes. J Nurs Care Qual. Apr. 1996;10(3):46-58. [pmid: 8634470].
18 Bloom JR, Alexander JA, Nuchols BA. Nurse staffing patterns and hospital efficiency in the United States. Soc Sci Med. Jan. 1997;44(2):147-55. [pmid: 9015868].
19 Minnick AF, Roberts MJ, Young WB, et al. What influences patients' reports of three aspects of hospital services?. Med Care. Apr. 1997;35(4):399-409. [pmid: 9107207].
20 Melberg SE. Effects of changing skill mix. Nurs Manage. Nov. 1997;28(11):47-8. [pmid: 9385157].
21 Leiter MP, Harvie P, Frizzell C. The correspondence of patient satisfaction and nurse burnout. Soc Sci Med. Nov. 1998;47(10):1611-7. [pmid: 9823056].
22 Kovner C, Gergen PJ. Nurse staffing levels and adverse events following surgery in U.S. hospitals. Image J Nurs Sch. 1998;30(4):315-21. [pmid: 9866290].
23 Hoover KW. The impact of managed care penetration, hospital organizational variables and nurse staffing on hospital patient outcomes. Dissertation 2000;DAI-B 61/08, p. 4062, Feb 2001:AAT 9984608.
24 Gandjour A. The effect of managed care penetration on hospital staffing in Tennessee, 1991—1995. Manag Care Interface Sep 2000;13(9):62–6, 70.
25 Ridge RA. The relationship between patient satisfaction with nursing care and nurse staffing. Dissertation 2001;DAI-B 62/01, p. 165, Jul 2001:AAT 3000170.
26 Bolton LB, Jones D, Aydin CE, et al. A response to California's mandated nursing ratios. J Nurs Scholarsh. 2001;33(2):179-84. [pmid: 11419315].
27 Aiken LH, Clarke SP, Sloane DM. Hospital restructuring: does it adversely affect care and outcomes?. J Health Hum Serv Adm. Spring. 2001;23(4):416-42. [pmid: 11924307].
28 Needleman J. NURSE STAFFING AND PATIENT OUTCOMES IN HOSPITALS. Final Report for Health Resources Services Administration 2001;Contract No. 230990021.
29 Needleman J, Buerhaus P, Mattke S, et al. Nurse-staffing levels and the quality of care in hospitals. N Engl J Med. May 30. 2002;346(22):1715-22. [pmid: 12037152].
30 Cho S-H. Nurse staffing and adverse patient outcomes. Dissertation 2002;DAI-B 63/02, p. 735, Aug 2002:AAT 3042055.
31 Oster CAH. The relationships between emergency department staffing and clinical outcomes of the acute myocardial infarction patient. Dissertation 2002;DAI-B 63/03, p. 1272, Sep 2002:AAT 3045751.
32 Cheung RB. The relationship between nurse staffing, nursing time, and adverse events in an acute care hospital. Dissertation 2002;DAI-B 63/05, p. 2301, Nov 2002:AAT 3052636.
33 Langemo DK, Anderson J, Volden CM. Nursing quality outcome indicators. The North Dakota Study. J Nurs Adm. Feb. 2002;32(2):98-105. [pmid: 11984237].
34 Seago JA, Ash M. Registered nurse unions and patient outcomes. J Nurs Adm. Mar. 2002;32(3):143-51. [pmid: 11984245].
35 Kovner C, Jones C, Zhan C, et al. Nurse staffing and postsurgical adverse events: an analysis of administrative data from a sample of U.S. hospitals, 1990-1996. Health Serv Res. Jun. 2002;37(3):611-29. [pmid: 12132597]. [pmcid: 1434654].
36 Whitman GR, Kim Y, Davidson LJ, et al. The impact of staffing on patient outcomes across specialty units. J Nurs Adm. Dec. 2002;32(12):633-9. [pmid: 12483084].
37 Beckman JAS. The effectiveness of nursing practice patterns in acute care nursing sub-units. Dissertation 2003;DAI-B 64/11, p. 5445, May 2004:AAT 3111973.
38 Cho SH, Ketefian S, Barkauskas VH, et al. The effects of nurse staffing on adverse events, morbidity, mortality, and medical costs. Nurs Res. Mar–Apr. 2003;52(2):71-9. [pmid: 12657982].
39 Aiken LH, Clarke SP, Cheung RB, et al. Educational levels of hospital nurses and surgical patient mortality. Jama. Sep 24. 2003;290(12):1617-23. [pmid: 14506121].
40 Potter P, Barr N, McSweeney M, et al. Identifying nurse staffing and patient outcome relationships: a guide for change in care delivery. Nurs Econ. Jul–Aug. 2003;21(4):158-66. [pmid: 14509874].
41 Langemo DK, Anderson J, Volden C. Uncovering pressure ulcer incidence. Nurs Manage. Oct. 2003;34(10):54-7. [pmid: 14557784].
42 Bolton LB, Aydin CE, Donaldson N, et al. Nurse staffing and patient perceptions of nursing care. J Nurs Adm. Nov. 2003;33(11):607-14. [pmid: 14608220].
43 Needleman J, Buerhaus PI, Mattke S, et al. Measuring hospital quality: can medicare data substitute for all-payer data?. Health Serv Res. Dec. 2003;38(6 Pt 1):1487-508. [pmid: 14727784]. [pmcid: 1360960].
44 Vahey DC, Aiken LH, Sloane DM, et al. Nurse burnout and patient satisfaction. Med Care. Feb. 2004;42(2 Suppl):II57-66. [pmid: 14734943].
45 Sochalski J. Is more better?: the relationship between nurse staffing and the quality of nursing care in hospitals. Med Care. Feb. 2004;42(2 Suppl):II67-73. [pmid: 14734944].
46 Van Doren ES, Bowman J, Landstrom GL, et al. Structure and process variables affecting outcomes for heart failure clients. Lippincotts Case Manag. Jan–Feb. 2004;9(1):21-6. [pmid: 15076834].
47 Boyle SM. Nursing unit characteristics and patient outcomes. Nurs Econ May–Jun 2004;22(3):111–9, 23, 07.
48 Tschannen DJ. Organizational structure, process, and outcome: The effects of nurse staffing and nurse-physician collaboration on patient length of stay. Dissertation 2005;DAI-B 66/02, p. 821, Aug 2005:AAT 3163954.
49 Houser E. Nurse staffing levels and patient outcomes. Dissertation 2005;DAI-B 66/04, p. 1978, Oct 2005:AAT 3172609.
50 Estabrooks CA, Midodzi WK, Cummings GG, et al. The impact of hospital nursing characteristics on 30-day mortality. Nurs Res. Mar–Apr. 2005;54(2):74-84. [pmid: 15778649].
51 Halm M, Peterson M, Kandels M, et al. Hospital nurse staffing and patient mortality, emotional exhaustion, and job dissatisfaction. Clin Nurse Spec. Sep–Oct. 2005;19(5):241-51. quiz 52–4. [pmid: 16179855].
52 Wan TT, Shukla RK. Contextual and organizational correlates of the quality of hospital nursing care. QRB Qual Rev Bull. Feb. 1987;13(2):61-4. [pmid: 3104860].
53 Flood SD, Diers D. Nurse staffing, patient outcome and cost. Nurs Manage May 1988;19(5):34–5, 8–9, 42–3.
54 Shortell SM, Hughes EF. The effects of regulation, competition, and ownership on mortality rates among hospital inpatients. N Engl J Med. Apr 28. 1988;318(17):1100-7. [pmid: 3127713].
55 Thorson MJ. Hours of nursing care: Relationship to patient outcomes. Dissertation 1995;DAI-B 57/02, p. 992, Aug 1996:AAT 9616239.
56 ANA. Implementing Nursing's Report Card. A Study of RN Staffing, Length of Stay and Patient Outcomes. The American Nurses Association. 1997;American Nurses Publishing, Washington DC, 1997.:ISBN 1558101349.
57 Archibald LK, Manning ML, Bell LM, et al. Patient density, nurse-to-patient ratio and nosocomial infection risk in a pediatric cardiac intensive care unit. Pediatr Infect Dis J. Nov. 1997;16(11):1045-8. [pmid: 9384337].
58 Blegen MA, Vaughn T. A multisite study of nurse staffing and patient occurrences. Nurs Econ. Jul–Aug. 1998;16(4):196-203. [pmid: 9748985].
59 Blegen MA, Goode CJ, Reed L. Nurse staffing and patient outcomes. Nurs Res. Jan–Feb. 1998;47(1):43-50. [pmid: 9478183].
60 Bond CA, Raehl CL, Pitterle ME, et al. Health care professional staffing, hospital characteristics, and hospital mortality rates. Pharmacotherapy. Feb. 1999;19(2):130-8. [pmid: 10030762].
61 Pronovost PJ, Jenckes MW, Dorman T, et al. Organizational characteristics of intensive care units related to outcomes of abdominal aortic surgery. Jama. Apr 14. 1999;281(14):1310-7. [pmid: 10208147].
62 Robertson RH, Hassan M. Staffing intensity, skill mix and mortality outcomes: the case of chronic obstructive lung disease. Health Serv Manage Res. Nov. 1999;12(4):258-68. [pmid: 10622804].
63 Lichtig LK, Knauf RA, Milholland DK. Some impacts of nursing on acute care hospital outcomes. J Nurs Adm. Feb. 1999;29(2):25-33. [pmid: 10029799].
64 Amaravadi RK, Dimick JB, Pronovost PJ, et al. ICU nurse-to-patient ratio is associated with complications and resource use after esophagectomy. Intensive Care Med. Dec. 2000;26(12):1857-62. [pmid: 11271096].
65 ANA. Nurse Staffing and Patient Outcomes: In the Inpatient Hospital Setting. American Nurses Publishing, Washington DC, 1997 2000:1558101519.
66 Unruh LY. The impact of hospital nurse staffing on the quality of patient care. Dissertation 2000;DAI-A 61/04, p. 1543, Oct 2000:AAT 9969789.
67 Silber JH, Kennedy SK, Even-Shoshan O, et al. Anesthesiologist direction and patient outcomes. Anesthesiology. Jul. 2000;93(1):152-63. [pmid: 10861159].
68 Whitman GR, Davidson LJ, Sereika SM, et al. Staffing and pattern of mechanical restraint use across a multiple hospital system. Nurs Res. Nov–Dec. 2001;50(6):356-62. [pmid: 11725937].
69 Ritter-Teitel J. An exploratory study of a predictive model for nursing-sensitive patient outcomes derived from patient care unit structure and process variables. Dissertation 2001;DAI-B 62/02, p. 785, Aug 2001:AAT 3003686.
70 Dimick JB, Swoboda SM, Pronovost PJ, et al. Effect of nurse-to-patient ratio in the intensive care unit on pulmonary complications and resource use after hepatectomy. Am J Crit Care. Nov. 2001;10(6):376-82. [pmid: 11688604].
71 Sovie MD, Jawad AF. Hospital restructuring and its impact on outcomes: nursing staff regulations are premature. J Nurs Adm. Dec. 2001;31(12):588-600. [pmid: 11771464].
72 Pronovost PJ, Dang D, Dorman T, et al. Intensive care unit nurse staffing and the risk for complications after abdominal aortic surgery. Eff Clin Pract. Sep–Oct. 2001;4(5):199-206. [pmid: 11685977].
73 Blegen MA, Vaughn TE, Goode CJ. Nurse experience and education: effect on quality of care. J Nurs Adm. Jan. 2001;31(1):33-9. [pmid: 11198839].
74 Aiken LH, Clarke SP, Sloane DM, et al. Hospital nurse staffing and patient mortality, nurse burnout, and job dissatisfaction. Jama. Oct 23–30. 2002;288(16):1987-93. [pmid: 12387650].
75 Dang D, Johantgen ME, Pronovost PJ, et al. Postoperative complications: does intensive care unit staff nursing make a difference?. Heart Lung. May–Jun. 2002;31(3):219-28. [pmid: 12011813].
76 Tourangeau AE, Giovannetti P, Tu JV, et al. Nursing-related determinants of 30-day mortality for hospitalized patients. Can J Nurs Res. Mar. 2002;33(4):71-88. [pmid: 11998198].
77 Barkell NP, Killinger KA, Schultz SD. The relationship between nurse staffing models and patient outcomes: a descriptive study. Outcomes Manag. Jan–Mar. 2002;6(1):27-33. [pmid: 12500413].
78 Stegenga J, Bell E, Matlow A. The role of nurse understaffing in nosocomial viral gastrointestinal infections on a general pediatrics ward. Infect Control Hosp Epidemiol. Mar. 2002;23(3):133-6. [pmid: 11918117].
79 Alonso-Echanove J, Edwards JR, Richards MJ, et al. Effect of nurse staffing and antimicrobial-impregnated central venous catheters on the risk for bloodstream infections in intensive care units. Infect Control Hosp Epidemiol. Dec. 2003;24(12):916-25. [pmid: 14700407].
80 Mark BA, Salyer J, Wan TT. Professional nursing practice: impact on organizational and patient outcomes. J Nurs Adm. Apr. 2003;33(4):224-34. [pmid: 12690254].
81 Unruh L. Licensed nurse staffing and adverse events in hospitals. Med Care. Jan. 2003;41(1):142-52. [pmid: 12544551].
82 Simmonds KA. Nursing workload and its relationship to vancomycin-resistant enterococci colonization in chronic dialysis patients. Dissertation 2004;MAI 43/02, p. 529, Apr 2005:AAT MQ93404.
83 Tallier PC. Nurse staffing ratios and patient outcomes. Dissertation 2003;DAI-B 64/05, p. 2133, Nov 2003:AAT 3091301.
84 Berney BL. Use, trends, and impacts of nurse overtime in New York hospitals, 1995—2000. Dissertation 2003;DAI-B 63/11, p. 5154, May 2003:AAT 3072377.
85 Zidek CK. Assessment of nursing care quality and the judgment of the professional nurse as reflected in nurse-determined patient acuity classification and staffing decisions. Dissertation 2003;DAI-B 64/02, p. 642, Aug 2003:AAT 3080441.
86 Hope J. Nosocomial infections and their relationship to nursing workload in an acute care hospital. Dissertation 2003;MAI 42/04, p. 1241, Aug 2004:AAT MQ86117.
87 Cimiotti JP. Nurse staffing and healthcare-associated infections in the neonatal ICU. Dissertation 2004;DAI-B 65/04, p. 1775, Oct 2004:AAT 3128935.
88 Person SD, Allison JJ, Kiefe CI, et al. Nurse staffing and mortality for Medicare patients with acute myocardial infarction. Med Care. Jan. 2004;42(1):4-12. [pmid: 14713734].
89 Mark BA, Harless DW, McCue M, et al. A longitudinal examination of hospital registered nurse staffing and quality of care. Health Serv Res. Apr. 2004;39(2):279-300. [pmid: 15032955]. [pmcid: 1361008].
90 Mark BA, Harless DW, McCue M. The impact of HMO penetration on the relationship between nurse staffing and quality. Health Econ. Jul. 2005;14(7):737-53. [pmid: 15744748].
91 Stratton KM. The relationship between pediatric nurse staffing and quality of care in the hospital setting. Dissertation 2005;DAI-B 66/11, p. 5906, May 2006:AAT 3196584.
92 Elting LS, Pettaway C, Bekele BN, et al. Correlation between annual volume of cystectomy, professional staffing, and outcomes: a statewide, population-based study. Cancer. Sep 1. 2005;104(5):975-84. [pmid: 16044400].
93 Seago JA, Williamson A, Atwood C. Longitudinal analyses of nurse staffing and patient outcomes: more about failure to rescue. J Nurs Adm. Jan. 2006;36(1):13-21. [pmid: 16404195].
94 Shortell SM, Zimmerman JE, Rousseau DM, et al. The performance of intensive care units: does good management make a difference?. Med Care. Apr. 1994;32(5):508-25. [pmid: 8182978].
95 Donaldson NE DSB, Linda Burnes Bolton, Carolyn Aydin, Steven Paul, Bruce A. Cooper, Kathleen Yule. Unit Level Nurse Workload Impacts on Patient Safety. the Agency for Healthcare Research and Quality Working Conditions Grant Initiative 2004;Grant R01 # HS11954.
96 Lankshear AJ, Sheldon TA, Maynard A. Nurse staffing and healthcare outcomes: a systematic review of the international research evidence. ANS Adv Nurs Sci. Apr–Jun. 2005;28(2):163-74. [pmid: 15920362].
97 Lang TA, Hodge M, Olson V, et al. Nurse-patient ratios: a systematic review on the effects of nurse staffing on patient, nurse employee, and hospital outcomes. J Nurs Adm. Jul–Aug. 2004;34(78):326-37. [pmid: 15303051].
98 Seago JA, Spetz J, Mitchell S. Nurse staffing and hospital ownership in California. J Nurs Adm. Apr. 2004;34(5):228-37. [pmid: 15167419].
99 Hodge MB, Romano PS, Harvey D, et al. Licensed caregiver characteristics and staffing in California acute care hospital units. J Nurs Adm. Mar. 2004;34(3):125-33. [pmid: 15024239].
100 McGillis Hall L, Doran D, Baker GR, et al. Nurse staffing models as predictors of patient outcomes. Med Care. Sep. 2003;41(9):1096-109. [pmid: 12972849].
101 McGillis Hall L, Doran D, Pink GH. Nurse staffing models, nursing hours, and patient safety outcomes. J Nurs Adm. Jan. 2004;34(1):41-5. [pmid: 14737034].
102 Skipper JK Jr, Jung FD, Coffey LC. Nurses and shiftwork: effects on physical health and mental depression. J Adv Nurs. Jul. 1990;15(7):835-42. [pmid: 2394892].
103 Gold DR, Rogacz S, Bock N, et al. Rotating shift work, sleep, and accidents related to sleepiness in hospital nurses. Am J Public Health. Jul. 1992;82(7):1011-4. [pmid: 1609900]. [pmcid: 1694075].
104 Ruggiero JS. Correlates of fatigue in critical care nurses. Res Nurs Health. Dec. 2003;26(6):434-44. [pmid: 14689460].
105 Rogers AE, Hwang WT, Scott LD, et al. The working hours of hospital staff nurses and patient safety. Health Aff (Millwood). Jul–Aug. 2004;23(4):202-12. [pmid: 15318582].
106 Trinkoff A, Geiger-Brown J, Brady B, et al. How long and how much are nurses now working?. Am J Nurs. Apr. 2006;106(4):60-71. quiz 2. [pmid: 16575241].
107 Havlovic SJ, Lau DC, Pinfield LT. Repercussions of work schedule congruence among full-time, part-time, and contingent nurses. Health Care Manage Rev. Fall. 2002;27(4):30-41. [pmid: 12433245].
108 Hoffman AJ, Scott LD. Role stress and career satisfaction among registered nurses by work shift patterns. J Nurs Adm. Jun. 2003;33(6):337-42. [pmid: 12796631].
109 Hughes KK, Marcantonio RJ. Recruitment, retention, and compensation of agency and hospital nurses. J Nurs Adm. Oct. 1991;21(10):46-52. [pmid: 1919774].
110 Hughes KK, Marcantonio RJ. The clinical practice of supplemental nursing personnel. Nurs Adm Q. Spring. 1993;17(3):83-7. [pmid: 8502426].
111 Warren IB, Rozell BR. Supplemental staffing. Nurse manager views of costs, benefits, and quality of care. J Nurs Adm. Jun. 1995;25(6):51-7. [pmid: 7776008].
112 Strzalka A, Havens DS. Nursing care quality: comparison of unit-hired, hospital float pool, and agency nurses. J Nurs Care Qual. Jul. 1996;10(4):59-65. [pmid: 8783546].
113 Jolma DJ. Relationship between nursing work load and turnover. Nurs Econ. Mar–Apr. 1990;8(2):110-4. [pmid: 2330060].
114 Wetzel K, Soloshy DE, Gallagher DG. The work attitudes of full-time and part-time registered nurses. Health Care Manage Rev. Summer. 1990;15(3):79-85. [pmid: 2398005].
115 Porter RT, Porter MJ. Career development: our professional responsibility. J Prof Nurs. Jul–Aug. 1991;7(4):208-12. [pmid: 1894840].
116 Burke RJ, Greenglass ER. Effects of hospital restructuring on full time and part time nursing staff in Ontario. Int J Nurs Stud. Apr. 2000;37(2):163-71. [pmid: 10684958].
117 Crawford L. Nurses educated in other countries: coming to America. JONAS Healthc Law Ethics Regul. Jul–Sep. 2004;6(3):66-8. [pmid: 15494629].
118 Dicicco-Bloom B. The racial and gendered experiences of immigrant nurses from Kerala, India. J Transcult Nurs. Jan. 2004;15(1):26-33. [pmid: 14768413].
119 Flynn L, Aiken LH. Does international nurse recruitment influence practice values in U.S. hospitals?. J Nurs Scholarsh. 2002;34(1):67-73. [pmid: 11901970].
120 Pizer CM, Collard AF, James SM, et al. Nurses' job satisfaction: are there differences between foreign and U.S.-educated nurses?. Image J Nurs Sch. Winter. 1992;24(4):301-6. [pmid: 1452185].
121 Xu Y, Kwak C. Characteristics of internationally educated nurses in the United States. Nurs Econ Sep–Oct 2005;23(5):233–8, 11.
122 Yi M, Jezewski MA. Korean nurses' adjustment to hospitals in the United States of America. J Adv Nurs. Sep. 2000;32(3):721-9. [pmid: 11012817].
123 Shader K, Broome ME, Broome CD, et al. Factors influencing satisfaction and anticipated turnover for nurses in an academic medical center. J Nurs Adm. Apr. 2001;31(4):210-6. [pmid: 11324334].
124 Berney B, Needleman J, Kovner C. Factors influencing the use of registered nurse overtime in hospitals, 1995-2000. J Nurs Scholarsh. 2005;37(2):165-72. [pmid: 15960061].
125 O'Brien-Pallas L, Shamian J, Thomson D, et al. Work-related disability in Canadian nurses. J Nurs Scholarsh. 2004;36(4):352-7. [pmid: 15636416].
126 Berney B, Needleman J. Trends in nurse overtime, 1995-2002. Policy Polit Nurs Pract. Aug. 2005;6(3):183-90. [pmid: 16443973].