# Appendix F. Analytic Framework

Appendix F contains details on analytical framework of the meta-analysis: definitions, hypotheses, and statistical models.

[underlined: Differences in definitions of nurse staffing]. The variation in the ways nurse staffing rates are calculated and expressed makes it difficult to summarize data across studies. The nurse to patient or patients to nurse ratio reflects the number of patients cared for by one nurse typically specified by job category (RN, LPN, or LVN); this ratio may be calculated by shift or by nursing unit; some researchers use this term to mean nurse hours per inpatient day.

Various authors used different operational definitions for the nurse to patient ratio, including:

- number of patients cared for by one nurse per shift
- FTE/1,000 patient-days
- nurse/patient-day or FTE/occupied bed

Total nursing staff or hours per patient day represent all staff or all hours of care including RN, LPN, LVN, and aides counted per patient day (a patient day is the number of days any one patient stays in the hospital, i.e. one patient staying 10 days would be 10 patient days).

RN, LPN, or LVN full-time equivalents per patient day: (an FTE is 2,080 hours per year and can be composed of multiple part-time or one full-time individual.^1^ FTE/occupied bed ratios were calculated based on FTE/mean annual number of occupied bed-days (patient-days).

We reported nursing rates as they were used by individual authors, but we have also created two standardized rates for purposes of comparison.

1 The number of patients cared by one nurse per shift. This ratio can be expressed as FTE/patient or patients/FTE per shift.
2 RN FTE/patient day ratio

We conducted separate analysis and report the results in these ways:

- with definitions the authors used
- corresponding to increase by 1 RN FTE/patient day
- in categories of patients/RN per shift in ICUs, and with surgical and medical patients.

Different methods have been used to estimate nurse hours per patient day from FTEs. Some investigators assume a 40 hour week and 52 working weeks per year (2,080 hours/year). Others use more conservative estimates (e.g. 37.5 hours per week for 48 weeks = 1,800 hours/year). In our conversions, we used the latter estimate:^2^

Nurse hours per patient day = (FTE*40)/patient days^3^

One nurse/patient day = 8 working hours per patient day ^2^

Then the patient/nurse ratio = 24 hours/nurse hours per patient day.^3^

We made the following assumptions:

37.5 hour work week on average;

48 working weeks/year (4 weeks vacation, holidays, sick time);

All FTE are full-time nurses with the same shift distribution (assume 3 8-hour shifts);

Length of shift does not modify the association between nurse staffing and patient outcomes;

Patient density is the same over the year.

The same estimation was used for the each nurse job category- RN, LPN, and UAP.

The following examples of calculations may help clarify the approach to conversions.

1. The authors reported RN FTE/1,000 patient-days.

We calculated:

RN hours/patient days: [(RN FTE/1,000 *1,800 hours)]/1,000

Nurse to patient per shift ratio:

Patient/nurse ratio = 24 hours/nurse hours per patient day^3^

Numeric example: The authors reported 3 RN FTE/1,000 patient days

RN hours/patient day = (3*1,800)/1,000=5.4 RN hours/patient day

Patients/RN per shift ratio = 24 hours/5.4 = 4.4 patients

2. The authors reported RN/patient day

We calculated

RN hours/patient days: (FTE*40)/5 patient days per week^3^

RN hours/patient day = FTE*8

Patients/RN per shift ratio = 24 hours/RN hours per patient day^3^

Numeric example: The authors reported 0.5 FTE/patient day

RN hours/patient day: 0.5 FTE*8 hours = 4 hours/patient day

Patients/RN per shift ratio = 24 hours/4 = 6 patients

3. The authors reported patients/RN per shift ratio.

We calculated

RN hours/patient day = 24 hours/reported ratio of patients/RN^3^

RN FTE/patient day = RN hours per patient day/8 hours

Numeric example: The authors reported 2 patients/RN/shift

RN hours/patient day = 24 hours/2 = 12 hours/patient day

RN FTE/patient day = 12 hours per patient day/8 hours = 1.5 RN FTE

When the authors reported outcome rates among different categories of nurse staffing; we extracted the reported means or calculated medians of nurse staffing ranges. When the authors reported changes in outcomes corresponding to 1 unit increase in nurse staffing ratio. We defined a reference nurse staffing level equal to the published means^4,^ ^5^ in different clinical settings assuming that the same linear association would be observed corresponding to an increase by 1 unit from the mean. This assumption ignores nonlinearity but provides more realistic staffing estimation. When the authors reported regression coefficients form several statistical models, we used maximum likelihood criteria to extract one regression coefficient for the pooled analysis—models with significant regression coefficient for the association:

- the smallest number of nonsignificant regression coefficients for confounding factors in the model
- main effects models without interaction and nonlinear associations.

[underlined: Independent staffing variables for questions 1, 2, and 4 extracted from the studies]:

RN FTE/patient day as a continuous variable

Patients/RN/shift ratio as a continuous variable

Quartiles of patients/RN/shift ratio as a categorical variable

Patients/LPN/shift ratio as a continuous variable

Patients/UAP/shift ratio as a continuous variable

Total nursing hours as a continuous variable equal nursing hours/patient or patient day

RN hours/patient day as a continuous variable equal RN hours/patient day

LPN hours/patient day as a continuous variable equal LPN hours/patient day

UAP hours/patient day as a continuous variable equal UAP hours/patient day

Licensed hours/patient day as a continuous variable equal RN and LPN hours/patient day

We calculated means, standard deviations, and quartiles of nurse staffing variables in different clinical settings to compare with published articles.^4,^ ^5^

Nurse Variables | Needleman et al
Number of hours of nursing care per patient-day | Mean ± STD
Registered nurse-hours | 7.8 ± 1.9
Licensed-practical nurse-hours | 1.2 ± 1.0
Aide hours | 2.4 ± 1.2
Total | 11.4 ± 2.3
Proportion of total hours of nursing care (%)
Registered nurse hours | 68 ± 10

The present report:

Nurse Staffing | Number of Studies | Mean | Standard Deviation
ICUs
RN FTE/patient day | 15 | 1.31 | 0.70
Patients/RN per shift | 15 | 3.11 | 1.82
Total nursing hours/patient day | 15 | 11.00 | 5.23
RN hours/patient day | 10 | 12.61 | 5.28
LPN hours/patient day | 3 | 0.34 | 0.57
UAP hours/patient day | 4 | 2.26 | 1.20
Licensed nurse hours/patient day | 1 | 7.29 | 0.43
Surgical patients
RN FTE/patient day | 13 | 1.14 | 0.84
Patients/RN per shift | 13 | 4.04 | 2.32
Patients/LPN per shift | 2 | 3.07 | 2.21
Total nursing hours/patient day | 12 | 7.73 | 4.31
RN hours/patient day | 11 | 7.81 | 5.28
LPN hours/patient day | 7 | 1.49 | 1.58
UAP hours/patient day | 5 | 2.07 | 0.62
Medical patients
RN FTE/patient day | 20 | 1.10 | 0.99
Patients/RN per shift | 20 | 4.42 | 2.94
Patients/LPN per shift | 6 | 13.25 | 8.52
Patients/UAP per shift | 4 | 11.95 | 8.87
Patients/licensed nurse per shift | 2 | 4.12 | 1.09
Total nursing hours/patient day | 27 | 8.23 | 4.36
RN hours/patient day | 23 | 6.06 | 3.60
LPN hours/patient day | 13 | 2.84 | 3.33
UAP hours/patient day | 12 | 2.97 | 3.22
Licensed nurse hours/patient day | 4 | 3.32 | 2.92

[underlined: Independent staffing strategies variables:]

Skill mix % of RN nurses/total nursing personnel as a continuous variable

% of nurses with BSN degrees/total nursing personnel as a continuous variable

% of licensed nurses (RNs + LPNs)/total nursing personnel as a continuous variable

Experience mix: nurse experience in years as a continuous variable

% of overtime nursing hours as a continuous variable

% of temporary nurses as a continuous variable

% of full-time nurses as a continuous variable

The authors used different operational definitions of the outcomes rates: the percentage of the patients with outcomes among all hospitalized patients and the rates of the outcomes per 1,000 patient days. We reported these rates as they were used by the individual authors, but we have also standardized rates as the percentage of patients with outcomes among all hospitalized patients for purposes of comparison. We estimated that Percentage of patients with outcomes = (rate per 1,000 patient days/10) * an average length of stay. We use published averages of length of stay in ICUs, in medical, and surgical patients.^4^

[underlined: Weighting variable:]

Sample size as patient or analytic unit number (when patient number was not reported); hospital number per every level of exposure.

[underlined: Tested sources of heterogeneity:]

1 Analytic unit
2 Patient population
3 Hospital unit
4 Study design
5 Adjustment for comorbidities
6 Definition of nurse to patient ratio
7 Quality scores
8 Adjustment for provider characteristics and patient socio-economic status
9 Adjustment for clustering between providers and patients
10 Source of the data (administrative vs. medical record)
11 Definition of outcomes

We tested the possible sources of heterogeneity as interaction variables which could modify the effect of nurse staffing on patient outcomes and conducted sensitivity analysis within each category of effect modifiers.

Hypotheses tested in pooled analysis:

1 The outcome is associated with nurse staffing as a continuous variable, weighted by the study sample size * number of hospitals, in a random effects model—random intercept for each study
2 The outcome is associated with nurse staffing as a continuous variable, weighted by the study sample size * number of hospitals, in a fixed effects model
3 The outcome is associated with nurse staffing as a continuous variable with nonlinear association, weighted by the study sample size * number of hospitals in a random effects model
4 The outcome is associated with nurse staffing as a continuous variable with nonlinear association, weighted by the study sample size * number of hospitals, in a fixed effects model
5 The association with nurse staffing as a continuous variable can be modified by analytic unit (hospital, unit, and patient levels), when the model is weighted by the study sample size * number of hospitals in a random effects model—random intercept for each study
6 The association with nurse staffing as a continuous variable can be modified by analytic unit when the model is weighted by the study sample size * number of hospitals in a fixed effects model
7 The association with nurse staffing as a continuous variable can be modified by hospital unit (ICU, medical, surgical) when the model is weighted by the study sample size * number of hospitals in a random effects model—random intercept for each study
8 The association with nurse staffing as a continuous variable can be modified by hospital unit when the model is weighted by the study sample size * number of hospitals in a fixed effects model
9 The association with nurse staffing as a continuous variable can be modified by patient type (medical vs. surgical) when the model is weighted by the study sample size * number of hospitals in a random effects model with a random intercept for each study.
10 The association with nurse staffing as continuous variables can be modified by patient type (medical vs. surgical) when the model is weighted by the study sample size * number of hospitals in a fixed effects model
11 The outcome was associated with nurse staffing as a categorical variables, weighted by the study sample size * number of hospitals, in a random effects model—random intercept for each study
12 The outcome is associated with nurse staffing as continuous variable weighted by the study sample size * number of hospitals in a fixed effects model
13 A sensitivity analysis by analytic units, hospital units, and patient population tested all previous hypotheses with random and fixed effects models weighted by the sample size in subgroups where the analytic units are hospitals, hospital units, and patients and the hospital units are ICU, medical, and surgical and the patients are medical and surgical
14 Individual studies were analyzed with simple linear regression in STATA to find slopes for each study when possible. Meta-analysis was used to estimate pooled regression coefficients: changes in outcomes corresponding to incremental changes by one unit in nurse staffing
15 Interaction models and sensitivity analysis examined the effects of the year of outcomes occurrence and adjustment for patient and provider characteristics and clustering of patients and providers.

[underlined: Algorithms of meta-analysis] ^6^

Pooled estimate as a weighted average:

Weights are inverse of variance (standard error):^2^

Standard error of pooled estimate:

Heterogeneity (between-study variability) measured by:

Assumptions for random effects model: true effect sizes qi have a normal distribution with mean q and variance t2; t2 is the between-study variance

Between study variance:

Where:

wi are the weights from the fixed effect inverse-variance method

Q is the heterogeneity test statistic from before (either from inverse-variance method or Mantel-Haenszel method)

k is the number of studies, and

t2 is set to zero if Q<k-1

Random effect pooled estimate is weighted average:

Weights used for the pooled estimate are similar to the inverse-variance, but now incorporate a component for between-study variation:

Standard error of pooled estimate

The likelihood-based approach to general linear mixed models was used to analyze the association between independent variable and outcomes with the basic assumption that the data are linearly related to unobserved multivariate normal random variables.

General linear model Y = Xβ + ε

(Y - the vector of observed y _i_'s, X - known matrix of x _ij_'s, β- the unknown fixed-effects parameter vector, and ε - the unobserved vector of independent and identically distributed Gaussian random errors) is written in the mixed model:

Y = Xβ + Zλ + ε

where Z - known design matrix, and λ the vector of unknown random-effects parameters.

The model assumes that λ and ε are normally distributed.

Attributable risk was calculated as the outcome events rate in patients exposed to different nurse staffing levels.^7^–^9^

Attributable risk of the outcome = rate of events in patients with below of the recommended nurse/patient ratio x (relative risk = 1)

Number needed to treat to prevent one adverse event was calculated as reciprocal to absolute risk differences in rates of outcomes events in the groups of the patients with different nurse staffing levels.^10^

Administrative data was obtained to estimate nurse shortage and distribution in a state level in the USA.^11,^ ^12^ Correlation between nurse distribution and fatal adverse events related to health care were computed with 95% confidence level to determine a strength and directions of the correlations.^13^

Definitions of fatal injuries related to health care:

Misadventures to patients during surgical and medical care (E870–E876):

E870 Accidental cut, puncture, perforation, or hemorrhage during medical care-

E870.0 Surgical operation

E870.1 Infusion or transfusion

E870.2 Kidney dialysis or other perfusion

E870.3 Injection or vaccination

E870.4 Endoscopic examination

E870.5 Aspiration of fluid or tissue, puncture, and catheterization

Abdominal paracentesis

Aspirating needle biopsy

Blood sampling

Lumbar puncture

Thoracentesis

E871 Foreign object left in body during procedure

E872 Failure of sterile precautions during procedure

E873 Failure in dosage

E873.0 Excessive amount of blood or other fluid during transfusion or infusion

- E873.1 Incorrect dilution of fluid during infusion
- E873.2 Overdose of radiation in therapy
- E873.3 Inadvertent exposure of patient to radiation during medical care
- E873.4 Failure in dosage in electroshock or insulin-shock therapy
- E873.5 Inappropriate [too hot or too cold] temperature in local application and packing
- E873.6 Nonadministration of necessary drug or medicinal substance
- E873.8 Other specified failure in dosage
- E873.9 Unspecified failure in dosage

E874 Mechanical failure of instrument or apparatus during procedure

E875 Contaminated or infected blood, other fluid, drug, or biological substance

Includes:

presence of:

bacterial pyrogens

endotoxin-producing bacteria

serum hepatitis-producing agent

E876 Other and unspecified misadventures during medical care

E876.0 Mismatched blood in transfusion

E876.1 Wrong fluid in infusion

E876.2 Failure in suture and ligature during surgical operation

E876.3 Endotracheal tube wrongly placed during anesthetic procedure

E876.4 Failure to introduce or to remove other tube or instrument

E876.5 Performance of inappropriate operation

E876.8 Other specified misadventures during medical care

Performance of inappropriate treatment NEC

E876.9 Unspecified misadventure during medical care

Surgical and medical procedures as the cause of abnormal reaction of patient or later complication, without mention of misadventure at the time of procedure (E878–E879)

Includes:

procedures as the cause of abnormal reaction, such as:

displacement or malfunction of prosthetic device

hepatorenal failure, postoperative

malfunction of external stoma

postoperative intestinal obstruction

rejection of transplanted organ

E878 Surgical operation and other surgical procedures as the cause of abnormal reaction of patient, or of later complication, without mention of misadventure at the time of operation

E879 Other procedures, without mention of misadventure at the time of procedure, as the cause of abnormal reaction of patient, or of later complication

Drugs, medicinal and biological substances causing adverse effects in therapeutic use (E930–E949)

Includes:

correct drug properly administered in therapeutic or prophylactic dosage, as the cause of any adverse effect including allergic or hypersensitivity reactions

## References for Appendix F

1 United States: Agency for Healthcare Research and Quality; University of California SF-SE-BPC. Making health care safer: a critical analysis of patient safety practices. Chapter 39. Nurse Staffing, Models of Care Delivery, and Interventions. Rockville, MD: Agency for Healthcare Research and Quality; 2001.
2 American Nurses Association. Nurse Staffing and Patient Outcomes: In the Inpatient Hospital Setting. Washington DC: American Nurses Association; 2000.
3 Spetz J. Minimum nurse staffing ratios in California acute care hospitals. San Francisco: California Workforce Initiative; 2000.
4 Needleman J. Nurse staffing and patient outcomes in hospitals. Final Report for Health Resources Services Administration. 2001; Contract No. 230990021.
5 Kovner C, Jones CB, Gergen PJ. Nurse Staffing in Acute Care Hospitals, 1990-1996. Policy, Politics, & Nursing Practice. 2000;1(3):194-204.
6 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
7 Dawson B and Trapp RG. Basic & Clinical Biostatistics (LANGE Basic Science). McGraw-Hill/Appleton & Lange. 2004.
8 Harold A. Kahn CTS. Statistical Methods in Epidemiology (Monographs in Epidemiology and Biostatistics). Oxford University Press, USA. 1989.
9 Egger M. Systematic Reviews in Health Care. BMJ, London, 2001 ISBN:0-7279-1488-X. http://www.blackwellpublishing.com/medicine/bmj/systreviews/pdfs/chapter18.pdf.
10 Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta-analysis. Caveats and pitfalls. Eval Health Prof. Jun. 2001;24(2):152-64. [pmid: 11523384].
11 Cho S-H. Nurse staffing and adverse patient outcomes [PhD]: Dissertation, University of Michigan; 2002.
12 Spratley E. The registered nurse population. March 2000, findings from the National Sample Survey of Registered Nurses. Rockville, MD; U.S. Dept. of Health & Human Services, Health Resources and Services Administration, Bureau of Health Professions, Division of Nursing. 2000: http://www.bhpr.hrsa.gov/healthworkforce/reports/rnsurvey/rnss1.htm.
13 Centers for Disease Control. WISQARS Injury Mortality Reports. 1999-2003; Dept. of Health and Human Services, Public Health Services; OCLC: 44350522: http://www.cdc.gov/ncipc/.