# Appendix E: Quality of the Studies

Table E1 shows the quality of the studies, using a 5 score scale from 0 (poorest) to 5 (highest):

A Study question clearly focused and appropriate
B Clear definition of exposure
C Clear definition of the primary and secondary outcomes
D Validation of exposure (yes or no, the responses do not count for the total scores)
E Validation of outcomes (yes or no, the responses do not count for the total scores)
F Sampling of study population:
  - 5 = Random population based sampling
  - 4 = Random clinic based sampling
  - 3 = Convenient
  - 2 = Self-selected
  - 1 = Single hospital study
  - 0 = Not specified
G Statistical Analysis: Assessment of confounding attempted
H Adjustment to examine the effects of various factors
  1) Patient characteristics: age; race; sex; comorbidities; SES - 1-3 scores
  2) Hospital characteristics - 1+2 - 4 scores
  3) Cluster of patients and hospitals - 1+2+3 - 5 scores
I Statistical methods used to take into account the effect of more than one variable on the outcome such as multiple regression, multivariate analysis, regression modeling
J Measure of effect for outcomes and appropriate measure of precision (SE, 95% CI)
K External validity: single hospital study; multi-site study; nationally representative sample
L Conclusions supported by results with possible bias and limitations taken into consideration; clinical significance of effect size provided
M Total score as a percentage of the maximum possible (50)

Each item was graded with 0 to 5 scores. We summarized scores (maximum possible 50) to have the overall quality score and to compare with the maximum.

Definitions

External validity - applicability of the results from the studies on different clinical settings.

Internal validity - the extent to which the findings of a study accurately represent the causal relationship between nurse staffing and patient outcomes. The truth why patients had different outcomes may be related to patient characteristics or quality of the treatments (surgical quality) more than nurse care. To examine how nurse ratios and hours may affect patient outcomes independent of all known factors they measured, the authors adjusted the results for confounding factors.

Table E1 Quality of the studies

Year | Author | Class | A | B | C | D | E | F | G | H | I | J | K | L | Total Score | M %
1982 | Arnow^1^ | II-2C | 5 | 4 | 5 | Yes | Yes | 5 | 3 | 0 | 3 | 2 | 2 | 4 | 33 | 66
1987 | Wan^2^ | II-2C | 5 | 4 | 4 | | | 3 | 4 | 2 | 4 | 4 | 4 | 4 | 38 | 76
1988 | Flood^3^ | III | 4 | 4 | 4 | | | 1 | 3 | 1 | 3 | 3 | 2 | 3 | 28 | 56
1989 | Hartz^4^ | III | 5 | 3 | 4 | | | 3 | 3 | 3 | 3 | 3 | 4 | 3 | 34 | 68
1992 | McDaniel^5^ | III | 4 | 4 | 5 | | | 4 | 3 | 0 | 2 | 2 | 2 | 3 | 29 | 58
1992 | Krakauer^6^ | III | 5 | 3 | 4 | | | 5 | 5 | 5 | 4 | 5 | 5 | 4 | 45 | 90
1993 | Halpine^7^ | III | 5 | 4 | 5 | | | 3 | 3 | 2 | 3 | 3 | 3 | 4 | 35 | 70
1994 | Aiken^8^ | II-2B | 5 | 4 | 5 | | | 4 | 5 | 5 | 4 | 5 | 4 | 4 | 45 | 90
1994 | Shamian^9^ | III | 4 | 3 | 3 | | | 3 | 3 | 2 | 3 | 3 | 4 | 4 | 32 | 64
1994 | Taunton^10^ | III | 5 | 4 | 4 | | | 2 | 3 | 0 | 2 | 3 | 3 | 4 | 30 | 60
1988 | Shortell^11^ | II-2C | 5 | 3 | 4 | | | 5 | 4 | 4 | 4 | 4 | 5 | 4 | 42 | 84
1994 | Shortell^12^ | II-2C | 5 | 4 | 4 | | | 4 | 3 | 3 | 3 | 4 | 4 | 4 | 38 | 76
1995 | Grillo-Peck^13^ | III | 5 | 5 | 4 | | | 3 | 2 | 1 | 3 | 2 | 3 | 3 | 31 | 62
1995 | Thorson^14^ | II-2C | 5 | 5 | 4 | | | 4 | 4 | 4 | 4 | 4 | 4 | 5 | 43 | 86
1996 | Fridkin^15^ | II-2C | 5 | 4 | 5 | | Yes | 4 | 5 | 4 | 5 | 4 | 3 | 4 | 43 | 86
1996 | Dugan^16^ | III | 3 | 3 | 4 | | | 2 | 0 | 0 | 3 | 2 | 2 | 3 | 22 | 44
1997 | Bloom^17^ | III | 4 | 4 | 5 | | | 4 | 3 | 3 | 4 | 4 | 5 | 4 | 40 | 80
1997 | Archibald^18^ | II-2C | 5 | 4 | 5 | | Yes | 3 | 3 | 2 | 3 | 3 | 2 | 4 | 34 | 68
1997 | Minnick^19^ | III | 3 | 3 | 3 | | | 4 | 3 | 2 | 4 | 4 | 4 | 4 | 34 | 68
1997 | Melberg^20^ | III | 0 | 4 | 5 | | | 3 | 0 | 0 | 2 | 2 | 3 | 3 | 22 | 44
1997 | ANA^21^ | II-2C | 5 | 4 | 4 | | | 3 | 3 | 4 | 3 | 4 | 4 | 4 | 38 | 76
1998 | Blegen^22^ | II-2C | 5 | 4 | 4 | | | 3 | 3 | 3 | 4 | 2 | 4 | 4 | 36 | 72
1998 | Blegen^23^ | II-2C | 5 | 4 | 5 | | | 3 | 4 | 3 | 4 | 4 | 3 | 4 | 39 | 78
1998 | Kovner^24^ | III | 5 | 4 | 4 | | | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 41 | 82
1998 | Leiter^25^ | III | 4 | 4 | 4 | | | 2 | 3 | 0 | 3 | 3 | 3 | 4 | 30 | 60
1998 | Aiken^26^ | II-2C | 5 | 3 | 5 | | Yes | 3 | 5 | 4 | 4 | 5 | 4 | 4 | 42 | 84
1999 | Pronovost^27^ | II-2C | 5 | 3 | 5 | | | 2 | 5 | 5 | 5 | 5 | 4 | 5 | 44 | 88
1999 | Aiken^28^ | II-2C | 5 | 3 | 5 | | Yes | 3 | 5 | 4 | 4 | 5 | 4 | 4 | 42 | 84
1999 | Robertson^29^ | II-2C | 5 | 4 | 5 | | | 3 | 4 | 4 | 4 | 4 | 4 | 4 | 41 | 82
1999 | Lichtig^30^ | II-2C | 5 | 4 | 4 | | | 3 | 4 | 4 | 3 | 4 | 3 | 4 | 38 | 76
1999 | Seago^31^ | III | 4 | 4 | 3 | | | 3 | 0 | 0 | 3 | 3 | 3 | 4 | 27 | 54
1999 | Bond^32^ | II-2C | 5 | 4 | 4 | | | 5 | 4 | 4 | 5 | 5 | 5 | 4 | 45 | 90
2000 | Amaravadi^33^ | II-2C | 5 | 4 | 5 | | Yes | 2 | 5 | 5 | 5 | 5 | 4 | 5 | 45 | 90
2000 | Gandjour^34^ | III | 3 | 3 | 5 | | | 3 | 4 | 3 | 3 | 4 | 3 | 4 | 35 | 70
2000 | Robert^35^ | II-2C | 5 | 5 | 5 | Yes | Yes | 4 | 4 | 2 | 5 | 4 | 3 | 5 | 42 | 84
2000 | Silber^36^ | II-2C | 5 | 4 | 5 | | | 5 | 4 | 5 | 5 | 5 | 5 | 4 | 47 | 94
2000 | ANA^37^ | II-2C | 5 | 3 | 4 | | | 5 | 3 | 3 | 4 | 3 | 5 | 4 | 39 | 78
2000 | Hoover^38^ | III | 5 | 4 | 5 | | | 3 | 4 | 4 | 3 | 3 | 3 | 4 | 38 | 76
2000 | Unruh^39^ | II-2C | 5 | 4 | 4 | | | 3 | 4 | 4 | 3 | 4 | 4 | 4 | 39 | 78
2001 | Pronovost^40^ | II-2C | 5 | 4 | 5 | | | 3 | 5 | 4 | 5 | 5 | 4 | 5 | 45 | 90
2001 | Dimick^41^ | II-2C | 5 | 4 | 5 | | | 2 | 5 | 4 | 4 | 5 | 4 | 5 | 43 | 86
2001 | Blegen^42^ | II-2C | 4 | 3 | 3 | | | 3 | 4 | 3 | 4 | 4 | 4 | 4 | 36 | 72
2001 | Needleman^43^ | III | 5 | 5 | 5 | | | 4 | 5 | 4 | 4 | 5 | 5 | 5 | 47 | 94
2001 | Bolton^44^ | III | 5 | 4 | 4 | | | 3 | 3 | 2 | 2 | 2 | 4 | 4 | 33 | 66
2001 | Aiken^45^ | III | 4 | 3 | 3 | | | 3 | 3 | 0 | 2 | 2 | 3 | 4 | 27 | 54
2001 | Whitman^46^ | II-2A | 4 | 4 | 5 | | | 3 | 2 | 2 | 3 | 3 | 3 | 4 | 33 | 66
2001 | Sovie^47^ | II-2C | 5 | 4 | 4 | | | 3 | 3 | 2 | 3 | 3 | 3 | 4 | 34 | 68
2001 | Ridge^48^ | III | 5 | 5 | 4 | | | 4 | 3 | 3 | 3 | 3 | 2 | 4 | 36 | 72
2001 | Ritter-Teitel^49^ | II-2C | 5 | 4 | 4 | | | 5 | 4 | 4 | 4 | 4 | 5 | 5 | 44 | 88
2002 | Dang^50^ | II-2C | 5 | 4 | 5 | | | 3 | 4 | 4 | 5 | 5 | 4 | 5 | 44 | 88
2002 | Aiken^51^ | II-2C | 5 | 3 | 5 | | Yes | 3 | 5 | 5 | 5 | 4 | 4 | 4 | 43 | 86
2002 | Seago^52^ | III | 5 | 4 | 5 | | Yes | 3 | 4 | 4 | 4 | 4 | 3 | 4 | 40 | 80
2002 | Tourangeau^53^ | II-2C | 5 | 4 | 5 | Yes | Yes | 3 | 5 | 4 | 4 | 4 | 5 | 5 | 44 | 88
2002 | Kovner^54^ | III | 5 | 4 | 4 | | | 5 | 4 | 4 | 4 | 5 | 4 | 5 | 44 | 88
2002 | Langemo^55^ | III | 5 | 3 | 4 | | | 3 | 3 | 0 | 2 | 0 | 3 | 3 | 26 | 52
2002 | Needleman^56^ | III | 5 | 4 | 4 | | | 3 | 5 | 4 | 5 | 5 | 5 | 5 | 45 | 90
2002 | Barkell^57^ | III | 5 | 4 | 5 | | Yes | 3 | 2 | 0 | 2 | 2 | 1 | 3 | 27 | 54
2002 | Stegenga^58^ | II-2C | 5 | 5 | 5 | Yes | Yes | 3 | 4 | 0 | 5 | 4 | 2 | 4 | 37 | 74
2002 | Whitman^59^ | III | 5 | 4 | 4 | | | 3 | 3 | 0 | 3 | 2 | 3 | 3 | 30 | 60
2002 | Cheung^60^ | III | 3 | 5 | 5 | Yes | Yes | 3 | 3 | 2 | 2 | 3 | 2 | 3 | 31 | 62
2002 | Oster^61^ | III | 5 | 5 | 5 | | | 3 | 4 | 3 | 4 | 3 | 3 | 3 | 38 | 76
2003 | Aiken^62^ | III | 5 | 4 | 5 | | Yes | 4 | 5 | 5 | 5 | 5 | 4 | 5 | 47 | 94
2003 | Beckman^63^ | III | 5 | 5 | 5 | Yes | Yes | 4 | 4 | 4 | 3 | 3 | 2 | 3 | 38 | 76
2003 | Berney^64^ | II-2C | 5 | 5 | 5 | | Yes | 3 | 5 | 5 | 4 | 5 | 4 | 5 | 46 | 92
2003 | Unruh^65^ | II-2C | 5 | 5 | 5 | | | 3 | 4 | 4 | 4 | 4 | 4 | 5 | 43 | 86
2003 | Cho^66,67^ | II-2C | 4 | 4 | 4 | | Yes | 3 | 5 | 4 | 5 | 5 | 4 | 5 | 43 | 86
2003 | Langemo^68^ | III | 4 | 3 | 3 | | | 3 | 2 | 0 | 2 | 2 | 2 | 3 | 24 | 48
2003 | Needleman^69^ | III | 5 | 4 | 4 | | | 4 | 4 | 4 | 4 | 4 | 5 | 4 | 42 | 84
2003 | Mark^70^ | II-1B | 5 | 3 | 4 | | | 3 | 2 | 1 | 3 | 2 | 3 | 4 | 30 | 60
2003 | Alonso-Echanove^71^ | II-2A | 5 | 5 | 5 | Yes | Yes | 4 | 4 | 4 | 5 | 4 | 4 | 5 | 45 | 90
2003 | Bolton^72^ | III | 5 | 4 | 4 | | | 3 | 2 | 1 | 2 | 3 | 4 | 3 | 31 | 62
2003 | Potter^73^ | III | 4 | 4 | 5 | | | 3 | 3 | 2 | 3 | 3 | 2 | 4 | 33 | 66
2003 | Hope^74^ | II-2C | 5 | 5 | 5 | Yes | Yes | 3 | 5 | 4 | 5 | 5 | 3 | 5 | 45 | 90
2003 | Simmonds^75^ | II-2C | 5 | 4 | 5 | | | 3 | 4 | 3 | 4 | 4 | 2 | 3 | 37 | 74
2003 | Zidek^76^ | II-2C | 5 | 4 | 4 | | | 3 | 3 | 3 | 3 | 3 | 3 | 3 | 34 | 68
2003 | Tallier^77^ | II-2C | 4 | 4 | 4 | | | 3 | 2 | 0 | 3 | 1 | 2 | 3 | 26 | 52
2004 | Person^78^ | II-2C | 5 | 4 | 5 | | | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 49 | 98
2004 | Sochalski^79^ | III | 5 | 3 | 3 | | | 5 | 3 | 2 | 4 | 3 | 4 | 3 | 35 | 70
2004 | Mark^80^ | II-2C | 5 | 4 | 4 | | | 4 | 4 | 4 | 5 | 5 | 4 | 5 | 44 | 88
2004 | Van Doren^81^ | III | 4 | 5 | 5 | | | 4 | 2 | 0 | 3 | 2 | 3 | 4 | 32 | 64
2004 | Vahey^82^ | III | 5 | 3 | 4 | | | 3 | 4 | 4 | 5 | 5 | 3 | 4 | 40 | 80
2004 | Boyle^83^ | III | 3 | 3 | 4 | | | 3 | 3 | 2 | 3 | 3 | 2 | 3 | 29 | 58
2004 | Cimiotti^84^ | II-2C | 5 | 4 | 4 | | | 3 | 4 | 4 | 4 | 4 | 3 | 4 | 39 | 78
2005 | Estabrooks^85^ | III | 5 | 3 | 5 | Yes | Yes | 3 | 4 | 4 | 5 | 5 | 4 | 4 | 42 | 84
2005 | Marcin^86^ | II-2C | 5 | 5 | 5 | Yes | Yes | 3 | 4 | 4 | 5 | 5 | 3 | 4 | 43 | 86
2005 | Elting^87^ | II-2C | 5 | 3 | 5 | | | 3 | 5 | 5 | 5 | 5 | 4 | 4 | 44 | 88
2005 | Mark^88^ | II-2C | 5 | 4 | 4 | | | 4 | 4 | 4 | 4 | 4 | 4 | 5 | 42 | 84
2004 | Donaldson^89^ | III | 5 | 4 | 3 | | | 3 | 3 | 2 | 4 | 3 | 4 | 4 | 35 | 70
2005 | Tschannen^90^ | III | 5 | 5 | 5 | Yes | Yes | 3 | 5 | 4 | 4 | 4 | 2 | 3 | 40 | 80
2005 | Houser^91^ | III | 5 | 4 | 5 | | | 5 | 4 | 4 | 4 | 4 | 5 | 5 | 45 | 90
2005 | Halm^92^ | III | 5 | 5 | 5 | | | 3 | 3 | 3 | 4 | 4 | 2 | 4 | 38 | 76
2005 | Donaldson^93^ | III | 5 | 5 | 4 | | | 3 | 4 | 5 | 4 | 5 | 4 | 4 | 43 | 86
2005 | Stratton^94^ | II-2C | 5 | 4 | 4 | | | 3 | 4 | 4 | 3 | 3 | 4 | 4 | 38 | 76
2006 | Seago^95^ | II-2C | 5 | 4 | 5 | | | 3 | 3 | 2 | 3 | 3 | 3 | 3 | 34 | 68

Figure E1 plots the quality scores (expressed as the percent of maximum possible scores) over time to look for changes in ratings. Although there is a modestly positive overall trend, it is not significant.

Figure E1. Association between quality of studies and time of publication

Table E2 Studies published in peer reviewed journals indexed in Medline

Source* | Number of Publications | Quality (% from maximum)
Am J Crit Care | 1 | 86
Anesthesiology | 1 | 94
book | 2 | 77
Can J Nurs Res | 1 | 88
Cancer | 1 | 88
Clin Nurse Spec | 1 | 76
Dissertation | 15 | 77
Eff Clin Pract | 1 | 90
Health Econ | 1 | 84
Health Serv Manage Res | 1 | 82
Health Serv Res | 4 | 88
Heart Lung | 1 | 88
Image J Nurs Sch | 1 | 82
Infect Control Hosp Epidemiol | 4 | 84
Intensive Care Med | 1 | 90
J Health Hum Serv Adm | 1 | 54
J Nurs Adm | 12 | 65
J Nurs Care Qual | 1 | 44
J Nurs Scholarsh | 1 | 66
J Trauma | 1 | 66
JAMA | 3 | 89
Lippincotts Case Manag | 1 | 64
Manag Care Interface | 1 | 70
Med Care | 8 | 82
N Engl J Med | 3 | 81
Nurs Adm Q | 1
Nurs Econ | 4 | 65
Nurs Manage | 3 | 49
Nurs Res | 4 | 79
Outcomes Manag | 1 | 54
Pediatr Crit Care Med | 1 | 86
Pediatr Infect Dis J | 1 | 68
Pharmacotherapy | 1 | 90
Phys Rev B Condens Matter | 1 | 76
Phys Rev C Nucl Phys | 1 | 78
Policy Polit Nurs Pract | 1 | 70
QRB Qual Rev Bull | 1 | 76
Qual Health C | 1 | 84
Report | 1 | 94
Report | 1 | 86
Soc Sci Med | 2 | 64

* Title abbreviations from the National Library of Medicine

Table E3 Assessment of patient comorbidities in included studies

Author | Source to Measure Patient Outcomes | Assessment of Comorbid Conditions Analytic Unit
Aiken | Medical charts of consecutively admitted patients | Severity classification for AIDS hospitalization, clinical AIDS Prognostic Staging
| | Analytic unit: Patient
Aiken | Hospitals discharge database | ICD codes for pre-existing comorbid conditions
| | Analytic unit: Patient
Aiken | Health Care Cost Containment Council | ICD codes for pre-existing co morbid conditions
| | Analytic unit: Patient
Aiken | HCFA database | Medicare Case Mix Index
| | Analytic unit: Hospital
Aiken | Patients survey | HIV risk categories, illness severity
| | Analytic unit: Patient
Alonso-Echanove | Medical charts | Secondary diagnoses and individual medical history present at the time of the admission
| | Analytic unit: Patient
Amaravadi | Uniform Hospital Health Discharge Data Set | ICD codes for comorbid conditions (secondary diagnoses and procedures)
| | Analytic unit: Patient
ANA | HCFA discharges database | Patients' case mix index and severity of Illness index
| | Analytic unit: Hospital
ANA | Uniform Hospital Discharge Data Set | Patient case mix index and severity of Illness index
| | Analytic unit: Hospital
Berney | New York Statewide Planning and Research Cooperative System | DRG codes for comorbid conditions
| | Analytic unit: Hospital
Blegen | Comparative occurrence reporting service (CORS) | Hospital Medicare Case Mix Scores
| | Analytic unit: Hospital Unit
Blegen | Hospitals discharge database | Hospital Medicare Case Mix Index
| | Analytic unit: Hospital Unit
Blegen | Hospital discharge records | Patient's acuity data from the monthly acuity system reports
| | Analytic unit: Hospital Unit
Bloom | Transaction Cost Analysis; Area Resource File | Medicare Case Mix Index
| | Analytic unit: Hospital
Bond | Hospital Medicare mortality rates from the Health Care Financing Administration | Medicare case mix, APACHE scores, Severity of Illness scores
| | Analytic unit: Hospital
Boyle | Hospital discharge data | Patients case mix index
| | Analytic unit: Patient
Cho | State inpatient databases | DRG codes to calculate the number of diagnoses at admission
| | Analytic unit: Patient and hospitals
Cimiotti | Patient discharges and medical records reviewed by study's nurse epidemiologist | DRG for comorbid conditions and procedures
| | Analytic unit: Patient
Dang | Uniform Hospital Health Discharge Data Set | ICD codes for comorbid conditions (secondary diagnoses and procedures)
| | Analytic unit: Patient
Dimick | Uniform Health Discharge Data Set | ICD codes for comorbid conditions (secondary diagnoses and procedures)
| | Analytic unit: Patient
Elting | Center for Medicare and Medicaid Services and the American Hospital Association | Comorbid conditions were coded using the Dartmouth Manitoba Adaptation of Charlson comorbidity score
| | Analytic unit: Hospital
Estabrooks | Hospital inpatient database | Charlson index modified by Devo
| | Analytic unit: Patient
Fridkin | Medical records | Severity of illness with APACHE II scores
| | Analytic unit: Patient
Gandjour | Health Care Financing Administration | Medicare case-mix
| | Analytic unit: Hospital
Halm | Hospital's data warehouse with patient discharges | DRGs codes for comorbid conditions
| | Analytic unit: Patient
Halpine | Hospital Medical Records Institute database | Case Mix Groups
| | Analytic unit: Patient
Hartz | Hospital discharges data from The Health Care Financing Administration (HCFA) | ICD codes for 4 secondary diagnoses, Severity of Illness index
| | Analytic unit: Hospital
Hoover | Health Care Financing Administration, HealthCareReportCards.com; MEDPAR database | Medicare Case Mix Index
| | Analytic unit: Hospital
Hope | Medical Microbiology Laboratory and Infection Control Services; Discharge Abstract Database | Patient severity of Illness index
| | Analytic unit: Patient
Houser | Nationwide inpatient sample of 2001 with hospital discharge records | ICD codes for comorbid conditions
| | Analytic unit: Patient
Kovner | National Inpatient Sample (NIS) | Medicare Case Mix Index
| | Analytic unit: Hospital
Kovner | Nationwide inpatient sample of hospital discharges | Medicare Case Mix Index
| | Analytic unit: Hospital
Krakauer | Medical records for all Medicare discharges | ICD codes for 4 comorbid conditions and additional clinical data with MediQual system
| | Analytic unit: Hospital
Marcin | Medical charts, Pediatric Intensive Care Unit Evaluations Database | Pediatric Risk of Mortality (PRISM) III index
| | Analytic unit: Patient
Mark | Centers for Medicare Services Minimum Cost and Capital File, CMS Provider of Services File, CMS Case Mix Index File, CMS Online Survey Certification and Reporting system (OSCAR) files, and HCUP files | CMS Case Mix Index
| | Analytic unit: Hospital
Mark | Hospital's incident reporting system | CMS Case Mix Index File
| | Analytic unit: Patient (survey)
Mark | Healthcare Cost and Utilization Project (HCUP) National Inpatient Sample (NIS) | CMS case mix index file, Medstat's Disease Staging methodology
| | Analytic unit: Hospital
Needleman | Hospital discharge data from 11 states (all patients and Medicare sample) and MedPAR national database (all Medicare patients) | DRGs codes for comorbid conditions
| | Analytic unit: Hospital and units
Person | Medicare database | Patients severity of illness index
| | Analytic unit: Patient
Pronovost | Uniform Hospital Health Discharge Data Set | ICD codes for comorbid conditions
| | Analytic unit: Patient
Pronovost | Uniform Hospital Health Discharge Data Set | ICD codes for comorbid conditions (secondary diagnoses and procedures)
| | Analytic unit: Patient
Ridge | Patient survey 2 weeks after discharge with computerized phone interview system | Medicare case mix
| | Analytic unit: Patient
Ritter-Teitel | Hospitals Incidence reports and patient surveys | Patients case mix index
| | Analytic unit: Unit
Robert | Medical charts | Severity of illness with APACHE II scores
| | Analytic unit: Patient
Robertson | HCFA database and Hospitals Information Reports | Medicare Case Mix Index
| | Analytic unit: Hospital
Seago | California Office of Statewide Health Planning and Development (OSHPD) Hospital Disclosure Report database | Patients severity of illness index
| | Analytic unit: Hospital
Seago | Incident reporting system, patient survey | Case-mix index
| | Analytic unit: Patient
Shamian | National Comparative Database for Nursing Resource Consumption | ICD codes for secondary diagnoses present at admission
| | Analytic unit: Unit
Shortell | MedPAR dataset of hospital discharges | Medicare case mix
| | Analytic unit: Hospital
Shortell | Hospitals discharge data | DRG codes for comorbid conditions, APACHE III scores
| | Analytic unit: Unit
Silber | Pennsylvania Medicare claims records; Medicare Standard Analytic Files; random sample of 50% of Medicare patients who underwent general surgical or orthopedic procedures | ICD codes for comorbid conditions present at admission and physician's current procedural terminology for outpatient visits within 3 months before index hospital stay
| | Analytic unit: Hospital
Tourangeau | Ontario Acute Care Hospitals Dataset | DCID codes for pre-existing comorbid conditions (Manitoba adaptation of the Charlson index)
| | Analytic unit: Hospital
Tschannen | Patient medical records | Patient Acuity Index, ICD codes for comorbid conditions
| | Analytic unit: Patient
Unruh | Pennsylvania Health Care Cost Containment Council | MediQual severity measure to calculate scores
| | Analytic unit: Hospital
Unruh | State Health Care Cost Containment Council | MediQual severity scores
| | Analytic unit: Patient
Wan | Hospital records | Patient Acuity Index
| | Analytic unit: Hospital
Zidek | Hospital discharge data, patient records, and chart audits | Patients severity of illness index
| | Analytic unit: Patient

## References for Appendix E

1 Arnow P, Allyn PA, Nichols EM, et al. Control of methicillin-resistant Staphylococcus aureus in a burn unit: role of nurse staffing. J Trauma. Nov. 1982;22(11):954-9. [pmid: 6923938].
2 Wan TT, Shukla RK. Contextual and organizational correlates of the quality of hospital nursing care. Qual Rev Bull. Feb. 1987;13(2):61-4.
3 Flood SD, Diers D. Nurse staffing, patient outcome and cost. Nurs Manage. May 1988; 19(5):34–5, 8–9, 42–3.
4 Hartz AJ, Krakauer H, Kuhn EM, et al. Hospital characteristics and mortality rates. N Engl J Med. Dec 21. 1989;321(25):1720-5. [pmid: 2594031].
5 McDaniel C, Patrick T. Leadership, nurses, and patient satisfaction: a pilot study. Nurs Adm Q. Spring. 1992;16(3):72-4. [pmid: 1584481].
6 Krakauer H, Bailey RC, Skellan KJ, et al. Evaluation of the HCFA model for the analysis of mortality following hospitalization. Health Serv Res. Aug. 1992;27(3):317-35. [pmid: 1500289]. [pmcid: 1069881].
7 Halpine S, Maloney S. Tracing the missing link between nursing workload and case mix groups: a validation study. Health Manage Forum. Fall. 1993;6(3):19-26.
8 Aiken LH, Smith HL, Lake ET. Lower Medicare mortality among a set of hospitals known for good nursing care. Med Care. Aug. 1994;32(8):771-87. [pmid: 8057694].
9 Shamian J, Hagen B, Hu TW, et al. The relationship between length of stay and required nursing care hours. J Nurs Adm. Jul–Aug. 1994;24(78):52-8. [pmid: 8057174].
10 Taunton RL, Kleinbeck SV, Stafford R, et al. Patient outcomes. Are they linked to registered nurse absenteeism, separation, or work load?. J Nurs Adm. Apr. 1994;24(4 Suppl):48-55. [pmid: 8068081].
11 Shortell SM, Hughes EF. The effects of regulation, competition, and ownership on mortality rates among hospital inpatients. N Engl J Med. Apr 28. 1988;318(17):1100-7. [pmid: 3127713].
12 Shortell SM, Zimmerman JE, Rousseau DM, et al. The performance of intensive care units: does good management make a difference?. Med Care. May. 1994;32(5):508-25. [pmid: 8182978].
13 Grillo-Peck AM, Risner PB. The effect of a partnership model on quality and length of stay. Nurs Econ. Nov–Dec 1995; 13(6):367–72, 74.
14 Thorson MJ. Hours of nursing care: Relationship to patient outcomes. Dissertation. 1995; DAI-B 57/02, p. 992, Aug 1996:AAT 9616239.
15 Fridkin SK, Pear SM, Williamson TH, et al. The role of understaffing in central venous catheter-associated bloodstream infections. Infect Control Hosp Epidemiol. Mar. 1996;17(3):150-8. [pmid: 8708352].
16 Dugan J, Lauer E, Bouquot Z, et al. Stressful nurses: the effect on patient outcomes. J Nurs Care Qual. Apr. 1996;10(3):46-58. [pmid: 8634470].
17 Bloom JR, Alexander JA, Nuchols BA. Nurse staffing patterns and hospital efficiency in the United States. Soc Sci Med. Jan. 1997;44(2):147-55. [pmid: 9015868].
18 Archibald LK, Manning ML, Bell LM, et al. Patient density, nurse-to-patient ratio and nosocomial infection risk in a pediatric cardiac intensive care unit. Pediatr Infect Dis J. Nov. 1997;16(11):1045-8. [pmid: 9384337].
19 Minnick AF, Roberts MJ, Young WB, et al. What influences patients' reports of three aspects of hospital services?. Med Care. Apr. 1997;35(4):399-409. [pmid: 9107207].
20 Melberg SE. Effects of changing skill mix. Nurs Manage. Nov. 1997;28(11):47-8. [pmid: 9385157].
21 ANA. Implementing Nursing's Report Card. A Study of RN Staffing, Length of Stay and Patient Outcomes. The American Nurses Association. 1997; American Nurses Publishing, Washington DC, 1997.:ISBN 1558101349.
22 Blegen MA, Goode CJ, Reed L. Nurse staffing and patient outcomes. Nurs Res. Jan–Feb. 1998;47(1):43-50. [pmid: 9478183].
23 Blegen MA, Vaughn T. A multisite study of nurse staffing and patient occurrences. Nurs Econ. Jul–Aug. 1998;16(4):196-203. [pmid: 9748985].
24 Kovner C, Gergen PJ. Nurse staffing levels and adverse events following surgery in U.S. hospitals. Image J Nurs Sch. 1998;30(4):315-21. [pmid: 9866290].
25 Leiter MP, Harvie P, Frizzell C. The correspondence of patient satisfaction and nurse burnout. Soc Sci Med. Nov. 1998;47(10):1611-7. [pmid: 9823056].
26 Aiken LH, Sloane DM, Sochalski J. Hospital organisation and outcomes. Qual Health Care. Dec. 1998;7(4):222-6. [pmid: 10339024].
27 Pronovost PJ, Jenckes MW, Dorman T, et al. Organizational characteristics of intensive care units related to outcomes of abdominal aortic surgery. JAMA. Apr 14. 1999;281(14):1310-7. [pmid: 10208147].
28 Aiken LH, Sloane DM, Lake ET, et al. Organization and outcomes of inpatient AIDS care. Med Care. Aug. 1999;37(8):760-72. [pmid: 10448719].
29 Robertson RH, Hassan M. Staffing intensity, skill mix and mortality outcomes: the case of chronic obstructive lung disease. Health Serv Manage Res. Nov. 1999;12(4):258-68. [pmid: 10622804].
30 Lichtig LK, Knauf RA, Milholland DK. Some impacts of nursing on acute care hospital outcomes. J Nurs Adm. Feb. 1999;29(2):25-33. [pmid: 10029799].
31 Seago JA. Evaluation of a hospital work redesign: patient-focused care. J Nurs Adm. Nov. 1999;29(11):31-8. [pmid: 10565318].
32 Bond CA, Raehl CL, Pitterle ME, et al. Health care professional staffing, hospital characteristics, and hospital mortality rates. Pharmacotherapy. Feb. 1999;19(2):130-8. [pmid: 10030762].
33 Amaravadi RK, Dimick JB, Pronovost PJ, et al. ICU nurse-to-patient ratio is associated with complications and resource use after esophagectomy. Intensive Care Med. Dec. 2000;26(12):1857-62. [pmid: 11271096].
34 Gandjour A. The effect of managed care penetration on hospital staffing in Tennessee, 1991-1995. Manag Care Interface. Sep 2000; 13(9):62–6, 70.
35 Robert J, Fridkin SK, Blumberg HM, et al. The influence of the composition of the nursing staff on primary bloodstream infection rates in a surgical intensive care unit. Infect Control Hosp Epidemiol. Jan. 2000;21(1):12-7. [pmid: 10656348].
36 Silber JH, Kennedy SK, Even-Shoshan O, et al. Anesthesiologist direction and patient outcomes. Anesthesiology. Jul. 2000;93(1):152-63. [pmid: 10861159].
37 ANA. Nurse Staffing and Patient Outcomes: In the Inpatient Hospital Setting. American Nurses Publishing, Washington DC, 1997. 2000:1558101519.
38 Hoover KW. The impact of managed care penetration, hospital organizational variables and nurse staffing on hospital patient outcomes. Dissertation. 2000; DAI-B 61/08, p. 4062, Feb 2001:AAT 9984608.
39 Unruh LY. The impact of hospital nurse staffing on the quality of patient care. Dissertation. 2000; DAI-A 61/04, p. 1543, Oct 2000:AAT 9969789.
40 Pronovost PJ, Dang D, Dorman T, et al. Intensive care unit nurse staffing and the risk for complications after abdominal aortic surgery. Eff Clin Pract. Sep–Oct. 2001;4(5):199-206. [pmid: 11685977].
41 Dimick JB, Swoboda SM, Pronovost PJ, et al. Effect of nurse-to-patient ratio in the intensive care unit on pulmonary complications and resource use after hepatectomy. Am J Crit Care. Nov. 2001;10(6):376-82. [pmid: 11688604].
42 Blegen MA, Vaughn TE, Goode CJ. Nurse experience and education: effect on quality of care. J Nurs Adm. Jan. 2001;31(1):33-9. [pmid: 11198839].
43 Needleman J. Nurse staffing and patient outcomes in hospitals. Final Report for Health Resources Services Administration. 2001; Contract No. 230990021.
44 Bolton LB, Jones D, Aydin CE, et al. A response to California's mandated nursing ratios. J Nurs Scholarsh. 2001;33(2):179-84. [pmid: 11419315].
45 Aiken LH, Clarke SP, Sloane DM. Hospital restructuring: does it adversely affect care and outcomes?. J Health Hum Serv Adm. Spring. 2001;23(4):416-42. [pmid: 11924307].
46 Whitman GR, Davidson LJ, Sereika SM, et al. Staffing and pattern of mechanical restraint use across a multiple hospital system. Nurs Res. Nov–Dec. 2001;50(6):356-62. [pmid: 11725937].
47 Sovie MD, Jawad AF. Hospital restructuring and its impact on outcomes: nursing staff regulations are premature. J Nurs Adm. Dec. 2001;31(12):588-600. [pmid: 11771464].
48 Ridge RA. The relationship between patient satisfaction with nursing care and nurse staffing. Dissertation. 2001; DAI-B 62/01, p. 165, Jul 2001:AAT 3000170.
49 Ritter-Teitel J. An exploratory study of a predictive model for nursing-sensitive patient outcomes derived from patient care unit structure and process variables. Dissertation. 2001; DAI-B 62/02, p. 785, Aug 2001:AAT 3003686.
50 Dang D, Johantgen ME, Pronovost PJ, et al. Postoperative complications: does intensive care unit staff nursing make a difference?. Heart Lung. May–Jun. 2002;31(3):219-28. [pmid: 12011813].
51 Aiken LH, Clarke SP, Sloane DM, et al. Hospital nurse staffing and patient mortality, nurse burnout, and job dissatisfaction. JAMA. Oct 23–30. 2002;288(16):1987-93. [pmid: 12387650].
52 Seago JA, Ash M. Registered nurse unions and patient outcomes. J Nurs Adm. Mar. 2002;32(3):143-51. [pmid: 11984245].
53 Tourangeau AE, Giovannetti P, Tu JV, et al. Nursing-related determinants of 30-day mortality for hospitalized patients. Can J Nurs Res. Mar. 2002;33(4):71-88. [pmid: 11998198].
54 Kovner C, Jones C, Zhan C, et al. Nurse staffing and postsurgical adverse events: an analysis of administrative data from a sample of U.S. hospitals, 1990-1996. Health Serv Res. Jun. 2002;37(3):611-29. [pmid: 12132597]. [pmcid: 1434654].
55 Langemo DK, Anderson J, Volden CM. Nursing quality outcome indicators. The North Dakota Study. J Nurs Adm. Feb. 2002;32(2):98-105. [pmid: 11984237].
56 Needleman J, Buerhaus P, Mattke S, et al. Nurse-staffing levels and the quality of care in hospitals. N Engl J Med. May 30. 2002;346(22):1715-22. [pmid: 12037152].
57 Barkell NP, Killinger KA, Schultz SD. The relationship between nurse staffing models and patient outcomes: a descriptive study. Outcomes Manag. Jan–Mar. 2002;6(1):27-33. [pmid: 12500413].
58 Stegenga J, Bell E, Matlow A. The role of nurse understaffing in nosocomial viral gastrointestinal infections on a general pediatrics ward. Infect Control Hosp Epidemiol. Mar. 2002;23(3):133-6. [pmid: 11918117].
59 Whitman GR, Kim Y, Davidson LJ, et al. The impact of staffing on patient outcomes across specialty units. J Nurs Adm. Dec. 2002;32(12):633-9. [pmid: 12483084].
60 Cheung RB. The relationship between nurse staffing, nursing time, and adverse events in an acute care hospital. Dissertation. 2002; DAI-B 63/05, p. 2301, Nov 2002:AAT 3052636.
61 Oster CAH. The relationships between emergency department staffing and clinical outcomes of the acute myocardial infarction patient. Dissertation. 2002; DAI-B 63/03, p. 1272, Sep 2002:AAT 3045751.
62 Aiken LH, Clarke SP, Cheung RB, et al. Educational levels of hospital nurses and surgical patient mortality. JAMA. Sep 24. 2003;290(12):1617-23. [pmid: 14506121].
63 Beckman JAS. The effectiveness of nursing practice patterns in acute care nursing sub-units. Dissertation. 2003; DAI-B 64/11, p. 5445, May 2004:AAT 3111973.
64 Berney BL. Use, trends, and impacts of nurse overtime in New York hospitals, 1995-2000. Dissertation. 2003; DAI-B 63/11, p. 5154, May 2003:AAT 3072377.
65 Unruh L. Licensed nurse staffing and adverse events in hospitals. Med Care. Jan. 2003;41(1):142-52. [pmid: 12544551].
66 Cho SH. Nurse staffing and adverse patient outcomes. Dissertation. 2002; DAI-B 63/02, p. 735, Aug 2002:AAT 3042055.
67 Cho SH, Ketefian S, Barkauskas VH, et al. The effects of nurse staffing on adverse events, morbidity, mortality, and medical costs. Nurs Res. Mar–Apr. 2003;52(2):71-9. [pmid: 12657982].
68 Langemo DK, Anderson J, Volden C. Uncovering pressure ulcer incidence. Nurs Manage. Oct. 2003;34(10):54-7. [pmid: 14557784].
69 Needleman J, Buerhaus PI, Mattke S, et al. Measuring hospital quality: can Medicare data substitute for all-payer data?. Health Serv Res. Dec. 2003;38(6 Pt 1):1487-508. [pmid: 14727784]. [pmcid: 1360960].
70 Mark BA, Salyer J, Wan TT. Professional nursing practice: impact on organizational and patient outcomes. J Nurs Adm. Apr. 2003;33(4):224-34. [pmid: 12690254].
71 Alonso-Echanove J, Edwards JR, Richards MJ, et al. Effect of nurse staffing and antimicrobial-impregnated central venous catheters on the risk for bloodstream infections in intensive care units. Infect Control Hosp Epidemiol. Dec. 2003;24(12):916-25. [pmid: 14700407].
72 Bolton LB, Aydin CE, Donaldson N, et al. Nurse staffing and patient perceptions of nursing care. J Nurs Adm. Nov. 2003;33(11):607-14. [pmid: 14608220].
73 Potter P, Barr N, McSweeney M, et al. Identifying nurse staffing and patient outcome relationships: a guide for change in care delivery. Nurs Econ. Jul–Aug. 2003;21(4):158-66. [pmid: 14509874].
74 Hope J. Nosocomial infections and their relationship to nursing workload in an acute care hospital. Dissertation. 2003; MAI 42/04, p. 1241, Aug 2004:AAT MQ86117.
75 Simmonds KA. Nursing workload and its relationship to vancomycin-resistant enterococci colonization in chronic dialysis patients. Dissertation. 2004; MAI 43/02, p. 529, Apr 2005:AAT MQ93404.
76 Zidek CK. Assessment of nursing care quality and the judgment of the professional nurse as reflected in nurse-determined patient acuity classification and staffing decisions. Dissertation. 2003; DAI-B 64/02, p. 642, Aug 2003:AAT 3080441.
77 Tallier PC. Nurse staffing ratios and patient outcomes. Dissertation. 2003; DAI-B 64/05, p. 2133, Nov 2003:AAT 3091301.
78 Person SD, Allison JJ, Kiefe CI, et al. Nurse staffing and mortality for Medicare patients with acute myocardial infarction. Med Care. Jan. 2004;42(1):4-12. [pmid: 14713734].
79 Sochalski J. Is more better? the relationship between nurse staffing and the quality of nursing care in hospitals. Med Care. Feb. 2004;42(2 Suppl):II67-73. [pmid: 14734944].
80 Mark BA, Harless DW, McCue M, et al. A longitudinal examination of hospital registered nurse staffing and quality of care. Health Serv Res. Apr. 2004;39(2):279-300. [pmid: 15032955]. [pmcid: 1361008].
81 Van Doren ES, Bowman J, Landstrom GL, et al. Structure and process variables affecting outcomes for heart failure clients. Lippincotts Case Manag. Jan–Feb. 2004;9(1):21-6. [pmid: 15076834].
82 Vahey DC, Aiken LH, Sloane DM, et al. Nurse burnout and patient satisfaction. Med Care. Feb. 2004;42(2 Suppl):II57-66. [pmid: 14734943].
83 Boyle SM. Nursing unit characteristics and patient outcomes. Nurs Econ. May–Jun 2004; 22(3):111–9, 23, 07.
84 Cimiotti JP. Nurse staffing and healthcare-associated infections in the neonatal ICU. Dissertation. 2004; DAI-B 65/04, p. 1775, Oct 2004:AAT 3128935.
85 Estabrooks CA, Midodzi WK, Cummings GG, et al. The impact of hospital nursing characteristics on 30-day mortality. Nurs Res. Mar–Apr. 2005;54(2):74-84. [pmid: 15778649].
86 Marcin JP, Rutan E, Rapetti PM, et al. Nurse staffing and unplanned extubation in the pediatric intensive care unit. Pediatr Crit Care Med. May. 2005;6(3):254-7. [pmid: 15857520].
87 Elting LS, Pettaway C, Bekele BN, et al. Correlation between annual volume of cystectomy, professional staffing, and outcomes: a statewide, population-based study. Cancer. Sep 1. 2005;104(5):975-84. [pmid: 16044400].
88 Mark BA, Harless DW, McCue M. The impact of HMO penetration on the relationship between nurse staffing and quality. Health Econ. Jul. 2005;14(7):737-53. [pmid: 15744748].
89 Donaldson NE Brown DS, Bolton, LB et al. Unit Level Nurse Workload Impacts on Patient Safety. the Agency for Healthcare Research and Quality Working Conditions Grant Initiative. 2004; Grant R01 # HS11954.
90 Tschannen DJ. Organizational structure, process, and outcome: The effects of nurse staffing and nurse-physician collaboration on patient length of stay. Dissertation. 2005; DAI-B 66/02, p. 821, Aug 2005:AAT 3163954.
91 Houser E. Nurse staffing levels and patient outcomes. Dissertation. 2005; DAI-B 66/04, p. 1978, Oct 2005:AAT 3172609.
92 Halm M, Peterson M, Kandels M, et al. Hospital nurse staffing and patient mortality, emotional exhaustion, and job dissatisfaction. Clin Nurse Spec. Sep–Oct. 2005;19(5):241-51. quiz 52–4. [pmid: 16179855].
93 Donaldson N, Bolton LB, Aydin C, et al. Impact of California's licensed nurse-patient ratios on unit-level nurse staffing and patient outcomes. Policy Polit Nurs Pract. Aug. 2005;6(3):198-210. [pmid: 16443975].
94 Stratton KM. The relationship between pediatric nurse staffing and quality of care in the hospital setting. Dissertation. 2005; DAI-B 66/11, p. 5906, May 2006:AAT 3196584.
95 Seago JA, Williamson A, Atwood C. Longitudinal analyses of nurse staffing and patient outcomes: more about failure to rescue. J Nurs Adm. Jan. 2006;36(1):13-21. [pmid: 16404195].