# Appendix C: Technical Expert Panel Members and Affiliation

Peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

TEP Member | Affiliation
Sandra Edwardson, Ph.D., R.N. | School of Nursing University of Minnesota
Colleen Goode, R.N., Ph.D., F.A.A.N. | Patient Care Services University of Colorado Hospital
Christine Kovner, Ph.D., R.N. | College of Nursing New York University
Barbara Mark, R.N., Ph.D., F.A.A.N. | School of Nursing University of North Carolina at Chapel Hill
Jack Needleman, Ph.D. | School of Public Health UCLA
Pamela Thompson, M.S., R.N., F.A.A.N. | Chief Executive Officer American Organization of Nurse Executives