# Appendix B: List of Excluded Studies

## References

1 Anonymous. Temporary or pseudo-permanent? Qld Nurse. Nov–Dec 1990;9(6):13. Comment.
2 Anonymous. Four easy ways to lose a job in nursing. Am J Nurs. Jun 1990;90(6):27–28. Comment.
3 Anonymous. Time oriented score system (TOSS): a method for direct and quantitative assessment of nursing workload for ICU patients. Italian Multicenter Group of ICU research (GIRTI). Intensive Care Med. 1991;17(6):340–345. Not eligible target population.
4 Anonymous. Flexible scheduling and part-time work. Focus Crit Care. Jun 1991;18(3):195–196, 198–199. Comment.
5 Anonymous. Infamous acuity system. Am J Nurs. Jun 1991;91(6):14. Comment.
6 Anonymous. An HIV-infected nurse must be reinstated. Am J Nurs. Dec 1992;92(12):9. News.
7 Anonymous. A case in point: “catch-all” clause protects nurses' rights. Mich Nurse. Mar 1992;65(3):19. Legal cases.
8 Anonymous. Draft guidelines on preventable medication errors. Am J Hosp Pharm. Mar 1992;49(3):640–648. Guideline.
9 Anonymous. Humanising the shiftwork systems. Qld Nurse. May–Jun 1992;11(3):23. Comment.
10 Anonymous. Nursing “cannibalistic” toward its elders, too. Nurs Manage. Oct 1993;24(10):8. Letter.
11 Anonymous. Mandatory AIDS testing could create hospital staffing problems. N J Med. May 1993;90(5):411. News.
12 Anonymous. Measuring neonatal nursing workload. Northern Neonatal Network. Arch Dis Child. May 1993;68(5 Spec No):539–543. Not eligible target population.
13 Anonymous. Self-scheduling guidelines. Pediatric unit. Mercy Hospital and Medical Center, San Diego, California. Aspens Advis Nurse Exec. Aug 1993;8(11):suppl 1. Guideline.
14 Anonymous. Low nursing staffing levels causing stress. OR Manager. Mar 1993;9(3):15, 26. Comment.
15 Anonymous. The challenge of operating within staffing budgets on the maternity unit at New England Memorial Hospital despite a fluctuating census. Qual Lett Healthc Lead. Feb 1993;5(1):15–17. No association tested.
16 Anonymous. NLN survey informs Dept. of Labor study. NLN Research & Policy PRISM Jun 1994;2(2):4–8. Not relevant.
17 Anonymous. Some guidelines for staffing in the absence of patient classification systems. Qld Nurse. Jul–Aug 1994;13(4):12. Not eligible target population.
18 Anonymous. Sister Susie. Lights, camera, traction! Nurs Stand. Feb 2–8 1994;8(19):47. Not eligible target population.
19 Anonymous. An issue of floating. Nursing. Nov 1994;24(11):76–77. Legal cases.
20 Anonymous. Enterprise bargaining in the private sector. Qld Nurse. Nov–Dec 1994;13(6):10–11. Comment.
21 Anonymous. Staffing patterns for patient care and support personnel in a general pediatric unit. American Academy of Pediatrics Committee on Hospital Care. Pediatrics. May 1994;93(5):850–854. No association tested.
22 Anonymous. And speaking of patient safety. AARN News Lett. Apr 1994;50(4):11. Comment.
23 Anonymous. Medication incident reporting forms. Lamp. Apr 1995;52(3):22–25. Comment.
24 Anonymous. Rebuilding a unit for seamless surgical care. OR Manager. Dec 1995;11(12):15–16. Comment.
25 Anonymous. Employees speak out. Testimonials help hospital recruit in- and out-of-state, boost staff morale and patient satisfaction. McLeod Regional Medical Center, Florence, SC. Profiles Healthc Mark. Mar–Apr 1995(64):2–7. Comment.
26 Anonymous. Stroke path calls for care when evaluating variances. Hosp Case Manag. Nov 1995;3(11):176–177. Comment.
27 Anonymous. Integrating an understanding of sleep knowledge into your practice (continuing education credit). Am Nurse. Mar 1995;27(2):20–21. Comment.
28 Anonymous. How do you know if your paycheck is correct? Ky Nurse. Jan–Mar 1995;43(1):11. Comment.
29 Anonymous. 38 hour week—your questions answered. Qld Nurse. Jan–Feb 1995;14(1):15–17. Not eligible target population.
30 Anonymous. A review of the use of DySSSy. Nurs Stand. Oct 9 1996;11(3):32. Not eligible target population.
31 Anonymous. Patient nurse dependency. Qld Nurse. Sep–Oct 1996;15(5):18. Comment.
32 Anonymous. IOM issues nursing staffing report: some positive recommendations yet report fails to address immediacy of hospital staffing problems. Am Nurse. Mar 1996;28(2):8; 23. Comment.
33 Anonymous. Position statement on minimum staffing in NICUs. Neonatal Netw. Mar 1996;15(2):48. Review.
34 Anonymous. Hospital nixes pathways, keeps case management. Hosp Case Manag. Jan 1996;4(1):6, 11–12. Comment.
35 Anonymous. Colorado case blurs line between board of nursing admin. law and criminal action. Am Nurse. Sep–Oct 1997;29(5):3. Legal cases.
36 Anonymous. Wound care team nips costly bed sore problems, slashes hospital expenses. Health Care Cost Reengineering Rep. Dec 1997;2(12):181–185; suppl 181–184. Not eligible exposure.
37 Anonymous. Nurses' report card project under way. Hosp Peer Rev. Jun 1997;22(6):76–78. Comment.
38 Anonymous. Renal transplantees have special education needs. Hosp Case Manag. Mar 1997;5(3):43–44, 49–51. Not eligible exposure.
39 Anonymous. Rx for cutting labor costs: add more registered nurses. Health Care Cost Reengineering Rep. Jun 1997;2(6):81–85. No association tested.
40 Anonymous. Patient commits suicide; hospital, nursing agencies settle for $700,000. Hosp Secur Saf Manage. Oct 1997;18(6):8–10. Comment.
41 Anonymous. Who should own case management within the continuum of care? Hosp Case Manag. Mar 1997;5(3):37–39. Comment.
42 Anonymous. Does an RN have the right to refuse to be floated to an area that she/he believes they are unqualified for? Chart. Apr 1997;94(4):5. Comment.
43 Anonymous. Cook County Hospital RNs take on restructuring. Chart. Nov 1997;94(11):1. Comment.
44 Anonymous. Issue: we never seem to have enough staffing on my unit. What can we do? Ohio Nurses Rev. Nov–Dec 1997;72(10):16. Comment.
45 Anonymous. Nurse staffing and quality of care in health care organizations research agenda of the Department of Health and Human Services, Agency for Health Care Policy and Research, National Institute for Nursing Research, Division of Nursing of HRSA. Nurs Outlook. Jul–Aug 1997;45(4):190–191. News.
46 Anonymous. What can you do to assist float nurses who are assigned to your unit? J N Y State Nurses Assoc. Jun 1997;28(2):19. Comment.
47 Anonymous. Patient abandonment. Nursing. Apr 1997;27(4):69. Legal cases.
48 Anonymous. Approaches to organising nursing shift patterns. Nurs Stand. Jan 22 1997;11(18):32–33. No association tested.
49 Anonymous. Hospital fails to diagnose CVA; EMTALA suit follows. Regan Rep Nurs Law. Mar 1998;38(10):1. Comment.
50 Anonymous. Voices from Colorado. Nurs Manage. Jun 1998;29(6):52–53. Legal cases.
51 Anonymous. To err is human to forgive is divine, as one nurse found out. Nurs Times. May 6–12 1998;94(18):49. Comment.
52 Anonymous. Cut pneumonia length of stay, costs, readmissions. Health Care Cost Reengineering Rep. Jan 1998;3(1):1–5; suppl 1–4. Not eligible exposure.
53 Anonymous. Telemetry unit moves from worst to best using redesign process. Patient Focus Care Satisf. Dec 1998;6(12):137–139. Comment.
54 Anonymous. Improving pain management for orthopedic patients at Hermann Hospital, Houston, TX. Qual Connect. Winter 1998;7(1):9. Not eligible target population.
55 Anonymous. The “take a nurse to lunch” program. A unique focus group improves and promotes food services. Health Care Food Nutr Focus. Oct 1998;15(2):5–7. Not eligible exposure.
56 Anonymous. Study reveals satisfaction with hospital experience major factor in decision to donate. Plus study finds health professionals not prepared to recommend donation. Nephrol News Issues. Jun 1998;12(6):64–66, 68. Not eligible exposure.
57 Anonymous. CVA (cerebrovascular accident) pathway cuts across seven hospital units. Hosp Case Manag. Feb 1998;6(2):33–34. Not eligible exposure.
58 Anonymous. Counter misleading data: adjust for patient acuity, indirect nursing hours. ED Manag. Mar 1998;10(3):29–30. Comment.
59 Anonymous. Are ED nursing staff levels under attack? Patient Focus Care Satisf. May 1998;6(5):59–62. No association tested.
60 Anonymous. How do you know you're productive in PACU (postanesthesia care unit)? OR Manager. Apr 1998;14(4):24–25. Comment.
61 Anonymous. Nursing staff levels under attack? Respond with data, increased efficiency. ED Manag. Mar 1998;10(3):25–29. No association tested.
62 Anonymous. Massachusetts board reprimands Dana-Farber nurses. Am Nurse. Sep–Oct 1999;31(5):6. Comment.
63 Anonymous. Court rules ‘no duty to consult with Dr. Re Meds.’ Case on point: Silves v. King, 970 P.2d 791-WA (1999). Regan Rep Nurs Law. Mar 1999;39(10):. Legal cases.
64 Anonymous. Fund to pay $10M: seeks contribution from nurse. Regan Rep Nurs Law. Mar 1999;39(10):1. Legal cases.
65 Anonymous. Defining provider roles. More work + changing roles = less satisfaction for providers and patients. Patient Focus Care Satisf. Nov 1999;7(11):121–123. Comment.
66 Anonymous. Foreign-educated nurses participate in the computerized clinical simulation testing (CST) pilot study. Issues 1999;20(1):5. Not relevant.
67 Anonymous. More RNs means fewer post-surgical complications. Mich Nurse. Mar 1999;72(3):9. News.
68 Anonymous. Cross-training programs offer scheduling flexibility. Patient Focus Care Satisf. Dec 1999;7(12):139–140. Comment.
69 Anonymous. Patient acuity profiles can keep you on budget. Patient Focus Care Satisf. Dec 1999;7(12):137–139. No association tested.
70 Anonymous. Take California's word: nurse staffing levels do impact quality of care. Patient Focus Care Satisf. Dec 1999;7(12):133–136. Comment.
71 Anonymous. Conscious sedation raises safe staffing concerns. Dimens Crit Care Nurs. Jan–Feb 1999;18(1):35. Comment.
72 Anonymous. Cutting RNs a false economy? Hosp Peer Rev. Feb 1999;24(2):29–30. Comment.
73 Anonymous. More RNs lower risk of UTIs, pneumonia. OR Manager. Jan 1999;15(1):7. Comment.
74 Anonymous. Appealing for compensation. Nursing. Mar 1999;29(3):25. Legal cases.
75 Anonymous. Critical care services and personnel: recommendations based on a system of categorization into two levels of care. American College of Critical Care Medicine of the Society of Critical Care Medicine. Crit Care Med. Feb 1999;27(2):422–426. Review.
76 Anonymous. Defining provider roles. Hartford uses report cards to teach nurses to teach. Patient Focus Care Satisf. Jan 2000;8(1):1–4. Comment.
77 Anonymous. Shortage spurs hunt for hospital staffing ratios. Patient Focus Care Satisf. Feb 2000;8(2):18–21. No association tested.
78 Anonymous. ‘It's about safe care’. Nurses strike Tenet-owned St. Vincent over mandatory overtime. Revolution. Mar–Apr 2000;1(2):10. News.
79 Anonymous. Texas' nursing education system. Can it respond to this nursing shortage? Tex Nurs. Apr 2000;74(4):4–5, 11–12. Comment.
80 Anonymous. Staffing shortages mean increased opportunities. Crit Care Nurse. Feb 2000;Suppl:16. Comment.
81 Anonymous. NHS Direct will not cure ward-level staffing and skill-mix problems. Nurs Times. Mar 23–29 2000;96(12):3. Not eligible target population.
82 Anonymous. State of the nursing shortage. Am J Nurs. Dec 2000;100(12):20–21. News.
83 Anonymous. Frustrated by the nursing shortage? Try these tactics instead of bonuses. ED Manag. Oct 2000;12(10):109–113. Comment.
84 Anonymous. California nurses win landmark victory. Am J Nurs. Jan 2000;100(1):20. News.
85 Anonymous. Patient safety alert. Has the nursing shortage decreased health care quality? Hosp Peer Rev. Jan 2001;26(1):1–2. Comment.
86 Anonymous. ED makes nurses happy by outsourcing calls. ED Manag. Oct 2001;13(10):113–115. Not eligible exposure.
87 Anonymous. Striving to become the employer of choice: the relationship of employee and patient satisfaction. Healthc Leadersh Manag Rep. Jul 2001;9(7):9–15. No association tested.
88 Anonymous. Has the nursing shortage decreased health care quality? Healthc Benchmarks. Jan 2001;8(1):suppl 1–2. Comment.
89 Anonymous. For safety's sake, bill aims to eliminate overtime. Hosp Case Manag. May 2001;9(5):78, 66. Interview.
90 Anonymous. Rules proposal intended to clarify nurse staffing. Tex Nurs. Mar 2001;75(3):4–5. Comment.
91 Anonymous. Terminated nurse alleges hospital violated ADA. Case on point: Phelps v. Optima Health Inc., 2001 WL 563921 N.E.2d-NH. Nurs Law Regan Rep. Jul 2001;42(2):4. Legal cases.
92 Anonymous. Occupational health. Court told overwork led to breakdown. Nurs Times. Jun 28–Jul 4 2001;97(26):7. Legal cases.
93 Anonymous. Staff safety. Violent patients get the red card. Nurs Times. Jun 21–27 2001;97(25):4. Comment.
94 Anonymous. Brief encounters costing the NHS dear. J Nurs Manag. Nov 2001;9(6):353–356. News.
95 Anonymous. Guidelines for nurse staffing in intensive care: a consultation document (3rd draft, July 2001). Intensive Crit Care Nurs. Oct 2001;17(5):254–258. News.
96 Anonymous. Mandatory overtime bill caps off successful legislative year. Am Nurse. Nov–Dec 2001;33(6):3, 17. Comment.
97 Anonymous. 2001 salary survey results. Are you losing staff to other facilities? Here's what ED managers need to do. ED Manag. Nov 2001;13(11):suppl 1–4. Comment.
98 Anonymous. The staffing shortage: dealing with the here and now. Healthc Leadersh Manag Rep. Jul 2001;9(7):1–7. No association tested.
99 Anonymous. Linking staffing and quality issues. Jt Comm Perspect. Aug 2001;21(8):8–9. Comment.
100 Anonymous. Perspectives. Work environment a top issue in nurse retention. Med Health. Aug 13 2001;55(31):7–8. News.
101 Anonymous. Nurses rally to ban forced overtime. OR Manager. Jul 2001;17(7):6–7. Comment.
102 Anonymous. Senate confronts the nursing shortage. ED Manag. Apr 2001;13(4):45–46. Review.
103 Anonymous. Temp staff become a fixture in ORs. OR Manager. Jun 2001;17(6):15. Comment.
104 Anonymous. Interviews find some ORs have vacancies, others waiting lists. OR Manager. Jun 2001;17(6):1, 13–14. Comment.
105 Anonymous. New study gauges scope of nursing shortage. Hosp Peer Rev. Jun 2001;26(6):83–85, 74. Comment.
106 Anonymous. Staffing watch. Hosp Health Netw. Apr 2001;75(4):26. News.
107 Anonymous. Off-shift choices help to keep nurses. OR Manager. Feb 2001;17(2):20. Comment.
108 Anonymous. Anger over double HIV test. Nurs Times. Mar 8–14 2001;97(10):7. News.
109 Anonymous. Solutions to health care's labor shortages. Russ Coiles Health Trends. Nov 2001;14(1):8–12. Comment.
110 Anonymous. Nurse's unintentional error is not ‘willful misconduct’. Nurs Law Regan Rep. Jan 2002;42(8):1. Legal cases.
111 Anonymous. Staff collaboration boosts adoption of best practices. Rn. Nov 2002;65(11):34hf32–35. Comment.
112 Anonymous. Patient safety alert. Closer link made between nursing shortage, safety. Healthcare Benchmarks Qual Improv. Oct 2002;9(10):suppl 1–3. Comment.
113 Anonymous. JCAHO: nurse shortage threat to patient safety. OR Manager. Sep 2002;18(9):8. Review.
114 Anonymous. JCAHO: nursing shortage puts patients at risk, demands immediate attention. Hosp Peer Rev. Sep 2002;27(9):117–119. Comment.
115 Anonymous. Nurses may be your best tool for improving quality of care. Hosp Peer Rev. Aug 2002;27(8):105–108. No association tested.
116 Anonymous. Sentinel event leads to safety checklist. Hosp Peer Rev. Jul 2002;27(7):91–94, 99. Comment.
117 Anonymous. Medication error. Salty language. Nursing. Apr 2002;32(4):12. Comment.
118 Anonymous. Greater nursing staff levels result in better care for hospital patients. Health Care Strateg Manage. Jun 2002;20(6):12. Comment.
119 Anonymous. California releases proposed nurse-to-patient ratios for acute care hospitals. Prairie Rose. Mar–May 2002;71(1):1, 3. Comment.
120 Anonymous. In our hands and in our hearts: finding solutions to the staffing crisis. Healthc Leadersh Manag Rep. Dec 2002;10(12):1–8. Comment.
121 Anonymous. The business planning framework—nursing resources. Qld Nurse. Sep–Oct 2002;21(5):13. Comment.
122 Anonymous. Developing a plan to improve the odds of retaining your staff. OR Manager. Dec 2002;18(12):1, 10–11. Review.
123 Anonymous. Spotlight on nursing. A focus on lasting workplace solutions. Tex Nurs. Aug 2002;76(7):8–10, 14. Comment.
124 Anonymous. Inadequate staffing linked to poor patient outcomes. Nurs Manage. Sep 2002;33(9):20. Review.
125 Anonymous. Senate and Assembly hold joint health committee hearing on nursing shortage and nurse staffing crisis. N J Nurse. Jul–Aug 2002;32(6):1, 6. Review.
126 Anonymous. OR staffing holds up, but coping with shortage is more challenging. OR Manager. Sep 2002;18(9):1, 11, 14–16 passi. Comment.
127 Anonymous. PSNA mandatory overtime survey summary. Pennsylvania Nurse Aug–Sep 2002;57(7):8–9. Not peer reviewed.
128 Anonymous. Proposed staffing rules pass. Implementation begins. Tex Nurs. Mar 2002;76(3):8–9. Comment.
129 Anonymous. Web survey. March results: ‘nurse staffing—beyond the ratios’. Mod Healthc. Apr 8 2002;32(14):35. Web survey.
130 Anonymous. Tough times in healthcare. J Nurs Adm. Mar 2002;32(3):122. Letter.
131 Anonymous. Hashing out California's staffing ratios. Am Nurse. Mar–Apr 2002;34(2):1, 16–17. Comment.
132 Anonymous. Position statement on intensive care nursing staffing. Aust Crit Care. Feb 2002;15(1):6–7. Not eligible target population.
133 Anonymous. Faced with staffing minimums, hospitals lure nurses with sign-on bonuses. Nephrol News Issues. Apr 2002;16(5):63. Comment.
134 Anonymous. Guidance paper: refocusing the role of the midwife. RCM Midwives J. Apr 2002;5(4):128–133. Not eligible target population.
135 Anonymous. Survey shows increasing vacancy rates. Synergy News Aug 2002:20–1. Not peer reviewed.
136 Anonymous. By the numbers. Staffing. Mod Healthc. Dec 23 2002;Suppl:44, 46, 48. Comment.
137 Anonymous. Data trends. The true cost of overtime. Healthc Financ Manage. Dec 2002;56(12):90. No association tested.
138 Anonymous. NY: nurse learns of pt's doubt re surgery site: hospital liabile for operation on wrong hand. Nurs Law Regan Rep. Dec 2003;44(7):3. Legal cases.
139 Anonymous. Deplorable ICU nursing results in $2.4 million judgment. Case on point: Mobile Infirmary Medical Center v. Hodgen, 2003 WL 22463340 so.2d—AL. Nurs Law Regan Rep. Nov 2003;44(6):2. Legal cases.
140 Anonymous. AL: wrong epinephrine dose—cardiac arrest: Ct. emphasizes the ‘5 Rs’ of drug administration. Nurs Law Regan Rep. Sep 2003;44(4):3. Legal cases.
141 Anonymous. Making your mark. Nursing. Aug 2003;33(8):18. News.
142 Anonymous. Nurses and pharmacists partner for patient safety. Healthcare Benchmarks Qual Improv. Aug 2003;10(8):92–93. Comment.
143 Anonymous. IL: Discovery of disciplining of RN post pt.'s death: RN's voluntary termination too remote in time. Nurs Law Regan Rep. Jan 2003;43(8):3. Legal cases.
144 Anonymous. RN's comp. claim based on PTSD resulting from short staffing, etc. Case on point: Smith-Price v. Charter Pines Behavioral Ctr., 584 S.E.2d 881-NC. Nurs Law Regan Rep. Sep 2003;44(4):2. Legal cases.
145 Anonymous. Do you address staffing effectiveness standards? Hosp Peer Rev. Sep 2003;28(9):122, 127–128. Comment.
146 Anonymous. ANA applauds federal legislation to mandate safe nurse-to-patient ratios. Ky Nurse. Jul–Sep 2003;51(3):6. News.
147 Anonymous. Federal safe staffing bill introduced. Am Nurse. May–Jun 2003;35(3):1, 5. News.
148 Anonymous. Tales from the trenches. Patient Care Manag. Feb 2003;19(2):10–12. Comment.
149 Anonymous. 5 resolutions for a happy 2003. Patient Care Manag. Jan 2003;19(1):1, 4–6. Comment.
150 Anonymous. CA: Nurse errs in giving pitocin to stop labor: father's suit for emotional distress fails. Nurs Law Regan Rep. Oct 2004;45(5):3. Legal cases.
151 Anonymous. Nurse sued when child dies from error in interpreting drug dosage. Nurs Law Regan Rep. Oct 2004;45(5):1. Legal cases.
152 Anonymous. Study shows 12-hour shifts increase errors. Healthcare Benchmarks Qual Improv. Sep 2004;11(9):105–106. Comment.
153 Anonymous. Adverse events. Focus on patient safety. Can Nurse. Feb 2004;100(2):30. Comment.
154 Anonymous. Nurses identify barriers to educating patients about meds. Hosp Health Netw. Jan 2004;78(1):64. Comment.
155 Anonymous. California patient care labor costs rise under staffing requirements. Healthc Financ Manage. Nov 2004;58(11):118. Comment.
156 Anonymous. Veteran nurses give patients a quick look to avoid waits. Perform Improv Advis. Aug 2004;8(8):85–87. Comment.
157 Anonymous. Preliminary report, mandatory overtime by RNs in Louisiana 2004 Louisiana Registered Nurse Population Survey. Pelican news Mar 2004;60(1):20. Not peer reviewed.
158 Anonymous. Shifts go up for bid: hospitals see boost in patient care, staff morale. Healthcare Benchmarks Qual Improv. Oct 2004;11(10):109–112. Comment.
159 Anonymous. Reducing junior doctors' hours will extend opportunities for nurses. Nurs Times. Jul 27–Aug 2 2004;100(30):15. Comment.
160 Anonymous. Levels of care: the impact of nurse-patient ratios. Prof Nurse. Jul 2004;19(11):6–7. News.
161 Anonymous. Research shows Michigan safe patient care initiatives save lives and money. Mich Nurse. Jun–Jul 2004:8. News.
162 Anonymous. Staffing the ED despite the nursing shortage. Rn. Feb 2004;67(2):26hf21–26hf22. Comment.
163 Anonymous. Flexible job options help maintain quality. Healthcare Benchmarks Qual Improv. Jan 2004;11(1):8–9. Comment.
164 Anonymous. JCAHO's 2006 National Patient Safety Goals: handoffs are biggest challenge. Hosp Peer Rev. Jul 2005;30(7):89–93. Comment.
165 Anonymous. Nurse terminated for meds. error: hospital attempts to deny access to records. Case on point: Chapman v. Health & Hospital Corporations, 2005 WL 697435—NY. Nurs Law Regan Rep. May 2005;45(12):2. Legal cases.
166 Anonymous. More than 40% of nurse errors not from medication. Healthcare Benchmarks Qual Improv. Apr 2005;12(4):41–43. Comment.
167 Anonymous. Women need flexible schedules and challenging assignments. Health Care Strateg Manage. Jun 2005;23(6):12. Comment.
168 Anonymous. AR:12-hour-shift RN falls on trip to cafeteria: workers' compensation benefits awarded to nurse. Nurs Law Regan Rep. Apr 2005;45(11):3. Legal cases.
169 Anonymous. AACN standards for establishing and sustaining healthy work environments: a journey to excellence. Am J Crit Care. May 2005;14(3):187–197. Review.
170 Anonymous. Position paper on safe staffing. Tar Heel Nurse. Jan–Feb 2005;67(1):20. Review.
171 Anonymous. An opportunity to shape patient care. Nurs Times. Jun 14–20 2005;101(24):69. Not eligible target population.
172 Anonymous. Wright S. Nursing development? Nurs Stand. Jun 12–18 1991;5(38):52–53. No association tested.
173 Abbott A, Barrow S, Lopresti F, et al. International employment in clinical practice: influencing factors for the dental hygienist. International Journal of Dental Hygiene. Feb. 2005;3(1):37-44. Not relevant. [pmid: 16451376].
174 Abbott J, Young A, Haxton R, Van Dyke P. Collaborative care: a professional model that influences job satisfaction. Nurs Econ. May–Jun 1994;12(3):167–169, 174. Not eligible exposure.
175 Abbott ME. Measuring the effects of a selfscheduling committee. Nurs Manage. Sep 1995;26(9):64A–64B, 64D, 64G. Not eligible outcomes.
176 Ackerman MH, Henry MB, Graham KM, Coffey N. Humor won, humor too: a model to incorporate humor into the healthcare setting. Nurs Forum. Oct–Dec. 1993;28(4):9-16. Not eligible exposure. [pmid: 8302661].
177 Ackley NL. Is a serious nurse shortage coming?. Tex Nurs. Mar. 1999;73(3):10-13. Comment. [pmid: 11949009].
178 Adam S. Plugging the gap—critical care skills are the current universal commodity. Nurs Crit Care. Sep–Oct. 2004;9(5):195-198. Editorial. [pmid: 15462117].
179 Adams A, Bond S. Clinical specialty and organizational features of acute hospital wards. J Adv Nurs. Dec. 1997;26(6):1158-1167. Not eligible target population. [pmid: 9429966].
180 Adams A, Bond S. Staffing in acute hospital wards: part 2. Relationships between grade mix, staff stability and features of ward organizational environment. J Nurs Manag. Sep. 2003;11(5):293-298. Not eligible target population. [pmid: 12930534].
181 Adams A, Bond S. Staffing in acute hospital wards: part 1. The relationship between number of nurses and ward organizational environment. J Nurs Manag. Sep. 2003;11(5):287-292. Not eligible target population. [pmid: 12930533].
182 Adams B. Are we our own jail keepers?. Revolution. Nov–Dec. 2000;1(6):30-31. Comment. [pmid: 12018045].
183 Adams B. Profile: Barry Adams in his own words. Revolution. Jan–Feb. 2000;1(1):10-11. Interview. [pmid: 11209337].
184 Adams B. Accountable but powerless. Health Aff (Millwood). Jan–Feb. 2002;21(1):218-223. Comment. [pmid: 11900080].
185 Adams DA. The relationship between use of varying proportions of part-time faculty and full-time nursing faculty perceptions of workload and collegial support. Not relevant.
186 Adams DA. The relationship between use of varying proportions of part-time faculty and full-time nursing faculty perceptions of workload and collegial support. Not relevant.
187 Adams K, Murphy J. Addressing barriers in headache care. Interview by Janis Smy. Nurs Times. May 11–17. 2004;100(19):26-27. Interview. [pmid: 15160498].
188 Adams KS, Zehrer CL, Thomas W. Comparison of a needleless system with conventional heparin locks. Am J Infect Control. Oct. 1993;21(5):263-269. Not eligible exposure. [pmid: 8267238].
189 Adamsen L, Rasmussen JM. Exploring and encouraging through social interaction: a qualitative study of nurses' participation in self-help groups for cancer patients. Cancer Nurs. Feb. 2003;26(1):28-36. Not eligible target population. [pmid: 12556710].
190 Adamsen L, Tewes M. Discrepancy between patients' perspectives, staff's documentation and reflections on basic nursing care. Scand J Caring Sci. 2000;14(2):120-129. Not eligible target population. [pmid: 12035275].
191 Adejumo O. Divergent backgrounds, unified goals: continuing education program for multinational nurses in a hospital in the Middle East. J Contin Educ Nurs. Mar–Apr. 1999;30(2):79-83. Not eligible target population. [pmid: 10382460].
192 Adomat R, Hewison A. Assessing patient category/dependence systems for determining the nurse/patient ratio in ICU and HDU: a review of approaches. J Nurs Manag. Sep. 2004;12(5):299-308. Not eligible target population. [pmid: 15315485].
193 Adomat R, Hicks C. Measuring nursing workload in intensive care: an observational study using closed circuit video cameras. J Adv Nurs. May. 2003;42(4):402-412. Not eligible target population. [pmid: 12752885].
194 Agbo M. Up to one's eyes. Nurs Stand. Oct 25–31. 1995;10(5):55. Comment. [pmid: 8546945].
195 Agnew T. Making a difference. Nurs Times. Jun 7–13. 1995;91(23):18. News. [pmid: 7603868].
196 Ahmad MM, Alasad JA. Predictors of patients' experiences of nursing care in medical-surgical wards. Int J Nurs Pract. Oct. 2004;10(5):235-241. Not eligible target population. [pmid: 15461693].
197 Ahmann E. Examining assumptions underlying nursing practice with children and families. Pediatr Nurs. Sep–Oct. 1998;24(5):467-469. No association tested. [pmid: 9832906].
198 Ahmed DS, Fecik S. The fatigue factor. When long shifts harm patients. Am J Nurs. Sep. 1999;99(9):12. Case reports.
199 Ahmed DS, Hamrah PM. Right drug, wrong dose. Am J Nurs. Jan. 1999;99(1 Pt 1):12. Case reports.
200 Ahmed S. Out-patients in vogue. Nurs Stand. May 18–24. 1994;8(34):40. Comment. [pmid: 8038071].
201 Ahrens T, Yancey V, Kollef M. Improving family communications at the end of life: implications for length of stay in the intensive care unit and resource use. Am J Crit Care. Jul. 2003;12(4):317-323. discussion 324. Not eligible exposure. [pmid: 12882061].
202 Aiken LH. More nurses, better patient outcomes: why isn't it obvious?. Eff Clin Pract. Sep–Oct. 2001;4(5):223-225. Comment. [pmid: 11685981].
203 Aiken LH. Evidence of our instincts: an interview with Linda H. Aiken. Interview by Alison P. Smith. Nurs Econ. Mar–Apr. 2002;20(2):58-61. Not eligible target population. [pmid: 11944531].
204 Aiken LH, Buchan J, Sochalski J, Nichols B, Powell M. Trends in international nurse migration. Health Aff (Millwood). May–Jun. 2004;23(3):69-77. Not eligible exposure. [pmid: 15160804].
205 Aiken LH, Clarke SP, Silber JH, Sloane D. Hospital nurse staffing, education, and patient mortality. LDI Issue Brief. Oct. 2003;9(2):1-4. Comment. [pmid: 14621688].
206 Aiken LH, Clarke SP, Sloane DM. Hospital restructuring: does it adversely affect care and outcomes?. J Nurs Adm. Oct. 2000;30(10):457-465. Published twice. [pmid: 11045104].
207 Aiken LH, Clarke SP, Sloane DM. Hospital staffing, organization, and quality of care: cross-national findings. Int J Qual Health Care. Feb. 2002;14(1):5-13. Not eligible target population. [pmid: 11871630].
208 Aiken LH, Clarke SP, Sloane DM. Hospital staffing, organization, and quality of care: Cross-national findings. Nurs Outlook. Sep–Oct. 2002;50(5):187-194. Not eligible target population. [pmid: 12386653].
209 Aiken LH, Havens DS, Sloane DM. The Magnet Nursing Services Recognition Program. Am J Nurs. Mar. 2000;100(3):26-35. quiz 35–26. Not eligible exposure. [pmid: 10738398].
210 Aiken LH, Havens DS, Sloane DM. Magnet nursing services recognition programme. Nurs Stand. Mar 8–14. 2000;14(25):41-47. No association tested. [pmid: 11235355].
211 Aiken LH, Patrician PA. Measuring organizational traits of hospitals: the Revised Nursing Work Index. Nurs Res. May–Jun. 2000;49(3):146-153. Review. [pmid: 10882319].
212 Aiken LH, Sloane DM, Klocinski JL. Hospital nurses' occupational exposure to blood: prospective, retrospective, and institutional reports. Am J Public Health. Jan. 1997;87(1):103-107. Not eligible outcomes. [pmid: 9065213]. [pmcid: 1380773].
213 Aiken LH, Sloane DM, Lake ET. Satisfaction with inpatient acquired immunodeficiency syndrome care. A national comparison of dedicated and scattered-bed units. Med Care. Sep. 1997;35(9):948-962. Not eligible exposure. [pmid: 9298083].
214 Aiken LH, Sloane DM, Lake ET, Sochalski J, Weber AL. Organization and outcomes of inpatient AIDS care. LDI Issue Brief. Sep. 1999;5(1):1-4. Comment. [pmid: 12523339].
215 Aikens A. Colors of the spectrum. Agency/registry nursing. Nurs Spectr (Wash D C). Nov 27. 1995;5(24):16. Comment. [pmid: 8535531].
216 Aitken LM. Critical care nurses' use of decision-making strategies. J Clin Nurs. Jul. 2003;12(4):476-483. Not eligible target population. [pmid: 12790860].
217 Akid M. Pay. Nurses threaten to quit bank as rates are slashed. Nurs Times. Jul 5–11. 2001;97(27):9. News.
218 Akid M. 800m pounds: the government's incentive to end NHS reliance on agency nurses. Nurs Times. Sep 6–12. 2001;97(36):12-13. Not eligible target population.
219 Akid M. The camera never lies. Nurs Times. Mar 29–Apr 4. 2001;97(13):10-11. News.
220 Albarran J, Scholes J. Blurred, blended or disappearing—the image of critical care nursing. Nurs Crit Care. Jan–Feb. 2005;10(1):1-3. Editorial. [pmid: 15739632].
221 Alberts MJ, Chaturvedi S, Graham G, Hughes RL, Jamieson DG, Krakowski F, Raps E, Scott P. Acute stroke teams: results of a national survey. National Acute Stroke Team Group. Stroke. Nov. 1998;29(11):2318-2320. Not eligible outcomes. [pmid: 9804640].
222 Alcock D, Jacobsen MJ, Sayre C. Competencies related to medication administration and monitoring. Can J Nurs Adm. Sep. 1997;10(3):54-73. Not eligible target population. [pmid: 9355285].
223 Alcock D, Lawrence J, Goodman J, Ellis J. Formative evaluation: implementation of primary nursing. Can J Nurs Res. Fall. 1993;25(3):15-28. Not eligible outcomes. [pmid: 8118766].
224 Alderman C. Nursing overseas: caring in a divided community. Nurs Stand. Apr 7–13. 1993;7(29):22-23. Comment. [pmid: 8499268].
225 Alex J, Rao VP, Cale AR, Griffin SC, Cowen ME, Guvendik L. Surgical nurse assistants in cardiac surgery: a UK trainee's perspective. Eur J Cardiothorac Surg. Jan. 2004;25(1):111-115. Not eligible target population. [pmid: 14690741].
226 Alexander C, Palladino M, Evans B, Harp K, Marable K, Whitmer K. Self-scheduling: two success stories. The art of the deal. Am J Nurs. Mar. 1993;93(3):70-74. Comment. [pmid: 8442482].
227 Alimoglu MK, Donmez L. Daylight exposure and the other predictors of burnout among nurses in a University Hospital. Int J Nurs Stud. Jul. 2005;42(5):549-555. Not eligible target population. [pmid: 15921986].
228 Allan D, Cornes D. The impact of management of change projects on practice: a description of the contribution that one educational programme made to the quality of health care. J Adv Nurs. Apr. 1998;27(4):865-869. Not eligible target population. [pmid: 9578220].
229 Allanach H. Go with the flow. Nurs Stand. Nov 10–16. 1999;14(8):23. Not eligible target population. [pmid: 11096854].
230 Allen C, Heffernan C, Pallent S, Weaver L. Uniforms: a strange custom?. Nurs Times. Sep 2–8. 1992;88(36):51. Comment. [pmid: 1528753].
231 Allen CI, Turner PS. The effect of an intervention programme on interactions on a continuing care ward for older people. J Adv Nurs. Oct. 1991;16(10):1172-1177. Not eligible target population. [pmid: 1757682].
232 Allen J, Mellor D. Work context, personal control, and burnout amongst nurses. West J Nurs Res. Dec. 2002;24(8):905-917. Not eligible target population. [pmid: 12469726].
233 Allen SK, Wilder K. Back belts pay off for nurses. Occup Health Saf. Jan. 1996;65(1):59-62. Not Eligible exposure. [pmid: 8570122].
234 Alleyne J, Thomas VJ. The management of sickle cell crisis pain as experienced by patients and their carers. J Adv Nurs. Apr. 1994;19(4):725-732. Not eligible target population. [pmid: 8021394].
235 Allgood C, O'Rourke K, VanDerslice J, Hardy MA. Job satisfaction among nursing staff in a military health care facility. Mil Med. Oct. 2000;165(10):757-761. Not eligible target population. [pmid: 11050873].
236 AllisonJones LL. Student and faculty perceptions of teaching effectiveness of full-time and part-time associate degree nursing faculty. Not relevant.
237 AllisonJones LL, Hirt JB. Comparing the teaching effectiveness of part-time & full-time clinical nurse faculty. Nursing Education Perspectives. Sep–Oct. 2004;25(5):238-43. Not relevant. [pmid: 15508563].
238 al-Ma'aitah R, Momani M. Assessment of nurses' continuing education needs in Jordan. J Contin Educ Nurs. Jul–Aug. 1999;30(4):176-181. Not eligible target population. [pmid: 10474420].
239 Almeida SL. Legislating nurse-patient ratios: A controversial approach to improving patient care?. J Emerg Nurs. Oct. 2002;28(5):377-378. Editorial. [pmid: 12386611].
240 Alspach G. Nurse staffing and patient outcomes. This is news?. Crit Care Nurse. Feb. 2003;23(1):14-15. Editorial. [pmid: 12640955].
241 Alspach G. When your work conditions are sicker than your patients. Crit Care Nurse. Jun 2005;25(3):11–12, 14. Editorial.
242 Altimier LB, Sanders JM. Cross-training in 3-D. Nurs Manage. Nov. 1999;30(11):59-62. Comment. [pmid: 10765277].
243 Altman S. Arbitrator upholds RN's refusal to work unsafe assignment. Chart. May. 1997;94(5):1-4. Legal cases. [pmid: 9573934].
244 Alward RR. Study links rotating shift work and nurses' risk of coronary heart disease. Am Nurse. Mar. 1996;28(2):12. Comment. [pmid: 8712532].
245 Alward RR, Monk TH. A comparison of rotating-shift and permanent night nurses. Int J Nurs Stud. 1990;27(3):297-302. Not eligible outcomes. [pmid: 2379988].
246 Alward RR, Monk TH. A ‘round-the-clock’ profession: coping with the effects of shift work. Nev Rnformation. Nov. 1995;4(4):18-19. Comment. [pmid: 8700300].
247 Amato M, Perton L, Sullivan B. Buttons, buttons, and more buttons: are they professional?. J Nurs Adm. Dec. 2001;31(12):559-560. Interview. [pmid: 11771458].
248 Ambrose C. Recruitment problems in intensive care: a solution. Nurs Stand. Dec 4–10. 2002;17(12):39-40. Not eligible target population. [pmid: 12518582].
249 Andersen SE. Implementing a new drug record system: a qualitative study of difficulties perceived by physicians and nurses. Qual Saf Health Care. Mar. 2002;11(1):19-24. Not eligible target population. [pmid: 12078363].
250 Anderson C. Enteral feeding: a change in practice. J Child Health Care. Winter. 2000;4(4):160-162. Not eligible target population. [pmid: 11855473].
251 Anderson DJ, Webster CS. A systems approach to the reduction of medication error on the hospital ward. J Adv Nurs. Jul. 2001;35(1):34-41. Not eligible target population. [pmid: 11442680].
252 Anderson FD, Maloney JP, Beard LW. A descriptive, correlational study of patient satisfaction, provider satisfaction, and provider workload at an army medical center. Mil Med. Feb. 1998;163(2):90-94. Not eligible target population. [pmid: 9503899].
253 Anderson FD, Maloney JP, Knight CD, Jennings BM. Utilization of supplemental agency nurses in an Army medical center. Mil Med. Jan. 1996;161(1):48-53. Not eligible target population. [pmid: 11082752].
254 Anderson LA, Schramm CA. Adapting charting by exception to the perianesthesia setting. J Perianesth Nurs. Oct. 1999;14(5):260-269. Comment. [pmid: 10827634].
255 Anderson MA, Clarke MM, Helms LB, Foreman MD. Hospital readmission from home health care before and after prospective payment. J Nurs Scholarsh. 2005;37(1):73-79. Not eligible target population. [pmid: 15813590].
256 Anderson RM. Economic and quality of care issues with implications for scopes of practice—physicians and nurses. Aspens Advis Nurse Exec. Apr 1994;9(7):suppl 1. Interview.
257 Anderson S, Eadie DR, MacKintosh AM, Haw S. Management of alcohol misuse in Scotland: the role of A&E nurses. Accid Emerg Nurs. Apr. 2001;9(2):92-100. Not eligible target population. [pmid: 11760630].
258 Anderson S, Wittwer W. Using bar-code point-of-care technology for patient safety. J Healthc Qual. Nov–Dec. 2004;26(6):5-11. Not eligible exposure. [pmid: 15603088].
259 Anderson TA, Hart GK. Data clarification. Aust Crit Care. Feb. 2002;15(1):4. author reply 4–5. Comment. [pmid: 11979991].
260 Ando S, Ono Y, Shimaoka M, Hiruta S, Hattori Y, Hori F, Takeuchi Y. Associations of self estimated workloads with musculoskeletal symptoms among hospital nurses. Occup Environ Med. Mar. 2000;57(3):211-216. Not eligible target population. [pmid: 10810105].
261 Ang R, Fong LC. Nursing leadership: the Singapore experience. Reflect Nurs Leadersh. 2003;29(1):26-28. Not eligible target population. [pmid: 12847979].
262 Angeles-Llerenas A, Alvarez del Rio A, Salazar-Martinez E, Kraus-Weissman A, Zamora-Munoz S, Hernandez-Avila M, Lazcano-Ponce E. Perceptions of nurses with regard to doctor-patient communication. Br J Nurs. Dec 11–2004 Jan 7. 2003;12(22):1312-1321. Not eligible target population. [pmid: 14688652].
263 Angus J, Hodnett E, O'Brien-Pallas L. Implementing evidence-based nursing practice: a tale of two intrapartum nursing units. Nurs Inq. Dec. 2003;10(4):218-228. Not eligible outcomes. [pmid: 14622368].
264 Anshus JS. The mentality of contraction. Am J Emerg Med. Jan. 1996;14(1):114. Letter. [pmid: 8630142].
265 Anthony MK. The relationship of authority to decision-making behavior: implications for redesign. Res Nurs Health. Oct. 1999;22(5):388-398. Not eligible exposure. [pmid: 10520191].
266 Anthony MK, Hudson-Barr D. A patient-centered model of care for hospital discharge. Clin Nurs Res. May. 2004;13(2):117-136. Not eligible exposure. [pmid: 15104855].
267 Anton D. Meet the travelers. Danielle Anton. Rn. Jan 2004;Suppl:22. Interview.
268 Aquila A. The Vascular Project: using data to improve processes and outcomes. J Vasc Nurs. Sep. 2001;19(3):80-86. Not eligible exposure. [pmid: 11533580].
269 Arafa MA, Nazel MW, Ibrahim NK, Attia A. Predictors of psychological well-being of nurses in Alexandria, Egypt. Int J Nurs Pract. Oct. 2003;9(5):313-320. Not eligible target population. [pmid: 14531854].
270 Arbesman MC, Wright C. Mechanical restraints, rehabilitation therapies, and staffing adequacy as risk factors for falls in an elderly hospitalized population. Rehabil Nurs. May–Jun. 1999;24(3):122-128. No association tested. [pmid: 10754898].
271 Archibald G. A post-modern nursing model. Nurs Stand. May 10–16. 2000;14(34):40-42. Not eligible target population. [pmid: 11974043].
272 Arford PH, Allred CA. Value = quality + cost. J Nurs Adm. Sep. 1995;25(9):64-69. No association tested. [pmid: 7674047].
273 Armstrong M. Staff mix and public safety. Nurs BC. Oct. 2004;36(4):5-6. Letter. [pmid: 15552174].
274 Armstrong-Stassen M, Cameron SJ, Horsburgh ME. Downsizing-initiated job transfer of hospital nurses: how do the job transferees fare?. J Health Hum Serv Adm. Spring. 2001;23(4):470-489. Not eligible outcomes. [pmid: 11924309].
275 Arndt M. Medication errors. Research in practice: how drug mistakes affect self-esteem. Nurs Times. Apr 13–19. 1994;90(15):27-30. Comment. [pmid: 8183705].
276 Arranz P, Ulla SM, Ramos JL, Del Rincon C, Lopez-Fando T. Evaluation of a counseling training program for nursing staff. Patient Educ Couns. Feb. 2005;56(2):233-239. Not eligible target population. [pmid: 15653254].
277 Arsenault S. Staffing is a concern in telemetry. Crit Care Nurse. Oct. 2000;20(5):14-16. Comment. [pmid: 11878483].
278 Arthur D. The validity and reliability of the measurement of the concept ‘expressed emotion’ in the family members and nurses of Hong Kong patients with schizophrenia. Int J Ment Health Nurs. Sep. 2002;11(3):192-198. Not eligible target population. [pmid: 12510597].
279 Arts SE, Francke AL, Hutten JB. Liaison nursing for stroke patients: results of a Dutch evaluation study. J Adv Nurs. Aug. 2000;32(2):292-300. Not eligible target population. [pmid: 10964175].
280 Artz M. Setting nurse-patient ratios: ANA bill calls for development of staffing systems in hospitals. Am J Nurs. May. 2005;105(5):97. News. [pmid: 15867547].
281 Arvanitopulos BL, Camino MK. You're pulling me where?. Medsurg Nurs. Dec. 1998;7(6):371-373. Comment. [pmid: 10036442].
282 Asch DA. Use of a coded postcard to maintain anonymity in a highly sensitive mail survey: cost, response rates, and bias. Epidemiology. Sep. 1996;7(5):550-551. Not eligible exposure. [pmid: 8862992].
283 Ashe N, Manzo L. Get customer sensitive. Nurs Manage. Jan. 2002;33(1):50-51. Comment. [pmid: 11984333].
284 Astelm J. Elizabeth and Alexandra's story. Child Care Health Dev. Nov. 1995;21(6):369-375. Case reports. [pmid: 8591657].
285 Atencio BL, Cohen J, Gorenberg B. Nurse retention: is it worth it? Nurs Econ. Nov–Dec 2003;21(6):262–268, 299, 259. Not eligible outcomes.
286 Atkins PM, Marshall BS, Javalgi RG. Happy employees lead to loyal patients. Survey of nurses and patients shows a strong link between employee satisfaction and patient loyalty. J Health Care Mark. Winter. 1996;16(4):14-23. Not eligible exposure. [pmid: 10169075].
287 Atkinson M. Arbitrator: hospital must tie admissions to RN staffing. Revolution. Mar–Apr. 2005;6(2):9. Comment. [pmid: 15948530].
288 Austin S. Staffing: know your liability. Nurs Manage. Jul. 2000;31(7):19. Legal cases. [pmid: 15127501].
289 Aveyard B. Education and person-centred approaches to dementia care. Nurs Older People. Feb. 2001;12(10):17-19. Not eligible target population. [pmid: 12008362].
290 Avigne J, McHugh N, Manley M, Sievers L. OR roundtable. Managers' advice on OR staffing. OR Manager. Jun 1999;15(6):15–17, 19. Interview.
291 Baarda S. Caring for staff nurses. AWHONN Lifelines. Aug–Sep. 2001;5(4):10-11. Letter. [pmid: 11982234].
292 Babus V. Tuberculosis morbidity risk in medical nurses in specialized institutions for the treatment of lung diseases in Zagreb. Int J Tuberc Lung Dis. Jun. 1997;1(3):254-258. Not eligible target population. [pmid: 9432373].
293 Badovinac CC, Wilson S, Woodhouse D. The use of unlicensed assistive personnel and selected outcome indications. Nurs Econ. Jul–Aug. 1999;17(4):194-200. Not eligible exposure. [pmid: 10711162].
294 Baggot DM, Hensinger B, Parry J, Valdes MS, Zaim S. The new hire/preceptor experience: cost-benefit analysis of one retention strategy. J Nurs Adm. Mar. 2005;35(3):138-145. Not eligible exposure. [pmid: 15761311].
295 Bailey BA. How to float safely and effectively. Nursing. Feb. 1990;20(2):113-116. No association tested. [pmid: 2300299].
296 Bailey DA, Mion LC. Improving care givers' satisfaction with information received during hospitalization. J Nurs Adm. Jan. 1997;27(1):21-27. Not eligible exposure. [pmid: 9006598].
297 Bailey F. A day in the life: a night to remember. Nurs Stand. Nov 1–6. 1995;10(6):38. Case reports. [pmid: 8546952].
298 Bailey L. Medical errors—what we can do? One informed patient's recommendations. S C Nurse. Oct–Dec. 2002;9(4):20. Comment.
299 Bailey M. Occupational HIV infection risk. Lancet. May 5. 1990;335(8697):1104-1105. Comment. [pmid: 1970408].
300 Bair B, Toth W, Johnson MA, Rosenberg C, Hurdle JF. Interventions for disruptive behaviors. Use and success. J Gerontol Nurs. Jan. 1999;25(1):13-21. Not eligible exposure. [pmid: 10205419].
301 Bair N, Bobek MB, Hoffman-Hogg L, Mion LC, Slomka J, Arroliga AC. Introduction of sedative, analgesic, and neuromuscular blocking agent guidelines in a medical intensive care unit: physician and nurse adherence. Crit Care Med. Mar. 2000;28(3):707-713. Not eligible exposure. [pmid: 10752819].
302 Baker H, Naphthine R. Nurses and medication. Part 6. Ritual+workloads = medication error. Aust Nurs J. Nov. 1994;2(5):34-36. Not eligible target population. [pmid: 7728238].
303 Baker H, Naphthine R. Nurses and medication. Part 5. Medication error: the big stick to beat you with. Aust Nurs J. Oct. 1994;2(4):28-30. Not eligible target population.
304 Baker HM. Rules outside the rules for administration of medication: a study in New South Wales, Australia. Image J Nurs Sch. 1997;29(2):155-158. Not eligible target population. [pmid: 9212512].
305 Baker K, Evans CB, Tiburzi T, Nolan MT, Frost GL, Kokoski P, Arrington DM. Costing services: comparing three i.v. medication systems. Nurs Manage. Mar. 1993;24(3):56-60. Not eligible exposure. [pmid: 8455896].
306 Balas MC, Scott LD, Rogers AE. The prevalence and nature of errors and near errors reported by hospital staff nurses. Appl Nurs Res. Nov. 2004;17(4):224-230. Not eligible outcomes. [pmid: 15573330].
307 Bale S, Tebbie N, Price P. A topical metronidazole gel used to treat malodorous wounds. Br J Nurs. Jun 10. 2004;13(11):S4-11. Not eligible target population. [pmid: 15218439].
308 Balhorn J. Patient classification used as a tool for assessment of staff/patient ratios. Edtna Erca J. Jan–Mar. 1998;24(1):13-16. Review. [pmid: 9873277].
309 Ball C, Walker G, Harper P, Sanders D, McElligott M. Moving on from ‘patient dependency’ and ‘nursing workload’ to managing risk in critical care. Intensive Crit Care Nurs. Apr. 2004;20(2):62-68. Not eligible target population. [pmid: 15072773].
310 Balling K, McCubbin M. Hospitalized children with chronic illness: parental caregiving needs and valuing parental expertise. J Pediatr Nurs. Apr. 2001;16(2):110-119. Not eligible exposure. [pmid: 11326399].
311 Ballweg DD. Implementing developmentally supportive family-centered care in the newborn intensive care unit as a quality improvement initiative. J Perinat Neonatal Nurs. Dec. 2001;15(3):58-73. Not eligible exposure. [pmid: 11785578].
312 Bamber M. Reasons for leaving among psychiatric nurses: a two-year prospective study. Nurs Pract. 1991;4(4):9-11. Not eligible exposure. [pmid: 1845385].
313 Bania K, Bergmooser G. A tool for improving supplemental staffing. Nurs Manage. May. 1997;28(5):78. Comment. [pmid: 9287804].
314 Banks N, Hardy B, Meskimen K. Take the plunge: expanding the float pool to “closed” units. Nurs Manage. Jan. 1999;30(1):51-55. Not eligible outcomes. [pmid: 9987390].
315 Barash PG, Rosenbaum SH. Staffing ICUs: the good news and the not-so-good news. Chest. Mar. 1998;113(3):569-570. Comment. [pmid: 9515825].
316 Barker P. Psychiatric caring. Nurs Times. Mar 8–14. 2001;97(10):38-39. Not eligible target population. [pmid: 11954313].
317 Barnes J. A life in the day of. Nurs Stand. Nov 24–30. 1999;14(10):26-27. Comment. [pmid: 11209325].
318 Barratt E. Investigating shift preferences. Nurs Times. May 8–14. 1991;87(19):44-45. Comment. [pmid: 2031017].
319 Barrington SF, Kettle AG, O'Doherty MJ, Wells CP, Somer EJ, Coakley AJ. Radiation dose rates from patients receiving iodine-131 therapy for carcinoma of the thyroid. Eur J Nucl Med. Feb. 1996;23(2):123-130. Not eligible target population. [pmid: 8925845].
320 Barta SK, Stacy RD. The effects of a theory-based training program on nurses' self-efficacy and behavior for smoking cessation counseling. J Contin Educ Nurs. May–Jun. 2005;36(3):117-123. Not eligible exposure. [pmid: 16022031].
321 Barton E. Workwise: a job problem shared. Nurs Stand. May 26–Jun 1. 1993;7(36):44-45. Comment. [pmid: 8512868].
322 Barton J. Nursing shifts. Is flexible rostering helpful?. Nurs Times. Feb 15–22. 1995;91(7):32-33. Not eligible target population. [pmid: 7885885].
323 Barton J, Spelten ER, Smith LR, et al. A classification of nursing and midwifery shift systems. International journal of nursing studies. Feb. 1993;30(1):65-80. Not relevant. [pmid: 8449659].
324 Barton J, Spelten E, Totterdell P, Smith L, Folkard S. Is there an optimum number of night shifts? Relationship between sleep, health and well-being. Work Stress. Apr–Sep. 1995;9(23):109-123. Not eligible target population. [pmid: 11539389].
325 Barton J, Spelten ER, Smith LR, Totterdell PA, Folkard S. A classification of nursing and midwifery shift systems. Int J Nurs Stud. Feb. 1993;30(1):65-80. Not eligible target population. [pmid: 8449659].
326 Bartram T, Joiner TA, Stanton P. Factors affecting the job stress and job satisfaction of Australian nurses: implications for recruitment and retention. Contemp Nurse. Oct. 2004;17(3):293-304. Not eligible target population. [pmid: 15551680].
327 Barzoloski-O'Connor B. Have license, will travel. Nurs Spectr (Wash D C). Jul 29. 1996;6(16):16. Comment. [pmid: 9433204].
328 Bassett D, Tsourtos G. Inpatient suicide in a general hospital psychiatric unit. A consequence of inadequate resources?. Gen Hosp Psychiatry. Sep. 1993;15(5):301-306. Not eligible target population. [pmid: 8307343].
329 Batalis NI, Prahlow JA. Accidental insulin overdose. J Forensic Sci. Sep. 2004;49(5):1117-1120. Case reports. [pmid: 15461121].
330 Bates E. Part-time working. Defective agency. Nurs Times. Feb 28–Mar 5. 1996;92(9):32-33. Comment. [pmid: 8700734].
331 Bates J. One day it could be you. Nurs Stand. Jun 2–8. 2004;18(38):24-25. Comment.
332 Bauer I. Nurses' perception of the first hour of the morning shift (6.00–7.00 a.m.) in a German hospital. J Adv Nurs. Jun. 1993;18(6):932-937. Not eligible target population. [pmid: 8320388].
333 Baulcomb JS. Management of change through force field analysis. J Nurs Manag. Jul. 2003;11(4):275-280. Not eligible target population. [pmid: 12801382].
334 Baxter B. Operating department staffing—a business manager's perspective. Br J Theatre Nurs. Oct 1997;7(7):11, 14–17. Not eligible target population.
335 Baxter B. Have I been here before?. Br J Theatre Nurs. Oct. 1998;8(7):41-42. Not eligible target population. [pmid: 10036395].
336 Beach SM, Engelsher J, Kinzeler EE. Databits. Hey, that's my grandma!. Ky Nurse. Oct–Dec. 2004;52(4):7. Comment. [pmid: 15595313].
337 Beard EL Jr. Stop floating—the next paradigm shift?. J Nurs Adm. Mar. 1994;24(3):4. Comment. [pmid: 8133324].
338 Beardsley D. Board of Nursing decision puts patients at risk. J Nurs Adm. Apr. 1999;29(4):4-5. Letter. [pmid: 10200778].
339 Beasley T, Gerbis P, Lyon J. Staffing and critical care. Nev Rnformation. Jun. 1995;4(2):7. Comment. [pmid: 7566267].
340 Beattie J, Calpin-Davies PJ. Workforce dilemmas: a comparison of staffing in a generalist and a specialist intensive care unit. Intensive Crit Care Nurs. Feb. 1999;15(1):52-57. Not eligible target population. [pmid: 10401341].
341 Bechel DL, Myers WA, Smith DG. Does patient-centered care pay off?. Jt Comm J Qual Improv. Jul. 2000;26(7):400-409. Not eligible exposure. [pmid: 10897457].
342 Beck KL, Larrabee JH. Measuring patients' perceptions of nursing care. Nurs Manage. Sep. 1996;27(9):32B-D. Not eligible exposure. [pmid: 8632867].
343 Becker A, Schulten-Oberborsch G, Beck U, Vestweber KH. Stoma care nurses: good value for money?. World J Surg. Jul. 1999;23(7):638-642. discussion 642–633. Not eligible target population. [pmid: 10390579].
344 Becker B, Woolard R, Nirenberg TD, Minugh A, Longabaugh R, Clifford PR. Alcohol use among subcritically injured emergency department patients. Acad Emerg Med. Sep. 1995;2(9):784-790. Not eligible outcomes. [pmid: 7584764].
345 Becker ER, Foster RW. Organizational determinants of nurse staffing patterns. Nurs Econ. Mar–Apr. 1988;6(2):71-75. Not eligible year. [pmid: 3352807].
346 Bednar B, McMullen N. A retrospective analysis of employee turnover in the health care setting. Nephrol News Issues. Feb. 1998;12(2):35-39. No association tested. [pmid: 9526369].
347 Bednar B, Sinitzky M, Thrall K, Wick G. Staff turnover in the dialysis unit. Interview by Diane Boudreau. Nephrol News Issues. Sep. 1995;9(9):39-40. No association tested. [pmid: 7501037].
348 Beeman J, Diehl B. A credentialing program for nursing staff caring for pediatric patients with an ilizarov apparatus. Rehabil Nurs. Sep–Oct. 1995;20(5):278-282. Not eligible exposure. [pmid: 7569307].
349 Beer HL, Duvvi S, Webb CJ, Tandon S. Blood loss estimation in epistaxis scenarios. J Laryngol Otol. Jan. 2005;119(1):16-18. Not eligible exposure. [pmid: 15807956].
350 Begley CM. ‘Knowing your place’: student midwives' views of relationships in midwifery in Ireland. Midwifery. Sep. 2001;17(3):222-233. Not eligible target population. [pmid: 11502142].
351 Begley CM. ‘Great fleas have little fleas’: Irish student midwives' views of the hierarchy in midwifery. J Adv Nurs. May. 2002;38(3):310-317. Not eligible target population. [pmid: 11972672].
352 Behrman AJ, Shofer FS, Green-McKenzie J. Trends in bloodborne pathogen exposure and follow-up at an urban teaching hospital: 1987 to 1997. J Occup Environ Med. Apr. 2001;43(4):370-376. Not eligible exposure. [pmid: 11322098].
353 Beitz JM, Fey J, O'Brien D. Perceived need for education vs. actual knowledge of pressure ulcer care in a hospital nursing staff. Medsurg Nurs. Oct. 1998;7(5):293-301. Not eligible exposure. [pmid: 10036431].
354 Belcher JV, Munjas B. Psychiatric-mental health head nurse management concerns. Arch Psychiatr Nurs. Aug. 1990;4(4):260-263. No association tested. [pmid: 2241245].
355 Bell M, Warner JA, Cameron AE. Patient flow patterns in a recovery room and implications for staffing. J R Soc Med. Jan. 1985;78(1):35-38. Not eligible year. [pmid: 3968669].
356 Beltzhoover M. Self-scheduling: an innovative approach. Nurs Manage. Apr. 1994;25(4):81-82. No association tested. [pmid: 8159352].
357 Ben-Ami S, Shaham J, Rabin S, Melzer A, Ribak J. The influence of nurses' knowledge, attitudes, and health beliefs on their safe behavior with cytotoxic drugs in Israel. Cancer Nurs. Jun. 2001;24(3):192-200. Not eligible target population. [pmid: 11409063].
358 Benjamin I. Staff allocation and rostering in a Queensland public hospital. Qld Nurse. Nov–Dec. 1990;9(6):10-11. No association tested. [pmid: 2092343].
359 Benko LB. Oregon passes nurses bill. Hospitals and nurses at odds over potential effect on staffing. Mod Healthc. Jun 18. 2001;31(25):52. News.
360 Benko LB. Workforce report 2003. Ratio daze in California. State staffing law may exacerbate nursing shortfall. Mod Healthc. Jun 16. 2003;33(24):30-31. Comment.
361 Bennett DS. The blind men and the elephant. A fable for health care safety. Crit Care Nurs Clin North Am. Dec 2002;14(4):xiii–xvi. Comment.
362 Bennett DS, Dune L. Everyday thoughts: harnessing the thought process toward a practical framework for increasing critical thinking and reducing error. Crit Care Nurs Clin North Am. Dec 2002;14(4):385–390, viii–ix. Review.
363 Benson RM. A non-specialist's guide to the CCU. Rn. Jan. 1991;54(1):50-53. Comment. [pmid: 1989058].
364 Berden HJ, Willems FF, Hendrick JM, Pijls NH, Knape JT. How frequently should basic cardiopulmonary resuscitation training be repeated to maintain adequate skills?. Bmj. Jun 12. 1993;306(6892):1576-1577. Not eligible target population. [pmid: 8329917]. [pmcid: 1677995].
365 Bergbom I, Svensson C, Berggren E, Kamsula M. Patients' and relatives' opinions and feelings about diaries kept by nurses in an intensive care unit: pilot study. Intensive Crit Care Nurs. Aug. 1999;15(4):185-191. Not eligible target population. [pmid: 10786503].
366 Berger MC, Seversen A, Chvatal R. Ethical issues in nursing. West J Nurs Res. Aug. 1991;13(4):514-521. Not eligible outcomes. [pmid: 1843182].
367 Berglin P. Leadership through shared governance. Colo Nurse. Mar. 1995;95(1):19-20. Comment. [pmid: 7493387].
368 Berland A. Controlling workload. Can Nurse. May. 1990;86(5):36-38. No association tested. [pmid: 2340482].
369 Berliner H. US healthcare. United straits. Health Serv J. Jun 27. 2002;112(5811):32. Comment. [pmid: 12125513].
370 Berman S. Health care: mandatory nurse-to-patient staffing ratios in California. J Law Med Ethics. Summer. 2002;30(2):312-313. Review. [pmid: 12066611].
371 Berrios CD, Jacobowitz WH. Therapeutic holding: outcomes of a pilot study. J Psychosoc Nurs Ment Health Serv. Aug. 1998;36(8):14-18. Not eligible exposure. [pmid: 9726081].
372 Berry D, Drury J, Prendeville B, Ranganathan P, Sumner J. Sexual abuse: giving support to nurses. Nurs Stand. Oct 13–19. 1993;8(4):25-27. Not eligible target population. [pmid: 8217708].
373 Berry DM. An inpatient classification system for nursing service staffing decisions. Commun Nurs Res. Mar. 1977;8:90-100. Not eligible year. [pmid: 585618].
374 Bertolini G, Rossi C, Brazzi L, Radrizzani D, Rossi G, Arrighi E, Simini B. The relationship between labour cost per patient and the size of intensive care units: a multicentre prospective study. Intensive Care Med. Dec. 2003;29(12):2307-2311. Not eligible target population. [pmid: 14600807].
375 Bertram DA, Thompson MC, Giordano D, Perla J, Rosenthal TC. Implementation of an inpatient case management program in rural hospitals. J Rural Health. Winter. 1996;12(1):54-66. Not eligible exposure. [pmid: 10157083].
376 Bethel S, Ridder J. Evaluating nursing practice: satisfaction at what cost? Nurs Manage. Sep 1994;25(9):41–43, 46–48. Not eligible outcomes.
377 Bevan J, Linton A. Continuous quality improvement: maintaining quality of care with changing staffing patterns. J Cannt. Spring. 1998;8(2):33-35. No association tested. [pmid: 9807331].
378 Beyea SC. Too tired to work safely?. Aorn J. Sep. 2004;80(3):559-562. Not eligible exposure. [pmid: 15497544].
379 Beyers M. Ask AONE's experts ... about staffing options. Nurs Manage. Jul. 1998;29(7):72. Comment.
380 Beyers M. Ask AONE's experts ... about patient-focused care. Nurs Manage. Aug. 1998;29(8):88. Comment.
381 Beyers M. Ask AONE's experts ... about how to reduce overtime and use of per diem staff. Nurs Manage. Dec. 1999;30(12):56. Comment.
382 Beyers M. Ask AONE's experts ... about counting short-stay census. Nurs Manage. May. 1999;30(5):72. Comment.
383 Bhatia R, Blackshaw G, Rogers A, Grant A, Kulkarni R. Developing a departmental culture for reporting adverse incidents. Int J Health Care Qual Assur Inc Leadersh Health Serv. 2003;16(23):154-156. Not eligible target population. [pmid: 12870255].
384 Bhengu BR. Exploring the critical care nurses' experiences regarding moonlighting. Curationis. May. 2001;24(2):48-53. Not eligible target population. [pmid: 11885476].
385 Biddle J. 9 tips for success. Nursing. Nov. 2002;32(11 Pt 1):80. Comment. [pmid: 12518753].
386 Bilchik GS. Norma Rae, R.N. Hosp Health Netw. Nov. 2000;74(11):40-44. Comment. [pmid: 11192673].
387 Biller AM. Implementing nursing case management. Rehabil Nurs. May–Jun. 1992;17(3):144-146. No association tested. [pmid: 1585045].
388 Billinghurst F, Morgan B, Arthur HM. Patient and nurse-related implications of remote cardiac telemetry. Clin Nurs Res. Nov. 2003;12(4):356-370. Not eligible exposure. [pmid: 14620692].
389 Binder RL, McNiel DE. Staff gender and risk of assault on doctors and nurses. Bull Am Acad Psychiatry Law. 1994;22(4):545-550. Not eligible exposure. [pmid: 7718927].
390 Bingham R. Leaving nursing. Health Aff (Millwood). Jan–Feb. 2002;21(1):211-217. Comment. [pmid: 11900079].
391 Binnekade JM, Vroom MB, de Mol BA, de Haan RJ. The quality of Intensive Care nursing before, during, and after the introduction of nurses without ICU-training. Heart Lung. May–Jun. 2003;32(3):190-196. Not eligible target population. [pmid: 12827104].
392 Binnie A. Freedom to practise: patient-centred nursing. Nurs Times. Jan 27–Feb 2. 2000;96(4):39-40. Comment. [pmid: 11188649].
393 Birnbaum D. Full-time equivalent (FTE) numbers. Infect Control Hosp Epidemiol. Mar. 2002;23(3):116-117. Comment. [pmid: 11918113].
394 Bischof J. Self-scheduling in critical care. Crit Care Nurse. Jan. 1992;12(1):50-55. No association tested. [pmid: 1732083].
395 Bishop S, Panjari M, Astbury J, Bell R. “A survey of antenatal clinic staff: some perceived barriers to the promotion of smoking cessation in pregnancy”. Aust Coll Midwives Inc J. Sep. 1998;11(3):14-18. Not eligible target population. [pmid: 10531816].
396 Bissonnette T. What was said, what we heard. Mich Nurse. Jun–Jul. 2005;78(5):10. Comment. [pmid: 16100999].
397 Bjork IT. Practical skill development in new nurses. Nurs Inq. Mar. 1999;6(1):34-47. Not eligible target population. [pmid: 10647399].
398 Bjork IT, Kirkevold M. Issues in nurses' practical skill development in the clinical setting. J Nurs Care Qual. Oct. 1999;14(1):72-84. Not eligible target population. [pmid: 10575833].
399 Black K. Specialized teams complement nursing. Patient satisfaction begins with satisfied professional and support teams. Healthc Exec. Mar–Apr. 2004;19(2):50-51. Comment. [pmid: 15017838].
400 Blain S. Attitudes to women undergoing TOP. Nurs Stand. Jun 2–8. 1993;7(37):30-33. Not eligible exposure. [pmid: 8338733].
401 Blair PD. Continuous assessment and regular communication foster patient safety. Nurs Manage. Aug 2003;34(8):22–23, 60. Comment.
402 Blanchfield KC, Biordi DL. Power in practice: a study of nursing authority and autonomy. Nursing administration quarterly. Spring. 1996;20(3):42-9. Not relevant. [pmid: 8710222].
403 Bland P. New grads face changing employment picture — a synopsis of a 1996 survey. Nurse to Nurse. Jan–Feb. 1997;8(1):14-5. Not peer reviewed.
404 Blank AE, Horowitz S, Matza D. Quality with a human face? The Samuels Planetree model hospital unit. Jt Comm J Qual Improv. Jun. 1995;21(6):289-299. Not eligible exposure. [pmid: 7550786].
405 Blegen MA, Vaughn T, Pepper G, Vojir C, Stratton K, Boyd M, Armstrong G. Patient and staff safety: voluntary reporting. Am J Med Qual. Mar–Apr. 2004;19(2):67-74. Not eligible exposure. [pmid: 15115277].
406 Blewitt DK, Jones KR. Using elements of the nursing minimum data set for determining outcomes. J Nurs Adm. Jun. 1996;26(6):48-56. Not eligible exposure. [pmid: 8648420].
407 Bliss-Holtz J. Discriminating types of medication calculation errors in nursing practice. Nurs Res. Nov–Dec. 1994;43(6):373-375. Not eligible outcomes. [pmid: 7971303].
408 Bloice C. Slash and burn redux. Hunter Group still bottom-line feeding. Revolution. May–Jun. 2002;3(3):6-7. News. [pmid: 12481364].
409 Bloodworth C, Lea A, Lane S, Ginn R. Challenging the myth of the 12-hour shift: a pilot evaluation. Nurs Stand. Apr 4–10. 2001;15(29):33-36. Not eligible target population. [pmid: 12216286].
410 Blumenfield M, Milazzo J, Wormser GP, Smith PJ. Reluctance to care for patients with AIDS. Gen Hosp Psychiatry. Nov. 1991;13(6):410. Letter. [pmid: 1765258].
411 Blythe J, Baumann A, Zeytinoglu I, Denton M, Higgins A. Full-time or part-time work in nursing: preferences, tradeoffs and choices. Healthc Q. 2005;8(3):69–77, 64. Not eligible outcomes.
412 Boehm C. PASNAP targets mandatory overtime. Revolution. May–Jun. 2005;6(3):11. Comment. [pmid: 16092475].
413 Boettger JE. Effects of a pressure-reduction mattress and staff education on the incidence of nosocomial pressure ulcers. J Wound Ostomy Continence Nurs. Jan. 1997;24(1):19-25. Not eligible exposure. [pmid: 9204847].
414 Bohnen MV, Balantac DD. Basic academic preparation of foreign-educated nurses: a base for developing continuing education courses. Journal of continuing education in nursing. Nov–Dec. 1994;25(6):258-62. Not relevant. [pmid: 7868743].
415 Boling J, Hoffmann L. The nursing shortage and its implications for case management. Case Manager. Nov–Dec. 2001;12(6):53-57. No association tested. [pmid: 11704735].
416 Bolton SC. Who cares? Offering emotion work as a ‘gift’ in the nursing labour process. J Adv Nurs. Sep. 2000;32(3):580-586. Not eligible exposure. [pmid: 11012799].
417 Bonadio WA, Carney M, Gustafson D. Efficacy of nurses suturing pediatric dermal lacerations in an emergency department. Ann Emerg Med. Dec. 1994;24(6):1144-1146. Not eligible exposure. [pmid: 7978597].
418 Bond CA, Raehl CL, Franke T. Medication errors in United States hospitals. Pharmacotherapy. Sep. 2001;21(9):1023-1036. Not eligible outcomes. [pmid: 11560192].
419 Bond CA, Raehl CL, Franke T. Interrelationships among mortality rates, drug costs, total cost of care, and length of stay in United States hospitals: summary and recommendations for clinical pharmacy services and staffing. Pharmacotherapy. Feb. 2001;21(2):129-141. Not eligible exposure. [pmid: 11213848].
420 Bond CA, Raehl CL, Franke T. Clinical pharmacy services, hospital pharmacy staffing, and medication errors in United States hospitals. Pharmacotherapy. Feb. 2002;22(2):134-147. Not eligible exposure. [pmid: 11837551].
421 Bond CA, Raehl CL, Pitterle ME. Staffing and the cost of clinical and hospital pharmacy services in United States hospitals. Pharmacotherapy. Jun. 1999;19(6):767-781. Not eligible exposure. [pmid: 10391424].
422 Bond GE, Fiedler FE. A comparison of leadership vs. renovation in changing staff values. Nurs Econ. Jan–Feb. 1999;17(1):37-43. Not eligible exposure. [pmid: 10335220].
423 Bondas TE. Caritative leadership. Ministering to the patients. Nurs Adm Q. Jul–Sep. 2003;27(3):249-253. Review. [pmid: 13677190].
424 Bonner R, Beaumont R, Smith B. Understanding rostering. Part 6. Changing rosters—managing roster change. Aust Nurs J. Aug. 1995;3(2):36-38. Not eligible target population. [pmid: 7550993].
425 Bonner R, Beaumont R, Smith B. Understanding rostering. Part 4. Products & consequences. Aust Nurs J. Jun. 1995;2(11):36-38. Not eligible target population. [pmid: 7663717].
426 Bonner R, Beaumont R, Smith B. Understanding rostering. Part 3. How a roster is developed. Aust Nurs J. May. 1995;2(10):40-42. Not eligible target population. [pmid: 7655634].
427 Bonner R, Beaumont R, Smith B. Understanding rostering. Part 1. The rights & wrongs of rostering. Aust Nurs J. Mar. 1995;2(8):18-20. Not eligible target population. [pmid: 7773371].
428 Booker JM, Roseman C. A seasonal pattern of hospital medication errors in Alaska. Psychiatry Res. Aug 28. 1995;57(3):251-257. Not eligible exposure. [pmid: 7501735].
429 Boomer MJ, Rissel C. An evaluation of a smoke free environment policy in two Sydney hospitals. Aust Health Rev. 2002;25(3):179-184. Not eligible target population. [pmid: 12136560].
430 Boosfeld B. Conflict in decision making: do nurses have a role?. Paediatr Nurs. Sep. 1995;7(7):21-23. Comment. [pmid: 7552430].
431 Booth B. Management of drug errors. Nurs Times. Apr 13–19. 1994;90(15):30-31. Comment.
432 Borg E. Professional liability during the shortage. Can Nurse. Sep. 2001;97(8):34-35. Comment. [pmid: 11868411].
433 Borg MA. Bed occupancy and overcrowding as determinant factors in the incidence of MRSA infections within general ward settings. J Hosp Infect. Aug. 2003;54(4):316-318. Not eligible target population. [pmid: 12919764].
434 Borromeo AR, Windle PE, Eagen MK. The professional salary model: meeting the bottom lines. Nurs Econ. Jul–Aug. 1996;14(4):241-244. No association tested. [pmid: 8826313].
435 Boscarino JA. Patients' perception of quality hospital care and hospital occupancy: are there biases associated with assessing quality care based on patients' perceptions?. Int J Qual Health Care. Oct. 1996;8(5):467-477. Not eligible outcomes. [pmid: 9117200].
436 Bosek MS. Mandatory overtime: professional duty, harms, and justice. JONAS Healthc Law Ethics Regul. Dec. 2001;3(4):99-102. Comment. [pmid: 11887783].
437 Bosman RJ, Rood E, Oudemans-van Straaten HM, Van der Spoel JI, Wester JP, Zandstra DF. Intensive care information system reduces documentation time of the nurses after cardiothoracic surgery. Intensive Care Med. Jan. 2003;29(1):83-90. Not eligible target population. [pmid: 12528027].
438 Bostrom J, Tisnado J, Zimmerman J, Lazar N. The impact of continuity of nursing care personnel on patient satisfaction. J Nurs Adm. Oct. 1994;24(10):64-68. Not eligible exposure. [pmid: 7931690].
439 Bostrom J, Zimmerman J. Restructuring nursing for a competitive health care environment. Nurs Econ. Jan–Feb 1993;11(1):35–41, 54. Not eligible outcomes.
440 Bostrom JM. Impact of physician practice on nursing care. Nurs Econ. Sep–Oct 1994;12(5):250–255, 286. Not eligible exposure.
441 Boudreaux ED, Ary R, Mandry C. Emergency department personnel accuracy at estimating patient satisfaction. J Emerg Med. Aug. 2000;19(2):107-112. Not eligible exposure. [pmid: 10903455].
442 Boumans NP, Landeweerd JA, Visser M. Differentiated practice, patient-oriented care and quality of work in a hospital in the Netherlands. Scand J Caring Sci. Mar. 2004;18(1):37-48. Not eligible target population. [pmid: 15005662].
443 Bourbonnais R, Comeau M, Vezina M. Job strain and evolution of mental health among nurses. J Occup Health Psychol. Apr. 1999;4(2):95-107. Not eligible outcomes. [pmid: 10212863].
444 Bourbonnais R, Vinet A, Vezina M, Gingras S. Certified sick leave as a non-specific morbidity indicator: a case-referent study among nurses. Br J Ind Med. Oct. 1992;49(10):673-678. Not eligible outcomes. [pmid: 1419853].
445 Bourgault AM, Smith S. The development of multi-level critical care competency statements for self-assessment by ICU nurses. Dynamics. Winter. 2004;15(4):15-18. Not eligible exposure. [pmid: 15638353].
446 Bouza E, Munoz P, Lopez-Rodriguez J, Jesus Perez M, Rincon C, Martin Rabadan P, Sanchez C, Bastida E. A needleless closed system device (CLAVE) protects from intravascular catheter tip and hub colonization: a prospective randomized study. J Hosp Infect. Aug. 2003;54(4):279-287. Not eligible exposure. [pmid: 12919758].
447 Bowden FJ, Pollett B, Birrell F, Dax EM. Occupational exposure to the human immunodeficiency virus and other blood-borne pathogens. A six-year prospective study. Med J Aust. Jun 21. 1993;158(12):810-812. Not eligible exposure. [pmid: 8326890].
448 Bowles C, Candela L. First job experiences of recent RN graduates: improving the work environment. J Nurs Adm. Mar. 2005;35(3):130-137. Not eligible outcomes. [pmid: 15761310].
449 Bowles KH. Application of the Omaha System in acute care. Res Nurs Health. Apr. 2000;23(2):93-105. Not eligible exposure. [pmid: 10782868].
450 Boyd G. Terminated. Radiol Manage. Jan–Feb. 2004;26(1):54. Review.
451 Boykin A, Schoenhofer SO, Smith N, St Jean J, Aleman D. Transforming practice using a caring-based nursing model. Nurs Adm Q. Jul–Sep. 2003;27(3):223-230. Not eligible exposure. [pmid: 13677187].
452 Boynton D, Rothman L. Stage managing change: supporting new patient care models. Nurs Econ. May–Jun. 1995;13(3):166-173. No association tested. [pmid: 7783790].
453 Braddy PK, Washburn TA, Carroll LL. Factors influencing nurses to work for agencies. Western journal of nursing research. Jun. 1991;13(3):353-62. Not relevant. [pmid: 2068809].
454 Bradley CF, Kozak C. Nursing care and management of the elderly hip fractured patient. J Gerontol Nurs. Aug. 1995;21(8):15-22. Not eligible exposure. [pmid: 7650300].
455 Bradley D. Ask the experts. Crit Care Nurse. Apr. 1998;18(2):98-99. Comment. [pmid: 9708126].
456 Bradley EH, Cherlin E, McCorkle R, Fried TR, Kasl SV, Cicchetti DV, Johnson-Hurzeler R, Horwitz SM. Nurses' use of palliative care practices in the acute care setting. J Prof Nurs. Jan–Feb. 2001;17(1):14-22. Not eligible outcomes. [pmid: 11211378].
457 Bradley G. Drug errors. Just one slip. Interview by Daloni Carlisle. Nurs Times. Apr 3–9. 1991;87(14):30-31. Interview. [pmid: 2011556].
458 Bradley S. Suffer the little children. The influence of nurses and parents in the evolution of open visiting in children's wards 1940-1970. Int Hist Nurs J. 2001;6(2):44-51. Not eligible target population. [pmid: 12143442].
459 Brady J. The nursing life. Stolen bases. Am J Nurs. Apr. 1994;94(4):51. Comment. [pmid: 8147411].
460 Bratt MM, Broome M, Kelber S, Lostocco L. Influence of stress and nursing leadership on job satisfaction of pediatric intensive care unit nurses. Am J Crit Care. Sep. 2000;9(5):307-317. Not eligible exposure. [pmid: 10976354].
461 Braun BI, Kritchevsky SB, Wong ES, Solomon SL, Steele L, Richards CL, Simmons BP. Preventing central venous catheter-associated primary bloodstream infections: characteristics of practices among hospitals participating in the Evaluation of Processes and Indicators in Infection Control (EPIC) study. Infect Control Hosp Epidemiol. Dec. 2003;24(12):926-935. No association tested. [pmid: 14700408].
462 Bremnes RM. Experience with and attitudes to chemotherapy among newly employed nurses in oncological and surgical departments: a longitudinal study. Support Care Cancer. Jan. 1999;7(1):11-16. Not eligible target population. [pmid: 9926968].
463 Brennan W, Scully W, Tarbuck P, Young C. Nurses' attire in a special hospital: perceptions of patients and staff. Nurs Stand. Apr 26–May 2. 1995;9(31):35-38. Not eligible exposure. [pmid: 7786726].
464 Breslawski S, Hamilton D. Operating room scheduling. Choosing the best system. Aorn J. May. 1991;53(5):1229-1237. Not eligible outcomes. [pmid: 2059021].
465 Brewer CS, Nauenberg E. Future intentions of registered nurses employed in the western New York labor market: relationships among demographic, economic, and attitudinal factors. Applied Nursing Research. Aug. 2003;16(3):144-55. Not relevant. [pmid: 12931328].
466 Brewer CS, Zayas LE, Kahn LS, et al. Nursing recruitment and retention in New York State: a qualitative workforce needs assessment. Policy, Politics, & Nursing Practice. Feb. 2006;7(1):54-63. Not relevant.
467 Brezynskie H, Pendon E, Lindsay P, Adam M. Identification of the perceived learning needs of balloon angioplasty patients. Can J Cardiovasc Nurs. 1998;9(2):8-14. Not eligible exposure. [pmid: 9801514].
468 Bridgeman J. How do nurses learn about family-centred care?. Paediatr Nurs. May. 1999;11(4):26-29. Not eligible target population. [pmid: 10542604].
469 Bridger JC. A study of nurses' views about the prevention of nosocomial urinary tract infections. Journal of clinical nursing. Sep. 1997;6(5):379-87. Not relevant. [pmid: 9355472].
470 Briggs B. Pumped up about i.v. system. Health Data Manag. Feb 2004;12(2):106–108, 110. Comment.
471 Brillhart B, Sills F. Analysis of the roles and responsibilities of rehabilitation nursing staff. Rehabilitation Nursing May–Jun 1994;19(3):145–50, 90. Not relevant.
472 Brillman JC, Doezema D, Tandberg D, Sklar DP, Davis KD, Simms S, Skipper BJ. Triage: limitations in predicting need for emergent care and hospital admission. Ann Emerg Med. Apr. 1996;27(4):493-500. Not eligible exposure. [pmid: 8604869].
473 Brockopp DY, Franey BN, Sage-Smith D, Romond EH, Cannon CC. Patients' knowledge of their caregivers' names. A teaching-hospital study. Hosp Top. Winter. 1992;70(1):25-28. Not eligible exposure. [pmid: 10118574].
474 Brockopp DY, Porter M, Kinnaird S, Silberman S. Fiscal and clinical evaluation of patient care. A case management model for the future. J Nurs Adm. Sep. 1992;22(9):23-27. Not eligible exposure. [pmid: 1432238].
475 Brodell E. Nursing career satisfaction: the effects of autonomy, social integration and flexible scheduling. Prairie Rose. Sep–Nov. 1996;65(3):4-6. No association tested. [pmid: 9006266].
476 Broekmans S, Vanderschueren S, Morlion B, Kumar A, Evers G. Nurses' attitudes toward pain treatment with opioids: a survey in a Belgian university hospital. Int J Nurs Stud. Feb. 2004;41(2):183-189. Not eligible target population. [pmid: 14725782].
477 Brogan G. Off and running!. Revolution. Jan–Feb. 2004;5(1):18-21. Not eligible target population. [pmid: 15052955].
478 Brokalaki H, Matziou V, Zyga S, Kapella M, Tsaras K, Brokalaki E, Myrianthefs P. Omissions and errors during oxygen therapy of hospitalized patients in a large city of Greece. Intensive Crit Care Nurs. Dec. 2004;20(6):352-357. Not eligible target population. [pmid: 15567676].
479 Bronder E. A decision that defies logic. Am J Nurs. Apr. 2001;101(4):57-58. Comment. [pmid: 11301686].
480 Brooks I. The lights are bright? Debating the future of the permanent night shift. J Manag Med. 1997;11(23):58-70. Not eligible target population. [pmid: 10173248].
481 Broomfield D, Humphris GM, Fisher SE, Vaughan D, Brown JS, Lane S. The orofacial cancer patient's support from the general practitioner, hospital teams, family, and friends. J Cancer Educ. Winter. 1997;12(4):229-232. Not eligible target population. [pmid: 9440015].
482 Brotherton JM, Bartlett MJ, Muscatello DJ, Campbell-Lloyd S, Stewart K, McAnulty JM. Do we practice what we preach? Health care worker screening and vaccination. Am J Infect Control. May. 2003;31(3):144-150. Not eligible target population. [pmid: 12734519].
483 Brous E. How to handle that staffing predicament. Rn. May. 2002;65(5):67-70. Comment. [pmid: 12046183].
484 Brown B. How to develop a unit personnel budget. Nurs Manage. Jun. 1999;30(6):34-35. No association tested. [pmid: 10562059].
485 Brown B. Formula for an effective acuity system. Nurs Manage. Jun. 1999;30(6):14. Comment. [pmid: 10562057].
486 Brown C, Arnetz B, Petersson O. Downsizing within a hospital: cutting care or just costs?. Soc Sci Med. Nov. 2003;57(9):1539-1546. Not eligible target population. [pmid: 12948565].
487 Brown G. Nursing is critically ill: why? What can be done to help alleviate the nursing shortage. Minor Nurse Newsl. Winter. 2003;10(1):2. Comment.
488 Brown H. Media frenzy follows diary publication. Nurs N Z. Aug. 1996;2(7):7. News. [pmid: 8945283].
489 Brown H. Nightmare on night shift. Nurs N Z. Jul. 1996;2(6):20. Comment. [pmid: 9006195].
490 Brown PW, Fay MS. Sentinel event review, Part II: A new spirit of inquiry. Aspens Advis Nurse Exec. Oct 1997;13(1):1, 5–6. Comment.
491 Browne R, Miller E. Leading your leader. Nurs Manage. Oct. 2003;34(10):58-62. Not eligible exposure. [pmid: 14557785].
492 Brownson K, Dowd SB. Floating: a nurse's nightmare?. Health Care Superv. Mar. 1997;15(3):10-15. No association tested. [pmid: 10165424].
493 Bruce J, Wong I. Parenteral drug administration errors by nursing staff on an acute medical admissions ward during day duty. Drug Saf. 2001;24(11):855-862. Not eligible target population. [pmid: 11665872].
494 Bruera E, Willey JS, Ewert-Flannagan PA, Cline MK, Kaur G, Shen L, Zhang T, Palmer JL. Pain intensity assessment by bedside nurses and palliative care consultants: a retrospective study. Support Care Cancer. Apr. 2005;13(4):228-231. Not eligible exposure. [pmid: 15480817].
495 Brumfield VC, Kee CC, Johnson JY. Preoperative patient teaching in ambulatory surgery settings. Aorn J. Dec 1996;64(6):941–946, 948, 951–942. Not eligible exposure.
496 Bruner DW. Radiation oncology nurses: staffing patterns and role development. Oncol Nurs Forum. May. 1993;20(4):651-655. Review. [pmid: 8321706].
497 Brunt BA. Continuing education evaluation of behavior change. J Nurses Staff Dev. Mar–Apr. 2000;16(2):49-54. Not eligible outcomes. [pmid: 11912691].
498 Brusco MJ, Futch J, Showalter MJ. Nurse staff planning under conditions of a nursing shortage. J Nurs Adm. Jul–Aug. 1993;23(78):58-64. No association tested. [pmid: 8360768].
499 Bryan YE, Hitchings KS, Fuss MA, Fox MA, Kinneman MT, Young MJ. Measuring and evaluating hospital restructuring efforts. Eighteen-month follow-up and extension to critical care, Part 1. J Nurs Adm. Sep. 1998;28(9):21-27. Not eligible exposure. [pmid: 9745658].
500 Bryant C. Role clarification: a quality improvement survey of hospital chaplain customers. J Healthc Qual. Jul–Aug. 1993;15(4):18-20. Not eligible exposure. [pmid: 10127220].
501 Bryant CJ, Crean SJ, Hopper C. Maxillofacial surgery and the role of the extended day case. Br Dent J. Feb 22. 1997;182(4):134-138. Not eligible target population. [pmid: 9061999].
502 Bryden DC, Gwinnutt CL. Tracheal intubation via the laryngeal mask airway: a viable alternative to direct laryngoscopy for nursing staff during cardiopulmonary resuscitation. Resuscitation. Jan. 1998;36(1):19-22. Not eligible exposure. [pmid: 9547839].
503 Buchan J. Shifting patterns of nurses' work. Nurs Stand. Jun 16–22. 1993;7(39):29. Comment.
504 Buchan J. Lessons from America? US magnet hospitals and their implications for UK nursing. J Adv Nurs. Feb. 1994;19(2):373-384. Review. [pmid: 8188971].
505 Buchan J. Shifting the patterns of nurses' work. Nurs Stand. Aug 2–8. 1995;9(45):29. Comment.
506 Buchan J. The shape of time to come. Nurs Stand. Mar 22–28. 1995;9(26):22-23. Not eligible target population.
507 Buchan J. Working on the bank: why do nurses do it?. Nurs Stand. Mar 15–21. 1995;9(25):33. Not eligible target population.
508 Buchan J. The quality of mercy. Nurs Stand. Jun 11. 1997;11(38):22-23. Not eligible target population. [pmid: 9216337].
509 Buchan J. The cost of understaffing. Nurs Stand. May 21. 1997;11(35):27. Comment. [pmid: 9239010].
510 Buchan J. Workforce planning. Your country needs you. Health Serv J. Jul 16. 1998;108(5613):22-25. Not eligible target population. [pmid: 10182616].
511 Buchan J. Still attractive after all these years? Magnet hospitals in a changing health care environment. J Adv Nurs. Jul. 1999;30(1):100-108. Review. [pmid: 10403986].
512 Buchan J. Rethink the weighting game. Nurs Stand. Aug 2–8. 2000;14(46):23. Comment. [pmid: 11974122].
513 Buchan J. Recruitment. Happy landings?. Health Serv J. Aug 24. 2000;110(5719):24-27. Not eligible target population. [pmid: 11184523].
514 Buchman TG, Ray SE, Wax ML, Cassell J, Rich D, Niemczycki MA. Families' perceptions of surgical intensive care. J Am Coll Surg. Jun. 2003;196(6):977-983. Review. [pmid: 12788436].
515 Bucknall TK. Critical care nurses' decision-making activities in the natural clinical setting. Journal of clinical nursing. Jan. 2000;9(1):25-36. Not relevant. [pmid: 11022489].
516 Buerhaus PI, Donelan K, Ulrich BT, Norman L, Dittus R. Is the shortage of hospital registered nurses getting better or worse? Findings from two recent national surveys of RNs. Nurs Econ. Mar–Apr 2005;23(2):61–71, 96, 55. Not eligible outcomes.
517 Buerhaus PI, Staiger DO, Auerbach DI. New signs of a strengthening U.S. nurse labor market? Health affairs Jul–Dec 2004;23(Supplement 2):W4-526–33. Not relevant.
518 Buerhaus PI, Staiger DO, Auerbach DI. Implications of an Aging Registered Nurse Workforce. JAMA. June 14, 2000. 2000;283(22):2948-2954. Not eligible outcomes. [pmid: 10865272].
519 Buerhaus PI, Staiger DO, Auerbach DI. Is the current shortage of hospital nurses ending?. Health Aff (Millwood). Nov–Dec. 2003;22(6):191-198. Not eligible exposure. [pmid: 14649446].
520 Buff DD, Shabti R. The night float system of resident on call: what do the nurses think?. J Gen Intern Med. Jul. 1995;10(7):400-402. Not eligible exposure. [pmid: 7472690].
521 Bull MJ. Patients' and professionals' perceptions of quality in discharge planning. J Nurs Care Qual. Jan. 1994;8(2):47-61. Not eligible exposure. [pmid: 8312594].
522 Bupp JE, Dinger M, Lawrence C, Wingate S. Placement of cardiac electrodes: written, simulated, and actual accuracy. Am J Crit Care. Nov. 1997;6(6):457-462. Not eligible exposure. [pmid: 9354224].
523 Burden B. Privacy or help? The use of curtain positioning strategies within the maternity ward environment as a means of achieving and maintaining privacy, or as a form of signalling to peers and professionals in an attempt to seek information or support. J Adv Nurs. Jan. 1998;27(1):15-23. Not eligible target population. [pmid: 9515603].
524 Burek C, Collins NA, Hodlin A. An easy way to communicate pathways to patients. Hosp Food Nutr Focus. Jun. 1996;12(10):4. suppl 1 p. Comment. [pmid: 10157815].
525 Burge J. Meet the travelers. Janis Burge. Rn. Jan 2004;Suppl:12. Interview.
526 Burgess L. Mixed-sex wards—the NT survey results. Nurs Times. Aug 3–9. 1994;90(31):35-38. Not eligible exposure. [pmid: 8065976].
527 Burgess L. Mixed-sex wards. Mixed responses. Nurs Times. Jan 12–18. 1994;90(2):30-34. Not eligible exposure. [pmid: 8302644].
528 Burhansstipanov L, Wound DB, Capelouto N, Goldfarb F, Harjo L, Hatathlie L, Vigil G, White M. Culturally relevant “Navigator” patient support. The Native sisters. Cancer Pract. May–Jun. 1998;6(3):191-194. No association tested. [pmid: 9652252].
529 Burke RJ. Surviving hospital restructuring. Next steps. J Nurs Adm. Apr. 2001;31(4):169-172. Not eligible outcomes. [pmid: 11324327].
530 Burke RJ. Work experiences and psychological well-being of former hospital-based nurses now employed elsewhere. Psychol Rep. Dec. 2002;91(3 Pt 2):1059-1064. Not eligible outcomes. [pmid: 12585513].
531 Burke RJ. Survivors and victims of hospital restructuring and downsizing: who are the real victims?. Int J Nurs Stud. Nov. 2003;40(8):903-909. Not eligible target population. [pmid: 14568371].
532 Burke RJ. Hospital restructuring stressors: support and nursing staff perceptions of unit functioning. Health Care Manag (Frederick). Jul–Sep. 2003;22(3):241-248. Not eligible exposure. [pmid: 12956226].
533 Burke RJ. Implementation of hospital restructuring and nursing staff perceptions of hospital functioning. J Health Organ Manag. 2004;18(45):279-289. Not eligible outcomes. [pmid: 15536756].
534 Burke RJ. Work status congruence, work outcomes, and psychologic well-being. Health Care Manag (Frederick). Apr–Jun. 2004;23(2):120-127. Not eligible outcomes. [pmid: 15192992].
535 Burke RJ. Correlates of nursing staff survivor responses to hospital restructuring and downsizing. Health Care Manag (Frederick). Apr–Jun. 2005;24(2):141-149. Not eligible exposure. [pmid: 15923926].
536 Burke RJ, Greenglass ER. Work-family congruence and work-family concerns among nursing staff. Can J Nurs Leadersh. May–Jun. 1999;12(2):21-29. Not eligible exposure. [pmid: 11094930].
537 Burke RL. When bad things happen to good organizations: a focused approach to recovery using the essentials of magnetism. Nurs Adm Q. Jul–Sep. 2005;29(3):228-240. Review. [pmid: 16056157].
538 Burkle NL. Using ‘weekenders’ to staff the OR. Aorn J. Sep 1990;52(3):632, 634, 636. No association tested.
539 Burke RJ, Greenglass ER. Juggling act: work concerns, family concerns. Canadian Nurse. Oct. 2000;96(9):20-3. Inadequate date presentation. [pmid: 11865502].
540 Burman ME. The impact of organizational and environmental factors on staffing in home health care. Public Health Nurs. Dec. 1993;10(4):233-240. Not eligible target population. [pmid: 8309890].
541 Burnard P. Implications of client-centred counselling for nursing practice. Nurs Times. Jun 28–Jul 4. 1995;91(26):35-37. Comment. [pmid: 7624247].
542 Burner OY, Cunningham P, Hattar HS. Managing a multicultural nurse staff in a multicultural environment. J Nurs Adm. Jun. 1990;20(6):30-34. Not eligible outcomes. [pmid: 2348248].
543 Burns J. Soviet nurses help alleviate Baltimore hospital's shortage. Mod Healthc. Aug 19. 1991;21(33):71-73. Not eligible outcomes. [pmid: 10112389].
544 Burns JP, Mitchell C, Griffith JL, Truog RD. End-of-life care in the pediatric intensive care unit: attitudes and practices of pediatric critical care physicians and nurses. Crit Care Med. Mar. 2001;29(3):658-664. Not eligible outcomes. [pmid: 11373439].
545 Burrows Z, O'Connor S. Let the team decide? Evaluation of self-rostering on an acute general medical ward. Prof Nurse. Nov. 1993;9(2):86-90. Not eligible target population. [pmid: 8234386].
546 Busby A, Gilchrist B. The role of the nurse in the medical ward round. J Adv Nurs. Mar. 1992;17(3):339-346. Not eligible target population. [pmid: 1573102].
547 Bushy A. Critical access hospitals: rural nursing issues. J Nurs Adm. Jun. 2001;31(6):301-310. Comment. [pmid: 11417169].
548 Butler D, Oswald SL, Turner DE. The effects of demographics on determinants of perceived health-care service quality. The case of users and observers. J Manag Med. 1996;10(5):8-20. Not eligible exposure. [pmid: 10166035].
549 Butler L. Valuing research in clinical practice: a basis for developing a strategic plan for nursing research. Can J Nurs Res. Winter. 1995;27(4):33-49. Not eligible outcomes. [pmid: 8697272].
550 Buttery J, Eades M, Frisch S, Giguere M, Mountjoy A. Family response to difficult hospitalizations: the phenomenon of ‘working through’. J Clin Nurs. Jul. 1999;8(4):459-466. Not eligible exposure. [pmid: 10624263].
551 Byrd ME. Child-focused single home visiting. Public Health Nurs. Oct. 1997;14(5):313-322. Not eligible exposure. [pmid: 9342923].
552 Byrne G, Richardson M, Brunsdon J, Patel A. Patient satisfaction with emergency nurse practitioners in A & E. J Clin Nurs. Jan. 2000;9(1):83-92. Not eligible target population. [pmid: 11022496].
553 Cadigan S. Issues of recruitment and retention. Qld Nurse. Jan–Feb. 1997;16(1):17. Comment. [pmid: 9282072].
554 Cahill J. Patient's perceptions of bedside handovers. J Clin Nurs. Jul. 1998;7(4):351-359. Not eligible target population. [pmid: 9830976].
555 Cain M. Looking for positive changes in nursing. Nurs N Z. Aug. 2002;8(7):28. Not eligible target population. [pmid: 12244839].
556 Calabretta N, Cavanaugh SK. Education for inpatients: working with nurses through the clinical information system. Med Ref Serv Q. Summer. 2004;23(2):73-79. Not eligible exposure. [pmid: 15148021].
557 Caldwell MF. Incidence of PTSD among staff victims of patient violence. Hosp Community Psychiatry. Aug. 1992;43(8):838-839. Not eligible exposure. [pmid: 1427689].
558 Callery P. Caring for parents of hospitalized children: a hidden area of nursing work. J Adv Nurs. Nov. 1997;26(5):992-998. Not eligible target population. [pmid: 9372405].
559 Callery P, Smith L. A study of role negotiation between nurses and the parents of hospitalized children. J Adv Nurs. Jul. 1991;16(7):772-781. Not eligible target population. [pmid: 1918639].
560 Calliari D. The relationship between a calculation test given in nursing orientation and medication errors. J Contin Educ Nurs. Jan–Feb. 1995;26(1):11-14. Not eligible exposure. [pmid: 7890873].
561 Calliari D. A method to increase attendance at mandatory classes. J Nurs Staff Dev. Jul–Aug. 1996;12(4):213-215. Not eligible exposure. [pmid: 8936167].
562 Calligaro KD, Miller P, Dougherty MJ, Raviola CA, DeLaurentis DA. Role of nursing personnel in implementing clinical pathways and decreasing hospital costs for major vascular surgery. J Vasc Nurs. Sep. 1996;14(3):57-61. Not eligible exposure. [pmid: 9258016].
563 Callister LC. The role of the nurse in childbirth: perceptions of the childbearing woman. Clin Nurse Spec. Nov 1993;7(6):288–293, 317. Not eligible exposure.
564 Calpin-Davies PJ, Akehurst RL. Doctor-nurse substitution: the workforce equation. J Nurs Manag. Mar. 1999;7(2):71-79. Not eligible target population. [pmid: 10373846].
565 Campbell C. Annualised hours. Br J Perioper Nurs. Apr. 2001;11(4):170-171. Not eligible target population. [pmid: 11892348].
566 Campolo M, Pugh J, Thompson L, Wallace M. Pioneering the 12-hour shift in Australia—implementation and limitations. Aust Crit Care. Dec. 1998;11(4):112-115. Not eligible target population. [pmid: 10188407].
567 Canavan K. ANA study links nurse staffing to quality. Am Nurse. May–Jun. 1997;29(3):1-3. News.
568 Canning S. The Beverly Allitt case. More questions than answers. Nurs Stand. Feb 23–Mar 1. 1994;8(22):20. Not eligible target population. [pmid: 8123538].
569 Capitulo KL, Ankner ML, Miller J. Professional responsibility versus mandatory overtime. J Nurs Adm. Jun. 2001;31(6):290-292. Comment. [pmid: 11417167].
570 Caplan CA. Nursing staff and patient perceptions of the ward atmosphere in a maximum security forensic hospital. Arch Psychiatr Nurs. Feb. 1993;7(1):23-29. Not eligible exposure. [pmid: 8476314].
571 Capuano T, Bokovoy J, Halkins D, Hitchings K. Work flow analysis: eliminating non-value-added work. J Nurs Adm. May. 2004;34(5):246-256. Not eligible exposure. [pmid: 15167421].
572 Capuano T, Bokovoy J, Hitchings K, Houser J. Use of a validated model to evaluate the impact of the work environment on outcomes at a magnet hospital. Health Care Manage Rev. Jul–Sep. 2005;30(3):229-236. Not eligible outcomes. [pmid: 16093889].
573 Caraher M. A sociological approach to health promotion for nurses in an institutional setting. J Adv Nurs. Sep. 1994;20(3):544-551. Not eligible target population. [pmid: 7963063].
574 Carey RG, Teeters JL. CQI case study: reducing medication errors. Jt Comm J Qual Improv. May. 1995;21(5):232-237. Not eligible exposure. [pmid: 7663629].
575 Carlisle D. Paint and perseverance. Nurs Times. Dec 11–17. 1991;87(50):39. Comment. [pmid: 1766893].
576 Carlisle D. Arts in action. A stately pleasure dome. Nurs Times. Apr 17–23. 1991;87(16):28-29. Comment. [pmid: 2020593].
577 Carlisle D. A nurse in any language. Nurs Times. Sep 25–Oct 1. 1996;92(39):26-27. Comment.
578 Carlisle D, Hempel S. Conduct unbecoming?. Nurs Times. Jul 24–30. 1991;87(30):18. Comment.
579 Carlowe J. Don't bank on it. Nurs Stand. Mar 18–24. 1998;12(26):15. News. [pmid: 9697503].
580 Carlowe J. Trial by error. Nurs Times. Jul 23–29. 2002;98(30):22-24. Not eligible target population. [pmid: 12168266].
581 Carr A. GRASPing the nettle, the introduction of a workload measurement tool into an accident and emergency department. Accid Emerg Nurs. Jan. 1994;2(1):21-26. No association tested. [pmid: 7953821].
582 Carr SM. Refocusing health visiting — sharpening the vision and facilitating the process. J Nurs Manag. May. 2005;13(3):249-256. Not eligible target population. [pmid: 15819838].
583 Carr-Hill RA, Jenkins-Clarke S. Measurement systems in principle and in practice: the example of nursing workload. J Adv Nurs. Aug. 1995;22(2):221-225. Not eligible target population. [pmid: 7593940].
584 Carrick JA. Determining case manager workload: are there secrets to success?. Nurs Case Manag. May–Jun. 1998;3(3):128-130. Comment. [pmid: 10067550].
585 Carroll-Johnson RM. The good news and the bad news. Nurs Diagn. Jan–Mar. 2002;13(1):3-4. Editorial. [pmid: 11951380].
586 Carter H, MacInnes P. Nursing attitudes to the care of elderly patients at risk of continuing hospital care. J Adv Nurs. Sep. 1996;24(3):448-455. Not eligible target population. [pmid: 8876403].
587 Carter M. Betrayal of trust. Nurs Times. Aug 11–17. 1999;95(32):34-35. Case Reports. [pmid: 10603868].
588 Carveth JA. Perceived patient deviance and avoidance by nurses. Nurs Res. May–Jun. 1995;44(3):173-178. Not eligible exposure. [pmid: 7761294].
589 Carzoli RP, Martinez-Cruz M, Cuevas LL, Murphy S, Chiu T. Comparison of neonatal nurse practitioners, physician assistants, and residents in the neonatal intensive care unit. Arch Pediatr Adolesc Med. Dec. 1994;148(12):1271-1276. Not eligible exposure. [pmid: 7951805].
590 Cassard SD, Weisman CS, Gordon DL, Wong R. The impact of unit-based self-management by nurses on patient outcomes. Health Serv Res. Oct. 1994;29(4):415-433. Not eligible exposure. [pmid: 7928370]. [pmcid: 1070015].
591 Castledine G. Case 22: The incompetent practitioner. Serious concerns about a nurse's basic competencies. Br J Nurs. Mar 9–22. 2000;9(5):259. Not eligible target population. [pmid: 11042779].
592 Castledine G. Nurses need to sort out their system of care. Br J Nurs. Mar 8–21. 2001;10(5):350. Not eligible target population. [pmid: 12170679].
593 Castledine G. Nurse in charge who walked out on an understaffed ward. Br J Nurs. Oct 24–Nov 13. 2002;11(19):1231. Editorial. [pmid: 12419976].
594 Castledine G. Nurse who covered up for a sister who was having problems. Br J Nurs. Jan 23–Feb 12. 2003;12(2):79. Case Reports. [pmid: 12574710].
595 Castledine G. Staff nurse who had an alcohol problem and made nursing errors. Br J Nurs. Nov 25–Dec 8. 2004;13(21):1288. Not eligible target population. [pmid: 15580078].
596 Castledine G. Senior nurse whose incompetence resulted in the death of a patient. Br J Nurs. May 12–25. 2005;14(9):516. Not eligible target population. [pmid: 15924002].
597 Castleforte MR, Fraser L. Yes, primary nursing can survive 12-hour shifts. Nurs Manage. Mar. 1995;26(3):64-65. Comment. [pmid: 7746584].
598 Catalani C, Biggeri A, Gottard A, Benvenuti M, Frati E, Cecchini C. Prevalence of HCV infection among health care workers in a hospital in central Italy. Eur J Epidemiol. 2004;19(1):73-77. Not eligible target population. [pmid: 15012026].
599 Caterinicchio MJ. Redefining nursing according to patients' and families' needs: an evolving concept. AACN Certification Corporation. AACN Clin Issues. Feb. 1995;6(1):153-156. Comment. [pmid: 7736300].
600 Cating G. Mandatory OT is the last straw. Revolution. Sep–Oct. 2000;1(5):4. Letter. [pmid: 12018074].
601 Caty S, Larocque S, Koren I. Family-centered care in Ontario general hospitals: the views of pediatric nurses. Can J Nurs Leadersh. May–Jun. 2001;14(2):10-18. Not eligible outcomes. [pmid: 15487299].
602 Cavan DA, Hamilton P, Everett J, Kerr D. Reducing hospital inpatient length of stay for patients with diabetes. Diabet Med. Feb. 2001;18(2):162-164. Not eligible target population. [pmid: 11251683].
603 Celia B. Age and gender differences in pain management following coronary artery bypass surgery. J Gerontol Nurs. May. 2000;26(5):7-13. quiz 52–13. Not eligible exposure. [pmid: 11111515].
604 Ceria CD. Nursing absenteeism and its effects on the quality of patient care. J Nurs Adm. Dec. 1992;22(12):11-38. Not eligible outcomes. [pmid: 1469479].
605 Cerrai T, Michelassi S, Ierpi C, Toti G, Zignego AL, Lombardi M. Universal precautions and dedicated machines as cheap and effective measures to control HCV spread. Edtna Erca J. Apr–Jun 1998;24(2):43–45, 48. Not eligible target population.
606 Chaaya M, Rahal B, Morou G, Kaiss N. Implementing patient-centered care in Lebanon. J Nurs Adm. Sep. 2003;33(9):437-440. Not eligible target population. [pmid: 14501559].
607 Chamberlain G, Wraight A, Crowley P. Birth at home. Pract Midwife. Jul–Aug. 1999;2(7):35-39. Not eligible target population. [pmid: 10481690].
608 Chan DS. Validation of the Clinical Learning Environment Inventory. West J Nurs Res. Aug. 2003;25(5):519-532. Not eligible target population. [pmid: 12955969].
609 Chan FS. An evaluation of the role of the night nurse practitioner. Nurs Times. Sep 18–23. 1996;92(38):38-39. Not eligible target population. [pmid: 8949127].
610 Chan JC, Chu RW, Young BW, Chan F, Chow CC, Pang WC, Chan C, Yeung SH, Chow PK, Lau J, Leung PM. Use of an electronic barcode system for patient identification during blood transfusion: 3-year experience in a regional hospital. Hong Kong Med J. Jun. 2004;10(3):166-171. Not eligible target population. [pmid: 15181220].
611 Chan R, Molassiotis A, Chan E, Chan V, Ho B, Lai CY, Lam P, Shit F, Yiu I. Nurses' knowledge of and compliance with universal precautions in an acute care hospital. Int J Nurs Stud. Feb. 2002;39(2):157-163. Not eligible target population. [pmid: 11755446].
612 Chan S, Lam TH. Preventing exposure to second-hand smoke. Semin Oncol Nurs. Nov. 2003;19(4):284-290. Not eligible target population. [pmid: 14702863].
613 Chan SS, Leung GM, Tiwari AF, Salili F, Leung SS, Wong DC, Wong AS, Lai AS, Lam TH. The impact of work-related risk on nurses during the SARS outbreak in Hong Kong. Fam Community Health. Jul–Sep. 2005;28(3):274-287. Not eligible target population. [pmid: 15958885].
614 Chandler C. Solutions for inadequate staffing. Am J Nurs. Oct. 2003;103(10):14. Comment. [pmid: 14565201].
615 Chandra A, Willis WK. Importing nurses: combating the nursing shortage in America. Hosp Top. Spring. 2005;83(2):33-37. Review.
616 Chang AM, Lam LW. Evaluation of a health care assistant pilot programme. J Nurs Manag. Jul. 1997;5(4):229-236. Not eligible target population. [pmid: 9248413].
617 Chang E, Hancock K, Chenoweth L, Jeon YH, Glasson J, Gradidge K, Graham E. The influence of demographic variables and ward type on elderly patients' perceptions of needs and satisfaction during acute hospitalization. Int J Nurs Pract. Jun. 2003;9(3):191-201. Not eligible target population. [pmid: 12801251].
618 Chang SO. The conceptual structure of physical touch in caring. J Adv Nurs. Mar. 2001;33(6):820-827. Not eligible target population. [pmid: 11298220].
619 Charles J. Mandatory overtime: conflicts of conscience?. JONAS Healthc Law Ethics Regul. Mar. 2002;4(1):10-12. Review. [pmid: 11924250].
620 Chartier K. Fighting the shortage with strong retention strategies—University of Michigan Health System model. Nephrol News Issues. Jul. 2004;18(8):28-79. Comment. [pmid: 15624425].
621 Chartier K. National nurse-to-patient ratio proposed. Nephrol News Issues. Jul. 2004;18(8):23. News.
622 Chartier K. Staff ratios: California law may spread to other states. Nephrol News Issues. Apr. 2004;18(5):22. Comment. [pmid: 15125161].
623 Cheek J. Nurses and the administration of medications. Broadening the focus. Clin Nurs Res. Aug. 1997;6(3):253-274. Not eligible target population. [pmid: 9281929].
624 Chen WT, Han M, Holzemer WL. Nurses' knowledge, attitudes, and practice related to HIV transmission in northeastern China. AIDS Patient Care STDS. Jul. 2004;18(7):417-422. Not eligible target population. [pmid: 15307930].
625 Chesanow N. A medical crisis: who'll care for your patients? Med Econ. May 7 2001;78(9):67–68, 72, 74. Comment.
626 Chevron V, Menard JF, Richard JC, Girault C, Leroy J, Bonmarchand G. Unplanned extubation: risk factors of development and predictive criteria for reintubation. Crit Care Med. Jun. 1998;26(6):1049-1053. Not eligible target population. [pmid: 9635654].
627 Chewitt MD, Fallis WM, Suski MC. The surgical hotline. Bridging the gap between hospital and home. J Nurs Adm. Dec. 1997;27(12):42-49. Not eligible exposure. [pmid: 9418756].
628 Ching TY, Seto WH. Evaluating the efficacy of the infection control liaison nurse in the hospital. J Adv Nurs. Oct. 1990;15(10):1128-1131. Not eligible target population. [pmid: 2258518].
629 Cho SH. Nurse staffing and adverse patient outcomes: a systems approach. Nurs Outlook. Mar–Apr. 2001;49(2):78-85. Review. [pmid: 11309562].
630 Cho SH. Using multilevel analysis in patient and organizational outcomes research. Nurs Res. Jan–Feb. 2003;52(1):61-65. Review. [pmid: 12552178].
631 Choi E, Song M. Physical restraint use in a Korean ICU. J Clin Nurs. Sep. 2003;12(5):651-659. Not eligible target population. [pmid: 12919211].
632 Choi J, Bakken S, Larson E, Du Y, Stone PW. Perceived nursing work environment of critical care nurses. Nurs Res. Nov–Dec. 2004;53(6):370-378. Not eligible exposure. [pmid: 15586133].
633 Choi T, Jameson H, Brekke ML, Podratz RO, Mundahl H. Effects on nurse retention. An experiment with scheduling. Med Care. Nov. 1986;24(11):1029-1043. Not eligible year. [pmid: 3773577].
634 Choi-Kwon S, Lee SK, Park HA, Kwon SU, Ahn JS, Kim JS. What stroke patients want to know and what medical professionals think they should know about stroke: Korean perspectives. Patient Educ Couns. Jan. 2005;56(1):85-92. Not eligible target population. [pmid: 15590227].
635 Chokbunyasit N, Potacharoen O, Sirisanthana T. Prevalence of HBV infection in nurses and manual workers in Maharaj Nakorn Chiang Mai Hospital. J Med Assoc Thai. Jul. 1995;78(Suppl 1):S19-25. Not eligible target population. [pmid: 7666022].
636 Chong J, Marshall BJ, Barkin JS, McCallum RW, Reiner DK, Hoffman SR, O'Phelan C. Occupational exposure to Helicobacter pylori for the endoscopy professional: a sera epidemiological study. Am J Gastroenterol. Nov. 1994;89(11):1987-1992. Not eligible exposure. [pmid: 7942723].
637 Chou KR, Lu RB, Mao WC. Factors relevant to patient assaultive behavior and assault in acute inpatient psychiatric units in Taiwan. Arch Psychiatr Nurs. Aug. 2002;16(4):187-195. Not eligible target population. [pmid: 12143078].
638 Christensen P. RNs—hands-on care and more. Nurs Spectr (Wash D C). Jan 13. 1997;7(1):3. Editorial.
639 Christmas AB, Reynolds J, Hodges S, Franklin GA, Miller FB, Richardson JD, Rodriguez JL. Physician extenders impact trauma systems. J Trauma. May. 2005;58(5):917-920. Not eligible exposure. [pmid: 15920403].
640 Christmas D. Meet the travelers. Diane Christmas. Rn. Jan 2004;Suppl:30. Interview.
641 Chung K, Choi YB, Moon S. Toward efficient medication error reduction: error-reducing information management systems. J Med Syst. Dec. 2003;27(6):553-560. Review. [pmid: 14626480].
642 Chung LH, Chong S, French P. The efficiency of fluid balance charting: an evidence-based management project. J Nurs Manag. Mar. 2002;10(2):103-113. Not eligible target population. [pmid: 11882111].
643 Cimino MA, Kirschbaum MS, Brodsky L, Shaha SH. Assessing medication prescribing errors in pediatric intensive care units. Pediatr Crit Care Med. Mar. 2004;5(2):124-132. Not eligible exposure. [pmid: 14987341].
644 Cimiotti JP, Wu F, Della-Latta P, Nesin M, Larson E. Emergence of resistant staphylococci on the hands of new graduate nurses. Infect Control Hosp Epidemiol. May. 2004;25(5):431-435. Not eligible outcomes. [pmid: 15188851].
645 Cina J, Baroletti S, Churchill W, Hayes J, Messinger C, Mogan-McCarthy P, Harmuth Y. Interdisciplinary education program for nurses and pharmacists. Am J Health Syst Pharm. Nov 1. 2004;61(21):2294-2296. Not eligible exposure. [pmid: 15552638].
646 Cirone N. Taking orders by phone?. Nursing. Aug. 1998;28(8):56-57. Comment. [pmid: 9739256].
647 Clark AP. Nurse staffing levels and prevention of adverse events. Clin Nurse Spec. Sep. 2002;16(5):237-238. Review. [pmid: 12394110].
648 Clark BA, Rutledge C, Bush S, Knaub G, Beeken JE, Larsen PD. An experience with “research by committee”. J Nurses Staff Dev. Sep–Oct. 1998;14(5):244-249. Not eligible exposure. [pmid: 9807342].
649 Clark JS. An aging population with chronic disease compels new delivery systems focused on new structures and practices. Nurs Adm Q. Apr–Jun. 2004;28(2):105-115. Not eligible exposure. [pmid: 15181676].
650 Clark K, Normile LB. Delays in implementing admission orders for critical care patients associated with length of stay in emergency departments in six mid-Atlantic states. J Emerg Nurs. Dec. 2002;28(6):489-495. Not eligible exposure. [pmid: 12509725].
651 Clark MF. Traveling nurses. One solution to supplementing your OR staff. Aorn J. May. 1992;55(5):1249-1253. No association tested. [pmid: 1580628].
652 Clark N, Kiyimba F, Bowers L, Jarrett M, McFarlane L. Absconding: nurses views and reactions. J Psychiatr Ment Health Nurs. Jun. 1999;6(3):219-224. Not eligible target population. [pmid: 10633675].
653 Clarke A, Hadfield-Law L, Neal K. I've been told I have to move to another part of the unit, but I don't want to go. What doI do?. Nurs Times. May 4–10. 2000;96(18):30. Comment. [pmid: 11961832].
654 Clarke M. Speaking up. Nurs Times. Jan 13–19. 1993;89(2):42-44. Comment. [pmid: 8424082].
655 Clarke SP. Balancing staffing and safety. Nurs Manage. Jun. 2003;34(6):44-48. Review. [pmid: 12789053].
656 Clarke SP. The policy implications of staffing-outcomes research. J Nurs Adm. Jan. 2005;35(1):17-19. Review. [pmid: 15647663].
657 Clarke SP, Aiken LH. Failure to rescue. Am J Nurs. Jan. 2003;103(1):42-47. Review. [pmid: 12544057].
658 Clarke SP, Sloane DM, Aiken LH. Effects of hospital staffing and organizational climate on needlestick injuries to nurses. Am J Public Health. Jul. 2002;92(7):1115-1119. Not eligible outcomes. [pmid: 12084694]. [pmcid: 1447200].
659 Clarke T, Abbenbroek B, Hardy L. The impact of a high dependency unit continuing education program on nursing practice and patient outcomes. Aust Crit Care. Dec 1996;9(4):138–147, 149. Not eligible target population.
660 Clay ML. An opinion: staff nurses at risk; increasing use of practical nurses. Pa Nurse. Mar. 1997;52(3):7. Comment. [pmid: 9095988].
661 Cleary M, Edwards C. ‘Something always comes up’: nurse-patient interaction in an acute psychiatric setting. J Psychiatr Ment Health Nurs. Dec. 1999;6(6):469-477. Not eligible target population. [pmid: 10818870].
662 Cleary PD. A hospitalization from hell: a patient's perspective on quality. Ann Intern Med. Jan 7. 2003;138(1):33-39. Case Reports. [pmid: 12513042].
663 Clement J. “Change is inevitable and desirable”: an interview with Ontario's Minister of Health and Long-Term Care. Interview by Peggy Leatt. Hosp Q. Fall. 2001;5(1):56-59. Interview. [pmid: 11765495].
664 Clifton B. The end is night. Nurs Stand. Oct 20–26. 1993;8(5):45. Comment. [pmid: 8217725].
665 Cline D, Reilly C, Moore JF. What's behind RN turnover?. Nurs Manage. Oct. 2003;34(10):50-53. Comment. [pmid: 14557783].
666 Clissold G, Smith P, Acutt B. The impact of unwaged domestic work on the duration and timing of sleep of female nurses working full-time on rotating 3-shift rosters. J Hum Ergol (Tokyo). Dec. 2001;30(12):345-349. Not eligible target population. [pmid: 14564906].
667 Coates M, Heilmann S. Self-scheduling: a practical application of shared governance. Aspens Advis Nurse Exec. Aug. 1993;8(11):6-7. Comment. [pmid: 8343307].
668 Cobb MD. Dealing fairly with medication errors. Nursing. Mar. 1990;20(3):42-43. Comment. [pmid: 2314693].
669 Cody WK. Affirming reflection. Nurs Sci Q. Jan. 1999;12(1):4-6. Comment. [pmid: 11847650].
670 Cohen H, Mandrack MM. Application of the 80/20 rule in safeguarding the use of high-alert medications. Crit Care Nurs Clin North Am. Dec. 2002;14(4):369-374. Not eligible exposure. [pmid: 12400627].
671 Cohen LM, McCue JD, Green GM. Do clinical and formal assessments of the capacity of patients in the intensive care unit to make decisions agree?. Arch Intern Med. Nov 8. 1993;153(21):2481-2485. Not eligible exposure. [pmid: 8215753].
672 Cohen MR. Special care units need all pharmacy services. Nursing. Sep. 1990;20(9):12. Comment. [pmid: 2395543].
673 Cohen MR. Don't let doctors intimidate you. Nursing. Jan. 1992;22(1):18. Case Reports. [pmid: 1741080].
674 Cohen MR, Davis NM. Comments on ASHP guidelines for preventing medication errors. Am J Hosp Pharm. May. 1993;50(5):913. Comment. [pmid: 8506868].
675 Cohen MZ, Hausner J, Johnson M. Knowledge and presence: accountability as described by nurses and surgical patients. J Prof Nurs. May–Jun. 1994;10(3):177-185. Not eligible exposure. [pmid: 7518479].
676 Cohen-Katz J, Wiley S, Capuano T, Baker DM, Deitrick L, Shapiro S. The effects of mindfulness-based stress reduction on nurse stress and burnout: a qualitative and quantitative study, part III. Holist Nurs Pract. Mar–Apr. 2005;19(2):78-86. Not eligible exposure. [pmid: 15871591].
677 Cohran J, Larson E, Roach H, Blane C, Pierce P. Effect of intravascular surveillance and education program on rates of nosocomial bloodstream infections. Heart Lung. Mar–Apr. 1996;25(2):161-164. Not eligible exposure. [pmid: 8682688].
678 Coile RC, Jr. Nursing workforce shortages: “code blue” for RN staffing across America. Russ Coiles Health Trends. Nov 2001;14(1):1, 4–7. Comment.
679 Cole A. Shifting shifts. Nurs Times. May 15–21. 1991;87(20):21. Comment.
680 Cole A. Satisfied customers. Nurs Times. Mar 6–12. 1996;92(10):20-21. News.
681 Coleman JC, Paul GL. Relationship between staffing ratios and effectiveness of inpatient psychiatric units. Psychiatr Serv. Oct. 2001;52(10):1374-1379. Not eligible outcomes. [pmid: 11585955].
682 Coleman S, Dracup K, Moser DK. Comparing methods of cardiopulmonary resuscitation instruction on learning and retention. J Nurs Staff Dev. Mar–Apr. 1991;7(2):82-87. Not eligible exposure. [pmid: 2030413].
683 Colen HB, Neef C, Schuring RW. Identification and verification of critical performance dimensions. Phase 1 of the systematic process redesign of drug distribution. Pharm World Sci. Jun. 2003;25(3):118-125. Not eligible target population. [pmid: 12840965].
684 Collier V, Fraser J, Evans C. Change from the bottom up. Nurs Times. Feb 4–10. 1998;94(5):68-69. Comment. [pmid: 9536770].
685 Collins SE. Nurse attorney notes. Fla Nurse. Feb–Mar. 1996;44(3):13. Legal Cases.
686 Colodny A. Spinal cord injury nurses in action: partners in practice. SCI Nurs. Sep. 1997;14(3):79-82. No association tested. [pmid: 9355613].
687 Comack M, Smith SD, Bowman A, Gillow K, Hunt M, Snell L, Thomsen F, Turner D. Planning change in scheduling practices: a theoretical perspective. Can J Nurs Adm. Mar–Apr. 1991;4(1):17-21. No association tested. [pmid: 2059641].
688 Condliffe B. Witness for the prosecution. Nurs Times. Jul 19–25. 2001;97(29):26-27. Not eligible target population. [pmid: 11957499].
689 Conklin D, MacFarland V, Kinnie-Steeves A, Chenger P. Medication errors by nurses: contributing factors. AARN News Lett. Jan. 1990;46(1):8-9. No association tested. [pmid: 2301203].
690 Connell J, Bradley S. Visiting children in hospital: a vision from the past. Paediatr Nurs. Apr. 2000;12(3):32-35. Not eligible target population. [pmid: 11220864].
691 Conners AM. Patient classification system in a rural emergency department. Accid Emerg Nurs. Jan. 1994;2(1):7-20. No association tested. [pmid: 7953829].
692 Connor D. Family-centred care in practice. Nurs N Z. May. 1998;4(4):18-19. Not eligible target population. [pmid: 10586746].
693 Considine J, Ung L, Thomas S. Triage nurses' decisions using the National Triage Scale for Australian emergency departments. Accid Emerg Nurs. Oct. 2000;8(4):201-209. Not eligible target population. [pmid: 11760322].
694 Conway R. The mysteries of the Milton Tank!. Nurs Prax N Z. Nov. 1996;11(3):27-31. Not eligible target population. [pmid: 9155371].
695 Cook AF, Hoas H, Guttmannova K, Joyner JC. An error by any other name. Am J Nurs. Jun. 2004;104(6):32-43. quiz 44. Not eligible outcomes. [pmid: 15187607].
696 Cook DJ, Guyatt GH, Jaeschke R, Reeve J, Spanier A, King D, Molloy DW, Willan A, Streiner DL. Determinants in Canadian health care workers of the decision to withdraw life support from the critically ill. Canadian Critical Care Trials Group. Jama. Mar 1. 1995;273(9):703-708. Not eligible exposure. [pmid: 7853627].
697 Cook R. Day in the life: Back to school nurses. Nurs Stand. Aug 12–18. 1992;6(47):45. Comment.
698 Cooke P. One-to-one midwifery: Part 6. Mod Midwife. Sep. 1996;6(9):23-25. Comment. [pmid: 8945215].
699 Cookson ST, Ihrig M, O'Mara EM, Denny M, Volk H, Banerjee SN, Hartstein AI, Jarvis WR. Increased bloodstream infection rates in surgical patients associated with variation from recommended use and care following implementation of a needleless device. Infect Control Hosp Epidemiol. Jan. 1998;19(1):23-27. Not eligible exposure. [pmid: 9475345].
700 Coombs M. The challenge facing critical care nurses in the UK: a personal perspective. Nurs Crit Care. Mar–Apr. 1999;4(2):81-84. Not eligible target population. [pmid: 10410039].
701 Cooper C, Connor T. Easing winter pressure: commissioning and evaluating a medical day case unit. Nurs Stand. Jun 30–Jul 6. 1999;13(41):32-34. Not eligible target population. [pmid: 10497524].
702 Cooper J, Spencer D. The challenges and benefits of job sharing in palliative care education. Br J Nurs. Oct 9–22. 1997;6(18):1071-1075. Not eligible target population. [pmid: 9370572].
703 Cooper JE, Tate R, Yassi A. Work hardening in an early return to work program for nurses with back injury. WORK: A Journal of Prevention, Assessment & Rehabilitation. Mar. 1997;8(2):149-56. Not relevant.
704 Cooper MC. Can a zero defects philosophy be applied to drug errors?. J Adv Nurs. Mar. 1995;21(3):487-491. Not eligible target population. [pmid: 7745202].
705 Cooper PG. Nurse-patient ratios revisited. Nurs Forum. Apr–Jun. 2004;39(2):3-4. Editorial.
706 Copeland-Fields L, Griffin T, Jenkins T, Buckley M, Wise LC. Comparison of outcome predictions made by physicians, by nurses, and by using the Mortality Prediction Model. Am J Crit Care. Sep. 2001;10(5):313-319. Not eligible exposure. [pmid: 11548564].
707 Corby S. Opportunity 2000 in the National Health Service: a missed opportunity for women. J Manag Med. 1997;11(56):279-293. Not eligible target population. [pmid: 10176822].
708 Corder L. Part-time working. Level the playing field. Nurs Times. Feb 28–Mar 5. 1996;92(9):30-32. Not eligible target population. [pmid: 8700733].
709 Corley MC, Huff S, Sayles L, Short L. Patient and nurse criteria for heart transplant candidacy. Medsurg Nurs. Jun. 1995;4(3):211-215. Not eligible exposure. [pmid: 7780475].
710 Cormack K. Audit of consent forms. Br J Theatre Nurs. Dec. 1998;8(9):14-16. Not eligible target population. [pmid: 10076232].
711 Corona GG. We turned med/surg staff into telemetry experts. Rn. Oct 1992;55(10):21–22, 24. No association tested.
712 Costello A, Tsushima ST. Agency nursing: one hospital's experience. Nurs Manage. Feb 1996;27(2):63, 65, 67. Comment.
713 Costello A, Tsushima ST. Notes from the field. Agency nursing: one hospital's experience. Nursing management Feb 1996;27(2):63, 5, 7. Inadequate data presentation.
714 Costello K. Managed competition vs. single payer: what's best for patients and RNs?. Calif Nurse. Jun. 1994;90(6):6. Comment. [pmid: 8025862].
715 Coston B. Fighting through an appeals process. Rn. Feb. 1995;58(2):57-59. Comment. [pmid: 7624716].
716 Coughlin C. Care centered organizations, Part 2. The changing role of the nurse executives. J Nurs Adm. Mar. 2001;31(3):113-120. No association tested. [pmid: 11263059].
717 Cowin L. The effects of nurses' job satisfaction on retention: an Australian perspective. J Nurs Adm. May. 2002;32(5):283-291. Not eligible target population. [pmid: 12021569].
718 Cox C. Should we be getting danger money?. Nurs Times. Jul 19–25. 2001;97(29):23. Comment. [pmid: 11957497].
719 Coyle GA, Heinen M. Evolution of BCMA within the Department of Veterans Affairs. Nurs Adm Q. Jan–Mar. 2005;29(1):32-38. Not eligible exposure. [pmid: 15779703].
720 Coyle J, Williams B. Valuing people as individuals: development of an instrument through a survey of person-centredness in secondary care. J Adv Nurs. Nov. 2001;36(3):450-459. Not eligible target population. [pmid: 11686760].
721 Craig EA, Hanna IT, McGilvray S, Docherty P, Donlevy S. Nurse or doctor: biometry for intraocular lens power calculation, who should measure?. Health Bull (Edinb). Mar. 1995;53(2):105-109. Not eligible target population. [pmid: 7737871].
722 Cramer LD, McCorkle R, Cherlin E, Johnson-Hurzeler R, Bradley EH. Nurses' attitudes and practice related to hospice care. J Nurs Scholarsh. 2003;35(3):249-255. Not eligible target population. [pmid: 14562493].
723 Crandall M. Nurse-to-patient ratios. Addressing concerns in legislation. AWHONN Lifelines. Apr–May. 2000;4(2):21. News. [pmid: 11146922].
724 Crellin DJ, Johnston L. Poor agreement in application of the Australasian Triage Scale to paediatric emergency department presentations. Contemp Nurse. Aug. 2003;15(12):48-60. Not eligible target population. [pmid: 14649508].
725 Crimlisk JT, McNulty MJ, Francione DA. New graduate RNs in a float pool. An inner-city hospital experience. J Nurs Adm. Apr. 2002;32(4):211-217. Not eligible exposure. [pmid: 11984257].
726 Crispin C, Daffurn K. Nurses' responses to acute severe illness. Aust Crit Care. Dec. 1998;11(4):131-133. Not eligible target population. [pmid: 10188410].
727 Crome P, McDaniel C, Rotunna S, Tachibana C. Staffing solutions: an in-house agency. Nurs Manage. Aug 1993;24(8):64A–64B, 64D, 64F. Not eligible outcomes.
728 Cronin-Stubbs D, Swanson B, Dean-Baar S, Sheldon JA, Duchene P. The effects of a training program on nurses' functional performance assessments. Appl Nurs Res. Feb. 1992;5(1):38-43. Not eligible exposure. [pmid: 1570959].
729 Crouch D. ‘I'm delighted the new role is making a difference’. Nurs Times. Nov 25–Dec 1. 2003;99(47):26-27. Comment. [pmid: 14689670].
730 Crout LA, Chang E, Cioffi J. Why do registered nurses work when ill?. J Nurs Adm. Jan. 2005;35(1):23-28. Not eligible target population. [pmid: 15647665].
731 Crow D. Foreign nurse recruitment. Healthtexas. Aug. 1991;47(2):10-11. Comment. [pmid: 10112944].
732 Crownover AJ. The other foot: who is an agency nurse?. Tenn Nurse. Spring. 1993;56(1):15-20. Comment. [pmid: 8490040].
733 Cruickshank JF, MacKay RC, Matsuno K, Williams AM. Appraisal of the clinical competence of registered nurses in relation to their designated levels in the Western Australian nursing career structure. Int J Nurs Stud. Jun. 1994;31(3):217-230. Not eligible target population. [pmid: 8088934].
734 Cullen L, Greiner J, Bombei C, Comried L. Excellence in evidence-based practice: organizational and unit exemplars. Crit Care Nurs Clin North Am. Jun. 2005;17(2):127-142. Not eligible exposure. [pmid: 15862735].
735 Cumbie SA, Conley VM, Burman ME. Advanced practice nursing model for comprehensive care with chronic illness: model for promoting process engagement. ANS Adv Nurs Sci. Jan–Mar. 2004;27(1):70-80. Not eligible exposure. [pmid: 15027663].
736 Cupitt JM, Vinayagam S, McConachie I. Radiation exposure of nurses on an intensive care unit. Anaesthesia. Feb. 2001;56(2):183. Letter. [pmid: 11167482].
737 Curley MA. Caring for parents of critically ill children. Crit Care Med. Sep. 1993;21(9 Suppl):S386-387. No association tested. [pmid: 8365242].
738 Curry L, Porter M, Michalski M, Gruman C. Individualized care: perceptions of certified nurse's aides. J Gerontol Nurs. Jul. 2000;26(7):45-51. quiz 52–43. Not eligible target population. [pmid: 11261067].
739 Curtin L. Policies hinder nursing staff. J Emerg Nurs. Dec. 2000;26(6):539. Letter. [pmid: 11106444].
740 Curtin LL. Lean, mean and stupid!. Nurs Manage. May. 1997;28(5):7-8. Editorial.
741 Curtin LL. An integrated analysis of nurse staffing and related variables: effects on patient outcomes. Online J Issues Nurs. 2003;8(3):5. Review. [pmid: 14656199].
742 Czaplinski C, Diers D. The effect of staff nursing on length of stay and mortality. Med Care. Dec. 1998;36(12):1626-1638. Not eligible exposure. [pmid: 9860053].
743 Czurylo K, Gattuso M, Epsom R, Ryan C, Stark B. Continuing education outcomes related to pain management practice. J Contin Educ Nurs. Mar–Apr. 1999;30(2):84-87. Not eligible exposure. [pmid: 10382461].
744 D'Addario V, Curley A. How case management can improve the quality of patient care. Int J Qual Health Care. Dec. 1994;6(4):339-345. Not eligible outcomes. [pmid: 7719669].
745 D'Agata EM, Wise S, Stewart A, Lefkowitz LB Jr. Nosocomial transmission of Mycobacterium tuberculosis from an extrapulmonary site. Infect Control Hosp Epidemiol. Jan. 2001;22(1):10-12. Not eligible exposure. [pmid: 11198015].
746 Daghistani D, Horn M, Rodriguez Z, Schoenike S, Toledano S. Prevention of indwelling central venous catheter sepsis. Med Pediatr Oncol. Jun. 1996;26(6):405-408. Not eligible exposure. [pmid: 8614377].
747 Dahlman GB, Dykes AK, Elander G. Patients' evaluation of pain and nurses' management of analgesics after surgery. The effect of a study day on the subject of pain for nurses working at the thorax surgery department. J Adv Nurs. Oct. 1999;30(4):866-874. Not eligible target population. [pmid: 10520099].
748 Dalayon AP. Components of preoperative patient teaching in Kuwait. J Adv Nurs. Mar. 1994;19(3):537-542. Not eligible target population. [pmid: 7516939].
749 Dale C, Lynch J. Blueprint for healthcare. Nurs Manag (Harrow). Oct. 1996;3(6):22-24. Not eligible target population. [pmid: 9077200].
750 Dale J, Williams S, Wellesley A, Glucksman E. Training and supervision needs and experience: a longitudinal, cross-sectional survey of accident and emergency department senior house officers. Postgrad Med J. Feb. 1999;75(880):86-89. Not eligible target population. [pmid: 10448468].
751 Daly BJ, Phelps C, Rudy EB. A nurse-managed special care unit. J Nurs Adm. Jul–Aug. 1991;21(78):31-38. Comment. [pmid: 1870004].
752 Daly BJ, Thomas D, Dyer MA. Procedures used in withdrawal of mechanical ventilation. Am J Crit Care. Sep. 1996;5(5):331-338. Not eligible Exposure. [pmid: 8870856].
753 Danchaivijitr S, Suthisanon L, Jitreecheue L, Tantiwatanapaibool Y. Effects of education on the prevention of pressure sores. J Med Assoc Thai. Jul. 1995;78(Suppl 1):S1-6. Not eligible target population. [pmid: 7666018].
754 Dandrinos-Smith S, Garman DA, Baranowski SL, Davol LH, Person CD. The making of a supermodel. Nurs Manage. Oct. 2000;31(10):33-36. Comment. [pmid: 15127555].
755 Daniel M, Banerjee AR. Is a doctor needed in the adult ENT pre-admission clinic?. J Laryngol Otol. Oct. 2004;118(10):796-798. Not eligible target population. [pmid: 15550187].
756 Dann D, Miller B, Hobbs M, Gentzsch P, Pierson C. Successful interviewing and selection strategies for patient-centered care delivery. Semin Nurse Manag. Mar. 1995;3(1):27-35. Comment. [pmid: 7743257].
757 Darby DN, Daniel K. Factors that influence nurses' customer orientation. J Nurs Manag. Sep. 1999;7(5):271-280. Not eligible target population. [pmid: 10786546].
758 Darby M. Optimal staffing for hospitals: in search of solutions. Qual Lett Healthc Lead. Jun. 1999;11(6):2-10. Review.
759 Darling H. Satisfying a hunger ... a personal journey of self discovery through further nursing education. Nurs Prax N Z. Mar. 1995;10(1):12-21. Not eligible target population. [pmid: 7626945].
760 Darmer MR, Ankersen L, Nielsen BG, Landberger G, Lippert E, Egerod I. The effect of a VIPS implementation programme on nurses' knowledge and attitudes towards documentation. Scand J Caring Sci. Sep. 2004;18(3):325-332. Not eligible target population. [pmid: 15355528].
761 Darvas JA, Hawkins LG. What makes a good intensive care unit: a nursing perspective. Aust Crit Care. May. 2002;15(2):77-82. Not eligible target population. [pmid: 12154701].
762 Das HS, Sawant P, Shirhatti RG, Vyas K, Vispute S, Dhadphale S, Patrawalla V, Desai N. Efficacy of low dose intradermal hepatitis B vaccine: results of a randomized trial among health care workers. Trop Gastroenterol. Jul–Sep. 2002;23(3):120-121. Not eligible exposure. [pmid: 12693152].
763 Daubener J. A look at travel nursing: two sides to the coin. J Emerg Nurs. Oct. 2001;27(5):507-510. Comment. [pmid: 11577297].
764 Daugherty J. “Premium shifts”: a solution to an expensive option. Nurs Manage. Apr. 1992;23(4):88. Comment. [pmid: 1560959].
765 Davidhizar R. Preparing a nursing department for downshifting. Todays OR Nurse. Jul–Aug. 1993;15(4):51-53. Comment.
766 Davidhizar R, Poole V, Giger JN. Power nap rejuvenates body, mind. Pa Nurse. Mar. 1996;51(3):6-7. Comment. [pmid: 8716446].
767 Davidson H, Folcarelli PH, Crawford S, Duprat LJ, Clifford JC. The effects of health care reforms on job satisfaction and voluntary turnover among hospital-based nurses. Med Care. Jun. 1997;35(6):634-645. Not eligible exposure. [pmid: 9191707].
768 Davidson J. Golden slumbers. Br J Perioper Nurs. Feb. 2000;10(2):74-75. Comment. [pmid: 11042793].
769 Davidson SB, Scott R, Minarik P. Thinking critically about delegation. Am J Nurs. Jun. 1999;99(6):61-62. Comment. [pmid: 10489563].
770 Davies H. Client-centred midwifery. No easy option. Pract Midwife. Jun. 2001;4(6):26-28. Not eligible target population. [pmid: 12026843].
771 D'Avirro J, Dotson T, LaPierre B, Marshall W, Mishler MB, Tanger JL. An interdisciplinary clinical advancement program within a patient-centered care model. Rehabil Nurs. May–Jun. 1996;21(3):132-138. Not eligible exposure. [pmid: 8711259].
772 Davis D. Partnering with nurses to handle personnel shortages. Am J Health Syst Pharm. Oct 1. 2002;59(19):1824-1826. Comment. [pmid: 12374065].
773 Davis E. Autonomy at work: woman-centered birth and midwifery. Midwifery Today Childbirth Educ. Summer. 1997;(42):23-25. Comment. [pmid: 9429428].
774 Davis JE. Nursing resources in accident and emergency departments. J Nurs Manag. Jan. 1995;3(1):11-18. Not eligible target population. [pmid: 7704362].
775 Davis LA. A phenomenological study of patient expectations concerning nursing care. Holist Nurs Pract. May–Jun. 2005;19(3):126-133. Not eligible exposure. [pmid: 15923939].
776 Davis NM. Always read medication labels. Am J Nurs. Nov. 1993;93(11):14. Comment.
777 Davis NM. Combating confirmation bias. Am J Nurs. Jul. 1994;94(7):17. Comment.
778 Davis NM. Teaching patients to prevent errors. Am J Nurs. May. 1994;94(5):17. Comment.
779 Davis NM. Concentrating on interruptions. Am J Nurs. Mar. 1994;94(3):14. Comment.
780 Davis R. The quick fix?. Am J Nurs. Apr. 1991;91(4):56. Comment. [pmid: 2014815].
781 Dawson C, Barrett V, Ross J. A case of a financial approach to manpower planning in the NHS. Health Manpow Manage. 1991;17(1):15-23. Not eligible target population. [pmid: 10114956].
782 Dawson D. Development of a new eye care guideline for critically ill patients. Intensive Crit Care Nurs. Apr. 2005;21(2):119-122. Not eligible target population. [pmid: 15778076].
783 Day GR. Is there a relationship between 12-hour shifts and job satisfaction in nurses?. Alabama Nurse. Jun–Aug. 2004;31(2):11-2. Not peer reviewed. [pmid: 15524121].
784 Day T, Wainwright SP, Wilson-Barnett J. An evaluation of a teaching intervention to improve the practice of endotracheal suctioning in intensive care units. J Clin Nurs. Sep. 2001;10(5):682-696. Not eligible target population. [pmid: 11822519].
785 Daynard D, Yassi A, Cooper JE, Tate R, Norman R, Wells R. Biomechanical analysis of peak and cumulative spinal loads during simulated patient-handling activities: a substudy of a randomized controlled trial to prevent lift and transfer injury of health care workers. Appl Ergon. Jun. 2001;32(3):199-214. Not eligible exposure. [pmid: 11394461].
786 De Groot HA, Burke LJ, George VM. Implementing the differentiated pay structure model. Process and outcomes. J Nurs Adm. May. 1998;28(5):28-38. Not eligible exposure. [pmid: 9601491].
787 de Keizer NF, Bonsel GJ, Al MJ, Gemke RJ. The relation between TISS and real paediatric ICU costs: a case study with generalizable methodology. Intensive Care Med. Oct. 1998;24(10):1062-1069. Not eligible target population. [pmid: 9840241].
788 De La Cour J. Suicide in the ward setting. Nurs Times. Oct 5–11. 2000;96(40):39-40. Not eligible target population. [pmid: 11968643].
789 de Lima RA, Rocha SM, Scochi CG, Callery P. Involvement and fragmentation: a study of parental care of hospitalized children in Brazil. Pediatr Nurs. Nov–Dec 2001;27(6):559–564, 580. Not eligible target population.
790 de Lusignan S, Wells S, Russell C. A model for patient-centred nurse consulting in primary care. Br J Nurs. Jan 23–Feb 12. 2003;12(2):85-90. Not eligible target population. [pmid: 12574712].
791 de Lusignan S, Wells SE, Russell C, Bevington WP, Arrowsmith P. Development of an assessment tool to measure the influence of clinical software on the delivery of high quality consultations. A study comparing two computerized medical record systems in a nurse run heart clinic in a general practice setting. Med Inform Internet Med. Dec. 2002;27(4):267-280. Not eligible target population. [pmid: 12745907].
792 de Rond M, de Wit R, van Dam F. The implementation of a Pain Monitoring Programme for nurses in daily clinical practice: results of a follow-up study in five hospitals. J Adv Nurs. Aug. 2001;35(4):590-598. Not eligible target population. [pmid: 11529959].
793 de Rond ME, de Wit R, van Dam FS, Muller MJ. A Pain Monitoring Program for nurses: effect on the administration of analgesics. Pain. Dec 15. 2000;89(1):25-38. Not eligible target population. [pmid: 11113290].
794 de Ruyter A. Casual work in nursing and other clinical professions: evidence from Australia. J Nurs Manag. Jan. 2004;12(1):62-68. Not eligible target population. [pmid: 15101457].
795 de Vries K, Sque M, Bryan K, Abu-Saad H. Variant Creutzfeldt-Jakob disease: need for mental health and palliative care team collaboration. Int J Palliat Nurs. Dec. 2003;9(12):512-520. Not eligible target population. [pmid: 14765007].
796 Dean KA. Negligent patient abandonment. Fla Nurse. Sep. 2003;51(3):15. Legal Cases. [pmid: 14560518].
797 Dearholt SL, Feathers CA. Self-scheduling can work. Nurs Manage. Aug. 1997;28(8):47-48. No association tested. [pmid: 9325955].
798 Dechairo-Marino AE, Jordan-Marsh M, Traiger G, Saulo M. Nurse/physician collaboration: action research and the lessons learned. J Nurs Adm. May. 2001;31(5):223-232. Not eligible outcomes. [pmid: 11388158].
799 Dechant GM. Self-scheduling for nursing staff. AARN News Lett. May. 1990;46(5):4-8. No association tested. [pmid: 2356696].
800 Decter MB. Canadian hospitals in transformation. Med Care. Oct. 1997;35(10 Suppl):OS70-75. Not eligible target population. [pmid: 9339778].
801 Deitzer D, Wessell J, Myles K, et al. Agency nurses: the right solution to staffing problems?. Journal of Long-Term Care Administration. Fall. 1992;20(3):29-33. Nursing home. [pmid: 10122533].
802 DeMoro D. Market value & real values: industry's choice in implementing ratios. Revolution. Jan–Feb. 2004;5(1):27-29. Comment. [pmid: 15052957].
803 DeMoss C, McGrail M Jr, Haus E, Crain AL, Asche SE. Health and performance factors in health care shift workers. J Occup Environ Med. Dec. 2004;46(12):1278-1281. Not eligible outcomes. [pmid: 15591980].
804 Dennis S. The Tredgold model of nursing. J Adv Nurs. Apr. 1998;27(4):825-828. Not eligible target population. [pmid: 9578214].
805 Denyes MJ, Neuman BM, Villarruel AM. Nursing actions to prevent and alleviate pain in hospitalized children. Issues Compr Pediatr Nurs. Jan–Mar. 1991;14(1):31-48. Not eligible outcomes. [pmid: 1810913].
806 Devadas D. Short-changed?. Nurs Times. Sep 13–19. 2001;97(37):27. Comment. [pmid: 11935867].
807 Devanney JJ. Testing the limits: shift rotation and the ADA. Nurs Manage. Mar. 1999;30(3):35-37. Legal Cases. [pmid: 10188530].
808 Devine J. Opportunity afforded by junior doctors' hours being reduced. Nurs Stand. Jul 10–16. 1991;5(42):43. Not eligible target population. [pmid: 1908275].
809 Devins GM, Paul LC, Barre PE, Mandin H, Taub K, Binik YM. Convergence of health ratings across nephrologists, nurses, and patients with end-stage renal disease. J Clin Epidemiol. Apr. 2003;56(4):326-331. Not eligible exposure. [pmid: 12767409].
810 Dewsall J, King K. Children's nurse and service manager in acute paediatrics. Interview by Loretta Loach. Nurs Times. Nov 26–Dec 2. 1997;93(48):40-41. Interview. [pmid: 9423480].
811 Dexter F, Epstein RH, Marcon E, de Matta R. Strategies to reduce delays in admission into a postanesthesia care unit from operating rooms. J Perianesth Nurs. Apr. 2005;20(2):92-102. Review. [pmid: 15806526].
812 Dexter F, Rittenmeyer H. Quantification of phase I postanesthesia nursing activities in the phase II postanesthesia care unit. Nurs Outlook. Mar–Apr. 1997;45(2):86-88. Not eligible exposure. [pmid: 9127349].
813 Diba VC, Chowdhury MM, Adisesh A, Statham BN. Occupational allergic contact dermatitis in hospital workers caused by methyldibromo glutaronitrile in a work soap. Contact Dermatitis. Feb. 2003;48(2):118-119. Not eligible target population. [pmid: 12694221].
814 Dickens GL, Stubbs JH, Haw CM. Smoking and mental health nurses: a survey of clinical staff in a psychiatric hospital. J Psychiatr Ment Health Nurs. Aug. 2004;11(4):445-451. Not eligible target population. [pmid: 15255919].
815 Dickenson-Hazard N. Every nurse is a leader. Nursing. Nov. 2000;30(11):8. Editorial. [pmid: 11111648].
816 Dickie H, Vedio A, Dundas R, Treacher DF, Leach RM. Relationship between TISS and ICU cost. Intensive Care Med. Oct. 1998;24(10):1009-1017. Not eligible target population. [pmid: 9840233].
817 Dickson J. Casualisation crisis. Nurs N Z. Jul. 1993;1(4):12-14. Not eligible target population. [pmid: 8343817].
818 Dickson M, King MC. The effect of child care proximity on maternal reports of separation anxiety in employed nurses. Pediatric nursing. Jan–Feb. 1992;18(1):64-6. Not relevant. [pmid: 1542527].
819 Didovich K. Working year. Nurs Stand. Feb 26. 1997;11(23):28. Not eligible target population.
820 Diehl-Oplinger L, Kaminski MF. Need critical care nurses? Inquire within. Nurs Manage. Mar. 2000;31(3):44-46. Comment. [pmid: 10827721].
821 DiFrancesco M, Andrews T. Alamance Regional Medical Center improves patient safety with CPOE. J Healthc Inf Manag. Winter. 2004;18(1):18-23. Not eligible exposure. [pmid: 14971075].
822 DiIorio C, Manteuffel B. Preferences concerning epilepsy education: opinions of nurses, physicians, and persons with epilepsy. J Neurosci Nurs. Feb. 1995;27(1):29-34. Not eligible exposure. [pmid: 7769325].
823 Dijkers M, Paradise T. PCS: one system for both staffing and costing. Nurs Manage. Jan. 1986;17(1):25-34. Not eligible year. [pmid: 3632821].
824 DiMeglio K, Padula C, Piatek C, Korber S, Barrett A, Ducharme M, Lucas S, Piermont N, Joyal E, DeNicola V, Corry K. Group cohesion and nurse satisfaction: examination of a team-building approach. J Nurs Adm. Mar. 2005;35(3):110-120. Not eligible outcomes. [pmid: 15761307].
825 Dimond B, Dilemma. Linda was a nurse working on night duty and concerned about staffing levels. Accid Emerg Nurs. Jul. 1998;6(3):172-174. Not eligible target population. [pmid: 9887696].
826 Dimond B. Confidentiality. 9: The law relating to whistle blowing. Br J Nurs. Oct 28–Nov 10. 1999;8(19):1322-1323. Not eligible target population. [pmid: 10887811].
827 Dingley J. A computer-aided comparative study of progressive alertness changes in nurses working two different night-shift rotas. J Adv Nurs. Jun. 1996;23(6):1247-1253. Not eligible target population. [pmid: 8796475].
828 Dingman SK, Williams M, Fosbinder D, Warnick M. Implementing a caring model to improve patient satisfaction. J Nurs Adm. Dec. 1999;29(12):30-37. Not eligible exposure. [pmid: 10608938].
829 Dinsdale P. Post haste. Nurs Times. Mar 11–17. 1998;94(10):14. Not eligible target population. [pmid: 9735760].
830 Dinsdale P. The more, the better. Nurs Stand. Jul 7–13. 2004;18(43):12-13. Not eligible target population. [pmid: 15318643].
831 Discher CL, Klein D, Pierce L, Levine AB, Levine TB. Heart failure disease management: impact on hospital care, length of stay, and reimbursement. Congest Heart Fail. Mar–Apr. 2003;9(2):77-83. Not eligible exposure. [pmid: 12671338].
832 Disomma C, Wilkerson S. Staff roles. All of the people most of the time. Health Serv J. Jul 13. 1995;105(5461):28-29. Not eligible target population. [pmid: 10144640].
833 Dixon L. Pre-admission clinic in an ENT unit. Nurs Stand. Mar 23–29. 1994;8(26):23-26. Comment. [pmid: 8180054].
834 Dodd-McCue D, Tartaglia A, Myer K, Kuthy S, Faulkner K. Unintended consequences: the impact of protocol change on critical care nurses' perceptions of stress. Prog Transplant. Mar. 2004;14(1):61-67. Not eligible exposure. [pmid: 15077740].
835 Dodd-McCue D, Tartaglia A, Veazey KW, Streetman PS. The impact of protocol on nurses' role stress: a longitudinal perspective. J Nurs Adm. Apr. 2005;35(4):205-216. Not eligible exposure. [pmid: 15834260].
836 Dodge JA. Patient-centred cystic fibrosis services. J R Soc Med. 2005;98(Suppl 45):2-6. Not eligible target population. [pmid: 16025762]. [pmcid: 1308803].
837 Dogan O, Ertekin S, Dogan S. Sleep quality in hospitalized patients. J Clin Nurs. Jan. 2005;14(1):107-113. Not eligible target population. [pmid: 15656855].
838 Doman M, Prowse M, Webb C. Exploring nurses' experiences of providing high dependency care in children's wards. J Child Health Care. Sep. 2004;8(3):180-197. Not eligible target population. [pmid: 15358884].
839 Donadio G. Improving healthcare delivery with the transformational whole person care model. Holist Nurs Pract. Mar–Apr. 2005;19(2):74-77. Not eligible exposure. [pmid: 15871590].
840 Donlevy JA, Pietruch BL. The connection delivery model: care across the continuum. Nurs Manage. May. 1996;27(5):34-36. No association tested. [pmid: 8710342].
841 Donoghue J, Decker V, Mitten-Lewis S, Blay N. Critical care dependency tool: monitoring the changes. Aust Crit Care. May. 2001;14(2):56-63. Not eligible target population. [pmid: 11899442].
842 Donovan JL, Peters TJ, Noble S, Powell P, Gillatt D, Oliver SE, Lane JA, Neal DE, Hamdy FC. Who can best recruit to randomized trials? Randomized trial comparing surgeons and nurses recruiting patients to a trial of treatments for localized prostate cancer (the ProtecT study). J Clin Epidemiol. Jul. 2003;56(7):605-609. Not eligible target population. [pmid: 12921927].
843 Doreen F, Robinson C. “Magnet” status as markers of healthy work environments. Interview by Joanne Disch. Creat Nurs. 2002;8(2):4-6. Interview. [pmid: 12154696].
844 Dorsey G, Borneo HT, Sun SJ, Wells J, Steele L, Howland K, Perdreau-Remington F, Bangsberg DR. A heterogeneous outbreak of Enterobacter cloacae and Serratia marcescens infections in a surgical intensive care unit. Infect Control Hosp Epidemiol. Jul. 2000;21(7):465-469. Not eligible exposure. [pmid: 10926397].
845 Doucette JN. Serving up uncommon service. Nurs Manage. Nov. 2003;34(11):26-30. Review. [pmid: 14671446].
846 Dougan M, Lanigan C, Szalapski J. Meeting supplemental staffing needs: an in-house approach. Nurs Econ. Mar–Apr 1991;9(2):128–130, 132. Not eligible outcomes.
847 Douglas DA, Mayewski J. Census variation staffing. Nurs Manage. Feb 1996;27(2):32–33, 36. Not eligible outcomes.
848 Dowding D. Examining the effects that manipulating information given in the change of shift report has on nurses' care planning ability. J Adv Nurs. Mar. 2001;33(6):836-846. Not eligible target population. [pmid: 11298222].
849 Doyle KA, Maslin-Prothero S. Promoting children's rights: the role of the children's nurse. Paediatr Nurs. Oct. 1999;11(8):23-25. Not eligible target population. [pmid: 10723368].
850 Dracup K, Bryan-Brown CW. One solution to poor staffing ratios. Am J Crit Care. Mar. 2001;10(2):71-73. Editorial. [pmid: 11244673].
851 Drennan V. The more things change. Nurs Times. Sep 27–Oct 3. 2001;97(39):25. Not eligible target population. [pmid: 11935765].
852 Drew JA. If you don't know where you're going, anywhere you end up is OK. GHA Today. Jul. 2001;45(7):2. Comment.
853 Driedger L. The other side of the bed. Can Nurse. Feb. 2000;96(2):49-50. Case Reports. [pmid: 11188579].
854 Duchene P. Deliver empowered care. Nurs Manage. Nov. 2002;33(11):11. Comment. [pmid: 12441867].
855 Duchene P. Staff ratios: just about numbers?. Nurs Manage. Jul. 2002;33(7):10. Comment. [pmid: 12163762].
856 Duckett R. Night nursing. Thirst for knowledge. Nurs Times. Sep 1–7. 1993;89(35):29-31. Comment. [pmid: 8139956].
857 Duffin C. US survey finds link between patient recovery and nurse numbers. Nurs Manag (Harrow). Jun. 2000;7(3):4. News. [pmid: 12004414].
858 Duffin C. Waiting in vain. Nurs Stand. Jan 10–16. 2001;15(17):12. Comment.
859 Duffy D. Out of the shadows: a study of the special observation of suicidal psychiatric in-patients. J Adv Nurs. May. 1995;21(5):944-950. Not eligible target population. [pmid: 7602003].
860 Dugger B. Introducing products to prevent needlesticks. Nurs Manage. Oct. 1992;23(10):62-66. Not eligible exposure. [pmid: 1306655].
861 Dumais MM. Use error: a nurse's perspective. Biomed Instrum Technol. Jul–Aug. 2004;38(4):313-315. Comment. [pmid: 15338839].
862 Dummett S. Avoiding drug administration errors: the way forward. Nurs Times. Jul 29–Aug 4. 1998;94(30):58-60. Not eligible target population. [pmid: 9749054].
863 Dumont M, Montplaisir J, InfanteRivard C. Sleep quality of former night-shift workers... XIIth International Symposium on Night and Shiftwork. Foxwoods symposium series, June 1995. International Journal of Occupational and Environmental Health Jul–Sep 1997;3(3): Suppl):S10–4. Conference abstract.
864 Dumont R, van der Loo R, van Merode F, Tange H. User needs and demands of a computer-based patient record. Medinfo. 1998;9(Pt 1):64-69. Not eligible target population. [pmid: 10384421].
865 Duncan K, Pozehl B. Effects of performance feedback on patient pain outcomes. Clin Nurs Res. Nov. 2000;9(4):379-397. discussion 398–401. Not eligible outcomes. [pmid: 11881696].
866 Duncan SM, Hyndman K, Estabrooks CA, et al. Nurses' experience of violence in Alberta and British Columbia hospitals. Canadian Journal of Nursing Research. Mar. 2001;32(4):57-78. Not relevant. [pmid: 11928302].
867 Dunn L. Job sharing—the way forward?. Nurs Stand. Sep 5–11. 1990;4(50):32-36. Not eligible target population. [pmid: 2119762].
868 Dunton N, Gajewski B, Taunton RL, et al. Nurse staffing and patient falls on acute care hospital units. Nursing outlook. Jan–Feb. 2004;52(1):53-9. Not relevant. [pmid: 15014380].
869 Durham S. The phone call that changed my life. Interview by Mary Hampshire. Nurs Stand. May 17–23. 2000;14(35):18-19. Interview. [pmid: 11973981].
870 Duxbury J. Avoiding disturbed sleep in hospitals. Nurs Stand. Nov 30–Dec 6. 1994;9(10):31-34. Not eligible outcomes. [pmid: 7833239].
871 Duxbury J. Night nurses: why are they undervalued?. Nurs Stand. Dec 7–13. 1994;9(11):33-36. No association tested. [pmid: 7999539].
872 Duxbury M, Brown C, Lambert A. Surgical gloves. How do you change yours?. Br J Perioper Nurs. Jan. 2003;13(1):17-20. Not eligible exposure. [pmid: 12593055].
873 Dykes F. A critical ethnographic study of encounters between midwives and breast-feeding women in postnatal wards in England. Midwifery. Sep. 2005;21(3):241-252. Not eligible target population. [pmid: 15967551].
874 Dzendrowskyj P, Shaw G, Johnston L. Effects of nursing industrial action on relatives of Intensive Care Unit patients: a 16-month follow-up. N Z Med J. Nov 5. 2004;117(1205):U1150. Not eligible target population. [pmid: 15570333].
875 Eagle DJ, Salama S, Whitman D, Evans LA, Ho E, Olde J. Comparison of three instruments in predicting accidental falls in selected inpatients in a general teaching hospital. J Gerontol Nurs. Jul. 1999;25(7):40-45. Not eligible exposure. [pmid: 10476130].
876 Eastaugh SR. Hospital nursing technical efficiency: nurse extenders and enhanced productivity. Hosp Health Serv Adm. Winter. 1990;35(4):561-573. Not eligible outcomes. [pmid: 10107387].
877 Eastaugh SR. Hospital nurse productivity. J Health Care Finance. Fall. 2002;29(1):14-22. Not eligible outcomes. [pmid: 12199492].
878 Eastman M. Staff mix and public safety. Nurs BC. Oct. 2004;36(4):5. Letter. [pmid: 15552172].
879 Edel EM. A perioperative patient acuity system: planning and design. Nurs Manage. May. 1995;26(5):48N-48P. Comment.
880 Edvardsson JD, Sandman PO, Rasmussen BH. Meanings of giving touch in the care of older patients: becoming a valuable person and professional. J Clin Nurs. Jul. 2003;12(4):601-609. Not eligible target population. [pmid: 12790874].
881 Edwards DF. The Synergy Model: linking patient needs to nurse competencies. Crit Care Nurse. Feb 1999;19(1):88–90, 97–89. Case Reports.
882 Edwards N. The implications of day surgery for in-patient hospital wards. Nurs Times. Sep 11–17. 1996;92(37):32-34. Not eligible exposure.
883 Edwards SD. Are nursing's ‘extraordinary’ moral standards realistic?. Nurs Times. Oct 23–29. 1996;92(43):34-35. Comment. [pmid: 8932187].
884 Efraimsson E, Sandman PO, Hyden LC, Rasmussen BH. Discharge planning: “fooling ourselves?”—patient participation in conferences. J Clin Nurs. Jul. 2004;13(5):562-570. Not eligible target population. [pmid: 15189409].
885 Eischens MJ, Elliott BA, Elliott TE. Two hospice quality of life surveys: a comparison. Am J Hosp Palliat Care. May–Jun. 1998;15(3):143-148. Not eligible target population. [pmid: 9729959].
886 Elder R, Neal C, Davis BA, Almes E, Whitledge L, Littlepage N. Patient satisfaction with triage nursing in a rural hospital emergency department. J Nurs Care Qual. Jul–Sep. 2004;19(3):263-268. Not eligible exposure. [pmid: 15326996].
887 Ellefsen B, Kim HS. Nurses' construction of clinical situations: a study conducted in an acute-care setting in Norway. Can J Nurs Res. Jun. 2004;36(2):114-131. Not eligible target population. [pmid: 15369169].
888 Ellett ML, Lou Q, Chong SK. Prevalence of immunoglobulin G to Helicobacter pylori among endoscopy nurses/technicians. Gastroenterol Nurs. Jan–Feb. 1999;22(1):3-6. Not eligible outcomes. [pmid: 10222917].
889 Ellila H, Sourander A, Valimaki M, Piha J. Characteristics and staff resources of child and adolescent psychiatric hospital wards in Finland. J Psychiatr Ment Health Nurs. Apr. 2005;12(2):209-214. Not eligible target population. [pmid: 15788039].
890 Ellis J. Overtime and fatigue. To stay or not to stay. Nurs BC. Jun. 2001;33(3):32-33. Comment. [pmid: 12152569].
891 Ellis J, Etheridge G, Buckley J. Improving the ward environment through observation of care. Nurs Times. Nov 16–22. 2004;100(46):36-38. Not eligible target population.
892 Ellis JM. Barriers to effective screening for domestic violence by registered nurses in the emergency department. Crit Care Nurs Q. May. 1999;22(1):27-41. Not eligible exposure. [pmid: 10646461].
893 Ellis S. The patient-centred care model: holistic/multiprofessional/reflective. Br J Nurs. Mar 11–24. 1999;8(5):296-301. Not eligible target population. [pmid: 10362931].
894 Ellis S. More on mandatory overtime and wearing blue ribbons. J Emerg Nurs. Feb. 2001;27(1):9-10. Letter. [pmid: 11174259].
895 Endacott R, Chellel A. Nursing dependency scoring: measuring the total workload. Nurs Stand. Jun 5. 1996;10(37):39-42. Not eligible target population. [pmid: 8716976].
896 Endacott R, Dawson D. Clinical decisions made by nurses in intensive care—results of a telephone survey. Nurs Crit Care. Jul–Aug. 1997;2(4):191-196. Not eligible target population. [pmid: 9873322].
897 Engler AJ, Cusson RM, Brockett RT, Cannon-Heinrich C, Goldberg MA, West MG, Petow W. Neonatal staff and advanced practice nurses' perceptions of bereavement/end-of-life care of families of critically ill and/or dying infants. Am J Crit Care. Nov. 2004;13(6):489-498. Not eligible exposure. [pmid: 15568654].
898 Enmon P, Demetropoulos S. Bringing talk to the table. Nurs Manage. Mar. 2004;35(3):50-52. Not eligible exposure. [pmid: 15021804].
899 Erickson JI, Hamilton GA, Jones DE, Ditomassi M. The value of collaborative governance/staff empowerment. J Nurs Adm. Feb. 2003;33(2):96-104. Not eligible exposure. [pmid: 12584462].
900 Erickson ST. Mother's Hours: “extra” RNs balance the workload. Nurs Manage. Sep 1991;22(9):45–46, 48. No association tested.
901 Erlen JA, Sereika SM. Critical care nurses, ethical decision-making and stress. J Adv Nurs. Nov. 1997;26(5):953-961. Not eligible exposure. [pmid: 9372400].
902 Ermer GR, McEleney BJ, West IJ. An oral history of the “joint” nursing experience at Landstuhl Regional Medical Center. Mil Med. Feb. 2000;165(2):131-134. Not eligible target population. [pmid: 10709375].
903 Eschiti VS. Planting seeds at Esalen: collaborative relationships in holistic healthcare. Beginnings. Summer. 2005;25(3):3-17. Comment. [pmid: 16018301].
904 Escriba-Aguir V. Nurses' attitudes towards shiftwork and quality of life. Scand J Soc Med. Jun. 1992;20(2):115-118. Not eligible target population. [pmid: 1496330].
905 Esposito L. Blizzard forces nursing home evacuation. Nurs Spectr (Wash D C). Jan 16. 1996;6(2):6. Not eligible target population.
906 Estabrooks CA, Tourangeau AE, Humphrey CK, Hesketh KL, Giovannetti P, Thomson D, Wong J, Acorn S, Clarke H, Shamian J. Measuring the hospital practice environment: a Canadian context. Res Nurs Health. Aug. 2002;25(4):256-268. Not eligible outcomes. [pmid: 12124720].
907 Estryn-Behar M, Vinck L, Caillard JF. Work schedules in health care in France: very few changes between 1991 and 1998, according to national data. J Hum Ergol (Tokyo). Dec. 2001;30(12):327-332. Not eligible target population. [pmid: 14564903].
908 Eubanks P. New act may limit recruitment of foreign nurses. Hospitals. Feb 5. 1990;64(3):67. Comment. [pmid: 2298429].
909 Evans J, Doswell N. Cross currents. Interview by Dina Leifer. Nurs Stand. Aug 15–21. 2001;15(48):16. Interview. [pmid: 12296276].
910 Evans M. Putting a price on care. Low nurse-to-patient ratios save lives but are costly: study. Mod Healthc. Aug 8. 2005;35(32):14. News.
911 Evans M. Will work for visa. Bill would boost visas for skilled workers. Mod Healthc. Jan 10. 2005;35(2):16. News.
912 Evans ML, Martin ML, Winslow EH. Nursing care and patient satisfaction. Am J Nurs. Dec. 1998;98(12):57-59. No association tested. [pmid: 9875184].
913 Evans SK, Laundon T, Yamamoto WG. Projecting staffing requirements for intensive care units. J Nurs Adm. Jul. 1980;10(7):34-42. Not eligible year. [pmid: 6902761].
914 Eve M. Low staffing levels leave little time for care. Crit Care Nurse. Aug. 2001;21(4):20. Comment. [pmid: 11858684].
915 Ewens A, Richards J. Concepts of health: implications for public health work. Br J Community Nurs. Aug. 2000;5(8):404-408. Not eligible target population. [pmid: 12271235].
916 Facchinetti NJ, Campbell GM, Jones DP. Evaluating dispensing error detection rates in a hospital pharmacy. Med Care. Jan. 1999;37(1):39-43. Not eligible exposure. [pmid: 10413391].
917 Fagerstrom L, Engberg IB, Eriksson K. A comparison between patients' experiences of how their caring needs have been met and the nurses' patient classification—an explorative study. J Nurs Manag. Nov. 1998;6(6):369-377. Not eligible target population. [pmid: 10076270].
918 Fahs MC, Fulop G, Strain J, Sacks HS, Muller C, Cleary PD, Schmeidler J, Turner B. The inpatient AIDS unit: a preliminary empirical investigation of access, economic, and outcome issues. Am J Public Health. Apr. 1992;82(4):576-578. Not eligible exposure. [pmid: 1546777]. [pmcid: 1694095].
919 Fairburn K. Nurses' attitudes to visiting in coronary care units. Intensive Crit Care Nurs. Sep. 1994;10(3):224-233. Not eligible outcomes. [pmid: 7803974].
920 Falk-Rafael AR. Empowerment as a process of evolving consciousness: a model of empowered caring. ANS Adv Nurs Sci. Sep. 2001;24(1):1-16. Not eligible exposure. [pmid: 11554530].
921 Fanello S, Jousset N, Roquelaure Y, Chotard-Frampas V, Delbos V. Evaluation of a training program for the prevention of lower back pain among hospital employees. Nurs Health Sci. Mar–Jun. 2002;4(12):51-54. Not eligible outcomes. [pmid: 12084021].
922 Fargen J, Richards T, Kirchhoff K, et al. Mandatory overtime: a survey of registered nurses. Stat Bulletin. Nov. 2001;70(11):4-5. Not peer reviewed.
923 Farnham JA, Maez-Rauzi V, Conway K. Balancing assignments: a PCS for a step-down unit. Nurs Manage. Mar 1992;23(3):49–50, 52. Not eligible exposure.
924 Farr BM. Understaffing: a risk factor for infection in the era of downsizing?. Infect Control Hosp Epidemiol. Mar. 1996;17(3):147-149. Comment. [pmid: 8708351].
925 Farrell C, Heaven C, Beaver K, Maguire P. Identifying the concerns of women undergoing chemotherapy. Patient Educ Couns. Jan. 2005;56(1):72-77. Not eligible target population. [pmid: 15590225].
926 Farrell GA. How accurately do nurses perceive patients' needs? A comparison of general and psychiatric settings. J Adv Nurs. Sep. 1991;16(9):1062-1070. Not eligible target population. [pmid: 1939919].
927 Farrington M, Trundle C, Redpath C, Anderson L. Effects on nursing workload of different methicillin-resistant Staphylococcus aureus (MRSA) control strategies. J Hosp Infect. Oct. 2000;46(2):118-122. Not eligible target population. [pmid: 11049704].
928 Farwell B. Health care in America: an intimate glimpse. Ann Intern Med. Dec 15. 1996;125(12):1005-1006. Comment. [pmid: 8967689].
929 Feddersen E, Lockwood DH. An inpatient diabetes educator's impact on length of hospital stay. Diabetes Educ. Mar–Apr. 1994;20(2):125-128. Not eligible exposure. [pmid: 7851225].
930 Feldberg C. Labor law: no minimum wage for nurses' off-premises, on-call hours. J Law Med Ethics. Fall–Winter. 2001;29(34):413-414. Legal Cases. [pmid: 12056383].
931 Feldstein MA, Gemma PB. Oncology nurses and chronic compounded grief. Cancer Nurs. Jun. 1995;18(3):228-236. Not eligible outcomes. [pmid: 7600555].
932 Feng JY, Wu YW. Nurses' intention to report child abuse in Taiwan: a test of the theory of planned behavior. Res Nurs Health. Aug. 2005;28(4):337-347. Not eligible target population. [pmid: 16028263].
933 Ferguson TB Jr. Continuous quality improvement in medicine: validation of a potential role for medical specialty societies. Am Heart Hosp J. Fall. 2003;1(4):264-272. Not eligible exposure. [pmid: 15815120].
934 Fermin P, Mjolsness E, McLeay J, Chisholm L. An innovative approach to maintaining critical skills. Nurs Manage. Jan. 1991;22(1):64A-64C. No association tested.
935 Ferns T. The nature and causes of violent incidents in intensive-care settings. Prof Nurse. Dec. 2002;18(4):207-210. Not eligible target population. [pmid: 12518614].
936 Fernsebner B, Beyea S. Survey provides a snapshot of staffing challenges in the OR. OR Manager. Jun 2001;17(6):1, 10–13. Not eligible outcomes.
937 Ferrante A. The nursing shortage crisis in Quebec's McGill University affiliated teaching hospitals: strategies that can work. Can J Nurs Adm. Sep–Oct. 1993;6(3):26-31. No association tested. [pmid: 8312298].
938 Fetzer SJ. Seeing with new eyes. J Perianesth Nurs. Dec. 2003;18(6):377-379. Editorial. [pmid: 14730518].
939 Feutz SA. How to cope with under staffing. Nursing. Aug. 1991;21(8):54-55. Comment. [pmid: 1870778].
940 Field PA, Renfrew M. Teaching and support: nursing input in the postpartum period. Int J Nurs Stud. 1991;28(2):131-144. Not eligible outcomes. [pmid: 1894461].
941 Fiesseler F, Szucs P, Kec R, Richman PB. Can nurses appropriately interpret the Ottawa Ankle Rule?. Am J Emerg Med. May. 2004;22(3):145-148. Not eligible exposure. [pmid: 15138947].
942 Fiesta J. The nursing shortage: whose liability problem? Part II. Nurs Manage. Feb. 1990;21(2):22-23. Comment.
943 Fiesta J. Staffing implications: a legal update. Nurs Manage. Jun. 1994;25(6):34-35. Comment. [pmid: 8004423].
944 Filipovich CC. Teach nurses effective ways to deal with inadequate staffing. Nurs Manage. Dec. 1999;30(12):38. Comment. [pmid: 10818925].
945 Findlay J. Shifting time. Nurs Times. Jan 12–18. 1994;90(2):42-44. Comment. [pmid: 8302647].
946 Findlay J, Stewart L, Kettles A. Flexible working. Good timing. Health Serv J. Jul 13. 1995;105(5461):30. Not eligible target population. [pmid: 10144641].
947 Fine JM, Fine MJ, Galusha D, Petrillo M, Meehan TP. Patient and hospital characteristics associated with recommended processes of care for elderly patients hospitalized with pneumonia: results from the medicare quality indicator system pneumonia module. Arch Intern Med. Apr 8. 2002;162(7):827-833. Not eligible outcomes. [pmid: 11926859].
948 Fine MJ, Orloff JJ, Rihs JD, Vickers RM, Kominos S, Kapoor WN, Arena VC, Yu VL. Evaluation of housestaff physicians' preparation and interpretation of sputum Gram stains for community-acquired pneumonia. J Gen Intern Med. May–Jun. 1991;6(3):189-198. Not eligible exposure. [pmid: 1712384].
949 Fink JL. Emma & the med error. J Christ Nurs. Spring 2000;17(2):26–27, 29. Comment.
950 Fink R, Thompson CJ, Bonnes D. Overcoming barriers and promoting the use of research in practice. J Nurs Adm. Mar. 2005;35(3):121-129. Not eligible exposure. [pmid: 15761309].
951 Finn T, King J, Thorburn J. The educational needs of part time clinical facilitators. Contemporary Nurse. Jun. 2000;9(2):132-9. Not relevant. [pmid: 11855001].
952 Finnema EJ, Louwerens JW, Slooff CJ, van den Bosch RJ. Expressed emotion on long-stay wards. J Adv Nurs. Sep. 1996;24(3):473-478. Not eligible target population. [pmid: 8876406].
953 Firn S. No sex, please. Nurs Times. Apr 6–12. 1994;90(14):57. Comment. [pmid: 8183694].
954 Fischer JE, Calame A, Dettling AC, Zeier H, Fanconi S. Objectifying psychomental stress in the workplace—an example. Int Arch Occup Environ Health. Jun. 2000;73(Suppl):S46-52. Not eligible target population. [pmid: 10968561].
955 Fisher ML, Hinson N, Deets C. Selected predictors of registered nurses' intent to stay. J Adv Nurs. Nov. 1994;20(5):950-957. Not eligible exposure. [pmid: 7745189].
956 Fisk J, Arcona S. Tympanic membrane vs. pulmonary artery thermometry. Nurs Manage. Jun 2001;32(6):42, 45–48. Not eligible exposure.
957 Fitch JA, Munro CL, Glass CA, Pellegrini JM. Oral care in the adult intensive care unit. Am J Crit Care. Sep. 1999;8(5):314-318. Not eligible exposure. [pmid: 10467468].
958 FitzGerald EL. The possible dream. Revolution. Jan–Feb. 2000;1(1):22-27. Comment. [pmid: 11209341].
959 Fitzpatrick F, Murphy OM, Brady A, Prout S, Fenelon LE. A purpose built MRSA cohort unit. J Hosp Infect. Dec. 2000;46(4):271-279. Not eligible target population. [pmid: 11170758].
960 Fitzpatrick JJ, Salinas TK, O'Connor LJ, Stier L, Callahan B, Smith T, White MT. Nursing care quality initiative for care of hospitalized elders and their families. J Nurs Care Qual. Apr–Jun. 2004;19(2):156-161. Not eligible exposure. [pmid: 15077833].
961 Fitzpatrick JJ, Stier L, Eichorn A, Dlugacz YD, O'Connor LJ, Salinas TK, Smith T, White MT. Hospitalized elders: changes in functional and mental status. Outcomes Manag. Jan–Mar. 2004;8(1):52-56. Not eligible outcomes. [pmid: 14740585].
962 Fitzpatrick JM, While AE, Roberts JD. Shift work and its impact upon nurse performance: current knowledge and research issues. J Adv Nurs. Jan. 1999;29(1):18-27. Not eligible target population. [pmid: 10064278].
963 Fitzpatrick MA. The numbers game, again?. Nurs Manage. Apr. 2002;33(4):6. Editorial.
964 Flaherty MJ. Insubordination—patient load. NLN Publ. Jun 1990(20–2294):318–326. Not eligible exposure.
965 Flannelly LT, Flannelly KJ, Cox. Evaluating improvements in nursing staff at a state psychiatric hospital. Issues in Mental Health Nursing. Sep. 2001;22(6):621-32. Not relevant. [pmid: 11881519].
966 Fletcher CE. Failure mode and effects analysis. An interdisciplinary way to analyze and reduce medication errors. J Nurs Adm. Dec. 1997;27(12):19-26. Not eligible exposure. [pmid: 9418753].
967 Fletcher CE. Hospital RNs' job satisfactions and dissatisfactions. J Nurs Adm. Jun. 2001;31(6):324-331. No association tested. [pmid: 11417172].
968 Fletcher E, Stevenson C. Launching the Tidal Model in an adult mental health programme. Nurs Stand. Aug 22–28. 2001;15(49):33-36. Not eligible target population. [pmid: 12214392].
969 Fletcher M. Inquest produces change. Can Nurse. Nov. 2001;97(10):20. Comment. [pmid: 11765433].
970 Flood D. An Afghan hospital in wartime. Nurses, physicians, and wounded fighters—a photo essay. Am J Nurs. Feb. 2002;102(2):42-45. Not eligible target population. [pmid: 11953518].
971 Flook DJ, Crumplin MK. The efficiency of management of emergency surgery in a district general hospital—a prospective study. Ann R Coll Surg Engl. Jan. 1990;72(1):27-31. Not eligible target population. [pmid: 2301900].
972 Flucker CJ, Hart E, Weisz M, Griffiths R, Ruth M. The 50-millilitre syringe as an inexpensive training aid in the application of cricoid pressure. Eur J Anaesthesiol. Jul. 2000;17(7):443-447. Not eligible target population. [pmid: 10964146].
973 Flynn EA, Barker KN, Pepper GA, Bates DW, Mikeal RL. Comparison of methods for detecting medication errors in 36 hospitals and skilled-nursing facilities. Am J Health Syst Pharm. Mar 1. 2002;59(5):436-446. Not eligible exposure. [pmid: 11887410].
974 Flynn ER, Wolf ZR, McGoldrick TB, Jablonski RA, Dean LM, McKee EP. Effect of three teaching methods on a nursing staff's knowledge of medication error risk reduction strategies. J Nurs Staff Dev. Jan–Feb. 1996;12(1):19-26. Not eligible exposure. [pmid: 8699272].
975 Flynn K. Nursing in Saudi Arabia. Interview by Margaret Atkin. Qld Nurse. Jul–Aug. 1990;9(4):10. Interview. [pmid: 2122487].
976 Flynn L. Agency characteristics most valued by home care nurses: findings of a nationwide study. Home Healthc Nurse. Dec. 2003;21(12):812-817. Not eligible target population. [pmid: 14665968].
977 Flynn L, Aiken LH. Does international nurse recruitment influence practice values in U.S. hospitals?. J Nurs Scholarsh. 2002;34(1):67-73. Not eligible exposure. [pmid: 11901970].
978 Flynn L, Deatrick JA. Home care nurses' descriptions of important agency attributes. J Nurs Scholarsh. 2003;35(4):385-390. Not eligible target population. [pmid: 14735683].
979 Flynn S. Multiple sclerosis: the Treetops model of residential care. Br J Nurs. May 9–22. 2002;11(9):635-642. Not eligible target population. [pmid: 12048478].
980 Fochsen G, Sjogren K, Josephson M, Lagerstrom M. Factors contributing to the decision to leave nursing care: a study among Swedish nursing personnel. J Nurs Manag. Jul. 2005;13(4):338-344. Not eligible target population. [pmid: 15946173].
981 Fogle M. One solution to poor staffing ratios. Am J Crit Care. Jul. 2001;10(4):294. Comment. [pmid: 11432218].
982 Foley BJ, Kee CC, Minick P, Harvey SS, Jennings BM. Characteristics of nurses and hospital work environments that foster satisfaction and clinical expertise. J Nurs Adm. May. 2002;32(5):273-282. Not eligible target population. [pmid: 12021568].
983 Foley DR. Baltimore hospital bucks RN staff reduction trend. Revolution. Spring. 1997;7(1):51-53. Comment. [pmid: 9277294].
984 Foley M. Staffing: the ANA's primary concern. Am J Nurs. Jan. 2001;101(1):88. Comment. [pmid: 11211697].
985 Fondiller SH. Midwest jobfocus. Transplant care: giving patients a new lease on life. Am J Nurs. Mar 1991;91(3):73, 75–76, 78 passim. News.
986 Fontaine K, Rositani R. Cost, quality, and satisfaction with hospice after-hours care. Hosp J. 2000;15(1):1-13. Not eligible target population. [pmid: 11033656].
987 Forbes MA. The practice of professional nurse case management. Nurs Case Manag. Jan–Feb. 1999;4(1):28-33. Not eligible outcomes. [pmid: 10232220].
988 Forchuk C, Gibson D, Best H. Strike contingency planning. Can Nurse. Jan. 1999;95(1):33-37. Comment. [pmid: 10401273].
989 Forchuk C, Westwell J, Martin ML, Azzapardi WB, Kosterewa-Tolman D, Hux M. Factors influencing movement of chronic psychiatric patients from the orientation to the working phase of the nurse-client relationship on an inpatient unit. Perspect Psychiatr Care. Jan–Mar. 1998;34(1):36-44. Not eligible exposure. [pmid: 9847826].
990 Ford K, Turner D. Stories seldom told: paediatric nurses' experiences of caring for hospitalized children with special needs and their families. J Adv Nurs. Feb. 2001;33(3):288-295. Not eligible target population. [pmid: 11251715].
991 Forrester DA. AIDS-related risk factors, medical diagnosis, do-not-resuscitate orders and aggressiveness of nursing care. Nurs Res. Nov–Dec. 1990;39(6):350-354. Not eligible exposure.
992 Forrester DA, McCabe-Bender J, Tiedeken K. Fall risk assessment of hospitalized adults and follow-up study. J Nurses Staff Dev. Nov–Dec. 1999;15(6):251-258. discussion 258–259. Not eligible exposure. [pmid: 10839066].
993 Forrester DA, McCabe-Bender J, Walsh N, Bell-Bowe J. Physical restraint management of hospitalized adults and follow-up study. J Nurses Staff Dev. Nov–Dec. 2000;16(6):267-276. Not eligible exposure. [pmid: 11912819].
994 Forrester DA, Murphy PA. Nurses' attitudes toward patients with AIDS and AIDS-related risk factors. J Adv Nurs. Oct. 1992;17(10):1260-1266. Not eligible exposure. [pmid: 1430630].
995 Fox M. Primary nursing in long-term geriatric units. Can Nurse. Nov. 1992;88(10):29-32. Comment. [pmid: 1490267].
996 Fox ML, Dwyer DJ. An investigation of the effects of time and involvement in the relationship between stressors and work-family conflict. J Occup Health Psychol. Apr. 1999;4(2):164-174. Not eligible exposure. [pmid: 10212868].
997 Foxall MJ, Zimmerman L, Standley R, Bene B. A comparison of frequency and sources of nursing job stress perceived by intensive care, hospice and medical-surgical nurses. J Adv Nurs. May. 1990;15(5):577-584. Not eligible exposure. [pmid: 1694193].
998 Fraenkel DJ, Cowie M, Daley P. Quality benefits of an intensive care clinical information system. Crit Care Med. Jan. 2003;31(1):120-125. Not eligible target population. [pmid: 12545004].
999 France DJ, Miles P, Cartwright J, Patel N, Ford C, Edens C, Whitlock JA. A chemotherapy incident reporting and improvement system. Jt Comm J Qual Saf. Apr. 2003;29(4):171-180. Not eligible exposure. [pmid: 12698807].
1000 Francke AL, Garssen B, Luiken JB, De Schepper AM, Grypdonck M, Abu-Saad HH. Effects of a nursing pain programme on patient outcomes. Psychooncology. Dec. 1997;6(4):302-310. Not eligible exposure. [pmid: 9451749].
1001 Francke AL, Luiken JB, Garssen B, Abu-Saad HH, Grypdonck M. Effects of a pain programme on nurses' psychosocial, physical and relaxation interventions. Patient Educ Couns. Jul. 1996;28(2):221-230. Not eligible exposure. [pmid: 8852097].
1002 Frank IC. ED crowding and diversion: strategies and concerns from across the United States. J Emerg Nurs. Dec. 2001;27(6):559-565. Review. [pmid: 11712009].
1003 Freeman BA, Coronado JR. The nursing shortage: dynamics and solutions. A supportive clinical practice model. Nurs Clin North Am. Sep. 1990;25(3):551-560. No association tested. [pmid: 2381858].
1004 French E. Pediatric and neonatal nurses get “one more hand”. Crit Care Nurse. Oct. 1999;19(5):96. Comment.
1005 Frick S, Uehlinger DE, Zuercher Zenklusen RM. Medical futility: predicting outcome of intensive care unit patients by nurses and doctors—a prospective comparative study. Crit Care Med. Feb. 2003;31(2):456-461. Not eligible target population. [pmid: 12576951].
1006 Frid I, Bergbom-Engberg I, Haljamae H. Brain death in ICUs and associated nursing care challenges concerning patients and families. Intensive Crit Care Nurs. Feb. 1998;14(1):21-29. Not eligible target population. [pmid: 9652258].
1007 Friend B. Trapped in Iraq. Nurs Times. Nov 14–20. 1990;86(46):16-17. News.
1008 Fryklund B, Tullus K, Berglund B, Burman LG. Importance of the environment and the faecal flora of infants, nursing staff and parents as sources of gram-negative bacteria colonizing newborns in three neonatal wards. Infection. Sep–Oct. 1992;20(5):253-257. Not eligible target population. [pmid: 1428181].
1009 Fuchs BC, Pass CM. Smoking practices of hospital employed nurses. South Carolina Nurse. Summer. 1990;5(2):36-7. Not relevant.
1010 Fudge L. Team-based self-rostering. Br J Perioper Nurs. Jul. 2001;11(7):310-316. Not eligible target population. [pmid: 11892566].
1011 Fujino M, Nojima Y. Effects of ward rotation on subsequent transition processes of Japanese clinical nurses. Nurs Health Sci. Mar. 2005;7(1):37-44. Not eligible target population. [pmid: 15670005].
1012 Fuortes LJ, Shi Y, Zhang M, Zwerling C, Schootman M. Epidemiology of back injury in university hospital nurses from review of workers' compensation records and a case-control survey. J Occup Med. Sep. 1994;36(9):1022-1026. Not eligible outcomes. [pmid: 7823214].
1013 Furillo J. Behind (and between) the lines. Revolution. Sep–Oct. 2000;1(5):25-27. Comment. [pmid: 12018073].
1014 Furillo J. Ensuring safe nurse-to-patient ratios: Safe Staffing Bill mandates ratios based on patients' needs rather than budgets. West J Med. Apr. 2001;174(4):233-234. News. [pmid: 11290665]. [pmcid: 1071338].
1015 Furillo J, Kercher L. Should nurse-to-patient staffing ratios be mandated by legislation?. MCN Am J Matern Child Nurs. Jul–Aug. 2001;26(4):176-177. Comment. [pmid: 11452660].
1016 Furlong S, Ward M. Assessing patient dependency and staff skill mix. Nurs Stand. Mar 12. 1997;11(25):33-38. Not eligible target population. [pmid: 9115870].
1017 Gabrielson A. Patient-centered care in the OR: is this possible?. Can Oper Room Nurs J. Mar–Apr. 1997;15(1):8-10. Comment. [pmid: 9287536].
1018 Gadbois C. Different job demands of nightshifts in hospitals. J Hum Ergol (Tokyo). Dec. 2001;30(12):295-300. Not eligible target population. [pmid: 14564898].
1019 Gagnon AJ, Waghorn K, Jones MA, Yang H. Indicators nurses employ in deciding to test for hyperbilirubinemia. J Obstet Gynecol Neonatal Nurs. Nov–Dec. 2001;30(6):626-633. Not eligible Exposure.
1020 Gagnon J, Bouchard F, Landry M, Belles-Isles M, Fortier M, Fillion L. Implementing a hospital-based animal therapy program for children with cancer: a descriptive study. Can Oncol Nurs J. Fall. 2004;14(4):210-222. Not eligible exposure.
1021 Gajewska K, Schroeder M, De Marre F, Vincent JL. Analysis of terminal events in 109 successive deaths in a Belgian intensive care unit. Intensive Care Med. Jun. 2004;30(6):1224-1227. Not eligible target population. [pmid: 15105984].
1022 Gale J, FothergillBourbonnais F, Chamberlain M. Measuring nursing support during childbirth. MCN: The American Journal of Maternal/Child Nursing. Sep–Oct. 2001;26(5):264-71. Not relevant.
1023 Gallagher RM, Kany KA, Rowell PA, Peterson C. ANA's nurse staffing principles. Am J Nurs. Apr 1999;99(4):50, 52–53. Review.
1024 Gamble DA. Filipino nurse recruitment as a staffing strategy. J Nurs Adm. Apr. 2002;32(4):175-177. Not eligible target population. [pmid: 11984249].
1025 Ganapathy S, Zwemer FL Jr. Coping with a crowded ED: an expanded unique role for midlevel providers. Am J Emerg Med. Mar. 2003;21(2):125-128. Not eligible exposure. [pmid: 12671813].
1026 Ganong LH, Coleman M. Effects of family structure information on nurses' impression formation and verbal responses. Res Nurs Health. Apr. 1997;20(2):139-151. Not eligible exposure. [pmid: 9100744].
1027 Ganz DA, Simmons SF, Schnelle JF. Cost-effectiveness of recommended nurse staffing levels for short-stay skilled nursing facility patients. BMC Health Serv Res. May 10. 2005;5(1):35. Not eligible target population. [pmid: 15885148]. [pmcid: 1145183].
1028 Garbett R. Part-time working: speaking out. Nurs Times. Sep 4–10. 1996;92(36):52-53. Not eligible target population. [pmid: 8868773].
1029 Garcia de Lucio L, Garcia Lopez FJ, Marin Lopez MT, Mas Hesse B, Caamano Vaz MD. Training programme in techniques of self-control and communication skills to improve nurses' relationships with relatives of seriously ill patients: a randomized controlled study. J Adv Nurs. Aug. 2000;32(2):425-431. Not eligible target population. [pmid: 10964191].
1030 Gardner KG, Tilbury M. A longitudinal cost analysis of primary and team nursing. Nursing Economics. Mar–Apr. 1991;9(2):97-104. Not relevant. [pmid: 1902557].
1031 Gardiner WC. Documenting JCAHO standards in assigning nursing staff. J Healthc Qual. Jul–Aug. 1992;14(4):50-53. No association tested. [pmid: 10119905].
1032 Gardner DL. Career commitment in nursing. J Prof Nurs. May–Jun. 1992;8(3):155-160. Not eligible exposure. [pmid: 1634656].
1033 Gardner J. Help, with strings. Hospitals may find Congress will attach some controls to funding for new nurses. Mod Healthc. Aug 6. 2001;31(32):24. Not eligible exposure.
1034 Gardulf A, Soderstrom IL, Orton ML, Eriksson LE, Arnetz B, Nordstrom G. Why do nurses at a university hospital want to quit their jobs?. J Nurs Manag. Jul. 2005;13(4):329-337. Not eligible target population. [pmid: 15946172].
1035 Garfield M, Jeffrey R, Ridley S. An assessment of the staffing level required for a high-dependency unit. Anaesthesia. Feb. 2000;55(2):137-143. Not eligible target population. [pmid: 10651674].
1036 Garretson S. Nurse to patient ratios in American health care. Nurs Stand. Dec 15–2005 Jan 4. 2004;19(1416):33-37. Review. [pmid: 15633873].
1037 Garrett DK, McDaniel AM. A new look at nurse burnout: the effects of environmental uncertainty and social climate. J Nurs Adm. Feb. 2001;31(2):91-96. Not eligible exposure. [pmid: 11271685].
1038 Garvey A. Counting the costs. Nurs Stand. Jul 30–Aug 5. 2003;17(46):12. News. [pmid: 12961945].
1039 Gary R, Marrone S, Boyles C. The use of gaming strategies in a transcultural setting. J Contin Educ Nurs. Sep–Oct. 1998;29(5):221-227. Review. [pmid: 9923232].
1040 Gaston TA, Blankenship J. The shortage of full-time nurses working at the bedside is becoming a national concern. J Nurses Staff Dev. May–Jun. 2004;20(3):150-151. author reply 151. Comment. [pmid: 15201837].
1041 Gates D. “Patient-focused care” and other incantations. Mo Nurse. Mar–Apr. 1995;64(2):14-15. Comment. [pmid: 7643845].
1042 Gaudine AP. What do nurses mean by workload and work overload?. Can J Nurs Leadersh. May–Jun. 2000;13(2):22-27. Not eligible target population. [pmid: 15495406].
1043 Gaze H. Starved of attention. Nurs Times. Jan 17–23. 1990;86(3):20. Comment.
1044 Georges CA, Bolton LB, Bennett C. Quality of care in African-American communities and the nursing shortage. J Natl Black Nurses Assoc. Dec. 2003;14(2):16-24. No association tested. [pmid: 15011940].
1045 Gerace LM, Hughes TL, Spunt J. Improving nurses' responses toward substance-misusing patients: a clinical evaluation project. Arch Psychiatr Nurs. Oct. 1995;9(5):286-294. Not eligible exposure. [pmid: 7487170].
1046 Geraci EB, Geraci TA. An observational study of the emergency triage nursing role in a managed care facility. Journal of Emergency Nursing. Jun. 1994;20(3):189-94. Not relevant. [pmid: 8007494].
1047 Gerberich SG, Church TR, McGovern PM, Hansen HE, Nachreiner NM, Geisser MS, Ryan AD, Mongin SJ, Watt GD. An epidemiological study of the magnitude and consequences of work related violence: the Minnesota Nurses' Study. Occup Environ Med. Jun. 2004;61(6):495-503. Not eligible exposure. [pmid: 15150388].
1048 Gerrish K, Griffith V. Integration of overseas Registered Nurses: evaluation of an adaptation programme. J Adv Nurs. Mar. 2004;45(6):579-587. Not eligible target population. [pmid: 15012635].
1049 Geschwinder RF. Anticoagulation therapy a success with patient-focused model. Nurse Pract. Aug. 2004;29(8):46-47. Not eligible exposure. [pmid: 15553918].
1050 Gestes JL. Oncology outcomes among supplemental staff. Okla Nurse. Sep–Nov. 2002;47(3):24-25. Comment. [pmid: 12244585].
1051 Geyer S. Workforce. Nursing arithmetic. Trustee. Jun. 2003;56(6):31-32. Comment. [pmid: 12825422].
1052 Ghosh B, Cruz G. Nurse requirement planning: a computer-based model. J Nurs Manag. Jul. 2005;13(4):363-371. Not eligible target population. [pmid: 15946176].
1053 Gibbs G, Harrison C. Recruitment. Dare to be different. Nurs Times. Aug 18–24. 1999;95(33):36-38. Not eligible target population. [pmid: 10614414].
1054 Gill KP, Ursic P. The impact of continuing education on patient outcomes in the elderly hip fracture population. J Contin Educ Nurs. Jul–Aug. 1994;25(4):181-185. Not eligible exposure. [pmid: 8046057].
1055 Gill SL. The little things: perceptions of breastfeeding support. J Obstet Gynecol Neonatal Nurs. Jul–Aug. 2001;30(4):401-409. Not eligible exposure.
1056 Gillan J. Night nursing. Reflex action. Nurs Times. Sep 1–7. 1993;89(35):26-28. Case Reports. [pmid: 8139955].
1057 Gillespie BM, Kermode S. How do perioperative nurses cope with stress?. Contemp Nurse. Dec–2004 Feb. 2003;16(12):20-29. Review. [pmid: 14994893].
1058 Gilliland M. Workforce reductions: low morale, reduced quality care. Nurs Econ. Nov–Dec. 1997;15(6):320-322. Review. [pmid: 9416099].
1059 Gillis AJ. Nurses' knowledge of growth and development principles in meeting psychosocial needs of hospitalized children. J Pediatr Nurs. Apr. 1990;5(2):78-87. Not eligible exposure. [pmid: 2324932].
1060 Gilman JA. A quality improvement project for better glycemic control in hospitalized patients with diabetes. Diabetes Educ. Jul–Aug. 2001;27(4):541-546. Not eligible exposure. [pmid: 12212342].
1061 Ginsburg L, Norton PG, Casebeer A, Lewis S. An educational intervention to enhance nurse leaders' perceptions of patient safety culture. Health Serv Res. Aug. 2005;40(4):997-1020. Not eligible outcomes. [pmid: 16033489]. [pmcid: 1361187].
1062 Giovannetti P, Johnson JM. A new generation patient classification system. J Nurs Adm. May. 1990;20(5):33-40. No association tested. [pmid: 2335788].
1063 Giraud T, Dhainaut JF, Vaxelaire JF, Joseph T, Journois D, Bleichner G, Sollet JP, Chevret S, Monsallier JF. Iatrogenic complications in adult intensive care units: a prospective two-center study. Crit Care Med. Jan. 1993;21(1):40-51. Not eligible target population. [pmid: 8420729].
1064 Girou E, Chai SH, Oppein F, Legrand P, Ducellier D, Cizeau F, Brun-Buisson C. Misuse of gloves: the foundation for poor compliance with hand hygiene and potential for microbial transmission?. J Hosp Infect. Jun. 2004;57(2):162-169. Not eligible target population. [pmid: 15183248].
1065 Gladstone J. Drug administration errors: a study into the factors underlying the occurrence and reporting of drug errors in a district general hospital. J Adv Nurs. Oct. 1995;22(4):628-637. Not eligible target population. [pmid: 8708180].
1066 Glassford B. Putting patient safety first. Am J Nurs. Nov. 2004;104(11):81. Comment. [pmid: 15619737].
1067 Glover D. Look before you leap. Nurs Times. Mar 3–9. 1999;95(9):31. Comment. [pmid: 10196986].
1068 Gobbi M. Nursing practice as bricoleur activity: a concept explored. Nurs Inq. Jun. 2005;12(2):117-125. Not eligible target population. [pmid: 15892727].
1069 Gobis L. The perils of floating. Am J Nurs. Sep. 2001;101(9):78. Legal Cases. [pmid: 11559989].
1070 Godin M. A patient classification system for the hemodialysis setting. Nurs Manage. Nov. 1995;26(11):66-67. Comment. [pmid: 7478373].
1071 Gold DR, Rogacz S, Bock N, Tosteson TD, Baum TM, Speizer FE, Czeisler CA. Rotating shift work, sleep, and accidents related to sleepiness in hospital nurses. Am J Public Health. Jul. 1992;82(7):1011-1014. Not eligible outcomes. [pmid: 1609900]. [pmcid: 1694075].
1072 Golder DJ. Long night's journey into day. Am J Nurs. May. 1994;94(5):88. Comment. [pmid: 8166182].
1073 Goldman BD. Nontraditional staffing models in long-term care. J Gerontol Nurs. Sep. 1998;24(9):29-34. Not eligible target population. [pmid: 9814276].
1074 Goldman HG. Role expansion in intensive care: survey of nurses' views. Intensive Crit Care Nurs. Dec. 1999;15(6):313-323. Not eligible target population. [pmid: 11868579].
1075 Goldman RL, Bates DP 3rd, Bradbury M, Breaux DK, Caron M, Gerardo C, Copoulos S, Hansen LL, Oien SM, Semones C, et al. Marketing alternatives for hospitals to the nursing crisis. J Hosp Mark. 1990;4(1):71-95. No association tested. [pmid: 10106888].
1076 Goldstein MJ, Kim E, Widmann WD, Hardy MA. A 360 degrees evaluation of a night-float system for general surgery: a response to mandated work-hours reduction. Curr Surg. Sep–Oct. 2004;61(5):445-451. Not eligible exposure. [pmid: 15475093].
1077 Golightly C, Wright LK, Pogue L. A model to facilitate interactive planning. J Nurs Adm. Sep. 1990;20(9):16-19. No association tested. [pmid: 2203883].
1078 Gomez CR, Malkoff MD, Sauer CM, Tulyapronchote R, Burch CM, Banet GA. Code stroke. An attempt to shorten inhospital therapeutic delays. Stroke. Oct. 1994;25(10):1920-1923. Not eligible exposure. [pmid: 8091434].
1079 Goncalves MB, Fischer FM, Lombardi M Junior, Ferreira RM. Work activities of practical nurses and risk factors for the development of musculoskeletal disorders. J Hum Ergol (Tokyo). Dec. 2001;30(12):369-374. Not eligible target population. [pmid: 14564910].
1080 Gonzalez JC, Routh DK, Armstrong FD. Differential medication of child versus adult postoperative patients: the effect of nurses' assumptions. Child Health Care. Winter. 1993;22(1):47-59. Not eligible exposure. [pmid: 10125240].
1081 Gonzalez-Torre PL, Adenso-Diaz B, Sanchez-Molero O. Capacity planning in hospital nursing: a model for minimum staff calculation. Nurs Econ. Jan–Feb. 2002;20(1):28-36. Not eligible target population. [pmid: 11892545].
1082 Goodacre SW, Gillett M, Harris RD, Houlihan KP. Consistency of retrospective triage decisions as a standardised instrument for audit. J Accid Emerg Med. Sep. 1999;16(5):322-324. Not eligible target population. [pmid: 10505909].
1083 Goodare L. All right on the nights. Nurs Times. Oct 21–27. 2003;99(42):38-39. Comment. [pmid: 14618987].
1084 Goode CJ. Impact of a CareMap and case management on patient satisfaction and staff satisfaction, collaboration, and autonomy. Nurs Econ. Nov–Dec 1995;13(6):337–348, 361. Not eligible exposure.
1085 Goode CJ. What variables should I consider when making staffing decisions?. Nurs Manage. Jun. 2001;32(6):13-14. Review. [pmid: 15103861].
1086 Goode CJ, Krugman ME, Smith K, Diaz J, Edmonds S, Mulder J. The pull of magnetism: a look at the standards and the experience of a western academic medical center hospital in achieving and sustaining Magnet status. Nurs Adm Q. Jul–Sep. 2005;29(3):202-213. Not eligible exposure. [pmid: 16056154].
1087 Gooding L. A hard day's night. Nurs Manag (Harrow). Sep. 2004;11(5):23-26. Not eligible target population. [pmid: 15471040].
1088 Goossen WT, Epping PJ, Van den Heuvel WJ, Feuth T, Frederiks CM, Hasman A. Development of the Nursing Minimum Data Set for the Netherlands (NMDSN): identification of categories and items. J Adv Nurs. Mar. 2000;31(3):536-547. Not eligible target population. [pmid: 10718872].
1089 Gordon S. The impact of managed care on female caregivers in the hospital and home. J Am Med Womens Assoc. Spring 1997;52(2):75–77, 80. Not eligible outcomes.
1090 Gordon S, Buresh B. Sounding the alarm. Am J Nurs. Jun. 1996;96(6):21-22. Comment.
1091 Gosztyla J, Fowler S. Survival skills in the acute care workplace: a “float” pool perspective. N J Nurse. Jun–Jul. 1998;28(6):14. Comment. [pmid: 10614353].
1092 Gosztyla J, Fowler S. Staff nurse column. Survival skills in the acute care workplace: a “float” pool perspective. New Jersey nurse. Jun–Jul. 1998;28(6):14. Not peer reviewed. [pmid: 10614353].
1093 Gottvall K, Waldenstrom U. Does birth center care during a woman's first pregnancy have any impact on her future reproduction?. Birth. Sep. 2002;29(3):177-181. Not eligible target population. [pmid: 12153648].
1094 Gould D. Systematic observation of hand decontamination. Nurs Stand. Aug 4–10. 2004;18(47):39-44. Not eligible target population. [pmid: 15357552].
1095 Gould D, Chamberlain A. The use of a ward-based educational teaching package to enhance nurses' compliance with infection control procedures. J Clin Nurs. Jan. 1997;6(1):55-67. Not eligible exposure. [pmid: 9052110].
1096 Gould J, Charlton S. The impact of change on violent patients. Nurs Stand. Feb 2–8. 1994;8(19):38-40. Not eligible exposure. [pmid: 8136248].
1097 Grady C, Jacob J, Romano C. Confidentiality: a survey in a research hospital. J Clin Ethics. Spring. 1991;2(1):25-30. discussion 30–24. Not eligible exposure. [pmid: 1932793].
1098 Grady C, Griffith CA. A modified simulation program addressing a staff nurse educational need identified by a student clinical nurse specialist across three shifts in a cardiac step-down unit. Clinical Nurse Specialist. Mar–Apr. 2006;20(2):90. Not relevant.
1099 Grady G. Temporary assignments can open many doors. Crit Care Nurse. Feb 2000;Suppl:18. Comment.
1100 Grady MA, Bloom KC. Pregnancy outcomes of adolescents enrolled in a CenteringPregnancy program. J Midwifery Womens Health. Sep–Oct. 2004;49(5):412-420. Not eligible exposure. [pmid: 15351331].
1101 Graf E. Pulling from Peter to save Paul: is “floating” administratively or professionally sound?. Revolution. Fall. 1994;4(3):47-49. Comment. [pmid: 7788050].
1102 Graf E. Pulling from Peter to save Paul: is “floating” administratively or professionally sound?. Revolution. Fall–Winter. 1998;8(34):80-83. Comment. [pmid: 10711217].
1103 Graff LG, Radford MJ. Formula for emergency physician staffing. Am J Emerg Med. May. 1990;8(3):194-199. Not eligible exposure. [pmid: 2331258].
1104 Graham IW. Reflective narrative and dementia care. J Clin Nurs. Nov. 1999;8(6):675-683. Not eligible target population. [pmid: 10827614].
1105 Graham IW. Reflective practice and its role in mental health nurses' practice development: a year-long study. J Psychiatr Ment Health Nurs. Apr. 2000;7(2):109-117. Not eligible target population. [pmid: 11146906].
1106 Graham MV. A day-to-day decision support tool. Nurs Manage. Mar. 1995;26(3):48I-48L. Comment.
1107 Granberg A, Engberg IB, Lundberg D. Acute confusion and unreal experiences in intensive care patients in relation to the ICU syndrome. Part II. Intensive Crit Care Nurs. Feb. 1999;15(1):19-33. Not eligible target population. [pmid: 10401338].
1108 Grandell-Niemi H, Hupli M, Leino-Kilpi H, Puukka P. Medication calculation skills of nurses in Finland. J Clin Nurs. Jul. 2003;12(4):519-528. Not eligible target population. [pmid: 12790865].
1109 Grant AM, Grinspun D, Hernandez CA. The revision of a workload measurement tool to reflect the nursing needs of patients with traumatic brain injury. Rehabil Nurs. Nov–Dec 1995;20(6):306–309, 313. No association tested.
1110 Grant LA, Potthoff SJ, Ryden M, Kane RA. Staff ratios, training, and assignment in Alzheimer's special care units. J Gerontol Nurs. Jan. 1998;24(1):9-16. quiz 59. Not eligible target population. [pmid: 9510716].
1111 Grant M, Ferrell BR, Rivera LM, Lee J. Unscheduled readmissions for uncontrolled symptoms. A health care challenge for nurses. Nurs Clin North Am. Dec. 1995;30(4):673-682. Not eligible exposure. [pmid: 7501535].
1112 Granum V. Nursing students' perceptions of nursing as a subject and a function. J Nurs Educ. Jul. 2004;43(7):297-304. Not eligible target population. [pmid: 15303582].
1113 Grassman D. Development of inpatient oncology educational and support programs. Oncol Nurs Forum. May. 1993;20(4):669-676. No association tested. [pmid: 7686668].
1114 Gray J, Cass J, Harper DW, O'Hara PA. A controlled evaluation of a lifts and transfer educational program for nurses. Geriatr Nurs. Mar–Apr. 1996;17(2):81-85. Review. [pmid: 8707157].
1115 Gray JE, Safran C, Davis RB, Pompilio-Weitzner G, Stewart JE, Zaccagnini L, Pursley D. Baby CareLink: using the internet and telemedicine to improve care for high-risk infants. Pediatrics. Dec. 2000;106(6):1318-1324. Not eligible exposure. [pmid: 11099583].
1116 Greaves C. Patients' perceptions of bedside handover. Nurs Stand. Dec 8–14. 1999;14(12):32-35. Not eligible target population. [pmid: 11971334].
1117 Green A, Beeney J, Johnson N, Carlson B. Action STAT! The crisis nurse. Nurs Manage. Oct. 1998;29(10):41-42. Comment. [pmid: 9814309].
1118 Green JM, Kitzinger JV, Coupland VA. Stereotypes of childbearing women: a look at some evidence. Midwifery. Sep. 1990;6(3):125-132. Not eligible target population. [pmid: 2233393].
1119 Greenberg M. Hailing one of health care's priceless resources—nurses commentary. S C Nurse. Apr–Jun. 2002;9(2):31. Comment. [pmid: 12001510].
1120 Greene J. From whodunit to what happened. Hosp Health Netw. Apr 1999;73(4):50–52, 54. Comment.
1121 Greene J. Medical staff. Hitting the visa limit. Hosp Health Netw. Jan. 2004;78(1):16. News.
1122 Greene J, Nordhaus-Bike AM. Nurse shortage. Where have all the RNs gone?. Hosp Health Netw. Aug 5–20. 1998;72(1516):78-80. Comment. [pmid: 9738152].
1123 Greene SA, Powell CW. Expansion of clinical pharmacy services through staff development. Am J Hosp Pharm. Aug. 1991;48(8):1704-1708. Not eligible target population. [pmid: 1897549].
1124 Greeneich D. Developing a consumer-focused unit culture. Aspens Advis Nurse Exec. Apr. 1994;9(7):1-4. Comment. [pmid: 8167069].
1125 Greenglass ER, Burke RJ. Stress and the effects of hospital restructuring in nurses. Can J Nurs Res. Sep. 2001;33(2):93-108. Not eligible exposure. [pmid: 11928340].
1126 Greengold NL, Shane R, Schneider P, Flynn E, Elashoff J, Hoying CL, Barker K, Bolton LB. The impact of dedicated medication nurses on the medication administration error rate: a randomized controlled trial. Arch Intern Med. Oct 27. 2003;163(19):2359-2367. Not eligible outcomes. [pmid: 14581257].
1127 Gregoire MB. Quality of patient meal service in hospitals: delivery of meals by dietary employees vs delivery by nursing employees. J Am Diet Assoc. Oct. 1994;94(10):1129-1134. Not eligible exposure. [pmid: 7930316].
1128 Gregoire MB. Who should serve patient meals?. Hosp Food Nutr Focus. Jul. 1995;11(11):6-7. Not eligible exposure. [pmid: 10143467].
1129 Gresk KD. Twelve-hour shifts on a new telemetry unit. Nurs Manage. Feb. 1991;22(2):40-42. No association tested. [pmid: 1990335].
1130 Grewal PS, Sawant NH, Deaney CN, Gibson KM, Gupta AM, Haverty PF, Panditaratne HG, Samarasinghe SR, Sharma A, Singh S, Turner SA, Wilkinson SL, Wood SP, Glickman S. Pressure sore prevention in hospital patients: a clinical audit. J Wound Care. Mar. 1999;8(3):129-131. Not eligible target population. [pmid: 10362991].
1131 Grice AS, Picton P, Deakin CD. Study examining attitudes of staff, patients and relatives to witnessed resuscitation in adult intensive care units. Br J Anaesth. Dec. 2003;91(6):820-824. Not eligible target population. [pmid: 14633752].
1132 Griesmer H. Self-scheduling turned us into a winning team. Rn. Dec. 1993;56(12):21-23. No association tested. [pmid: 8265985].
1133 Griffith DE, Hardeman JL, Zhang Y, Wallace RJ, Mazurek GH. Tuberculosis outbreak among healthcare workers in a community hospital. Am J Respir Crit Care Med. Aug. 1995;152(2):808-811. Case Reports. [pmid: 7633747].
1134 Griffiths H. Responding to Esther's voice: improving the care of acutely ill older adults. Nurs BC. Dec. 2004;36(5):8-11. Comment. [pmid: 15633521].
1135 Griffiths P. Clinical outcomes for nurse-led in-patient care. Nurs Times. Feb 28–Mar 5. 1996;92(9):40-43. Not eligible target population. [pmid: 8700737].
1136 Griffiths P, Riddington L. Nurses' use of computer databases to identify evidence for practice—a cross-sectional questionnaire survey in a UK hospital. Health Info Libr J. Mar. 2001;18(1):2-9. Not eligible target population. [pmid: 11260287].
1137 Grindel CG, Patsdaughter CA, Medici G, Babington LM. Adult-health/medical-surgical nurses' perceptions of students' contributions to clinical agencies. Medsurg Nurs. Apr. 2003;12(2):117-123. Not eligible exposure. [pmid: 12736931].
1138 Grindel CG, Peterson K, Kinneman M, Turner TL. The Practice Environment Project. A process for outcome evaluation. J Nurs Adm. May. 1996;26(5):43-51. No association tested. [pmid: 8627392].
1139 Grinspun D. Putting patients first: the role of nursing caring. Hosp Q. Summer. 2000;3(4):22-24. Comment. [pmid: 11482265].
1140 Gropper EI, Boily CA. Breathing life into customer satisfaction. Nurs Manage. Nov. 1999;30(11):64-68. No association tested. [pmid: 10765278].
1141 Gropper RG. Spotlight on. Redesigning faculty roles to enhance program outcomes: a case study. Nurse educator. Jul–Aug. 1995;20(4):5-7. Not relevant. [pmid: 7630542].
1142 Grossman I, Weiss LM, Simon D, Tanowitz HB, Wittner M. Blastocystis hominis in hospital employees. Am J Gastroenterol. Jun. 1992;87(6):729-732. Not eligible exposure. [pmid: 1590309].
1143 Grossman RJ. The staffing crisis. Health Forum J. May–Jun. 2002;45(3):10-15. Review. [pmid: 12055902].
1144 Grossman S, Wheeler K, Lippman D. Role-modeling experience improves nursing students' attitudes toward people living with AIDS. Nursingconnections. Spring. 1998;11(1):41-49. Not eligible exposure. [pmid: 9644480].
1145 Grouse A, Bishop R. Non-medical technicians reduce emergency department waiting times. Emerg Med (Fremantle). Mar. 2001;13(1):66-69. Not eligible target population. [pmid: 11476416].
1146 Grumbach K, Ash M, Seago JA, Spetz J, Coffman J. Measuring shortages of hospital nurses: how do you know a hospital with a nursing shortage when you see one?. Med Care Res Rev. Dec. 2001;58(4):387-403. Not eligible exposure. [pmid: 11759196].
1147 Grzybowski M, Ownby DR, Peyser PA, Johnson CC, Schork MA. The prevalence of anti-latex IgE antibodies among registered nurses. J Allergy Clin Immunol. Sep. 1996;98(3):535-544. Not eligible exposure. [pmid: 8828531].
1148 Guidez C. [How can a nursing team participate in a clinical trial? Zoladex, flutamide trial]. Soins. Sep 1990(540):53. Not eligible target population.
1149 Gullick J. A study into safe and efficient use of defibrillators by nurses. Nurs Times. Nov 2–8. 2004;100(44):42-44. Not eligible target population. [pmid: 15552492].
1150 Gullick J, Shepherd M, Ronald T. The effect of an organisational model on the standard of care. Nurs Times. Mar 9–15. 2004;100(10):36-39. Not eligible target population. [pmid: 15045779].
1151 Gundogmus UN, Ozkara E, Mete S. Nursing and midwifery malpractice in Turkey based on the Higher Health Council records. Nurs Ethics. Sep. 2004;11(5):489-499. Not eligible target population. [pmid: 15362358].
1152 Gunning CS. Looking to the future: health professions education in Texas. Tex Nurs. Apr. 2000;74(4):11-12. Comment. [pmid: 11949095].
1153 Gupta A, Della-Latta P, Todd B, San Gabriel P, Haas J, Wu F, Rubenstein D, Saiman L. Outbreak of extended-spectrum beta-lactamase-producing Klebsiella pneumoniae in a neonatal intensive care unit linked to artificial nails. Infect Control Hosp Epidemiol. Mar. 2004;25(3):210-215. Not eligible exposure. [pmid: 15061412].
1154 Gupta S, Pati AK. Desynchronization of circadian rhythms in a group of shift working nurses: effects of pattern of shift rotation. J Hum Ergol (Tokyo). Dec. 1994;23(2):121-131. Not eligible target population. [pmid: 7730597].
1155 Guy J, Persaud J, Davies E, Harvey D. Drug errors: what role do nurses and pharmacists have in minimizing the risk?. J Child Health Care. Dec. 2003;7(4):277-290. Not eligible target population. [pmid: 14636432].
1156 Hackel R, Butt L, Banister G. How nurses perceive medication errors. Nurs Manage. Jan 1996;27(1):31,33–34. No association tested.
1157 Hackenschmidt A. Living with nurse staffing ratios: early experiences. J Emerg Nurs. Aug. 2004;30(4):377-379. Review. [pmid: 15282526].
1158 Haddad A. Ethics in action. A float nurse from the newborn nursery who has scant critical care experience. Rn. Jul 1995;58(7):21–22, 24. Comment.
1159 Haddad A. Ethics in action. “Fess up” to patients?. Rn. Sep. 2003;66(9):27-30. Not eligible exposure.
1160 Hader R, Claudio T. Seven methods to effectively manage patient care labor resources. J Nurs Adm. Feb. 2002;32(2):66-68. Review. [pmid: 11984230].
1161 Hafsteinsdottir TB, Grypdonck MH. NDT competence of nurses caring for patients with stroke. J Neurosci Nurs. Oct. 2004;36(5):289-294. Not eligible target population. [pmid: 15524247].
1162 Hagenow NR. Why not person-centered care? The challenges of implementation. Nurs Adm Q. Jul–Sep. 2003;27(3):203-207. Case reports. [pmid: 13677184].
1163 Hagenstad R, Weis C, Brophy K. Strike a balance with decentralized housekeeping. Nurs Manage. Jun. 2000;31(6):39-43. Not eligible exposure. [pmid: 15127530].
1164 Hageseth KL. Flexible scheduling and part-time work. Focus Crit Care. Aug. 1991;18(4):273. Comment. [pmid: 1874329].
1165 Haggart R, Rushforth H. ‘A child's eye view’: the development and evaluation of a teaching video. Paediatr Nurs. Dec–2000 Jan. 1999;11(10):27-30. Not eligible exposure. [pmid: 10723390].
1166 Haigh C, Neild A, Duncan F. Balance of power—do patients use researchers to survive hospital?. Nurse Res. 2005;12(4):71-81. Not eligible target population. [pmid: 16045048].
1167 Hainsworth DS. The effect of death education on attitudes of hospital nurses toward care of the dying. Oncol Nurs Forum. Jul. 1996;23(6):963-967. Not eligible exposure. [pmid: 8829166].
1168 Haisfield ME, McGuire DB, Krumm S, Shore AD, Zabora J, Rubin HR. Patients' and healthcare providers' opinions regarding advance directives. Oncol Nurs Forum. Aug. 1994;21(7):1179-1187. Not eligible exposure. [pmid: 7971428].
1169 Hale C. Evaluating a change to primary nursing: some methodological issues. Nurs Pract. 1991;4(4):12-16. No association tested. [pmid: 1845380].
1170 Hale PC, Houghton A, Taylor PR, Mason RC, Owen WJ, Bonell C, McColl L. Crossover trial of partial shift working and a one in six rota system for house surgeons in two teaching hospitals. J R Coll Surg Edinb. Feb. 1995;40(1):55-58. Not eligible target population. [pmid: 7738901].
1171 Haley RW, Cushion NB, Tenover FC, Bannerman TL, Dryer D, Ross J, Sanchez PJ, Siegel JD. Eradication of endemic methicillin-resistant Staphylococcus aureus infections from a neonatal intensive care unit. J Infect Dis. Mar. 1995;171(3):614-624. No association tested. [pmid: 7876608].
1172 Hall DS. Work-related stress of registered nurses in a hospital setting. J Nurses Staff Dev. Jan–Feb. 2004;20(1):6-14. quiz 15–16. Not eligible exposure. [pmid: 15076122].
1173 Hall EO. A double concern: Danish grandfathers' experiences when a small grandchild is critically ill. Intensive Crit Care Nurs. Feb. 2004;20(1):14-21. Not eligible target population. [pmid: 14726249].
1174 Hall LM, Doran D. Nurse staffing, care delivery model, and patient care quality. J Nurs Care Qual. Jan–Mar. 2004;19(1):27-33. Not eligible association presentation. [pmid: 14717145].
1175 Hall LM, Doran D, Laschinger HS, Mallette C, Pedersen C, O'Brien-Pallas LL. A balanced scorecard approach for nursing report card development. Outcomes Manag. Jan–Mar. 2003;7(1):17-22. Review. [pmid: 12593121].
1176 Hall LMPRN. Nursing staff mix models and outcomes. Journal of Advanced Nursing. October. 2003;44(2):217-226. Not eligible outcomes. [pmid: 14521688].
1177 Hall M. My sham trial. Nurs Stand. Oct 15–21. 1997;12(4):18-19. Comment. [pmid: 9392271].
1178 Hallberg IR, Norberg A. Strain among nurses and their emotional reactions during 1 year of systematic clinical supervision combined with the implementation of individualized care in dementia nursing. J Adv Nurs. Dec. 1993;18(12):1860-1875. Not eligible target population. [pmid: 8132916].
1179 Haller E, McNiel DE, Binder RL. Impact of a smoking ban on a locked psychiatric unit. J Clin Psychiatry. Aug. 1996;57(8):329-332. Not eligible exposure. [pmid: 8752014].
1180 Halloran EJ. RN staffing: more care—less cost. Nurs Manage. Sep. 1983;14(9):18-22. Not eligible year. [pmid: 6555625].
1181 Halpern JS, Leah L. Curtin discusses the nursing shortage. Int J Trauma Nurs. Jul–Sep. 2000;6(3):85-87. Interview. [pmid: 10891845].
1182 Hamer G. A patient rates nurses: the good, the bad and the loving. J Christ Nurs. Summer. 1990;7(3):28-31. No association tested. [pmid: 2370628].
1183 Hamilton D, Strawn N. Keeping your eye on the ball: an open letter to nurse executives. Aspens Advis Nurse Exec. Jun. 1998;13(9):9-11. Comment. [pmid: 10067446].
1184 Hamilton J. Ten tips for telling people what they don't want to hear. Aspens Advis Nurse Exec. May. 1993;8(8):1-2. Comment. [pmid: 8489848].
1185 Hamilton J, Edgar L. A survey examining nurses' knowledge of pain control. J Pain Symptom Manage. Jan. 1992;7(1):18-26. Not eligible outcomes. [pmid: 1538176].
1186 Hamilton M. Combining utilization management and discharge planning. J Healthc Qual. Jul–Aug 1995;17(4):7–10, 17; quiz 17, 44. Not eligible exposure.
1187 Hampton S. Can electric beds aid pressure sore prevention in hospitals?. Br J Nurs. Sep 24–Oct 7. 1998;7(17):1010-1017. Not eligible exposure. [pmid: 9830895].
1188 Han Y, Huh SJ, Ju SG, Ahn YC, Lim do H, Lee JE, Park W. Impact of an electronic chart on the staff workload in a radiation oncology department. Jpn J Clin Oncol. Aug. 2005;35(8):470-474. Not eligible target population. [pmid: 16024532].
1189 Hancock MR. A pointless system?. Am J Nurs. Aug. 1992;92(8):18. Comment. [pmid: 1524102].
1190 Hand D. NHS cuts: shifting attitudes. Nurs Stand. Dec 5–11. 1990;5(11):20. Not eligible target population. [pmid: 2124837].
1191 Handelman E. Short-staffed but safe. Am J Nurs. Nov. 2003;103(11):120. News. [pmid: 14625434].
1192 Hansen HE, Biros MH, Delaney NM, Schug VL. Research utilization and interdisciplinary collaboration in emergency care. Acad Emerg Med. Apr. 1999;6(4):271-279. Not eligible exposure. [pmid: 10230977].
1193 Hanson RH, Balk JA. A replication study of staff injuries in a state hospital. Hosp Community Psychiatry. Aug. 1992;43(8):836-837. Comment. [pmid: 1290532].
1194 Hansten R. Streamline change-of-shift report. Nurs Manage. Aug. 2003;34(8):58-59. Comment. [pmid: 12888737].
1195 Hansten R, Washburn MJ. Professional practice: facts & impact. Am J Nurs. Mar. 1998;98(3):42-45. Comment. [pmid: 9536178].
1196 Harber P, Pena L, Hsu P, Billet E, Greer D, Kim K. Personal history, training, and worksite as predictors of back pain of nurses. Am J Ind Med. Apr. 1994;25(4):519-526. Not eligible outcomes. [pmid: 8010294].
1197 Hardin S, Hussey L. AACN Synergy model for patient care. Case study of a CHF patient. Crit Care Nurse. Feb. 2003;23(1):73-76. Case Reports. [pmid: 12640962].
1198 Harding LK, Harding NJ, Warren H, Mills A, Thomson WH. The radiation dose to accompanying nurses, relatives and other patients in a nuclear medicine department waiting room. Nucl Med Commun. Jan. 1990;11(1):17-22. Not eligible target population. [pmid: 2338965].
1199 Harding R. Reflections on family-centred care. Paediatr Nurs. Nov. 1997;9(9):19-21. Not eligible target population. [pmid: 9423492].
1200 Hardy LK. Nursing work and the implications of “the second shift”. Can J Nurs Adm. Nov–Dec. 1990;3(4):23-26. Not eligible exposure. [pmid: 2078564].
1201 Hardy M, Barrett C. Interpretation of trauma radiographs by radiographers and nurses in the UK: a comparative study. Br J Radiol. Aug. 2004;77(920):657-661. Not eligible target population. [pmid: 15326043].
1202 Hardy ML, Barrett C. Requesting and interpreting trauma radiographs: a role extension for accident & emergency nurses. Accid Emerg Nurs. Oct. 2003;11(4):202-213. Not eligible target population. [pmid: 14521966].
1203 Harloe LJ, Greenway MN, O'Connor S, Fowle T, Hayes K, Pendall D, Stewart C, Squires L, Bond M, White K. Generating ideas for research: an Australian research experience. Gastroenterol Nurs. Jul–Aug. 1995;18(4):138-141. Not eligible target population. [pmid: 7654810].
1204 Harmond K. Time out. Nurs Stand. May 30–Jun 5. 1990;4(36):47. Not eligible target population. [pmid: 2112721].
1205 Harmond K. Caring for sick buildings. Nurs Stand. Jun 19–25. 1991;5(39):44. Not eligible target population. [pmid: 1907189].
1206 Harrahill M, Eastes L. Trauma nurse practitioner: the perfect job?. J Emerg Nurs. Aug. 1999;25(4):337-338. Comment. [pmid: 10424968].
1207 Harrington SS, Walker BL. Is computer-based instruction an effective way to present fire safety training to long-term care staff?. J Nurses Staff Dev. May–Jun. 2003;19(3):147-154. Not eligible exposure. [pmid: 12794540].
1208 Harris M, Gavel P, Conn W. Planning Australia's hospital workforce. Aust Health Rev. 2002;25(5):61-77. Not eligible target population. [pmid: 12474502].
1209 Harrison JP, Nolin J, Suero E. The Effect of Case Management on U.S. Hospitals. Nursing Economics. March–April 2004. 2004;22(2):64-70. Not eligible outcomes. [pmid: 15108474].
1210 Harrison S, Hutton L, Nowak M. An investigation of professional advice advocating therapeutic sun exposure. Aust N Z J Public Health. Apr. 2002;26(2):108-115. Not eligible exposure. [pmid: 12054327].
1211 Hart A, Lockey R. Inequalities in health care provision: the relationship between contemporary policy and contemporary practice in maternity services in England. J Adv Nurs. Mar. 2002;37(5):485-493. Not eligible target population. [pmid: 11843988].
1212 Hart J, Neiman V, Chaimoff C, Wolloch Y, Djaldetti M. Patient satisfaction in two departments of surgery in a community hospital. Isr J Med Sci. Dec. 1996;32(12):1338-1343. Not eligible target population. [pmid: 9007186].
1213 Hart SE. Hospital ethical climates and registered nurses' turnover intentions. J Nurs Scholarsh. 2005;37(2):173-177. Not eligible exposure. [pmid: 15960062].
1214 Hartley J. Reduced doctors' hours. Nurs Times. Jul 27–Aug 2. 2004;100(30):20-23. Not eligible target population.
1215 Hartley J. Nurses face a lottery over choice of shifts. Nurs Times. Jul 5–11. 2005;101(27):10-11. News.
1216 Harty-Golder B. How should a lab design a fail-safe system for point-of-care testing?. MLO Med Lab Obs. Dec. 2001;33(12):22-23. Comment. [pmid: 11799623].
1217 Hasan-Stein L. Two hospitals report: the pros and cons of 12-hour shifts. Nurs N Z. Mar. 1998;4(2):14-15. Not eligible target population. [pmid: 10586729].
1218 Hastings C, Waltz C. Assessing the outcomes of professional practice redesign. Impact on staff nurse perceptions. J Nurs Adm. Mar. 1995;25(3):34-42. Not eligible exposure. [pmid: 7884526].
1219 Hatcher I, Sullivan M, Hutchinson J, Thurman S, Gaffney FA. An intravenous medication safety system: preventing high-risk medication errors at the point of care. J Nurs Adm. Oct. 2004;34(10):437-439. Not eligible exposure. [pmid: 15577664].
1220 Havens DS, Vasey J. Measuring staff nurse decisional involvement: the Decisional Involvement Scale. J Nurs Adm. Jun. 2003;33(6):331-336. Not eligible outcomes. [pmid: 12796630].
1221 Havlovic SJ, Lau DC, Pinfield LT. Repercussions of work schedule congruence among full-time, part-time, and contingent nurses. Health Care Manage Rev. Fall. 2002;27(4):30-41. Not eligible exposure. [pmid: 12433245].
1222 Hawkins CA, O'Connor L, Potter S. ‘The ones that got away’: implementing an exit policy for nurses in a public hospital. Contemp Nurse. Aug. 2003;15(12):29-36. Not eligible target population. [pmid: 14649506].
1223 Hawkins T, Sutton K. Self-scheduling in a CVICU (cardiovascular intensive care unit). Nurs Manage. Nov 1991;22(11):64A, 64D, 64F passim. Not eligible outcomes.
1224 Hay E, Bekerman L, Rosenberg G, Peled R. Quality assurance of nurse triage: consistency of results over three years. Am J Emerg Med. Mar. 2001;19(2):113-117. Not eligible target population. [pmid: 11239253].
1225 Hayes J. Non-nursing duties are eroding our status. Aust Nurs J. Dec–2000 Jan. 1999;7(6):3. Not eligible target population. [pmid: 11894351].
1226 Hayes J. Time to change. Nurs Stand. Feb 23–Mar 1. 2005;19(24):78. Comment. [pmid: 15754929].
1227 Haynes G, Lewer H, Woolford P. Night nurse practitioners are not ‘mini-doctors’. Br J Nurs. Nov 26–Dec 9. 1992;1(14):722-725. Comment. [pmid: 1490064].
1228 Healy AN. Teaming up for more with less. Provider. Apr. 2004;30(4):41-42. Comment. [pmid: 15095583].
1229 Heatlie JM. Reducing insulin medication errors: evaluation of a quality improvement initiative. J Nurses Staff Dev. Mar–Apr. 2003;19(2):92-98. Not eligible exposure. [pmid: 12679661].
1230 Hecht WA, Landstrom G, Nisbet MM, Ratcliffe CJ, Tyler JL. Meeting the nursing shortage head on. A round table discussion. Healthc Financ Manage. Mar 2003;57(3):52–58, 60. Comment.
1231 Heckert DA, Fottler MD, Swartz BW, Mercer AA. The impact of the changing healthcare environment on the attitudes of nursing staff: a longitudinal case study. Health Serv Manage Res. Aug. 1993;6(3):191-202. Not eligible exposure. [pmid: 10128827].
1232 Hedstrom M, Skolin I, von Essen L. Distressing and positive experiences and important aspects of care for adolescents treated for cancer. Adolescent and nurse perceptions. Eur J Oncol Nurs. Mar. 2004;8(1):6-17. discussion 18–19. Not eligible target population. [pmid: 15003739].
1233 Heinz D. Hospital nurse staffing and patient outcomes: a review of current literature. Dimens Crit Care Nurs. Jan–Feb. 2004;23(1):44-50. Review. [pmid: 14734900].
1234 Heller A. Nurses rightfully are tired. Mich Nurse. Feb. 2001;74(2):4-5. Comment. [pmid: 11987639].
1235 Hemmings P. Shift systems: staying power. Nurs Stand. Aug 10–16. 1994;8(46):42. Comment. [pmid: 7917950].
1236 Hendel T, Fish M, Aboudi S. Strategies used by hospital nurses to cope with a national crisis: a manager's perspective. Int Nurs Rev. Dec. 2000;47(4):224-231. Not eligible target population. [pmid: 11153519].
1237 Hendel T, Fish M, Galon V. Leadership style and choice of strategy in conflict management among Israeli nurse managers in general hospitals. J Nurs Manag. Mar. 2005;13(2):137-146. Not eligible target population. [pmid: 15720483].
1238 Hendler I, Nahtomi O, Segal E, Perel A, Wiener M, Meyerovitch J. The effect of full protective gear on intubation performance by hospital medical personnel. Mil Med. Apr. 2000;165(4):272-274. Not eligible target population. [pmid: 10802998].
1239 Hendy R. Auditing PICC line management. Nurs Times. Sep 20–26. 2001;97(38):32-33. Not eligible target population. [pmid: 11935852].
1240 Henneman EA, Gawlinski A. A “near-miss” model for describing the nurse's role in the recovery of medical errors. J Prof Nurs. May–Jun. 2004;20(3):196-201. Not eligible exposure. [pmid: 15211429].
1241 Henninger DE, Nolan MT. A comparative evaluation of two educational strategies to promote publication by nurses. J Contin Educ Nurs. Mar–Apr. 1998;29(2):79-84. Not eligible exposure. [pmid: 9582776].
1242 Hensing G, Alexanderson K. The association between sex segregation, working conditions, and sickness absence among employed women. Occup Environ Med. Feb. 2004;61(2):e7. Not eligible target population. [pmid: 14739391].
1243 Hensinger B, Harkins D, Bruce T. Self-scheduling: two success stories. No more short staffing. Am J Nurs. Mar. 1993;93(3):66-69. Comment. [pmid: 8442480].
1244 Herman CJ, Speroff T, Cebul RD. Improving compliance with immunization in the older adult: results of a randomized cohort study. J Am Geriatr Soc. Nov. 1994;42(11):1154-1159. Not eligible exposure. [pmid: 7963201].
1245 Herrmann J. Canadian nurses head South. Health Syst Rev. May–Jun. 1992;25(3):33-35. News. [pmid: 10117844].
1246 Herrmann LL, Zabramski JM. Tandem practice model: a model for physician-nurse practitioner collaboration in a specialty practice, neurosurgery. J Am Acad Nurse Pract. Jun. 2005;17(6):213-218. Review. [pmid: 15924563].
1247 Hertting A, Nilsson K, Theorell T, Larsson US. Downsizing and reorganization: demands, challenges and ambiguity for registered nurses. J Adv Nurs. Jan. 2004;45(2):145-154. Not eligible target population. [pmid: 14705999].
1248 Hess RG Jr. Wrinkles in time. Nurs Spectr (Wash D C). May 5. 1997;7(9):3. Editorial.
1249 Hesterly SC, Schaffner A, Lounsbery K. Milestone Action Plans. Empowering nurses to manage care. J Nurs Adm. Nov. 1992;22(11):53-56. No association tested. [pmid: 1432229].
1250 Hewitt BE. The challenge of providing family-centred care during air transport: an example of reflection on action in nursing practice. Contemp Nurse. Aug. 2003;15(12):118-124. Not eligible exposure. [pmid: 14649516].
1251 Hewlett PO. Conceptualizing nursing work-force redevelopment. J Nurs Adm. Oct 1999;29(10):8–10, 29. No association tested.
1252 Heyman EN, Lombardo BA. Managing costs: the confused, agitated, or suicidal patient. Nurs Econ. Mar–Apr 1995;13(2):107–111, 118. Not eligible exposure.
1253 Hibbs PJ. Skill mix in hospital. Sr Nurse. Sep–Oct. 1992;12(5):14-17. No association tested. [pmid: 1299898].
1254 Higgins J, Wiles R. Private patients' perceptions of nursing practice in the National Health Service. Nurs Pract. 1992;5(3):20-22. Not eligible target population. [pmid: 1625762].
1255 Higgins LW. Nurses' perceptions of collaborative nurse-physician transfer decision making as a predictor of patient outcomes in a medical intensive care unit. J Adv Nurs. Jun. 1999;29(6):1434-1443. Not eligible outcomes. [pmid: 10354239].
1256 Higgins R, Hurst K, Wistow G. Nursing acute psychiatric patients: a quantitative and qualitative study. J Adv Nurs. Jan. 1999;29(1):52-63. Not eligible target population. [pmid: 10064282].
1257 Higuchi KA, Dulberg C, Duff V. Factors associated with nursing diagnosis utilization in Canada. Nurs Diagn. Oct–Dec. 1999;10(4):137-147. Not eligible exposure. [pmid: 10786554].
1258 Hill A, Burge A, Skinner C. Tuberculosis in National Health Service hospital staff in the west Midlands region of England, 1992-5. Thorax. Nov. 1997;52(11):994-997. Not eligible target population. [pmid: 9487349].
1259 Hilton J. A care pathway for home parenteral nutrition. Nurs Times. May 4–10. 2000;96(18):38-39. Not eligible exposure. [pmid: 11961835].
1260 Hilton P, Goddard M. Taken to task. Nurs Times. Apr 17–23. 1996;92(16):44-45. Not eligible target population. [pmid: 8710594].
1261 Himali U. An unsafe equation: fewer RNs = more workplace injuries. Am Nurse. Jul–Aug. 1995;27(5):19. Comment.
1262 Himali U. ANA sounds alarm about unsafe staffing levels: PR campaing sheds light on RN replacement trends. Am Nurse. Mar. 1995;27(2):1-7. Comment.
1263 Hinds PS, Hockenberry-Eaton M, Gilger E, Kline N, Burleson C, Bottomley S, Quargnenti A. Comparing patient, parent, and staff descriptions of fatigue in pediatric oncology patients. Cancer Nurs. Aug. 1999;22(4):277-288. quiz 288–279. Not eligible exposure. [pmid: 10452204].
1264 Hines J. Communication problems of hearing-impaired patients. Nurs Stand. Jan 26–Feb 1. 2000;14(19):33-37. Not eligible exposure. [pmid: 11209387].
1265 Hinshaw AS, Scofield R, Atwood JR. Staff, patient, and cost outcomes of all-registered nurse staffing. J Nurs Adm. Nov–Dec. 1981;11(1112):30-36. Not eligible year. [pmid: 6915081].
1266 Hirter J. Van Nest RL. Vigilance: a concept and a reality. Crna. May. 1995;6(2):96-98. Comment. [pmid: 7633350].
1267 Hiscott RD. Changes in employment status: the experiences of Ontario registered nurses. Canadian Journal of Nursing Research. Summer. 1994;26(2):43-60. Not relevant. [pmid: 7882195].
1268 Hiscott RD. Changes in the school-to-work transition for Canadian nursing program graduates. Canadian Journal of Nursing Research. Winter. 1995;27(4):151-63. Not relevant. [pmid: 8697271].
1269 Hiscott RD, Connop PJ. Job turnover among nursing professionals: impact of shift length and kinship responsibilities. Sociology and Social Research. Oct. 1990;75(1):32-7. Not relevant.
1270 Hiscott RD, Sharratt MT, Stewart TO, et al. Research examines nurse mobility. Registered Nurse. Oct–Nov. 1993;5(5):38-40. Not peer reviewed.
1271 Hitchings KS. Job sharing: a viable option. Nurs Staff Dev Insid. May–Jun. 1992;1(3):3-8. No association tested.
1272 Hodby D. Dollars and sense: the economics and outcomes of patients undergoing carotid endarterectomy at Royal Adelaide Hospital. J Vasc Nurs. Mar. 2002;20(1):6-11. quiz 12–13. Not eligible target population. [pmid: 11938344].
1273 Hodge MB. The effect of 12 hour shifts on cognition, fatigue, and mood in acute care nurses... 34th Annual Communicating Nursing Research Conference/15th Annual WIN Assembly, “Health Care Challenges Beyond 2001: Mapping the Journey for Research and Practice,” held April 19–21, 2001 in Seattle, Washington. Communicating nursing research. Spring. 2001;34:296. Conference abstract.
1274 Hodge MB, Asch SM, Olson VA, Kravitz RL, Sauve MJ. Developing indicators of nursing quality to evaluate nurse staffing ratios. J Nurs Adm. Jun. 2002;32(6):338-345. Not eligible outcomes. [pmid: 12055490].
1275 Hodgson J. Nursing must look after its young. Nurs Stand. Oct 18–24. 1995;10(4):47. Comment. [pmid: 7492505].
1276 Hodnett ED, Lowe NK, Hannah ME, Willan AR, Stevens B, Weston JA, Ohlsson A, Gafni A, Muir HA, Myhr TL, Stremler R. Effectiveness of nurses as providers of birth labor support in North American hospitals: a randomized controlled trial. Jama. Sep 18. 2002;288(11):1373-1381. Not eligible outcomes. [pmid: 12234231].
1277 Hoffart N, Willdermood S. Self-scheduling in five med/surg units. A comparison. Nurs Manage. Apr. 1997;28(4):42-45. quiz 426. No association tested. [pmid: 9287780].
1278 Hoffman AJ, Scott LD. Role stress and career satisfaction among registered nurses by work shift patterns. J Nurs Adm. Jun. 2003;33(6):337-342. Not eligible outcomes. [pmid: 12796631].
1279 Hoffman LA, Tasota FJ, Zullo TG, Scharfenberg C, Donahoe MP. Outcomes of care managed by an acute care nurse practitioner/attending physician team in a subacute medical intensive care unit. Am J Crit Care. Mar. 2005;14(2):121-130. quiz 131–122. Not eligible exposure. [pmid: 15728954].
1280 Hogan J. Staff ratios in intensive care: are they adequate?. Br J Nurs. Jul 13–26. 2000;9(13):817. Not eligible target population. [pmid: 11261053].
1281 Hogan J, Playle JF. The utilization of the healthcare assistant role in intensive care. Br J Nurs. Jun 22–Jul 12. 2000;9(12):794-801. Not eligible target population. [pmid: 11235301].
1282 Hogan M. Understanding rostering. Part 5. Shiftwork and the hierarchy. Aust Nurs J. Jul. 1995;3(1):34-36. Comment. [pmid: 7663723].
1283 Hogston R. Evaluating quality nursing care through peer review and reflection; the findings of a qualitative study. Int J Nurs Stud. Apr. 1995;32(2):162-172. Not eligible target population. [pmid: 7790156].
1284 Holdnak BJ, Harsh J, Bushardt SC. An examination of leadership style and its relevance to shift work in an organizational setting. Health care management review. Summer. 1993;18(3):21-30. Not relevant. [pmid: 8225962].
1285 Hollar-Ruegg T. Recruiting nurses from the Philippines to combat the nursing shortage in central Ohio. Ohio Nurses Rev. Feb. 2002;77(2):4. Letter. [pmid: 15131847].
1286 Holle ML. A prescription for success: integrating 12 inpatient and 17 outpatient programs. Aspens Advis Nurse Exec. Jan. 1995;10(4):1-3. Comment. [pmid: 7833180].
1287 Hollingdale R, Warin J. Back pain in nursing and associated factors: a study. Nurs Stand. Jun 18. 1997;11(39):35-38. Not eligible exposure. [pmid: 9224063].
1288 Holloway IM, Smith P, Warren J. Time in hospital. J Clin Nurs. Sep. 1998;7(5):460-466. Not eligible target population. [pmid: 9855998].
1289 Holmas TH. Keeping nurses at work: a duration analysis. Health Econ. Sep. 2002;11(6):493-503. Not eligible target population. [pmid: 12203753].
1290 Holmes L. Theatre nursing (2). Br J Theatre Nurs. Oct. 1994;4(7):27-28. Comment. [pmid: 7827392].
1291 Holness A, Williams J, Scott E, Bolstad B, McCrary P. Shift coordinators dispel myths. Nurs Manage. Oct. 1992;23(10):81-82. Comment. [pmid: 1407847].
1292 Holness DL, Tarlo SM, Sussman G, Nethercott JR. Exposure characteristics and cutaneous problems in operating room staff. Contact Dermatitis. Jun. 1995;32(6):352-358. Not eligible exposure. [pmid: 7554882].
1293 Holt AW, Bersten AD, Fuller S, Piper RK, Worthley LI, Vedig AE. Intensive care costing methodology: cost benefit analysis of mask continuous positive airway pressure for severe cardiogenic pulmonary oedema. Anaesth Intensive Care. Apr. 1994;22(2):170-174. Not eligible target population. [pmid: 8210020].
1294 Holt AW, Bury LK, Bersten AD, Skowronski GA, Vedig AE. Prospective evaluation of residents and nurses as severity score data collectors. Crit Care Med. Dec. 1992;20(12):1688-1691. Not eligible target population. [pmid: 1458947].
1295 Holtom BC, O'Neill BS. Job embeddedness: a theoretical foundation for developing a comprehensive nurse retention plan. J Nurs Adm. May. 2004;34(5):216-227. Not eligible outcomes. [pmid: 15167418].
1296 Holyoake DD. Who's the boss? Children's perception of hospital hierarchy. Paediatr Nurs. Jun. 1999;11(5):33-36. Not eligible exposure. [pmid: 10595157].
1297 Homsted L, Nilsson M. Safe staffing: a serious concern. Fla Nurse. Mar. 2003;51(1):1-14. Comment. [pmid: 12743945].
1298 Hopia H, Tomlinson PS, Paavilainen E, Astedt-Kurki P. Child in hospital: family experiences and expectations of how nurses can promote family health. J Clin Nurs. Feb. 2005;14(2):212-222. Not eligible target population. [pmid: 15669930].
1299 Hopkins S. Junior doctors' hours and the expanding role of the nurse. Nurs Times. Apr 3–9. 1996;92(14):35-36. Not eligible exposure. [pmid: 8700702].
1300 Horner M. A review of a supervised practice programme for overseas nurses. Nurs Times. Jul 6–12. 2004;100(27):38-41. Not eligible exposure. [pmid: 15317262].
1301 Horns KM, Gills MB. Neonatal nurse knowledge of penicillin therapy. Neonatal Netw. Oct. 1998;17(7):52-55. Case Reports. [pmid: 9850196].
1302 Hostetter A, Roda PI, Phillips CY. Heart-smart service. Nurs Manage. Jan. 2001;32(1):22-25. Not eligible exposure. [pmid: 15103777].
1303 Hostutler JJ, Taft SH, Snyder C. Patient needs in the emergency department: nurses' and patients' perceptions. J Nurs Adm. Jan. 1999;29(1):43-50. Not eligible exposure. [pmid: 9921148].
1304 Hotchkiss JR, Strike DG, Simonson DA, Broccard AF, Crooke PS. An agent-based and spatially explicit model of pathogen dissemination in the intensive care unit. Crit Care Med. Jan. 2005;33(1):168-176. discussion 253–164. Not eligible exposure. [pmid: 15644665].
1305 Houchins G. Taking a closer look at employee turnover in the dialysis unit. Nephrol News Issues. Sep. 1995;9(9):37-38. Comment. [pmid: 7501036].
1306 Houser BP. The power of collaboration: Arizona's best kept secret. Nurs Adm Q. Jul–Sep. 2005;29(3):263-267. Review. [pmid: 16056161].
1307 Houser E. It's all in the mix. Mich Health Hosp. Mar–Apr. 2000;36(2):24-26. Comment. [pmid: 11009896].
1308 Houser J. A model for evaluating the context of nursing care delivery. J Nurs Adm. Jan. 2003;33(1):39-47. Not eligible target population. [pmid: 12544624].
1309 Howell M. Confidentiality during staff reports at the bedside. Nurs Times. Aug 24–30. 1994;90(34):44-45. Not eligible exposure. [pmid: 8084800].
1310 Howenstein MA, Bilodeau K, Brogna MJ, Good G. Factors associated with critical thinking among nurses. J Contin Educ Nurs. May–Jun. 1996;27(3):100-103. Not eligible outcomes. [pmid: 8715875].
1311 Howse E, Bailey J. Resistance to documentation—a nursing research issue. Int J Nurs Stud. Nov. 1992;29(4):371-380. Review. [pmid: 1428602].
1312 Huang PY, Yano EM, Lee ML, Chang BL, Rubenstein LV. Variations in nurse practitioner use in Veterans Affairs primary care practices. Health Serv Res. Aug. 2004;39(4 Pt 1):887-904. Not eligible exposure. [pmid: 15230933]. [pmcid: 1361043].
1313 Huarng F. A primary shift rotation nurse scheduling using zero-one linear goal programming. Comput Nurs. May–Jun. 1999;17(3):135-144. Not eligible target population. [pmid: 10341479].
1314 Huber DA. Staffing issues in the gastroenterology setting. Gastroenterol Nurs. Jan–Feb. 2005;28(1):43-44. Editorial. [pmid: 15738731].
1315 Huch MH. Case management: is it another passing fad?. Nurs Sci Q. Jan. 2000;13(1):73-74. Comment. [pmid: 11847785].
1316 Huckabay LM, Tilem-Kessler D. Patterns of parental stress in PICU emergency admission. Dimens Crit Care Nurs. Mar–Apr. 1999;18(2):36-42. Case Reports. [pmid: 10640009].
1317 Hudon PS. Leapfrog standards: implications for nursing practice. Nurs Econ. Sep–Oct. 2003;21(5):233-236. Review. [pmid: 14618973].
1318 Hudson J, Caruthers TE, Lantiegne K. Intensive care nursing requirements: resource allocation according to patient status. Crit Care Med. Feb. 1979;7(2):69-75. Not eligible year. [pmid: 456002].
1319 Huff C. Workforce. Crossing the U.S. border. Hosp Health Netw. Sep. 2004;78(9):24-26. News. [pmid: 15460817].
1320 Hughes KK, Marcantonio RJ. Recruitment, retention, and compensation of agency and hospital nurses. J Nurs Adm. Oct. 1991;21(10):46-52. Not eligible outcomes. [pmid: 1919774].
1321 Hughes KK, Marcantonio RJ. The clinical practice of supplemental nursing personnel. Nurs Adm Q. Spring. 1993;17(3):83-87. Not eligible outcomes. [pmid: 8502426].
1322 Hughes KK, Young WB. Decision making: stability of clinical decisions. Nurse educator. May–Jun. 1992;17(3):12-6. Not relevant. [pmid: 1518569].
1323 Hughes R, Stone P. The perils of shift work: evening shift, night shift, and rotating shifts: are they for you?. Am J Nurs. Sep. 2004;104(9):60-63. Review. [pmid: 15365343].
1324 Humenick SS, Hill PD, Spiegelberg PL. Breastfeeding and health professional encouragement. J Hum Lact. Dec. 1998;14(4):305-310. Not eligible exposure. [pmid: 10205449].
1325 Humm C. Night duty: all night long. Nurs Stand. Aug 17–23. 1994;8(47):40. Comment. [pmid: 7947118].
1326 Humm C. A shift in time. Nurs Stand. Jun 12. 1996;10(38):22-24. Comment.
1327 Hundley VA, Cruickshank FM, Milne JM, Glazener CM, Lang GD, Turner M, Blyth D, Mollison J. Satisfaction and continuity of care: staff views of care in a midwife-managed delivery unit. Midwifery. Dec. 1995;11(4):163-173. Not eligible target population. [pmid: 8569517].
1328 Hung R. A cyclical schedule of 10-hour, four-day workweeks. Nurs Manage. Sep. 1991;22(9):30-33. Not eligible outcomes. [pmid: 1891147].
1329 Hung R. A note on nurse self-scheduling. Nurs Econ. Jan–Feb. 2002;20(1):37-39. Not eligible target population. [pmid: 11892546].
1330 Hunt J, Hagen S. Nurse to patient ratios and patient outcomes. Nurs Times. Nov 11–17. 1998;94(45):63-66. Not eligible target population. [pmid: 9919285].
1331 Hunt JM. The cardiac surgical patient's expectations and experiences of nursing care in the intensive care unit. Aust Crit Care. Jun. 1999;12(2):47-53. Not eligible target population. [pmid: 10624186].
1332 Hunter PR, Harrison GA, Fraser CA. Cross-infection and diversity of Candida albicans strain carriage in patients and nursing staff on an intensive care unit. J Med Vet Mycol. 1990;28(4):317-325. Not eligible target population. [pmid: 2269911].
1333 Hupcey JE, Penrod J, Morse JM. Establishing and maintaining trust during acute care hospitalizations. Sch Inq Nurs Pract. Fall. 2000;14(3):227-242. discussion 243–228. Not eligible exposure. [pmid: 11153315].
1334 Hurst I. Vigilant watching over: mothers' actions to safeguard their premature babies in the newborn intensive care nursery. J Perinat Neonatal Nurs. Dec. 2001;15(3):39-57. Not eligible exposure. [pmid: 11785577].
1335 Hurst K. Multi-skilled health carers: nature, purpose and implications. Health Manpow Manage. 1997;23(6):197-211. Not eligible target population. [pmid: 10179091].
1336 Hurst K. Relationships between patient dependency, nursing workload and quality. Int J Nurs Stud. Jan. 2005;42(1):75-84. Not eligible target population. [pmid: 15582641].
1337 Hwang JL, Desombre T, Eves A, Kipps M. An analysis of catering options within NHS acute hospitals. Int J Health Care Qual Assur Inc Leadersh Health Serv. 1999;12(67):293-308. Not eligible target population. [pmid: 10724573].
1338 Hydes-Greenwood J, Nellestein I, Leach V. Home and away. Successful strategies in recruitment and retention of overseas nurses. Nurs Manag (Harrow). Sep. 2002;9(5):26-29. Not eligible target population. [pmid: 12271543].
1339 Iapichino G, Radrizzani D, Bertolini G, Ferla L, Pasetti G, Pezzi A, Porta F, Miranda DR. Daily classification of the level of care. A method to describe clinical course of illness, use of resources and quality of intensive care assistance. Intensive Care Med. Jan. 2001;27(1):131-136. Not eligible target population. [pmid: 11280624].
1340 Idel M, Melamed S, Merlob P, Yahav J, Hendel T, Kaplan B. Influence of a merger on nurses' emotional well-being: the importance of self-efficacy and emotional reactivity. J Nurs Manag. Jan. 2003;11(1):59-63. Not eligible target population. [pmid: 12472869].
1341 Idelson C. RNs press California to finalize ratios. Hospitals step up attack at public hearings. Revolution. Nov–Dec. 2002;3(6):10-12. News. [pmid: 12599703].
1342 Idelson C. Hospital industry still resisting ratios. Revolution. Jan–Feb. 2004;5(1):6. Comment. [pmid: 15052950].
1343 Idelson C. RNs win court fight, keep ratios. Revolution. May–Jun. 2005;6(3):8-9. News. [pmid: 16092473].
1344 Idvall E, Hamrin E, Sjostrom B, Unosson M. Patient and nurse assessment of quality of care in postoperative pain management. Qual Saf Health Care. Dec. 2002;11(4):327-334. Not eligible target population. [pmid: 12468692].
1345 Ikegami A, Niwa A. A study of nurse scheduling in Japan. J Hum Ergol (Tokyo). Dec. 2001;30(12):71-76. Not eligible target population. [pmid: 14564861].
1346 Iliffe J. Campaigning for quality health care. Aust Nurs J. May. 2000;7(10):1. Editorial.
1347 Ingersoll GL, Brooks AM, Fischer MS, Hoffere DA, Lodge RH, Wigsten KS, Costello D, Hartung DA, Kiernan ME, Parrinello KM, et al. Professional practice model research collaboration. Issues in longitudinal, multisite designs. J Nurs Adm. Jan. 1995;25(1):39-46. No association tested.
1348 Ingersoll GL, Fisher M, Ross B, et al. Employee response to major organizational redesign. Applied Nursing Research. Feb. 2001;14(1):18-28. Not relevant. [pmid: 11172226].
1349 Innis J, Bikaunieks N, Petryshen P, Zellermeyer V, Ciccarelli L. Patient satisfaction and pain management: an educational approach. J Nurs Care Qual. Oct–Dec. 2004;19(4):322-327. Not eligible exposure. [pmid: 15535537].
1350 Inwood H. Knowledge of resuscitation. Intensive Crit Care Nurs. Feb. 1996;12(1):33-39. Not eligible target population. [pmid: 8696022].
1351 Irurita VF. Factors affecting the quality of nursing care: the patient's perspective. Int J Nurs Pract. Jun. 1999;5(2):86-94. Not eligible target population. [pmid: 10633634].
1352 Irurita VF. The problem of patient vulnerability. Collegian. Jan. 1999;6(1):10-15. Not eligible target population. [pmid: 10401281].
1353 Irurita VF, Williams AM. Balancing and compromising: nurses and patients preserving integrity of self and each other. Int J Nurs Stud. Oct. 2001;38(5):579-589. Not eligible target population. [pmid: 11524104].
1354 Irving K. Governing the conduct of conduct: are restraints inevitable?. J Adv Nurs. Nov. 2002;40(4):405-412. Not eligible target population. [pmid: 12421399].
1355 Isken MW, Hancock WM. A heuristic approach to nurse scheduling in hospital units with non-stationary, urgent demand, and a fixed staff size. J Soc Health Syst. 1991;2(2):24-41. No association tested. [pmid: 1836967].
1356 Ito H, Nozaki M, Maruyama T, Kaji Y, Tsuda Y. Shift work modifies the circadian patterns of heart rate variability in nurses. Int J Cardiol. Jul. 2001;79(23):231-236. Not eligible target population. [pmid: 11461746].
1357 Itzhaky H, Gerber P, Dekel R. Empowerment, skills, and values: a comparative study of nurses and social workers. Int J Nurs Stud. May. 2004;41(4):447-455. Not eligible target population. [pmid: 15050855].
1358 Iverson J, Kirklin S, Becket N, Stone T, Pesanti L. Premium pay cuts agency costs. J Nurs Adm. Oct. 1992;22(10):8-33. Comment. [pmid: 1432218].
1359 Iwata N, Ichii S, Egashira K. Effects of bright artificial light on subjective mood of shift work nurses. Ind Health. 1997;35(1):41-47. Not eligible target population. [pmid: 9009500].
1360 Jabez A. Nursing abroad: a place of extremes. Nurs Stand. Apr 21–27. 1993;7(31):18-19. Comment. [pmid: 8512832].
1361 Jacelon CS. Attitudes and behaviors of hospital staff toward elders in an acute care setting. Appl Nurs Res. Nov. 2002;15(4):227-234. Not eligible exposure. [pmid: 12444581].
1362 Jackson A. Improving staffing and quality: a nursing support team. Paediatr Nurs. Nov. 1999;11(9):22-24. Not eligible target population. [pmid: 10723378].
1363 Jackson AL, Pokorny ME, Vincent P. Relative satisfaction with nursing care of patients with ostomies. J ET Nurs. Nov–Dec. 1993;20(6):233-238. Not eligible exposure. [pmid: 8110893].
1364 Jackson BS, Kasoff J, Casavis L, Hoffmeister R. Raising the bar and keeping it there. J Nurs Adm. Mar. 2003;33(3):134-135. Comment. [pmid: 12629298].
1365 Jackson BS, Robley LR, Cortes TA, Annella EJ. How far do we go to protect patient welfare? Breaching unit staff confidentiality and trust. J Nurs Adm. Jun. 1997;27(6):7-9. Comment. [pmid: 9235365].
1366 Jackson L. Nurs/patient ratio too high. Nursing. Dec. 1991;21(12):6. Letter. [pmid: 1749554].
1367 Jackson LB, Marcell J, Benedict S. Nurses' attitudes toward parental visitation on the postanesthesia care unit. J Perianesth Nurs. Feb. 1997;12(1):2-6. Not eligible outcomes. [pmid: 9069869].
1368 Jackson M. A preceptor incentive program. Am J Nurs. Jun 2001;101(6):24A–24C, 24E. Comment.
1369 Jackson NV. A survey of part-time faculty in baccalaureate schools of nursing and their learning needs. Not relevant.
1370 Jackson TL, Beun L. A prospective study of cost, patient satisfaction, and outcome of treatment of chalazion by medical and nursing staff. Br J Ophthalmol. Jul. 2000;84(7):782-785. Not eligible target population. [pmid: 10873994]. [pmcid: 1723539].
1371 Jacobs C. How to plan for times of high patient census. Nurs Manage. May 2002;33(5):46, 48–51. Comment.
1372 Jacobs L. ‘Saint B’ gets an A in ratios. Revolution. Jan–Feb. 2004;5(1):22-26. Comment. [pmid: 15052956].
1373 Jacobsen C, Holson D, Farley J, Charles J, Suel P. Surviving the perfect storm: staff perceptions of mandatory overtime. JONAS Healthc Law Ethics Regul. Sep. 2002;4(3):57-66. Not eligible exposure. [pmid: 12352578].
1374 Jacobson AK, Seltzer JE, Dam EJ. New methodology for analyzing fluctuating unit activity. Nurs Econ. Jan–Feb. 1999;17(1):55-59. Not eligible outcomes. [pmid: 10335224].
1375 Jacobson SF, Jordan KF. Nurses' reasons for participating in a longitudinal panel survey. West J Nurs Res. Aug. 1993;15(4):509-515. Not eligible outcomes. [pmid: 8356841].
1376 Jaklevic MC. Law allows some hiring of foreign nurses. Mod Healthc. Nov 29. 1999;29(48):38. News.
1377 Jakob SM, Rothen HU. Intensive care 1980-1995: change in patient characteristics, nursing workload and outcome. Intensive Care Med. Nov. 1997;23(11):1165-1170. Not eligible target population. [pmid: 9434923].
1378 James DV, Fineberg NA, Shah AK, Priest RG. An increase in violence on an acute psychiatric ward. A study of associated factors. Br J Psychiatry. Jun. 1990;156:846-852. Not eligible target population. [pmid: 2207515].
1379 James G. Nursing precious resources. Health Serv J. May 16. 1991;101(5252):24-25. Not eligible target population. [pmid: 10111213].
1380 Jannotta M, Maldonado T. Self-management for nurses. J Nurs Adm. Jun. 1992;22(6):59-63. No association tested. [pmid: 1597762].
1381 Janssen PA, Keen L, Soolsma J, Seymour LC, Harris SJ, Klein MC, Reime B. Perinatal nursing education for single-room maternity care: an evaluation of a competency-based model. J Clin Nurs. Jan. 2005;14(1):95-101. Not eligible exposure. [pmid: 15656853].
1382 Jarman H, Jacobs E, Zielinski V. Medication study supports registered nurses' competence for single checking. Int J Nurs Pract. Dec. 2002;8(6):330-335. Not eligible target population. [pmid: 12390586].
1383 Jarvi M, Uusitalo T. Job rotation in nursing: a study of job rotation among nursing personnel from the literature and via a questionnaire. J Nurs Manag. Sep. 2004;12(5):337-347. Not eligible target population. [pmid: 15315490].
1384 Jarvis LA, Beale B, Martin K. A client-centered model: discharge planning in Juvenile Justice Centres in New South Wales, Australia. Int Nurs Rev. Sep. 2000;47(3):184-190. Not eligible target population. [pmid: 11043488].
1385 Jarvis R, Young SW, Hardy P, Ward S. Implementation of a patient classification system: using current resources to achieve organizational goals. Health Care Superv. Sep. 1991;10(1):51-57. No association tested. [pmid: 10112257].
1386 Jaworski Miller L, Corbett G, Herold M, Tavares D, Kirchner L, Heath J. Journey to the Beacon Award: the Georgetown University Hospital perspective. Crit Care Nurs Clin North Am. Jun 2005;17(2):155–161, x. Review.
1387 Jeang A. Flexible nursing staff planning when patient demands are uncertain. J Med Syst. Jun. 1994;18(3):125-138. Not eligible target population. [pmid: 7964219].
1388 Jeang A. Flexible nursing staff planning with adjustable patient demands. J Med Syst. Aug. 1996;20(4):173-182. Not eligible target population. [pmid: 8892047].
1389 Jeffe DB, Dunagan WC, Garbutt J, Burroughs TE, Gallagher TH, Hill PR, Harris CB, Bommarito K, Fraser VJ. Using focus groups to understand physicians' and nurses' perspectives on error reporting in hospitals. Jt Comm J Qual Saf. Sep. 2004;30(9):471-479. Not eligible exposure. [pmid: 15469124].
1390 Jenkins CG. (Relatively) painless downsizing. MLO Med Lab Obs. Mar. 1996;28(3):36-39. Comment. [pmid: 10156310].
1391 Jenkins LS, George V. Heart Watch: national survey of continuous electrocardiographic monitoring in U.S. hospitals. J Nurs Adm. Apr. 1995;25(4):38-44. Not eligible exposure. [pmid: 7714629].
1392 Jenkins R, Elliott P. Stressors, burnout and social support: nurses in acute mental health settings. J Adv Nurs. Dec. 2004;48(6):622-631. Not eligible target population. [pmid: 15548253].
1393 Jennings BM. The role of research in the policy puzzle: nurse staffing research as a case in point. Res Nurs Health. Dec. 2001;24(6):443-445. Editorial. [pmid: 11746073].
1394 Jennings BM, Loan LA, DePaul D, Brosch LR, Hildreth P. Lessons learned while collecting ANA indicator data. J Nurs Adm. Mar. 2001;31(3):121-129. Review. [pmid: 11263060].
1395 Jensen L. Self-administered cardiac medication program evaluation. Can J Cardiovasc Nurs. 2003;13(2):35-44. Not eligible target population. [pmid: 12802837].
1396 Jeppesen HJ, Boggild H. Management of health and safety in the organization of worktime at the local level. Scand J Work Environ Health. 1998;24(Suppl 3):81-87. Not eligible target population. [pmid: 9916822].
1397 Jerant AF, Azari R, Martinez C, Nesbitt TS. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Serv Q. 2003;22(1):1-20. Not eligible exposure. [pmid: 12749524].
1398 Jette DU, Warren RL, Wirtalla C. Rehabilitation in skilled nursing facilities: effect of nursing staff level and therapy intensity on outcomes. Am J Phys Med Rehabil. Sep. 2004;83(9):704-712. Not eligible target population. [pmid: 15314535].
1399 Jevitt CM, Beckstead JW. Retirement among Florida's certified nurse-midwives: an impending workforce crisis. Journal of midwifery & women's health. Jan–Feb. 2004;49(1):39-46. Not relevant.
1400 Jickling JL, Graydon JE. The information needs at time of hospital discharge of male and female patients who have undergone coronary artery bypass grafting: a pilot study. Heart Lung. Sep–Oct. 1997;26(5):350-357. Not eligible exposure. [pmid: 9315463].
1401 Jinks A, Smith M, Ashdown-Lambert J. The public health roles of health visitors and school nurses: a survey. Br J Community Nurs. Nov. 2003;8(11):496-501. Not eligible target population. [pmid: 14685133].
1402 Johanson W. Nurse staffing. Health Aff (Millwood). Jan–Feb. 2003;22(1):281. author reply 281–282. Comment. [pmid: 12528865].
1403 Johansson P, Oleni M, Fridlund B. Nurses' assessments and patients' perceptions: development of the Night Nursing Care Instrument (NNCI), measuring nursing care at night. Int J Nurs Stud. Jul. 2005;42(5):569-578. Not eligible target population. [pmid: 15921988].
1404 Johnson DE. Hospitals can control patient days to stem nurse demand. Health Care Strateg Manage. Jul 2001;19(7):1, 18–19. Comment.
1405 Johnson DE. Leapfrog's report is incomplete, misleading. Health Care Strateg Manage. Feb. 2002;20(2):2-3. Review.
1406 Johnson DE. How severe is the nurse shortage?. Health Care Strateg Manage. Jan. 2003;21(1):2-3. Comment.
1407 Johnson F, Smithson S. International recruitment. Travellers' checks. Health Serv J. Jul 4. 2002;112(5812):25. News. [pmid: 12138742].
1408 Johnson J, Brown KK, Neal K. Designs that make a difference: the Cardiac Universal Bed model. J Cardiovasc Manag. Sep–Oct. 2003;14(5):16-20. No association tested. [pmid: 14567269].
1409 Johnson JE. Management perspectives. I am a nursing executive in an institution whose goal is to change its culture to become more customer oriented. Nurs Spectr (Wash D C). Aug 7. 1995;5(16):5. Comment. [pmid: 7640787].
1410 Johnson LJ. Your liability for a nurse's mistake. Med Econ. Sep 9. 2002;79(17):115. Comment. [pmid: 12298125].
1411 Johnson M, Stewart H, Langdon R, Kelly P, Yong L. Women-centred care and caseload models of midwifery. Collegian. Jan. 2003;10(1):30-34. Not eligible target population. [pmid: 15481509].
1412 Johnson N. Congressional outlook: nursing shortages. Hosp Outlook. Feb. 2001;4(2):7. Comment. [pmid: 11246779].
1413 Johnson SH. The right balance. Dimens Crit Care Nurs. Jan–Feb. 1996;15(1):2-3. Editorial. [pmid: 8631217].
1414 Johnson SH. Coping with census fluctuations. Nurs Manage. Oct. 1998;29(10):48L. Comment.
1415 Johnston CL. Changing care patterns and registered nurse job satisfaction. Holist Nurs Pract. Apr. 1997;11(3):69-77. Review. [pmid: 9165788].
1416 Johnstone L. Mental health. In the same boat?. Nurs Times. Jul 7–13. 1993;89(27):30-31. Comment. [pmid: 8159528].
1417 Jolley S. Promoting teenage sexual health: an investigation into the knowledge, activities and perceptions of gynaecology nurses. J Adv Nurs. Oct. 2001;36(2):246-255. Not eligible target population. [pmid: 11580799].
1418 Jones A. Perceptions on individualized approaches to mental health care. J Psychiatr Ment Health Nurs. Aug. 2005;12(4):396-404. Not eligible target population. [pmid: 16011494].
1419 Jones CB. The costs of nurse turnover, part 2: application of the Nursing Turnover Cost Calculation Methodology. J Nurs Adm. Jan. 2005;35(1):41-49. Not eligible outcomes. [pmid: 15647669].
1420 Jones D. I am that agency nurse. Accid Emerg Nurs. Jan. 1998;6(1):51-52. Comment. [pmid: 9528520].
1421 Jones GJ, Vanderpump MP, Easton M, Baker DM, Ball C, Leenane M, O'Brien H, Turner N, Else M, Reid WM, Johnson M. Achieving compliance with the European Working Time Directive in a large teaching hospital: a strategic approach. Clin Med. Sep–Oct. 2004;4(5):427-430. Not eligible target population. [pmid: 15536871].
1422 Jones HE, Cleave B, Zinman B, Szalai JP, Nichol HL, Hoffman BR. Efficacy of feedback from quarterly laboratory comparison in maintaining quality of a hospital capillary blood glucose monitoring program. Diabetes Care. Feb. 1996;19(2):168-170. Not eligible exposure. [pmid: 8718440].
1423 Jones IH. Night moves. Nurs Times. May 2–8. 1990;86(18):21. Comment. [pmid: 2342912].
1424 Jones J, Black N, Sanderson C. Levels of nurse staffing. Sr Nurse. Jan–Feb. 1993;13(1):20-24. Comment. [pmid: 8460298].
1425 Jones J, Ward M, Wellman N, Hall J, Lowe T. Psychiatric inpatients' experience of nursing observation. A United Kingdom perspective. J Psychosoc Nurs Ment Health Serv. Dec. 2000;38(12):10-20. Not eligible target population. [pmid: 11131403].
1426 Jones JS, Holstege CP, Riekse R, White L, Bergquist T. Metered-dose inhalers: do emergency health care providers know what to teach?. Ann Emerg Med. Sep. 1995;26(3):308-311. Not eligible exposure. [pmid: 7661420].
1427 Jones K, Yancer DA, McGinley SJ, Galbraith P. An agency-staffed nursing unit project. Nurs Manage. Oct 1990;21(10):36–37, 40. No association tested.
1428 Jones M. Stress and burnout in nursing: causes and prevention. Okla Nurse. Apr–Jun. 1996;41(2):20-21. Comment. [pmid: 8826128].
1429 Jones S. Managing pain using the partnership model of care. Paediatr Nurs. Feb. 1995;7(1):21-24. No association tested. [pmid: 7704638].
1430 Jordan C, Tabone S. Mandatory overtime and on call: growing concerns for nurses. Tex Nurs. Sep. 2000;74(8):4-6. Comment.
1431 Jordan CB. Nurse staffing: are the answers emerging? Tex Nurs. May 2000;74(5):4–5, 15. Comment.
1432 Jordan CB. Preparing for the 2001 Texas Legislative session. Nurse staffing. What's adequate? What'ssafe? Tex Nurs. Feb 2000;74(2):4–5, 10. Comment.
1433 Jorde R, Nordoy A. Improvement in clinical work through feedback: intervention study. Bmj. Jun 26. 1999;318(7200):1738-1739. Not eligible target population. [pmid: 10381710]. [pmcid: 31103].
1434 Joseph HJ. Attitudes and cultural self-efficacy levels of nurses caring for patients in army hospitals. J Natl Black Nurses Assoc. Jul. 2004;15(1):5-16. Not eligible target population. [pmid: 15712815].
1435 Jung FD, Pearcey LG, Phillips JL. Evaluation of a program to improve nursing assistant use. J Nurs Adm. Mar. 1994;24(3):42-47. Not eligible exposure. [pmid: 8133325].
1436 Junger A, Brenck F, Hartmann B, Klasen J, Quinzio L, Benson M, Michel A, Rohrig R, Hempelmann G. Automatic calculation of the nine equivalents of nursing manpower use score (NEMS) using a patient data management system. Intensive Care Med. Jul. 2004;30(7):1487-1490. Not eligible target population. [pmid: 15085320].
1437 Kafkia T, Kourakos M, Lagkazali B, Eleftheroudi M, Tsougia P, Doula M, Laskari A, Thanassa G, De Vos JY, Elseviers M. European practice database: results from Greece. Edtna Erca J. Jan–Mar. 2005;31(1):43-48. Not eligible target population. [pmid: 16083028].
1438 Kageyama T, Kobayashi T, Nishikido N, Oga J, Kawashima M. Associations of sleep problems and recent life events with smoking behaviors among female staff nurses in Japanese hospitals. Ind Health. Jan. 2005;43(1):133-141. Not eligible target population. [pmid: 15732316].
1439 Kageyama T, Nishikido N, Kobayashi T, Oga J, Kawashima M. Cross-sectional survey on risk factors for insomnia in Japanese female hospital nurses working rapidly rotating shift systems. J Hum Ergol (Tokyo). Dec. 2001;30(12):149-154. Not eligible target population. [pmid: 14564874].
1440 Kaissi A, Johnson T, Kirschbaum MS. Measuring teamwork and patient safety attitudes of high-risk areas. Nurs Econ. Sep–Oct 2003;21(5):211–218, 207. Not eligible exposure.
1441 Kamineni S, Higgins A, Edmunds C. Specialist surgical nursing assistant. Br J Hosp Med. Feb 5–18. 1997;57(3):112. Letter. [pmid: 9196596].
1442 Kandolin I, Huida O. Individual flexibility: an essential prerequisite in arranging shift schedules for midwives. J Nurs Manag. Jul. 1996;4(4):213-217. Not eligible target population. [pmid: 8868708].
1443 Kane D. Job sharing as a part-time employment alternative. J Nurs Adm. Mar. 1995;25(3):5-33. Comment. [pmid: 7884529].
1444 Kane D. Job sharing: a retention strategy for nurses. Can J Nurs Leadersh. Nov–Dec. 1999;12(4):16-22. Not eligible exposure. [pmid: 11094939].
1445 Kane-Urrabazo C. Should you dive into that float assignment?. Nursing. Jun. 2004;34(6):64. Comment. [pmid: 15187719].
1446 Kangas S, Kee CC, McKee-Waddle R. Organizational factors, nurses' job satisfaction, and patient satisfaction with nursing care. J Nurs Adm. Jan. 1999;29(1):32-42. Not eligible exposure. [pmid: 9921147].
1447 Kanji Z. Implementation of a sedation and analgesia scale. J Nurs Care Qual. Jan–Mar. 2005;20(1):13-15. Not eligible exposure. [pmid: 15686072].
1448 Kany K. How can nurses combat mandatory overtime?. Am J Nurs. Aug. 1999;99(8):77. Comment. [pmid: 10456027].
1449 Kany K. Combating staffing problems. Am J Nurs. Apr. 1999;99(4):68. Comment. [pmid: 10234328].
1450 Kany K. Policy vs. reality. Am J Nurs. May. 2001;101(5):87. Comment. [pmid: 11355502].
1451 Kaplan M. Hospital caregivers are in a bad mood. Am J Nurs. Mar. 2000;100(3):25. Comment. [pmid: 10738397].
1452 Kaplow R. AACN Synergy Model for Patient Care: a framework to optimize outcomes. Crit Care Nurse. Feb 2003;Suppl:27–30. Review.
1453 Kaprowy J, Schilder E. Restraint or martial arts: should nurses tie people down?. Ky Hosp Mag. Winter. 1991;8(1):12-16. Comment. [pmid: 10109282].
1454 Karadeniz G, Cakmakci A. Nurses' perceptions of medication errors. Int J Clin Pharmacol Res. 2002;22(34):111-116. Not eligible target population. [pmid: 12837048].
1455 Karas C. RN staffing is key. Hosp Health Netw. Aug. 2001;75(8):16. Comment. [pmid: 11573434].
1456 Karch AM, Karch FE. What did you say? I can't quite understand your spoken order. Am J Nurs. Aug. 1999;99(8):12. Case Reports.
1457 Karch AM, Karch FE. The naked decimal point. And eight other common errors that can be avoided. Am J Nurs. Dec. 2001;101(12):22. Case Reports. [pmid: 12585062].
1458 Kardos L, Szeles G, Gombkoto G, Szeremi M, Tompa A, Adany R. Cancer deaths among hospital staff potentially exposed to ethylene oxide: an epidemiological analysis. Environ Mol Mutagen. 2003;42(1):59-60. Not eligible target population. [pmid: 12874814].
1459 Karkkainen O, Eriksson K. Recording the content of the caring process. J Nurs Manag. May. 2005;13(3):202-208. Not eligible target population. [pmid: 15819832].
1460 Karlowicz MG, McMurray JL. Comparison of neonatal nurse practitioners' and pediatric residents' care of extremely low-birth-weight infants. Arch Pediatr Adolesc Med. Nov. 2000;154(11):1123-1126. Not eligible exposure. [pmid: 11074854].
1461 Kater V, Braverman N, Chuwers P. Would provision of childcare for nurses with young children ensure response to a call-up during a wartime disaster? An Israeli hospital nursing survey. Public Health Rev. 1992;20(34):313-316. Not eligible exposure. [pmid: 1343368].
1462 Kauffmann E, Harrison MB, Burke SO, Wong C. Stress-point intervention for parents of children hospitalized with chronic conditions. Pediatr Nurs. Jul–Aug. 1998;24(4):362-366. Not eligible exposure. [pmid: 9849271].
1463 Kautzman L, Miller LH. Growing replacements for our ‘graying’ perioperative nurses. Todays Surg Nurse. Mar–Apr. 1999;21(2):22-25. Comment. [pmid: 10232286].
1464 Kavanaugh K, Engstrom JL, Meier PP, Lysakowski TY. How reliable are scales for weighing preterm infants?. Neonatal Netw. Oct. 1990;9(3):29-32. Not eligible exposure. [pmid: 2215443].
1465 Kawik L. Nurses' and parents' perceptions of participation and partnership in caring for a hospitalized child. Br J Nurs. Apr 11–24. 1996;5(7):430-437. Not eligible target population. [pmid: 8788392].
1466 Kaya S, Vural G, Eroglu K, Sain G, Mersin H, Karabeyoglu M, Sezer K, Turkkani B, Restuccia JD. Liability and validity of the Appropriateness Evaluation Protocol in Turkey. Int J Qual Health Care. Aug. 2000;12(4):325-329. Not eligible target population. [pmid: 10985271].
1467 Kaye W, Mancini ME, Giuliano KK, Richards N, Nagid DM, Marler CA, Sawyer-Silva S. Strengthening the in-hospital chain of survival with rapid defibrillation by first responders using automated external defibrillators: training and retention issues. Ann Emerg Med. Feb. 1995;25(2):163-168. Not eligible exposure. [pmid: 7832341].
1468 Kayuha AA. Acclimating to shift work—a survival kit. Healthc Trends Transit. Apr 1990;1(5):18, 20, 22–15. No association tested.
1469 Keatinge D, Gilmore V. Shared care: a partnership between parents and nurses. Aust J Adv Nurs. Sep–Nov. 1996;14(1):28-36. Not eligible target population. [pmid: 9128467].
1470 Keddy B, Gregor F, Foster S, et al. Theorizing about nurses' work lives: the personal and professional aftermath of living with healthcare ‘reform’. Nursing inquiry. Mar. 1999;6(1):58-64. Not relevant. [pmid: 10647401].
1471 Keenan GM, Cooke R, Hillis SL. Norms and nurse management of conflicts: keys to understanding nurse-physician collaboration. Res Nurs Health. Feb. 1998;21(1):59-72. Not eligible exposure. [pmid: 9472238].
1472 Keim J, Robinson S. Work environment factors influencing burnout among third shift nurses. J Nurs Adm. Nov. 1992;22(11):52-56. Comment. [pmid: 1432228].
1473 Keller KL. The management of stress and prevention of burnout in emergency nurses. J Emerg Nurs. Mar–Apr. 1990;16(2):90-95. Not eligible exposure. [pmid: 2181198].
1474 Keller LO, Strohschein S, Lia-Hoagberg B, Schaffer M. Population-based public health nursing interventions: a model from practice. Public Health Nurs. Jun. 1998;15(3):207-215. Not eligible exposure. [pmid: 9629035].
1475 Kellett J. Taking the blame. Nurs Stand. Dec 11. 1996;11(12):21-23. Not eligible target population. [pmid: 8974248].
1476 Kelley LS, Swanson E, Maas ML, Tripp-Reimer T. Family visitation on special care units. J Gerontol Nurs. Feb. 1999;25(2):14-21. Not eligible exposure. [pmid: 10347433].
1477 Kelly AM. Nurse-managed analgesia for renal colic pain in the emergency department. Aust Health Rev. 2000;23(2):185-189. Not eligible target population. [pmid: 11010571].
1478 Kelly AM, Miljesic S, Mant P, Ashton W. Plaster checks by nurses: safe and efficient?. Accid Emerg Nurs. Apr. 1996;4(2):76-77. Not eligible exposure. [pmid: 8716423].
1479 Kelly B. Hospital nursing: ‘it's a battle!’ A follow-up study of English graduate nurses. J Adv Nurs. Nov. 1996;24(5):1063-1069. No association tested. [pmid: 8933268].
1480 Kelly M, Williams C, Murdoch I. Comparison of costing tools in paediatric intensive care. Paediatr Nurs. Nov. 1999;11(9):14-16. Not eligible target population. [pmid: 10723376].
1481 Kelly TM, Donovan K. Cardiac rehabilitation in the time of health-care reform. AACN Clin Issues. Aug. 1995;6(3):432-442. Not eligible exposure. [pmid: 7627787].
1482 Kemper KJ, Benson MS, Bishop MJ. Interobserver variability in assessing pediatric postextubation stridor. Clin Pediatr (Phila). Jul. 1992;31(7):405-408. Not eligible exposure. [pmid: 1617865].
1483 Kemppainen JK, Dubbert PM, McWilliams P. Effects of group discussion and guided patient care experience on nurses' attitudes towards care of patients with AIDS. J Adv Nurs. Aug. 1996;24(2):296-302. Not eligible target population. [pmid: 8858433].
1484 Kendig EL Jr, Kirkpatrick BV, Carter WH, Hill FA, Caldwell K, Entwistle M. Underreading of the tuberculin skin test reaction. Chest. May. 1998;113(5):1175-1177. Not eligible exposure. [pmid: 9596290].
1485 Kenney PA. Maintaining quality care during a nursing shortage using licensed practical nurses in acute care. J Nurs Care Qual. Jul. 2001;15(4):60-68. Not eligible exposure. [pmid: 11452642].
1486 Kenny MF, Gapas J, Hilton G. Cross utilization in critical care. Nurs Manage. May 1995;26(5):48D, 48F–48I. No association tested.
1487 Kenny P, King MT, Cameron S, Shiell A. Satisfaction with postnatal care—the choice of home or hospital. Midwifery. Sep. 1993;9(3):146-153. Not eligible exposure. [pmid: 8412835].
1488 Keogh A, Dealey C. Profiling beds versus standard hospital beds: effects on pressure ulcer incidence outcomes. J Wound Care. Feb. 2001;10(2):15-19. Not eligible exposure. [pmid: 12964222].
1489 Kercher LL. Appropriate staffing: our right, our responsibility. Nurs Manage. Feb. 1999;30(2):4. Editorial. [pmid: 10188502].
1490 Kerfoot KM, Cox M. The synergy model: the ultimate mentoring model. Crit Care Nurs Clin North Am. Jun 2005;17(2):109–112, ix. Comment.
1491 Kern D, Kettner P, Albrizio M. An exploration of the variables involved when instituting a do-not-resuscitate order for patients undergoing bone marrow transplantation. Oncol Nurs Forum. May. 1992;19(4):635-640. Not eligible exposure. [pmid: 1603678].
1492 Kerr MP. A qualitative study of shift handover practice and function from a socio-technical perspective. J Adv Nurs. Jan. 2002;37(2):125-134. Not eligible target population. [pmid: 11851780].
1493 Kester-Beaver P. Tales from travelers. Am J Nurs. Apr. 1991;91(4):50-56. Comment. [pmid: 2014813].
1494 Ketter J. Have you worked through lunch lately? Fair Labor Standards Act protectsRNs against wage abuse. Am Nurse. Jul–Aug. 1995;27(5):14. Comment. [pmid: 7653900].
1495 Ketter J. ANA and SNAs tackle hospital restructuring. Am Nurse. Mar. 1995;27(2):8-18. Comment.
1496 Khan ZU, Chandy R, Metwali KE. Candida albicans strain carriage in patients and nursing staff of an intensive care unit: a study of morphotypes and resistotypes. Mycoses. Dec. 2003;46(1112):479-486. Not eligible target population. [pmid: 14641621].
1497 Kidner MC. How to keep float nurses from sinking. Rn. Sep. 1999;62(9):35-39. Comment. [pmid: 10542638].
1498 Kiekkas P, Poulopoulou M, Papahatzi A, Androutsopoulou C, Maliouki M, Prinou A. Workload of postanaesthesia care unit nurses and intensive care overflow. Br J Nurs. Apr 28–May 11. 2005;14(8):434-438. Not eligible target population. [pmid: 15924023].
1499 Killeen MB. A system with many methods to adjust staffing. Mich Nurse. Sep 2004:13–15. Comment.
1500 Kinard J, Little B. Are hospitals facing a critical shortage of skilled workers?. Health Care Superv. Jun. 1999;17(4):54-62. No association tested. [pmid: 10537685].
1501 King LA, Wasdovich A, Young C. Transforming nursing practice: clinical systems and the nursing unit of the future. J Healthc Inf Manag. Summer. 2004;18(3):32-36. Not eligible exposure. [pmid: 15301415].
1502 King RB, Shaw K, Adams JG. ED overcrowding-meeting many needs. Pediatr Emerg Care. Oct. 2004;20(10):710-716. Interview. [pmid: 15454750].
1503 King S. Goodbye Holladay Park. Oreg Nurse. Sep. 1994;59(3):3. Comment.
1504 King S. Hospital nurse staffing—the public's interest. Oreg Nurse. Sep. 1999;64(3):3. Comment.
1505 King S. Safe staffing levels for children's wards. Paediatr Nurs. Mar. 2000;12(2):28-31. No association tested. [pmid: 11220842].
1506 King S. Hospital staffing law effective Oct. 1. Oreg Nurse. Sep. 2002;67(3):1-8. Legal Cases. [pmid: 12298316].
1507 Kinley H, Czoski-Murray C, George S, McCabe C, Primrose J, Reilly C, Wood R, Nicolson P, Healy C, Read S, Norman J, Janke E, Alhameed H, Fernandes N, Thomas E. Effectiveness of appropriately trained nurses in preoperative assessment: randomised controlled equivalence/non-inferiority trial. Bmj. Dec 7. 2002;325(7376):1323. Not eligible target population. [pmid: 12468478]. [pmcid: 137803].
1508 Kinley H, Czoski-Murray C, George S, McCabe C, Primrose J, Reilly C, Wood R, Nicolson P, Healy C, Read S, Norman J, Janke E, Alhameed H, Fernandez N, Thomas E. Extended scope of nursing practice: a multicentre randomised controlled trial of appropriately trained nurses and pre-registration house officers in pre-operative assessment in elective general surgery. Health Technol Assess. 2001;5(20):1-87. Not eligible target population.
1509 Kinn S, Scott J. Nutritional awareness of critically ill surgical high-dependency patients. Br J Nurs. Jun 14–27. 2001;10(11):704-709. Not eligible target population. [pmid: 12048485].
1510 Kinney M. Flexible scheduling and part-time work: what price do we pay?. Focus Crit Care. Dec. 1990;17(6):439. Editorial. [pmid: 2265720].
1511 Kinrade S. Acting against discrimination. Prof Nurse. Aug. 2003;18(12):714-715. Not eligible target population. [pmid: 12955946].
1512 Kirby KK, Garfink CM. The University Hospital Nurse Extender Model. Part I, An overview and conceptual framework. J Nurs Adm. Jan. 1991;21(1):25-30. Not eligible target population. [pmid: 1987339].
1513 Kirchhoff KT, Beckstrand RL. Critical care nurses' perceptions of obstacles and helpful behaviors in providing end-of-life care to dying patients. Am J Crit Care. Mar. 2000;9(2):96-105. Not eligible exposure. [pmid: 10705423].
1514 Kirchhoff KT, Mateo MA. Roles and responsibilities of clinical nurse researchers. J Prof Nurs. Mar–Apr. 1996;12(2):86-90. Not eligible exposure. [pmid: 8632106].
1515 Kirkhart DG. Shared care: improving health care, reducing costs. Nurs Manage. Jun 1995;26(6):26, 28, 30 passim. Not eligible exposure.
1516 Kirsch E, Talbott J. Outpatient and short-stay patient classification systems. Nurs Manage. Sep 1990;21(9):118–119, 122. No association tested.
1517 Kitajima T, Ohida T, Harano S, Kamal AM, Takemura S, Nozaki N, Kawahara K, Minaowa M. Smoking behavior, initiating and cessation factors among Japanese nurses: a cohort study. Public Health. Nov. 2002;116(6):347-352. Not eligible target population. [pmid: 12407474].
1518 Kivimaki M, Makinen A, Elovainio M, Vahtera J, Virtanen M, Firth-Cozens J. Sickness absence and the organization of nursing care among hospital nurses. Scand J Work Environ Health. Dec. 2004;30(6):468-476. quiz 476. Not eligible target population. [pmid: 15633598].
1519 Kjellberg K, Lagerstrom M, Hagberg M. Patient safety and comfort during transfers in relation to nurses' work technique. J Adv Nurs. Aug. 2004;47(3):251-259. Not eligible target population. [pmid: 15238119].
1520 Kleinbeck SV, McKennett M. Challenges of measuring intraoperative patient outcomes. Aorn J. Nov 2000;72(5):845–850, 853. No association tested.
1521 Kleinman C. The relationship between managerial leadership behaviors and staff nurse retention. Hosp Top. Fall. 2004;82(4):2-9. Not eligible outcomes. [pmid: 15898399].
1522 Kluska KM, Laschinger HK, Kerr MS. Staff nurse empowerment and effort-reward imbalance. Can J Nurs Leadersh. Mar. 2004;17(1):112-128. Not eligible exposure. [pmid: 15503922].
1523 Knight P, Cassady G. Control of infection due to Klebsiella pneumoniae in an intensive care nursery. J Perinatol. Dec. 1990;10(4):357-360. Not eligible exposure. [pmid: 2277281].
1524 Kobylus K. Innovations, local solutions arise from the shortage. Healthtexas. Mar. 1991;46(9):15-16. comment. [pmid: 10109784].
1525 Koch F. Staffing outcomes: skill mix changes. Semin Perioper Nurs. Jan. 1996;5(1):32-35. No association tested. [pmid: 8696287].
1526 Koenig HG, Bearon LB, Hover M, Travis JL 3rd. Religious perspectives of doctors, nurses, patients, and families. J Pastoral Care. Fall. 1991;45(3):254-267. Not eligible exposure. [pmid: 10114080].
1527 Koivisto K, Janhonen S, Vaisanen L. Patients' experiences of being helped in an inpatient setting. J Psychiatr Ment Health Nurs. Jun. 2004;11(3):268-275. Not eligible target population. [pmid: 15149373].
1528 Koivula M, Paunonen M, Laippala P. Prerequisites for quality improvement in nursing. J Nurs Manag. Nov. 1998;6(6):333-342. Not eligible target population. [pmid: 10076266].
1529 Kollee I, Pearson E. Hemodialysis teaching protocols: an educational tool for both patients and nurses. Cannt J. Apr–Jun. 2000;10(2):26-29. Not eligible exposure. [pmid: 15712465].
1530 Kollef MH, Shapiro SD, Silver P, St John RE, Prentice D, Sauer S, Ahrens TS, Shannon W, Baker-Clinkscale D. A randomized, controlled trial of protocol-directed versus physician-directed weaning from mechanical ventilation. Crit Care Med. Apr. 1997;25(4):567-574. Not eligible exposure. [pmid: 9142019].
1531 Koncar DR. A day in the life ... sudden shifts. Debbie Cuaresma, RN cardiac nurse. Revolution. Nov–Dec. 2001;2(6):18-21. Interview.
1532 Kooijman CJ, Klaassen-Leil CC. Extraction, preparation, and presentation of patient classification-data for the benefit of management overviews. Medinfo. 1995;8(Pt 2):1382-1385. Not eligible target population. [pmid: 8591455].
1533 Korst LM, EusebioAngeja AC, Chamorro T, et al. Nursing documentation time during implementation of an electronic medical record. Journal of Nursing Administration. Jan. 2003;33(1):24-30. Not relevant. [pmid: 12544622].
1534 Kosgeroglu N, Ayranci U, Vardareli E, Dincer S. Occupational exposure to hepatitis infection among Turkish nurses: frequency of needle exposure, sharps injuries and vaccination. Epidemiol Infect. Jan. 2004;132(1):27-33. Not eligible target population. [pmid: 14979586].
1535 Kosowsky JM, Shindel S, Liu T, Hamilton C, Pancioli AM. Can emergency department triage nurses predict patients' dispositions?. Am J Emerg Med. Jan. 2001;19(1):10-14. Not eligible exposure. [pmid: 11146009].
1536 Kovner C, Stave CM, Lavelle K, et al. An analysis of vacancy rates, turnover, and wages among nursing occupations in New York state hospitals, nursing homes, and diagnostic and treatment facilities. Journal of the New York State Nurses Association. Sep. 1994;25(3):20-7. Not peer reviewed.
1537 Kovner CT. State regulation of RN-to-patient ratios. Am J Nurs. Nov 2000;100(11):61–63, 65. Review.
1538 Kovner CT, Harrington C. The changing picture of hospital nurses. Am J Nurs. May. 2002;102(5):93-94. Review. [pmid: 12006860].
1539 Kramer M, Schmalenberg C. Job satisfaction and retention. Insights for the '90s. Part 2. Nursing. Apr. 1991;21(4):51-55. Not eligible exposure. [pmid: 2020421].
1540 Kramer M, Schmalenberg C. Development and evaluation of essentials of magnetism tool. J Nurs Adm. Jul–Aug. 2004;34(78):365-378. Not eligible exposure. [pmid: 15303055].
1541 Kramer M, Schmalenberg C. Revising the Essentials of Magnetism tool: there is more to adequate staffing than numbers. J Nurs Adm. Apr. 2005;35(4):188-198. Not eligible exposure. [pmid: 15834258].
1542 Kramer M, Schmalenberg C, Maguire P. Essentials of a magnetic work environment: part 3. Nursing. Aug. 2004;34(8):44-47. Not eligible exposure.
1543 Kreplick J. Unlicensed hospital assistive personnel: efficiency or liability?. J Health Hosp Law. Sep–Oct. 1995;28(5):292-309. Review. [pmid: 10156295].
1544 Krishnasamy M. What do cancer patients identify as supportive and unsupportive behaviour of nurses? A pilot study. Eur J Cancer Care (Engl). Jun. 1996;5(2):103-110. Not eligible exposure. [pmid: 8716206].
1545 Kristensson-Hallstrom I. Strategies for feeling secure influence parents' participation in care. J Clin Nurs. Sep. 1999;8(5):586-592. Not eligible target population. [pmid: 10786532].
1546 Kromhout H, Hoek F, Uitterhoeve R, Huijbers R, Overmars RF, Anzion R, Vermeulen R. Postulating a dermal pathway for exposure to anti-neoplastic drugs among hospital workers. Applying a conceptual model to the results of three workplace surveys. Ann Occup Hyg. Oct. 2000;44(7):551-560. Not eligible target population. [pmid: 11042258].
1547 Kroposki M, Murdaugh CL, Tavakoli AS, Parsons M. Role clarity, organizational commitment, and job satisfaction during hospital reengineering. Nursing connections. Spring. 1999;12(1):27-34. Not eligible exposure. [pmid: 10401399].
1548 Krugman M, Smith V. Charge nurse leadership development and evaluation. J Nurs Adm. May. 2003;33(5):284-292. Not eligible exposure. [pmid: 12792283].
1549 Ksykiewicz-Dorota A. Development of nursing time standards as a problem of optimalisation of health care system management. II. Comparative analysis of demand for nursing care. Ann Univ Mariae Curie Sklodowska [Med]. 1999;54:87-96. Not eligible target population.
1550 Ksykiewicz-Dorota A. Development of nursing time standards as a problem of optimalisation of health care system management. I. Evaluation of the correctness of patients' classification. Ann Univ Mariae Curie Sklodowska [Med]. 1999;54:79-86. Not eligible target population.
1551 Ksykiewicz-Dorota A, Wysokinski M. Special characteristics of nursing staff scheduling in intensive care units. Ann Univ Mariae Curie Sklodowska [Med]. 2001;56:313-318. Not eligible target population.
1552 Kubecka KE, Simon JM, Boettcher JH. Pain management knowledge of hospital-based nurses in a rural Appalachian area. J Adv Nurs. May. 1996;23(5):861-867. Not eligible exposure. [pmid: 8732510].
1553 Kubisiak J. Is this midwifery? Midwifery Today Int Midwife. Summer 1998(46):42. Comment.
1554 Kuhn EM, Hartz AJ, Gottlieb MS, Rimm AA. The relationship of hospital characteristics and the results of peer review in six large states. Med Care. Oct. 1991;29(10):1028-1038. Not eligible exposure. [pmid: 1921522].
1555 Kumarich D, Biordi DL, Milazzo-Chornick N. The impact of the 23-hour patient on nursing workload. J Nurs Adm. Nov. 1990;20(11):47-52. Not eligible exposure. [pmid: 2231015].
1556 Kupferman K. 10 ways to help students grow. Nursing. Apr. 2005;35(4):56. Comment. [pmid: 15818258].
1557 Kurian VA. Life-style impact for Christ. Christ Nurse Int. 1995;11(3):5. Comment. [pmid: 7656261].
1558 Kutash MB, Nelson D. Optimizing the use of nursing pool resources. J Nurs Adm. Jan. 1993;23(1):65-68. No association tested. [pmid: 8433178].
1559 Kydd A. Education and training in dementia care. Community Nurse. Jan. 2000;5(12):15-16. Comment. [pmid: 11189658].
1560 Kyle F. Your shift penalties under attack. Aust Nurses J. Apr. 1990;19(9):10-11. Not eligible target population. [pmid: 2372259].
1561 Lacombe DC. Avoiding a malpractice nightmare. Nursing. Jun. 1990;20(6):42-43. Case Reports. [pmid: 2362725].
1562 Lacovara JE. Does your acuity system come up short?. Nurs Manage. Jun. 1999;30(6):40A-40C. Not eligible exposure.
1563 LaDuke S. It can happen to you: the firsthand accounts of six nurses accused of and disciplined for professional misconduct. J Emerg Nurs. Aug. 2001;27(4):369-376. Legal cases. [pmid: 11468633].
1564 Lageson C. Quality focus of the first line nurse manager and relationship to unit outcomes. J Nurs Care Qual. Oct–Dec. 2004;19(4):336-342. Not eligible exposure. [pmid: 15535539].
1565 Laitinen P, Isola A. Promoting participation of informal caregivers in the hospital care of the elderly patient: informal caregivers' perceptions. J Adv Nurs. May. 1996;23(5):942-947. Not eligible target population. [pmid: 8732521].
1566 Lalani NS, Gulzar AZ. Nurses' role in patients' discharge planning at the Aga Khan University Hospital, Pakistan. J Nurses Staff Dev. Nov–Dec. 2001;17(6):314-319. Not eligible target population. [pmid: 11840014].
1567 Lamb J, Ross S. Pain management. A patient's perspective. Can Nurse. Aug. 1999;95(7):30-33. Comment. [pmid: 11141611].
1568 Lamb LS Jr, Parrish RS, Goran SF, Biel MH. Current nursing practice of point-of-care laboratory diagnostic testing in critical care units. Am J Crit Care. Nov. 1995;4(6):429-434. Not eligible exposure. [pmid: 8556083].
1569 Lambert C. In the red. Nurs Times. Oct 27–Nov 2. 1999;95(43):16-17. Comment. [pmid: 10847070].
1570 Lambing AY, Adams DL, Fox DH, Divine G. Nurse practitioners' and physicians' care activities and clinical outcomes with an inpatient geriatric population. J Am Acad Nurse Pract. Aug. 2004;16(8):343-352. Not eligible exposure. [pmid: 15455707].
1571 Lamkin L, Rosiak J, Buerhaus P, Mallory G, Williams M. Oncology Nursing Society Workforce Survey. Part II: perceptions of the nursing workforce environment and adequacy of nurse staffing in outpatient and inpatient oncology settings. Oncol Nurs Forum. Jan–Feb. 2002;29(1):93-100. Not eligible outcomes. [pmid: 11817495].
1572 Lampat L, Frederick B, Young D, Dankbar G. Changing the start of the hospital workweek. Nurs Econ. Jul–Aug. 1991;9(4):263-265. Not eligible exposure. [pmid: 1922428].
1573 Lancaster R. Lifting the lid. Nurs Stand. Aug 5–11. 1998;12(46):20-22. Comment. [pmid: 9823149].
1574 Lancelot A, Sims J. Mental illness and substance abuse. Nurs Times. Sep 27–Oct 3. 2001;97(39):36-37. Case reports. [pmid: 11935769].
1575 Landergan E. Staffing for census fluctuations. Nurs Manage. May. 1997;28(5):77-78. Comment. [pmid: 9287803].
1576 Landreville P, Dicaire L, Verrault R, et al. A training program for managing agitation of residents in longterm care facilities: description and preliminary findings. Journal of gerontological nursing Mar 2005;31(3):34–42, 55–6. Nursing home.
1577 Lang TA, Hodge M, Olson V, Romano PS, Kravitz RL. Nurse-patient ratios: a systematic review on the effects of nurse staffing on patient, nurse employee, and hospital outcomes. J Nurs Adm. Jul–Aug. 2004;34(78):326-337. Review. [pmid: 15303051].
1578 Langslow A. Nursing and the law. Vigilance in the OR. Aust Nurs J. Oct. 1996;4(4):30-32. Case Reports. [pmid: 8924095].
1579 Lankshear AJ, Sheldon TA, Maynard A. Nurse staffing and healthcare outcomes: a systematic review of the international research evidence. ANS Adv Nurs Sci. Apr–Jun. 2005;28(2):163-174. Review. [pmid: 15920362].
1580 Lanser EG. Leveraging your nursing resources. Healthc Exec. Jul–Aug. 2001;16(4):50-51. Comment. [pmid: 11434132].
1581 Lanza ML, Kayne HL, Hicks C, Milner J. Nursing staff characteristics related to patient assault. Issues Ment Health Nurs. Jun–Sep. 1991;12(3):253-265. Not eligible outcomes. [pmid: 2071386].
1582 Larcombe J. Bed-blockers. Mental block. Nurs Times. Jun 20–26. 1990;86(25):33-34. Case Reports. [pmid: 2359715].
1583 Lark K, Dean K, Mikos CA. Nursing liability risk—three perspectives. Fla Nurse. Mar. 2000;48(1):22-23. Legal Cases. [pmid: 11995164].
1584 Larkin GL, Rolniak S, Hyman KB, MacLeod BA, Savage R. Effect of an administrative intervention on rates of screening for domestic violence in an urban emergency department. Am J Public Health. Sep. 2000;90(9):1444-1448. Not eligible outcomes. [pmid: 10983204]. [pmcid: 1447616].
1585 Larkin H. The case for nurse practitioners. Used correctly, they can improve outcomes, lower costs and make up for reduced residents' hours. Hosp Health Netw. Aug 2003;77(8):54–58, 52. Not eligible exposure.
1586 Larrabee JH. Achieving outcomes in a joint-appointment role. Outcomes Manag Nurs Pract. Apr–Jun. 2001;5(2):52-56. Comment. [pmid: 11898327].
1587 Larrabee JH, Ostrow CL, Withrow ML, Janney MA, Hobbs GR Jr, Burant C. Predictors of patient satisfaction with inpatient hospital nursing care. Res Nurs Health. Aug. 2004;27(4):254-268. Not eligible exposure. [pmid: 15264264].
1588 Larson EL, Bryan JL, Adler LM, Blane C. A multifaceted approach to changing handwashing behavior. Am J Infect Control. Feb. 1997;25(1):3-10. Not eligible exposure. [pmid: 9057937].
1589 Larson EL, Cimiotti J, Haas J, Parides M, Nesin M, Della-Latta P, Saiman L. Effect of antiseptic handwashing vs alcohol sanitizer on health care-associated infections in neonatal intensive care units. Arch Pediatr Adolesc Med. Apr. 2005;159(4):377-383. Not eligible exposure. [pmid: 15809394].
1590 Larson L. Restoring the relationship: the key to nurse and patient satisfaction. Trustee. Oct 2004;57(9):8–10, 12–14, 11. Comment.
1591 Larsson G, Berg V. Linen in the hospital bed: effects on patients' well-being. J Adv Nurs. Aug. 1991;16(8):1004-1008. Not eligible target population. [pmid: 1779075].
1592 Larter J. Three-part model manages care from admission through postdischarge. Disch Plann Update. Mar–Apr 1993;13(2):1, 20–23. Not eligible outcomes.
1593 Laschinger HK. Almost J, Tuer-Hodes D. Workplace empowerment and magnet hospital characteristics: making the link. J Nurs Adm. Jul–Aug. 2003;33(78):410-422. Not eligible exposure. [pmid: 12909793].
1594 Laschinger HK, Finegan J, Shamian J, Casier S. Organizational trust and empowerment in restructured healthcare settings. Effects on staff nurse commitment. J Nurs Adm. Sep. 2000;30(9):413-425. Not eligible exposure. [pmid: 11006783].
1595 Laschinger HK, Finegan J, Shamian J, Wilk P. Impact of structural and psychological empowerment on job strain in nursing work settings: expanding Kanter's model. J Nurs Adm. May. 2001;31(5):260-272. Not eligible exposure. [pmid: 11388162].
1596 Laschinger HK, Wong C, McMahon L, Kaufmann C. Leader behavior impact on staff nurse empowerment, job tension, and work effectiveness. J Nurs Adm. May. 1999;29(5):28-39. Not eligible exposure. [pmid: 10333859].
1597 Laurent C. Ward managers. Too hot to handle?. Health Serv J. Aug 23. 2001;111(5769):22-25. Not eligible target population.
1598 Lauri S, Lepisto M, Kappeli S. Patients' needs in hospital: nurses' and patients' views. J Adv Nurs. Feb. 1997;25(2):339-346. Not eligible target population. [pmid: 9044009].
1599 Lawler K. How audit can improve provision of in-patient pain services. Prof Nurse. Sep. 2001;17(1):41. Comment. [pmid: 12030146].
1600 Lawson K. Trading places—a seasonal exchange program. Rn. Oct. 1990;53(10):19-21. No association tested. [pmid: 2218319].
1601 Lawson S, Aston S, Baker L, Fegan CD, Milligan DW. Trained nurses can obtain satisfactory bone marrow aspirates and trephine biopsies. J Clin Pathol. Feb. 1999;52(2):154-156. Not eligible target population. [pmid: 10396248]. [pmcid: 501065].
1602 Lawton LC, Rose P. Changing practice in invasive procedures: the experience of the Krishnan Chandran children's centre. J Child Health Care. Dec. 2003;7(4):248-257. Not eligible target population. [pmid: 14636430].
1603 Layon AJ, George BE, Hamby B, Gallagher TJ. Do elderly patients overutilize healthcare resources and benefit less from them than younger patients? A study of patients who underwent craniotomy for treatment of neoplasm. Crit Care Med. May. 1995;23(5):829-834. Not eligible exposure. [pmid: 7736739].
1604 Lazure LL. Strategies to increase patient control of visiting. Dimens Crit Care Nurs. Jan–Feb. 1997;16(1):11-19. Not eligible exposure. [pmid: 9016011].
1605 Le Blanc PM, de Jonge J, de Rijk AE, Schaufeli WB. Well-being of intensive care nurses (WEBIC): a job analytic approach. J Adv Nurs. Nov. 2001;36(3):460-470. Not eligible target population. [pmid: 11686761].
1606 Lea A, Bloodworth C. Modernising the 12-hour shift. Nurs Stand. Jan 22–28. 2003;17(19):33-36. Not eligible target population. [pmid: 12613422].
1607 Leach E. Have qualifications, will travel. Nurs Times. Apr 13–19. 2000;96(15):55-57. Comment. [pmid: 11309966].
1608 Leary TS, Milner QJ, Niblett DJ. The accuracy of the estimation of body weight and height in the intensive care unit. Eur J Anaesthesiol. Nov. 2000;17(11):698-703. Not eligible target population. [pmid: 11029569].
1609 L'Ecuyer PB, Schwab EO, Iademarco E, Barr N, Aton EA, Fraser VJ. Randomized prospective study of the impact of three needleless intravenous systems on needlestick injury rates. Infect Control Hosp Epidemiol. Dec. 1996;17(12):803-808. Not eligible exposure. [pmid: 8985767].
1610 Lee CS, Shiu AT. Perceived health care climate, diabetes knowledge and self-care practice of Hong Kong Chinese older patients: a pilot study. J Clin Nurs. May. 2004;13(4):534-535. Not eligible target population. [pmid: 15086640].
1611 Lee D. Overtime—mandatory or voluntary?. Br J Perioper Nurs. Feb. 2002;12(2):63. Not eligible target population. [pmid: 11889857].
1612 Lee DS. The morning tea break ritual: a case study. Int J Nurs Pract. Apr. 2001;7(2):69-73. Not eligible target population. [pmid: 11811319].
1613 Lee EH. Breast self-examination performance among Korean nurses. J Nurses Staff Dev. Mar–Apr. 2003;19(2):81-87. Not eligible target population. [pmid: 12679659].
1614 Lee EO, Ahn SH, You C, Lee DS, Han W, Choe KJ, Noh DY. Determining the main risk factors and high-risk groups of breast cancer using a predictive model for breast cancer risk assessment in South Korea. Cancer Nurs. Sep–Oct. 2004;27(5):400-406. Not eligible target population. [pmid: 15525868].
1615 Lee F. Violence in A&E: the role of training and self-efficacy. Nurs Stand. Aug 1–7. 2001;15(46):33-38. Not eligible target population. [pmid: 12214376].
1616 Lee G. The needs of the service. Pract Midwife. Feb. 2000;3(2):44. Comment. [pmid: 11040758].
1617 Lee H, Hwang S, Kim J, Daly B. Predictors of life satisfaction of Korean nurses. J Adv Nurs. Dec. 2004;48(6):632-641. Not eligible target population. [pmid: 15548254].
1618 Lee H, Song R, Cho YS, Lee GZ, Daly B. A comprehensive model for predicting burnout in Korean nurses. J Adv Nurs. Dec. 2003;44(5):534-545. Not eligible target population. [pmid: 14651702].
1619 Lee JM, Botteman MF, Nicklasson L, Cobden D, Pashos CL. Needlestick injury in acute care nurses caring for patients with diabetes mellitus: a retrospective study. Curr Med Res Opin. May. 2005;21(5):741-747. Not eligible exposure. [pmid: 15969873].
1620 Lee KA, Lipscomb J. Clinical update. Sleep among shiftworkers — a priority for clinical practice and research in occupational health nursing. AAOHN Journal. Oct. 2003;51(10):418-20. Not relevant. [pmid: 14596380].
1621 Lee KA. Self-reported sleep disturbances in employed women. Sleep. Dec. 1992;15(6):493-498. Not eligible outcomes. [pmid: 1475563].
1622 Lee KA, Rittenhouse CA. Prevalence of perimenstrual symptoms in employed women. Women Health. 1991;17(3):17-32. Not eligible outcomes. [pmid: 1957529].
1623 Lee KA, Rittenhouse CA. Health and perimenstrual symptoms: health outcomes for employed women who experience perimenstrual symptoms. Women Health. 1992;19(1):65-78. Not eligible exposure. [pmid: 1475996].
1624 Lee L, Goor E, Kennedy C, Walters S, Kirby L. Non-acute casemix in the Illawarra. J Qual Clin Pract. Mar. 1994;14(1):23-30. Not eligible target population. [pmid: 8199755].
1625 Lee RJ, Mills MEE. Management issues. International nursing recruitment experience. Journal of Nursing Administration. Nov. 2005;35(11):478-81. Not research. [pmid: 16282824].
1626 Lee S. Relocating elderly people and nursing staff from the NHS to the independent sector. J Adv Nurs. Oct. 1998;28(4):859-864. Not eligible target population. [pmid: 9829675].
1627 Lee S, Crockett MS. Effect of assertiveness training on levels of stress and assertiveness experienced by nurses in Taiwan, Republic of China. Issues Ment Health Nurs. Jul–Aug. 1994;15(4):419-432. Not eligible target population. [pmid: 8056571].
1628 Lee TH, Cook EF, Fendrick AM, Shammash JB, Wolfe EP, Weisberg MC, Goldman L. Impact of initial triage decisions on nursing intensity for patients with acute chest pain. Med Care. Aug. 1990;28(8):737-745. Not eligible exposure. [pmid: 2385143].
1629 Lee TT. Nurses' concerns about using information systems: analysis of comments on a computerized nursing care plan system in Taiwan. J Clin Nurs. Mar. 2005;14(3):344-353. Not eligible target population. [pmid: 15707445].
1630 Lee TT, Chang PC. Standardized care plans: experiences of nurses in Taiwan. J Clin Nurs. Jan. 2004;13(1):33-40. Not eligible target population. [pmid: 14687291].
1631 Lee YL, Cesario T, Tran C, Stone G, Thrupp L. Nasal colonization by methicillin-resistant coagulase-negative staphylococcus in community skilled nursing facility patients. Am J Infect Control. Jun. 2000;28(3):269-272. Not eligible target population. [pmid: 10840350].
1632 Lees L, Holmes C. Estimating date of discharge at ward level: a pilot study. Nurs Stand. Jan 5–11. 2005;19(17):40-43. Not eligible target population. [pmid: 15658837].
1633 Leftridge DW, Lydford CW. Decentralizing an overtime budget. Nurs Manage. Aug. 1993;24(8):52-53. No association tested. [pmid: 8345940].
1634 Leggett J, Silvester J. Care staff attributions for violent incidents involving male and female patients: a field study. Br J Clin Psychol. Nov. 2003;42(Pt 4):393-406. Not eligible target population. [pmid: 14633415].
1635 Leicht KT, Fennell ML, Witkowski KM. The effects of hospital characteristics and radical organizational change on the relative standing of health care professions. J Health Soc Behav. Jun. 1995;36(2):151-167. Not eligible outcomes. [pmid: 9113140].
1636 Leifer D. Anything but magnolia. Nurs Stand. Apr 3–9. 2002;16(29):16-17. Not eligible target population. [pmid: 11974697].
1637 Leifer D. A rotation programme that works. Nurs Stand. Mar 19–25. 2003;17(27):16. Comment.
1638 Leininger SM. Tools for building a successful orthopaedic pathway. Orthop Nurs. Mar–Apr. 1996;15(2):11-19. Not eligible exposure. [pmid: 8788606].
1639 Leino-Kilpi H, Valimaki M, Dassen T, Gasull M, Lemonidou C, Scott PA, Arndt M, Kaljonen A. Maintaining privacy on post-natal wards: a study in five European countries. J Adv Nurs. Jan. 2002;37(2):145-154. Not eligible target population. [pmid: 11851782].
1640 Leinonen T, Leino-Kilpi H, Stahlberg MR, Lertola K. Comparing patient and nurse perceptions of perioperative care quality. Appl Nurs Res. Feb. 2003;16(1):29-37. Not eligible target population. [pmid: 12624860].
1641 Lemmen SW, Zolldann D, Gastmeier P, Lutticken R. Implementing and evaluating a rotating surveillance system and infection control guidelines in 4 intensive care units. Am J Infect Control. Apr. 2001;29(2):89-93. Not eligible target population. [pmid: 11287875].
1642 Lemonidou C, Plati C, Brokalaki H, Mantas J, Lanara V. Allocation of nursing time. Scand J Caring Sci. 1996;10(3):131-136. Not eligible target population. [pmid: 9060782].
1643 Lenehan GP. ED short staffing: It is time to take a hard look at a growing problem and strategies such as standard nurse-patient ratios. J Emerg Nurs. Apr. 1999;25(2):77-78. Editorial. [pmid: 10097191].
1644 Lenehan GP. On mandatory overtime and wearing blue ribbons. J Emerg Nurs. Jun. 2000;26(3):201-202. Editorial. [pmid: 10839834].
1645 Lengacher CA, Kent K, Mabe PR, Heinemann D, VanCott ML, Bowling CD. Effects of the partners in care practice model on nursing outcomes. Nurs Econ. Nov–Dec. 1994;12(6):300-308. Not eligible exposure. [pmid: 7885486].
1646 Lengacher CA, Mabe PR, Heinemann D, VanCott ML, Kent K, Swymer S. Collaboration in research: testing the PIPC model on clinical and nonclinical outcomes. Nursingconnections. Spring. 1997;10(1):17-30. Not eligible exposure. [pmid: 9171689].
1647 Lepola I, Blom-Lange M. Participation in change: self-reflection of staff in a psychiatric admission unit. Nurs Health Sci. Sep. 1999;1(3):171-177. Not eligible target population. [pmid: 10894640].
1648 Leslie GD. Know your staff numbers—and know you're right. Aust Crit Care. Aug. 2003;16(3):83. Editorial. [pmid: 14533209].
1649 Letvak SA. Should a staff nurse's age be a consideration in making patient and shift assignments? Pro. MCN Am J Matern Child Nurs. Mar–Apr. 2005;30(2):84. Comment. [pmid: 15775800].
1650 Leveck ML, Jones CB. The nursing practice environment, staff retention, and quality of care. Res Nurs Health. Aug. 1996;19(4):331-343. Not eligible outcomes. [pmid: 8773556].
1651 Levenstam AK, Engberg IB. The Zebra system—a new patient classification system. J Nurs Manag. Sep. 1993;1(5):229-237. Not eligible target population. [pmid: 8313064].
1652 Levenstam AK, Engberg IB. How to translate nursing care into costs and staffing requirements: part two in the Zebra system. J Nurs Manag. Mar. 1997;5(2):105-114. Not eligible target population. [pmid: 9146210].
1653 Levy CR, Ely EW, Payne K, Engelberg RA, Patrick DL, Curtis JR. Quality of dying and death in two medical ICUs: perceptions of family and clinicians. Chest. May. 2005;127(5):1775-1783. Not eligible exposure. [pmid: 15888858].
1654 Lewandrowski K, Cheek R, Nathan DM, Godine JE, Hurxthal K, Eschenbach K, Laposata M. Implementation of capillary blood glucose monitoring in a teaching hospital and determination of program requirements to maintain quality testing. Am J Med. Oct. 1992;93(4):419-426. Not eligible exposure. [pmid: 1415305].
1655 Lewis EN. An in-house registry: a pragmatic approach that works! Nurs Manage. Feb 1991;22(2):43–44, 48. No association tested.
1656 Lewis JA, Della PR. Alternative nurse rostering: an evaluation. Aust Health Rev. 1994;17(2):29-39. Not eligible target population. [pmid: 10138377].
1657 Lewis KK. Nurse-to-patient ratios: research and reality. Issue Brief (Mass Health Policy Forum). Mar 30 2005(25):1–19. Review.
1658 Lewis L. Discussion & recommendations: safe medication administration: an invitational symposium recommends ways of addressing obstacles. J Infus Nurs. Mar–Apr 2005;28(2 Suppl):42–44, 46–47. Review.
1659 Lewis T, Abanobi B, Alleman P, et al. The Methodist Hospital CCU: a Beacon unit of excellence. Crit Care Nurs Clin North Am. Jun 2005;17(2):149–154, x. Review.
1660 Lewis T, Oliver G. Improving tracheostomy care for ward patients. Nurs Stand. Jan 19–25. 2005;19(19):33-37. Not eligible exposure. [pmid: 15700864].
1661 Libby DL, Bolduc PC. Float pool orientation. J Nurs Staff Dev. Nov–Dec. 1995;11(6):297-299. No association tested. [pmid: 8699265].
1662 Lichtenstein B, Brumfield C, Cliver S, Chapman V, Lenze D, Davis V. Giving birth, going home: influences on when low-income women leave hospital. Health (London). Jan. 2004;8(1):81-100. Not eligible exposure. [pmid: 15018719].
1663 Lilienberg A, Bengtsson M, Starkhammar H. Implantable devices for venous access: nurses' and patients' evaluation of three different port systems. J Adv Nurs. Jan. 1994;19(1):21-28. Not eligible target population. [pmid: 8138625].
1664 Lilley LL, Guanci R. Applying systems theory. Am J Nurs. Nov. 1995;95(11):14-15. Comment.
1665 Lilley LL, Guanci R. Sound-alike cephalosporins. How drugs with similar spellings and sounds can lead to serious errors. Am J Nurs. Jun. 1995;95(6):14. Comment.
1666 Lilley LL, Guanci R. Med errors: watch those labels. Am J Nurs. May. 1996;96(5):14. Case Reports.
1667 Lilley LL, Guanci R. Avoiding heparin dosing mistakes. Am J Nurs. Dec. 1997;97(12):12. Comment.
1668 Lilley LL, Guanci R. Look-alike abbreviations: prescriptions for confusion. Am J Nurs. Nov. 1997;97(11):12. Case Reports.
1669 Lilley LL, Guanci R. Careful with the zeros! How to minimize one of the most persistent causes of gross medication errors. Am J Nurs. May. 1997;97(5):14. Comment.
1670 Lilley LL, Guanci R. Neuromuscular blocking agents. Am J Nurs. Feb. 1997;97(2):12-14. Comment.
1671 Lilley LL, Guanci R. Distraction delays a dose. Am J Nurs. Feb. 1998;98(2):12. Case Reports.
1672 Lin MC, Chen CH. An investigation on the nursing competence of southern Taiwan nurses who have passed N3 case report accreditation. J Nurs Res. Sep. 2004;12(3):203-212. Not eligible target population. [pmid: 15362012].
1673 Lincoln LL, Dudley MN. Potential effect of oral antimicrobial therapy on nurse staffing requirements. Am J Hosp Pharm. Feb. 1990;47(2):386-388. No association tested. [pmid: 2309733].
1674 Lindley-Jones M, Finlayson BJ. Triage nurse requested x rays—are they worthwhile?. J Accid Emerg Med. Mar. 2000;17(2):103-107. Not eligible target population. [pmid: 10718230].
1675 Lindsay M. Is the postanesthesia care unit becoming an intensive care unit?. J Perianesth Nurs. Apr. 1999;14(2):73-77. Comment. [pmid: 10418416].
1676 Lindsey T, Watts-Tate N, Southwood E, Routhieaux J, Beatty J, Diane C, Phillips M, Lea G, Brown E, DeBaun MR. Chronic blood transfusion therapy practices to treat strokes in children with sickle cell disease. J Am Acad Nurse Pract. Jul. 2005;17(7):277-282. Not eligible exposure. [pmid: 15982248].
1677 Lininger RA. Pediatric peripheral i.v. insertion success rates. Pediatr Nurs. Sep–Oct. 2003;29(5):351-354. Not eligible outcomes. [pmid: 14651305].
1678 Lipley N. Millennium bed bug. Nurs Stand. Nov 3–9. 1999;14(7):12. Not eligible target population. [pmid: 11075114].
1679 Lipley N. Pressure gauge. Nurs Stand. Feb 9–15. 2000;14(21):12-13. Comment.
1680 Lipley N. Breaking the cycle of bad news. Nurs Stand. Oct 10–16. 2001;16(4):13. Comment.
1681 Little K, Palmer D. Central line exit sites: which dressing?. Nurs Stand. Aug 19–25. 1998;12(48):42-44. Not eligible exposure. [pmid: 9823178].
1682 Little M. When do you ‘say no’ to work assignments?. Tenn Nurse. Jun. 1991;54(3):17-19. Comment. [pmid: 1764437].
1683 Litvak E, Buerhaus PI, Davidoff F, et al. Managing unnecessary variability in patient demand to reduce nursing stress and improve patient safety. Jt Comm J Qual Patient Saf. Jun. 2005;31(6):330-338. Review. [pmid: 15999963].
1684 Liu JJ. Assessing the relationship between staffing levels and quality outcomes in nursing facilities. Dissertation. 2003;DAI-A 64/06, p. 2211, Dec 2003:AAT 3092765. Not eligible Target population.
1685 Livesley J. Telling tales: a qualitative exploration of how children's nurses interpret work with unaccompanied hospitalized children. J Clin Nurs. Jan. 2005;14(1):43-50. Not eligible exposure. [pmid: 15656847].
1686 Livingston C. Chicago jobfocus. A forceful health care community. Am J Nurs. Mar 1991;91(3):89–90, 92, 94–85. News.
1687 Livne M, Steinmann M. Pressure ulcer prevention project: an international outcomes report from Israel. Outcomes Manag. Jul–Sep. 2002;6(3):99-102. Not eligible target population. [pmid: 12134380].
1688 Lloyd G, McLauchlan A. Nurses' attitudes towards management of pain. Nurs Times. Oct 26–Nov 1. 1994;90(43):40-43. Not eligible exposure. [pmid: 7984461].
1689 Lloyd R, Goulding J. Nursing rotas. Shift up. Health Serv J. Oct 14. 1999;109(5676):28. Not eligible target population. [pmid: 10623151].
1690 Locsin RC. Caring and curing orientations of foreign-educated professional nurses. Philippine Journal of Nursing. Jan–Jun. 1997;67(12):27-32. Not relevant.
1691 Lomas C. Make the most of flexible working. Nurs Times. May 3–9. 2005;101(18):76-77. Comment. [pmid: 15892510].
1692 Long CG, Blackwell CC, Midgley M. An evaluation of two systems of in-patient care in a general hospital psychiatric unit. II: Measures of staff and patient performance. J Adv Nurs. Dec. 1990;15(12):1436-1442. Not eligible target population. [pmid: 2283456].
1693 Long CG, Blackwell CC, Midgley M. An evaluation of two systems of in-patient care in a general hospital psychiatric unit I: staff and patient perceptions and attitudes. J Adv Nurs. Jan. 1992;17(1):64-71. Not eligible target population. [pmid: 1537992].
1694 Long G. Measuring the benefits of bedside documentation systems. Aspens Advis Nurse Exec. Dec. 1994;10(3):1-4. Not eligible exposure. [pmid: 7811554].
1695 Long T. Pointing out medication errors. Am J Nurs. Feb. 1992;92(2):76-78. Comment. [pmid: 1739119].
1696 Lookinland S, Crenshaw J. Rewarding clinical competence in the ICU: using outcomes to reward performance. Dimens Crit Care Nurs. Jul–Aug. 1996;15(4):206-215. Comment. [pmid: 8717643].
1697 Lough-Miramontes A. Stop announcing JCAHO inspections. Nursing. Sep. 2002;32(9):12. Letter. [pmid: 12238498].
1698 Lovern E. Study: RNs can bolster outcomes. Mod Healthc. Apr 30. 2001;31(18):4-5. News.
1699 Lovett RB, McMillan SC. Validity and reliability of a bone marrow transplant acuity tool. Oncol Nurs Forum. Oct. 1993;20(9):1385-1392. Not eligible target population. [pmid: 8265443].
1700 Lovett RB, Wagner L, McMillan S. Validity and reliability of a pediatric hematology oncology patient acuity tool. J Pediatr Oncol Nurs. Jul. 1991;8(3):122-130. Not eligible outcomes. [pmid: 1930802].
1701 Lu WH, Kolkman K, Seger M, Sugrue M. An evaluation of trauma team response in a major trauma hospital in 100 patients with predominantly minor injuries. Aust N Z J Surg. May. 2000;70(5):329-332. Not eligible target population. [pmid: 10830593].
1702 Ludkin H, Quinn P, Jones SE, Wilkinson K. The benefits of setting up a nurse hysteroscopy service. Prof Nurse. Dec. 2003;19(4):220-222. Not eligible target population. [pmid: 14692257].
1703 Ludwig-Beymer P, Czurylo KT, Gattuso MC, Hennessy KA, Ryan CJ. The effect of testing on the reported incidence of medication errors in a medical center. J Contin Educ Nurs. Jan–Feb. 1990;21(1):11-17. Not eligible exposure. [pmid: 2106535].
1704 Lukacs A. Issues surrounding early postpartum discharge: effects on the caregiver. J Perinat Neonatal Nurs. Jun. 1991;5(1):33-42. Not eligible exposure. [pmid: 2027086].
1705 Lukman D, May JH, Shuman LJ, Wolfe HB. Knowledge-based schedule formulation and maintenance under uncertainty. J Soc Health Syst. 1991;2(2):42-64. No association tested. [pmid: 1760545].
1706 Lumsdon K. Crash course: piecing together the continuum of care. Hosp Health Netw. Nov 20 1994;68(22):26–28, 30, 32 passim. Comment.
1707 Lund CH, Osborne JW. Validity and reliability of the neonatal skin condition score. J Obstet Gynecol Neonatal Nurs. May–Jun. 2004;33(3):320-327. Not eligible exposure.
1708 Lund CH, Osborne JW, Kuller J, Lane AT, Lott JW, Raines DA. Neonatal skin care: clinical outcomes of the AWHONN/NANN evidence-based clinical practice guideline. Association of Women's Health, Obstetric and Neonatal Nurses and the National Association of Neonatal Nurses. J Obstet Gynecol Neonatal Nurs. Jan–Feb. 2001;30(1):41-51. Not eligible exposure.
1709 Lundgren A, Wahren LK. Effect of education on evidence-based care and handling of peripheral intravenous lines. J Clin Nurs. Sep. 1999;8(5):577-585. Not eligible target population. [pmid: 10786531].
1710 Lundgren S, Segesten K. Nurses' use of time in a medical-surgical ward with all-RN staffing. J Nurs Manag. Jan. 2001;9(1):13-20. Not eligible target population. [pmid: 11879440].
1711 Lundgren SM, Nordholm L, Segesten K. Job satisfaction in relation to change to all-RN staffing. J Nurs Manag. Jul. 2005;13(4):322-328. Not eligible target population. [pmid: 15946171].
1712 Lundgren SM, Segesten K. Nurses' altered conceptions of work in a ward with all-RN staffing. J Clin Nurs. Mar. 2002;11(2):197-204. Not eligible target population. [pmid: 11903719].
1713 Lunetta C. Employing foreign nurses. Trustee. Apr. 1991;44(4):3. News. [pmid: 10110148].
1714 Lunney M, Karlik BA, Kiss M, Murphy P. Accuracy of nurses' diagnoses of psychosocial responses. Nurs Diagn. Oct–Dec. 1997;8(4):157-166. Not eligible exposure. [pmid: 9624994].
1715 Lupfer PA, Altieri M, Sheridan MJ, Lilly CC. Patient flow in the emergency department: the chest pain patient. Am J Emerg Med. Mar. 1991;9(2):127-130. Not eligible exposure. [pmid: 1994938].
1716 Lupton D, Fenwick J. ‘They've forgotten that I'm the mum’: constructing and practising motherhood in special care nurseries. Soc Sci Med. Oct. 2001;53(8):1011-1021. Not eligible target population. [pmid: 11556771].
1717 Lush MT, Henry SB. Nurses use of health status data to plan for patient care: implications for the development of a computer-based outcomes infrastructure. Proc AMIA Annu Fall Symp. 1997:136–140. Not eligible exposure.
1718 Luther KM, Maguire L, Mazabob J, Sexton JB, Helmreich RL, Thomas E. Engaging nurses in patient safety. Crit Care Nurs Clin North Am. Dec. 2002;14(4):341-346. Not eligible exposure. [pmid: 12400624].
1719 Luther KM, Walsh K. Moving out of the red zone: addressing staff allocation to improve patient satisfaction. Jt Comm J Qual Improv. Jul. 1999;25(7):363-368. Not eligible exposure. [pmid: 10412083].
1720 Lynn MR, Kelley B. Effects of case management on the nursing context—perceived quality of care, work satisfaction, and control over practice. Image J Nurs Sch. 1997;29(3):237-241. Not eligible exposure. [pmid: 9378478].
1721 Lynn MR, McMillen BJ. Do nurses know what patients think is important in nursing care?. J Nurs Care Qual. Jun. 1999;13(5):65-74. Not eligible exposure. [pmid: 10343481].
1722 Lyon J. Power napping and work performance. Nev Rnformation. Nov. 1995;4(4):18. Comment. [pmid: 8700299].
1723 Lyon JC, Gerbis PR. Acuity vs staffing mix. Nev Rnformation. Nov. 1994;3(4):1-3. Comment.
1724 Ma CC, Samuels ME, Alexander JW. Factors that influence nurses' job satisfaction. J Nurs Adm. May. 2003;33(5):293-299. Not eligible exposure. [pmid: 12792284].
1725 MacDonald M, Bodzak W. The performance of a self-managing day surgery nurse team. J Adv Nurs. Apr. 1999;29(4):859-868. Not eligible target population. [pmid: 10215977].
1726 MacDonald MR, Miller-Grolla L. Developing a collective future: creating a culture specific nurse caring practice model for hospitals. Can J Nurs Adm. Sep–Oct. 1995;8(3):78-95. No association tested. [pmid: 8603065].
1727 Mackay I, Paterson B, Cassells C. Constant or special observations of inpatients presenting a risk of aggression or violence: nurses' perceptions of the rules of engagement. J Psychiatr Ment Health Nurs. Aug. 2005;12(4):464-471. Not eligible target population. [pmid: 16011502].
1728 MacKenzie J, Jordan K. Discharge planning. Oiling the wheels. Health Serv J. Oct 23. 1997;107(5576):32-33. Not eligible target population. [pmid: 10174937].
1729 Mackie PL, Joannidis PA, Beattie J. Evaluation of an acute point-of-care system screening for respiratory syncytial virus infection. J Hosp Infect. May. 2001;48(1):66-71. Not eligible target population. [pmid: 11358472].
1730 Mackintosh C. Do nurses provide adequate postoperative pain relief?. Br J Nurs. Apr 14–27. 1994;3(7):342-347. Not eligible target population. [pmid: 8173293].
1731 Macleod AJ, Freeland P. Should nurses be allowed to request X-rays in an accident & emergency department?. Arch Emerg Med. Mar. 1992;9(1):19-22. Not eligible target population. [pmid: 1567524].
1732 MacPhee M. Hospital networking. Comparing the work of nurses with flexible and traditional schedules. J Nurs Adm. Apr. 2000;30(4):190-198. Not eligible outcomes. [pmid: 10783699].
1733 Macready N. Trial of Denver nurses points up system flaws. OR Manager. Mar. 1999;15(3):32-33. Comment.
1734 MacStravic S. Employee success management: a cure for the staffing crisis? Health Care Strateg Manage. Aug 2002;20(8):1, 15–19. Comment.
1735 MacVicar J, Dobbie G, Owen-Johnstone L, Jagger C, Hopkins M, Kennedy J. Simulated home delivery in hospital: a randomised controlled trial. Br J Obstet Gynaecol. Apr. 1993;100(4):316-323. Not eligible target population. [pmid: 8494832].
1736 MacWhannell D. Take the medical model out of the menopause. Nurs Times. Oct 13–19. 1999;95(41):45-46. Not eligible target population. [pmid: 10786602].
1737 Mahon A. HSJ people. Ifs and cuts. Health Serv J. Dec 11. 2003;113(5885):36-37. Not eligible target population. [pmid: 14692105].
1738 Mahoney. The extent, nature, and response to victimization of emergency nurses in Pennsylvania... including commentary by Lanza ML with author response. Journal of Emergency Nursing. Oct. 1991;17(5):282-94. Not relevant. [pmid: 1921065].
1739 Mahony C. Watchdog's verdict: millions squandered, nurses neglected. Nurs Times. Sep 6–12. 2001;97(36):10-11. Not eligible target population.
1740 Mahrenholz DM. Colleagues in caring. Connecticut Nursing News. Jun–Aug. 1999;72(2):22-3. Not peer reviewed.
1741 Main J. Management of relatives of patients who are dying. J Clin Nurs. Nov. 2002;11(6):794-801. Not eligible target population. [pmid: 12427185].
1742 Makinen A, Kivimaki M, Elovainio M, Virtanen M, Bond S. Organization of nursing care as a determinant of job satisfaction among hospital nurses. J Nurs Manag. Sep. 2003;11(5):299-306. Not eligible target population. [pmid: 12930535].
1743 Makowiec-Dabrowska T, Krawczyk-Adamus P, Sprusinska E, Jozwiak ZW. Can nurses be employed in 12-hour shift systems?. Int J Occup Saf Ergon. 2000;6(3):393-403. Not eligible target population. [pmid: 11082553].
1744 Malcolmson L, Lavender T, Walkinshaw S. Visiting on the maternity wards. Pract Midwife. Mar. 1999;2(3):20-23. Not eligible target population. [pmid: 10382528].
1745 Malik U. Clients' health needs: nurses' concern. Nurs J India. Feb. 1996;87(2):29-32. Not eligible target population. [pmid: 8715809].
1746 Mallison MB. Let's identify the Yellowhearts in our midst. Am J Nurs. Feb. 1991;91(2):7. Editorial.
1747 Mallison MB. Cadillac or Chevrolet nursing? Look under the hood. Am J Nurs. Jan. 1992;92(1):7. Editorial.
1748 Malloch K, Conovaloff A. Patient classification systems, Part 1: The third generation. J Nurs Adm. Jul–Aug. 1999;29(78):49-56. No association tested. [pmid: 10451660].
1749 Malloch K, Neeld AP, McMurry C, Meeks L, Wallach M, Williams S, Conovaloff A. Patient classification systems, Part 2: The third generation. J Nurs Adm. Sep. 1999;29(9):33-42. Not eligible outcomes. [pmid: 10491667].
1750 Malone JA. Milieu and part-time nurses: a contradiction?. J Psychosoc Nurs Ment Health Serv. Jul. 1994;32(7):7. Editorial. [pmid: 7965948].
1751 Malone RE. Night shifts and breast cancer risk: policy implications. J Emerg Nurs. Apr. 2002;28(2):169-171. Review. [pmid: 11960134].
1752 Mamaril M. The official ASPAN position: ICU overflow patients in the PACU. J Perianesth Nurs. Aug. 2001;16(4):274-277. Comment. [pmid: 11481642].
1753 Mancher T. A better model by design ... and it works!. Nurs Manage. May. 2001;32(5):45-47. Comment. [pmid: 15103844].
1754 Manchester A. New care model threatens patient safety. Nurs N Z. Oct. 1997;3(9):26-27. News.
1755 Manheim LM, Feinglass J, Shortell SM, Hughes EF. Regional variation in Medicare hospital mortality. Inquiry. Spring. 1992;29(1):55-66. Not eligible exposure. [pmid: 1559724].
1756 Manias E, Aitken R, Dunning T. Medication management by graduate nurses: before, during and following medication administration. Nurs Health Sci. Jun. 2004;6(2):83-91. Not eligible target population. [pmid: 15130093].
1757 Manias E, Aitken R, Peerson A, Parker J, Wong K. Agency nursing work in acute care settings: perceptions of hospital nursing managers and agency nurse providers. J Clin Nurs. Jul. 2003;12(4):457-466. Not eligible target population. [pmid: 12790858].
1758 Manias E, Aitken R, Peerson A, Parker J, Wong K. Agency-nursing work: perceptions and experiences of agency nurses. Int J Nurs Stud. Mar. 2003;40(3):269-279. Not eligible target population. [pmid: 12605949].
1759 Manne SL, Jacobsen PB, Redd WH. Assessment of acute pediatric pain: do child self-report, parent ratings, and nurse ratings measure the same phenomenon?. Pain. Jan. 1992;48(1):45-52. Not eligible exposure. [pmid: 1738574].
1760 Manning ML, Archibald LK, Bell LM, Banerjee SN, Jarvis WR. Serratia marcescens transmission in a pediatric intensive care unit: a multifactorial occurrence. Am J Infect Control. Apr. 2001;29(2):115-119. Not eligible exposure. [pmid: 11287880].
1761 Manojlovich M. Spence Laschinger HK. The relationship of empowerment and selected personality characteristics to nursing job satisfaction. J Nurs Adm. Nov. 2002;32(11):586-595. Not eligible exposure. [pmid: 12464776].
1762 Mansheim P. Short-term psychiatric inpatient treatment of preschool children. Hosp Community Psychiatry. Jun. 1990;41(6):670-672. Not eligible exposure. [pmid: 2361674].
1763 Mansley A. Caring for rape survivors. Nurs Times. Apr 29–May 5. 1998;94(17):24-26. Case Reports. [pmid: 9625980].
1764 Mansson ME, Dykes AK. Practices for preparing children for clinical examinations and procedures in Swedish pediatric wards. Pediatr Nurs. May–Jun 2004;30(3):182–187, 229. Not eligible target population.
1765 Manthey M. Staffing and productivity. Nurs Manage. Dec. 1991;22(12):20-21. Comment.
1766 Manthey M. A core incremental staffing plan. J Nurs Adm. Sep. 2001;31(9):424-425. Comment. [pmid: 11561422].
1767 Maras V. Implementing cluster staffing. One manager's experience. Aorn J. Apr 1992;55(4):1074–1077, 1080. Comment.
1768 Marasovic C, Kenney C, Elliott D, Sindhusake D. Attitudes of Australian nurses toward the implementation of a clinical information system. Comput Nurs. Mar–Apr. 1997;15(2):91-98. Not eligible target population. [pmid: 9099028].
1769 Marchewka AE. The demand for hospital nursing personnel. DAI-A 55/07, p. 2087, Jan 1995. 1993:AAT 9432310. Not eligible outcomes.
1770 Marcus N. Night duty: sleeping sickness. Nurs Stand. Feb 22–28. 1995;9(22):56. Comment. [pmid: 7703140].
1771 Marden W. One bright initiative. Mater Manag Health Care. Jul 2002;11(7):20–22, 24. Comment.
1772 Mark BA. Characteristics of nursing practice models. J Nurs Adm. Nov. 1992;22(11):57-63. Not eligible outcomes. [pmid: 1432230].
1773 Mark BA, Salyer J, Harless DW. What explains nurses' perceptions of staffing adequacy?. J Nurs Adm. May. 2002;32(5):234-242. Not eligible exposure. [pmid: 12021564].
1774 Mark BA, Salyer J, Wan TT. Market, hospital, and nursing unit characteristics as predictors of nursing unit skill mix: a contextual analysis. J Nurs Adm. Nov. 2000;30(11):552-560. Not eligible outcomes. [pmid: 11098255].
1775 Markey DW. Applying the synergy model: clinical strategies. Crit Care Nurse. Jun. 2001;21(3):72-76. Comment. [pmid: 11858679].
1776 Markwick A. Defining what nursing is. Nurs Times. Mar 11–17. 1998;94(10):21. Case Reports. [pmid: 9735765].
1777 Maroun VM. A look at licensure of foreign-educated nurses. Issues. 1991;12(2):7. Not relevant.
1778 Marra C, Nimmo CR, Jewesson P. A prospective survey of knowledge and perceptions of ondansetron: what do health care workers know about this drug?. Can J Hosp Pharm. Dec. 1995;48(6):336-342. Not eligible exposure. [pmid: 10153865].
1779 Marson R, Taylor DM, Ashby K, Cassell E. Victorian Emergency Minimum Dataset: factors that impact upon the data quality. Emerg Med Australas. Apr. 2005;17(2):104-112. Not eligible exposure. [pmid: 15796723].
1780 Martin B, Mathisen L. Use of physical restraints in adult critical care: a bicultural study. Am J Crit Care. Mar. 2005;14(2):133-142. Not eligible exposure. [pmid: 15728955].
1781 Martin BJ. A successful approach to absenteeism. Nurs Manage. Aug. 1990;21(8):45-48. Not eligible exposure. [pmid: 2381601].
1782 Martin PA, Gustin TJ, Uddin DE, Risner P. Organizational dimensions of hospital nursing practice: longitudinal results. J Nurs Adm. Dec. 2004;34(12):554-561. No association tested. [pmid: 15632751].
1783 Martin SD. Striking nurses win from coast to coast. Am Nurse. Mar–Apr. 2002;34(2):8. Comment. [pmid: 11982140].
1784 Martinello RA, Jones L, Topal JE. Correlation between healthcare workers' knowledge of influenza vaccine and vaccine receipt. Infect Control Hosp Epidemiol. Nov. 2003;24(11):845-847. Not eligible exposure. [pmid: 14649773].
1785 Martorella C. Implementing a patient classification system. Nurs Manage. Dec. 1996;27(12):29-31. No association tested. [pmid: 9004698].
1786 Mason DJ. Nursing science: who cares?. Am J Nurs. Dec. 1999;99(12):7. Editorial.
1787 Mason DJ. How many patients are too many?. Am J Nurs. Nov. 2003;103(11):7. Editorial.
1788 Mason DJ. That's nursing! No, that's appalling. Am J Nurs. Jul. 2004;104(7):11. Editorial.
1789 Mason DJ, Kany KA. The state of the science: focus on work environments. Am J Nurs. Mar. 2005;105(3):33-34. Comment. [pmid: 15729038].
1790 Masta O. Night cover. Nurs Stand. Aug 20–26. 2003;17(49):16-18. Comment. [pmid: 12953370].
1791 Mateo MA, Smith SP. Workforce diversity in hospitals. Nurs Leadersh Forum. Summer. 2003;7(4):143-149. Not eligible outcomes. [pmid: 14528739].
1792 Mathew LJ, Gutsch HM, Hackney NW, Munsat EM. Promoting quality and cost-effective care to geropsychiatric patients. Issues Ment Health Nurs. Mar–Apr. 1994;15(2):169-185. Not eligible exposure. [pmid: 8169120].
1793 Mathias JM. Sharing OR staff can help meet unpredictable staffing demands. OR Manager. May 2005;21(5):1, 12, 14. Comment.
1794 Mathias Judith M, Patterson P. Leaders find ways to tackle staff shortage. OR Manager. Sep 2002;18(9):20–22, 26. Comment.
1795 Mathur K, Bhattacharya SK, Kashyap SK. Behavioral effects and body activity level in female hospital staff nurses during work hour. J Hum Ergol (Tokyo). Jun. 1995;24(1):1-11. Not eligible target population. [pmid: 8522784].
1796 Mattera MD. Outside the box. Rn. Apr. 1997;60(4):7. Editorial.
1797 Mattera MD. Strike?. Rn. Nov. 1999;62(11):7. Editorial.
1798 Mattera MD. Guts. Rn. Mar. 2000;63(3):7. Editorial.
1799 Matthiesen V, Lamb KV, McCann J, Hollinger-Smith L, Walton JC. Hospital nurses' views about physical restraint use with older patients. J Gerontol Nurs. Jun. 1996;22(6):8-16. Not eligible exposure. [pmid: 9036157].
1800 Maul I, Laubli T, Klipstein A, Krueger H. Course of low back pain among nurses: a longitudinal study across eight years. Occup Environ Med. Jul. 2003;60(7):497-503. Not eligible exposure. [pmid: 12819283].
1801 Maunder RG, Lancee WJ, Rourke S, Hunter JJ, Goldbloom D, Balderson K, Petryshen P, Steinberg R, Wasylenki D, Koh D, Fones CS. Factors associated with the psychological impact of severe acute respiratory syndrome on nurses and other hospital workers in Toronto. Psychosom Med. Nov–Dec. 2004;66(6):938-942. Not eligible exposure. [pmid: 15564361].
1802 Maurier WL, Northcott HC. Job uncertainty and health status for nurses during restructuring of health care in Alberta. West J Nurs Res. Aug. 2000;22(5):623-641. Not eligible outcomes. [pmid: 10943175].
1803 Maxam-Moore VA, Wilkie DJ, Woods SL. Analgesics for cardiac surgery patients in critical care: describing current practice. Am J Crit Care. Jan. 1994;3(1):31-39. Not eligible exposure. [pmid: 8118490].
1804 Maxwell M. Are you an HR star? Test your knowledge. Nurs Econ. Jul–Aug. 2004;22(4):214-215. Comment. [pmid: 15382400].
1805 May DD, Grubbs LM. The extent, nature, and precipitating factors of nurse assault among three groups of registered nurses in a regional medical center. J Emerg Nurs. Feb. 2002;28(1):11-17. Not eligible exposure. [pmid: 11830728].
1806 May J, Ellis-Hill C, Payne S. Gatekeeping and legitimization: how informal carers' relationship with health care workers is revealed in their everyday interactions. J Adv Nurs. Nov. 2001;36(3):364-375. Not eligible target population. [pmid: 11686751].
1807 Mayer C, Andrusyszyn MA, Iwasiw C. Codman Award Paper: self-efficacy of staff nurses for health promotion counselling of patients at risk for stroke. Axone. Jun. 2005;26(4):14-21. Not eligible exposure. [pmid: 16028726].
1808 Mayer GG, Buckley RF, White TL. Direct nursing care given to patients in a subacute rehabilitation center. Rehabilitation Nursing. Mar–Apr. 1990;15(2):86-8. Not relevant. [pmid: 2315552].
1809 Mayer T, Cates R, Flinn R. Fee-for-service nursing: an idea ready to be tested. ED Manag. Dec. 1998;10(12):142-144. Comment. [pmid: 10338730].
1810 Mayer TA, Cates RJ, Mastorovich MJ, Royalty DL. Emergency department patient satisfaction: customer service training improves patient satisfaction and ratings of physician and nurse skill. J Healthc Manag. Sep–Oct. 1998;43(5):427-440. discussion 441–422. Not eligible exposure. [pmid: 10182931].
1811 Mayer TA, Zimmermann PG. ED customer satisfaction survival skills: one hospital's experience. J Emerg Nurs. Jun. 1999;25(3):187-191. Not eligible exposure. [pmid: 10346840].
1812 Mayne JE. Teaching path balances LOS, education needs for MI. Hosp Case Manag. Nov. 1995;3(11):171-174. Not eligible exposure. [pmid: 10153569].
1813 Mayo AM, Duncan D. Nurse perceptions of medication errors: what we need to know for patient safety. J Nurs Care Qual. Jul–Sep. 2004;19(3):209-217. Not eligible exposure. [pmid: 15326990].
1814 McAlpine LC, Cargill G. Effects of summer employment on student nurses: implications for recruitment and retention of staff nurses. Canadian journal of nursing administration. Sep–Oct. 1992;5(3):23-7. Not relevant. [pmid: 1463760].
1815 McBride L, Walden-McBride D. Balancing the ‘heart’ of patient care. Home Healthc Nurse. Jul–Aug. 1995;13(4):46-49. Not eligible target population. [pmid: 7635748].
1816 McCabe C. Nurse-patient communication: an exploration of patients' experiences. J Clin Nurs. Jan. 2004;13(1):41-49. Not eligible exposure. [pmid: 14687292].
1817 McCann E, Bowers L. Training in cognitive behavioural interventions on acute psychiatric inpatient wards. J Psychiatr Ment Health Nurs. Apr. 2005;12(2):215-222. Not eligible target population. [pmid: 15788040].
1818 McCann TV. Willingness to provide care and treatment for patients with HIV/AIDS. J Adv Nurs. May. 1997;25(5):1033-1039. Not eligible target population. [pmid: 9147209].
1819 McCartney PR. Centering pregnancy: a renaissance in prenatal care?. MCN Am J Matern Child Nurs. Jul–Aug. 2004;29(4):261. Comment. [pmid: 15238755].
1820 McCarty MC, Zander KM, Hennrikus DJ, Lando HA. Barriers among nurses to providing smoking cessation advice to hospitalized smokers. Am J Health Promot. Nov–Dec 2001;16(2):85–87, ii. Not eligible exposure.
1821 McCloskey JM. Nurse staffing and patient outcomes. Nurs Outlook. Sep–Oct. 1998;46(5):199-200. Review. [pmid: 9805336].
1822 McConnell EA. American registered nurse medical device education: a comparison of simple and complex devices. Biomed Instrum Technol. Nov–Dec. 1995;29(6):520-526. Not eligible exposure. [pmid: 8574267].
1823 McConnell EA. How and what staff nurses learn about the medical devices they use in direct patient care. Res Nurs Health. Apr. 1995;18(2):165-172. Not eligible exposure. [pmid: 7899570].
1824 McConnell EA. Patients, machines, and staff nurses. Nursingconnections. Summer. 1997;10(2):5-11. Not eligible exposure. [pmid: 9335887].
1825 McConnell EA, Cattonar M, Manning J. Australian registered nurse medical device education: a comparison of simple vs. complex devices. J Adv Nurs. Feb. 1996;23(2):322-328. Not eligible target population. [pmid: 8708246].
1826 McConnell EA, Fletcher J, Nissen JH. A comparison of Australian and American registered nurses' use of life-sustaining medical devices in critical care and high-dependency units. Heart Lung. Sep–Oct. 1993;22(5):421-427. Not eligible target population. [pmid: 8226006].
1827 McConnell EA, Fletcher J, Nissen JH. Medical device education among Australian registered nurses. A comparison of agency and hospital nurses. Int J Technol Assess Health Care. Summer. 1995;11(3):585-594. Not eligible target population. [pmid: 7591554].
1828 McCormack B. A case study identifying nursing staffs' perception of the delivery method of nursing care in practice on a particular ward. J Adv Nurs. Feb. 1992;17(2):187-197. Not eligible target population. [pmid: 1556327].
1829 McCormack PJ, Cooper R, Sutherland S, Stewart H. The safe use of syringe drivers for palliative care: an action research project. Int J Palliat Nurs. Dec. 2001;7(12):574-580. Not eligible target population. [pmid: 11842680].
1830 McCoy AK. Developing self-scheduling in critical care. Dimens Crit Care Nurs. May–Jun. 1992;11(3):152-156. No association tested. [pmid: 1597104].
1831 McCrea J. Four honoured for rescue role. N Z Nurs J. Jun. 1992;85(5):9-34. News. [pmid: 1635687].
1832 McCrea MA, Atkinson M, Bloom T, Merkh K, Najera IL, Smith C. The healing energy of relationships. A journey to excellence. Nurs Adm Q. Jul–Sep. 2003;27(3):240-248. Comment. [pmid: 13677189].
1833 McCue M, Mark BA, Harless DW. Nurse staffing, quality, and financial performance. J Health Care Finance. Summer. 2003;29(4):54-76. Not eligible outcomes. [pmid: 12908654].
1834 McDaniel AM, Kristeller JL, Hudson DM. Chart reminders increase referrals for inpatient smoking cessation intervention. Nicotine Tob Res. Jun. 1999;1(2):175-180. Not eligible exposure. [pmid: 11072399].
1835 McDaniel C. Organizational culture and ethics work satisfaction. J Nurs Adm. Nov. 1995;25(11):15-21. Not eligible exposure. [pmid: 7472624].
1836 McDonald DD. Gender and ethnic stereotyping and narcotic analgesic administration. Res Nurs Health. Feb. 1994;17(1):45-49. Not eligible exposure. [pmid: 7907799].
1837 McDonald J. Justifying our practice. Can Nurse. Oct. 1998;94(9):47-48. Comment. [pmid: 10392051].
1838 McDonald S. An ethical dilemma: risk versus responsibility. J Psychosoc Nurs Ment Health Serv. Jan. 1994;32(1):19-25. No association tested. [pmid: 8145195].
1839 McElligott D, Holz MB, Carollo L, Somerville S, Baggett M, Kuzniewski S, Shi Q. A pilot feasibility study of the effects of touch therapy on nurses. J N Y State Nurses Assoc. Spring–Summer. 2003;34(1):16-24. Not eligible exposure. [pmid: 14639777].
1840 McEndree B. Shoes. Okla Nurse. Oct–Dec. 1996;41(4):13. Comment. [pmid: 9416142].
1841 McGavock MB. Third Annual Nursing Administration Recognition Program. Third Place...Flextra and incentive compensation. J Nurs Adm. Apr. 1991;21(4):16. Comment. [pmid: 2010824].
1842 McGillis Hall L, Doran D, Baker GR, Pink GH, Sidani S, O'Brien-Pallas L, Donner GJ. Nurse staffing models as predictors of patient outcomes. Med Care. Sep. 2003;41(9):1096-1109. Not eligible association presentation. [pmid: 12972849].
1843 McGillis Hall L, Doran D, Pink GH. Nurse staffing models, nursing hours, and patient safety outcomes. J Nurs Adm. Jan. 2004;34(1):41-45. Not eligible association presentation. [pmid: 14737034].
1844 McGloin S, Knowles J. An evaluation of the critical care assistant role within an acute NHS Trust Critical Care Unit. Nurs Crit Care. Jul–Aug. 2005;10(4):210-215. Not eligible exposure. [pmid: 15997975].
1845 McGregor LA. Short, shorter, shortest: continuing to improve the hospital stay for mothers and newborns. MCN Am J Matern Child Nurs. Jul–Aug. 1996;21(4):191-196. Comment. [pmid: 8754436].
1846 McGuire LC, Bell AZ. Developing an enhanced minor injury unit for support of urban festivities. Eur J Emerg Med. Sep. 2001;8(3):193-197. Not eligible exposure. [pmid: 11587464].
1847 McGuire T. Shiftwork. How to cope with life in the shadows. Alta RN. Oct. 2001;57(5):9. Comment. [pmid: 11899463].
1848 McHugh ML. Cost-effectiveness of clustered unit vs. unclustered nurse floating. Nursing Economics. Nov–Dec. 1997;15(6):294-300. Not relevant. [pmid: 9416095].
1849 McKay S, Smith SY. “What are they talking about? Is something wrong?” Information sharing during the second stage of labor. Birth. Sep. 1993;20(3):142-147. Not eligible exposure. [pmid: 8240622].
1850 McKenna H, Hasson F. A study of skill mix issues in midwifery: a multimethod approach. J Adv Nurs. Jan. 2002;37(1):52-61. Not eligible target population. [pmid: 11784398].
1851 McKenna HP. Nursing skill mix substitutions and quality of care: an exploration of assumptions from the research literature. J Adv Nurs. Mar. 1995;21(3):452-459. Not eligible target population. [pmid: 7745198].
1852 McKiel E. Impact of organizational restructuring on nurses' facilitation of parental participatory care. Can J Nurs Leadersh. Jan–Feb. 2002;15(1):14-17. Comment. [pmid: 11908538].
1853 McKillop A. Casual nurses meet a demand. Nurs N Z. Nov. 1995;1(10):20-21. Not eligible target population. [pmid: 8536100].
1854 McKinley A. Health care providers and facilities issue brief: health facilities: year end report-2004. Issue Brief Health Policy Track Serv. Dec 31 2004:1–12. Not eligible target population.
1855 McKnight JD, Glass DC. Perceptions of control, burnout, and depressive symptomatology: a replication and extension. J Consult Clin Psychol. Jun. 1995;63(3):490-494. Comment. [pmid: 7608364].
1856 McLain SR. Hospital workforce shortages—a glimpse at the reasons and possible solutions. Okla Nurse. Jun–Aug. 2003;48(2):14-16. Comment. [pmid: 12856451].
1857 McLaren BJ. Limitations on employment protection provided by the Americans with Disabilities Act (ADA). Colo Nurse. Dec. 1998;98(4):20-21. Legal Cases. [pmid: 10614218].
1858 McLaughlin FE, Barter M, Thomas SA, Rix G, Coulter M, Chadderton H. Perceptions of registered nurses working with assistive personnel in the United Kingdom and the United States. Int J Nurs Pract. Feb. 2000;6(1):46-57. Not eligible target population. [pmid: 10839041].
1859 McLennan CA. Workload measurement tool for an integrated OR/PACU. Can Oper Room Nurs J. Mar–Apr. 1994;12(1):28-31. Comment. [pmid: 8180895].
1860 McLeod A. Support role spreads the workload in intensive care. Nurs Times. Jul 19–25. 2001;97(29):40-41. Comment. [pmid: 11957506].
1861 McMillan SC, Tittle M, Hagan S, et al. Knowledge and attitudes of nurses in veterans hospitals about pain management in patients with cancer. Oncology nursing forum. Oct. 2000;27(9):1415-23. Not relevant. [pmid: 11058973].
1862 McMullin JP, Cook DJ, Meade MO, Weaver BR, Letelier LM, Kahmamoui K, Higgins DA, Guyatt GH. Clinical estimation of trunk position among mechanically ventilated patients. Intensive Care Med. Mar. 2002;28(3):304-309. Not eligible exposure. [pmid: 11904660].
1863 McNeal LJ. Should a staff nurse's age be a consideration in making patient and shift assignments? Con. MCN Am J Matern Child Nurs. Mar–Apr. 2005;30(2):85. Comment. [pmid: 15775801].
1864 McNees P, Dow KH, Loerzel VW. Application of the CuSum technique to evaluate changes in recruitment strategies. Nursing research. Nov–Dec. 2005;54(6):399-405. Not relevant. [pmid: 16317361].
1865 McSharry M. Quality of life: but in whose judgement?. Edtna Erca J. Jul–Sep. 1996;22(3):15-18. Not eligible target population. [pmid: 10723326].
1866 McVay K. Bottom line concerns eroding quality health care. Revolution. Winter. 1997;7(4):11. Comment. [pmid: 9615679].
1867 McWilliam CL, Stewart M, Vingilis E, Hoch J, Ward-Griffin C, Donner A, Browne G, Coyte P, Anderson K. Flexible client-driven in-home case management: an option to consider. Care Manag J. Summer. 2004;5(2):73-86. Not eligible target population. [pmid: 16047912].
1868 Medland JJ, Marcon J, Curia M. Sabbatical leave: a creative retention strategy. Crit Care Nurse. Dec. 1994;14(6):63-67. Not eligible exposure. [pmid: 7712802].
1869 Mee CL, Cirone NR, Levinger CV. MERG: medication event rating grid. Nurs Manage. Apr 1996;27(4):34, 36, 38. Comment.
1870 Meehan AJ, Carey N, Haynes DE. A clinical pathway for the secondary diagnosis of alcohol misuse: implications for the orthopaedic patient. Orthop Nurs. Nov–Dec 1998;17(6):49ndash;54, 64. Not eligible exposure.
1871 Meehan TC. Careful nursing: a model for contemporary nursing practice. J Adv Nurs. Oct. 2003;44(1):99-107. Not eligible target population. [pmid: 12956674].
1872 Mehn J, Haas D. What to tell families about drug errors. Hosp Health Netw. Feb. 1999;73(2):30. News. [pmid: 10094569].
1873 Meikle K. The role of health care assistants in hospitals. Nurs N Z. Feb. 2002;8(1):18-19. Not eligible target population. [pmid: 11979690].
1874 Melchior ME, Philipsen H, Abu-Saad HH, Halfens RJ, van de Berg AA, Gassman P. The effectiveness of primary nursing on burnout among psychiatric nurses in long-stay settings. J Adv Nurs. Oct. 1996;24(4):694-702. Not eligible target population. [pmid: 8894886].
1875 Melchior ME, van den Berg AA, Halfens R, Huyer Abu-Saad H, Philipsen H, Gassman P. Burnout and the work environment of nurses in psychiatric long-stay care settings. Soc Psychiatry Psychiatr Epidemiol. Apr. 1997;32(3):158-164. Not eligible target population. [pmid: 9130868].
1876 Melifonwu R. Ward leaders. Miracle worker. Interview by Jenine Willis. Nurs Times. Jun 23–29. 1999;95(25):30-31. Interview. [pmid: 10497586].
1877 Meltzer LS, Huckabay LM. Critical care nurses' perceptions of futile care and its effect on burnout. Am J Crit Care. May. 2004;13(3):202-208. Not eligible exposure. [pmid: 15149054].
1878 Melville E. Flexible working: banking your assets. Nurs Stand. Apr 20–26. 1994;8(30):90-91. Not eligible target population. [pmid: 8003431].
1879 Menzel NN, Brooks SM, Bernard TE, Nelson A. The physical workload of nursing personnel: association with musculoskeletal discomfort. Int J Nurs Stud. Nov. 2004;41(8):859-867. Not eligible Exposure. [pmid: 15476759].
1880 Merkouris A, Papathanassoglou ED, Lemonidou C. Evaluation of patient satisfaction with nursing care: quantitative or qualitative approach?. Int J Nurs Stud. May. 2004;41(4):355-367. Not eligible target population. [pmid: 15050847].
1881 Merkouris A, Papathanassoglou ED, Pistolas D, Papagiannaki V, Floros J, Lemonidou C. Staffing and organisation of nursing care in cardiac intensive care units in Greece. Eur J Cardiovasc Nurs. Jul. 2003;2(2):123-129. Not eligible target population. [pmid: 14622637].
1882 Merrion P, Ngeo C. Nursing relief. In answer to hospital shortages, bill would allow some foreign nurses to work in U.S. Mod Healthc. Nov 10. 1997;27(45):56. News. [pmid: 10174172].
1883 Metcalf KM. The helper model: nine ways to make it work. Nurs Manage. Dec. 1992;23(12):40-43. Comment. [pmid: 1465256].
1884 Meurier CE, Vincent CA, Parmar DG. Learning from errors in nursing practice. J Adv Nurs. Jul. 1997;26(1):111-119. Not eligible target population. [pmid: 9231284].
1885 Meyer MS, Siegel M. How much is enough? Agency nurse orientation. J Nurs Staff Dev. Jan–Feb. 1996;12(1):41-42. Comment. [pmid: 8699276].
1886 Meyers S. Real men choose nursing. Nursing schools and hospitals target men in their recruitment efforts. Trustee. May 2003;56(5):18–21, 11. News.
1887 Michael JE. Is it patient abandonment—or not?. Rn. Aug. 2002;65(8):67-70. Comment. [pmid: 12229106].
1888 Michie S, Ridout K, Johnston M. Stress in nursing and patients' satisfaction with health care. Br J Nurs. Sep 12–25. 1996;5(16):1002-1006. Not eligible target population. [pmid: 9006162].
1889 Middleton S, Lumby J. Comparing professional and patient outcomes for the same episode of care. Aust J Adv Nurs. Sep–Nov. 1999;17(1):22-27. Not eligible target population. [pmid: 10776088].
1890 Milette IH, Carnevale FA. I'm trying to heal...noise levels in a pediatric intensive care unit. Dynamics. Winter. 2003;14(4):14-21. Not eligible exposure. [pmid: 15453567].
1891 Millar B. Behind every great nurse. Nurs Times. Mar 22–28. 2001;97(12):24-26. Not eligible target population.
1892 Miller BK, Haber J, Byrne MW. The experience of caring in the acute care setting: patient and nurse perspectives. NLN Publ. Apr 1992(15–2465):137–156. No association tested.
1893 Miller D. Comparisons of pain ratings from postoperative children, their mothers, and their nurses. Pediatr Nurs. Mar–Apr. 1996;22(2):145-149. Not eligible exposure. [pmid: 8715850].
1894 Miller DL. Post procedural interventional cardiology patients on the progressive care unit. Prog Cardiovasc Nurs. Winter 1999;14(1):14–17, 36. Not eligible exposure.
1895 Miller E. Record snowstorm transforms hospitals to RN “dorms”. Nurs Spectr (Wash D C). Jan 16. 1996;6(2):4. Comment. [pmid: 9423565].
1896 Miller K. The road taken. Revolution. Oct–Nov. 2003;4(5):18-23. Comment. [pmid: 14631720].
1897 Miller KH, Grindel CG, Patsdaughter CA. Risk classification, clinical outcomes, and the use of nursing resources for cardiac surgery patients. Dimens Crit Care Nurs. Mar–Apr. 1999;18(2):44-49. Not eligible exposure. [pmid: 10640010].
1898 Miller KH, Grindel CG, Patsdaughter CA. Cardiac surgery's calculated risk. Nurs Manage. Jul 1999;30(7):34–36, 38–40. No association tested.
1899 Miller SF, Finley RK, Waltman M, Lincks J. Burn size estimate reliability: a study. J Burn Care Rehabil. Nov–Dec. 1991;12(6):546-559. Not eligible exposure. [pmid: 1779009].
1900 Mills-Senn P. Staffing. Avoiding culture clash. As the number of foreign-born nurses climbs, executives look for ways to bridge cultural gap. Hosp Health Netw. Apr. 2005;79(4):30-32. News. [pmid: 15916341].
1901 Milstead JA. Leapfrog Group: a prince in disguise or just another frog?. Nurs Adm Q. Summer. 2002;26(4):16-25. Review. [pmid: 12154626].
1902 Minichiello TM, Auerbach AD, Wachter RM. Caregiver perceptions of the reasons for delayed hospital discharge. Eff Clin Pract. Nov–Dec. 2001;4(6):250-255. Not eligible exposure. [pmid: 11769297].
1903 Minnick A, Leahey M, Pischke-Winn K. The impact of patient point-of-view pharmacy delivery on labor and quality. Nurs Econ. Jan–Feb. 1994;12(1):45-50. Not eligible exposure. [pmid: 8008103].
1904 Minnick A, Leipzig RM. The restraint match-up. Three lessons show how nurse leaders can influence the use of physical restraints. Nurs Manage. Mar. 2001;32(3):37-39. Comment. [pmid: 15103825].
1905 Minton JA, Creason NS. Evaluation of admission nursing diagnoses. Nurs Diagn. Jul–Sep. 1991;2(3):119-125. Not eligible outcomes. [pmid: 1931303].
1906 Miracle K. Restraints: friend or foe?. Ky Hosp Mag. Winter. 1991;8(1):10-11. Comment. [pmid: 10109281].
1907 Mistiaen P, van Harteveld J. A comment on the Duke University Center Health Profile. Med Care. Jun. 1992;30(6):471-472. Editorial. [pmid: 1593913].
1908 Mitchell A, Van Berkel C, Adam V, Ciliska D, Sheppard K, Baumann A, Underwood J, Walter S, Gafni A, Edwards N, et al. Comparison of liaison and staff nurses in discharge referrals of postpartum patients for public health nursing follow-up. Nurs Res. Jul–Aug. 1993;42(4):245-249. Not eligible exposure. [pmid: 8337164].
1909 Mitchell D, Grindel CG, Laurenzano C. Sexual abuse assessment on admission by nursing staff in general hospital psychiatric settings. Psychiatr Serv. Feb. 1996;47(2):159-164. Not eligible exposure. [pmid: 8825252].
1910 Mitchell GJ, Closson T, Coulis N, Flint F, Gray B. Patient-focused care and human becoming thought: connecting the right stuff. Nurs Sci Q. Jul. 2000;13(3):216-224. Case Reports. [pmid: 11847801].
1911 Mitchell PH, Lang NM. Nurse staffing: a structural proxy for hospital quality?. Med Care. Jan. 2004;42(1):1-3. Comment. [pmid: 14713733].
1912 Moait S. 10 hr night duty win. Lamp. May. 1996;53(4):10-12. Comment. [pmid: 9313468].
1913 Mobberley T. NT/3M National Nursing Awards. Family favourite. Nurs Times. Dec 29–2000 Jan 5. 1999;95(50):34-35. Comment. [pmid: 11107417].
1914 Moens G, Mylle G, Johannik K, Van Hoof R, Helsen G. Analysing and interpreting routinely collected data on sharps injuries in assessing preventative actions. Occup Med (Lond). Jun. 2004;54(4):245-249. Not eligible target population. [pmid: 15190161].
1915 Molloy P. Promoting night shift. Nurs N Z. Aug. 1995;1(7):13-15. Not eligible target population. [pmid: 7584637].
1916 Molzahn AE, Northcott HC, Dossetor JB. Quality of life of individuals with end stage renal disease: perceptions of patients, nurses, and physicians. Anna J. Jun. 1997;24(3):325-333. discussion 334–325. Not eligible exposure. [pmid: 9238904].
1917 Monet SS. Nurses indicted ... a wave of the future?. Hawaii Nurse (Honol). Jul–Aug. 1997;4(4):1-5. Legal Cases. [pmid: 9355376].
1918 Mongeau C. Voices from Colorado. Nursing. Jun. 1998;28(6):48-49. Case Reports. [pmid: 9668792].
1919 Moody L, Snyder PE. Hospital provider satisfaction with a new documentation system. Nursing Economics. Jan–Feb. 1995;13(1):24-31. Not relevant. [pmid: 7760945].
1920 Moody LE, Slocumb E, Berg B, Jackson D. Electronic health records documentation in nursing: nurses' perceptions, attitudes, and preferences. Comput Inform Nurs. Nov–Dec. 2004;22(6):337-344. Not eligible exposure. [pmid: 15602303].
1921 Moolenaar RL, Crutcher JM, San Joaquin VH, Sewell LV, Hutwagner LC, Carson LA, Robison DA, Smithee LM, Jarvis WR. A prolonged outbreak of Pseudomonas aeruginosa in a neonatal intensive care unit: did staff fingernails play a role in disease transmission?. Infect Control Hosp Epidemiol. Feb. 2000;21(2):80-85. Not eligible exposure. [pmid: 10697282].
1922 Moons M, Kerkstra A, Biewenga T. Specialized home care for patients with AIDS: an experiment in Rotterdam, The Netherlands. J Adv Nurs. Jun. 1994;19(6):1132-1140. Not eligible target population. [pmid: 7930094].
1923 Moore K, Lynn MR, McMillen BJ, Evans S. Implementation of the ANA report card. J Nurs Adm. Jun. 1999;29(6):48-54. Not eligible association presentation. [pmid: 10377925].
1924 Moore MM, Nguyen D, Nolan SP, Robinson SP, Ryals B, Imbrie JZ, Spotnitz W. Interventions to reduce decibel levels on patient care units. Am Surg. Sep. 1998;64(9):894-899. Not eligible exposure. [pmid: 9731822].
1925 Moran J. Finally, the 38-hour week. Qld Nurse. Nov–Dec. 1994;13(6):6-8. Comment. [pmid: 7886252].
1926 Morath J, Fleischmann R, Boggs G. A missing consideration: the psychiatric patient classification for scheduling-staffing systems. Perspect Psychiatr Care. 1990;25(34):40-47. Not eligible exposure. [pmid: 2385501].
1927 Moreno R, Reis Miranda D. Nursing staff in intensive care in Europe: the mismatch between planning and practice. Chest. Mar. 1998;113(3):752-758. Not eligible target population. [pmid: 9515853].
1928 Morgan SP, DeRose C. Reduce workload intensity with PCTs. Nurs Manage. Nov. 2003;34(11):9. Not eligible exposure. [pmid: 14671439].
1929 Morita T, Miyashita M, Kimura R, Adachi I, Shima Y. Emotional burden of nurses in palliative sedation therapy. Palliat Med. Sep. 2004;18(6):550-557. Not eligible target population. [pmid: 15453626].
1930 Morita T, Shima Y, Miyashita M, Kimura R, Adachi I. Physician- and nurse-reported effects of intravenous hydration therapy on symptoms of terminally ill patients with cancer. J Palliat Med. Oct. 2004;7(5):683-693. Not eligible target population. [pmid: 15588360].
1931 Morley B. Reclaiming the night. Nurs Times. Jun 29–Jul 5. 1994;90(26):54-55. Comment. [pmid: 8047442].
1932 Morohashi Y. Questions concerning medical care provided in hospitals. Jpn Hosp. Jul. 1992;11:1-9. Not eligible target population. [pmid: 10120542].
1933 Morrison AL, Beckmann U, Durie M, Carless R, Gillies DM. The effects of nursing staff inexperience (NSI) on the occurrence of adverse patient experiences in ICUs. Aust Crit Care. Aug. 2001;14(3):116-121. Not eligible target population. [pmid: 11899636].
1934 Morrison M. The paradigm shift from traditional obstetrics to single room maternity care. Fla Nurse. Mar. 1993;41(3):7. Comment. [pmid: 8467924].
1935 Morrison P. A multidimensional scalogram analysis of the use of seclusion in acute psychiatric settings. J Adv Nurs. Jan. 1990;15(1):59-66. Not eligible target population. [pmid: 2303615].
1936 Morrison P, Lehane M. The effect of staffing levels on the use of seclusion. J Psychiatr Ment Health Nurs. 1995;2(6):365-366. Comment. [pmid: 8696788].
1937 Morrison P, Lehane M. A study of the official records of seclusion. Int J Nurs Stud. Apr. 1996;33(2):223-235. Not eligible target population. [pmid: 8675382].
1938 Morrison P, Phillips C, Burnard P. Staff and patient satisfaction in a forensic unit. J Psychiatr Ment Health Nurs. 1996;3(1):67-69. Comment. [pmid: 8696800].
1939 Morrison WE, Haas EC, Shaffner DH, Garrett ES, Fackler JC. Noise, stress, and annoyance in a pediatric intensive care unit. Crit Care Med. Jan. 2003;31(1):113-119. Not eligible exposure. [pmid: 12545003].
1940 Morrissey J. Quality vs. quantity. IOM report: hospitals must cut back workload and hours of nurses to maintain patient safety. Mod Healthc. Nov 10. 2003;33(45):8-11. News.
1941 Morrow KL. Using staffing and scheduling information to support change. Nurs Manage. May. 1994;25(5):78-80. Comment. [pmid: 8196888].
1942 Morton HR, Himes JK, Stevens B. The Foreign Nurse Program: an innovative NCLEX review. J Contin Educ Nurs. Mar–Apr. 1992;23(2):81-82. Comment. [pmid: 1564175].
1943 Moskowitz DB. Marketplace. Why hospitals' staffing woes today are unlike previous nurse shortages. Med Health. Oct 30 2000;54(42):suppl 1–2. Comment.
1944 Moss J, Xiao Y. Improving operating room coordination: communication pattern assessment. J Nurs Adm. Feb. 2004;34(2):93-100. Not eligible exposure. [pmid: 14770069].
1945 Mrayyan MT. Perceptions of jordanian head nurses of variables that influence the quality of nursing care. J Nurs Care Qual. Jul–Sep. 2004;19(3):276-279. Not eligible target population. [pmid: 15326998].
1946 Mudge B, Helferty M, Wallace L, Ouwendyk M. Nocturnal hemodialysis (NHD) adapted to the in-centre setting—a pilot study. J Cannt. Winter. 1998;8(1):30-31. Not eligible target population. [pmid: 9582757].
1947 Muller K, Schwesig R, Leuchte S, Riede D. [Coordinative treatment and quality of life - a randomised trial of nurses with back pain]. Gesundheitswesen. Oct. 2001;63(10):609-618. Not eligible target population. [pmid: 11607869].
1948 Murphy CL, McLaws ML. Who coordinates infection control programs in Australia?. Am J Infect Control. Jun. 1999;27(3):291-295. Not eligible target population. [pmid: 10358235].
1949 Murphy F. Stress among nephrology nurses in Northern Ireland. Nephrol Nurs J. Jul–Aug. 2004;31(4):423-431. Not eligible target population. [pmid: 15453234].
1950 Murray MG, Snyder JC. When staff are assaulted. A nursing consultation support service. J Psychosoc Nurs Ment Health Serv. Jul. 1991;29(7):24-29. Not eligible outcomes. [pmid: 1875309].
1951 Mustard LW. The culture of patient safety. JONAS Healthc Law Ethics Regul. Dec. 2002;4(4):111-115. Review. [pmid: 12476068].
1952 Mustard LW. Improving patient satisfaction through the consistent use of scripting by the nursing staff. JONAS Healthc Law Ethics Regul. Sep. 2003;5(3):68-72. Not eligible exposure. [pmid: 12972950].
1953 Myers H, Nikoletti S. Fall risk assessment: a prospective investigation of nurses' clinical judgement and risk assessment tools in predicting patient falls. Int J Nurs Pract. Jun. 2003;9(3):158-165. Not eligible target population. [pmid: 12801247].
1954 Myers L. The NHS—a patient's perspective. Health Expect. Dec. 2001;4(4):205-208. Not eligible target population. [pmid: 11703493].
1955 Myers M. Trauma coordinator: full-time or part-time?. J Trauma Nurs. Jul–Sep. 1998;5(3):59-61. Editorial. [pmid: 10188439].
1956 Myers SM. Patient-focused care: what managers should know. Nurs Econ. Jul–Aug. 1998;16(4):180-188. No association tested. [pmid: 9748983].
1957 Myles GL, Perry AG, Malkoff MD, Shatto BJ, Scott-Killmade MC. Quantifying nursing care in barbiturate-induced coma with the therapeutic intervention scoring system. J Neurosci Nurs. Feb. 1995;27(1):35-42. Not eligible exposure. [pmid: 7769326].
1958 Nader R. Arnold imitates art. Revolution. Mar–Apr. 2005;6(2):7-8. Review. [pmid: 15948529].
1959 Nahalla CK, FitzGerald M. The impact of regular hospitalization of children living with thalassaemia on their parents in Sri Lanka: a phenomenological study. Int J Nurs Pract. Jun. 2003;9(3):131-139. Not eligible target population. [pmid: 12801245].
1960 Naish J. Recruitment crisis returns. Nurs Manag (Harrow). Jan. 1995;1(8):6-7. Comment.
1961 Naish J. Part-time working. Balancing act. Nurs Times. Feb 28–Mar 5. 1996;92(9):28-30. Not eligible target population. [pmid: 8700732].
1962 Nakagawa J, Ouk S, Schwartz B, Schriger DL. Interobserver agreement in emergency department triage. Ann Emerg Med. Feb. 2003;41(2):191-195. Not eligible outcomes. [pmid: 12548268].
1963 Napholz L. Sex role typology as a function of age among registered nurses. Health care for women international. Jul–Sep. 1992;13(3):303-12. Not relevant. [pmid: 1399870].
1964 Napthine R. Pen power—doctors under scrutiny. Aust Nurs J. Sep. 1995;3(3):28-29. Comment. [pmid: 7581927].
1965 Nardini J. Medical errors—is the system “ill?”. Nephrol Nurs J. Jun. 2000;27(3):272-273. Comment. [pmid: 11249325].
1966 Nash MG, Blackwood D, Boone EB 3rd, Klar R, Lewis E, MacInnis K, McKay J, Okress J, Richer S, Tannas C. Managing expectations between patient and nurse. J Nurs Adm. Nov. 1994;24(11):49-55. No association tested. [pmid: 7965182].
1967 Nash MG, Miller G, Everett LN, Faber-Bermudez I, Libcke J, Nalon K. Third Annual Nursing Administration Recognition Program. Honorable Mention...Economic model for a hospital-based supplemental staffing program. J Nurs Adm. Apr. 1991;21(4):17-18. Comment.
1968 Naumanen-Tuomela P. Finnish occupational health nurses' work and expertise: the clients' perspective. J Adv Nurs. May. 2001;34(4):538-544. Not eligible target population. [pmid: 11380721].
1969 Nava S, Evangelisti I, Rampulla C, Compagnoni ML, Fracchia C, Rubini F. Human and financial costs of noninvasive mechanical ventilation in patients affected by COPD and acute respiratory failure. Chest. Jun. 1997;111(6):1631-1638. Not eligible target population. [pmid: 9187186].
1970 Navarro VB, Stout WA Jr, Tolley FM. Allocation of nursing care hours in a combined ophthalmic nursing unit. Insight. Apr. 1995;20(1):14-16. No association tested. [pmid: 7616066].
1971 Nazarko L. Working parents: primary or secondary?. Nurs Stand. Mar 11–17. 1992;6(25):53-54. Not eligible target population. [pmid: 1550753].
1972 Nazarko L. Working parents: turning against rotation. Nurs Stand. Jun 10–16. 1992;6(38):44. Comment.
1973 Nazarko L. Working mothers: short shrift for long. Not eligible target population.
1974 Needham I, Abderhalden C, Dassen T, Haug HJ, Fischer JE. The perception of aggression by nurses: psychometric scale testing and derivation of a short instrument. J Psychiatr Ment Health Nurs. Feb. 2004;11(1):36-42. Not eligible target population. [pmid: 14723637].
1975 Needham I, Abderhalden C, Halfens RJ, Dassen T, Haug HJ, Fischer JE. The effect of a training course in aggression management on mental health nurses' perceptions of aggression: a cluster randomised controlled trial. Int J Nurs Stud. Aug. 2005;42(6):649-655. Not eligible exposure. [pmid: 15982464].
1976 Neitzel JJ, Miller EH, Shepherd MF, Belgrade M. Improving pain management after total joint replacement surgery. Orthop Nurs. Jul–Aug 1999;18(4):37–45, 64. Not eligible exposure.
1977 Nelson J. Visit at your peril. Nurs Stand. Mar 13–19. 1991;5(25):46. Case Reports. [pmid: 1900715].
1978 Nelson J. Shift patterns: a hard day's night. Nurs Stand. Jan 29–Feb 4. 1992;6(19):54. Comment. [pmid: 1739672].
1979 Nelson MS. A triage-based emergency department patient classification system. J Emerg Nurs. Dec. 1994;20(6):511-516. Not eligible exposure. [pmid: 7745905].
1980 Nelson NC, Evans RS, Samore MH, Gardner RM. Detection and prevention of medication errors using real-time bedside nurse charting. J Am Med Inform Assoc. Jul–Aug. 2005;12(4):390-397. Not eligible exposure. [pmid: 15802486]. [pmcid: 1174883].
1981 Nelson S. Staffing, ratios and skill mix—is there an Australian story?. Nurs Inq. Mar. 2005;12(1):1. Editorial. [pmid: 15743436].
1982 Nerdahl P, Berglund D, Bearinger LH, et al. New challenges, new answers: pediatric nurse practitioners and the care of adolescents. Journal of Pediatric Health Care. Jul–Aug. 1999;13(4):183-90. Not relevant. [pmid: 10690083].
1983 Nesbitt-Johnson M. Burn unit ensures expert, specialized staffing. Nurs Manage. Sep. 1998;29(9):40F. Comment.
1984 Neuhs HP. The nursing shortage: crisis as opportunity. J Nurs Adm. Mar. 1991;21(3):5-36. Editorial. [pmid: 1999739].
1985 Nevidjon B. Due to the nursing shortage, mandatory overtime is a necessary evil. Nurs Leadersh Forum.Winter 2001;6(2):32, 37–38. Comment.
1986 Newhouse RP, Johantgen M, Pronovost PJ, Johnson E. Perioperative nurses and patient outcomes—mortality, complications, and length of stay. Aorn J. Mar 2005;81(3):508–509, 513–522, 525–508. Not eligible exposure.
1987 Newman KM, Heine C. Availability of scheduling options important. J Nurs Adm. Jul–Aug. 1991;21(78):46-49. Comment. [pmid: 1870006].
1988 Ngin PM, Simms LM. Computer use for work accomplishment. A comparison between nurse managers and staff nurses. J Nurs Adm. Mar. 1996;26(3):47-55. Not eligible target population. [pmid: 8618125].
1989 Nguyen BQ. You're not one of us. When discrimination based on national origin becomes a problem. Am J Nurs. Jan. 2001;101(1):77. Comment. [pmid: 11211695].
1990 Nguyen GT, Proctor SE, SinkowitzCochran RL, et al. Status of infection surveillance and control programs in the United States, 1992-1996. American Journal of Infection Control. Dec. 2000;28(6):392-400. Not relevant. [pmid: 11114608].
1991 Nichol KL, Hauge M. Influenza vaccination of healthcare workers. Infect Control Hosp Epidemiol. Mar. 1997;18(3):189-194. Not eligible exposure. [pmid: 9090547].
1992 Nicholls DJ, Duplaga EA, Meyer LM. Nurses' attitudes about floating. Nurs Manage. Jan. 1996;27(1):56-58. Comment. [pmid: 8552363].
1993 Nicholson D, Ravenscroft E, Ray J, Stuart L. Staff mix and public safety. Nurs BC. Oct. 2004;36(4):5. Letter. [pmid: 15552173].
1994 Nicklin W, Graves E. Nursing and patient outcomes: it's time for healthcare leadership to respond. Healthc Manage Forum. Spring 2005;18(1):9–13, 40–15. Review.
1995 Niederstadt JA. Frequency and timing of activated clotting time levels for sheath removal. J Nurs Care Qual. Jan–Mar. 2004;19(1):34-38. Not eligible target population. [pmid: 14717146].
1996 Niedhammer I, Lert F, Marne MJ. Psychotropic drug use and shift work among French nurses (1980-1990). Psychol Med. Mar. 1995;25(2):329-338. Not eligible target population. [pmid: 7675921].
1997 Noak J. Do we need another model for mental health care?. Nurs Stand. Nov 7–13. 2001;16(8):33-35. Comment. [pmid: 11974782].
1998 Norrie P. Nurses' time management in intensive care. Nurs Crit Care. May–Jun. 1997;2(3):121-125. Not eligible target population. [pmid: 9873311].
1999 Northcott N, Facey S. Twelve-hour shifts: helpful or hazardous to patients?. Nurs Times. Feb 15–22. 1995;91(7):29-31. Comment. [pmid: 7885884].
2000 Norton A. Realistic rostering. Nurs N Z. Nov. 1994;2(10):11. Not eligible target population. [pmid: 7812320].
2001 Norton A. Shifting the emphasis. Nurs N Z. Jun. 1995;1(5):12. Not eligible target population.
2002 Noyes J. Are nurses respecting and upholding the human rights of children and young people in their care?. Paediatr Nurs. Mar. 2000;12(2):23-27. Not eligible target population. [pmid: 11220841].
2003 Nugent J. The NurseLink model of care. Contemp Nurse. Aug. 2003;15(12):110-113. Not eligible target population. [pmid: 14649514].
2004 Nyqvist KH, Rubertsson C, Ewald U, Sjoden PO. Development of the Preterm Infant Breastfeeding Behavior Scale (PIBBS): a study of nurse-mother agreement. J Hum Lact. Sep. 1996;12(3):207-219. Not eligible target population. [pmid: 9025428].
2005 Oates JD, Snowdon SL, Jayson DW. Failure of pain relief after surgery. Attitudes of ward staff and patients to postoperative analgesia. Anaesthesia. Sep. 1994;49(9):755-758. Not eligible exposure. [pmid: 7978127].
2006 O'Brien JA. Utilization of nursing personnel from supplemental staffing agencies by health care facilities in Minnesota. Minnesota nursing accent. Jan. 1991;63(1):16-7. Not peer reviewed. [pmid: 1847233].
2007 O'Brien RL, Serbin MF, O'Brien KD, Maier RV, Grady MS. Improvement in the organ donation rate at a large urban trauma center. Arch Surg. Feb. 1996;131(2):153-159. Not eligible exposure. [pmid: 8611071].
2008 O'Brien SP, Wind S, van Rijswijk L, Kerstein MD. Sequential biannual prevalence studies of pressure ulcers at Allegheny-Hahnemann University Hospital. Ostomy Wound Manage. Mar. 1998;44(3A Suppl):78S-88S. discussion 89S. Not eligible exposure. [pmid: 9626001].
2009 O'Brien-Pallas L, Shamian J, Thomson D, Alksnis C, Koehoorn M, Kerr M, Bruce S. Work-related disability in Canadian nurses. J Nurs Scholarsh. 2004;36(4):352-357. Not eligible outcomes. [pmid: 15636416].
2010 O'Brodovich M, Rappaport P. A study pre and post unit dose conversion in a pediatric hospital. Can J Hosp Pharm. Feb 1991;44(1):5–15, 50. Not eligible outcomes.
2011 O'Connor R. Getting them over there. Nurs Stand. Mar 5–11. 2003;17(25):16-17. News.
2012 O'Connor T. 12 hour shifts begin in Dunedin. N Z Nurs J. Nov. 1992;85(10):20-21. Not eligible target population. [pmid: 1480358].
2013 O'Connor T. Statistics show sick system. Nurs N Z. Jul. 1995;1(6):18-19. Not eligible target population.
2014 O'Connor T. Staffing levels cause concern. Nurs N Z. Nov. 1999;5(10):11. Comment. [pmid: 10865645].
2015 O'Dowd A. Scotland. Soaring violence against nurses. Nurs Times. Jul 13–19. 2000;96(28):5. News.
2016 O'Dowd A. Workplace violence. Call for police officer in every A&E. Nurs Times. Jul 20–26. 2000;96(29):12-13. News.
2017 O'Dowd A. London trust in a royal mess. Nurs Times. Oct 19–25. 2000;96(42):10-11. News.
2018 O'Dowd A. Are minimum staff ratios needed?. Nurs Times. Apr 6–12. 2004;100(14):12-13. Not eligible target population.
2019 O'Dowd A. Weighing up nurse-to-patient ratios. Nurs Times. Aug 2–8. 2005;101(31):20-22. Comment.
2020 Oehler JM, Davidson MG. Job stress and burnout in acute and nonacute pediatric nurses. Am J Crit Care. Sep. 1992;1(2):81-90. Not eligible exposure. [pmid: 1307895].
2021 Ofili AN, Asuzu MC, Okojie OH. Hospital workers' opinions on the predisposing factors to blood-related work accidents in Central Hospital, Benin City, Edo State, Nigeria. Public Health. Sep. 2003;117(5):333-338. Not eligible target population. [pmid: 12909423].
2022 O'Hare MC, Bradley AM, Gallagher T, Shields MD. Errors in administration of intravenous drugs. Bmj. Jun 10. 1995;310(6993):1536-1537. Letter. [pmid: 7787627].
2023 O'Hern-Martin P. Suburban hospital nurses fight for safe staffing. Revolution. Spring. 1997;7(1):18-20. Legal Cases. [pmid: 9277284].
2024 Ohrn KE, Wahlin YB, Sjoden PO. Oral care in cancer nursing. Eur J Cancer Care (Engl). Mar. 2000;9(1):22-29. Not eligible target population. [pmid: 11051939].
2025 Okolo SN, Ogbonna C. Knowledge, attitude and practice of health workers in Keffi local government hospitals regarding Baby-Friendly Hospital Initiative (BFHI) practices. Eur J Clin Nutr. May. 2002;56(5):438-441. Not eligible target population. [pmid: 12001015].
2026 Oldenkamp JH, Heesen C, Simons JL. Application of telematics for improving multiple schedules. Stud Health Technol Inform. 1997;43 Pt A:64–68. Not eligible target population.
2027 O'Leary J, Williamson J. Meeting the challanges in today's outpatient oncology setting: a case study. J Oncol Manag. May–Jun. 2003;12(3):24-26. No association tested. [pmid: 12803448].
2028 Oleni M, Johansson P, Fridlund B. Nursing care at night: an evaluation using the Night Nursing Care Instrument. J Adv Nurs. Jul. 2004;47(1):25-32. Not eligible target population. [pmid: 15186464].
2029 Oleson M, Heading C, Shadick KM, Bistodeau JA. Quality of life in long-stay institutions in England: nurse and resident perceptions. J Adv Nurs. Jul. 1994;20(1):23-32. Not eligible target population. [pmid: 7930123].
2030 Olive KE, Ballard JA. Attitudes of patients toward smoking by health professionals. Public Health Rep. May–Jun. 1992;107(3):335-339. Not eligible exposure. [pmid: 1594744]. [pmcid: 1403657].
2031 Olson ME, Smith MJ. An evaluation of single-room maternity care. Health Care Superv. Sep. 1992;11(1):43-49. Not eligible exposure. [pmid: 10120035].
2032 O'Neil E, Seago JA. Meeting the challenge of nursing and the nation's health. Jama. Oct 23–30. 2002;288(16):2040-2041. Comment. [pmid: 12387657].
2033 O'Neill KL, Ross-Kerr JC. Impact of an instructional program on nurses' accuracy in capillary blood glucose monitoring. Clin Nurs Res. May. 1999;8(2):166-178. Not eligible exposure. [pmid: 10887868].
2034 O'Neill TR, Tannenbaum RJ, Tiffen J. Recommending a minimum English proficiency standard for entry-level nursing. Journal of nursing measurement. Fall. 2005;13(2):129-46. Not relevant. [pmid: 16401043].
2035 O'Reilly M. Dying in an acute-care setting. Nurs N Z. Nov. 2000;6(10):16-17. Comment. [pmid: 12012481].
2036 Ornstein H. The floating dilemma. Can Nurse. Oct. 1992;88(9):20-22. Comment. [pmid: 1477833].
2037 Orsted HL, Campbell KE, Keast DH, Coutts P, Sterling W. Chronic wound caring ... a long journey toward healing. Ostomy Wound Manage. Oct. 2001;47(10):26-36. Case Reports. [pmid: 11890076].
2038 Osborne J, Blais K, Hayes JS. Nurses' perceptions: when is it a medication error?. J Nurs Adm. Apr. 1999;29(4):33-38. Not eligible exposure. [pmid: 10200784].
2039 Osmon S, Harris CB, Dunagan WC, Prentice D, Fraser VJ, Kollef MH. Reporting of medical errors: an intensive care unit experience. Crit Care Med. Mar. 2004;32(3):727-733. Not eligible exposure. [pmid: 15090954].
2040 Ostrowski M. Turn up the volume. Rn. Mar. 2002;65(3):7. Editorial. [pmid: 11961871].
2041 Ostry AS, Tomlin KM, Cvitkovich Y, Ratner PA, Park IH, Tate RB, Yassi A. Choosing a model of care for patients in alternate level care: caregiver perspectives with respect to staff injury. Can J Nurs Res. Mar. 2004;36(1):142-157. Not eligible outcomes. [pmid: 15133924].
2042 Ostry AS, Yassi A, Ratner PA, Park I, Tate R, Kidd C. Work organization and patient care staff injuries: the impact of different care models for “alternate level of care” patients. Am J Ind Med. Oct. 2003;44(4):392-399. Not eligible outcomes. [pmid: 14502767].
2043 O'Sullivan J. Healthcare changes bring increased liability risk for nurses. Mo Nurse. Sep–Oct. 1995;64(5):4. Comment. [pmid: 7494536].
2044 Overdyk FJ, Harvey SC, Fishman RL, Shippey F. Successful strategies for improving operating room efficiency at academic institutions. Anesth Analg. Apr. 1998;86(4):896-906. Not eligible exposure. [pmid: 9539621].
2045 Owen BD, Keene K, Olson S. An ergonomic approach to reducing back/shoulder stress in hospital nursing personnel: a five year follow up. Int J Nurs Stud. Mar. 2002;39(3):295-302. Not eligible exposure. [pmid: 11864653].
2046 Owen C, Tarantello C, Jones M, Tennant C. Violence and aggression in psychiatric units. Psychiatr Serv. Nov. 1998;49(11):1452-1457. Not eligible target population. [pmid: 9826247].
2047 Owen L. The named nurse: patient and nurse expectations. Prof Nurse. Aug. 1997;12(11):769-771. Not eligible target population. [pmid: 9287858].
2048 Oz F. Impact of training on empathic communication skills and tendency of nurses. Clin Excell Nurse Pract. 2001;5(1):44-51. Not eligible target population. [pmid: 11154393].
2049 Ozkarahan I. An integrated nurse scheduling model. J Soc Health Syst. 1991;3(2):79-101. No association tested. [pmid: 1817703].
2050 Pacini CM. Synergy: a framework for leadership development and transformation. Crit Care Nurs Clin North Am. Jun 2005;17(2):113–119, ix. No association tested.
2051 Padilla-Harris C. Night fever. Nurs Stand. Oct 17–23. 2001;16(5):23. News. [pmid: 11977793].
2052 Padmam R. Extroversion, neuroticism and job satisfaction: a comparative study of staff nurses and students. Nurs J India. Mar. 1995;86(3):65-68. Not eligible target population. [pmid: 7479166].
2053 Page B. Where have all the nurses gone?. Can Oncol Nurs J. May. 1998;8(2):91-92. Editorial. [pmid: 9677913].
2054 Page D. Paramedics—above & beyond. Hosp Health Netw. Mar. 2000;74(3):30. Comment. [pmid: 10776377].
2055 Page JS. Nurse staffing and outcomes: differentiating care delivery by education preparation. J Nurs Adm. Jan. 2005;35(1):7. Comment. [pmid: 15647658].
2056 Page L, McCourt C, Beake S, Vail A, Hewison J. Clinical interventions and outcomes of One-to-One midwifery practice. J Public Health Med. Sep. 1999;21(3):243-248. Not eligible target population. [pmid: 10528949].
2057 Page M. Tailoring nursing models to clients' needs. Using the Roper, Logan and Tierney model after discharge. Prof Nurse. Feb. 1995;10(5):284-288. Comment. [pmid: 7708783].
2058 Paget-Wilkes M. Self-rostering on a neonatal intensive care unit. Nurs Stand. Feb 19. 1997;11(22):39-42. Not eligible target population. [pmid: 9096510].
2059 Pallarito K. Rule delay leaves foreign nurses in limbo. Mod Healthc. Dec 3. 1990;20(48):6. News.
2060 Pallarito K. Labor proposes rules governing foreign nurses. Mod Healthc. Jul 23. 1990;20(29):4. News.
2061 Palmer J. Eight- and 12-hour shifts: comparing nurses' behavior patterns. Nurs Manage. Sep. 1991;22(9):42-44. No association tested. [pmid: 1891149].
2062 Panagiotopoulou K, Kerr SM. Pressure area care: an exploration of Greek nurses' knowledge and practice. J Adv Nurs. Nov. 2002;40(3):285-296. Not eligible target population. [pmid: 12383180].
2063 Papadatou D, Martinson IM, Chung PM. Caring for dying children: a comparative study of nurses' experiences in Greece and Hong Kong. Cancer Nurs. Oct. 2001;24(5):402-412. Not eligible target population. [pmid: 11605711].
2064 Pape TM. Applying airline safety practices to medication administration. Medsurg Nurs. Apr. 2003;12(2):77-93. quiz 94. Not eligible exposure. [pmid: 12736927].
2065 Pape TM, Guerra DM, Muzquiz M, Bryant JB, Ingram M, Schranner B, Alcala A, Sharp J, Bishop D, Carreno E, Welker J. Innovative approaches to reducing nurses' distractions during medication administration. J Contin Educ Nurs. May–Jun. 2005;36(3):108-116. quiz 141–102. Not eligible exposure. [pmid: 16022030].
2066 Paredes SD, Frank DI. Nurse/parent role perceptions in care of neonatal intensive care unit infants: implications for the advanced practice nurse. Clin Excell Nurse Pract. Sep. 2000;4(5):294-301. Not eligible exposure. [pmid: 11858451].
2067 Parish C. Minimum effort. Nurs Stand. Jul 3–9. 2002;16(42):12-13. Comment.
2068 Park EK, Song M. Communication barriers perceived by older patients and nurses. Int J Nurs Stud. Feb. 2005;42(2):159-166. Not eligible target population. [pmid: 15680614].
2069 Park HA, Park JH. Development of a computerized patient classification and staffing system. Stud Health Technol Inform. 1997;46:508-511. Not eligible target population. [pmid: 10175451].
2070 Parker MT, Leggett-Frazier N, Vincent PA, Swanson MS. The impact of an educational program on improving diabetes knowledge and changing behaviors of nurses in long-term care facilities. Diabetes Educ. Nov–Dec. 1995;21(6):541-545. Not eligible exposure. [pmid: 8549258].
2071 Parse RR. Language: words reflect and cocreate meaning. Nurs Sci Q. Jul. 2000;13(3):187. Editorial. [pmid: 11847795].
2072 Parsons LC. Building RN confidence for delegation decision-making skills in practice. J Nurses Staff Dev. Nov–Dec. 1999;15(6):263-269. Not eligible exposure. [pmid: 10839068].
2073 Parsons ML, Scaltrito S, Vondle DP. A program to manage nurse staffing costs. Nurs Manage. Oct. 1990;21(10):42-44. No association tested. [pmid: 2216161].
2074 Parsons ML, Stonestreet J. Staff nurse retention. Laying the groundwork by listening. Nurs Leadersh Forum. Spring. 2004;8(3):107-113. No association tested. [pmid: 15160633].
2075 Paterson I. Service assistants threaten nursing. Nurs N Z. May. 1997;3(4):32-33. Not eligible target population. [pmid: 9306836].
2076 Patrician PA. Multiple imputation for missing data. Res Nurs Health. Feb. 2002;25(1):76-84. Review. [pmid: 11807922].
2077 Patterson B. Safe patient care legislation addresses growing national problem. Mich Nurse. Aug. 2004;5:16. Review.
2078 Patterson P. PACU staffing. Staffing the recovery areas an art as well as a science. OR Manager. Apr 1998;14(4):1, 19–22. Not eligible target population.
2079 Patterson P. How ORs manage on-call varies by local market. OR Manager. Feb 2000;16(2):1, 8–11. Comment.
2080 Payne D. Time for judgement. Nurs Times. Jun 3–9. 1998;94(22):15. Comment.
2081 Payne S, Hardey M, Coleman P. Interactions between nurses during handovers in elderly care. J Adv Nurs. Aug. 2000;32(2):277-285. Not eligible target population. [pmid: 10964173].
2082 Pearce L. Your hospital needs you. Nurs Stand. Nov 1–7. 2000;15(7):14-15. Comment. [pmid: 11971425].
2083 Pederson C. Nonpharmacologic interventions to manage children's pain: immediate and short-term effects of a continuing education program. J Contin Educ Nurs. May–Jun. 1996;27(3):131-140. Not eligible exposure. [pmid: 8715881].
2084 Peerson A, Aitken R, Manias E, Parker J, Wong K. Agency nursing in Melbourne, Australia: a telephone survey of hospital and agency managers. J Adv Nurs. Dec. 2002;40(5):504-512. Not eligible target population. [pmid: 12437599].
2085 Penticuff JH, Arheart KL. Effectiveness of an intervention to improve parent-professional collaboration in neonatal intensive care. J Perinat Neonatal Nurs. Apr–Jun. 2005;19(2):187-202. Not eligible outcomes. [pmid: 15923969].
2086 Pepper GA. Errors in drug administration by nurses. Am J Health Syst Pharm. Feb 15. 1995;52(4):390-395. No association tested. [pmid: 7757866].
2087 Pereira LJ, Lee GM, Wade KJ. An evaluation of five protocols for surgical handwashing in relation to skin condition and microbial counts. J Hosp Infect. May. 1997;36(1):49-65. Not eligible exposure. [pmid: 9172045].
2088 Perez PG, Herrick LM. Doulas: exploring their roles with parents, hospitals, & nurses. AWHONN Lifelines. Apr. 1998;2(2):54-55. Comment. [pmid: 9633309].
2089 Perkins L. Support grows for Massachusetts RN staffing bill. Revolution. Oct–Nov. 2003;4(5):5. News. [pmid: 14631716].
2090 Perlow M, Rudolth LG. Registered nurse perceptions of nursing practice. Kentucky nurse. Oct–Dec. 1995;43(4):28-9. Not peer reviewed. [pmid: 8714982].
2091 Perras ST, Mattern M. A practical approach to TQI. Anna J. Apr 1994;21(2):129–136, 143. Not eligible outcomes.
2092 Perry K. The problem-free assignment. Nursing. Jun. 1998;28(6):86-87. Not eligible target population. [pmid: 9668805].
2093 Perry K. Time to try travel nurses?. Nurs Manage. Feb. 1999;30(2):39-40. No association tested. [pmid: 10188511].
2094 Perry L. Screening swallowing function of patients with acute stroke. Part one: Identification, implementation and initial evaluation of a screening tool for use by nurses. J Clin Nurs. Jul. 2001;10(4):463-473. Not eligible target population. [pmid: 11822494].
2095 Persuhn PG. Job sharing: two who made it work. Am J Nurs. Sep. 1992;92(9):75-80. Comment. [pmid: 1510105].
2096 Peters N, Cox J. Could a process improvement program improve your quality assurance. Case Manager. Mar–Apr. 2000;11(2):78-81. No association tested. [pmid: 11935529].
2097 Petersen MF, Cohen J, Parsons V. Family-centered care: do we practice what we preach?. J Obstet Gynecol Neonatal Nurs. Jul–Aug. 2004;33(4):421-427. Not eligible exposure.
2098 Petroff J. Registered nurses: do you have a right to overtime pay?. Ohio Nurses Rev. Aug. 1996;71(7):13. Comment. [pmid: 8945344].
2099 Petty DS. ECT in the PACU? It's possible. Nurs Manage. Nov. 2000;31(11):42-44. Comment. [pmid: 15127469].
2100 Phillips CY. Postdischarge follow-up care: effect on patient outcomes. J Nurs Care Qual. Jul. 1993;7(4):64-72. Not eligible exposure. [pmid: 8393358].
2101 Phillips H, Brunke L. Self scheduling helps nurses balance their personal & professional lives. RNABC News. Jul–Aug. 1990;22(4):15-16. No association tested. [pmid: 2396076].
2102 Phillips M. Telemedicine in the neonatal intensive care unit. Pediatr Nurs. Mar–Apr 1999;25(2):185–186, 189. Not eligible exposure.
2103 Phipps W, Honghong W, Min Y, Burgess J, Pellico L, Watkins CW, Guoping H, Williams A. Risk of medical sharps injuries among Chinese nurses. Am J Infect Control. Aug. 2002;30(5):277-282. Not eligible target population. [pmid: 12163861].
2104 Picton CE. An exploration of family-centred care in Neuman's model with regard to the care of the critically ill adult in an accident and emergency setting. Accid Emerg Nurs. Jan. 1995;3(1):33-37. Comment. [pmid: 7712222].
2105 Pieper B, Mattern JC. Critical care nurses' knowledge of pressure ulcer prevention, staging and description. Ostomy Wound Manage. Mar 1997;43(2):22–26, 28, 30–21. Not eligible exposure.
2106 Pillar B, Jarjoura D. Assessing the impact of reengineering on nursing. J Nurs Adm. May. 1999;29(5):57-64. Not eligible outcomes. [pmid: 10333862].
2107 Piloian BB. Alternative staffing strategies for community hospital-based diabetes education programs. Diabetes Educ. Jul–Aug 1992;18(4):293, 295–296. Not eligible exposure.
2108 Piltz-Kirkby M. The nursing assignment pattern study in clinical practice. Nurs Manage. May 1991;22(5):96HH, 96LL, 96NN. No association tested.
2109 Pink GH, Hall LM, Leatt P. Canadian-trained nurses in North Carolina. Healthcare Quarterly 2004;7(3): Longwoods Review, Volume 2, Number 2):2–11. Not relevant.
2110 Pinkerton S. Payoffs from investments: improving, transforming, and building skills. Nurs Econ. Sep–Oct. 2002;20(5):244-248. Comment. [pmid: 12382545].
2111 Pinnock D. Experience of being a shift co-ordinator. Nurs Crit Care. Sep–Oct. 1998;3(5):227-236. Not eligible target population. [pmid: 9887771].
2112 Pioro MH, Landefeld CS, Brennan PF, Daly B, Fortinsky RH, Kim U, Rosenthal GE. Outcomes-based trial of an inpatient nurse practitioner service for general medical patients. J Eval Clin Pract. Feb. 2001;7(1):21-33. Not eligible exposure. [pmid: 11240837].
2113 Pirret AM. Utilizing TISS to differentiate between intensive care and high-dependency patients and to identify nursing skill requirements. Intensive Crit Care Nurs. Feb. 2002;18(1):19-26. Not eligible target population. [pmid: 12008873].
2114 Pisarski A, Bohle P. Effects of supervisor support and coping on shiftwork tolerance. J Hum Ergol (Tokyo). Dec. 2001;30(12):363-368. Not eligible target population. [pmid: 14564909].
2115 Pisarski A, Bohle P, Callan VJ. Effects of coping strategies, social support and work-nonwork conflict on shift worker's health. Scand J Work Environ Health. 1998;24(Suppl 3):141-145. Not eligible target population. [pmid: 9916831].
2116 Pitt HA, Murray KP, Bowman HM, Coleman J, Gordon TA, Yeo CJ, Lillemoe KD, Cameron JL. Clinical pathway implementation improves outcomes for complex biliary surgery. Surgery. Oct. 1999;126(4):751-756. discussion 756–758. Not eligible exposure. [pmid: 10520925].
2117 Pizer CM, Collard AF, Bishop CE, James SM, Bonaparte B. Recruiting and employing foreign nurse graduates in a large public hospital system. Hosp Health Serv Adm. Spring. 1994;39(1):31-46. Not eligible exposure. [pmid: 10132099].
2118 Place B, Cornock M. Critical timing. Nurs Times. Jun 25–Jul 1. 1997;93(26):26-28. Not eligible target population. [pmid: 9239051].
2119 Plant ML, Plant MA, Foster J. Stress, alcohol, tobacco and illicit drug use amongst nurses: a Scottish study. J Adv Nurs. Sep. 1992;17(9):1057-1067. Not eligible target population. [pmid: 1401547].
2120 Plati C, Lanara VA, Katostaras T, Mantas J. Nursing absenteeism—one determining factor for the staffing plan. Scand J Caring Sci. 1994;8(3):143-148. Not eligible outcomes. [pmid: 7724921].
2121 Plowright C. Auditing quality of nursing care. Intensive Crit Care Nurs. Dec. 1995;11(6):354-359. No association tested. [pmid: 8574088].
2122 Plowright C, O'Riordan B, Scott G. The perception of ward-based nurses seconded into an Outreach Service. Nurs Crit Care. May–Jun. 2005;10(3):143-149. Not eligible target population. [pmid: 15918427].
2123 Plum SD. Three Denver nurses may face prison in a case that bodes ill for the profession. Revolution. Summer. 1997;7(2):11-12. Comment. [pmid: 9277304].
2124 Plum SD. Medication error—nurses indicated. Nursing. Jul. 1997;27(7):34-35. Comment. [pmid: 9275764].
2125 Poirrier GP, Granger M, Todaro M. ACE—Alliance for Clinical Enhancement: a collaborative model. Nursingconnections. Fall. 1993;6(3):53-61. Not eligible exposure. [pmid: 8107899].
2126 Poissonnet CM, Iwatsubo Y, Cosquer M, Quera Salva MA, Caillard JF, Veron M. A cross-sectional study of the health effects of work schedules on 3212 hospital workers in France: implications for the new French work schedules policy. J Hum Ergol (Tokyo). Dec. 2001;30(12):387-391. Not eligible target population. [pmid: 14564913].
2127 Polkki T, Vehvilainen-Julkunen K, Pietila AM. Nonpharmacological methods in relieving children's postoperative pain: a survey on hospital nurses in Finland. J Adv Nurs. May. 2001;34(4):483-492. Not eligible target population. [pmid: 11380715].
2128 Pongsatha S, Morakote N, Sribanditmongkol N, Chaovisitsaree S. Symptoms of estrogen deficiency in nursing personnel in Maharaj Nakorn Chiang Mai Hospital. J Med Assoc Thai. Apr. 2004;87(4):405-409. Not eligible target population. [pmid: 15217179].
2129 Pope BB. The Synergy match-up. Nurs Manage. May. 2002;33(5):38-41. Comment. [pmid: 12006887].
2130 Pope M. A mix-up of tubes. Medication administered through the wrong access line. Am J Nurs. Apr. 2002;102(4):23. Case Reports. [pmid: 11943915].
2131 Poroch D, McIntosh W. Barriers to assertive skills in nurses. Aust N Z J Ment Health Nurs. Sep. 1995;4(3):113-123. Not eligible target population. [pmid: 9086937].
2132 Poquette MC, Platte J, Casey K. Meeting the staffing challenge: development of a voluntary on-call system. Critical care nursing quarterly. Nov. 1992;15(3):29-36. Not relevant. [pmid: 1490231].
2133 Porter-O'Grady T. Mission with a margin. Nurs Manage. Jun. 2000;31(6):8. Editorial.
2134 Potter P, Boxerman S, Wolf L, Marshall J, Grayson D, Sledge J, Evanoff B. Mapping the nursing process: a new approach for understanding the work of nursing. J Nurs Adm. Feb. 2004;34(2):101-109. Not eligible exposure. [pmid: 14770070].
2135 Potter P, Wolf L, Boxerman S, et al. Understanding the cognitive work of nursing in the acute care environment. Journal of Nursing Administration. Jul–Aug. 2005;35(7/8):327-35. Not relevant. [pmid: 16077274].
2136 Powell C, Walker J, Christie M, Mitchell-Pedersen L, Rauscher C. The unexpected relocation of elderly in-patients in response to a threatened strike. J Adv Nurs. Apr. 1990;15(4):423-429. Not eligible exposure. [pmid: 2341687].
2137 Powers BA. Everyday ethics in assisted living facilitites: a framework for assessing resident-focused issues. J Gerontol Nurs. Jan. 2005;31(1):31-37. Case Reports. [pmid: 15675782].
2138 Powers J, Daniels D. Turning points: implementing kinetic therapy in the ICU. Nurs Manage. May 2004;35(5):suppl 1–7; quiz 8. Not eligible exposure.
2139 Powers JL. Accepting and refusing assignments. Nurs Manage. Sep 1993;24(9):64–66, 68. Comment.
2140 Pownall M. Shifting ground. Nurs Times. Oct 31–Nov 6. 1990;86(44):19. Comment.
2141 Prater M. Victory for Youngstown nurses. New contract ensures safe hours, safe staffing and quality patient care for RNs. Ohio Nurses Rev. Aug. 2001;76(7):1. Comment. [pmid: 15706817].
2142 Pratt R, Burr G, Leelarthaepin B, Blizard P, Walsh S. The effects of All-RN and RN-EN staffing on the quality and cost of patient care. Aust J Adv Nurs. Mar–May. 1993;10(3):27-39. Case Reports. [pmid: 8240762].
2143 Prescott PA, Soeken KL. Measuring nursing intensity in ambulatory care. Part II: Developing and testing PINAC. Nurs Econ. Mar–Apr 1996;14(2):86–91, 116. Not eligible target population.
2144 Prescott PA, Soeken KL, Ryan JW. Measuring patient intensity. A reliability study. Eval Health Prof. Sep. 1989;12(3):255-269. Not eligible year. [pmid: 10303834].
2145 Price C. A national uprising. United actions push mandatory overtime, inadequate staffing to forefront. Am J Nurs. Dec. 2000;100(12):75-76. Review. [pmid: 11202790].
2146 Pringle D. What do nursing and the law have in common: retention. Can J Nurs Leadersh. Mar 2004;17(1):1–2, 4. Editorial.
2147 Procter S. It all depends. Health Serv J. Jan 21. 1993;103(5336):27. Not eligible target population. [pmid: 10124806].
2148 Proctor M. Medicalisation of life: are nurses involved?. Contemp Nurse. Sep–Dec. 2000;9(34):263-264. Case Reports. [pmid: 11855035].
2149 Proehl JA. Developing emergency nursing competence. Nurs Clin North Am. Mar 2002;37(1):89–96, vii. Not eligible exposure.
2150 Pronger L. Floating: sink or swim. Can Nurse. Dec. 1995;91(11):28-32. No association tested. [pmid: 8713148].
2151 Pronitis-Ruotolo D. Surviving the night shift. Am J Nurs. Jul 2001;101(7):63–65, 67–68. Comment.
2152 Pronovost P, Wu AW, Dorman T, Morlock L. Building safety into ICU care. J Crit Care. Jun. 2002;17(2):78-85. Case Reports. [pmid: 12096370].
2153 Puckett F. Medication-management component of a point-of-care information system. Am J Health Syst Pharm. Jun 15. 1995;52(12):1305-1309. Not eligible exposure. [pmid: 7656117].
2154 Pullenayegum S, Fielding B, Du Plessis E, Peate I. The value of the role of the rehabilitation assistant. Br J Nurs. Jul 28–Aug 10. 2005;14(14):778-784. Not eligible target population. [pmid: 16116384].
2155 Pumford S, Pettigrew C, Sargent J. Revising routines. Nurs Times. Aug 28–Sep 3. 1991;87(35):31-33. Comment. [pmid: 1881803].
2156 Puntillo K, Neighbor M, O'Neil N, Nixon R. Accuracy of emergency nurses in assessment of patients' pain. Pain Manag Nurs. Dec. 2003;4(4):171-175. Not eligible exposure. [pmid: 14663795].
2157 Purnell LD. A survey of emergency department triage in 185 hospitals: physical facilities, fast-track systems, patient-classification systems, waiting times, and qualification, training, and skills of triage personnel. J Emerg Nurs. Dec. 1991;17(6):402-407. Not eligible outcomes. [pmid: 1749147].
2158 Quigley P, Janzen SK, King I, Goucher E. Nurse staffing and patient outcomes from one acute care setting within the Department of Veterans' Affairs. Fla Nurse. Jun. 1999;47(2):34. No association tested. [pmid: 11995138].
2159 Quinn S. Making a nonsense of training. RCM Midwives. Jul. 2004;7(7):312. Not eligible target population. [pmid: 15314931].
2160 Rae CP, Gallagher G, Watson S, Kinsella J. An audit of patient perception compared with medical and nursing staff estimation of pain during burn dressing changes. Eur J Anaesthesiol. Jan. 2000;17(1):43-45. Not eligible target population. [pmid: 10758443].
2161 Rainer SR. Ratio bill gains support. N J Nurse. Sep–Oct. 2003;33(7):1-12. News. [pmid: 14603741].
2162 Raines DA. Choices of neonatal nurses in ambiguous clinical situations. Neonatal Netw. Feb. 1996;15(1):17-25. Not eligible exposure. [pmid: 8700079].
2163 Ralston R. Clinical governance. One year on: Part 2. Pract Midwife. Jun. 2001;4(6):33-34. Not eligible target population. [pmid: 12026845].
2164 Rambur B, McIntosh B, Palumbo MV, Reinier K. Education as a determinant of career retention and job satisfaction among registered nurses. J Nurs Scholarsh. 2005;37(2):185-192. Not Eligible Exposure. [pmid: 15960064].
2165 Ramritu P, Courtney M, Stanley T, Finlayson K. Experiences of the generalist nurse caring for adolescents with mental health problems. J Child Health Care. Dec. 2002;6(4):229-244. Not eligible target population. [pmid: 12503894].
2166 Ramsey P, Cathelyn J, Gugliotta B, Glenn LL. Restricted versus open ICUs. Nurs Manage. Jan. 2000;31(1):42-44. Not eligible exposure. [pmid: 10818942].
2167 Ramudu L, Bellet B, Higgs J, Latimer C, Smith R. How effectively do we use double staff time?. Aust J Adv Nurs. Mar–May. 1994;11(3):5-10. Not eligible target population. [pmid: 7980883].
2168 Randolph AG, Zollo MB, Wigton RS, Yeh TS. Factors explaining variability among caregivers in the intent to restrict life-support interventions in a pediatric intensive care unit. Crit Care Med. Mar. 1997;25(3):435-439. Not eligible exposure. [pmid: 9118659].
2169 Rankin JM. ‘Patient satisfaction’: knowledge for ruling hospital reform—an institutional ethnography. Nurs Inq. Mar. 2003;10(1):57-65. Comment. [pmid: 12622805].
2170 Rapala K. Mentoring staff members as patient safety leaders: the Clarian Safe Passage Program. Crit Care Nurs Clin North Am. Jun 2005;17(2):121–126, ix. No association tested.
2171 Rasmussen BH, Sandman PO. Nurses' work in a hospice and in an oncological unit in Sweden. Hosp J. 2000;15(1):53-75. Not eligible target population. [pmid: 11033659].
2172 Rauhala A, Fagerstrom L. Determining optimal nursing intensity: the RAFAELA method. J Adv Nurs. Feb. 2004;45(4):351-359. Not eligible target population. [pmid: 14756829].
2173 Rawal N, Das G, Kishen M. Assessment of contraceptive services in a maternity unit of a district general hospital in the UK. J Obstet Gynaecol. Feb. 2005;25(2):179-181. Not eligible target population. [pmid: 15814401].
2174 Rawlinson D. Audit of nutritional practice and knowledge. Prof Nurse. Feb. 1998;13(5):291-294. Not eligible target population. [pmid: 9544080].
2175 Rawnsley MM. Response to Kim's human living concept as a unifying perspective for nursing. Nurs Sci Q. Jan. 2000;13(1):41-44. Comment. [pmid: 11847779].
2176 Ray CE, Jagim M, Agnew J, McKay JI, Sheehy S. ENA's new guidelines for determining emergency department nurse staffing. J Emerg Nurs. Jun. 2003;29(3):245-253. Guidelines. [pmid: 12776080].
2177 Rayens MK, Svavarsdottir EK. A new methodological approach in nursing research: an actor, partner, and interaction effect model for family outcomes. Res Nurs Health. Oct. 2003;26(5):409-419. Not eligible exposure. [pmid: 14579261].
2178 Ream KA. California to mandate nurse-patient staffing ratio. J Emerg Nurs. Dec. 2000;26(6):29A. News.
2179 Redfern S, Norman I. Quality of nursing care perceived by patients and their nurses: an application of the critical incident technique. Part 2. J Clin Nurs. Jul. 1999;8(4):414-421. Not eligible target population. [pmid: 10624258].
2180 Redfern S, Norman I. Quality of nursing care perceived by patients and their nurses: an application of the critical incident technique. Part 1. J Clin Nurs. Jul. 1999;8(4):407-413. Not eligible target population. [pmid: 10624257].
2181 Redshaw ME, Harris A. Nursing skill mix in neonatal care. J Nurs Manag. Jan. 1994;2(1):15-23. Not eligible target population. [pmid: 7952685].
2182 Redshaw ME, Harris A, Ingram JC. Nursing and medical staffing in neonatal units. J Nurs Manag. Sep. 1993;1(5):221-228. Not eligible target population. [pmid: 8313063].
2183 Reed J, Morgan D. Discharging older people from hospital to care homes: implications for nursing. J Adv Nurs. Apr. 1999;29(4):819-825. Not eligible target population. [pmid: 10215972].
2184 Reed JL, Lyne M. Inpatient care of mentally ill people in prison: results of a year's programme of semistructured inspections. Bmj. Apr 15. 2000;320(7241):1031-1034. Not eligible target population. [pmid: 10764360]. [pmcid: 27341].
2185 Reed L, Blegen MA, Goode CS. Adverse patient occurrences as a measure of nursing care quality. J Nurs Adm. May. 1998;28(5):62-69. Not eligible exposure. [pmid: 9601494].
2186 Reed P, Smith P, Fletcher M, Bradding A. Promoting the dignity of the child in hospital. Nurs Ethics. Jan. 2003;10(1):67-76. Not eligible target population. [pmid: 12572762].
2187 Reeder L. “Coopetition,” perks and price tags: stakes grow higher as the workforce crisis worsens. Healthc Leadersh Manag Rep. Mar. 2002;10(3):1-9. Review.
2188 Reedy JE. Transfer of a patient with a ventricular assist device to a non-critical care area. Heart Lung. Jan–Feb. 1993;22(1):71-76. Case Reports. [pmid: 8420859].
2189 Rees C, Lehane M. Witnessing violence to staff: a study of nurses' experiences. Nurs Stand. Dec 18. 1996;11(1315):45-47. Not eligible target population. [pmid: 9000944].
2190 Reeve K, Calabro K, AdamsMcNeill J. Tobacco cessation intervention in a nurse practitioner managed clinic. Journal of the American Academy of Nurse Practitioners. May. 2000;12(5):163-9. Not relevant. [pmid: 11930337].
2191 Regan S. Fewer graduates able to find full-time employment. Nursing BC. Dec. 2004;36(5):14-5. Not peer reviewed. [pmid: 15633522].
2192 Reichelt PA, Larson PA. Preimplementation financial evaluation of a structural work change: cost analysis of an innovative staffing schedule. Nurs Adm Q. Spring. 1994;18(3):68-73. No association tested. [pmid: 8196859].
2193 Reid C. Developing a tissue viability nursing assistant role. Nurs Stand. Apr 21–27. 2004;18(32):68-72. Not eligible target population. [pmid: 15132039].
2194 Reid N, Robinson G, Todd C. The 12-hour shift: the views of nurse educators and students. J Adv Nurs. May. 1994;19(5):938-946. Not eligible target population. [pmid: 8056923].
2195 Reid N, Todd C, Robinson G. Educational activities on wards under 12 hour shifts. Int J Nurs Stud. 1991;28(1):47-54. Not eligible target population. [pmid: 1856033].
2196 Reid T. Work well campaign. A suitable case for treatment. Nurs Times. Jun 14–20. 1995;91(24):28-30. Case Reports.
2197 Reilly P. A case for more nurses. JAMA study: chance of dying increases with more patients under nurse's care. Mod Healthc. Oct 28. 2002;32(43):14. News. [pmid: 12436771].
2198 Reilly P. In need of nurses. Illinois hospital makes name for itself through RN retention, recruitment. Mod Healthc. Nov 24. 2003;33(47):S19-20. Comment. [pmid: 14666577].
2199 Reilly P. Importing controversy. U.S. hospitals' recruitment of foreign nurses stirs debate as poorer countries struggle with staffing shortages of their own. Mod Healthc. Mar 31. 2003;33(13):20-24. Comment.
2200 Reilly P. Foreign certification. AHA seeks delay on regs for immigrant nurses. Mod Healthc. Feb 23. 2004;34(8):17. News.
2201 Reis Miranda D, Moreno R, Iapichino G. Nine equivalents of nursing manpower use score (NEMS). Intensive Care Med. Jul. 1997;23(7):760-765. Not eligible target population. [pmid: 9290990].
2202 Reisdorfer JT. Building a patient-focused care unit. Nurs Manage. Oct 1996;27(10):38, 40, 42 passim. No association tested.
2203 Renaud M. Mandatory overtime: whose right is right?. Revolution. Jul–Aug. 2000;1(4):31. Comment. [pmid: 12017599].
2204 Render ML, Kim HM, Welsh DE, Timmons S, Johnston J, Hui S, Connors AF Jr, Wagner D, Daley J, Hofer TP. Automated intensive care unit risk adjustment: results from a National Veterans Affairs study. Crit Care Med. Jun. 2003;31(6):1638-1646. Not eligible exposure. [pmid: 12794398].
2205 Retsas A, Pinikahana J. Manual handling activities and injuries among nurses: an Australian hospital study. J Adv Nurs. Apr. 2000;31(4):875-883. Not eligible target population. [pmid: 10759984].
2206 Reynolds M, Thomsen C, Black L, Moody R. The nuts and bolts of organizing and initiating a pediatric transport team. The Sutter Memorial experience. Crit Care Clin. Jul. 1992;8(3):465-480. No association tested. [pmid: 1638435].
2207 Ricci M, Goldman AP, de Leval MR, Cohen GA, Devaney F, Carthey J. Pitfalls of adverse event reporting in paediatric cardiac intensive care. Arch Dis Child. Sep. 2004;89(9):856-859. Not eligible exposure. [pmid: 15321866].
2208 Rich K. Inhospital cardiac arrest: pre-event variables and nursing response. Clin Nurse Spec. May. 1999;13(3):147-153. quiz 154–146. Not eligible exposure. [pmid: 10531841].
2209 Richardson A, Burnand V, Colley H, Coulter C. Ward nurses' evaluation of critical care outreach. Nurs Crit Care. Jan–Feb. 2004;9(1):28-33. Not eligible target population. [pmid: 14871007].
2210 Richardson A, Dabner N, Curtis S. Twelve-hour shift on ITU: a nursing evaluation. Nurs Crit Care. May–Jun. 2003;8(3):103-108. Not eligible target population. [pmid: 12859080].
2211 Richardson JR, Braitberg G, Yeoh MJ. Multidisciplinary assessment at triage: a new way forward. Emerg Med Australas. Feb. 2004;16(1):41-46. Not eligible target population. [pmid: 15239754].
2212 Richardson T. Patient focused care: consultants, foundations, educational programs. Revolution. Spring. 1996;6(1):35-38. Comment. [pmid: 8705046].
2213 Richie K, Peeler C. Plug into success with centralized flex staffing. Nurs Manage. Feb. 2005;36(2):18. Review. [pmid: 15701998].
2214 Ricketts T. General satisfaction and satisfaction with nursing communication on an adult psychiatric ward. J Adv Nurs. Sep. 1996;24(3):479-487. Not eligible target population. [pmid: 8876407].
2215 Riddell AM, Charig MJ. A survey of current practice in out of hours percutaneous nephrostomy insertion in the United Kingdom. Clin Radiol. Dec. 2002;57(12):1067-1069. Not eligible target population. [pmid: 12475529].
2216 Ridge KW, Jenkins DB, Noyce PR, Barber ND. Medication errors during hospital drug rounds. Qual Health Care. Dec. 1995;4(4):240-243. Not eligible target population. [pmid: 10156392].
2217 Ridley S, Biggam M, Stone P. Cost of intensive therapy. A description of methodology and initial results. Anaesthesia. Jul. 1991;46(7):523-530. Not eligible target population. [pmid: 1862888].
2218 Riley J. Cross-training: maximizing staffing flexibility. Nurs Manage. Jun. 1990;21(6):48I-48J. No association tested.
2219 Riley V. Dangerous liaison. Nurs Times. Nov 11–17. 1998;94(45):30-31. Case Reports. [pmid: 9919273].
2220 Ringerman ES, Ventura S. An outcomes approach to skill mix change in critical care. Nurs Manage. Oct. 2000;31(10):42-46. No association tested. [pmid: 15127557].
2221 Ritter-Teitel J. Registered nurse hours worked per patient day: the key to assessing staffing effectiveness and ensuring patient safety. J Nurs Adm. Apr. 2004;34(4):167-169. No association tested. [pmid: 15097210].
2222 Ritz DA, Dugan MF. 12-hour shifts. A scheduling alternative for ORs. Aorn J. Mar 1990;51(3):810–811, 813, 815. No association tested.
2223 Rivares AV, Navarrete IG, Pueyo CG, Torrent AM, Duran MM, Gatius JR, Mussol LR, Solano M. Evaluation of relationships between haemodialysis unit professionals. Edtna Erca J. Jan–Mar. 2004;30(1):27-30. Not eligible target population. [pmid: 15163031].
2224 Rivers FM, Lavallee SM, Nenninger KM, Nichols D. Evaluation of a bed utilization system in a surgical nursing section. Mil Med. Dec. 1998;163(12):839-843. Not eligible exposure. [pmid: 9866364].
2225 Robb EA, Determan AC, Lampat LR, Scherbring MJ, Slifka RM, Smith NA. Self-scheduling: satisfaction guaranteed?. Nurs Manage. Jul. 2003;34(7):16-18. Comment. [pmid: 12843713].
2226 Roberts D. Competence increases comfort for float nurses. Medsurg Nurs. Jun. 2004;13(3):142. Editorial. [pmid: 15219161].
2227 Roberts G, Fielding P. No vacancies. Nurs Stand. Jan 13–19. 1999;13(17):16. News. [pmid: 10076360].
2228 Roberts M, Potter J, McColl J, Reilly J. Can prescription of sip-feed supplements increase energy intake in hospitalised older people with medical problems?. Br J Nutr. Aug. 2003;90(2):425-429. Not eligible exposure. [pmid: 12908904].
2229 Robertson MA, Molyneux EM. Triage in the developing world—can it be done?. Arch Dis Child. Sep. 2001;85(3):208-213. Not eligible target population. [pmid: 11517102].
2230 Robertson MS, Cade JF, Clancy RL. Helicobacter pylori infection in intensive care: increased prevalence and a new nosocomial infection. Crit Care Med. Jul. 1999;27(7):1276-1280. Not eligible target population. [pmid: 10446820].
2231 Robertson RH, Dowd SB, Hassan M. Skill-specific staffing intensity and the cost of hospital care. Health Care Manage Rev. Fall. 1997;22(4):61-71. Not eligible outcomes. [pmid: 9358261].
2232 Robinson A, Street A. Improving networks between acute care nurses and an aged care assessment team. J Clin Nurs. May. 2004;13(4):486-496. Not eligible exposure. [pmid: 15086635].
2233 Robinson CA. Magnet nursing services recognition: transforming the critical care environment. AACN Clin Issues. Aug. 2001;12(3):411-423. Not eligible exposure. [pmid: 11759359].
2234 Robinson J. Education. Think pink. Nurs Stand. Nov 14–20. 1990;5(8):43. No association tested. [pmid: 2123699].
2235 Robinson K. Nursing's perfect storm—staff shortages and patient ratios. J Emerg Nurs. Jun. 2003;29(3):199-200. Review. [pmid: 12776070].
2236 Robinson S. Florence of Arabia. Nurs Times. Oct 18–24. 1995;91(42):46-47. Comment. [pmid: 7479158].
2237 Robinson SE, Roth SL, Keim J, et al. Nurse burnout: work related and demographic factors as culprits. Research in nursing & health. Jun. 1991;14(3):223-8. Not relevant. [pmid: 1887102].
2238 Robinson SE, Roth SL, Keim J, Levenson M, Flentje JR, Bashor K. Nurse burnout: work related and demographic factors as culprits. Res Nurs Health. Jun. 1991;14(3):223-228. Not eligible outcomes. [pmid: 1887102].
2239 Rocker G, Cook D, Sjokvist P, Weaver B, Finfer S, McDonald E, Marshall J, Kirby A, Levy M, Dodek P, Heyland D, Guyatt G. Clinician predictions of intensive care unit mortality. Crit Care Med. May. 2004;32(5):1149-1154. Not eligible exposure. [pmid: 15190965].
2240 Rodriguez L. Recruitment and retention. Four ways to make a difference. Nurs Staff Dev Insid. Jan–Feb. 1992;1(1):4-7. Comment. [pmid: 1304932].
2241 Rodriguez RM, Dresden GM, Young JC. Patient and provider attitudes toward commercial television film crews in the emergency department. Acad Emerg Med. Jul. 2001;8(7):740-745. Not eligible exposure. [pmid: 11435191].
2242 Rogers AE, Hwang WT, Scott LD, Aiken LH, Dinges DF. The working hours of hospital staff nurses and patient safety. Health Aff (Millwood). Jul–Aug. 2004;23(4):202-212. Not eligible outcomes. [pmid: 15318582].
2243 Rogers AE, Hwang W, Scott LD. The effects of work breaks on staff nurse performance. Journal of Nursing Administration. Nov. 2004;34(11):512-9. Not relevant. [pmid: 15586072].
2244 Rogers R. The Beverly Allitt case. Qualified in caring?. Nurs Stand. Feb 23–Mar 1. 1994;8(22):21-22. Not eligible target population. [pmid: 8123539].
2245 Rohland P. N.J. passes bill to end mandatory overtime. Revolution. Jul–Aug. 2000;1(4):10-11. News. [pmid: 12017593].
2246 Rollins D. Study side notes. Nurs Manage. Sep. 2003;34(9):10. Comment. [pmid: 14501523].
2247 Rollins G. Workforce. Who's exempt? New overtime rules still getting scrutiny from nurse unions and lawmakers. Hosp Health Netw. Apr. 2005;79(4):30. News. [pmid: 15916340].
2248 Romea S, Alkiza ME, Ramon JM, Oromi J. Risk for occupational transmission of HIV infection among health care workers. Study in a Spanish hospital. Eur J Epidemiol. Apr. 1995;11(2):225-229. Not eligible target population. [pmid: 7672081].
2249 Ronsmans C, Etard JF, Walraven G, Hoj L, Dumont A, de Bernis L, Kodio B. Maternal mortality and access to obstetric services in West Africa. Trop Med Int Health. Oct. 2003;8(10):940-948. Not eligible target population. [pmid: 14516306].
2250 Roscoe J, Haig N. Shift work. Planning shift patterns. Nurs Times. Sep 19–25. 1990;86(38):31-33. Comment. [pmid: 2216822].
2251 Roseman C, Booker JM. Workload and environmental factors in hospital medication errors. Nurs Res. Jul–Aug. 1995;44(4):226-230. Not eligible outcomes. [pmid: 7624233].
2252 Rosen LF. The changing face of staffing—UAPs. Todays Surg Nurse. May–Jun. 1999;21(3):39-40. Comment. [pmid: 10808961].
2253 Rosenbach ML. CRNA vacancy rates in US hospitals. Nurse anesthesia. Jun. 1990;1(2):61-70. Not relevant. [pmid: 2285717].
2254 Rosenfeld P, Harrington C. Hospital care for elderly. Am J Nurs. May. 2003;103(5):115. Review. [pmid: 12759616].
2255 Rosenstein AH, O'Daniel M. Study links disruptive behavior to negative patient outcomes. OR Manager. Mar 2005;21(3):1, 20, 22. Comment.
2256 Rosenthal VD, Guzman S, Safdar N. Effect of education and performance feedback on rates of catheter-associated urinary tract infection in intensive care units in Argentina. Infect Control Hosp Epidemiol. Jan. 2004;25(1):47-50. Not eligible exposure. [pmid: 14756219].
2257 Rothberg MB, Abraham I, Lindenauer PK, Rose DN. Improving nurse-to-patient staffing ratios as a cost-effective safety intervention. Med Care. Aug. 2005;43(8):785-791. Review. [pmid: 16034292].
2258 Rothman LW. Implementing patient-focused care: success indicators for measuring satisfaction. Recruit Retent Restruct Rep. Sep. 1995;8(9):1-6. No association tested. [pmid: 7551910].
2259 Rothrock JC, Smith DA. Selecting the perioperative patient focused model. Aorn J. May 2000;71(5):1030–1034, 1036–1037. Not eligible exposure.
2260 Routh BA, Stafford R. Implementing a patient-focused care delivery model. J Nurs Staff Dev. Jul–Aug. 1996;12(4):208-212. No association tested. [pmid: 8936166].
2261 Rowe J. Making oneself at home? Examining the nurse-parent relationship. Contemp Nurse. Sep. 1996;5(3):101-106. Not eligible target population. [pmid: 9110654].
2262 Rowen L, Raymond R, Thomas K. The patient care delivery mode at Mercy Medical Center: a licensed caregiver model. Aspens Advis Nurse Exec. Dec 1998;14(3):1, 3–6. Not eligible exposure.
2263 Rowland W. Patients' perceptions of nurse uniforms. Nurs Stand. Feb 2–8. 1994;8(19):32-36. Not eligible exposure. [pmid: 8136247].
2264 Ruane-Morris M, Thompson G, Lawton S. Designing a nursing model for dermatology. Prof Nurse. Jun. 1995;10(9):565-566. Comment. [pmid: 7604053].
2265 Rudy EB, Lucke JF, Whitman GR, Davidson LJ. Benchmarking patient outcomes. J Nurs Scholarsh. 2001;33(2):185-189. Not eligible outcomes. [pmid: 11419316].
2266 Rudy S, Sions J. Floating: managing a recruitment and retention issue. J Nurs Adm. Apr. 2003;33(4):196-198. No association tested. [pmid: 12690249].
2267 Ruflin P, Matlack R, Holy C, Sorbello S, Nadzan L, Selden T. Closed-unit staffing speaks volumes. Nurs Manage. Jun. 1999;30(6):37-39. quiz 40. Comment. [pmid: 10562060].
2268 Ruland CM, Ravn IH. Usefulness and effects on costs and staff management of a nursing resource management information system. Journal of nursing management. May. 2003;11(3):208-15. Not relevant. [pmid: 12694368].
2269 Runeson I, Hallstrom I, Elander G, Hermeren G. Children's participation in the decision-making process during hospitalization: an observational study. Nurs Ethics. Nov. 2002;9(6):583-598. Not eligible target population. [pmid: 12449996].
2270 Runy LA. The health care workforce. State-by-state numbers and initiatives. Hosp Health Netw. Aug. 2002;76(8):41-46. Comment. [pmid: 12197039].
2271 Rusch LM. Supporting clinical nursing leadership and professional practice at the unit level. Nurs Leadersh Forum. Winter. 2004;9(2):61-66. No association tested. [pmid: 16033045].
2272 Rush J, Fiorino-Chiovitti R, Kaufman K, Mitchell A. A randomized controlled trial of a nursery ritual: wearing cover gowns to care for healthy newborns. Birth. Mar. 1990;17(1):25-30. Not eligible exposure. [pmid: 2189428].
2273 Rushforth K. A randomised controlled trial of weaning from mechanical ventilation in paediatric intensive care (PIC). Methodological and practical issues. Intensive Crit Care Nurs. Apr. 2005;21(2):76-86. Not eligible target population. [pmid: 15778071].
2274 Russell D. Changing public health nursing practice. Nurs N Z. Dec–2000 Jan. 1999;5(11):18-19. Comment. [pmid: 12008211].
2275 Russell LJ, Reynolds TM. How accurate are pressure ulcer grades? An image-based survey of nurse performance. J Tissue Viability. Apr 2001;11(2):67, 70–65. Not eligible target population.
2276 Russell S. Reducing readmissions to the intensive care unit. Heart Lung. Sep–Oct. 1999;28(5):365-372. Not eligible target population. [pmid: 10486454].
2277 Ruth M, Locsin R. The effect of music listening on acute confusion and delirium in elders undergoing elective hip and knee surgery. J Clin Nurs. Sep. 2004;13(6B):91-96. Not eligible exposure. [pmid: 15724823].
2278 Ryan CA, Clark LM, Malone A, Ahmed S. The effect of a structured neonatal resuscitation program on delivery room practices. Neonatal Netw. Feb. 1999;18(1):25-30. Not eligible target population. [pmid: 10205469].
2279 Ryan DW, Bayly PJ, Weldon OG, Jingree M. A prospective two-month audit of the lack of provision of a high-dependency unit and its impact on intensive care. Anaesthesia. Mar. 1997;52(3):265-270. Legal cases. [pmid: 9124669].
2280 Ryan M. On the record. Nurs Stand. Mar 18–24. 1998;12(26):23. Comment. [pmid: 9697508].
2281 Ryan M. A buddy program for international nurses. J Nurs Adm. Jun. 2003;33(6):350-352. News. [pmid: 12796633].
2282 Ryan T, Hills B, Webb L. Nurse staffing levels and budgeted expenditure in acute mental health wards: a benchmarking study. J Psychiatr Ment Health Nurs. Feb. 2004;11(1):73-81. Not eligible target population. [pmid: 14723642].
2283 Ryrie I, McGowan J. Staff perceptions of substance use among acute psychiatry inpatients. J Psychiatr Ment Health Nurs. Apr. 1998;5(2):137-142. Not eligible target population. [pmid: 9661415].
2284 Sadaba JR, Wheatley GH. Surgical assistants and working time directives. Eur J Cardiothorac Surg. Jun. 2004;25(6):1130-1131. author reply 1131–1132. Comment. [pmid: 15145026].
2285 Safdar N, Kluger DM, Maki DG. A review of risk factors for catheter-related bloodstream infection caused by percutaneously inserted, noncuffed central venous catheters: implications for preventive strategies. Medicine (Baltimore). Nov. 2002;81(6):466-479. Review. [pmid: 12441903].
2286 Saigal S, Stoskopf BL, Feeny D, Furlong W, Burrows E, Rosenbaum PL, Hoult L. Differences in preferences for neonatal outcomes among health care professionals, parents, and adolescents. Jama. Jun 2. 1999;281(21):1991-1997. Not eligible exposure. [pmid: 10359387].
2287 Salamon L, Lennon M. Decreasing companion usage without negatively affecting patient outcomes: a performance improvement project. MEDSURG Nursing. Aug. 2003;12(4):230-7. Not relevant. [pmid: 14515602].
2288 Sales A, Lurie N, Moscovice I, Goes J. Is quality in the eye of the beholder?. Jt Comm J Qual Improv. May. 1995;21(5):219-225. Not eligible exposure. [pmid: 7663627].
2289 Salluzzo RF, Bartfield JM, Freed H, Graber M, Peters T. Attitude of emergency department patients toward HIV-infected health care workers. Am J Emerg Med. Mar. 1997;15(2):141-144. Not eligible exposure. [pmid: 9115513].
2290 Salt P, Clancy M. Implementation of the Ottawa Ankle Rules by nurses working in an accident and emergency department. J Accid Emerg Med. Nov. 1997;14(6):363-365. Not eligible target population. [pmid: 9413774].
2291 Salvage D. Drug administration and professional accountability. Prof Nurse. Aug. 1997;12(11):827. Comment. [pmid: 9287868].
2292 Salyer J. Environmental turbulence. Impact on nurse performance. J Nurs Adm. Apr. 1995;25(4):12-20. Not eligible exposure. [pmid: 7714626].
2293 Sanchez-Sweatman L. The law, nurses and coffee breaks. Can Nurse. Dec. 1995;91(11):39-40. Legal cases. [pmid: 8713150].
2294 Sandall J. Choice, continuity and control: changing midwifery, towards a sociological perspective. Midwifery. Dec. 1995;11(4):201-209. Not eligible target population. [pmid: 8569521].
2295 Sanderson D. Research shows nursing agencies in a positive light. Br J Nurs. Jun 24–Jul 7. 2004;13(12):690. Not eligible target population. [pmid: 15284628].
2296 Sandford DA, Elzinga RH, Iversen R. A quantitative study of nursing staff interactions in psychiatric wards. Acta Psychiatr Scand. Jan. 1990;81(1):46-51. Not eligible target population. [pmid: 2330828].
2297 Sandiford R. ‘I call it the rock and roll of nursing’. Nurs Times. Aug 3–9. 2004;100(31):28-29. Comment. [pmid: 15360075].
2298 Sandlin D. Take a bite out of high employee turnover. J Perianesth Nurs. Apr. 2001;16(2):109-111. Comment. [pmid: 11290993].
2299 Sanford K. Nurses, let's support each other more. Nursing. Jan. 1990;20(1):109-118. Not eligible exposure. [pmid: 2300281].
2300 Santamaria N. The relationship between nurses' personality and stress levels reported when caring for interpersonally difficult patients. Aust J Adv Nurs. Dec–2001 Feb. 2000;18(2):20-26. Not eligible exposure. [pmid: 11878496].
2301 Santamaria N, O'Sullivan S. Stress in perioperative nursing: sources, frequency and correlations to personality factors. Collegian. Jul. 1998;5(3):10-15. Not eligible target population. [pmid: 9887709].
2302 Sanz C, Sunol R, Abello C, Blanc A. Design and results of the nursing quality assurance program in Hospital de la Santa Creu i Sant Pau: an integrated effort. Qual Assur Health Care. Sep. 1993;5(3):267-273. Not eligible target population. [pmid: 8260645].
2303 Sartain SA, Clarke CL, Heyman R. Hearing the voices of children with chronic illness. J Adv Nurs. Oct. 2000;32(4):913-921. Not eligible target population. [pmid: 11095230].
2304 Sasichay-Akkadechanunt T, Scalzi CC, Jawad AF. The relationship between nurse staffing and patient outcomes. J Nurs Adm. Sep. 2003;33(9):478-485. Not eligible target population. [pmid: 14501564].
2305 Saver C. Nursing gets an “A”. Nurs Spectr (Wash D C). Aug 11. 1997;7(16):3. Editorial.
2306 Sawaki Y, Parker RK, White PF. Patient and nurse evaluation of patient-controlled analgesia delivery systems for postoperative pain management. J Pain Symptom Manage. Nov. 1992;7(8):443-453. Not eligible exposure. [pmid: 1287106].
2307 Saxena AK, Panhotra BR. The impact of nurse understaffing on the transmission of hepatitis C virus in a hospital-based hemodialysis unit. Med Princ Pract. May–Jun. 2004;13(3):129-135. Not eligible target population. [pmid: 15073424].
2308 Saxena AK, Panhotra BR, Sundaram DS, Naguib M, Venkateshappa CK, Uzzaman W, Mulhim KA. Impact of dedicated space, dialysis equipment, and nursing staff on the transmission of hepatitis C virus in a hemodialysis unit of the middle east. Am J Infect Control. Feb. 2003;31(1):26-33. Not eligible target population. [pmid: 12548254].
2309 Sayers M, Marando R, Fisher S, Aquila A, Morrison B, Dailey T. No need for pain. J Healthc Qual. May–Jun. 2000;22(3):10-15. Not eligible exposure. [pmid: 11066912].
2310 Scarbrough ML, Landis SE. A pilot study for the development of a hospital-based immunization program. Clin Nurse Spec. Mar. 1997;11(2):70-75. Not eligible exposure. [pmid: 9233146].
2311 Schaffner A, Costa L, Propotnik T. Nurse sabbatical: reflections on professionalism. Nurs Manage. Sep. 1992;23(9):118. Comment. [pmid: 1518596].
2312 Schaffner JW, Alleman S, Ludwig-Beymer P, Muzynski J, King DJ, Pacura LJ. Developing a patient care model for an integrated delivery system. J Nurs Adm. Sep. 1999;29(9):43-50. Review. [pmid: 10491668].
2313 Schaffner M. Fighting fatigue. More than just a resident issue?. Gastroenterol Nurs. Mar–Apr. 2003;26(2):82-83. Comment. [pmid: 12682529].
2314 Scharer K. Nurse-parent relationship building in child psychiatric units. J Child Adolesc Psychiatr Nurs. Oct–Dec. 1999;12(4):153-167. Not eligible exposure. [pmid: 10876517].
2315 Scharer K. Admission: a crucial point in relationship building between parents and staff in child psychiatric units. Issues Ment Health Nurs. Dec. 2000;21(8):723-744. Not eligible exposure. [pmid: 11854979].
2316 Scharf L, Caley L. Patients', nurses', and physicians' perceptions of nurses' caring behaviors. Nursingconnections. Spring. 1993;6(1):3-12. Not eligible outcomes. [pmid: 8487873].
2317 Scheerle PK. P. K. Scheerle. Interview by Marietta Lee. Am J Nurs. Jul. 1994;94(7):38-40. Interview. [pmid: 8017495].
2318 Scherer YK, Haughey BP, Wu YW, Miller CM. A longitudinal study of nurses' attitudes toward caring for patients with AIDS in Erie County. J N Y State Nurses Assoc. Sep. 1992;23(3):10-15. Not eligible exposure. [pmid: 1432268].
2319 Schildmeier D. Brockton nurses end 103-day strike. Contract includes staffing/mandatory OT protections. Revolution. Sep–Oct. 2001;2(5):5. News. [pmid: 12018103].
2320 Schildmeier D. Massachusetts safe staffing: time runs out for bill this year but final hurdle on horizon. Revolution. Jul–Aug. 2004;5(4):9. News. [pmid: 15468587].
2321 Schildmeier D. MNA blows whistle on hospitals using paramedics in RN roles. Revolution. Jan–Feb. 2004;5(1):8-9. Review. [pmid: 15052952].
2322 Schmidt CE, Bottoni T. Improving medication safety and patient care in the emergency department. J Emerg Nurs. Feb. 2003;29(1):12-16. Comment. [pmid: 12556823].
2323 Schmidt LA. Patients' perceptions of nurse staffing, nursing care, adverse events, and overall satisfaction with the hospital experience. Nurs Econ. Nov–Dec 2004;22(6):295–306, 291. Not eligible exposure.
2324 Schmieder RA, Smith CS. Moderating effects of social support in shiftworking and non-shiftworking nurses. Work & Stress. Apr–Jun. 1996;10(2):128-40. Not relevant.
2325 Schneider MP, Cotting J, Pannatier A. Evaluation of nurses' errors associated in the preparation and administration of medication in a pediatric intensive care unit. Pharm World Sci. Aug. 1998;20(4):178-182. Not eligible target population. [pmid: 9762730].
2326 Schnelle JF, Simmons SF, Harrington C, et al. Relationship of nursing home staffing to quality of care. Health services research. Apr. 2004;39(2):225-50. Nursing home. [pmid: 15032952]. [pmcid: 1361005].
2327 Schoenfeld PS, Baker MD. Documentation in the pediatric emergency department: a review of resuscitation cases. Ann Emerg Med. Jun. 1991;20(6):641-643. Not eligible exposure. [pmid: 2039102].
2328 Scholz DA. Establishing and monitoring an endemic medication error rate. J Nurs Qual Assur. Feb. 1990;4(2):71-74. Not eligible outcomes. [pmid: 2312664].
2329 Scholz JA. Issue: how do you tell your patients that you are short-staffed?. Ohio Nurses Rev. Feb. 1997;72(2):16. Comment.
2330 Scholz JA. Issue: what guidelines does the Joint Commission on Accreditation of Healthcare Organizations use to determine if a hospital has adequate staffing for patient care?. Ohio Nurses Rev. May. 1998;73(5):16. Comment.
2331 Schraeder M, Friedman LH. Collective bargaining in the nursing profession: salient issues and recent developments in healthcare reform. Hosp Top. Summer. 2002;80(3):21-24. Review. [pmid: 12471881].
2332 Schroder PJ, Washington WP. Administrative decision making: staff-patient ratios (a patient classification system for a psychiatric setting). Perspect Psychiatr Care. Jul–Sep. 1982;20(3):111-123. Not eligible year. [pmid: 6923194].
2333 Schulmeister L. Chemotherapy medication errors: descriptions, severity, and contributing factors. Oncol Nurs Forum. Jul. 1999;26(6):1033-1042. Not eligible outcomes. [pmid: 10420421].
2334 Schumacher KL. Reconceptualizing family caregiving: family-based illness care during chemotherapy. Res Nurs Health. Aug. 1996;19(4):261-271. Not eligible exposure. [pmid: 8773550].
2335 Schwarz HO, Brodowy BA. Implementation and evaluation of an automated dispensing system. Am J Health Syst Pharm. Apr 15. 1995;52(8):823-828. Not eligible exposure. [pmid: 7634117].
2336 Sciabarra C, Kronawetter N, Jacob M, Ruelo V, Falero Y, Quigley PA. Implementing practice innovations to improve nurse-client relationships. Rehabil Nurs. Mar–Apr. 1999;24(2):51-54. Not eligible outcomes. [pmid: 10410055].
2337 Scott CA, Fish TR, Allen PJ. Design of an intensive epilepsy monitoring unit. Epilepsia. 2000;41(Suppl 5):S3-8. Not eligible target population.
2338 Scott LD, Hwang W, Rogers AE. The impact of multiple care giving roles on fatigue, stress, and work performance among hospital staff nurses. Journal of Nursing Administration. Feb. 2006;36(2):86-95. Not relevant. [pmid: 16528150].
2339 Scott H. Putting patient-centred care at the heart of nursing. Br J Nurs. Sep 9–22. 2004;13(16):937. Editorial. [pmid: 15389132].
2340 Scott J. The closing down of a hospital is deeply traumatic for patients and staff. Nurs Times. Dec 1–7. 1999;95(48):21. Not eligible target population. [pmid: 11096921].
2341 Scott RA. Multi-site coverage gives new meaning to “beyond the walls”. Clin Nurse Spec. Mar. 2000;14(2):51-53. News. [pmid: 11188446].
2342 Seaberg DC, MacLeod BA. Correlation between triage nurse and physician ordering of ED tests. Am J Emerg Med. Jan. 1998;16(1):8-11. Not eligible exposure. [pmid: 9451306].
2343 Seago JA. Registered nurses, unlicensed assistive personnel, and organizational culture in hospitals. J Nurs Adm. May. 2000;30(5):278-286. Not eligible outcomes. [pmid: 10823180].
2344 Seago JA. A comparison of two patient classification instruments in an acute care hospital. J Nurs Adm. May. 2002;32(5):243-249. Not eligible exposure. [pmid: 12021565].
2345 Seccombe I. Right to nurse. Pay special: a bit excessive. Nurs Stand. Mar 8–14. 1995;9(24):45. Not eligible target population. [pmid: 7727232].
2346 Sefton G, Farrell M, Noyes J. The perceived learning needs of paediatric intensive care nurses caring for children requiring haemofiltration. Intensive Crit Care Nurs. Feb. 2001;17(1):40-50. Not eligible target population. [pmid: 11176007].
2347 Segesten K, Lundgren S, Lindstrom I. Versatility—consequence of changing from mixed to all registered nurse staffing on a surgical ward. J Nurs Manag. Jul. 1998;6(4):223-230. Not eligible target population. [pmid: 9832727].
2348 Seigerst EG. East Liverpool City Hospital nurses make sweeping improvements. Ohio Nurses Rev. Aug. 2000;75(7):15. Not eligible target population. [pmid: 15706835].
2349 Seigerst EG. Geneva negotiations. Ohio Nurses Rev. Feb. 2000;75(2):12. News. [pmid: 12017590].
2350 Selbst SM, Fein JA, Osterhoudt K, Ho W. Medication errors in a pediatric emergency department. Pediatr Emerg Care. Feb. 1999;15(1):1-4. Not eligible exposure. [pmid: 10069301].
2351 Selekman J, Snyder B. Nursing perceptions of using physical restraints on hospitalized children. Pediatr Nurs. Sep–Oct. 1995;21(5):460-464. Not eligible exposure. [pmid: 8684849].
2352 Sella S, MacLeod JA. One year later: evaluating a changing delivery system. Nurs Forum. 1991;26(2):5-11. Not eligible outcomes. [pmid: 1876495].
2353 Sellick KJ, Russell S, Beckmann JL. Primary nursing: an evaluation of its effects on patient perception of care and staff satisfaction. International Journal of Nursing Studies (1983), 20, 265–273. Int J Nurs Stud. Jul. 2003;40(5):545-551. discussion 553–544. Not eligible target population. [pmid: 12828978].
2354 Selvam A. The state of the health care workforce. Hosp Health Netw. Aug 2001;75(8):41, 43–46, 48. Comment.
2355 Seo Y, Ko J, Price JL. The determinants of job satisfaction among hospital nurses: a model estimation in Korea. Int J Nurs Stud. May. 2004;41(4):437-446. Not eligible target population. [pmid: 15050854].
2356 Sermeus W, Hoy D, Jodrell N, Hyslop A, Gypen T, Kinnunen J, Mantas J, Delesie L, Tansley J, Hofdijk J. The WISECARE Project and the impact of information technology on nursing knowledge. Stud Health Technol Inform. 1997;46:176-181. Not eligible target population. [pmid: 10175393].
2357 Shader K, Broome ME, Broome CD, West ME, Nash M. Factors influencing satisfaction and anticipated turnover for nurses in an academic medical center. J Nurs Adm. Apr. 2001;31(4):210-216. Not eligible outcomes. [pmid: 11324334].
2358 Shah A, De T. The effect of an educational intervention package about aggressive behaviour directed at the nursing staff on a continuing care psychogeriatric ward. Int J Geriatr Psychiatry. Jan. 1998;13(1):35-40. Not eligible exposure. [pmid: 9489579].
2359 Shaha SH, Bush C. Fixing acuity: a professional approach to patient classification and staffing. Nurs Econ. Nov–Dec. 1996;14(6):346-356. No association tested. [pmid: 9087032].
2360 Shahinpour N, Hollinger-Smith L, Perlia MA. The medical-psychiatric consultation liaison nurse. Meeting psychosocial needs of medical patients in the acute care setting. Nurs Clin North Am. Mar. 1995;30(1):77-86. Not eligible exposure. [pmid: 7885926].
2361 Shamian J. Skill mix and clinical outcomes. Can Oper Room Nurs J. Jun. 1998;16(2):36-41. No association tested. [pmid: 9775780].
2362 Shang E, Suchner U, Dormann A, Senkal M. Structure and organisation of 47 nutrition support teams in Germany: a prospective investigation in 2000 German hospitals in 1999. Eur J Clin Nutr. Oct. 2003;57(10):1311-1316. Not eligible target population. [pmid: 14506494].
2363 Sharma T, Carson J, Berry C. Patient voices. Health Serv J. Jan 16. 1992;102(5285):20-21. Not eligible target population. [pmid: 10116992].
2364 Sharu D. Attribution of blame for a child's disability. Prof Nurse. Sep. 1996;11(12):790-792. Not eligible target population. [pmid: 9137048].
2365 Shattell M. Nurse bait: strategies hospitalized patients use to entice nurses within the context of the interpersonal relationship. Issues Ment Health Nurs. Feb–Mar. 2005;26(2):205-223. Not eligible exposure. [pmid: 15962923].
2366 Shen HC, Cheng Y, Tsai PJ, Lee SH, Guo YL. Occupational stress in nurses in psychiatric institutions in Taiwan. J Occup Health. May. 2005;47(3):218-225. Not eligible target population. [pmid: 15953843].
2367 Sherer JL. Next steps for nursing. Hosp Health Netw. Aug 20. 1993;67(16):26-28. Comment. [pmid: 8348173].
2368 Sheward L, Hunt J, Hagen S, Macleod M, Ball J. The relationship between UK hospital nurse staffing and emotional exhaustion and job dissatisfaction. J Nurs Manag. Jan. 2005;13(1):51-60. Not eligible target population. [pmid: 15613094].
2369 Shields L, Hunter J, Hall J. Parents' and staff's perceptions of parental needs during a child's admission to hospital: an English perspective. J Child Health Care. Mar. 2004;8(1):9-33. Not eligible target population. [pmid: 15090112].
2370 Shields L, King S. Qualitative analysis of the care of children in hospital in four countries-Part 2. J Pediatr Nurs. Jun. 2001;16(3):206-213. Not eligible target population. [pmid: 11398133].
2371 Shields L, Tanner A. Pilot study of a tool to investigate perceptions of family-centered care in different care settings. Pediatr Nurs. May–Jun. 2004;30(3):189-197. Not eligible target population. [pmid: 15311642].
2372 Shih FJ, Liao YC, Chan SM, Duh BR, Gau ML. The impact of the 9–21 earthquake experiences of Taiwanese nurses as rescuers. Soc Sci Med. Aug. 2002;55(4):659-672. Not eligible target population. [pmid: 12188470].
2373 Shindul-Rothschild J. Patient care. How good is it where you work?. Am J Nurs. Mar. 1996;96(3):22-24. Comment. [pmid: 8607541].
2374 Shindul-Rothschild J, Long-Middleton E, Berry D. 10 keys to quality care. Am J Nurs. Nov. 1997;97(11):35-43. No association tested. [pmid: 9372707].
2375 Shinkman R. Hasta la vista for Calif. nursing ratios? Healthc Leadersh Manag Rep. Nov 2003;11(11):1, 7–11, 13. Comment.
2376 Shinkman R. Calif. hospitals move to comply with nurse ratios despite litigation. Healthc Leadersh Rep. Jan. 2004;12(1):10-11. News. [pmid: 15060893].
2377 Shuldham CM. Commentary. Nursing skill mix and staffing. J Nurs Manag. Nov. 2004;12(6):385-387. Not eligible target population. [pmid: 15509265].
2378 Shullanberger G. Nurse staffing decisions: an integrative review of the literature. Nursing Economics May–Jun 2000;18(3):124–32, 46–8. Integrative review.
2379 Shusterman C. How immigration laws affect hospitals. Hosp Top. Summer. 1993;71(3):38-40. Comment. [pmid: 10129080].
2380 Sibbald B. Getting an early start on early discharge. Can Nurse. Mar. 1997;93(3):18. Comment. [pmid: 9110633].
2381 Siders AM, Peterson M. Increasing patient satisfaction and nursing productivity through implementation of an automated nursing discharge summary. Proc Annu Symp Comput Appl Med Care. 1991:136–140. Not eligible outcomes.
2382 Silber JH, Williams SV, Krakauer H, Schwartz JS. Hospital and patient characteristics associated with death after surgery. A study of adverse occurrence and failure to rescue. Med Care. Jul. 1992;30(7):615-629. Not eligible exposure. [pmid: 1614231].
2383 Silva N, Aderholdt B. Monitoring nursing productivity: a unique approach integrating an on-line kardex with workload measurement. Comput Nurs. Nov–Dec. 1992;10(6):232-234. Comment. [pmid: 1458361].
2384 Silverman HJ, Tuma P, Schaeffer MH, Singh B. Implementation of the patient self-determination act in a hospital setting. An initial evaluation. Arch Intern Med. Mar 13. 1995;155(5):502-510. Not eligible exposure. [pmid: 7864706].
2385 Silvestro R, Silvestro C. An evaluation of nurse rostering practices in the National Health Service. J Adv Nurs. Sep. 2000;32(3):525-535. Not eligible target population. [pmid: 11012793].
2386 Simmer TL, Nerenz DR, Rutt WM, Newcomb CS, Benfer DW. A randomized, controlled trial of an attending staff service in general internal medicine. Med Care. Jul. 1991;29(7 Suppl):JS31-40. Not eligible exposure. [pmid: 1906962].
2387 Simmons BL, Nelson DL. Eustress at work: the relationship between hope and health in hospital nurses. Health Care Manage Rev. Fall. 2001;26(4):7-18. Not eligible outcomes. [pmid: 11721311].
2388 Simmons M. Implementation of a patient falls risk-management strategy. Prof Nurse. Nov. 2001;17(3):168-171. Not eligible target population. [pmid: 12029892].
2389 Simon HK, McLario D, Daily R, Lanese C, Castillo J, Wright J. “Fast tracking” patients in an urban pediatric emergency department. Am J Emerg Med. May. 1996;14(3):242-244. Not eligible exposure. [pmid: 8639192].
2390 Simons J, Roberson E. Poor communication and knowledge deficits: obstacles to effective management of children's postoperative pain. J Adv Nurs. Oct. 2002;40(1):78-86. Not eligible target population. [pmid: 12230532].
2391 Simons JM, Macdonald LM. Pain assessment tools: children's nurses' views. J Child Health Care. Dec. 2004;8(4):264-278. Not eligible target population. [pmid: 15507464].
2392 Simpson RG, Scothern G, Vincent M. Survey of carer satisfaction with the quality of care delivered to in-patients suffering from dementia. J Adv Nurs. Sep. 1995;22(3):517-527. Not eligible target population. [pmid: 7499620].
2393 Simpson RL. IT takes a village. Improving health care in the 21st century. Nurs Adm Q. Apr–Jun. 2003;27(2):180-183. Review. [pmid: 12765110].
2394 Simpson RL. In direct proportion: ratios, IT, and trust. Nurs Manage. Feb. 2005;36(2):14-16. Comment. [pmid: 15701997].
2395 Sims CE. Increasing clinical, satisfaction, and financial performance through nurse-driven process improvement. J Nurs Adm. Feb. 2003;33(2):68-75. Not eligible exposure. [pmid: 12584458].
2396 Sims L, Kippenbrock TA. Psychiatric nurses' satisfaction with a patient classification system for staffing. Issues Ment Health Nurs. Jul–Aug. 1994;15(4):409-417. Not eligible exposure. [pmid: 8056570].
2397 Sinclair BP. Mandatory staffing ratios: a dilemma. AWHONN Lifelines. Apr–May. 2002;6(2):91-92. Editorial. [pmid: 11975133].
2398 Sinclair K, Collins D, Potokar J. Drug misuse by patients in an inner-city hospital. Nurs Stand. Jun 25–Jul 1. 2003;17(41):33-37. Not eligible target population. [pmid: 12861802].
2399 Sincox AK. Mandatory overtime can hurt a hospital's financial status. Mich Nurse. Nov. 2004;77(9):9. Comment.
2400 Sincox AK, Harris E, Bissonnette T, Stevenson T. Safe patient care: a crisis in nursing. Mich Nurse. Aug. 2004;4:16. Comment.
2401 Siviter B, Scullion J, Jebb P, Humm C. Safety in numbers?. Nurs Stand. Sep 25–Oct 1. 2002;17(2):22. Not eligible target population. [pmid: 12373981].
2402 Skeie B, Mishra V, Vaaler S, Amlie E. A comparison of actual cost, DRG-based cost, and hospital reimbursement for liver transplant patients. Transpl Int. Oct. 2002;15(910):439-445. Not eligible target population. [pmid: 12389074].
2403 Sklar J. Pain-less floating. Nurs Manage. Jul. 1992;23(7):104. Comment. [pmid: 1378954].
2404 Slaughter J. Up against a giant. Nurses quash Tenet's demand for 16-hour shifts, win ‘slam-dunk’. Revolution. May–Jun. 2000;1(3):5. News. [pmid: 12017721].
2405 Slaughter J. Beyond outrage. Revolution. Jan–Feb. 2000;1(1):28-35. Comment. [pmid: 11209342].
2406 Slomka J, Hoffman-Hogg L, Mion LC, Bair N, Bobek MB, Arroliga AC. Influence of clinicians' values and perceptions on use of clinical practice guidelines for sedation and neuromuscular blockade in patients receiving mechanical ventilation. Am J Crit Care. Nov. 2000;9(6):412-418. Not eligible exposure. [pmid: 11072557].
2407 Slota MC, Balas-Stevens S. Implementing and evaluating a change to 12-hour shifts. Neonatal Netw. Jun. 1990;8(6):51-56. Not eligible outcomes. [pmid: 2348815].
2408 Smedbold HT, Ahlen C, Unimed S, Nilsen AM, Norback D, Hilt B. Relationships between indoor environments and nasal inflammation in nursing personnel. Arch Environ Health. Mar–Apr. 2002;57(2):155-161. Not eligible target population. [pmid: 12194160].
2409 Smedley J, Egger P, Cooper C, Coggon D. Prospective cohort study of predictors of incident low back pain in nurses. Bmj. Apr 26. 1997;314(7089):1225-1228. Not eligible target population. [pmid: 9154024].
2410 Smedley J, Inskip H, Buckle P, Cooper C, Coggon D. Epidemiological differences between back pain of sudden and gradual onset. J Rheumatol. Mar. 2005;32(3):528-532. Not eligible target population. [pmid: 15742448].
2411 Smedley J, Inskip H, Cooper C, Coggon D. Natural history of low back pain. A longitudinal study in nurses. Spine. Nov 15. 1998;23(22):2422-2426. Not eligible target population. [pmid: 9836356].
2412 Smedley J, Inskip H, Trevelyan F, Buckle P, Cooper C, Coggon D. Risk factors for incident neck and shoulder pain in hospital nurses. Occup Environ Med. Nov. 2003;60(11):864-869. Not eligible target population. [pmid: 14573717].
2413 Smedley J, Trevelyan F, Inskip H, Buckle P, Cooper C, Coggon D. Impact of ergonomic intervention on back pain among nurses. Scand J Work Environ Health. Apr. 2003;29(2):117-123. Not eligible target population. [pmid: 12718497].
2414 Smeltzer CH. The Chicago plan: innovative strategies to change nurses' work patterns. J Nurs Adm. Sep. 1990;20(9):3-5. Editorial. [pmid: 2395033].
2415 Smetzer JL. Lesson from Colorado. Beyond blaming individuals. Nurs Manage. Jun. 1998;29(6):49-51. Legal Cases. [pmid: 9807432].
2416 Smith AM, Ortiguera SA, Laskowski ER, Hartman AD, Mullenbach DM, Gaines KA, Larson DR, Fisher W. A preliminary analysis of psychophysiological variables and nursing performance in situations of increasing criticality. Mayo Clin Proc. Mar. 2001;76(3):275-284. Not eligible exposure. [pmid: 11243274].
2417 Smith AP. Saving nurses, saving patients: responses to the labor crisis. J Med Pract Manage. Jan–Feb. 2004;19(4):193-197. Review. [pmid: 15018365].
2418 Smith DM, Gow P. Towards excellence in quality patient care: a clinical pathway for myocardial infarction. J Qual Clin Pract. Jun. 1999;19(2):103-105. Not eligible target population. [pmid: 10408751].
2419 Smith DR, Ohmura K, Yamagata Z. Prevalence and correlates of hand dermatitis among nurses in a Japanese teaching hospital. J Epidemiol. May. 2003;13(3):157-161. Not eligible target population. [pmid: 12749603].
2420 Smith F, Valentine F. Value added decisions. Paediatr Nurs. Sep. 1999;11(7):9-10. Not eligible target population. [pmid: 10723355].
2421 Smith GB. Shifts in attitudes about self-esteem in the recovering chemically dependent nurse. Addictions Nursing Network. Summer. 1993;5(2):60-3. Not peer reviewed.
2422 Smith J, Crawford L. Medication errors and difficulty in first patient assignments of newly licensed nurses. JONAS Healthc Law Ethics Regul. Sep. 2003;5(3):65-67. Not eligible outcomes. [pmid: 12972949].
2423 Smith J, Gamroth LM. The resident: the heart of it. Geriatr Nurs. May–Jun. 1995;16(3):113-116. Case Reports. [pmid: 7782002].
2424 Smith K, Uphoff ME. Uncharted terrain: dilemmas born in the NICU grow up in the PICU. J Clin Ethics. Fall. 2001;12(3):231-238. Case Reports. [pmid: 11789066].
2425 Smith LW, Mills JV. Psychometric evaluation of pharmacology calculation test for hospital staff nurses. J Healthc Educ Train. 1993;7(2):1-6. Not eligible exposure. [pmid: 10126596].
2426 Smith M, Doctor M, Boulter T. Unique considerations in caring for a pediatric burn patient: a developmental approach. Crit Care Nurs Clin North Am. Mar. 2004;16(1):99-108. Case reports. [pmid: 15062416].
2427 Smith M, Specht J, Buckwalter KC. Geropsychiatric inpatient care: what is state of the art?. Issues Ment Health Nurs. Jan. 2005;26(1):11-22. No association tested. [pmid: 15842103].
2428 Smith MK, Janzen SK, Schaefer S, Hixon AK. Administrative support for addressing staff nurses' ethical concerns regarding staffing. J Nurs Adm. Mar. 2001;31(3):103-104. Letter. [pmid: 11263055].
2429 Smith P. The effectiveness of a preceptorship model in postgraduate education for rural nurses. Aust J Rural Health. Aug. 1997;5(3):147-152. Not eligible target population. [pmid: 9437942].
2430 Smith P, Adams D, Bersante S, Kalma S. Planning for patient care redesign: success through continuous quality improvement. J Nurs Care Qual. Jan. 1994;8(2):73-80. Comment. [pmid: 8312596].
2431 Smith S. Understanding the experience of training for overseas nurses. Nurs Times. Oct 5–11. 2004;100(40):40-42. Not eligible target population.
2432 Smith SA. RNs and UAPs: not much difference?. Rn. Jul. 1998;61(7):37-38. Comment. [pmid: 9687815].
2433 Smith SP. Nurses on the move. Saudi Arabia: land of adventure & opportunity. Revolution. Spring. 1995;5(1):39-42. Not eligible target population. [pmid: 7613680].
2434 SmithBattle L, Diekemper M, Leander S. Getting your feet wet: becoming a public health nurse, part 1. Public Health Nursing. Jan–Feb. 2004;21(1):3-11. Not relevant. [pmid: 14692984].
2435 Sneed NV, Hollerbach AD. Accuracy of heart rate assessment in atrial fibrillation. Heart Lung. Sep–Oct. 1992;21(5):427-433. Case Reports. [pmid: 1399661].
2436 Snow T. Too few to care. Nurs Stand. Sep 8–14. 2004;18(52):12-13. Comment.
2437 Snowdon AW. Personal Construct Theory: a strategy for the study of multidimensional phenomena in nursing. Can J Nurs Res. Sep. 2004;36(3):131-145. Not eligible exposure. [pmid: 15551667].
2438 Soar J, McKay U. A revised role for the hospital cardiac arrest team?. Resuscitation. Sep. 1998;38(3):145-149. Not eligible target population. [pmid: 9872635].
2439 Sobo EJ. Pediatric nurses may misjudge parent communication preferences. J Nurs Care Qual. Jul–Sep. 2004;19(3):253-262. Not eligible exposure. [pmid: 15326995].
2440 Sochalski J, Estabrooks CA, Humphrey CK. Nurse staffing and patient outcomes: evolution of an international study. Can J Nurs Res. Dec. 1999;31(3):69-88. Review. [pmid: 10696170].
2441 Soderberg A, Gilje F, Norberg A. Dignity in situations of ethical difficulty in intensive care. Intensive Crit Care Nurs. Jun. 1997;13(3):135-144. Not eligible target population. [pmid: 9287575].
2442 Soliman F. Improving resource utilization through patient dependency systems. J Med Syst. Oct. 1997;21(5):291-302. Not eligible target population. [pmid: 9507405].
2443 Soliman F. Patient Dependency Knowledge-Based Systems. J Med Syst. Oct. 1998;22(5):357-370. Not eligible target population. [pmid: 9809275].
2444 Soliman F. Automation of patient dependency systems. J Med Syst. Aug. 1998;22(4):225-236. Not eligible target population. [pmid: 9690180].
2445 Soltani H, Dickinson F, Tanner J. Developing a maternity unit visiting policy. Pract Midwife. Oct. 2004;7(9):27-30. Not eligible exposure. [pmid: 15536819].
2446 Somers A, Petrovic M, Robays H, Bogaert M. Reporting adverse drug reactions on a geriatric ward: a pilot project. Eur J Clin Pharmacol. Feb. 2003;58(10):707-714. Not eligible target population. [pmid: 12610749].
2447 Sorrentino EA, Simunek LA. Nurses' perceptions of temporary nursing service agencies. Health Care Supervisor. Apr. 1991;9(3):55-62. Inadequate data presentation. [pmid: 10109458].
2448 Souder E, O'Sullivan P. Disruptive behaviors of older adults in an institutional setting. Staff time required to manage disruptions. J Gerontol Nurs. Aug. 2003;29(8):31-36. Not eligible target population. [pmid: 13677158].
2449 Souhrada L. Bumpy junction may lie between supplies and nursing models. Mater Manag Health Care. Jun 1995;4(6):34, 36, 38. Comment.
2450 Sourial R, McCusker J, Cole M, Abrahamowicz M. Agitation in demented patients in an acute care hospital: prevalence, disruptiveness, and staff burden. Int Psychogeriatr. Jun. 2001;13(2):183-197. Not eligible target population. [pmid: 11495393].
2451 Southard-Ritter M. Patient-focused care: what it is—what it is not. Pa Nurse. May. 1995;50(5):6-7. Comment. [pmid: 7651748].
2452 Spangler Z. Culture care of Philippine and Anglo-American nurses in a hospital context. Culture care diversity and universality: a theory of nursing National League for Nursing 1991(Leininger MM):119–46. (57 ref) (Pamhet #15–2402). Not relevant.
2453 Spangler Z. Transcultural care values and nursing practices of Philippine-American nurses. Journal of Transcultural Nursing. Winter. 1992;3(2):28-37. Not relevant. [pmid: 1596377].
2454 Speas J. A shift in staff relationships. Holist Nurs Pract. Sep–Oct. 2004;18(5):235-237. Review. [pmid: 15497602].
2455 Spetz J. Public policy and nurse staffing: what approach is best?. J Nurs Adm. Jan. 2005;35(1):14-16. Review. [pmid: 15647662].
2456 Spetz J, Adams S. How can employment-based benefits help the nurse shortage?. Health Aff (Millwood). Jan–Feb. 2006;25(1):212-218. No association tested. [pmid: 16403756].
2457 Spiegel R, Brunner C, Ermini-Funfschilling D, Monsch A, Notter M, Puxty J, Tremmel L. A new behavioral assessment scale for geriatric out- and in-patients: the NOSGER (Nurses' Observation Scale for Geriatric Patients). J Am Geriatr Soc. Apr. 1991;39(4):339-347. Not eligible target population. [pmid: 2010583].
2458 Spiegel T. Flexible sigmoidoscopy training for nurses. Gastroenterol Nurs. Nov–Dec. 1995;18(6):206-209. Not eligible exposure. [pmid: 8562583].
2459 Spilsbury K, Meyer J. Use, misuse and non-use of health care assistants: understanding the work of health care assistants in a hospital setting. J Nurs Manag. Nov. 2004;12(6):411-418. Not eligible target population. [pmid: 15509270].
2460 Sproat LJ, Inglis TJ. A multicentre survey of hand hygiene practice in intensive care units. J Hosp Infect. Feb. 1994;26(2):137-148. Not eligible target population. [pmid: 7911148].
2461 Squires A. New graduate orientation in the rural community hospital. Journal of continuing education in nursing. Sep–Oct. 2002;33(5):203-9. Not relevant. [pmid: 12269758].
2462 Stabenow D. A prescription for addressing Michigan's nursing shortage. Mich Nurse. Sep. 2005;78(7):11. Comment. [pmid: 16161490].
2463 Stacchini J. Does your staffing agency have JCAHO's stamp of approval?. Nurs Manage. Apr. 2005;36(4):65-67. Review. [pmid: 15812342].
2464 Stahl M. What makes the ideal dialysis setting?. Nephrol News Issues. Oct. 1998;12(10):39-40. Comment. [pmid: 10196954].
2465 Stamouli MA, Mantas J. Development and evaluation of a nursing service management and administration information system at district hospital. Medinfo. 2001;10(Pt 1):759-763. Not eligible target population. [pmid: 11604839].
2466 Standing T, Anthony MK, Hertz JE. Nurses' narratives of outcomes after delegation to unlicensed assistive personnel. Outcomes Manag Nurs Pract. Jan–Mar. 2001;5(1):18-23. Not eligible exposure. [pmid: 11898301].
2467 Stanford D. Who is accountable for inadequate staffing?. Nurs N Z. Sep. 2001;7(8):4. Letter. [pmid: 15462084].
2468 Stannard D. The Synergy Model in practice. Being a good dance partner. Crit Care Nurse. Dec. 1999;19(6):86-87. Case Reports. [pmid: 10889608].
2469 Staring SL. Addressing the educational needs of shiftworkers: should shift be a consideration?. J Contin Educ Nurs. Mar–Apr. 1995;26(2):79-83. Not eligible outcomes. [pmid: 7745144].
2470 Stead L. Practice makes perfect. Nurs Times. Jan 20–26. 2000;96(3):41. Comment. [pmid: 11961804].
2471 Stearley HE. Stat nursing—alive and well. Nurs Econ. Mar–Apr 1994;12(2):96–99, 105. Comment.
2472 Stechmiller JK, Yarandi HN. Job satisfaction among critical care nurses. Am J Crit Care. Nov. 1992;1(3):37-44. Not eligible outcomes. [pmid: 1307905].
2473 Stechmiller JK, Yarandi HN. Predictors of burnout in critical care nurses. Heart Lung. Nov–Dec. 1993;22(6):534-541. Not eligible outcomes. [pmid: 8288457].
2474 Steele D. Mother country. Nurs Stand. Jul 1–7. 1998;12(41):24-25. Comment. [pmid: 9776894].
2475 Steele L. Shifting patterns. Nurs Stand. Nov 20. 1996;11(9):14. Comment.
2476 Steenkamp WC, van der Merwe AE. The psychosocial functioning of nurses in a burn unit. Burns. May. 1998;24(3):253-258. Not eligible exposure. [pmid: 9677029].
2477 Steinbrook R. Nursing in the crossfire. N Engl J Med. May 30. 2002;346(22):1757-1766. Comment. [pmid: 12037165].
2478 Steinhauser KE, Maddox GL, Person JL, Tulsky JA. The evolution of volunteerism and professional staff within hospice care in North Carolina. Hosp J. 2000;15(1):35-51. Not eligible target population. [pmid: 11033658].
2479 Stelling J. But is it nursing? Nurs Que. Jul–Aug 1991;11(4):25–30, 64–29. No association tested.
2480 Stelling J, Milne-Smith J. Breakpoints and continuities: a case study of reactive change. Nurs Adm Q. Spring. 1994;18(3):43-50. No association tested. [pmid: 8196855].
2481 Stephen H. Yellow card for violent patients. Nurs Stand. Sep 16–22. 1998;12(52):14. News.
2482 Stewart M. New nursing shortage hits; causes complex. Am Nurse. Mar–Apr. 1998;30(2):32. Comment. [pmid: 10568364].
2483 Stimler C. A pressure ulcer toolbox for facilitating hospital-wide quality. Adv Wound Care. May–Jun. 1998;11(3 Suppl):13. Comment. [pmid: 9729954].
2484 Stodart K. Flash point in Nelson. N Z Nurs J. Jul. 1990;83(6):16-18. Not eligible target population. [pmid: 2371010].
2485 Stolman CJ, Gregory JJ, Dunn D, Levine JL. Evaluation of patient, physician, nurse, and family attitudes toward do not resuscitate orders. Arch Intern Med. Mar. 1990;150(3):653-658. Not eligible outcomes. [pmid: 2310285].
2486 Stopfkuchen H. Impact of national health system financing on quality of care in the intensive care unit: the German experience. Crit Care Med. Sep. 1993;21(9 Suppl):S406-407. Not eligible target population. [pmid: 8365261].
2487 Stotka JL, Wong ES, Williams DS, Stuart CG, Markowitz SM. An analysis of blood and body fluid exposures sustained by house officers, medical students, and nursing personnel on acute-care general medical wards: a prospective study. Infect Control Hosp Epidemiol. Oct. 1991;12(10):583-590. Not eligible exposure. [pmid: 1787308].
2488 Stratton KM, Blegen MA, Pepper G, Vaughn T. Reporting of medication errors by pediatric nurses. J Pediatr Nurs. Dec. 2004;19(6):385-392. Not eligible outcomes. [pmid: 15637579].
2489 Street A, Cuddihy L, Best D, Wilks D, Geladas D, Chew S. Rostering: placing the nurse in the picture. Contemp Nurse. Dec. 1997;6(34):145-151. Not eligible target population. [pmid: 9511656].
2490 Street K, Ashcroft R, Henderson J, Campbell AV. The decision making process regarding the withdrawal or withholding of potential life-saving treatments in a children's hospital. J Med Ethics. Oct. 2000;26(5):346-352. Not eligible target population. [pmid: 11055037].
2491 Strzalka A, Havens DS. Nursing care quality: comparison of unit-hired, hospital float pool, and agency nurses. J Nurs Care Qual. Jul. 1996;10(4):59-65. Not eligible exposure. [pmid: 8783546].
2492 Stumpf LR. A comparison of governance types and patient satisfaction outcomes. J Nurs Adm. Apr. 2001;31(4):196-202. Not eligible association presentation. [pmid: 11324332].
2493 Sugrue NM. Public policy initiatives and the nursing shortage: a disconnect. J Nurs Adm. Jan. 2005;35(1):19-22. Review. [pmid: 15647664].
2494 Suhonen R, Valimaki M, Leino-Kilpi H, Katajisto J. Testing the individualized care model. Scand J Caring Sci. Mar. 2004;18(1):27-36. Not eligible target population. [pmid: 15005661].
2495 Sujijantararat R, Booth RZ, Davis LL. Nosocomial urinary tract infection: nursing-sensitive quality indicator in a Thai hospital. J Nurs Care Qual. Apr–Jun. 2005;20(2):134-139. Not eligible target population. [pmid: 15839292].
2496 Sullivan J, Howland-Gradman J, Schell M, Goldsmith J. Reducing costs and improving processes for the interventional cardiology patient. J Cardiovasc Nurs. Jan. 1997;11(2):22-36. Not eligible exposure. [pmid: 8982879].
2497 Sullivan RJ, Menapace LW, White RM. Truth-telling and patient diagnoses. J Med Ethics. Jun. 2001;27(3):192-197. Not eligible outcomes. [pmid: 11417028].
2498 Suominen T, Leino-Kilpi H, Laippala P. Nurses' role in informing breast cancer patients: a comparison between patients' and nurses' opinions. J Adv Nurs. Jan. 1994;19(1):6-11. Not eligible target population. [pmid: 8138631].
2499 Suominen T, Leino-Kilpi H, Merja M, Doran DI, Puukka P. Staff empowerment in Finnish intensive care units. Intensive Crit Care Nurs. Dec. 2001;17(6):341-347. Not eligible target population. [pmid: 11853010].
2500 Sutherland K, Morgan J, Semple S. Self-administration. QMC study methodology. Nurs Times. Jun 7–13. 1995;91(23):30-31. Comment. [pmid: 7603871].
2501 Sutherland K, Morgan J, Semple S. Self-administration. Education and accountability. Nurs Times. Jun 7–13. 1995;91(23):32-33. Comment. [pmid: 7603872].
2502 Sutton J, Standen P, Wallace A. Incidence and documentation of patient accidents in hospital. Nurs Times. Aug 17–23. 1994;90(33):29-35. Not eligible target population. [pmid: 8084784].
2503 Svenson J, Besinger B, Stapczynski JS. Critical care of medical and surgical patients in the ED: length of stay and initiation of intensive care procedures. Am J Emerg Med. Nov. 1997;15(7):654-657. Not eligible exposure. [pmid: 9375548].
2504 Swain S. Serving suggestions. The ward sister's view. Nurs Times. Aug 12–18. 1998;94(32):27. Not eligible target population. [pmid: 9752171].
2505 Sweeney YT, Whitaker C. Successful change: renaissance without revolution. Semin Nurse Manag. Dec. 1994;2(4):196-202. Not eligible exposure. [pmid: 7704648].
2506 Sznajder M, Leleu G, Buonamico G, Auvert B, Aegerter P, Merliere Y, Dutheil M, Guidet B, Le Gall JR. Estimation of direct cost and resource allocation in intensive care: correlation with Omega system. Intensive Care Med. Jun. 1998;24(6):582-589. Not eligible target population. [pmid: 9681780].
2507 Tabet N, Hudson S, Sweeney V, Sauer J, Bryant C, Macdonald A, Howard R. An educational intervention can prevent delirium on acute medical wards. Age Ageing. Mar. 2005;34(2):152-156. Not eligible target population. [pmid: 15713859].
2508 Tabone S. Unsung nursing heroes. Tex Nurs. Jun–Jul. 1997;71(6):7. Comment. [pmid: 9355633].
2509 Tabone S. Don't get mad—get help. Tex Nurs. Feb. 1997;71(2):11. Comment. [pmid: 9305176].
2510 Tabone S. Staff models for the next millennium. Tex Nurs. May 1999;73(5):6–7, 10. Comment.
2511 Tabone S. Staff nurse participation is key. Tex Nurs. Mar. 2001;75(3):7-10. Comment. [pmid: 15341113].
2512 Tabone S. Nurse fatigue: the human factor. Tex Nurs. Jun–Jul. 2004;78(5):8-10. Review. [pmid: 15470943].
2513 Tahan HA. Essentials of advocacy in case management. Lippincotts Case Manag. May–Jun. 2005;10(3):136-145. quiz 146–137. Review. [pmid: 15931045].
2514 Takenouchi J. When no news isn't good news. How hospital ties with a newspaper put a story on the spike. Revolution. Sep–Oct. 2001;2(5):18-19. Comment. [pmid: 12018098].
2515 Tamblyn S. High risk nursing in Los Angeles. Aust Nurses J. Feb. 1990;19(7):18-20. Comment. [pmid: 2357169].
2516 Tamburri LM, DiBrienza R, Zozula R, Redeker NS. Nocturnal care interactions with patients in critical care units. Am J Crit Care. Mar. 2004;13(2):102-112. quiz 114–105. Not eligible exposure. [pmid: 15043238].
2517 Tammelleo AD. Legal case briefs for nurses. IL: failure to diagnose pt.'s TB: attending nurse sues: N.H.: the school nurse: a professional engaged in teaching?. Regan Rep Nurs Law. Mar. 1991;31(10):3. Case Reports.
2518 Tammelleo AD. Mystery nurse reports child's sexually transmitted disease in error. Case in point: Perez v. Bay Area Hospital (829 P. Rptr. 2d 700—OR [1992]). Regan Rep Nurs Law. Jul. 1992;33(2):4. Case Reports.
2519 Tammelleo AD. Legal case briefs for nurses. IL.: “medication dosage misadventure” triggers libel suit: privileged communication; IL.: spinal meningitis misdiagnosed: “patient dumping” charged. Regan Rep Nurs Law. Feb. 1992;32(9):3. Case Reports.
2520 Tammelleo AD. Court upholds nurse's refusal to float. Case in point: Winkleman v. Beloit Memorial Hosp. (483 N.W. 2d 211—WI [1992]). Regan Rep Nurs Law. Jul. 1992;33(2):2. Legal Cases.
2521 Tammelleo AD. Nurse denied pay differential for unscheduled work. Regan Rep Nurs Law. Jun. 1992;33(1):1. Legal Cases.
2522 Tammelleo AD. Care allegedly provided without proper supervision. Case in point: Raicevich v. Plum Creek Medical P.C. 918 F. Supp. 2d 929—CO (1993). Regan Rep Nurs Law. Nov. 1993;34(6):4. Case Reports.
2523 Tammelleo AD. Failure to follow orders: patient arrests—coma results. Case in point: Sullivan v. Sumrall By Ritchley 618 So. 2d 1274—MS (1993). Regan Rep Nurs Law. Aug. 1993;34(3):4. Case Reports.
2524 Tammelleo AD. Legal case briefs for nurses. OK: Slip and fall of “medicated” patient: nurse abandons patient in shower. NY: Failure to diagnose fetal distress: suit for prolongation of distress. Regan Rep Nurs Law. May. 1993;33(12):3. Case Reports.
2525 Tammelleo AD. Death after E.R. treatment: proximate cause issue. Case in point: Godeaux v. Rayne Branch Hosp. (606 So. 2d 948—LA [1992]). Regan Rep Nurs Law. Feb. 1993;33(9):4. Case Reports.
2526 Tammelleo AD. Legal case briefs for nurses. IA: unattended pt. falls in bathroom: “routine nonmedicale care” standard applied; OR: nurses state “all sponges ... removed”: court rejects “captain of ship” doctrine. Regan Rep Nurs Law. Nov. 1993;34(6):3. Case Reports.
2527 Tammelleo AD. Legal case briefs for nurses. NY: refusal to stay for additional shift: “abandonment” charged—suspension results. AL: substance abuse—licence revocation: highly qualified and talented nurse. Regan Rep Nurs Law. Mar. 1993;33(10):3. Case Reports.
2528 Tammelleo AD. Legal case briefs for nurses. GA: “non-life-threatening” assessment: four hour delay—patient leaves E.R. and dies; LA: nurse gives I.M. instead of I.V.: pharmacy failure to give directions. Regan Rep Nurs Law. May. 1994;34(12):3. Case Reports.
2529 Tammelleo AD. Legal case briefs for nurses. NY: overworked nurse falls asleep at wheel: auto accident—workers' comp. issue; NY: working outside of job description: union contract and civil service violations. Regan Rep Nurs Law. Jul. 1994;35(2):3. Legal Cases.
2530 Tammelleo AD. Failure to follow protocols: hospital vulnerability. Case in point: Romo v. Union Memorial Hospital, Inc. 878 F. Supp. 837—NC (1995). Regan Rep Nurs Law. May. 1995;35(12):2. Case Reports.
2531 Tammelleo AD. OH: “LifeFlight” nurse & pilot to marry: hospital's nepotism policy mandates transfer. Regan Rep Nurs Law. Sep. 1995;36(4):3. Legal Cases.
2532 Tammelleo AD. Arbitrator's award of E.R. job to existing employee upheld. Regan Rep Nurs Law. Sep. 1995;36(4):2. Legal Cases.
2533 Tammelleo AD. Nurse risk manager alleges “retaliatory transfer”. Regan Rep Nurs Law. Sep. 1995;36(4):1. Legal Cases.
2534 Tammelleo AD. FL: did physician prescribe excess dosage?: did nurse err in administering meds.?. Regan Rep Nurs Law. Dec. 1997;38(7):3. Legal Cases.
2535 Tammelleo AD. Refusal to be party to ‘trumped-up’ charges—retaliatory termination. Case on point: Gerard v. Camden Cnty. Health Srvcs. Ctr., N.J. Supr.App.Div. 3/6/2002-NJ. Nurs Law Regan Rep. Mar. 2002;42(10):4. Legal Cases. [pmid: 11980420].
2536 Tan SG, Lim SH, Malathi I. Does routine gowning reduce nosocomial infection and mortality rates in a neonatal nursery? A Singapore experience. Int J Nurs Pract. Nov. 1995;1(1):52-58. Not eligible target population. [pmid: 9264888].
2537 Tanabe P, Gimbel R, Yarnold PR, Kyriacou DN, Adams JG. Reliability and validity of scores on The Emergency Severity Index version 3. Acad Emerg Med. Jan. 2004;11(1):59-65. Not eligible exposure. [pmid: 14709429].
2538 Tanner CA. Living in the midst of a paradigm shift. J Nurs Educ. Feb. 1995;34(2):51-52. Editorial. [pmid: 7707136].
2539 Tarnow-Mordi WO, Hau C, Warden A, Shearer AJ. Hospital mortality in relation to staff workload: a 4-year study in an adult intensive-care unit. Lancet. Jul 15. 2000;356(9225):185-189. Not eligible target population. [pmid: 10963195].
2540 Tate ET, Lund CH, Smart R. A Flex-Ability Nurse (FAN) program. Nurs Manage. May. 1998;29(5):46. Comment. [pmid: 9807415].
2541 Tattam A. The sun the moon & the stars. Aust Nurs J. Mar. 1995;2(8):21-22. Comment. [pmid: 7773372].
2542 Taunton RL, Kleinbeck SVM, Stafford R, et al. Patient outcomes: are they linked to registered nurse absenteeism, separation, or work load? Journal of Nursing Administration Apr 1994;24(4S): Suppl):48–55. Not relevant; patient outcomes.
2543 Taxis K, Barber N. Ethnographic study of incidence and severity of intravenous drug errors. Bmj. Mar 29. 2003;326(7391):684. Not eligible target population. [pmid: 12663404]. [pmcid: 152365].
2544 Taxis K, Barber N. Incidence and severity of intravenous drug errors in a German hospital. Eur J Clin Pharmacol. Jan. 2004;59(11):815-817. Not eligible target population. [pmid: 14586530].
2545 Taylor C, Gardner B, Heslop L, Lowe E, Habner M, Athan D. Identification of factors contributing to increased length of stay in two diagnosis related groups. Aust Health Rev. 2001;24(4):81-90. Not eligible target population. [pmid: 11842719].
2546 Taylor C, Ogle KR, Olivieri D, English R, Dennis M. Taking on the student role: how can we improve the experience of registered nurses returning to study?. Aust Crit Care. Sep. 1999;12(3):98-102. Not eligible target population. [pmid: 10795181].
2547 Taylor CB, Houston-Miller N, Killen JD, DeBusk RF. Smoking cessation after acute myocardial infarction: effects of a nurse-managed intervention. Ann Intern Med. Jul 15. 1990;113(2):118-123. Not eligible exposure. [pmid: 2360750].
2548 Taylor JA, Brownstein D, Christakis DA, Blackburn S, Strandjord TP, Klein EJ, Shafii J. Use of incident reports by physicians and nurses to document medical errors in pediatric patients. Pediatrics. Sep. 2004;114(3):729-735. Not eligible exposure. [pmid: 15342846].
2549 Taylor M, Keighron K. Healing is who we are ... and who are we?. Nurs Adm Q. Oct–Dec. 2004;28(4):241-248. Comment. [pmid: 15612397].
2550 Taylor ME. SWAT team: aggressive approach to the '90s. Nurs Econ. Nov–Dec. 1991;9(6):431-433. Not eligible outcomes. [pmid: 1956431].
2551 Taylor NT. The Magnetic pull. Nurs Manage. Jan. 2004;35(1):38-44. Review. [pmid: 14718766].
2552 Teahan B. Implementation of a self-scheduling system: a solution to more than just schedules!. J Nurs Manag. Nov. 1998;6(6):361-368. Not eligible target population. [pmid: 10076269].
2553 Ter Maat M. An appropriate nursing skill mix: survey of acuity systems in rehabilitation hospitals. Rehabil Nurs. Jul–Aug. 1993;18(4):244-248. No association tested. [pmid: 7938886].
2554 Teresi JA, Grant LA, Holmes D, Ory MG. Staffing in traditional and special dementia care units. Preliminary findings from the National Institute on Aging Collaborative Studies. J Gerontol Nurs. Jan. 1998;24(1):49-53. Review. [pmid: 9510721].
2555 Terris J, Leman P, O'Connor N, Wood R. Making an IMPACT on emergency department flow: improving patient processing assisted by consultant at triage. Emerg Med J. Sep. 2004;21(5):537-541. Not eligible target population. [pmid: 15333523].
2556 Thanasa G, Afthentopoulos IE. The patient with diabetic nephropathy in the hospital. Edtna Erca J. Oct–Dec. 1999;25(4):28-31. Not eligible target population. [pmid: 10827596].
2557 Theelen B, Rorive G, Krzesinski JM, Collart F. Belgian peer review experience on the Achille's Heel in haemodialysis care: vascular access. Edtna Erca J. Oct–Dec. 2002;28(4):164-166. Not eligible target population. [pmid: 12638928].
2558 Thomas EJ, Sexton JB, Helmreich RL. Discrepant attitudes about teamwork among critical care nurses and physicians. Crit Care Med. Mar. 2003;31(3):956-959. Not eligible exposure. [pmid: 12627011].
2559 Thomas L. Attractive force of nursing. Nurs Stand. Mar 8–14. 2000;14(25):3. Editorial.
2560 Thomas LH. A comparison of the verbal interactions of qualified nurses and nursing auxiliaries in primary, team and functional nursing wards. Int J Nurs Stud. Jun. 1994;31(3):231-244. Not eligible exposure. [pmid: 8088935].
2561 Thomas MB. Study examines working hours and feelings of fatigue by reported nurses. Texas Board of Nursing Bulletin. Oct. 2005;36(4):2-3. Not peer reviewed.
2562 Thomas N. Pain control: patient and staff perceptions of PCA. Nurs Stand. Mar 31–Apr 6. 1993;7(28):37-39. Not eligible target population. [pmid: 8499258].
2563 Thompson CR. When your patient doesn't want to leave. Am J Nurs. Mar. 1998;98(3):40-41. Comment. [pmid: 9536177].
2564 Thompson DG. Critical pathways in the intensive care & intermediate care nurseries. MCN Am J Matern Child Nurs. Jan–Feb. 1994;19(1):29-32. Not eligible exposure. [pmid: 8201859].
2565 Thompson DM, Kozak SE, Sheps S. Insulin adjustment by a diabetes nurse educator improves glucose control in insulin-requiring diabetic patients: a randomized trial. Cmaj. Oct 19. 1999;161(8):959-962. Not eligible exposure. [pmid: 10551191]. [pmcid: 1230704].
2566 Thompson DN, Wolf GA, Spear SJ. Driving improvement in patient care: lessons from Toyota. J Nurs Adm. Nov. 2003;33(11):585-595. Not eligible target population. [pmid: 14608217].
2567 Thompson J, Irvine T, Grathwohl K, Roth B. Misuse of metered-dose inhalers in hospitalized patients. Chest. Mar. 1994;105(3):715-717. Not eligible exposure. [pmid: 8131531].
2568 Thompson K, Melby V, Parahoo K, Ridley T, Humphreys WG. Information provided to patients undergoing gastroscopy procedures. J Clin Nurs. Nov. 2003;12(6):899-911. Not eligible target population. [pmid: 14632983].
2569 Thompson S. After the volcano. Interview by Lynne Wallis. Nurs Stand. Sep 8–14. 2004;18(52):20-21. Interview. [pmid: 15473203].
2570 Thompson TM. Can medical error self-reporting be easily implemented? Counterpoint. Nurs Leadersh Forum. Fall. 2001;6(1):5-8. Not eligible outcomes. [pmid: 12152460].
2571 Thompson W. Don't scapegoat temporary nurses. Nurs Stand. Jan 15. 1997;11(17):16. News. [pmid: 9016096].
2572 Thomson D. Outcomes of hospital staffing research project: a preliminary report. Concern. Feb. 1999;28(1):9. Comment. [pmid: 10595019].
2573 Thomson PJ. Cancelled operations. A current problem in oral and maxillofacial surgery. Br Dent J. Oct 19. 1991;171(8):244-245. Not eligible exposure. [pmid: 1804271].
2574 Thornton L. The Model of Whole-Person Caring: creating and sustaining a healing environment. Holist Nurs Pract. May–Jun. 2005;19(3):106-115. Not eligible exposure. [pmid: 15923936].
2575 Thrall TH. Workforce. Tightening ratios. Hosp Health Netw. Jan. 2004;78(1):24-26. News. [pmid: 14768445].
2576 Thrall TH. Workforce. Creative recruiting in southern Ohio. Cincinnati-area hospitals get serious—and a little silly—to cut nurse vacancy rate. Hosp Health Netw. Apr. 2005;79(4):20-22. News.
2577 Thurston J, Field S. Should accident and emergency nurses request radiographs? Results of a multicentre evaluation. J Accid Emerg Med. Mar. 1996;13(2):86-89. Not eligible exposure. [pmid: 8653256].
2578 Thurtle V. Why do nurses enter community and public health practice?. Community Pract. Apr. 2005;78(4):140-145. Not eligible target population. [pmid: 15875602].
2579 Thyer GL. Dare to be different: transformational leadership may hold the key to reducing the nursing shortage. J Nurs Manag. Mar. 2003;11(2):73-79. Not eligible target population. [pmid: 12581394].
2580 Tibby SM, Correa-West J, Durward A, Ferguson L, Murdoch IA. Adverse events in a paediatric intensive care unit: relationship to workload, skill mix and staff supervision. Intensive Care Med. Jun. 2004;30(6):1160-1166. Not eligible target population. [pmid: 15067503].
2581 Tieman J. Registered nurses key to good patient outcomes, study finds. But national nursing groups disagree over ratio laws and how best to recruit and retain quality nurses. Mod Healthc. Jun 3. 2002;32(22):10-11. News.
2582 Tieman J. Nursing the nurse shortage. As feds collaborate, states and localities act on own. Mod Healthc. May 20. 2002;32(20):20-21. News.
2583 Tieman J. Double standards. Amid push for nurse ratio laws, the nation's hospitals also face new JCAHO requirements for measuring staffing effectiveness. Mod Healthc. Apr 8. 2002;32(14):30-32. Review.
2584 Tien SF. Nurses' knowledge of traditional Chinese postpartum customs. West J Nurs Res. Nov. 2004;26(7):722-732. Not eligible target population. [pmid: 15466610].
2585 Tierney AJ, Taylor J. Research in practice: an ‘experiment’ in researcher-practitioner collaboration. J Adv Nurs. May. 1991;16(5):506-510. Not eligible target population. [pmid: 1856368].
2586 Tierney MJ, Lavelle M. An investigation into modification of personality hardiness in staff nurses. J Nurs Staff Dev. Jul–Aug. 1997;13(4):212-217. Not eligible exposure. [pmid: 9287629].
2587 Tigert JA, Laschinger HK. Critical care nurses' perceptions of workplace empowerment, magnet hospital traits and mental health. Dynamics. Winter. 2004;15(4):19-23. Not eligible exposure. [pmid: 15638354].
2588 Tillman HJ, Salyer J, Corley MC, Mark BA. Environmental turbulence: staff nurse perspectives. J Nurs Adm. Nov. 1997;27(11):15-22. No association tested. [pmid: 9372803].
2589 Timmins F, Kaliszer M. Information needs of myocardial infarction patients. Eur J Cardiovasc Nurs. Apr. 2003;2(1):57-65. Not eligible target population. [pmid: 14622649].
2590 Timmons S, Tanner J. Operating theatre nurses: emotional labour and the hostess role. Int J Nurs Pract. Apr. 2005;11(2):85-91. Not eligible target population. [pmid: 15752323].
2591 Tippett J. Nurses' acquisition and retention of knowledge after trauma training. Accid Emerg Nurs. Jan. 2004;12(1):39-46. Not eligible target population. [pmid: 14700571].
2592 Titone NJ, Cross R, Sileo M, Martin G. Taking family-centered care to a higher level on the heart and kidney unit. Pediatr Nurs. Nov–Dec. 2004;30(6):495-497. Not eligible exposure. [pmid: 15704601].
2593 Todd C, Robinson G, Reid N. 12-hour shifts: job satisfaction of nurses. J Nurs Manag. Sep. 1993;1(5):215-220. Not eligible target population. [pmid: 8313062].
2594 Todd V, Van Rosendaal G, Duregon K, Verhoef M. Percutaneous endoscopic gastrostomy (PEG): the role and perspective of nurses. J Clin Nurs. Feb. 2005;14(2):187-194. Not eligible exposure. [pmid: 15669927].
2595 Tokarski C. Government eases up on foreign nurses. Mod Healthc. Dec 10. 1990;20(49):2. News.
2596 Tomlinson PS, Kirschbaum M, Tomczyk B, Peterson J. The relationship of child acuity, maternal responses, nurse attitudes and contextual factors in the bone marrow transplant unit. Am J Crit Care. May. 1993;2(3):246-252. Not eligible outcomes. [pmid: 8364676].
2597 Tomlinson PS, Swiggum P, Harbaugh BL. Identification of nurse-family intervention sites to decrease health-related family boundary ambiguity in PICU. Issues Compr Pediatr Nurs. Jan–Mar. 1999;22(1):27-47. Not eligible exposure. [pmid: 10640064].
2598 Tonges MC. Job design for nurse case managers. Intended and unintended effects on satisfaction and well-being. Nurs Case Manag. Jan–Feb. 1998;3(1):11-23. quiz 24–15. Not eligible exposure. [pmid: 9526392].
2599 Tonges MC, Baloga-Altieri B, Atzori M. Amplifying nursing's voice through a staff-management partnership. J Nurs Adm. Mar. 2004;34(3):134-139. Review. [pmid: 15024240].
2600 Tonuma M, Winbolt M. From rituals to reason: creating an environment that allows nurses to nurse. Int J Nurs Pract. Aug. 2000;6(4):214-218. Not eligible target population. [pmid: 11261051].
2601 Torkelson DJ, Dobal MT. Constant observation in medical-surgical settings: a multihospital study. Nurs Econ. May–Jun. 1999;17(3):149-155. Not eligible exposure. [pmid: 10711154].
2602 Tornabeni J. Care 2000—a patient-focused care model. Calif Hosp. Jul–Aug. 1994;8(4):12-13. Comment. [pmid: 10136643].
2603 Tourangeau AE, White P, Scott J, McAllister M, Giles L. Evaluation of a partnership model of care delivery involving registered nurses and unlicensed assistive personnel. Can J Nurs Leadersh. May–Jun. 1999;12(2):4-20. Not eligible exposure. [pmid: 11094929].
2604 Toyry E, Herve R, Mutka R, Savolainen P, Seppanen M. Ethics in health care management: developing an instrument to assess humane caring. Nurs Ethics. May. 1998;5(3):228-235. Not eligible target population. [pmid: 9653220].
2605 Trafford A. The nursing shortage—a Washington Post columnist's perspective. Interview by Iris C. Frank. J Emerg Nurs. Aug. 2001;27(4):391-393. Interview. [pmid: 11468635].
2606 Trammell TR, Fisher D, Brueckmann FR, Haines N. Closed-wound drainage systems. The Solcotrans Plus versus the Stryker-CBC ConstaVAC. Orthop Rev. Jun. 1991;20(6):536-542. Not eligible exposure. [pmid: 1908569].
2607 Tranmer JE, Lochhaus-Gerlach J, Lam M. The effect of staff nurse participation in a clinical nursing research project on attitude towards, access to, support of and use of research in the acute care setting. Can J Nurs Leadersh. Jan–Feb. 2002;15(1):18-26. Not eligible exposure. [pmid: 11908539].
2608 Travers D. Triage: how long does it take? how long should it take?. J Emerg Nurs. Jun. 1999;25(3):238-240. Not eligible exposure. [pmid: 10346850].
2609 Travis M. Cash in the bank. Nurs Times. Feb 12–18. 1997;93(7):27. Not eligible target population. [pmid: 9095945].
2610 Treloar AJ, Macdonald AJ. Recognition of cognitive impairment by day and night nursing staff among acute geriatric patients. J R Soc Med. Apr. 1995;88(4):196-198. Not eligible target population. [pmid: 7745564]. [pmcid: 1295162].
2611 Trossman S. Fighting the clock: nurses take on mandatory overtime. Am Nurse. May–Jun. 1998;30(3):1-12. Comment.
2612 Trossman S. ANA, MNA support Dana-Farber nurses facing disciplinary action. Am Nurse. Mar–Apr. 1999;31(2):1-10. Comment.
2613 Trossman S. Working 'round the clock. Am Nurse. Sep–Oct. 1999;31(5):1-2. Comment.
2614 Trossman S. Staffing smart: a difficult proposition. Am Nurse. Jan–Feb. 1999;31(1):1-2. News.
2615 Trossman S. The global reach of the nursing shortage. Am J Nurs. Mar 2002;102(3):85, 87, 89. Comment.
2616 Trossman S. Nurses' Rx for medication errors. Am Nurse. May–Jun 2003;35(3):1–2, 12. Comment.
2617 Trossman S. Have RN, will travel?. Nurs Manage. Jul. 2003;34(Suppl 4):15-16. Comment. [pmid: 12845324].
2618 Trossman S. Increased hours, more errors. Am Nurse. Jul–Aug 2004;36(4):1, 3–4. Comment.
2619 Trossman S. Move over eBay? A potential trend involving bidding for shifts online. Am Nurse. May–Jun 2004;36(3):1, 8, 12. Comment.
2620 Trundle CM, Farrington M, Anderson L, Redpath CK. GRASPing infection: a workload measurement tool for infection control nurses. J Hosp Infect. Nov. 2001;49(3):215-221. Not eligible target population. [pmid: 11716640].
2621 Tsai SL, Tsai WW, Chai SK, Sung WH, Doong JL, Fung CP. Evaluation of computer-assisted multimedia instruction in intravenous injection. Int J Nurs Stud. Feb. 2004;41(2):191-198. Not eligible target population. [pmid: 14725783].
2622 Tschannen D. The effect of individual characteristics on perceptions of collaboration in the work environment. Medsurg Nurs. Oct. 2004;13(5):312-318. Not eligible exposure. [pmid: 15587130].
2623 Tselebis A, Moulou A, Ilias I. Burnout versus depression and sense of coherence: study of Greek nursing staff. Nurs Health Sci. Jun. 2001;3(2):69-71. Not eligible target population. [pmid: 11882180].
2624 Tselikis P. It's a hard knocks life for providers ... and getting harder! State Health Care Am. 2001:40–43. Review.
2625 Tsuru S, Shindob S, Takatanic Y, Seod A. A conception of a support system for optimising the organisation of nursing staff from the viewpoint of the nursing care needs structure. Stud Health Technol Inform. 1997;46:275-278. Not eligible target population. [pmid: 10175409].
2626 Tucker D, Dirico L. Managing costly Medicare patients in the hospital. Geriatr Nurs. Sep–Oct. 2003;24(5):294-297. No association tested. [pmid: 14571245].
2627 Tucker J. Patient volume, staffing, and workload in relation to risk-adjusted outcomes in a random stratified sample of UK neonatal intensive care units: a prospective evaluation. Lancet. Jan 12. 2002;359(9301):99-107. Not eligible target population. [pmid: 11809250].
2628 Turk M, Davas A, Ciceklioglu M, Sacaklioglu F, Mercan T. Knowledge, attitude and safe behaviour of nurses handling cytotoxic anticancer drugs in Ege University Hospital. Asian Pac J Cancer Prev. Apr–Jun. 2004;5(2):164-168. Not eligible target population. [pmid: 15244519].
2629 Turley S. Development of the ‘Euro Rota’ in A & E. Accid Emerg Nurs. Oct. 1997;5(4):178-180. Not eligible target population. [pmid: 9407771].
2630 Turnbull GB. Office of Inspector General (OIG) issues draft compliance program for pharmaceutical manufacturers. Ostomy Wound Manage. Dec. 2002;48(12):12-13. Comment.
2631 Turner G. Parents' experiences of ambulatory care. Paediatr Nurs. Oct 1998;10(8):12–13, 16. Not eligible target population.
2632 Turner JT, Lee V, Fletcher K, Hudson K, Barton D. Measuring quality of care with an inpatient elderly population. The geriatric resource nurse model. J Gerontol Nurs. Mar. 2001;27(3):8-18. Not eligible exposure. [pmid: 11915260].
2633 Turner M. Shiftwork strategies. Can Nurse. Dec. 1995;91(11):41-42. Not eligible exposure. [pmid: 8713151].
2634 Turnock C, Gibson V. Validity in action research: a discussion on theoretical and practice issues encountered whilst using observation to collect data. J Adv Nurs. Nov. 2001;36(3):471-477. Not eligible target population. [pmid: 11686762].
2635 Turrill S. Interpreting family-centred care within neonatal nursing. Paediatr Nurs. May. 1999;11(4):22-24. Not eligible target population. [pmid: 10542603].
2636 Turrittin J, Hagey R, Guruge S, et al. The experiences of professional nurses who have migrated to Canada: cosmopolitan citizenship or democratic racism?. International journal of nursing studies. Aug. 2002;39(6):655-67. Not relevant. [pmid: 12100877].
2637 Tuttas CA. Decreasing nurse staffing costs in a hospital setting: development and support of core staff stability. J Nurs Care Qual. Jul–Sep. 2003;18(3):226-240. Review. [pmid: 12856907].
2638 Tuttle DM. A “transfer fair” approach to staffing. Nurs Manage. Dec. 1992;23(12):72-74. Comment. [pmid: 1465265].
2639 Tutuarima JA, de Haan RJ, Limburg M. Number of nursing staff and falls: a case-control study on falls by stroke patients in acute-care settings. J Adv Nurs. Jul. 1993;18(7):1101-1105. Not eligible target population. [pmid: 8370900].
2640 Tyson PD, Pongruengphant R. Five-year follow-up study of stress among nurses in public and private hospitals in Thailand. Int J Nurs Stud. Mar. 2004;41(3):247-254. Not eligible target population. [pmid: 14967181].
2641 Tzeng HM. Demand and supply for nursing competencies in Taiwan's hospital industry. Nurs Econ. May–Jun. 2003;21(3):130-139. Not eligible target population. [pmid: 12847987].
2642 Tzeng HM. Nurses' self-assessment of their nursing competencies, job demands and job performance in the Taiwan hospital system. Int J Nurs Stud. Jul. 2004;41(5):487-496. Not eligible target population. [pmid: 15120977].
2643 Tzeng HM, Ketefian S. Demand for nursing competencies: an exploratory study in Taiwan's hospital system. J Clin Nurs. Jul. 2003;12(4):509-518. Not eligible target population. [pmid: 12790864].
2644 Tzeng HM, Ketefian S, Redman RW. Relationship of nurses' assessment of organizational culture, job satisfaction, and patient satisfaction with nursing care. Int J Nurs Stud. Jan. 2002;39(1):79-84. Not eligible target population. [pmid: 11722836].
2645 Uchal M, Tjugum J, Martinsen E, Qiu X, Bergamaschi R. The impact of sleep deprivation on product quality and procedure effectiveness in a laparoscopic physical simulator: a randomized controlled trial. Am J Surg. Jun. 2005;189(6):753-757. Not eligible exposure. [pmid: 15910732].
2646 Ugrovics A, Wright J. 12-hour shifts: does fatigue undermine ICU nursing judgments? Nursing management Jan 1990;21(1): Crit Care Manage Ed):64A, F-G. Inadequate data presentation.
2647 Uitterhoeve R, Duijnhouwer E, Ambaum B, van Achterberg T. Turning toward the psychosocial domain of oncology nursing: a main problem analysis in the Netherlands. Cancer Nurs. Feb. 2003;26(1):18-27. Not eligible target population. [pmid: 12556709].
2648 Ullmer D. Legislative protection against mandatory overtime. Gastroenterol Nurs. Jul–Aug. 2002;25(4):165-166. Comment. [pmid: 12195151].
2649 Ulrich BT, Buerhaus PI, Donelan K, Norman L, Dittus R. How RNs view the work environment: results of a national survey of registered nurses. J Nurs Adm. Sep. 2005;35(9):389-396. Not eligible exposure. [pmid: 16200006].
2650 Umansky PW. Management during the off-shifts. Nurs Spectr (Wash D C). Sep 9. 1996;6(19):6-7. Comment. [pmid: 9434416].
2651 Unruh L. Trends in adverse events in hospitalized patients. J Healthc Qual. Sep–Oct. 2002;24(5):4-10. quiz 10, 18. Not eligible exposure. [pmid: 12240543].
2652 Unruh LY, Fottler. Projections and trends in RN supply: what do they tell us about the nursing shortage?. Policy, Politics, & Nursing Practice. Aug. 2005;6(3):171-82. Not relevant.
2653 Upenieks VV. Assessing differences in job satisfaction of nurses in magnet and nonmagnet hospitals. J Nurs Adm. Nov. 2002;32(11):564-576. Not eligible exposure. [pmid: 12464774].
2654 Upenieks VV. What constitutes effective leadership? Perceptions of magnet and nonmagnet nurse leaders. J Nurs Adm. Sep. 2003;33(9):456-467. Not eligible exposure. [pmid: 14501562].
2655 Urden LD. Development of a nurse executive decision support database. A model for outcomes evaluation. J Nurs Adm. Oct. 1996;26(10):15-21. No association tested. [pmid: 8858010].
2656 Vail JD, Morton DA, Rieder KA. Workload management system highlights staffing needs. Nurs Health Care. May. 1987;8(5):289-293. Not eligible year. [pmid: 3647286].
2657 Vale MJ, Jelinek MV, Best JD, Dart AM, Grigg LE, Hare DL, Ho BP, Newman RW, McNeil JJ. Coaching patients On Achieving Cardiovascular Health (COACH): a multicenter randomized trial in patients with coronary heart disease. Arch Intern Med. Dec 8–22. 2003;163(22):2775-2783. Not eligible target population. [pmid: 14662633].
2658 Valouxis C, Housos E. Hybrid optimization techniques for the workshift and rest assignment of nursing personnel. Artif Intell Med. Oct. 2000;20(2):155-175. Not eligible target population. [pmid: 10936751].
2659 van den Bemt PM, Egberts AC, Lenderink AW, Verzijl JM, Simons KA, van der Pol WS, Leufkens HG. Adverse drug events in hospitalized patients. A comparison of doctors, nurses and patients as sources of reports. Eur J Clin Pharmacol. Apr. 1999;55(2):155-158. Not eligible target population. [pmid: 10335912].
2660 Van der Geest S, Sarkodie S. The fake patient: a research experiment in a Ghanaian hospital. Soc Sci Med. Nov. 1998;47(9):1373-1381. Not eligible target population. [pmid: 9783880].
2661 van der Voort PH, van der Hulst RW, Zandstra DF, van der Ende A, Kesecioglu J, Geraedts AA, Tytgat GN. Gut decontamination of critically ill patients reduces Helicobacter pylori acquisition by intensive care nurses. J Hosp Infect. Jan. 2001;47(1):41-45. Not eligible exposure. [pmid: 11161897].
2662 Van Der Zwet WC, Parlevliet GA, Savelkoul PH, Stoof J, Kaiser AM, Van Furth AM, Vandenbroucke-Grauls CM. Outbreak of Bacillus cereus infections in a neonatal intensive care unit traced to balloons used in manual ventilation. J Clin Microbiol. Nov. 2000;38(11):4131-4136. Not eligible target population. [pmid: 11060080]. [pmcid: 87553].
2663 van Servellen G, Leake B. Emotional exhaustion and distress among nurses: how important are AIDS-care specific factors?. Journal of the Association of Nurses in AIDS Care. Mar–Apr. 1994;5(2):11-9. Not relevant. [pmid: 8032009].
2664 van Servellen G, Schultz MA. Demystifying the influence of hospital characteristics on inpatient mortality rates. J Nurs Adm. Apr. 1999;29(4):39-47. Review. [pmid: 10200785].
2665 Van Slyck A. A systems approach to the management of nursing services. Part III: Staffing system. Nurs Manage. May 1991;22(5):30, 32, 34. Comment.
2666 van Wissen K, Woodman K. Nurses' attitudes and concerns to HIV/AIDS: a focus group approach. J Adv Nurs. Dec. 1994;20(6):1141-1147. Not eligible target population. [pmid: 7860861].
2667 Vanderschueren S, Van Renterghem L, Plum J, Verhofstede C, Mak R, Vincke J. Hepatitis C among risk groups for HIV and hepatitis B. Int J STD AIDS. May–Jun. 1991;2(3):185-187. Not eligible target population. [pmid: 1650587].
2668 Vanderslott J. A study of incidents of violence towards staff by patients in an NHS Trust hospital. J Psychiatr Ment Health Nurs. Aug. 1998;5(4):291-298. Not eligible target population. [pmid: 9807366].
2669 Vaughan CA, Reeds LB, Percifull D. A strategic nursing assistance program—SNAP. Nurs Econ. Nov–Dec. 1990;8(6):426-427. No association tested. [pmid: 2267035].
2670 Vejlgaard T, Addington-Hall JM. Attitudes of Danish doctors and nurses to palliative and terminal care. Palliat Med. Mar. 2005;19(2):119-127. Not eligible target population. [pmid: 15810750].
2671 Velianoff GD. Establishing a 10-hour schedule. Nurs Manage. Sep. 1991;22(9):36-38. No association tested. [pmid: 1891148].
2672 Verghese C, Prior-Willeard PF, Baskett PJ. Immediate management of the airway during cardiopulmonary resuscitation in a hospital without a resident anaesthesiologist. Eur J Emerg Med. Sep. 1994;1(3):123-125. Not eligible target population. [pmid: 9422153].
2673 Veyckemans F. Patient-controlled analgesia in children. Acta Anaesthesiol Belg. 1992;43(1):57-61. Not eligible target population. [pmid: 1350877].
2674 Vicca AF. Nursing staff workload as a determinant of methicillin-resistant Staphylococcus aureus spread in an adult intensive therapy unit. J Hosp Infect. Oct. 1999;43(2):109-113. Not eligible target population. [pmid: 10549310].
2675 Vieira AM. Caught short-staffed. Am J Nurs. Jun. 1996;96(6):63. Comment. [pmid: 8651339].
2676 Viney C, Poxon I, Jordan C, Winter B. Does the APACHE II scoring system equate with the Nottingham Patient Dependency System? Can these systems be used to determine nursing workload and skill mix? Nurs Crit Care. Mar–Apr 1997;2(2):59, 62–53. Not eligible target population.
2677 Vinh DT, Johnson CW, Phelps CL. Rigorously assessing whether the data backs the back school. AMIA Annu Symp Proc. 2003:1041. Comment.
2678 Violante FS, Fiori M, Fiorentini C, Risi A, Garagnani G, Bonfiglioli R, Mattioli S. Associations of psychosocial and individual factors with three different categories of back disorder among nursing staff. J Occup Health. Mar. 2004;46(2):100-108. Not eligible target population. [pmid: 15090684].
2679 Visina CE, Chen J, Gerthoffer TD, Biggs R, Ting D. Community hospital physician and nurse attitudes about pain management. J Pain Palliat Care Pharmacother. 2003;17(2):51-62. Not eligible exposure. [pmid: 14649388].
2680 Vitacca M, Clini E, Porta R, Ambrosino N. Preliminary results on nursing workload in a dedicated weaning center. Intensive Care Med. Jun. 2000;26(6):796-799. Not eligible target population. [pmid: 10945400].
2681 von Essen L, Sjoden PO. The importance of nurse caring behaviors as perceived by Swedish hospital patients and nursing staff. Int J Nurs Stud. 1991;28(3):267-281. Not eligible target population. [pmid: 1938183].
2682 von Essen L, Sjoden PO. Patient and staff perceptions of caring: review and replication. J Adv Nurs. Nov. 1991;16(11):1363-1374. Not eligible target population. [pmid: 1721634].
2683 von Essen L, Sjoden PO. Perceived importance of caring behaviors to Swedish psychiatric inpatients and staff, with comparisons to somatically-ill samples. Res Nurs Health. Aug. 1993;16(4):293-303. Not eligible target population. [pmid: 8378559].
2684 von Essen L, Sjoden PO. Perceived occurrence and importance of caring behaviours among patients and staff in psychiatric, medical and surgical care. J Adv Nurs. Feb. 1995;21(2):266-276. Not eligible target population. [pmid: 7536224].
2685 von Essen L, Sjoden PO. The importance of nurse caring behaviors as perceived by Swedish hospital patients and nursing staff. International Journal of Nursing Studies (1991), 28, 267–281. Int J Nurs Stud. Jul. 2003;40(5):487-497. discussion 499–502. Not eligible target population. [pmid: 12828970].
2686 Vonfrolio LG. Staffing ratios are the answer. Rn. Jun. 2004;67(6):80. Comment.
2687 Vore AL. Enhancing verbal communication skills and promoting effective socialization of newly hired Spanish-speaking registered nurses. J Nurs Staff Dev. Nov–Dec. 1991;7(6):286-289. Not eligible outcomes. [pmid: 1748895].
2688 Vyas A, Pickering CA, Oldham LA, Francis HC, Fletcher AM, Merrett T, Niven RM. Survey of symptoms, respiratory function, and immunology and their relation to glutaraldehyde and other occupational exposures among endoscopy nursing staff. Occup Environ Med. Nov. 2000;57(11):752-759. Not eligible target population. [pmid: 11024199].
2689 Waid EO. Job sharing meets nurses' needs. Ohio Nurses Rev. Jul. 1996;71(6):10-11. Comment. [pmid: 8920538].
2690 Wainwright TA. The perceived function of health care assistants in intensive care: nurses views. Intensive Crit Care Nurs. Jun. 2002;18(3):171-180. Not eligible target population. [pmid: 12405272].
2691 Wakefield BJ, Blegen MA, Uden-Holman T, Vaughn T, Chrischilles E, Wakefield DS. Organizational culture, continuous quality improvement, and medication administration error reporting. Am J Med Qual. Jul–Aug. 2001;16(4):128-134. Not eligible outcomes (medication error reporting perception). [pmid: 11477957].
2692 Wakefield BJ, Wakefield DS, Uden-Holman T, Blegen MA. Nurses' perceptions of why medication administration errors occur. Medsurg Nurs. Feb. 1998;7(1):39-44. Not eligible exposure. [pmid: 9544009].
2693 Wakefield DS, Wakefield BJ, Borders T, Uden-Holman T, Blegen M, Vaughn T. Understanding and comparing differences in reported medication administration error rates. Am J Med Qual. Mar–Apr. 1999;14(2):73-80. Not eligible exposure. [pmid: 10446668].
2694 Wakefield DS, Wakefield BJ, Uden-Holman T, Blegen MA. Perceived barriers in reporting medication administration errors. Best Pract Benchmarking Healthc. Jul–Aug. 1996;1(4):191-197. Not eligible exposure. [pmid: 9192569].
2695 Wakefield DS, Wakefield BJ, Uden-Holman T, Borders T, Blegen M, Vaughn T. Understanding why medication administration errors may not be reported. Am J Med Qual. Mar–Apr. 1999;14(2):81-88. Not eligible exposure. [pmid: 10446669].
2696 Walczak JR, McGuire DB, Haisfield ME, Beezley A. A survey of research-related activities and perceived barriers to research utilization among professional oncology nurses. Oncol Nurs Forum. May. 1994;21(4):710-715. Not eligible outcomes. [pmid: 8047469].
2697 Waldenstrom U. Continuity of carer and satisfaction. Midwifery. Dec. 1998;14(4):207-213. Not eligible target population. [pmid: 10076315].
2698 Walder B, Francioli D, Meyer JJ, Lancon M, Romand JA. Effects of guidelines implementation in a surgical intensive care unit to control nighttime light and noise levels. Crit Care Med. Jul. 2000;28(7):2242-2247. Not eligible target population. [pmid: 10921547].
2699 Walker AC. Safety and comfort work of nurses glimpsed through patient narratives. Int J Nurs Pract. Feb. 2002;8(1):42-48. Not eligible target population. [pmid: 11831426].
2700 Walker CA. STAR Day: one hospital's solution to educational challenges. J Nurses Staff Dev. Nov–Dec. 2002;18(6):293-296. Not eligible exposure. [pmid: 12476057].
2701 Walker DD, Jones SL, Yamauchi SS, Lima C, Archer S, Mathews BP, Harris M, Kamikawa C, Irvine N, Lanier J, et al. The Queen's Medical Center Honolulu, Hawaii. Nurs Adm Q. Fall. 1994;19(1):33-65. Not eligible target population. [pmid: 7777214].
2702 Walker EK. Staffing accommodations to hospital unit admissions. Nursing Economics. Sep–Oct. 1990;8(5):314-8. Not relevant. [pmid: 2234137].
2703 Walker J, Brooksby A, McInerny J, Taylor A. Patient perceptions of hospital care: building confidence, faith and trust. J Nurs Manag. Jul. 1998;6(4):193-200. Not eligible target population. [pmid: 9832723].
2704 Walker JK. Nurse managers making a difference: creating a healing place. Semin Nurse Manag. Dec. 1994;2(4):234-238. Review. [pmid: 7704655].
2705 Walker R, Adam J. Changing time in an operating suite. Int J Nurs Stud. Feb. 2001;38(1):25-35. Not eligible target population. [pmid: 11137720].
2706 Walker SB, Lowe MJ. Nurses' views on reporting medication incidents. Int J Nurs Pract. Jun. 1998;4(2):97-102. Not eligible target population. [pmid: 9748938].
2707 Wallace SA, Gullan RW, Byrne PO, Bennett J, Perez-Avila CA. Use of a pro forma for head injuries in the accident and emergency department—the way forward. J Accid Emerg Med. Mar. 1994;11(1):33-42. Not eligible target population. [pmid: 7921548].
2708 Walrath JM, Tomallo-Bowman R, Maguire JM. Emergency department: improving patient satisfaction. Nurs Econ. Mar–Apr 2004;22(2):71–74, 55. Not eligible exposure.
2709 Walsh B, Steiner A, Warr J, Sheron L, Pickering R. Nurse-led inpatient care: opening the ‘black box’. Int J Nurs Stud. Mar. 2003;40(3):307-319. Not eligible target population. [pmid: 12605953].
2710 Walsh C. A measurable framework for improving quality. Prof Nurse. Nov. 1999;15(2):80-84. Not eligible target population. [pmid: 10765309].
2711 Walters AJ. A hermeneutic study of the concept of ‘focusing’ in critical care nursing practice. Nurs Inq. Nov. 1994;1(1):23-30. No association tested. [pmid: 7850621].
2712 Walters JA. Nurses' perceptions of reportable medication errors and factors that contribute to their occurrence. Appl Nurs Res. May. 1992;5(2):86-88. Not eligible outcomes. [pmid: 1642491].
2713 Walther SM, Jonasson U, Karlsson S, Nordlund P, Johansson A, Malstam J. Multicentre study of validity and interrater reliability of the modified Nursing Care Recording System (NCR11) for assessment of workload in the ICU. Acta Anaesthesiol Scand. Jul. 2004;48(6):690-696. Not eligible target population. [pmid: 15196100].
2714 Wang CE. Knowing and approaching hope as human experience: implications for the medical-surgical nurse. Medsurg Nurs. Aug. 2000;9(4):189-192. Case reports. [pmid: 11040661].
2715 Ward D. Infection control: reducing the psychological effects of isolation. Br J Nurs. Feb 10–23. 2000;9(3):162-170. Not eligible exposure. [pmid: 11033629].
2716 Ward D, Berkowitz B. Arching the flood: how to bridge the gap between nursing schools and hospitals. Health Aff (Millwood). Sep–Oct. 2002;21(5):42-52. Review. [pmid: 12224908].
2717 Ward KG. A TEAM approach to NICU care. Rn. Feb. 1999;62(2):47-49. Comment. [pmid: 10086017].
2718 Warminger P. Staff and patient communications—trends and technologies. Health Estate J. Jul. 1990;44(6):2-8. Not eligible target population. [pmid: 10105618].
2719 Warren DK, Zack JE, Cox MJ, Cohen MM, Fraser VJ. An educational intervention to prevent catheter-associated bloodstream infections in a nonteaching, community medical center. Crit Care Med. Jul. 2003;31(7):1959-1963. Not eligible exposure. [pmid: 12847389].
2720 Warren IB, Rozell BR. Supplemental staffing. Nurse manager views of costs, benefits, and quality of care. J Nurs Adm. Jun. 1995;25(6):51-57. Not eligible outcomes. [pmid: 7776008].
2721 Washburn M. Fatigue and critical thinking on eight- and twelve-hour shifts. Nursing management Sep 1991;22(9): Crit Care Manage Ed):80A- F-H. Inadequate data presentation.
2722 Washington GT, Macnee CL. Evaluation of outcomes: the effects of continuous lateral rotational therapy. J Nurs Care Qual. Jul–Sep. 2005;20(3):273-282. Not eligible exposure. [pmid: 15965394].
2723 Watanakunakorn C, Wang C, Hazy J. An observational study of hand washing and infection control practices by healthcare workers. Infection Control and Hospital Epidemiology. Nov. 1998;19(11):858-60. Not relevant. [pmid: 9831945].
2724 Waters A. A matter of life and death. Nurs Stand. Jun 30–Jul 6. 1999;13(41):12-13. Comment.
2725 Waters A. It's all in the mix. Nurs Stand. Feb 19–25. 2003;17(23):14-17. Not eligible target population.
2726 Watson LD, Quinn DA. Stages of stroke: a model for stroke rehabilitation. Br J Nurs. Jun 25–Jul 8 1998;7(12):suppl 8p. Not eligible exposure.
2727 Weaver J. Many American nurses are having trouble finding jobs. Nurs Spectr (Wash D C). Jun 17. 1996;6(13):5. News. [pmid: 9433228].
2728 Webb AA, Bower DA, Gill S. Satisfaction with nursing care: a comparison of patients with HIV/AIDS, non-HIV/AIDS infectious diseases, and medical diagnoses. J Assoc Nurses AIDS Care. Mar–Apr. 1997;8(2):39-46. Not eligible exposure. [pmid: 9152890].
2729 Webb D, Tour C, Hurt R, van Kammen DP. Recognizing excellence. Giving your AWE. J Nurs Adm. Sep. 1992;22(9):54-56. Not eligible exposure. [pmid: 1432244].
2730 Webb SS, Price SA, Coeling HE. Valuing authority/responsibility relationships. The essence of professional practice. J Nurs Adm. Feb. 1996;26(2):28-33. Not eligible exposure. [pmid: 8601825].
2731 Webber S. Cluster staffing: cooperation, competence, and caring. Todays OR Nurse. Mar–Apr. 1993;15(2):5-7. No association tested.
2732 Weber DO. Harrison Memorial in Bremerton, Washington records satisfaction all around from 2-year-old “private practice” unit nursing experiment. Strateg Healthc Excell. Dec. 1992;5(12):1-10. Not eligible exposure.
2733 Weber S, Herwaldt LA, McNutt LA, Rhomberg P, Vaudaux P, Pfaller MA, Perl TM. An outbreak of Staphylococcus aureus in a pediatric cardiothoracic surgery unit. Infect Control Hosp Epidemiol. Feb. 2002;23(2):77-81. Not eligible exposure. [pmid: 11893152].
2734 Webster DC, Vaughn K, Martinez R. Introducing solution-focused approaches to staff in inpatient psychiatric settings. Arch Psychiatr Nurs. Aug. 1994;8(4):254-261. Not eligible exposure. [pmid: 7979558].
2735 Webster J, Cowart P. An innovative professional nursing practice model. Nurs Adm Q. Spring. 1999;23(3):11-16. Comment. [pmid: 10363015].
2736 Wedge C, Gosney M. Pressure-relieving equipment: promoting its correct use amongst nurses via differing modes of educational delivery. J Clin Nurs. Apr. 2005;14(4):473-478. Not eligible target population. [pmid: 15807754].
2737 Weetch RM. Patient satisfaction with information received after a diagnosis of angina. Prof Nurse. Nov. 2003;19(3):150-153. Not eligible exposure. [pmid: 14639904].
2738 Wehby D, Brenner PS. Perceived learning needs of patients with heart failure. Heart Lung. Jan–Feb. 1999;28(1):31-40. Not eligible exposure. [pmid: 9915929].
2739 Weinberg AD, Lesene AJ, Richards CL, et al. Quality care indicators and staffing levels in a nursing facility subacute unit. Journal of the American Medical Directors Association. Jan–Feb. 2002;3(1):1-4. Not relevant. [pmid: 12807556].
2740 Weinstein SM, Antonova S, Goryunova M. Enhancing nurse-physician collaboration: a staffing innovation. J Nurs Adm. Apr. 2003;33(4):193-195. Review. [pmid: 12690248].
2741 Weir R, Stewart L, Browne G, Roberts J, Gafni A, Easton S, Seymour L. The efficacy and effectiveness of process consultation in improving staff morale and absenteeism. Med Care. Apr. 1997;35(4):334-353. Not eligible exposure. [pmid: 9107203].
2742 Weisman CS, Gordon DL, Cassard SD, Bergner M, Wong R. The effects of unit self-management on hospital nurses' work process, work satisfaction, and retention. Med Care. May. 1993;31(5):381-393. Not eligible outcomes. [pmid: 8501987].
2743 Weiss JP. Using the nurse practitioner in the acute care setting. Aspens Advis Nurse Exec. Aug. 1994;9(11):4-6. Comment. [pmid: 8060724].
2744 Welford M. Night shifts: light-headed night staff. Nurs Stand. Aug 5–11. 1992;6(46):44-45. Not eligible exposure. [pmid: 1390071].
2745 Wells B. Taking charge of your practice. Nurs BC. Jan–Feb. 1998;30(1):16-17. Comment. [pmid: 10095564].
2746 Wells N, Johnson R, Salyer S. Interdisciplinary collaboration. Clin Nurse Spec. Jul. 1998;12(4):161-168. Not eligible exposure. [pmid: 9987223].
2747 Weltman AC, Short LJ, Mendelson MH, Lilienfeld DE, Rodriguez M. Disposal-related sharps injuries at a New York City Teaching Hospital. Infect Control Hosp Epidemiol. May. 1995;16(5):268-274. Not eligible exposure. [pmid: 7657974].
2748 Wenzel K, Miller M, Falco J. Differentiated practice in Colorado—what's happening?. Colo Nurse. Dec. 1996;96(4):17-18. Comment. [pmid: 9025372].
2749 Werab B, Alexander C, Brunt B, Wester F. The use of medication modules for medication administration problems. J Nurs Staff Dev. Jan–Feb. 1994;10(1):16-21. Not eligible exposure. [pmid: 8120641].
2750 Wermers MA, Dagnillo R, Glenn R, Macfarlane R, St Clair V, Scott D. Planning and assessing a cross-training initiative with multi-skilled employees. Jt Comm J Qual Improv. Jun. 1996;22(6):412-426. Not eligible exposure. [pmid: 8806044].
2751 West JC. Agency not liable for actions of nurse supplied by agency. Hansen v. Caring Professionals, Inc. J Healthc Risk Manag. Fall. 1997;17(4):51-53. Comment. [pmid: 10169966].
2752 Westera D. A profile of part-time faculty in Canadian university nursing programmes. Canadian Journal of Nursing Research. Winter. 1992;24(4):47-59. Not relevant. [pmid: 1306401].
2753 Western H. New, but hardly improved. Nurs Times. Oct 13–19. 1999;95(41):49. Not eligible target population. [pmid: 10786604].
2754 Westfall NL, Burrow CM. Are daily bed linen changes necessary?. Nurs Manage. Nov. 1997;28(11):90-92. Comment. [pmid: 9385168].
2755 Wetzel K, Soloshy DE, Gallagher DG. The work attitudes of full-time and part-time registered nurses. Health Care Manage Rev. Summer. 1990;15(3):79-85. Not eligible outcomes. [pmid: 2398005].
2756 Wheaton M. Cross-training: meeting staffing needs in the ICU. Nurs Manage. Nov. 1996;27(11):32B. Not eligible exposure. [pmid: 8632867].
2757 Wheeler EC. The CNS's impact on process and outcome of patients with total knee replacement. Clin Nurse Spec. Jul. 2000;14(4):159-169. quiz 170–152. Not eligible exposure. [pmid: 11188426].
2758 Wheeler J. How to delegate your way to a better working life. Nurs Times. Sep 6–12. 2001;97(36):34-35. Not eligible target population.
2759 Whelchel C. Patients first when budgeting. Nurs Manage. Mar. 2004;35(3):16. Review. [pmid: 15021794].
2760 Whiley K. The nurse manager's role in creating a healthy work environment. AACN Clin Issues. Aug. 2001;12(3):356-365. Comment. [pmid: 11759354].
2761 Whitby RM, McLaws ML. Hollow-bore needlestick injuries in a tertiary teaching hospital: epidemiology, education and engineering. Med J Aust. Oct 21. 2002;177(8):418-422. Not eligible target population. [pmid: 12381250].
2762 White C. Pique practice. Nurs Times. Jun 18–24. 2002;98(25):24-25. Comment. [pmid: 12168221].
2763 White CL. Changing pain management practice and impacting on patient outcomes. Clin Nurse Spec. Jul. 1999;13(4):166-172. Not eligible exposure. [pmid: 10690052].
2764 White F, Buswell C, Scullion J, Baldwin M. Doctor's orders. Nurs Stand. Feb 19–25. 2003;17(23):21. Not eligible target population. [pmid: 12655762].
2765 White RJ. Cost-cutters eliminate skilled nurses. Revolution. Summer. 1997;7(2):2. Editorial. [pmid: 9277303].
2766 Whitehead E. Staff shortages would be a thing of the past with a return to ward-based training. Nurs Times. Dec 1–7. 1999;95(48):43. Not eligible target population. [pmid: 11096932].
2767 Whitman GR, Kim Y, Davidson LJ, Wolf GA, Wang SL. Measuring nurse-sensitive patient outcomes across specialty units. Outcomes Manag. Oct–Dec. 2002;6(4):152-158. quiz 159–160. Not eligible exposure. [pmid: 12385166].
2768 Whittington R, Wykes T. Violence in psychiatric hospitals: are certain staff prone to being assaulted?. J Adv Nurs. Feb. 1994;19(2):219-225. Not eligible target population. [pmid: 8188951].
2769 Whittington R, Wykes T. An evaluation of staff training in psychological techniques for the management of patient aggression. J Clin Nurs. Jul. 1996;5(4):257-261. Not eligible exposure. [pmid: 8718059].
2770 Wichowski HC, Kubsch SM, Ladwig J, Torres C. Patients' and nurses' perceptions of quality nursing activities. Br J Nurs. Oct 23–Nov 12. 2003;12(19):1122-1129. Not eligible exposure. [pmid: 14593259].
2771 Widmark-Petersson V, von Essen L, Lindman E, Sjoden PO. Cancer patient and staff perceptions of caring vs clinical care. Scand J Caring Sci. 1996;10(4):227-233. Not eligible target population. [pmid: 9060777].
2772 Widmark-Petersson V, von Essen L, Sjoden PO. Perceptions of caring among patients with cancer and their staff. Differences and disagreements. Cancer Nurs. Feb. 2000;23(1):32-39. Not eligible exposure. [pmid: 10673805].
2773 Wiesner G, Harth M, Szulc R, Jurczyk W, Sobczynski P, Hoerauf KH, Hobbhahn J, Taeger K. A follow-up study on occupational exposure to inhaled anaesthetics in Eastern European surgeons and circulating nurses. Int Arch Occup Environ Health. Jan. 2001;74(1):16-20. Not eligible target population. [pmid: 11196076].
2774 Wiklander M, Samuelsson M, Asberg M. Shame reactions after suicide attempt. Scand J Caring Sci. Sep. 2003;17(3):293-300. Not eligible target population. [pmid: 12919465].
2775 Wild D, Bradley EH. The gap between nurses and residents in a community hospital's error-reporting system. Jt Comm J Qual Patient Saf. Jan. 2005;31(1):13-20. Not eligible exposure. [pmid: 15691206].
2776 Wild D, Nawaz H, Chan W, Katz DL. Effects of interdisciplinary rounds on length of stay in a telemetry unit. J Public Health Manag Pract. Jan–Feb. 2004;10(1):63-69. Not eligible exposure. [pmid: 15018343].
2777 Wiles R, Postle K, Steiner A, Walsh B. Nurse-led intermediate care: patients' perceptions. Int J Nurs Stud. Jan. 2003;40(1):61-71. Not eligible target population. [pmid: 12550151].
2778 Wilhoite SL, Ferguson DA Jr, Soike DR, Kalbfleisch JH, Thomas E. Increased prevalence of Helicobacter pylori antibodies among nurses. Arch Intern Med. Mar 22. 1993;153(6):708-712. Not eligible exposure. [pmid: 8447708].
2779 Wilkinson CL. An evaluation of an educational program on the management of assaultive behaviors. J Gerontol Nurs. Apr. 1999;25(4):6-11. Not eligible outcomes. [pmid: 10426029].
2780 Wilkinson R. Safe practice: machine age killers. Nurs Stand. Jul 15–21. 1992;6(43):44-45. Comment. [pmid: 1503960].
2781 Williams AM, Irurita VF. Therapeutically conducive relationships between nurses and patients: an important component of quality nursing care. Aust J Adv Nurs. Dec–1999 Feb. 1998;16(2):36-44. Not eligible target population. [pmid: 10196875].
2782 Williams AM, Irurita VF. Therapeutic and non-therapeutic interpersonal interactions: the patient's perspective. J Clin Nurs. Oct. 2004;13(7):806-815. Not eligible target population. [pmid: 15361154].
2783 Williams AM, Irurita VF. Enhancing the therapeutic potential of hospital environments by increasing the personal control and emotional comfort of hospitalized patients. Appl Nurs Res. Feb. 2005;18(1):22-28. Not eligible exposure. [pmid: 15812732].
2784 Williams C, George L, Lowry M. A framework for patient assessment. Nurs Stand. Jun 15–21. 1994;8(38):29-33. No association tested. [pmid: 8080753].
2785 Williams G, Slater K. Absenteeism and the impact of a 38-hour week, rostered day off option. Aust Health Rev. 2000;23(4):89-96. Not eligible target population. [pmid: 11256275].
2786 Williams KA, Stotts RC, Jacob SR, et al. Inactive nurses: a source for alleviating the nursing shortage?. Journal of Nursing Administration. Apr. 2006;36(4):205-10. Not relevant. [pmid: 16609343].
2787 Williams J. Orienting foreign nurse graduates through preceptors. J Nurs Staff Dev. Jul–Aug. 1992;8(4):155-158. Comment. [pmid: 1517861].
2788 Williams R. Happy together. Nurs Stand. Aug 23–29. 2000;14(49):18-19. Comment.
2789 Williams R. It all adds up. Nurs Stand. Apr 19–25. 2000;14(31):12-13. Review. [pmid: 11973933].
2790 Williams RP. Nurse leaders' perceptions of quality nursing: an analysis from academe. Nurs Outlook. Nov–Dec. 1998;46(6):262-267. Review. [pmid: 9879083].
2791 Williams S. Missing RN would threaten safety in OR. Revolution. Jul–Aug. 2000;1(4):9. News. [pmid: 12017602].
2792 Williams S, McGowan S. Professional autonomy: a pilot study to determine the effects of a professional development program on nurses' attitudes. J Nurs Staff Dev. May–Jun. 1995;11(3):150-155. Not eligible outcomes. [pmid: 7782873].
2793 Williams S, Whelan A, Weindling AM, Cooke RW. Nursing staff requirements for neonatal intensive care. Arch Dis Child. May. 1993;68(5 Spec No):534-538. Not eligible target population. [pmid: 8323351].
2794 Williams SA. The relationship of patients' perceptions of holistic nurse caring to satisfaction with nursing care. J Nurs Care Qual. Jun. 1997;11(5):15-29. Not eligible exposure. [pmid: 9212543].
2795 Willis E. Benchmarking working time in health care: the case of Excelcare. Aust Health Rev. 2002;25(3):134-140. Not eligible target population. [pmid: 12136554].
2796 Willis J. Unpalatable options. Nurs Times. Aug 12–18. 1998;94(32):28-29. Case Reports.
2797 Willson B. Floating to another worksite. Can I say no? Nurs BC. Apr. 2002;34(2):23. Comment.
2798 Wilson CK. Getting results with integrity. Aspens Advis Nurse Exec. Oct. 1998;14(1):2-3. Editorial.
2799 Wilson M. Client centred approach to community child and family care: a descriptive account of social support services provided by Plunket nurses in the central region. Nurs Prax N Z. Mar. 1996;11(1):12-18. Not eligible target population. [pmid: 8826346].
2800 Wilson N. I can see clearly now. Interview by Debbie Smith. Nurs Stand. Jun 28–Jul 4. 2000;14(41):18-19. Interview. [pmid: 11974230].
2801 Wilson TA, Jenkins EL. Development of a women's wellness center in Almaty, Kazakhstan. J Obstet Gynecol Neonatal Nurs. Mar–Apr. 2001;30(2):231-239. Not eligible target population.
2802 Windsor K. Temporary assignments: a new process. Nurs Manage. Nov. 1997;28(11):84-86. Comment. [pmid: 9385166].
2803 Wing KT. When flex comes to shove: staffing and hospital census. Nurs Manage. Jan. 2001;32(1):43-46. Case Reports. [pmid: 15103782].
2804 Winkleman L. Nursing in Texas—a personal account. AARN News Lett. Mar. 1993;49(3):10-11. Comment. [pmid: 8484300].
2805 Winnefeld M, Richard MA, Drancourt M, Grob JJ. Skin tolerance and effectiveness of two hand decontamination procedures in everyday hospital use. Br J Dermatol. Sep. 2000;143(3):546-550. Not eligible target population. [pmid: 10971327].
2806 Winstead-Fry P, Bormolini S, Keech RR. Clinical care coordination program: a working partnership. J Nurs Adm. Jul–Aug. 1995;25(78):46-51. No association tested. [pmid: 7636573].
2807 Wintle JM, Pattrin L, Crutchfield JE, Allgeier PJ, Gaston-Johansson F. Job satisfaction and the 12-hour shift. Nurs Manage. Feb. 1995;26(2):54. Comment. [pmid: 7724085].
2808 Wirt GL. Causes of institutionalism: patient and staff perspectives. Issues Ment Health Nurs. May–Jun. 1999;20(3):259-274. Not eligible target population. [pmid: 10633644].
2809 Wise LC. The erosion of nursing resources: employee withdrawal behaviors. Res Nurs Health. Feb. 1993;16(1):67-75. Not eligible outcomes. [pmid: 8488314].
2810 Witchell L. Managing international recruits. Nurs Manag (Harrow). Jun. 2002;9(3):10-14. Not eligible target population. [pmid: 12077865].
2811 Wolf G, Gabriel VH, Omachonu VK. Using simulation to project staffing levels. Nurs Manage. Aug 1992;23(8):64A, 64D, 64F passim. Not eligible outcomes.
2812 Wolf ZR, Colahan M, Costello A. Relationship between nurse caring and patient satisfaction. Medsurg Nurs. Apr. 1998;7(2):99-105. Not eligible exposure. [pmid: 9727124].
2813 Wolf ZR, Haakenson DA, Jablonski RA, McGoldrick TB. Nurses' perceptions of harmful outcomes from medication errors. Medsurg Nurs. Dec 1995;4(6):460–467, 471. Not eligible outcomes.
2814 Wolsieffer D. Retention and work environment. Nurs Econ. May–Jun. 2004;22(3):165. Letter. [pmid: 15211924].
2815 Wong DF, Leung SS, So CK. Differential impacts of coping strategies on trati the mental health of Chinese nurses in hospitals in Hong Kong. Int J Nurs Pract. Jun. 2001;7(3):188-198. Not eligible target population. [pmid: 11811815].
2816 Wong FK, Chow S, Chang K, Lee A, Liu J. Effects of nurse follow-up on emergency room revisits: a randomized controlled trial. Soc Sci Med. Dec. 2004;59(11):2207-2218. Not eligible target population. [pmid: 15450698].
2817 Wood CJ. Can nurses safely assess the need for endotracheal suction in short-term ventilated patients, instead of using routine techniques?. Intensive Crit Care Nurs. Aug. 1998;14(4):170-178. Not eligible target population. [pmid: 9849243].
2818 Wood D. Acting on complaints about mental health services. Implications of power imbalances. J Manag Med. 1996;10(3):31-38. Not eligible target population. [pmid: 10162932].
2819 Wood D. Nurses receive bonuses for patient satisfaction. Pa Nurse. Jan–Feb. 2004;59(1):4. News. [pmid: 15032083].
2820 Wood L. Autotransfusion in the postanesthesia care unit. J Post Anesth Nurs. Apr. 1991;6(2):98-101. Not eligible outcomes. [pmid: 2007991].
2821 Woodcraft B. Shift work: benighted existence. Nurs Stand. Mar 18–24. 1992;6(26):46. Comment. [pmid: 1562484].
2822 Woodhouse AJ. A late shift in accident and emergency. Accid Emerg Nurs. Oct. 1995;3(4):219-220. Not eligible target population. [pmid: 8520944].
2823 Woodward W. Preparing a new workforce. Nurs Adm Q. Jul–Sep. 2003;27(3):215-222. Review. [pmid: 13677186].
2824 Woogara J. Patients' rights to privacy and dignity in the NHS. Nurs Stand. Jan 12–18. 2005;19(18):33-37. Not eligible target population. [pmid: 15683053].
2825 Woolliscroft JO, Howell JD, Patel BP, Swanson DB. Resident-patient interactions: the humanistic qualities of internal medicine residents assessed by patients, attending physicians, program supervisors, and nurses. Acad Med. Mar. 1994;69(3):216-224. Not eligible exposure. [pmid: 8135980].
2826 Wootten N. Evaluation of 12-hour shifts on a cardiology nursing development unit. Br J Nurs. Nov 9–22. 2000;9(20):2169-2174. Not eligible target population. [pmid: 12271186].
2827 Worthington K. Reproductive hazards on the job. Am J Nurs. Oct. 2001;101(10):104. Comment.
2828 Wortley V, Grierson-Hill L. Developing a successful self-rostering shift system. Nurs Stand. Jul 2–8. 2003;17(42):40-42. Not eligible target population. [pmid: 12874926].
2829 Wotton K, Gassner LA, Ingham E. Flushing an i.v. line: a simple but potentially costly procedure for both patient and health unit. Contemp Nurse. Oct. 2004;17(3):264-273. Not eligible target population. [pmid: 15551677].
2830 Wright B. Nursing: an ageing population. Accid Emerg Nurs. Apr. 1998;6(2):65. Editorial. [pmid: 9677871].
2831 Wright B. Can you work?. Accid Emerg Nurs. Jul. 2000;8(3):127. Editorial. [pmid: 10893552].
2832 Wright S. Standing up for Pink. Nurs Times. Oct 3–9. 1990;86(40):18. Comment. [pmid: 2216854].
2833 Wright S. Eastern light. Nurs Stand. Nov 24–30. 2004;19(11):20-21. Comment. [pmid: 15615167].
2834 Wright V. It just doesn't add up. Br J Perioper Nurs. Jul. 2004;14(7):300. Not eligible target population. [pmid: 15704375].
2835 Wrona-Sexton S. Patient classification systems: another perspective. Nurs Manage. Dec. 1992;23(12):38-39. Not eligible exposure. [pmid: 1465255].
2836 Wu ML, Courtney M, Berger G. Models of nursing care: a comparative study of patient satisfaction on two orthopaedic wards in Brisbane. Aust J Adv Nurs. Jun–Aug. 2000;17(4):29-34. Not eligible target population. [pmid: 11249397].
2837 Wylie DM. Staffing to meet patient care needs. Can J Nurs Adm. Jan–Feb. 1998;11(1):5-6. Editorial. [pmid: 9616553].
2838 Wynd C. Leapfrog Group jumps over nursing. Nurs Manage. Dec. 2002;33(12):20. News. [pmid: 12488632].
2839 Wynd CA, Samstag DE, Lapp AM. Bacterial carriage on the fingernails of OR nurses. Aorn J. Nov 1994;60(5):796, 799–805. Not eligible exposure.
2840 Yang KP. Relationships between nurse staffing and patient outcomes. J Nurs Res. Sep. 2003;11(3):149-158. Not eligible target population. [pmid: 14579192].
2841 Yang KP, Huang CK. The effects of staff nurses' morale on patient satisfaction. J Nurs Res. Jun. 2005;13(2):141-152. Not eligible exposure. [pmid: 15986315].
2842 Yang Y, Koh D, Ng V, Lee FC, Chan G, Dong F, Chia SE. Salivary cortisol levels and work-related stress among emergency department nurses. J Occup Environ Med. Dec. 2001;43(12):1011-1018. Not eligible target population. [pmid: 11765672].
2843 Yassi A, Tate R, Cooper J, Jenkins J, Trottier J. Causes of staff abuse in health care facilities. Implications for prevention. Aaohn J. Oct. 1998;46(10):484-491. Not eligible exposure. [pmid: 9830870].
2844 Yeakel S, Maljanian R, Bohannon RW, Coulombe KH. Nurse caring behaviors and patient satisfaction: improvement after a multifaceted staff intervention. J Nurs Adm. Sep. 2003;33(9):434-436. Not eligible exposure. [pmid: 14501558].
2845 Yeh SH, Lee LN, Ho TH, Chiang MC, Lin LW. Implications of nursing care in the occurrence and consequences of unplanned extubation in adult intensive care units. Int J Nurs Stud. Mar. 2004;41(3):255-262. Not eligible target population. [pmid: 14967182].
2846 Yeung SS, Genaidy A, Deddens J, Sauter S. The relationship between protective and risk characteristics of acting and experienced workload, and musculoskeletal disorder cases among nurses. J Safety Res. 2005;36(1):85-95. Not eligible target population. [pmid: 15752486].
2847 Yi M, Jezewski MA. Korean nurses' adjustment to hospitals in the United States of America. J Adv Nurs. Sep. 2000;32(3):721-729. Not eligible outcomes. [pmid: 11012817].
2848 Yip VY. New low back pain in nurses: work activities, work stress and sedentary lifestyle. J Adv Nurs. May. 2004;46(4):430-440. Not eligible outcomes. [pmid: 15117354].
2849 Yip Y. A study of work stress, patient handling activities and the risk of low back pain among nurses in Hong Kong. J Adv Nurs. Dec. 2001;36(6):794-804. Not eligible target population. [pmid: 11903709].
2850 Yoder LH. Staff nurses' career development relationships and self-reports of professionalism, job satisfaction, and intent to stay. Nurs Res. Sep–Oct. 1995;44(5):290-297. Not eligible target population. [pmid: 7567485].
2851 Young J. Changing attitudes towards families of hospitalized children from 1935 to 1975: a case study. J Adv Nurs. Dec. 1992;17(12):1422-1429. Not eligible exposure. [pmid: 1474240].
2852 Young WB, Lehrer EL, White WD. The effect of education on the practice of nursing. Image J Nurs Sch. Summer. 1991;23(2):105-108. Not eligible outcomes. [pmid: 2060948].
2853 Young WB, Minnick AF, Marcantonio R. How wide is the gap in defining quality care? Comparison of patient and nurse perceptions of important aspects of patient care. J Nurs Adm. May. 1996;26(5):15-20. Not eligible exposure. [pmid: 8627388].
2854 Yurugen B. Patient-centred care in Turkey. Edtna Erca J. Apr–Jun. 2002;28(2):95-96. Not eligible target population. [pmid: 12216853].
2855 Yuska C, Crabtree-Tonges M, Schaps MT. Staff nurse weekend program proves cost effective. Nurs Adm Q. Winter. 1984;8(2):62-73. Not eligible year. [pmid: 6422352].
2856 Zahr LK, William SG, el-Hadad A. Patient satisfaction with nursing care in Alexandria, Egypt. Int J Nurs Stud. 1991;28(4):337-342. Not eligible target population. [pmid: 1761378].
2857 Zahourek RP. Intentionality: evolutionary development in healing: a grounded theory study for holistic nursing. Journal of Holistic Nursing. Mar. 2005;23(1):89-109. Not relevant. [pmid: 15665270].
2858 Zarich S, Pust-Marcone J, Amoateng-Adjepong Y, Manthous CA. Failure of a brief educational program to improve interpretation of pulmonary artery occlusion pressure tracings. Intensive Care Med. Jun. 2000;26(6):698-703. Not eligible exposure. [pmid: 10945386].
2859 ZborilBenson LR. Why nurses are calling in sick: the impact of heath-care restructuring. Canadian Journal of Nursing Research. Mar. 2002;33(4):89-107. Not relevant. [pmid: 11998199].
2860 Zeler KM, McPharlane TJ, Salamonsen RF. Effectiveness of nursing involvement in bedside monitoring and control of coagulation status after cardiac surgery. Am J Crit Care. Sep. 1992;1(2):70-75. Not eligible target population. [pmid: 1307893].
2861 Zeleznik J, Agard-Henriques B, Schnebel B, Smith DL. Terminology used by different health care providers to document skin ulcers: the blind men and the elephant. J Wound Ostomy Continence Nurs. Nov. 2003;30(6):324-333. Not eligible exposure. [pmid: 14615762].
2862 Ziegler E, Mason HJ, Baxter PJ. Occupational exposure to cytotoxic drugs in two UK oncology wards. Occup Environ Med. Sep. 2002;59(9):608-612. Not eligible target population. [pmid: 12205233].
2863 Zimmermann PG. “On call” staffing. J Emerg Nurs. Dec. 1993;19(6):529-531. Comment. [pmid: 8309149].
2864 Zimmermann PG. Use of “stat” nurses in the emergency department. J Emerg Nurs. Aug. 1995;21(4):335-337. Comment. [pmid: 7658635].
2865 Zimmermann PG. Self-scheduling in the emergency department. J Emerg Nurs. Feb. 1995;21(1):58-61. Comment. [pmid: 7776585].
2866 Zimmermann PG, Will TL, Soules DM, Fiore T. Avoiding registered nurse layoffs: three hospitals share how it's done. J Emerg Nurs. Aug. 1996;22(4):323-327. Comment. [pmid: 8936144].
2867 Zohar Z, Eitan A, Halperin P, Stolero J, Hadid S, Shemer J, Zveibel FR. Pain relief in major trauma patients: an Israeli perspective. J Trauma. Oct. 2001;51(4):767-772. Not eligible target population. [pmid: 11586173].
2868 Zurbrugg HR, Piehler S, Weiss HM. How to run a heart surgical unit: experiences during the first year of the Department of Cardiothoracic and Vascular Surgery, University Clinic of Regensburg. J Cardiovasc Surg (Torino). Feb. 1997;38(1):53-61. Not eligible target population.