# Appendix A: Exact Search Strings

[underlined: Search Strategy for Questions 1, 2, and 4]

The following data bases were searched:

- Med Line (PubMed)
- CINAHL
- The Cochrane Database of Systematic Reviews
- The Cochrane Central Register of Controlled Trials
- EBSCO Research Database
- BioMed Central
- Government agencies and nurse's associations' websites are searched to identify unpublished reports of the conducted surveys and regulatory documents of nursing hospital staffing:
- United States Department of Health and Human Services
- Agency for Healthcare Research and Quality
- National Database of Nursing Quality Indicators
- National Center for Health Workforce Analysis
- American Nurses Association
- American Academy of Nurse Practitioners
- Government publications.
- Database http://www.marcive.com/webdocs
- [underlined: Catalog of U.S. Government Publications (U.S. GPO)]
- Digital Dissertations
- Internet (www.google.com) with the key words identical MeSH terms
- Manual search of the references in articles to identify eligible studies published before 1990

The following MeSH terms and key words (in databases other than Medline) and their combinations were used to search the data bases from 1990 through June 2006:

“Nurses” [MeSH] (Q 1–4)*

“Nursing staff, hospital” [MeSH] (Q 1–4)

“Nursing administration research” [MeSH] (Q 1–4)

“Nursing audit” [MeSH] (Q 1–2, 4)

“Nursing education research” [MeSH] (Q 1–2, 4)

“Clinical competence” [MeSH] (Q 1–2)

“Health care quality, access, and evaluation” [MeSH] (Q1–2, 4)

“Health services research” [MeSH] (Q1, 2, 4)

“Outcome assessment (health care)” [MeSH] (Q1–2, 4)

“Health care category” [MeSH] (Q1, 2, 4)

“Patients” [MeSH] (Q1–2, 4)

“Length of stay” [MeSH] (Q1–2, 4)

“Patient satisfaction” [MeSH] (Q1–2, 4)

“Hospital units” [MeSH] (Q1, 2, 4)

“Personnel staffing and scheduling” [MeSH] (Q1–3)

“Patient centered care” [MeSH] (Q4)

“Nurse patient relations” [MeSH] (Q1–2, 4)

“Hospital patient relations” [MeSH] (Q1–2, 4)

“Models, nursing” [MeSH] (Q 4)

“Labor unions” [MeSH] (Q 4)

“Malpractice” [MeSH]

“Hospitals” [MeSH] (Q4)

Nurse to patient ratio (keyword) (Q1–3)

“Skill mix” [MeSH] (Q3)

"Part time employment [MeSH] (Q3)

"Foreign nurses [MeSH] (Q3)

“Registry personnel” [MeSH] (Q3)

Overtime (keyword) (Q3)

Flexible scheduling (keyword) (Q3)

Shift work (key word) (Q3)

* The numbers in parentheses refer to the question for which this term was relevant

[underlined: Search Strategy for Question 3]

(Inclusion criteria for all studies: North American hospitals, research in peer reviewed journal, published between 1990-2006)

Shift work staffing policy variable

58 eligible for review

51 excluded:

- 41 Not relevant (not related to variable of interest)
- 1 Integrative review not related to study variable
- 2 Conference abstract
- 2 Nursing home
- 3 Not peer reviewed journal
- 2 Inadequate data presentation

7 included

Overtime staffing policy variable

20 eligible for review

14 excluded:

- 9 Not relevant (not related to variable of interest)
- 1 Inadequate data presentation
- 4 Not peer reviewed journal

6 included

Full and part time staff use variable

28 eligible for review

22 excluded:

- 15 Not relevant (not related to variable of interest)
- 6 Not peer reviewed journal
- 1 Inadequate data presentation

6 included

Foreign educated nurses variable

20 eligible for review

14 excluded

- 12 Not relevant (not related to variable of interest)
- 1 Not research
- 1 Not peer reviewed journal

6 included

Agency/contract nurses variable

21 eligible for review

16 excluded:

- 10 Not relevant (not related to variable of interest)
- 1 Nursing home
- 2 Inadequate data presentation
- 3 Not peer reviewed journal

5 included

Total studies on staffing policy variables

147 eligible for review

117 excluded:

- 87 Not relevant (not related to variable of interest)
- 2 Conference proceedings
- 1 Integrative review not related to variable of interest
- 3 Nursing home
- 17 Not peer reviewed journal
- 6 Inadequate presentation of data
- 1 Not research

30 included

[underlined: Literature Search Strings]

MeSH terms | Studies
The National Library of Medicine via PubMed:
“Nurses” [MeSH] | 51,730
“Nursing staff, hospital”[MeSH] | 28,092
“Nursing administration research”[MeSH] | 1,218
“Nursing audit”[MeSH] | 2,349
“Nursing education research”[MeSH] | 3,285
“Clinical competence”[MeSH] | 33,806
“Health care quality, access, and evaluation”[MeSH] | 3,090,640
“Health services research”[MeSH] | 64,621
“Outcome assessment (health care)”[MeSH] | 286,369
“Health care category”[MeSH] | 4,438,573
“Personnel administration, hospital”[MeSH] | 4,968
“Patients”[MeSH] | 35,872
“Length of stay”[MeSH] | 33,382
“Patient satisfaction”[MeSH] | 28,736
“Hospital units”[MeSH] | 48,491
“United States/epidemiology”[MeSH] | 77,520
“Personnel staffing and scheduling”[MeSH] | 9,484
“Models, nursing”[MeSH] | 7,513
“Foreign professional personnel”[MeSH] | 3,523
(“Safety management”[MeSH] OR “risk management”[MeSH]) | 82,840
(“Safety management”[MeSH] OR “risk management”[MeSH]) Limits: English, humans | 70,596
(“Safety management”[MeSH] OR “risk management”[MeSH]) NOT review NOT letters NOT editorials Limits: English, humans | 48,105
“Nurses”[MeSH] NOT review NOT letters NOT editorials | 43,370
“Nursing staff, hospital”[MeSH] NOT review NOT letters NOT editorials | 25,773
“Nursing administration research ”[MeSH] NOT review NOT letters NOT editorials | 994
“Nursing audit”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 1,450
“Nursing education research ”[MeSH] NOT review NOT letters NOT editorials Limits: humans | 2,723
“Clinical competence”[MeSH] NOT review NOT letters NOT editorials Limits: humans | 22,181
“Health care quality, access, and evaluation”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 1,798,295
“Health services research”[MeSH] NOT review NOT letters NOT editorials Limits: humans | 43,486
“Outcome assessment (health care)”[MeSH] AND “health services research” [MeSH] NOT review NOT letters NOT editorials Limits: humans | 15
“Health care category”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 2,320,378
“Personnel administration, hospital”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 1,601
“Patients”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 23,507
“Length of stay”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 22,937
“Patient satisfaction”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 20,849
“Hospital units”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 27,731
“United States/epidemiology”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 57,481
“Personnel staffing and scheduling”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 5,335
“Models, nursing”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 4,544
“Foreign professional personnel”[MeSH] NOT review NOT letters NOT editorials Limits: English, humans | 1,375
“Nurses”[MeSH] NOT review NOT letters NOT editorials AND “patients”[MeSH] Limits: English, humans | 396
“Nurses”[MeSH] NOT review NOT letters NOT editorials AND “clinical competence” Limits: English, humans | 6
“Nurses”[MeSH] NOT review NOT letters NOT editorials AND “health care quality, access, and evaluation”[MeSH] Limits: English, humans | 49
“Nurses”[MeSH] NOT review NOT letters NOT editorials AND “health services research” Limits: English, humans | 2
“Nurses”[MeSH] NOT review NOT letters NOT editorials AND “outcome assessment (health care)” Limits: English, humans | 1
“Nurses”[MeSH] NOT review NOT letters NOT editorials AND “personnel administration, hospital” Limits: English, humans | 0
“Nurses”[MeSH] NOT review NOT letters NOT editorials AND “length of stay” Limits: English, humans | 2
“Nurses”[MeSH] NOT review NOT letters NOT editorials AND “patient satisfaction” Limits: English, humans | 2
“Nurses”[MeSH] NOT review NOT letters NOT editorials AND personnel staffing and scheduling Limits: English, humans | 2
“Epidemiologic studies”[MeSH] Limits: English, humans | 728,060
“Epidemiologic studies”[MeSH] AND “nurses”[MeSH] Limits: English, humans | 1,210
“Epidemiologic studies”[MeSH] AND “nursing staff, hospital”[MeSH] Limits: English, humans | 731
“Epidemiologic studies”[MeSH] AND “nursing administration research”[MeSH] Limits: English, humans | 99
“Epidemiologic studies”[MeSH] AND “nursing audit”[MeSH] Limits: English, humans | 210
“Epidemiologic studies”[MeSH] AND “nursing education research ”[MeSH] Limits: English, humans | 187
“Epidemiologic studies”[MeSH] AND “clinical competence”[MeSH] Limits: English, humans | 2,169
“Epidemiologic studies”[MeSH] AND “health care quality, access, and evaluation”[MeSH] Limits: English, humans | 728,210
“Epidemiologic studies”[MeSH] AND “health services research”[MeSH] AND “nurses”[MeSH] Limits: English, humans | 85
“Epidemiologic studies”[MeSH] AND “nurses”[MeSH] AND “outcome assessment (health care)”[MeSH] Limits: English, humans | 108
“Epidemiologic studies”[MeSH] AND “nurses”[MeSH] AND “personnel administration, hospital” [MeSH] Limits: English, humans | 0
“Epidemiologic studies”[MeSH] AND “nurses”[MeSH] AND “patients” [MeSH] Limits: English, humans | 23
“Epidemiologic studies”[MeSH] AND “nurses”[MeSH] AND “length of stay”[MeSH] Limits: English, humans | 38
“Epidemiologic studies”[MeSH] AND “nurses”[MeSH] AND “patient satisfaction”[MeSH] Limits: English, humans | 56
“Epidemiologic studies”[MeSH] AND “models, nursing” Limits: English, humans | 190
“Epidemiologic studies”[MeSH] AND “nursing staff, hospital”[MeSH] AND “safety management” Limits: English, humans | 1
“Nursing staff, hospital”[MeSH] AND “patients”[MeSH] Limits: English, humans | 506
“Nursing staff, hospital”[MeSH] AND “length of stay”[MeSH] Limits: English, humans | 192
“Nursing staff, hospital”[MeSH] AND “patient satisfaction”[MeSH] Limits: English, humans | 324
“Nursing staff, hospital”[MeSH] AND “safety management”[MeSH] Limits: English, humans | 188
“Safety management”[MeSH] AND “nursing administration research ”[MeSH] Limits: English, humans | 17
“Safety management”[MeSH] AND “nursing audit”[MeSH] Limits: English, humans | 18
“Safety management”[MeSH] AND “clinical competence”[MeSH] Limits: English, humans | 125
“Safety management”[MeSH] AND “health dare quality, access, and evaluation”[MeSH] Limits: English, humans | 3,253
“Safety management”[MeSH] AND “health services research”[MeSH] Limits: English, humans | 465
“Safety management”[MeSH] AND “outcome assessment (health care)”[MeSH] Limits: English, humans | 111
“Safety management”[MeSH] AND “models, nursing” Limits: English, humans | 27
“Outcome assessment (health care)”[MeSH] AND “nursing staff, hospital”[MeSH] Limits: English, humans | 344
CINAHL - Cumulative Index to Nursing & Allied Health Literature:
“Personnel staffing and scheduling” | 9,271
“Nursing staff, hospital/manpower” | 57
“Length of stay” | 5,269
“Patient safety” | 14,395
“Nurses” | 72,321
“Personnel staffing and scheduling” or “nursing staff, hospital/manpower” AND “length of stay” or “patient safety” | 1,025
“Personnel staffing and scheduling” or “nursing staff, hospital/manpower” AND “length of stay” or “patient safety” limit on English, NOT review or letter | 86
The Cochrane Library:
“Nursing staff, hospital” and “outcome assessment (health care)” | 0
“Nurse” AND “patient” | 4
BioMed Central:
“Nursing staff, hospital” AND “patient safety” | 0
“Nursing staff, hospital” AND “patient outcomes” | 0
Nursing staff, hospital AND health services research | 287
Nursing staff, hospital AND adverse events | 79
Google scholar: “nursing staff, hospital” AND “patient outcomes” NOT long-term care, published after 1990 | 1,700
[underlined: Catalog of U.S. Government Publications (U.S. GPO):]
Nursing Staff, Hospital | 9
LexisNexis™ Government Periodicals Index:
“Nurses and nursing” AND “Hospitals” | 25
Digital Dissertations:
Nurse AND patient | 1,863
Nursing staff, hospital | 0
Nurse AND staffing AND hospital AND patient | 20
Agency of Health Care Research and Quality:
Nurse staffing and Patient | 893

[underlined: Positive Likelihood of MeSH Terms and Keywords (*) to Identify Studies Eligible for Questions 1, 2, and 4]

Algorithm:

Sensitivity = TP/(TP+FN)

Specificity = TN/(FP+TN)

Positive Likelihood = SENS/(1-SPEC)

Negative Likelihood = (1-SENS)/SPEC

Study status | Eligible | Excluded | Total
Keyword Present | TP | FP
Keyword absent | FN | TN
| 96 | 2,762 | 2,858

A. Highest Positive Predictive Likelihood

MeSH terms and keywords | Sensitivity, % | Specificity, % | Positive Likelihood
*Burnout professional | 3.13 | 99.96 | 86.31
Decubitus ulcer/epidemiology | 6.25 | 99.93 | 86.31
Nurses/*supply & distribution | 3.13 | 99.96 | 86.31
United States Centers for Medicare and Medicaid Services | 5.21 | 99.93 | 71.93
Accidental falls s & numerical data | 9.38 | 99.86 | 64.73
*Mortality | 2.08 | 99.96 | 57.54
Comorbidity | 2.08 | 99.96 | 57.54
Medicare/*statistics & numerical data | 2.08 | 99.96 | 57.54
Nursing service | 2.08 | 99.96 | 57.54
Urinary tract infection | 2.08 | 99.96 | 57.54
California/epidemiology | 5.21 | 99.89 | 47.95
Health services research/methods | 3.13 | 99.93 | 43.16
*Anesthesiology | 1.04 | 99.96 | 28.77
*Economic competition | 1.04 | 99.96 | 28.77
*Economics | 1.04 | 99.96 | 28.77
*Outcome and process assessment (health care) | 5.21 | 99.82 | 28.77
Acquired immunodeficiency syndrome | 1.04 | 99.96 | 28.77
Bacteremia/epidemiology | 1.04 | 99.96 | 28.77
Bacteremia/epidemiology/etiology | 1.04 | 99.96 | 28.77
Burn units/*manpower | 1.04 | 99.96 | 28.77
Contract services/organization & administration | 1.04 | 99.96 | 28.77
Cross infection/*prevention & control | 2.08 | 99.93 | 28.77
Cross infection/epidemiology | 1.04 | 99.96 | 28.77
Cross infection/epidemiology/*etiology/ prevention & control | 1.04 | 99.96 | 28.77
Delivery of health care/*organization & administration | 1.04 | 99.96 | 28.77
Disease outbreak | 1.04 | 99.96 | 28.77
Economics hospital | 1.04 | 99.96 | 28.77
Education nursing | 1.04 | 99.96 | 28.77
Health maintenance organizations | 1.04 | 99.96 | 28.77
Health maintenance organizations *organization & administration | 1.04 | 99.96 | 28.77
Hospital restructuring | 1.04 | 99.96 | 28.77
Hospitals pediatric | 1.04 | 99.96 | 28.77
Hospitals university | 1.04 | 99.96 | 28.77
Hospitals urban | 1.04 | 99.96 | 28.77
Hospitals/*standards | 1.04 | 99.96 | 28.77
Hospitals/classification | 1.04 | 99.96 | 28.77
Hospitals/*standards/statistics & numerical data | 1.04 | 99.96 | 28.77
Iatrogenic disease | 1.04 | 99.96 | 28.77
Insurance claim | 1.04 | 99.96 | 28.77
Intensive care units neonatal/economics | 1.04 | 99.96 | 28.77
Intensive care units pediatric/*organization & administration | 1.04 | 99.96 | 28.77
Medicare | 2.08 | 99.93 | 28.77
Nurses' aides/supply & distribution | 2.08 | 99.93 | 28.77
Nursing staff hospital/*economics/organization & administration | 1.04 | 99.96 | 28.77
Nursing staff hospital/*education/*standards | 1.04 | 99.96 | 28.77
Nursing staff hospital/organization & administration/statistics | 1.04 | 99.96 | 28.77
Outcome assessment | 1.04 | 99.96 | 28.77
Pediatrics | 1.04 | 99.96 | 28.77
Pennsylvania/epidemiology | 1.04 | 99.96 | 28.77
Personnel management | 1.04 | 99.96 | 28.77
Pneumonia/epidemiology | 1.04 | 99.96 | 28.77
Postoperative complications/epidemiology | 1.04 | 99.96 | 28.77
Quality of health care | 1.04 | 99.96 | 28.77
Quality of health care/*classification | 1.04 | 99.96 | 28.77
Restraint physical | 1.04 | 99.96 | 28.77
Safety management | 1.04 | 99.96 | 28.77
Surgical procedures operative/*statistics & numerical data | 1.04 | 99.96 | 28.77
United States Agency for Healthcare Research and Quality | 1.04 | 99.96 | 28.77
Urinary tract infections/epidemiology/etiology | 1.04 | 99.96 | 28.77
Workload/ psychology | 2.08 | 99.93 | 28.77
Workload/standards | 2.08 | 99.93 | 28.77
*Hospital mortality | 13.54 | 99.49 | 26.72
Cross Infection/epidemiology | 3.13 | 99.86 | 21.58
Medication error | 6.25 | 99.71 | 21.58
Iatrogenic disease | 2.08 | 99.89 | 19.18
Morbidity | 2.08 | 99.89 | 19.18
Nursing care/psychology | 2.08 | 99.89 | 19.18
Probability | 2.08 | 99.89 | 19.18
Odds ratio | 5.21 | 99.67 | 15.98
United States/epidemiology | 14.58 | 99.02 | 14.92
*Educational standards | 1.04 | 99.93 | 14.39
*Treatment outcome | 1.04 | 99.93 | 14.39
Catheterization | 1.04 | 99.93 | 14.39
Databases factual | 1.04 | 99.93 | 14.39
Diagnosis related groups/statistics & numerical data | 1.04 | 99.93 | 14.39
Education nursing baccalaureate | 2.08 | 99.86 | 14.39
Hospital units/*organization & administration/ standards | 1.04 | 99.93 | 14.39
Hospitals public | 1.04 | 99.93 | 14.39
Hospitals teaching | 1.04 | 99.93 | 14.39
Length of stay/epidemiology | 1.04 | 99.93 | 14.39
Maryland | 2.08 | 99.86 | 14.39
Matched-pair analysis | 1.04 | 99.93 | 14.39
Minnesota/epidemiology | 1.04 | 99.93 | 14.39
Nursing service | 2.08 | 99.86 | 14.39
Nursing staff hospital | 1.04 | 99.93 | 14.39
Patient isolation | 1.04 | 99.93 | 14.39
Personnel hospital | 1.04 | 99.93 | 14.39
Referral and con | 1.04 | 99.93 | 14.39
Sentinel surveillance | 1.04 | 99.93 | 14.39
Workload/psychology | 1.04 | 99.93 | 14.39
*Outcome assessment (health care ) | 15.63 | 98.84 | 13.49
Nurses' aides/* | 2.08 | 99.82 | 11.51
*Education nursing | 1.04 | 99.89 | 9.59
Nursing staff hospital/*organization & administration/standards | 1.04 | 99.89 | 9.59
Accidental falls | 1.04 | 99.89 | 9.59
Chronic disease | 2.08 | 99.78 | 9.59
Health services research/*method | 1.04 | 99.89 | 9.59
Hospital costs/*statistics & numerical data | 1.04 | 99.89 | 9.59
Hospital restructuring | 1.04 | 99.89 | 9.59
Hospitals teaching/standards | 1.04 | 99.89 | 9.59
Hospitals teaching/statistics & numerical data | 1.04 | 99.89 | 9.59
Mortality | 1.04 | 99.89 | 9.59
Nursing assessment/organization & administration | 1.04 | 99.89 | 9.59
Nursing staff hospital/*organization & administration/*standard | 1.04 | 99.89 | 9.59
Nursing staff hospital/economic/psychology/* supply & distribution | 1.04 | 99.89 | 9.59
Ontario/epidemiology | 1.04 | 99.89 | 9.59
Patient discharge | 1.04 | 99.89 | 9.59
Personnel staffing and scheduling/*legislation & jurisprudence/*standards | 1.04 | 99.89 | 9.59
Personnel staffing and scheduling/*standards/ statistics & numerical data | 1.04 | 99.89 | 9.59
Poisson distribution | 1.04 | 99.89 | 9.59
Psychology industrial | 1.04 | 99.89 | 9.59
Quality of health care/standards | 1.04 | 99.89 | 9.59
Risk adjustment | 1.04 | 99.89 | 9.59
Statistics | 1.04 | 99.89 | 9.59
Personnel staffing and scheduling/*statistics & numerical data | 5.21 | 99.46 | 9.59
Multivariate analysis | 9.38 | 98.95 | 8.93
Diagnosis related | 3.13 | 99.64 | 8.63
*Quality indicators, health care | 5.21 | 99.38 | 8.46
Logistic models | 9.38 | 98.84 | 8.09
Pennsylvania | 4.17 | 99.46 | 7.67
Hospital mortality | 7.29 | 99.02 | 7.46
Continuity of patient care/standards | 1.04 | 99.86 | 7.19
Medication error | 1.04 | 99.86 | 7.19
Models theoretical | 1.04 | 99.86 | 7.19
Outcome and process assessment (health care)/*organization & | 1.04 | 99.86 | 7.19
Ownership | 1.04 | 99.86 | 7.19
Patient education | 1.04 | 99.86 | 7.19
Patient readmission | 1.04 | 99.86 | 7.19
Personnel staffing and scheduling/economics/* standards | 1.04 | 99.86 | 7.19
Personnel staffing and scheduling/statistics & numerical data/*trends | 1.04 | 99.86 | 7.19
Risk | 1.04 | 99.86 | 7.19
Administration/utilization | 1.04 | 99.86 | 7.19
Acute disease/nursing | 3.13 | 99.57 | 7.19
Linear models | 3.13 | 99.53 | 6.64
Research support | 23.96 | 96.16 | 6.24
Research support | 4.17 | 99.31 | 6.06
*Licensure nursing | 1.04 | 99.82 | 5.75
American Hospital Association | 1.04 | 99.82 | 5.75
Confidence intervals | 1.04 | 99.82 | 5.75
Feasibility studies | 1.04 | 99.82 | 5.75
Hospital bed capacity | 1.04 | 99.82 | 5.75
Least-squares analysis | 1.04 | 99.82 | 5.75
Likelihood function | 1.04 | 99.82 | 5.75
Medical staff hospital/statistics & numerical data | 1.04 | 99.82 | 5.75
Nurses | 1.04 | 99.82 | 5.75
Nursing staff hospital/*standards/supply & distribution | 1.04 | 99.82 | 5.75
Population surveillance | 1.04 | 99.82 | 5.75
Postoperative care | 1.04 | 99.82 | 5.75
Proportional hazard | 1.04 | 99.82 | 5.75
Salaries and fringes | 1.04 | 99.82 | 5.75
Tennessee | 1.04 | 99.82 | 5.75
Health care survey | 6.25 | 98.91 | 5.75
Benchmarking | 4.17 | 99.28 | 5.75
Case-control study | 4.17 | 99.24 | 5.48
Outcome and process assessment (health care) | 3.13 | 99.42 | 5.39
Sampling studies | 2.08 | 99.60 | 5.23
Workload/*statistics | 2.08 | 99.60 | 5.23
Midwestern United States | 3.13 | 99.38 | 5.08
Health services | 10.42 | 97.94 | 5.05

B. MeSH Terms and Keywords in Eligible Studies (Sensitivity >0)

MeSH terms | Sensitivity | Specificity | Positive Predictive Likelihood
*Models statistics | 1.04 | 99.78 | 4.80
Alberta | 1.04 | 99.78 | 4.80
Critical pathway | 1.04 | 99.78 | 4.80
District of Columbia | 1.04 | 99.78 | 4.80
Nursing staff hospital/*legislation & jurisprudence/*supply & | 1.04 | 99.78 | 4.80
Patient care planning | 1.04 | 99.78 | 4.80
Patients | 1.04 | 99.78 | 4.80
Length of stay | 10.42 | 97.79 | 4.72
Regression analysis | 9.38 | 97.97 | 4.62
Intensive care units | 4.17 | 99.09 | 4.60
Length of stay/standards | 5.21 | 98.84 | 4.50
Quality indicators health care | 4.17 | 99.06 | 4.43
Hospital bed capacity | 2.08 | 99.53 | 4.43
Length of stay/economics | 2.08 | 99.53 | 4.43
Cohort studies | 3.13 | 99.28 | 4.32
*Patients | 1.04 | 99.75 | 4.11
Bed occupancy | 1.04 | 99.75 | 4.11
Consumer satisfaction | 1.04 | 99.75 | 4.11
Hospital costs/standards | 1.04 | 99.75 | 4.11
Hospital-patient relations | 1.04 | 99.75 | 4.11
Hospitalization | 1.04 | 99.75 | 4.11
Intensive care units/*organization & administration | 1.04 | 99.75 | 4.11
Medical errors | 1.04 | 99.75 | 4.11
Patient satisfaction | 1.04 | 99.75 | 4.11
Southeastern union | 1.04 | 99.75 | 4.11
Nursing supervisory | 2.08 | 99.49 | 4.11
American Nurses' Association | 2.08 | 99.46 | 3.84
Personnel turnover | 2.08 | 99.46 | 3.84
Outcome assessment (health care) | 9.38 | 97.54 | 3.81
*Length of stay | 1.04 | 99.71 | 3.60
*Models organizational | 1.04 | 99.71 | 3.60
Choice behavior | 1.04 | 99.71 | 3.60
Forms and records | 1.04 | 99.71 | 3.60
Nurses' aides/*organization & administration | 1.04 | 99.71 | 3.60
Safety | 2.08 | 99.42 | 3.60
Risk assessment | 2.08 | 99.38 | 3.38
*Patient care team | 1.04 | 99.67 | 3.20
Education nursing | 1.04 | 99.67 | 3.20
Hospital bed cap | 1.04 | 99.67 | 3.20
Hospitals public | 1.04 | 99.67 | 3.20
Medical staff hospital/standard | 1.04 | 99.67 | 3.20
Missouri | 1.04 | 99.67 | 3.20
Nursing staff hospital/education*organization | 1.04 | 99.67 | 3.20
Physician-nurse relations | 1.04 | 99.67 | 3.20
Hospital restructuring/*organization & administration | 2.08 | 99.35 | 3.20
Patient satisfaction/*statistics & numerical data | 2.08 | 99.35 | 3.20
Predictive value | 3.13 | 98.99 | 3.08
Risk factors | 15.63 | 94.71 | 2.96
*Intensive care | 1.04 | 99.64 | 2.88
*Personnel staff | 1.04 | 99.64 | 2.88
Health policy | 1.04 | 99.64 | 2.88
Nursing care/*organization | 1.04 | 99.64 | 2.88
Nursing service | 1.04 | 99.64 | 2.88
Safety management | 1.04 | 99.64 | 2.88
Administration/standards | 1.04 | 99.64 | 2.88
*Quality of health care | 10.42 | 96.16 | 2.71
Quality of health care | 8.33 | 96.92 | 2.71
Nursing administration research | 14.58 | 94.61 | 2.70
Severity of illness | 4.17 | 98.44 | 2.68
*Efficiency organization | 1.04 | 99.60 | 2.62
Hospitals/*standards | 1.04 | 99.60 | 2.62
Length of stay/*statistics & numerical data | 1.04 | 99.60 | 2.62
Stress psychological | 1.04 | 99.60 | 2.62
Personnel staffing and scheduling/standards | 3.13 | 98.77 | 2.54
Personnel turnover | 3.13 | 98.73 | 2.47
Acute disease | 2.08 | 99.13 | 2.40
*Clinical competition | 3.13 | 98.70 | 2.40
Clinical nursing | 1.04 | 99.57 | 2.40
Connecticut | 1.04 | 99.57 | 2.40
Night care/*manpower | 1.04 | 99.57 | 2.40
Nursing staff hospital/psychology/supply & distribution | 1.04 | 99.57 | 2.40
Numerical data | 2.08 | 99.09 | 2.30
Nursing care/*standards | 3.13 | 98.62 | 2.27
*Quality assurance health care | 1.04 | 99.53 | 2.21
Absenteeism | 1.04 | 99.53 | 2.21
Nursing staff hospital/organization & administration | 1.04 | 99.53 | 2.21
Pain measurement | 1.04 | 99.53 | 2.21
Case management | 1.04 | 99.49 | 2.06
Nursing care/statistics | 1.04 | 99.49 | 2.06
Outcome assessment | 1.04 | 99.49 | 2.06
Nursing staff hospital/economic | 2.08 | 98.91 | 1.92
Internal-external control | 1.04 | 99.46 | 1.92
Organizational case studies | 1.04 | 99.46 | 1.92
Prevalence | 2.08 | 98.88 | 1.86
*Nursing staff | 1.04 | 99.42 | 1.80
Total quality management | 1.04 | 99.42 | 1.80
Treatment outcome | 2.08 | 98.81 | 1.74
Costs and cost assessment | 1.04 | 99.38 | 1.69
Patient discharge | 1.04 | 99.38 | 1.69
Health services | 2.08 | 98.73 | 1.64
Models organizational | 2.08 | 98.73 | 1.64
Ontario | 2.08 | 98.73 | 1.64
*Personnel management | 1.04 | 99.35 | 1.60
Nursing research | 1.04 | 99.35 | 1.60
Nursing staff hospital/*supply distribution | 16.67 | 89.54 | 1.59
Aged | 14.58 | 90.55 | 1.54
Pilot projects | 4.17 | 97.28 | 1.53
Personnel staffing and scheduling/*standards | 7.29 | 95.22 | 1.53
*Occupational health | 1.04 | 99.31 | 1.51
Evidence-based | 1.04 | 99.31 | 1.51
Hospital costs | 1.04 | 99.31 | 1.51
Statistics nonparametric | 1.04 | 99.31 | 1.51
Incidence | 2.08 | 98.59 | 1.48
*Professional autonomy | 1.04 | 99.28 | 1.44
Hospital bed capacity | 1.04 | 99.28 | 1.44
Hospital units | 1.04 | 99.28 | 1.44
Research support | 23.96 | 83.09 | 1.42
*Leadership | 1.04 | 99.24 | 1.37
Educational status | 1.04 | 99.24 | 1.37
Distribution | 3.13 | 97.68 | 1.35
Retrospective studies | 5.21 | 96.13 | 1.34
Risk management | 1.04 | 99.20 | 1.31
Administration | 1.04 | 99.20 | 1.31
Prospective studies | 7.29 | 94.28 | 1.27
California | 3.13 | 97.54 | 1.27
Workload | 7.29 | 94.24 | 1.27
*Decision making | 1.04 | 99.17 | 1.25
Analysis of variance | 3.13 | 97.50 | 1.25
Data | 1.04 | 99.17 | 1.25
Michigan | 1.04 | 99.13 | 1.20
Longitudinal studies | 3.13 | 97.36 | 1.18
Nurse-patient relations | 4.17 | 96.45 | 1.17
Organizational innovation | 4.17 | 96.45 | 1.17
Age 80 and over | 4.17 | 96.38 | 1.15
Male | 25.00 | 78.17 | 1.15
Job satisfaction | 6.25 | 94.42 | 1.12
Quality assurance | 1.04 | 99.06 | 1.11
administration/psychology | 1.04 | 99.06 | 1.11
Patient satisfaction | 6.25 | 94.32 | 1.10
United States | 15.63 | 85.37 | 1.07
Cross-sectional | 7.29 | 93.16 | 1.07
Cost control | 1.04 | 98.99 | 1.03
Patient care team | 1.04 | 98.99 | 1.03
Time factors | 4.17 | 95.87 | 1.01
Factor analysis | 1.04 | 98.95 | 0.99
Power (psychology) | 1.04 | 98.95 | 0.99
*Patient satisfaction | 4.17 | 95.80 | 0.99
Canada | 1.04 | 98.91 | 0.96
Nursing evaluation on research | 6.25 | 93.41 | 0.95
Middle age | 14.58 | 84.43 | 0.94
Nurse administrators | 1.04 | 98.88 | 0.93
Texas | 1.04 | 98.88 | 0.93
Female | 25.00 | 72.88 | 0.92
Evaluation studies | 1.04 | 98.84 | 0.90
Personnel staffing and scheduling | 7.29 | 91.64 | 0.87
Child | 4.17 | 95.22 | 0.87
Data collection | 2.08 | 97.57 | 0.86
*Job satisfaction | 3.13 | 96.31 | 0.85
*Inpatients | 1.04 | 98.77 | 0.85
*Personnel staff | 7.29 | 91.24 | 0.83
Cost-benefit | 1.04 | 98.62 | 0.76
Humans | 71.88 | 2.75 | 0.74
Efficiency organization | 1.04 | 98.59 | 0.74
Comparative study | 6.25 | 90.84 | 0.68
Adult | 14.58 | 77.62 | 0.65
Infant | 1.04 | 98.37 | 0.64
Medical staff hospital | 1.04 | 98.33 | 0.63
Nursing audit | 1.04 | 98.30 | 0.61
Attitude of health | 5.21 | 91.31 | 0.60
Child preschool | 1.04 | 98.23 | 0.59
Inpatients/*psychology | 1.04 | 98.19 | 0.58
Job description | 1.04 | 98.12 | 0.55
Organizational care | 2.08 | 96.20 | 0.55
Professional autonomy | 1.04 | 98.04 | 0.53
Reproducibility | 1.04 | 98.04 | 0.53
Adolescent | 2.08 | 96.05 | 0.53
Hospitals teach | 1.04 | 97.97 | 0.51
*Nursing staff hospital | 4.17 | 91.67 | 0.50
Nurse's role | 2.08 | 95.58 | 0.47
*Nurse's role | 1.04 | 97.72 | 0.46
Personnel staffing and scheduling/*organization & administration | 3.13 | 93.12 | 0.45
Personnel staffing and scheduling/*legislation & jurisprudence | 1.04 | 97.61 | 0.44
Social support | 1.04 | 97.61 | 0.44
Clinical competence | 1.04 | 97.57 | 0.43
*Models nursing | 2.08 | 95.11 | 0.43
Clinical compete | 1.04 | 97.47 | 0.41
Questionnaires | 6.25 | 82.48 | 0.36
Infant newborn | 1.04 | 97.07 | 0.36
Interprofessional relations | 1.04 | 96.85 | 0.33
Needs assessment | 1.04 | 96.02 | 0.26
Models nursing | 1.04 | 95.37 | 0.22

C. MeSH Terms and Keywords in Excluded Studies (Sensitivity = 0)

MeSH Terms

*Absenteeism

*Accidental fall

*Accidental falls/economics

*Accidents

*Accidents occupational

*Accidents occupational/prevention & control/statistics & numerical data

*Accreditation

*Aftercare/statistics & numerical data

*Allied health personnel

*American Nurses Association

*Ancillary services hospital/statistics & numerical data

*Automatic data processing

*Automation

*Bed occupancy

*Bed occupancy/economics

*Benchmarking

*Bereavement

*Burnout professional/epidemiology/etiology/psychology

*Burnout professional/etiology/prevention & control

*Burnout professional/etiology/ prevention & control/psychology

*Burnout professional/prevention & control/psychology

*Caregivers

*Case management

*Cause of death

*Clinical nursing research

*Clinical protocols

*Communication

*Communication barriers

*Consumer satisfaction

*Continuity of patient care

*Contract services

*Contract services/economics

*Cost of illness

*Cost-benefit analysis

*Counseling/education/standards

*Credentialing

*Cross infection

*Cross infection/nursing/transmission/virology

*Cross-cultural comparison

*Data collection

*Data interpretation statistical

*Death

*Decision making

*Decision support

*Decision support systems management

*Decision support techniques

*Decision trees

*Delivery of health care

*Diagnosis-related groups

*Diagnostic errors

*Disease transmission professional-to-patient

*Documentation

*Drug combinations

*Drug compounding

*Drug delivery systems

*Drug labeling

*Drug therapy computer-assisted

*Economics hospital

*Economics nursing

*Education medical continuing

*Education nursing baccalaureate

*Education nursing continuing

*Educational measurement

*Efficiency

*Emergency medicine/organization & administration*emergency nursing

*Emergency nursing/organization & administration

*Emergency service hospital

*Emergency service hospital/organization & administration

*Employee discipline

*Employee incentive plans

*Employee performance appraisal

*Employment

*Episode of care

*Ethics

*Ethics business

*Ethics clinical

*Ethics institutional

*Ethics nursing

*Evidence-based medicine

*Expert testimony/*legislation & jurisprudence

*Foreign professional personnel

*Foreign professional personnel/education/psychology

*Foreign professional personnel/standards

*Health care rationing

*Health care reform

*Health care surveys

*Health education

*Health education/methods

*Health facility closure

*Health facility environment

*Health facility environment/ethics/organization & administration*health facility merger

*Health knowledge attitudes practice

*Health manpower

*Health services accessibility

*Health services needs and demand

*Health services statistics & numerical data

*Health services research

*Hospital administration

*Hospital communication systems/organization & administration

*Hospital costs

*Hospital design and construction*hospital information systems

*Hospital information systems/organization & administration

*Hospital restructuring

*Hospital units

*Hospital-patient relations

*Hospitalization

*Hospitalization/economics

*Hospitalization/statistics & numerical data

*Hospitals

*Infection control practitioners

*Inpatients/education/psychology

*Inpatients/psychology

*Inpatients/psychology/statistics & numerical data

*Intensive care units/manpower

*Intensive care units/statistics

*Interpersonal relations

*Inter professional relations

*Joint Commission on Accreditation of Healthcare Organizations

*Labor unions

*Labor unions/trends

*Legislation hospital

*Legislation nursing

*Length of stay/legislation & jurisprudence/statistics & numerical data

*Liability legal

*Linear models

*Malpractice

*Medical errors/adverse effects

*Medical staff hospital

*Medical staff hospital/education/psychology

*Medical staff hospital/psychology/statistics & numerical data

*Medication errors/adverse effects

*Medication errors/classification

*Medication errors/methods/nursing/prevention & control/statistics &

*Medication errors/statistics & numerical data

*Models nursing

*Models organizational

*Monitoring intra operative/methods/nursing

*Nurse administrators

*Nurse administrators/education/psychology

*Nurse administrators/organization & administration/psychology

*Nurse practitioners

*Nurse practitioners/economics

*Nurse's role/psychology

*Nurse-patient relations

*Nurseries hospital

*Nurses

*Nurses' aides

*Nurses' aides/education

*Nurses' aides/education/organization & administration/psychology*nursing

*Nursing administration research

*Nursing assessment

*Nursing assessment/methods/standards

*Nursing audit

*Nursing care

*Nursing care/manpower

*Nursing care/organization & administration/psychology

*Nursing care/psychology/standards

*Nursing care/psychology/statistics & numerical data

*Nursing diagnosis

*Nursing methodology research

*Nursing process

*Nursing process/standards

*Nursing records

*Nursing research

*Nursing service hospital

*Nursing staff

*Nursing staff hospital

*Nursing staff hospital/economics/standards

*Nursing staff hospital/economics statistics & numerical data

*Nursing staff hospital/economics/supply & distribution

*Nursing staff hospital/education

*Nursing staff hospital/education/organization

*Nursing staff hospital/education/organization & administration

*Nursing staff hospital/education/psychology

*Nursing staff hospital/education/psychology/supply & distribution

*Nursing staff hospital/education/standards

*Nursing staff hospital/education/supply & distribution

*Nursing staff hospital/legislation & jurisprudence/supply & distribution

*Nursing staff hospital/organization & administration/standards

*Nursing staff hospital/organization & administration/statistics &

*Nursing staff hospital/organization & administration/supply &

*Nursing staff hospital/psychology

*Nursing staff hospital/psychology/standards

*Nursing staff hospital/psychology/statistics & numerical data

*Nursing staff hospital/psychology/supply & distribution

*Nursing staff hospital/statistics & numerical data

*Nursing staff hospital/supply & distribution

*Nursing staff hospital/utilization

*Nursing staff/education/organization & administration/psychology

*Nursing theory

*Nursing practice

*Nursing supervisory

*Nursing team

*Nutrition assessment

*Nutrition/education

*Outcome assessment (health care)/economics (health care)

*Outcome and process assessment (health care)/methods

*Outcome and process assessment (health care)/statistics & numerical data

*Personnel administration hospital

*Personnel management/*methods

*Personnel selection

*Personnel selection/*organization & administration

*Personnel selection/trends

*Personnel staffing and scheduling/*legislation & jurisprudence

*Personnel staffing and scheduling/ economics/legislation &

*Personnel staffing and scheduling/legislation & jurisprudence

*Personnel staffing and scheduling/organization

*Personnel staffing and scheduling/organization & administration

*Personnel staffing and scheduling/standards

*Personnel staffing and scheduling/statistics & numerical data

*Personnel turnover

*Personnel turnover/statistics & numerical data

*Personnel turnover/statistics & numerical data/ trends

*Professional-patient relations

*Program development

*Program evaluation

*Programmed instruction/standards

*Progressive patient care

*Qualitative research

*Quality indicators health care/standards

*Quality of health care/legislation & jurisprudence

*Quality of health care/legislation & jurisprudence/statistics & numerical

*Quality of life

*Restraint physical

*Restraint physical/adverse effects

*Resuscitation

*Risk assessment

*Risk management

*Risk management/methods/organization & administration

*Safety

*Safety management

*Salaries and fringe benefits

*Staff development

*Staff development/methods

*Total quality management

*Work schedule tolerance

*Work schedule tolerance/psychology

*Workload

*Workload/economics

*Workload/psychology

*Workload/statistics & numerical data

*Workplace

*Workplace/organization & administration/psychology

*Workplace/psychology

Academic medical centers/*manpower

Academic medical centers/*organization & administration

Academic medical centers/*organization & administration/*statistics &

Academic medical centers/economics/*manpower/organization & administration

Academic medical centers/economics/standards/statistics & numerical data

Academic medical centers/manpower

Access to information/*legislation & jurisprudence

Accidental falls/*prevention & control

Accidental falls/* statistics & numerical data

Accidental falls/economics/statistics & numerical data

Accidental falls/prevention & control

Accidental falls/prevention & control/*statistic/prevention & control/*statistics & numerical data

Accidental falls/prevention & control/*statistic/*statistics & numerical data

Accidents occupational/*prevention & control

Accidents occupational/*statistics & numerical data

Accidents occupational/economics/*prevention & control/statistics

Accidents occupational/economics/prevention & control/*statistics

Accidents occupational/prevention & control

Accidents/*statistics & numerical data

Accreditation

Accreditation/*legislation & jurisprudence

Accreditation/*methods

Accreditation/*standards

Administrative personnel

Adverse drug reaction reporting systems

Adverse drug reaction reporting systems/*statistics & numerical data

Adverse drug reaction reporting

Systems/*utilization

Adverse drug reaction reporting systems/standard

Adverse drug reaction reporting

Systems/statistics & numerical data

Adverse drug reaction reporting systems/utilization

Allied health personnel

Allied health personnel/*psychology

Allied health personnel/*supply & distribution

Allied health personnel/*utilization

Allied health personnel/economics/statistics & numerical data

Allied health personnel/organization & administration

Allied health personnel/psychology

Allied health personnel/standards/supply & distribution

Allied health personnel/statistics & numerical data/supply & distribution

Allied health personnel/supply & distribution

American Nurses' Association/organization & administration

Analgesia/*nursing

Analgesia/methods/*nursing

Analgesia/nursing/*standards

Analgesia/nursing/*utilization

Ancillary services hospital/*trends

Ancillary services

Bed occupancy/classification

Bed occupancy/economics

Bed occupancy/statistics & numerical data

Bed rest/*adverse effects/nursing

Bed rest/adverse effects/nursing

Benchmarking/*methods

Benchmarking/*methods/standards

Benchmarking/*organization & administration

Benchmarking/methods

Benchmarking/organization & administration

Benchmarking/standards

Burnout professional

Burnout professional/*diagnosis/*psychology

Burnout professional/*epidemiology/*psychology

Burnout professional/*epidemiology

Burnout professional/*etiology

Burnout professional/*etiology/psychology

Burnout professional/*etiology/psychology

Burnout professional/*prevention & control

Burnout professional/*prevention & control/*psychology

Burnout professional/*prevention & control/psychology

Burnout professional/*psychology

Burnout professional/classification/diagnosis/etiology/*prevention

Burnout professional/complications/*epidemiology

Burnout professional/diagnosis/*epidemiology/prevention &

Burnout professional/diagnosis/*epidemiology/psychology

Burnout professional/diagnosis/epidemiology/*psychology

Burnout professional/diagnosis/epidemiology/psychology

Burnout professional/diagnosis/etiology/*prevention & control

Burnout professional/diagnosis/etiology/prevention & control/*psychology

Burnout professional/diagnosis/physiopathology/*prevention &

Burnout professional/epidemiology

Burnout professional/epidemiology/*etiology

Burnout professional/epidemiology/etiology/*psychology

Burnout professional/epidemiology/etiology/prevention &

Burnout professional/epidemiology/etiology/psychology

Burnout professional/epidemiology/psychology

Burnout professional/etiology/prevention & control

Burnout professional/etiology/prevention & control/psychology

Burnout professional/etiology/psychology

Burnout professional/prevention control

Burnout professional/prevention & control/*psychology

Burnout professional/prevention & control/psychology

Burnout professional/psychology

Cardiac surgical procedures/*adverse effects/*nursing

Cardiac surgical procedures/*nursing

Cardiac surgical procedures/*nursing/standards

Cardiac surgical procedures/adverse effects/mortality/*nursing

Cardiac surgical procedures/economics/*nursing

Cardiac surgical procedures/nursing

Cardiology service hospital/*manpower

Cardiology service hospital/economics/manpower/*organization &

Cardiopulmonary resuscitation/*education/*methods/nursing

Cardiopulmonary resuscitation/education/*nursing

Cardiovascular diseases/*nursing

Case management

Case management/*trends

Case management/organization & administration*

Causality

Cause of death

Censuses

Centralized hospital services

Centralized hospital services/*organization & administration

Cerebrovascular accident/*nursing/rehabilitation

Cerebrovascular accident/classification/nursing

Cerebrovascular accident/nursing

Cerebrovascular disorders/*nursing

Cerebrovascular disorders/*nursing/*rehabilitation

Cerebrovascular disorders/*nursing/rehabilitation

Certificate of need/legislation & jurisprudence

Certification/*organization & administration

Certification/*standards

Cesarean section/*nursing/psychology

Clinical competence/*legislation & jurisprudence/*standards

Clinical competence/*legislation & jurisprudence/standards

Clinical competence/*standards

Clinical competence/*statistics & numerical data

Clinical competence/legislation & jurisprudence

Clinical competence/legislation & jurisprudence/*standards

Clinical competence/legislation & jurisprudence/standards

Clinical competence/standards/*statistics & numerical data

Clinical competence/statistics & numerical data

Clinical nursing research/*methods

Clinical nursing research/*organization & administration

Clinical nursing research/method

Clinical nursing research/organization & administration/*standards

Clinical protocols

Clinical protocols/standards

Collective bargaining

Collective bargaining/*legislation & jurisprudence

Collective bargaining/*organization & administration

Collective bargaining/organization & administration

Confounding factors (epidemiology)

Confusion/*nursing

Confusion/*nursing/psychology

Confusion/etiology/nursing/*psychology

Conscious sedation/*nursing

Conscious sedation/adverse effects/*nursing

Conscious sedation/nursing/*psychology

Consumer satisfaction/*statistics & numerical data

Continuity of patient care

Continuity of patient care/*organization & administration

Continuity of patient care/*standards

Continuity of patient care/organization & administration

Continuity of patient care/organization & administration/statistics &

Contract services

Contract service/*organization & administration

Contract services/*standards

Contract services/legislation & jurisprudence

Contract services/statistics & numerical data/*utilization

Contracts

Coronary disease/*nursing

Coronary disease/*nursing/surgery

Cost control/methods

Cost control/trends

Cost of illness

Costs and cost analysis/*methods

Costs and cost analysis/economics

Costs and cost analysis/statistics & numerical data

Critical care/*manpower/methods

Critical care/*manpower/standard

Critical care/*methods

Critical care/*organization & administration

Critical care/economics/*manpower

Critical pathways

Critical pathway/*standards

Cross infection/*epidemiology/*etiology

Cross infection/*epidemiology/microbiology

Cross infection/*epidemiology/transmission

Cross infection/*microbiology

Cross infection/diagnosis/drug therapy/*prevention & control/*transmission

Cross infection/economics/*epidemiology/*etiology/prevention & control

Cross infection/epidemiology/*microbiology/*transmission

Cross infection/epidemiology/*microbiology/prevention &

Cross infection/epidemiology/*microbiology/transmission

Cross infection/epidemiology/*prevention & control

Cross infection/epidemiology/*prevention & control/virology

Cross infection/epidemiology/etiology/*prevention & control

Cross infection/epidemiology/microbiology/*prevention &

Cross infection/epidemiology/microbiology/*transmission

Cross infection/etiology

Cross infection/etiology/*prevention & control

Cross infection/microbiology/*prevention &

Cross infection/microbiology/*prevention & control/transmission

Cross infection/mortality/*prevention & control

Cross infection/nursing/*prevention & control/*psychology

Cross infection/prevention & control

Cross infection/prevention & control/*transmission

Data collection

Data collection/*methods/*standards

Data collection/ methods/standards

Data collection/*methods/standards/*statistics & numerical data

Data collection/methods

Data collection/ methods/*standards

Data collection/methods/standards

Data display

Data interpretation statistical/statistics & numerical data

Day care/manpower/*organization & administration/statistics & numerical

Decision making

Organizational decubitus ulcer *classification/nursing/pathology

Decubitus ulcer/*economics/epidemiology/*therapy

Decubitus ulcer/*epidemiology/*prevention & control

Decubitus ulcer/*etiology/*prevention & control

Decubitus ulcer/*etiology/nursing/*prevention & control

Decubitus ulcer/*nursing

Decubitus ulcer/*nursing/*psychology

Decubitus ulcer/*prevention & control

Decubitus ulcer/economics/ epidemiology/*prevention & control

Decubitus ulcer/epidemiology/etiology

Decubitus ulcer/epidemiology/etiology/*prevention & control

Decubitus ulcer/etiology

Decubitus ulcers/prevention & control

Decubitus ulcer/etiology/*prevention & control

Decubitus ulcer/nursing/*prevention & control

Delivery of health care

Delivery of health care integrated

Delivery of health care integrated/*manpower

Delivery of health care integrated/*organization & administration

Delivery of health care integrated/*standards

Delivery of health care integrated/organization & administration

Delivery of health care/*economics

Delivery of health care/*history

Delivery of health care/*manpower

Delivery of health care/*standards

Delivery of health care/economics/standards/*trends

Delivery of health care/organization & administration

Delivery obstetric/*methods

Delivery obstetric/*nursing/statistics & numerical data

Diabetes mellitus/*nursing

Diagnosis-related groups/*classification

Direct service costs/*statistics & numerical data

Direct service costs/statistics & numerical data

Disease management

Disease outbreaks/*prevention & control/statistics & numerical data

Disease transmission professional-to-patient

Disease transmission professional-to-patient/*prevention & control

Disease transmission professional-to-patient/*statistics & numerical data

Disease transmission professional-to-patient/prevention & control

Disease transmission professional-to-patient/statistics & numerical data

Drug administration schedule

Drug monitoring/*nursing

Drug monitoring/nursing/standards

Drug monitoring/methods/nursing

Drug monitoring/nursing/standards

Economics nursing education continuing

Education continuing/*methods

Education nursing associate/*trends

Education nursing baccalaureate/*methods

Education nursing baccalaureate/*organization & administration

Education nursing baccalaureate/*standards

Education nursing baccalaureate/*trends

Education nursing baccalaureate/standards

Education nursing baccalaureate/statistics & numerical data

Education nursing continuing

Education nursing continuing/*manpower

Education nursing continuing/*methods

Education nursing continuing/*organization & administration

Education nursing continuing/*standards

Education nursing continuing/methods

Education nursing continuing/methods/*standard

Education nursing continuing/organization & administration

Education nursing continuing/standards

Education nursing continuing/statistics & numerical data

Education nursing diploma programs

Education nursing diploma programs/*standards

Education nursing graduate/*manpower

Education nursing graduate/*organization & administration

Education nursing graduate/*trends

Education nursing/*organization & administration

Education nursing/*statistics & numerical data

Education nursing/economics

Education nursing/economics/legislation & jurisprudence

Education nursing/history

Education nursing/methods

Education nursing/standards

Education nursing/standards/trends

Education nursing/trends

Efficiency organizational/standards

Emergencies/*nursing

Emergency nursing

Emergency nursing/*education

Emergency nursing/*education/*methods

Emergency nursing/*education/standards

Emergency nursing/*manpower

Emergency nursing/*methods

Emergency nursing/*methods/standards

Emergency nursing/*organization & administration

Nursing/*standards

Emergency nursing/*standards/trends

Emergency nursing/*statistics & numerical data

Emergency nursing/education/*methods

Emergency nursing/education/*methods/standards

Emergency nursing/education/*organization & administration

Emergency nursing/education/*standards

Emergency nursing education/organization & administration

Emergency nursing/manpower

Emergency nursing/manpower/*standards

Emergency nursing/manpower/standards

Emergency nursing/standards

Emergency service hospital/economics/*manpower

Emergency service hospital/economics/*manpower/organization &

Employee discipline

Employee performance appraisal/*methods/standards

Employment/*legislation & jurisprudence

Employment/*organization & administration

Employment/*psychology

Epidemiologic studies

Ethics nursing evidence-based medicine/*organization & administration

Evidence-based medicine/organization & administration

Evidence-based medicine/standards

Foreign medical graduates

Foreign medical graduates/*legislation & jurisprudence/supply &

Foreign medical graduates/psychology/statistics & numerical data

Foreign professional personnel

Foreign professional personnel/*education

Foreign professional personnel/*education/*psychology/supply &

Foreign professional personnel/*education/psychology

Foreign professional personnel/*education/psychology/supply & distribution

Foreign professional personnel/*education/supply & distribution

Foreign professional personnel/*history

Foreign professional personnel/*legislation & jurisprudence

Foreign professional personnel/*legislation & jurisprudence/supply &

Foreign professional personnel/*psychology

Foreign professional personnel/*psychology/supply & distribution

Foreign professional personnel/*standards

Foreign professional personnel/*supply & distribution

Foreign professional personnel/*utilization

Foreign professional personnel/education

Foreign professional personnel/education/*psychology

Foreign professional personnel/education/*psychology/supply & distribution

Foreign professional personnel/education/*supply& distribution

Foreign professional personnel/education/legislation &

Foreign professional personnel/education/psychology/*supply & distribution

Foreign professional personnel/legislation & jurisprudence/supply

Foreign professional personnel/standards

Foreign professional personnel/standards/statistics & numerical

Foreign professional personnel/supply & distribution

Foreign professional personnel/utilization

Government agencies

Government agencies/organization & administration

Government regulation

Guideline adherence/*standards

Health care coalitions/*organization & administration

Health care costs

Health care costs/standards

Health care costs/statistics & numerical data

Health care rationing

Health care rationing/*methods

Health care rationing/*organization & administration

Health care reform

Health care reform/*organization & administration

Health care reform/*trends

Health care reform/economics/*standards

Health care reform/organization & administration

Health care reform/trends

Health care sector

Health care sector/trends

Health insurance portability and accountability act

Health insurance portability and accountability act/legislation

Health maintenance organizations/manpower

Health manpower

Health manpower/*classification/statistics & numerical data

Health manpower/*economics

Health manpower/*statistics & numerical data/trends

Health manpower/*trends

Health manpower/statistics & numerical data/*trends

Health manpower/trends

Health personnel/*education

Health services accessibility/*organization & administration

Health services accessibility/*standards

Health services accessibility/economics/standards

Health services accessibility/organization & administration

Health services accessibility/standards/*statistics & numerical data

Health services misuse/*statistics & numerical data

Health services misuse/economics/*statistics & numerical data

Health services needs and demand/*organization & administration

Health services needs and demand*statistics & numerical data

Health services needs and demand/trends

Health services research/*methods/*standards

Health services research/*organization & administration

Heart arrest/nursing

Heart diseases/nursing

Heart failure congestive/*nursing

Heart failure congestive/classification/nursing

Heart failure congestive/complications/*nursing

Holistic nursing/*education/*organization & administration

Holistic nursing/*organization & administration

Holistic nursing/*standards

Holistic nursing/education/*standards

Holistic nursing/methods/*standards

Hospital administration

Hospital administration*/economics

Hospital administration*/standards

Hospital administration/*economics/*legislation & jurisprudence

Hospital administration/*methods

Hospital administration/*organization & administration

Hospital administration/economic

Hospital administration/education

Hospital administration/manpower/*statistics & numerical data

Hospital administration/methods

Hospital administrators

Hospital administrators/*organization & administration

Hospital administrators/*supply & distribution

Hospital administrators/organization & administration/psychology

Hospital administrators/psychology/*supply & distribution

Hospital administrators/supply & distribution

Hospital departments/*organization & administration

Hospital departments/*organization & administration/statistics &numerical

Hospital departments/*standards

Hospital design and construction economics/*legislation & jurisprudence

Hospital design and construction/standards

Hospital distribution systems

Hospital distribution systems/*standards

Hospital distribution systems/organization & administration/

Hospital mortality/*trends

Hospital mortality/trends

Hospital planning/*organization & administration

Hospital records

Hospital restructuring/*manpower

Hospital restructuring/*standard

Hospital restructuring/*trends

Hospital restructuring/manpower

Hospital restructuring/manpower/*organization & administration

Hospital restructuring/manpower/methods

Hospital restructuring/manpower/organization & administration/*trends

Hospital restructuring/manpower/standards

Hospital restructuring/organization & administration

Hospital restructuring/organization & administration/*standards

Hospital restructuring/trends

Hospital units/*economics/manpower

Hospital units*/economics/organization & administration

Hospital units/*legislation & jurisprudence/*manpower

Hospital units/*manpower

Hospital units/*manpower/organization & administration

Hospital units/*organization & administration

Hospital units/*standards

Hospital units/*statistics & numerical data

Hospital units/*supply & distribution

Hospital units*/utilization

Hospital units/classification/*standards

Hospital units/classification/manpower

Hospital units/economics/*organization & administration

Hospital units/economics/manpower/organization & administration

Hospital units/economics/organization & administration/*standards

Hospital units/manpower

Hospital units/manpower/*organization & administration

Hospital units/manpower/*organization & administration/statistics &

Hospital units/organization & administration

Hospital units/organization & administration/*standards

Hospital units/organization & administration/*statistics & numerical data

Hospital units/organization & administration/*trends

Hospital units/standards

Hospital/*manpower/standards/utilization

Hospitalization/*statistics & numerical data

Hospitalization/statistics & numerical data

Hospitals

Hospitals community

Hospitals community/*legislation & jurisprudence

Hospitals community/*manpower/organization & administration

Hospitals community/*organization & administration

Hospitals community/legislation & jurisprudence

Hospitals community/manpower

Hospitals community/manpower/organization & administration

Hospitals community/organization & administration

Hospitals community/organization & administration/*standards

Hospitals community/standards

Hospitals district/manpower

Hospitals general/classification/*manpower

Hospitals general/manpower

Hospitals general/manpower/organization & administration

Hospitals general/standards

Hospitals general/statistics & numerical data

Hospitals group practice/*manpower/utilization

Hospitals maternity

Hospitals maternity/manpower

Hospitals municipal/*manpower

Hospitals pediatric

Hospitals pediatric/*organization & administration/standards

Hospitals pediatric/*standards

Hospitals pediatric/*standards/statistics & numerical data

Hospitals pediatric/manpower

Hospitals pediatric/manpower/*organization & administration

Hospitals private

Hospitals private/*manpower

Hospitals private/economics/manpower

Hospitals private/organization & administration

Hospitals psychiatric/*manpower

Hospitals psychiatric/manpower/*statistics & numerical data

Hospitals psychiatric/manpower/statistics & numerical data

Hospitals psychiatric/organization & administration/*standards

Hospitals public/*manpower

Hospitals public/*organization & administration

Hospitals public/*organization & administration/statistics & numerical

Hospitals public/*standards

Hospitals public/*statistics & numerical data

Hospitals public/economics/manpower

Hospitals public/manpower/*standards

Hospitals public/manpower/organization & administration

Hospitals public/organization & administration

Hospitals public/organization & administration*

Hospitals public/organization & administration/standards

Hospitals public/organization & administration/standards/*utilization

Hospitals public/standards

Hospitals public/utilization

Hospitals rural

Hospitals rural/*organization & administration

Hospitals special/organization & administration/standards

Hospitals state/manpower/*statistics & numerical data

Hospitals state/manpower/statistics & numerical data

Hospitals teaching/*organization & administration

Hospitals teaching/*organization & administration/utilization

Hospitals teaching/*standards

Hospitals teaching/*statistics & numerical data

Hospitals teaching/economics/manpower/organization & administration

Hospitals teaching/manpower

Hospitals teaching/manpower/*organization & administration/standards

Hospitals teaching/manpower/*standards

Hospitals university

Hospitals university/*economics/utilization

Hospitals university/*manpower

Hospitals university/*standards

Hospitals university/economics

Hospitals university/economics/organization & administration

Hospitals university/manpower

Hospitals university/manpower/organization & administration/statistics &

Hospitals university/manpower/statistics & numerical data

Hospitals urban

Hospitals urban/*manpower

Hospitals urban/manpower/*standards

Hospitals veterans/*standards/statistics & numerical data

Hospitals veterans/manpower

Hospitals veterans/manpower/*standards

Hospitals/*manpower

Hospitals/*manpower/trends

Hospitals/*statistics & numerical data

Hospitals/classification/*manpower/statistics & numerical data

Hospitals/statistics & numerical data

Iatrogenic disease/prevention & control

Infection control/methods/standards

Infection control/organization & administration/*standards

Infection/epidemiology/etiology/inpatients

Inpatients/*classification

Inpatients/*education

Inpatients/*legislation & jurisprudence/*psychology

Inpatients/*psychology

Inpatients/*psychology/statistics & numerical data

Inpatients/*statistics & numerical data

Inpatients/classification

Inpatients/education/*psychology/inpatients/history/psychology

Intensive care units neonatal/economics/*manpower

Intensive care units neonatal/economics/manpower/utilization

Intensive care units neonatal/manpower

Intensive care units neonatal/manpower/*organization & administration

Intensive care units neonatal/manpower/*statistics & numerical data

Intensive care units pediatric

Intensive care units pediatric/*economics/manpower

Intensive care units pediatric/economics/manpower/utilization

Intensive care units pediatric/manpower/*organization & administration

Intensive care units pediatric/organization & administration/*standards

Intensive care units/*economics

Intensive care units/*legislation & jurisprudence/*manpower

Intensive care units/*manpower/*utilization

Intensive care units/*manpower/organization & administration

Intensive care units/*manpower/organization & administration/statistics &

Intensive care units/*manpower/standards

Intensive care units/economics/*manpower

Intensive care units/economics/manpower

Intensive care/manpower/*organization & administration

Intensive care/methods/*standards

Interdisciplinary communication

Internal medicine/manpower/*standards

Internal medicine/organization & administration

Interpersonal relations

Intervention studies on accreditation of healthcare

Joint Commission on Accreditation of Healthcare Organizations

Labor unions

Labor unions/*organization & administration

Labor unions/organization & administration

Legislation nursing

Length of stay/*economics

Length of stay/economics/*statistics & numerical data

Length of stay/trends

Licensure nursing

Licensure nursing/*legislation & jurisprudence

Licensure nursing/legislation & jurisprudence

Licensure nursing/statistics & numerical data

Malpractice

Malpractice/*economics/*legislation & jurisprudence

Malpractice/*legislation & jurisprudence

Malpractice/legislation & jurisprudence

Malpractice/legislation & jurisprudence/*statistics & numerical data

Managed care programs

Managed care programs/*economics

Managed care programs/*organization & administration

Managed care programs/economics

Managed care programs/manpower

Managed care programs/standards

Maternal-child nursing

Maternal-child nursing/*manpower

Maternal-child nursing/*organization & administration

Maternal-child nursing/*standards

Maternal-child nursing/*trends

Maternal-child nursing/education/*methods

Maternal-child nursing/education/*organization & administration

Maternal-child nursing/education/organization & administration

Maternal-child nursing/manpower/*standards

Maternal-child nursing/methods/*standards

Medical errors/*adverse effects/*prevention & control

Medical errors/*nursing/prevention & control/*statistics & numerical data

Medical errors/*nursing/statistics & numerical data

Medical errors/nursing/prevention & control/*statistics & numerical data

Medical staff hospital/*economics/supply & distribution

Medication errors/*nursing/standards/statistics & numerical data

Medication errors/methods/nursing/*prevention &control

Neonatal nursing/*manpower/*methods

Neonatal nursing/*organization & administration

Neonatal nursing/*standards

Neonatal nursing/education/*organization & administration

Night care/*organization & administration

Nurse administrators/*education

Nurse administrators/*education/*organization & administration/psychology

Nurse administrators/*legislation & jurisprudence

Nurse administrators/*organization & administration

Nurse administrators/*organization & administration/*psychology

Nurse administrators/*organization & administration/psychology

Nurse administrators/economics/supply & distribution

Nurse administrators/education

Nurse administrators/education/*organization & administration

Nurse administrators/education/*psychology

Nurse administrators/education/organization & administration/*psychology

Nurse administrators/education/organization & administration/psychology

Nurse administrators/legislation & jurisprudence/psychology

Nurse administrators/statistics & numerical data

Nurse clinicians

Nurse clinicians/*organization & administration

Nurse clinicians/*organization & administration/*psychology

Nurse clinicians/*organization & administration/psychology

Nurse clinicians/*organization & administration/standards

Nurse clinicians/*standards

Nurse clinicians/*supply & distribution

Nurse clinicians/education

Nurse clinicians/education/*organization & administration

Nurse clinicians/education/*organization & administration/psychology

Nurse clinicians/education/standards/supply & distribution

Nurse clinicians/legislation & jurisprudence

Nurse clinicians/organization & administration

Nurse clinicians/psychology/*supply & distribution

Nurse's role*

Nurse's role/*psychology

Nurse-patient relations/*ethics

Nurses' aides

Nurses' aides/*economics/education/supply & distribution

Nurses' aides/*education

Nurses' aides/*organization & administration/psychology

Nurses' aides/*psychology

Nurses' aides/*standards

Nurses' aides/distribution

Nurses' aides/education/*organization & administration

Nurses' aides/education/*organization & administration/psychology

Nurses' aides/education/*psychology

Nurses' aides/education/*supply & distribution

Nurses' aides/education/*utilization

Nurses' aides/education/organization & administration

Nurses' aides/education/organization & administration/psychology

Nurses' aides/education/psychology

Nurses' aides/education/supply & distribution

Nurses' aides/legislation & jurisprudence

Nurses' aides/legislation & jurisprudence/utilization

Nurses' aides/organization & administration

Nurses' aides/organization & administration/psychology

Nurses' aides/psychology/*supply & distribution

Nurses' aides/standards

Nurses' aides/statistics & numerical data/*utilization

Nurses/*organization & administration

Nurses/*psychology

Nurses/economics/organization & administration/utilization

Nurses/economics/statistics & numerical data/*supply & distribution

Nurses/psychology

Nurses/psychology/*statistics & numerical data

Nurses/supply & distribution

Nursing administration research/*education

Nursing administration research/*methods

Nursing administration research/*methods/standards

Nursing administration research/*methods/statistics & numerical data

Nursing administration research/*organization & administration

Nursing administration research/methods

Nursing administration research/methods/standards

Nursing administration research/organization & administration

Nursing assessment

Nursing assessment/*ethics/methods

Nursing assessment/*legislation & jurisprudence

Nursing assessment/*methods

Nursing assessment/*methods/*statistics & numerical data

Nursing assessment/*methods/standards

Nursing assessment/*organization & administration

Nursing assessment/methods/standards/statistics & numerical data

Nursing audit/*methods

Nursing audit/*organization & administration

Nursing audit/organization & administration

Nursing care

Nursing care/*classification

Nursing care/*classification/methods

Nursing care/*methods

Nursing care/*methods/*psychology

Nursing care/*psychology

Nursing care/*psychology/*standards

Nursing care/*standards/statistics & numerical data

Nursing care/*utilization

Nursing care/classification

Nursing care/classification/*methods/standards/*statistics & numerical

Nursing care/classification/*psychology/*standards

Nursing care/manpower/methods/*statistics & numerical data

Nursing care/methods/*psychology

Nursing care/methods/organization & administration

Nursing care/organization & administration

Nursing care/psychology/standards

Nursing care/statistics & numerical data

Nursing diagnosis

Nursing diagnosis/*standards

Nursing diagnosis/*utilization

Nursing education research

Nursing evaluation research/*methods

Nursing evaluation research/*methods/standards

Nursing evaluation research/*organization & administration

Nursing evaluation research/methods

Nursing methodology research

Nursing methodology research/*methods

Nursing methodology research/*methods/*standards

Nursing methodology research/*methods/standards

Nursing methodology research/education/*methods

Nursing methodology research/methods/standards

Nursing process

Nursing process/*organization & administration

Nursing process/*statistics & numerical data

Nursing process/classification/standards/*statistics & numerical data

Nursing records

Nursing records*legislation & jurisprudence

Nursing records/*standards

Nursing records/*standards/statistics & numerical data

Nursing records/legislation & jurisprudence/*standards

Nursing records/standards

Nursing records/standards/statistics & numerical data

Nursing records/statistics & numerical data

Nursing research/*methods/standards

Nursing research/*methods/statistics & numerical data

Nursing research/*organization & administration

Nursing research/education

Nursing research/education/*organization & administration

Nursing service hospital

Nursing service hospital/*classification

Nursing service hospital/*economics

Nursing service hospital/*history/manpower/organization & administration

Nursing service hospital/*manpower

Hospital/*manpower/*standards

Nursing service hospital/*organization & administration

Nursing service hospital/*organization & administration/trends

Nursing service hospital/classification/*utilization

Nursing service hospital/classification/manpower/*organization

Nursing service hospital/economics

Nursing service hospital/economics/*organization & administration

Nursing service hospital/economics/*standards

Nursing service hospital/economics/*trends

Nursing service hospital/economics/manpower/*organization &

Nursing service hospital/manpower/*organization &

Nursing service hospital/manpower/*organization & administration

Nursing service hospital/manpower/*organization & administration/trends

Nursing service

Nursing staff

Nursing staff hospital

Nursing staff hospital/*economics

Nursing staff hospital/*economics/*legislation & jurisprudence

Nursing staff hospital/*economics/*supply & distribution

Nursing staff hospital/*economics/legislation & jurisprudence

Nursing staff hospital/*economics/legislation & jurisprudence/statistics

Nursing staff hospital/*economics/organization & administration/trends

Nursing staff hospital/*economics/psychology

Nursing staff hospital/*economics/standards

Nursing staff hospital/*economics/standards/supply & distribution

Nursing staff hospital/*economics/supply & distribution

Nursing staff hospital/*education

Nursing staff hospital/*education/*legislation & jurisprudence

Nursing staff hospital/*education/*organization &

Nursing staff hospital/*education/*organization administration

Nursing staff hospital/*education/*psychology

Nursing staff hospital/*education/*psychology/supply & distribution

Nursing staff hospital/*education/*supply & distribution

Nursing staff hospital/*education/*supply & distribution/trends

Nursing staff hospital/*education/organization

Nursing staff hospital/organization & administration

Nursing staff hospital/*ethics/organization & administration/*psychology

Nursing staff hospital/*ethics/psychology

Nursing staff hospital/*legislation & jurisprudence

Nursing staff hospital/*legislation & jurisprudence/*standards

Nursing staff hospital/*legislation & jurisprudence/statistics

Nursing staff hospital/*legislation & jurisprudence/supply & distribution

Nursing staff hospital/*organization &

Nursing staff hospital/*organization & administration/*psychology

Nursing staff hospital/*organization & administration/*statistics &

Nursing staff hospital/*organization & administration/*supply &

Nursing staff hospital/*organization & administration/psychology

Nursing staff hospital/economics/*legislation & jurisprudence

Nursing staff hospital/economics/*statistics & numerical data

Nursing staff hospital/economics/*supply & distribution/utilization

Nursing staff hospital/economics/*utilization

Nursing staff hospital/economics/education

Nursing staff hospital/legislation & jurisprudence

Nursing staff hospital/legislation & jurisprudence/*organization &

Nursing staff hospital/legislation & jurisprudence/psychology/*supply &

Nursing staff hospital/organization & administration/*standards

Nursing staff hospital/organization & administration/*utilization

Nursing staff hospital/standards/*utilization

Nursing staff hospital/standards/supply & distribution

Nursing staff hospital/statistics & numerical data

Nursing staff hospital/statistics & numerical data/*supply & distribution

Nursing staff hospital/supply & distribution

Nursing staff hospital/supply & distribution/*trends

Nursing staff hospital/supply & distribution/*utilization

Nursing staff hospital/trends

Nursing theory

Nursing practical

Nursing practical

Nursing practical methods

Nursing practical/*legislation & jurisprudence

Nursing practical/*manpower

Nursing practical/*statistics & numerical data

Nursing practical/economics/*manpower

Nursing practical/education

Nursing practical/education/*manpower

Nursing practical/education/organization & administration

Nursing practical/education/standards

Nursing practical/legislation & jurisprudence

Nursing practical/standards

Nursing practical/statistics & numerical data

Nursing supervisory/*economics

Nursing supervisory/*legislation & jurisprudence

Nursing supervisory/*methods

Nursing supervisory/*organization & administration

Nursing supervisory/*standards

Nursing supervisory/economics

Nursing supervisory/legislation & jurisprudence

Nursing supervisory/methods

Nursing supervisory/organization & administration

Nursing supervisory/standards

Nursing team

Nursing team/*organization & administration

Nursing team/organization & administration

Nursing team/statistics & numerical data

Nursing/*manpower

Nursing/*manpower/trends

Nursing/*organization & administration

Oncologic nursing

Oncologic nursing/*manpower

Oncologic nursing/*methods/standards

Oncologic nursing/*organization & administration

Oncologic nursing/*standards

Oncologic nursing/economics/education/*manpower

Oncologic nursing/education

Oncologic nursing/legislation & jurisprudence

Oncologic nursing/manpower

Oncologic nursing/manpower/*standards

Oncologic nursing/methods/*standards

Oncologic nursing/statistics & numerical data

Orthopedic nursing/*organization & administration/standards

Outcome assessment (health care)/economics/*statistics & numerical data

Outcome assessment (health care) /methods

Outcome assessment (health care)/organization & administration

Outcome assessment (health care)/standards

Outcome and process assessment (health care)/*statistics & numerical data

Outcome and process assessment (health care)/economics

Process assessment (health care)/methods

Outcome and process assessment (health care)/organization & administration

Pain postoperative/*nursing

Pain postoperative/diagnosis/etiology/*nursing/*prevention & control

Pain postoperative/diagnosis/etiology/*nursing/psychology

Pain/*nursing

Pain/*nursing/*therapy

Pain/diagnosis/nursing

Patient care

Patient care planning

Patient care planning/*classification

Patient care planning/*economics/standards

Patient care planning/*methods

Patient care planning/*organization & administration

Patient care planning/economics/statistics & numerical data

Patient care planning/organization & administration

Patient care planning/organization & administration/*standards

Patient care team/*organization & administration

Patient care team/*standards

Patient care team/*statistics & numerical data

Patient care team/economics

Patient care team/economics/*organization & administration

Patient care team/economics /statistics & numerical data/*utilization

Patient care team/organization & administration

Patient care team/standards

Patient care/*economics

Patient care/economics

Patient readmission

Patient readmission/*statistics & numerical data

Patient readmission/economics

Patient readmission/statistics & numerical data

Patient transfer/manpower/*organization & administration/standards

Patient transfer/methods/*organization & administration

Patient transfer/methods/*standards

Patient transfer/methods/organization & administration/*standard

Patient-centered care

Patient-centered care/*economics

Patient-centered care/*ethics/organization & administration

Patient-centered care/*manpower

Patient-centered care/*manpower/*organization & administration

Patient-centered care/*methods

Patient-centered care/*organization & administration

Patient-centered care/*organization & administration/*statistics

Patient-centered care/*standards

Patient-centered care/*trends

Patient-centered care/economics/*manpower/standards

Patient-centered care/history

Patient-centered care/methods

Patient-centered care/methods/*organization & administration

Patient-centered care/methods/*standards

Patient-centered care/organization & administration

Care/standards

Pediatric nursing

Pediatric nursing/*education

Pediatric nursing/*education/*organization & administration

Pediatric nursing/*history

Pediatric nursing/*legislation & jurisprudence

Pediatric nursing/*manpower

Pediatric nursing/*methods

Pediatric nursing/*methods/standards

Pediatric nursing/*organization & administration

Pediatric nursing/*organization & administration/*standards

Pediatric nursing/*standards

Pediatric nursing/*statistics & numerical data

Pediatric nursing/education

Pediatric nursing/education/*manpower

Pediatric nursing/education/*methods

Pediatric nursing/education/*methods/standards

Pediatric nursing/education/*organization & administration

Pediatric nursing/education/*standards

Pediatric nursing/history

Pediatric nursing/manpower

Pediatric nursing/manpower/standards

Pediatric nursing/methods

Pediatric nursing/organization & administration

Pediatric nursing/statistics & numerical data

Perioperative care/manpower

Perioperative care/nursing/organization & administration

Perioperative nursing

Perioperative nursing/*education

Perioperative nursing/*manpower

Perioperative nursing/*manpower/standards

Perioperative nursing/*manpower/statistics & numerical data

Perioperative nursing/*methods

Perioperative nursing/*organization & administration

Perioperative nursing/*organization & administration/standards

Perioperative nursing/*standards

Perioperative nursing/education

Perioperative nursing/education/*manpower

Perioperative nursing/education/*methods

Perioperative nursing/education/*methods/*standards

Perioperative nursing/education/methods/standards

Personal autonomy

Personal satisfaction

Personal space

Personality

Personality inventory

Personnel administration hospital

Personnel administration hospital/*legislation & jurisprudence

Personnel administration hospital/*methods

Personnel administration hospital/*methods/statistics & numerical data

Personnel administration hospital/*standards

Personnel administration hospital/*statistics & numerical data

Personnel administration hospital/economics

Personnel administration hospital/economics/*methods/trends

Personnel administration hospital/legislation & jurisprudence/*standards

Personnel administration hospital/methods

Personnel administration hospital/standards

Personnel administration hospital/standards/statistics & numerical data

Personnel management/*legislation & jurisprudence

Personnel management/*methods

Personnel management/*organization & administration

Personnel management/*standards

Personnel management/*trends

Personnel management/economics/*methods

Personnel management/methods

Personnel management/standards

Personnel staffing and scheduling information

Personnel staffing and scheduling information systems

Personnel staffing and scheduling information systems/*organization &

Personnel staffing and scheduling/*classification

Personnel staffing and scheduling/*classification/organization &

Personnel staffing and scheduling/*economics/organization & administration

Personnel staffing and scheduling/*legislation &

Personnel staffing and scheduling/*legislation & jurisprudence/standards

Personnel staffing and scheduling/*organization

Personnel staffing and scheduling/*organization & administration/standards

Personnel staffing and scheduling/*statistics & numerical data/*trends

Personnel staffing and scheduling/*statistics & numerical data/trends

Personnel staffing and scheduling/economics/*legislation & jurisprudence

Personnel staffing and scheduling/legislation & jurisprudence/standards

Personnel staffing and scheduling/organization & administration/*standards

Personnel staffing and scheduling/organization & administration/standards

Personnel staffing and scheduling/organization & administration/statistics

Personnel turnover/*statistics & numerical data

Personnel turnover/*trends

Personnel turnover/economics

Personnel turnover/economics/*statistics & numerical data

Personnel turnover/statistics & numerical data/*trends

Personnel hospital/*statistics & numerical data

Personnel hospital/classification/economics/*supply & distribution

Personnel hospital/economics

Personnel hospital/education/*standards

Personnel hospital/education/psychology

Personnel hospital/legislation & jurisprudence

Personnel hospital/standards/*supply & distribution

Personnel hospital/statistics & numerical data/*utilization

Personnel hospital/statistics & numerical data/supply & distribution

Philosophy nursing

Pneumonia/classification/nursing

Postnatal care/economics/manpower/*organization & postoperative care/*nursing/*standards

Postoperative care/methods/nursing

Postoperative care/nursing/*standards

Postoperative care/nursing/psychology/statistics & numerical data

Preoperative care/*preoperative care/economics/*

Primary health care

Primary health care/*manpower

Primary health care/*organization & administration

Primary health care/organization & administration

Primary nursing care

Primary nursing care/*manpower

Primary nursing care/*methods

Primary nursing care/*organization & administration

Primary nursing care/manpower

Primary nursing care/methods/*standard

Primary nursing care/organization & administration

Primary nursing care/organization & administration/*standards

Primary nursing care/statistics & numerical data

Process assessment (health care)

Process assessment (health care) /organization & administration

Process assessment (health care)/methods

Professional competence

Professional competence/*standards

Progressive patient care

Progressive patient care/*manpower

Progressive patient care/*organization & administration

Progressive patient care/classification/*standards

Progressive patient care/organization & administration

Qualitative research

Quality assurance health care/*legislation & jurisprudence

Quality assurance health care/*methods

Quality assurance health care/*organization & administration

Quality assurance health care/*statistics & numerical data

Quality assurance health care/economics/trends

Quality assurance health care/legislation & jurisprudence

Quality assurance health care/methods

Quality assurance health care/organization & administration

Quality assurance health care/standards

Quality assurance health care/statistics & numerical data

Quality control

Quality indicators health care

Quality indicators health care/organization & administration

Quality indicators health care/*statistics & numerical data

Quality indicators health care/legislation & jurisprudence

Quality indicators health care/standards

Quality of health care/*legislation &

Quality of health care/*statistics & numerical data

Quality of health care/*trends

Quality of health care/legislation & jurisprudence

Quality of health care/organization & administration

Quality of health care/organization & administration/standards

Quality of health care/standards

Rehabilitation nursing/*legislation & jurisprudence

Rehabilitation nursing/*manpower/*methods

Restraint physical

Resuscitation

Resuscitation orders

Resuscitation/*education/standards

Resuscitation/*standards/statistics & numerical data

Risk management/*organization & administration

Risk management/*organization & administration/statistics & numerical data

Risk management/*standards

Risk management/*statistics & numerical data

Safety management/*

Safety management/*methods

Safety management/*organization & administration

Safety management/*standards

Safety management/legislation & jurisprudence

Safety management/methods

Safety management/methods/standards

Safety management/organization & administration

Safety/*legislation & jurisprudence

Safety/standards

Total quality management/*organization & administration

Total quality management/organization & administration

Unnecessary procedures/nursing/statistics & numerical data

Urinary catheterization/*adverse effects/*nursing

Urinary catheterization/adverse effects/*nursing

Urinary catheterization/nursing/*standards

Work schedule tolerance

Workload/*classification/economics

Workload/*legislation & jurisprudence

Workload/*legislation & jurisprudence/*standards

Workload/*legislation & jurisprudence/standards

Workload/*psychology

Workload/*psychology/statistics & numerical data

Workload/*standards

Workload/economics/statistics & numerical data

Workload/legislation & jurisprudence

Workload/legislation & jurisprudence/*standards/statistics & numerical data

Workload/legislation & jurisprudence/standards

Workload/legislation & jurisprudence/statistics & numerical data

Workload/psychology/*statistics & numerical data

Workload/statistics & numerical data

Workplace

Workplace/*organization & administration