# Appendixes

Appendix A: Exact Search Strings

Appendix B: List of Excluded Studies

Appendix C: Technical Expert Panel Members and Affiliation

Appendix D: Sample Abstraction Forms

Appendix E: Quality of the Studies

Appendix F. Analytic Framework

Appendix G: Evidence Tables