# Extra Tables

- Table 1. Extra Table. Studies examined the factors that might affect the acceptance of genetic testing.
- Table 2. Extra table. Surveys of genetic centers or insurance providers.
- Table 3. Extra Table. Factors that might affect the compliance with CRC screening.

Table 1 Extra Table. Studies examined the factors that might affect the acceptance of genetic testing

Author, year | Findings
Atkan-Collan 2000; 2001a; 2001b; 2001c | Acceptors differ from decliners in more often having a spouse or partner, being employed and having higher education. On multivariate analysis, the only significant factor for accepting genetic testing was employment status.
| Most common reasons cited against undergoing testing were: being old already and having no children (23%), would not trust result (15%), timing found unsuitable because of pregnancy 1 (8%), no reason given (54%)
| 53% indicated that they might have used professional psychological support along with counseling if it had been provided. The support might have been used by women with children more than by others.
Berth, 2002 | Survey sent to 2076 persons of the general population and 36 patients at high risk for HNPCC or FAP (familial adenomatous polyposis)
| “Overall, both the general population and at-risk persons hold a favorable attitude toward genetic testing”.
Brodersen, 2004 | Cross sectional study to examine anticipated reactions to genetic testing for HNPCC in 437 asymptomatic people with a family history of colorectal cancer.
| More women anticipated feeling fairly or extremely worried if they did not have the test (36 versus 23 percent, p =0.009) or if the test was positive (64 versus 40 percent, p =0.008).
| More women anticipated that they would feel fairly or extremely regretful if the test showed that they were at high risk (30 versus 20 percent, p =0.03).
| More women thought that they would feel fairly or extremely angry if the test showed that they were at high risk (33 versus 13, p <0.001).
| There was only one significant difference between men and women in anticipated reaction following genetic testing: if at low risk more women then men would try to adopt a healthier lifestyle (p=0.007).
| When asked if they would have more screening if found to be at high risk, 416/432 (96%) said that they probably (23%) or definitely (74%) would.
Codori, 1999 | Evaluated uptake of genetic testing for HNPCC among first-degree relatives of CRC by comparing test acceptors (N=77) and decliners (N=181).
| Significant predictors of acceptance on multivariate analysis were: perceived ability to cope with a positive gene test result, risk perception, frequency of thoughts about CRC (not at all or rarely versus sometimes or more) and CRC screening history.
| Coping with positive test results: ≥ 90% confident OR 4.0 (95% CI 1.53–10.3, p=0.005)
| CRC screening: never had a colonoscopy (OR 0.45, 95% CI 0.21–0.93, p=0.030)
| Cancer thoughts: Rarely/never versus sometimes, often, a lot: OR 0.44 95% CI 0.17–1.13, p =0.088)
Graff, 2005 | Investigated experiences of 12 individuals with HNPCC (pathogenic mutation) in a semi structured telephone interview. All patients had been asked to inform family members.
| 12 subjects (4 men and 3 women). Respondents older than nonrespondents (55 versus 49) had more cancer diagnoses per individual and were more likely to be female (no statistical comparisons made).
| All had told some (mainly immediate family) at-risk family members about predictive testing.
| Family reactions ranged form interest to disinterest.
| Men expressed a need for guidance and support in communicating to relatives more than women.
| Letters and booklets were thought to enhance the quality of information but further aids were unlikely to increase the number of relatives made aware of predictive testing by the probands.
Hadley, 2003 | Elucidate factors affecting decisions regarding genetic testing in individuals form families with newly identified HNPCC.
| 104/165 (63%) eligible patients (including index cases and 1^st^ degree relatives agreed to participate. This included 54 probands (of whom 87% agreed to participate) and 111 family members of whom 51% agreed to participate.
| Awareness of genetic testing: those at higher household income levels were more aware of genetic testing for cancer (p=0.001) and colon cancer (p=0.009) than those at lower household income levels. There was no significant association between participants' awareness and age, sex, personal cancer history or number of 1s-degree relatives.
| Perceived risk of being a carrier: Participant's feelings about their chances of getting colon cancer were significantly associated with their beliefs about the likelihood that they carry a mutation (p<0.001)
| Intentions toward genetic testing: The intention to pursue genetic testing was found to have a positive association with participant's beliefs that cancer may be explained by family heredity (p=0.006). Concern about the psychosocial effect of genetic testing on the family demonstrated a negative association with their intention to pursue testing (p=0.001). Participant's concerns about their ability to handle the emotional aspects of genetic test results demonstrated a negative association with their intentions to pursue testing (p<0.001). No association between age, sex or cancer status in regard to their intentions toward genetic testing.
| Reasons for pursuing genetic tests: 50% of respondents believe that the most important reason for undergoing genetic testing was to learn about their children's risk. Second most important reason (17%) was to guide cancer screening; third (13%) as to confirm their belief that they carry a mutation. With respect to the importance of genetic testing for reproductive decision making, a statistically significant difference was detected between those younger than the median age of 43 or older (p=0.002).
| Reasons for not pursuing testing: Worry about losing health insurance (39%), concerns about how it might affect the family (27%), concerns about handling the results emotionally (10%). A statistically significant difference was detected between those younger than the median age of 43 compared with those older with respect to concerns about handling the emotional aspects of genetic testing (p=0.006).
| Testing decisions: 44/54 (81%) of eligible probands eventually chose to undergo genetic testing for HNPCC. 56/111 eligible first-degree relatives chose to pursue genetic testing (intention-to-treat analysis).
| Of those agreeing to participate in the study, 44/47 (94%) probands agreed to undergo genetic testing and 56/57 (98%) of family members agreed.
Keller, 2004 | Of 140 eligible patients and their families, 36 families participated in the information session, 25 participants were patients, and 11 were spouses or relatives of patients who had died or were too ill to attend. Participation rate 26%. Of the 104 nonparticipating patients addressed by mail, 61 responded (59%), 12 died, 48 returned a completed questionnaire. Sample here consisted of 73 patients: 25 participants and 48 nonparticipants.
| Among participants, 60% reported being very worried because of familial cancer; among nonparticipants 35% reported being very worry because of familial cancer (P<0.05).
| 28% of participants reported impairment of daily life because of these worries compared to 19% of nonparticipants (difference not significant). Similarly, perceived distress of spouse and family from patient's point of view was higher in participants than in nonparticipants (difference not significant).
| Regardless of whether patients participated in the information session, most were in favor of genetic testing. Twice as many nonparticipants (25%) as participants (13%) were undecided about whether to accept genetic testing. All participants definitely expressed the wish to know whether a mutation is present in the family, compared to 81% of nonparticipants.
Lerman, 1996 | This was a pilot study in preparation for a prospective study of genetic testing for HNPCC-associated mutations. 24 consecutive index colon cancer patients (who did not fulfill the Amsterdam criteria) identified 61 first-degree relatives for the study (index patient consent rate = 83%). Of these first degree relatives, 44 (72%) completed the interview, 2 (2%) declined, 16 (26%) could not be reached.
| Anticipated reactions to positive and negative results of a genetic test:
| Over ½ of respondents indicated that they would become depressed or very anxious if they tested positive.
| Most subjects reported that they would react by changing their health habits, including diet and screening behaviors.
| In response to negative test result, about 1/3 of respondents anticipated they would feel guilty and ½ would still worry because the test might be wrong. About ½ of respondents expected that they would decrease their use of screening tests and make fewer attempts to reduce dietary fat if they tested negative.

Table 2 Extra table. Surveys of genetic centers or insurance providers

Author, year | Findings
Brain, 2003 | Survey obtained from 16 regional genetic centers involved in predictive testing for HNPCC. Purpose was to gain evidence regarding core elements of the pre-test counseling protocol for HNPCC. 16/20 centers participated. One declined because of few patients counseled. No other details provided.
| Average number of pre-test counseling sessions was 2 (range 1–3) with an average of 4 weeks between sessions.
| Minimum number of sessions was 1 (range 1–2).
| Counselors included clinical geneticists and genetic nurse and gastroenterologists.
| Some included home visits, psychiatric consultation, explicit circumstances in which a client would be excluded or postponed from testing. Four centers reported that they were considered shortening the counseling protocol.
| Centers described a total of 144 topics as being core topics of pre-test counseling.
Norum 2000 | 11 health insurers in Norway were mailed a questionnaire to evaluate two hypothetical individuals' requests for insurance; one has HNPCC mutation, the other has BRCA1/BRCA2.
| 9/11 insurers responded.
| 2 companies reported results on personal indemnity insurance.
| There were no restrictions for individuals with a genetic risk of breast CA when seeking life insurance or disability pension. One company raised premium on the one with genetic risk of CRC.
| Another company offered standard or higher rate of premium on personal indemnity insurance in the person with genetic risk of CRC.

Table 3 Extra Table. Factors that might affect the compliance with CRC screening

Author, year | Findings
Adams, 2003 | Secondary analysis of data recorded for a study on polyp prevention (a database) on chemopreventive effects of aspirin. Study had included 600 patients with HNPCC; of these 154 were available for analysis and full data were available on 134. Of these 134, 49 had a personal history of CRC.
| Socioeconomic status assessed using the Town-Deprivation Score (TDS) of the current enumeration district of residence. This score is based on relative material deprivation based on census data.
| There was a statistically non-significant correlation between the TDS and the age of first resection indicating that individuals in less deprived areas tended to have their colorectal cancer resected at an earlier age than those living in more deprived areas.
Bleiker, 2005 | 178 patients at high risk for CRC (27 Amsterdam I criteria; 43 familial CRC occurrence). All had received counseling from a geneticist and were advised to have periodic colonoscopy.
| Objective and self-reported compliance.
| 149/178 returned a completed questionnaire. Respondents significantly older than nonrespondents.
| Average f/u 5.8 years
| 61% of study sample fulfilled Amsterdam I
| Objective compliance data available for 132/149. Of these 95 (72%) were found to be compliant with screening advice.
| Of 37 (28%) noncompliant, 20 had postponed screening for at least 1 year, 13 were screened only once, and 4 never underwent screening.
| Compliers were significantly younger than noncompliers and there was a nonsignificant trend to increased level of education, mutation status, and type of colon screening.
| No difference between perceived colon cancer risk.
| Noncompliers significantly more likely to perceive barriers to screening.
| Noncompliers rated screening as being more embarrassing.
| On multivariate analysis only the perceived number of barriers to screening was associated significantly with noncompliance (OR 1.2, 95% CI 1.1–1.3).
| Of self-reported data, noncompliance was associated with embarrassment with screening procedure and sigmoidoscopy rather than colonoscopy.
| Compliers were significantly more likely to have remembered receiving a reminder letter.