# Overview Tables

Table 1. Overview Table: Key Question 6b.

Table 2. Overview Table. Key Questions 8b and 8c.

Table 3. Overview Table. Key Questions 8a and 9.

Table 4. Overview table. Key Question 10.

Table 5. Overview Table. Key Question 11.

Table 1 Overview Table: Key Question 6b

Reported Outcomes | Body of evidence (study duration) | Summary
Prognosis of CRC | 1 Retro study (~8 yr) | - ⇔ Comparing mutation carriers to non-carriers with MSI; - Better, comparing mutation carriers to non-carriers with MSS
Survival of patients with endometrial cancer | 1 Retro study (ND) | - ⇔ Comparing MMR mutation carriers to non-carriers
Survival of CRC patients | 5 Retro studies (12–153 mo)^a^ | - Results were inconsistent among studies that compared survival in patients with CRC who fulfilled Amsterdam I criteria with those considered to have sporadic CRC; - ⇔ Comparing Amsterdam I to Japanese A criteria; - ↑ Comparing Amsterdam I to Japanese B criteria; - ⇔ Comparing MSH2 and/or MLH1 status by IHC in patients with sporadic CRC; - ⇔ Comparing MSI-H to MSI-L/MSS CRC; - ⇔ 5-year cumulative survival comparing patients with endometrial cancer who were mutation positive to those who were mutation negative.; - ⇔ Comparing stage III CRC patients receiving adjuvant chemotherapy with MSI tumors to those with MSS/MSI-L.

↑ Statistically increased

↑ Increased, but not statistically significant

⇔ No statistically significant differences

↓ Statistically decreased

↓ Decreased, but not statistically significant

a Only two studies reported the study duration

Table 2 Overview Table. Key Questions 8b and 8c

Reported Outcomes | Body of evidence (study duration) | Summary
CRC risks in family members of probands with positive MMR mutations; factors that influenced the accuracy of testing | 2 Retro studies (ND) | - In a Finland population, lifetime risk of CRC was 68.7% for men and 52.2% for women with MMR mutations. Mean age of diagnosis of CRC 55.1 for men and 60.3 for women.; - In a Scottish population, cumulative risk of CRC (95% CI) by age 70 yr was 74% for men and 30% for women with MMR mutations (P=0.0066). The risk of CRC was significantly higher at all ages in men than in women.
CRC risks in family members of probands with HNPCC based on clinical criteria; factors that influenced the accuracy of testing | 1 Prosp study (2 yr) and 3 Retro studies (8 yr)^a^ | - Cumulative risk of CRC (95% CI) by age 75 yr:; Am I families=57.1% (46–68.8%); Am II families=41.2% (33.3–50.1%); Bethesda families=; - Men 41.7% (39.4–44.1%); - Women 23.3% (22.2–24.4%); - SIR of CRC (95% CI):; ↑ Proband<50 yr; MSI = 21(12–35); ↑ Proband<50 yr; MSS = 7 (3–14); ⇔ Proband>50 yr = 1.07 (0.74–1.40); - 8% in the group fulfilled Amsterdam I criteria had adenomas, while 2% in the group with family history of CRC only had adenomas.; - ↑ CRC risk, compared 1^st^ degree relatives of CRC probands who developed a second primary in the HNPCC spectrum with the single primary group (RR=3.2, p<0.00001)
CRC risks in kindreds with HNPCC based on clinical criteria and/or genetic criteria; factors that influenced the accuracy of testing | 6 Retro studies (ND) | - Cumulative risk of CRC by age 70 yr was 82% in MLH1/MSH2 mutation carriers, compared with only 1.6% in the Finnish population as a whole.; - Cumulative risk of CRC by age 60 yr:; MLH1 mutation (+): 84% – 94% in men compared to 63% in women (p=NS); MSH2 mutation (+): 71% – 96% in males compared to 39% in women (p=0.034); - SIR 95%CI of CRC in HNPCC families based on genetic criteria:; MLH1/MSH2 mutation (+): 68 (56–81) - SIR was higher in men (83) than in women (48); - SIR and 95%CI of CRC in HNPCC families meeting either Amsterdam or Bethesda criteria:; Mutation (-): 158.61 (132.8–189.4); MLH1 mutation (+): 196.76 (143.0–270.7); MSH2 mutation (+): 134.24 (99.1–181.8); - Comparing family members with pathogenic MSH6 mutations to those with MLH1/MSH2 mutations:; ↓ Prevalence of CRC; ↓ Cumulative risk by age to develop CRC or any tumor; - Compared MSH2 carriers to MLH1 carriers:; ↑ Risk of CRC (p=0.13); - Relative risk of developing adenoma before age 54 yr compared to reference group^b^:; ↑ MMR mutation carriers (MSH2, MLH1, or hMSH6) (RR=4.4. p<0.001); - ↑ Risk of CRC comparing male to female MSH2 mutation carriers (p<0.01); - ⇔ Risk of CRC comparing male to female MLH1 or MSH6 mutation carriers; - Comparing family members with pathogenic MSH6 mutations to those with MLH1/MSH2 mutations:; ↑ Median age of CRC onset (54 vs. 44 yr); - ↑ Age at diagnosis compared MMR mutation (+) to mutation (-) (+ 5 yr); - ⇔ Age at diagnosis compared MSH2 mutation (+) to MLH1 mutation (+), adjusted for familial clustering.; - Proportion of patients younger than 50 found to have an adenoma: ↑ Amsterdam I

SIR=standardized incidence rate.

↑ Statistically increased

↑ Increased, but not statistically significant

⇔ No statistically significant differences

↓ Statistically decreased

↑ Decreased, but not statistically significant

a Only one study reported the duration of follow-up.

b Reference group was based on three published forensic autopsy studies used for estimates of adenoma prevalence in the normal population.

Table 3 Overview Table. Key Questions 8a and 9

Reported Outcomes | Body of evidence (study duration) | Summary
Decision to genetic testing | 2 Prosp studies (1 mo to 1 yr) | - 1%–2% family members of HNPCC enrolled in the studies opted not to undergo genetic testing.
Shortened vs. extended pre-test counseling | 1 RCT (3 mo) | - High satisfaction in both groups.; - ⇔ Decision making outcomes or knowledge about HNPCC between groups.; - Mutation carriers had higher psychological distress in extended pre-test counseling group but lower psychological distress in shortened pre-test counseling group, compared to non-carriers.
Satisfaction in decision to undergo testing | 1 Prosp study & 1 RCT (1 mo to 1 yr) | - No short-term difference in satisfaction in decision to undergo genetic testing between carriers and noncarriers, but MMR mutation carriers were less satisfied in decision to undergo testing 1 year after testing.
Anxiety | 6 Prosp studies (2 wk to 1 yr) | - ↓ Anxiety levels immediately after genetic counseling; - Anxiety levels of HNPCC family members were within normal ranges compared to the general population.; - Generally there was no change or decrease in anxiety level over-time among non-carriers, while there was no change or increase in anxiety level among mutation carriers over-time.; - MMR mutation carriers had higher anxiety levels than non-carriers shortly after genetic test results were revealed, but this difference generally disappeared with time.
Depression | 5 Prosp studies (2 wk to 1 yr) | - ↓ Depression levels immediately after genetic counseling; - Depression levels of HNPCC family members were within normal ranges compared to the general population.; - Conflicting results on changes in depression levels over-time; - Conflicting results comparing MMR mutation carriers to non-carriers
Distress | 5 Prosp studies & 1 RCT (2 wk to 1 yr) | - Psychological distress, cancer-specific distress (including Intrusive and avoidant thoughts about CRC or cancer worries), and distress from receiving test results generally decreased with time.; - In general, MMR mutation carriers had higher cancer-specific distress levels than non-carriers.
Quality of life | 2 Prosp studies (2 wk to 1 yr) | - QOL of HNPCC family members were within normal ranges compared to the general population.; - ⇔ QOL compared MMR mutation carriers to non-carriers

↑ Statistically increased

↑ Increased, but not statistically significant

⇔ No statistically significant differences

↓ Statistically decreased

↑ Decreased, but not statistically significant

Table 4 Overview table. Key Question 10

Reported Outcomes | Body of evidence (study duration) | Summary
Decision making | 6 Prosp studies (1 mo & 1 yr) | - Compared mutation carriers with non-carriers:; ↑ Intention to undergo colonoscopy & colonoscopy within 1 yr after genetic testing; ↑ TVU within 1 yr after genetic testing; ↑ Endometrial sampling within 1 yr after genetic testing; - Following a positive test result, 67% were considering prophylactic colectomy. 87% were considering prophylactic total abdominal hysterectomy and bilateral salpingo-oophorectomy
Age at onset CRC | 1 Retro study (~8 yr) | - ⇔ Comparing mutation carriers to non-carriers with MSI; - Younger, comparing mutation carriers to non-carriers with MSS
Frequency of CRC | 1 Prosp study (15 yr) | - ↓ HNPCC members who received colonoscopy screening regularly, regardless of mutation status
Survival of family members | 1 Prosp (15 yr) | - ↑ Among asymptomatic HNPCC members who received colonoscopy screening regularly, regardless of mutation status

↑ Statistically increased

↑ Increased, but not statistically significant

⇔ No statistically significant differences

↓ Statistically decreased

↓ Decreased, but not statistically significant

Table 5 Overview Table. Key Question 11

Reported Outcomes | Body of evidence (study duration) | Summary
Harms | 3 Retro studies (0.1–35 yr), 1 Prosp study (6 mo to ~8 yr), & 1 RCT (12 wk) | - 1 patient (0.25%) had a cardiac arrest due to screening exams.; - 1 patient (0.3%) had surgical complications from hysterectomy.; - ⇔ Anxiety but ↑ depression and ↓ metal health & vitality scores associated with colonoscopies. These scores were within the normal ranges for the general population.; - Colonoscopy unpleasant 57%, fearful 32%, painful 51%, shameful 16%. Worry about complications of colonoscopy 14%; - No side effect was reported for 1.5 g calcium supplementation daily
Outcomes relating to subsequent actions or interventions | 6 Retro (0.1–82 yr), 1 Prosp study (6 mo to ~8 yr), & & 1 RCT (12 wk) | - Colonoscopy and/or sigmoidoscopy:; ↓ Mortality; ↓ CRC mortality; ⇔ Risk of developing CRC; - TVU, TAH, and/or breast mammography:; ↓ Risk of extracolonic cancer; ↓ Risk of endometrial cancer; ↓ Risk of ovarian cancer; - 1.5 g calcium supplementation daily: Cytolytic activity decreased with calcium but difference was not statistically significant.; - ⇔ Survival b/w HNPCC, FAP, and sporadic CRC groups adjusting for age, gender, stage and tumor location; - 5-year survival rate in patients with gastric cancers (40% also had CRC) was 48% vs. 15%, in those who received radical surgery and those who received palliative surgery or explorative laparotomy alone, respectively.; - No cases of endometrial carcinoma detected by ultrasound but one case of endometrial carcinoma was found (in a woman with an MLH1 mutation)

TVU=transvaginal ultrasound; TAH= Prophylactic hysterectomy

↑ Statistically increased

↑ Increased, but not statistically significant

⇔ No statistically significant differences

↓ Statistically decreased

↓ Decreased, but not statistically significant