# List of Acronyms and Abbreviations

Acronym/Abbreviation | Meaning
ACCE | Four components of test evaluation—analytic validity, clinical validity, clinical utility and associated ethical, legal and social implications.
AM1, AM2 | Amsterdam I criteria, Amsterdam II criteria
AHRQ | Agency for Healthcare Research and Quality
BethR-All | Testing strategy - Perform MMR testing only among those fulfilling the revised Bethesda guidelines
BethR-IHC | Testing strategy - Perform IHC testing on patients fulfilling the revised Bethesda guidelines; perform MMR only among those with suggestive IHC test
BethR-MSI | Testing strategy - Perform MSI testing on patients fulfilling the revised Bethesda guidelines; perform MMR only among those with suggestive MSI test
CDC | Centers for Disease Control and Prevention
CI | Confidence interval
3Clinical-All | Testing strategy - Perform MMR testing only among those fulfilling at least one of the three simple clinical criteria (age <50y at diagnosis, 1^st^ degree family history of CRC or endometrial cancer or multiple, synchronous or metachronous, CRC or endometrial cancer in the same patient)
3Clinical-IHC | Testing strategy - Perform IHC testing on patients fulfilling at least one of the three simple clinical criteria (age <50y at diagnosis, 1^st^ degree family history of CRC or endometrial cancer or multiple, synchronous or metachronous, CRC or endometrial cancer in the same patient); perform MMR only among those with suggestive IHC test
3Clinical-MSI | Testing strategy - perform MSI testing on patients fulfilling at least one of the three simple clinical criteria (age <50y at diagnosis, 1^st^ degree family history of CRC or endometrial cancer or multiple, synchronous or metachronous, CRC or endometrial cancer in the same patient); perform MMR only among those with suggestive MSI test
CRC | Colorectal cancer
CSGE | Conformation sensitive gel electrophoresis
DGGE | Denaturing gradient gel electrophoresis
DHPLC | Denaturing high-pressure liquid chromatography
DNA | Deoxyribonucleic acid
EGAPP | Evaluation of Genomic Applications in Practice and Prevention (EGAPP) Project, Office of Genomics and Disease Prevention,
| Centers for Disease Control and Prevention
HNPCC | Hereditary Nonpolyposis Colorectal Cancer
hMLH1 | MMR gene mutation in the human mutL homolog 1 gene
hMSH2 | MMR gene mutation in the human mutS homolog 2 gene
hMSH6 | MMR gene mutation in the human mutS homolog 6 gene
hPMS2 | MMR gene mutation in the human postmeiotic segregation 2
IHC | Immunohistochemistry
IHC-All | Testing strategy - Perform IHC testing on all patients; followed by MMR testing only among those with suggestive IHC test
MLPA | Multiplex ligation-dependent probe amplification
MMR | Mismatch repair
MMR-All | Testing strategy - perform MMR testing on all colorectal cancer patients
MSI | Microsatellite instability
MSI-All | Testing strategy - Perform MSI testing on all patients; followed by MMR testing only among those with suggestive MSI test
MSI-high | High microsatellite instability
MSI-low | Low microsatellite instability
MSS | Microsatellite stable
NCI | National Cancer Institute
ND | No data
ROC | Receiver operating curve
SSCP | Single-stranded conformation polymorphism
SROC | Summary receiver operating curve
TEP | Technical Expert Panel