# References and Included Studies

1 Chung DC, Rustgi AK. The hereditary nonpolyposis colorectal cancer syndrome: genetics and clinical implications. Ann Intern Med. 2003;138(7):560-70. [pmid: 12667026].
2 Raevaara TE, Korhonen MK, Lohi H, et al. Functional significance and clinical phenotype of nontruncating mismatch repair variants of MLH1. Gastroenterology. 2005;129(2):537-49. [pmid: 16083711].
3 Vasen HF, Wijnen JT, Menko FH, et al. Cancer risk in families with hereditary nonpolyposis colorectal cancer diagnosed by mutation analysis. Gastroenterology. 1996;110(4):1020-7. [pmid: 8612988].
4 Lynch HT, Drouhard T, Vasen HF, et al. Genetic counseling in a Navajo hereditary nonpolyposis colorectal cancer kindred. Cancer. 1996;77(1):30-35. [pmid: 8630936].
5 Mecklin JP, Jarvinen HJ. Tumor spectrum in cancer family syndrome (hereditary nonpolyposis colorectal cancer). Cancer. 1991;68(5):1109-12. [pmid: 1913482].
6 Watson P, Lynch HT. Extracolonic cancer in hereditary nonpolyposis colorectal cancer. Cancer. 1993;71(3):677-85. [pmid: 8431847].
7 Gruber SB. New developments in Lynch syndrome (hereditary nonpolyposis colorectal cancer) and mismatch repair gene testing. Gastroenterology. 2006;130(2):577-587. [pmid: 16472609].
8 Hampel H, Frankel WL, Martin E, et al. Screening for the Lynch syndrome (hereditary nonpolyposis colorectal cancer). N Engl J Med. 2005;352(18):1851-60. [pmid: 15872200].
9 Mecklin JP. Frequency of hereditary colorectal carcinoma. Gastroenterology. 1987;93(5):1021-5. [pmid: 2820826].
10 Samowitz WS, Curtin K, Lin HH, et al. The colon cancer burden of genetically defined hereditary nonpolyposis colon cancer. Gastroenterology. 2001;121(4):830-8. [pmid: 11606497].
11 Barnetson RA, Tenesa A, Farrington SM, et al. Identification and survival of carriers of mutations in DNA mismatch-repair genes in colon cancer. N Engl J Med. 2006;354(26):2751-2763. [pmid: 16807412].
12 Pinol V, Castells A, Andreu M, et al. Accuracy of revised Bethesda guidelines, microsatellite instability, and immunohistochemistry for the identification of patients with hereditary nonpolyposis colorectal cancer. JAMA. 2005;293(16):1986-94. [pmid: 15855432].
13 Jemal A, Murray T, Ward E, et al. Cancer statistics, 2005. CA Cancer J Clin. 2005;55(1):10-30. [pmid: 15661684].
14 Banno K, Susumu N, Yanokura M, et al. Association of HNPCC and endometrial cancers. Int J Clin Oncol. 2004;9(4):262-269. [pmid: 15375702].
15 Gruber SB, Thompson WD. A population-based study of endometrial cancer and familial risk in younger women. Cancer and Steroid Hormone Study Group. Cancer Epidemiol Biomarkers Prev. 1996;5(6):411-417. [pmid: 8781735].
16 Dunlop MG, Farrington SM, Nicholl I, et al. Population carrier frequency of hMSH2 and hMLH1 mutations. Br J Cancer. 2000;83(12):1643-1645. [pmid: 11104559].
17 Douglas JA, Gruber SB, Meister KA, et al. History and molecular genetics of Lynch syndrome in family G: a century later. JAMA. 2005;294(17):2195-202. [pmid: 16264161].
18 Lu KH, Dinh M, Kohlmann W, et al. Gynecologic cancer as a “sentinel cancer” for women with hereditary nonpolyposis colorectal cancer syndrome. Obstet Gynecol. 2005;105(3):569-74. [pmid: 15738026].
19 Ramsey SD, Clarke L, Etzioni R, et al. Cost-effectiveness of microsatellite instability screening as a method for detecting hereditary nonpolyposis colorectal cancer. Ann Intern Med. 2001;135(8 Pt 1):577-88. [pmid: 11601929].
20 Hampel H, Stephens JA, Pukkala E, et al. Cancer risk in hereditary nonpolyposis colorectal cancer syndrome: later age of onset. Gastroenterology. 2005;129(2):415-21. [pmid: 16083698].
21 Jo WS, Bandipalliam P, Shannon KM, et al. Correlation of Polyp Number and Family History of Colon Cancer With Germline MYH Mutations. Clin Gastroenterol Hepatol. 2005;3(10):1022-8. [pmid: 16234049].
22 Lindor NM, Rabe K, Petersen GM, et al. Lower cancer incidence in Amsterdam-I criteria families without mismatch repair deficiency: familial colorectal cancer type X. JAMA. 2005;293(16):1979-85. [pmid: 15855431].
23 Boland CR. Decoding hereditary colorectal cancer. N Engl J Med. 2006;354(26):2815-2817. [pmid: 16807419].
24 Rodriguez-Bigas MA, Boland CR, Hamilton SR, et al. A National Cancer Institute Workshop on Hereditary Nonpolyposis Colorectal Cancer Syndrome: meeting highlights and Bethesda guidelines. J Natl Cancer Inst. 1997;89(23):1758-62. [pmid: 9392616].
25 Vasen HF, Mecklin JP, Khan PM, Lynch HT. The International Collaborative Group on Hereditary Non-Polyposis Colorectal Cancer (ICG-HNPCC). Dis Colon Rectum. 1991;34(5):424-5. [pmid: 2022152].
26 Vasen HF, Watson P, Mecklin JP, Lynch HT. New clinical criteria for hereditary nonpolyposis colorectal cancer (HNPCC, Lynch syndrome) proposed by the International Collaborative group on HNPCC. Gastroenterology. 1999;116(6):1453-6. [pmid: 10348829].
27 Umar A, Boland CR, Terdiman JP, et al. Revised Bethesda Guidelines for hereditary nonpolyposis colorectal cancer (Lynch syndrome) and microsatellite instability. J Natl Cancer Inst. 2004;96(4):261-8. [pmid: 14970275].
28 Wullenweber HP, Sutter C, Autschbach F, et al. Evaluation of Bethesda guidelines in relation to microsatellite instability. Dis Colon Rectum. 2001;44(9):1281-9. [pmid: 11584201].
29 Raedle J, Trojan J, Brieger A, et al. Bethesda guidelines: relation to microsatellite instability and MLH1 promoter methylation in patients with colorectal cancer. Ann Intern Med. 2001;135(8 Pt 1):566-76. [pmid: 11601928].
30 Murff HJ, Spigel DR, Syngal S. Does this patient have a family history of cancer? An evidence-based analysis of the accuracy of family cancer history. JAMA. 2004;292(12):1480-9. [pmid: 15383520].
31 Grover S, Stoffel EM, Bussone L, Tschoegl E, Syngal S. Physician assessment of family cancer history and referral for genetic evaluation in colorectal cancer patients. Clin Gastroenterol Hepatol. 2004;2(9):813-9. [pmid: 15354282].
32 Ward RL, Turner J, Williams R, et al. Routine testing for mismatch repair deficiency in sporadic colorectal cancer is justified. J Pathol. 2005;207(4):377-384. [pmid: 16175654].
33 Giardiello FM, Brensinger JD, Petersen GM. AGA technical review on hereditary colorectal cancer and genetic testing. Gastroenterology. 2001;121(1):198-213. [pmid: 11438509].
34 Engel C, Forberg J, Holinski-Feder E, et al. Novel strategy for optimal sequential application of clinical criteria, immunohistochemistry and microsatellite analysis in the diagnosis of hereditary nonpolyposis colorectal cancer. Int J Cancer. 2006;118(1):115-122. [pmid: 16003745].
35 Young J, Simms LA, Biden KG, et al. Features of colorectal cancers with high-level microsatellite instability occurring in familial and sporadic settings: parallel pathways of tumorigenesis. Am J Pathol. 2001;159(6):2107-16. [pmid: 11733361]. [pmcid: 1850604].
36 Alexander J, Watanabe T, Wu TT, et al. Histopathological identification of colon cancer with microsatellite instability. Am J Pathol. 2001;158(2):527-35. [pmid: 11159189]. [pmcid: 1850324].
37 De Felice C, Parrini S, Chitano G, et al. Fordyce granules and hereditary non-polyposis colorectal cancer syndrome. Gut. 2005;54(9):1279-1282. [pmid: 15879014]. [pmcid: 1774669].
38 Jover R, Paya A, Alenda C, et al. Defective mismatch-repair colorectal cancer: clinicopathologic characteristics and usefulness of immunohistochemical analysis for diagnosis. Am J Clin Pathol. 2004;122(3):389-94. [pmid: 15362369].
39 Lindor NM, Burgart LJ, Leontovich O, et al. Immunohistochemistry versus microsatellite instability testing in phenotyping colorectal tumors. J Clin Oncol. 2002;20(4):1043-8. [pmid: 11844828].
40 Young NA, Moriarty AT, Walsh MK, Wang E, Wilbur DC. The potential for failure in gynecologic regulatory proficiency testing with current slide validation criteria: results from the College of American Pathologists Interlaboratory Comparison in Gynecologic Cytology Program. Arch Pathol Lab Med. 2006;130(8):1114-1118. [pmid: 16879010].
41 Statement of the American Society of Clinical Oncology: genetic testing for cancer susceptibility, Adopted on February 20, 1996. J Clin Oncol 1996; 14(5):1730–6.
42 Jarvinen HJ, Aarnio M, Mustonen H, et al. Controlled 15-year trial on screening for colorectal cancer in families with hereditary nonpolyposis colorectal cancer. Gastroenterology. 2000;118(5):829-34. [pmid: 10784581].
43 Syngal S, Weeks JC, Schrag D, Garber JE, Kuntz KM. Benefits of colonoscopic surveillance and prophylactic colectomy in patients with hereditary nonpolyposis colorectal cancer mutations. Ann Intern Med. 1998;129(10):787-96. [pmid: 9841584].
44 Dove-Edwin I, Boks D, Goff S, et al. The outcome of endometrial carcinoma surveillance by ultrasound scan in women at risk of hereditary nonpolyposis colorectal carcinoma and familial colorectal carcinoma. Cancer. 2002;94(6):1708-12. [pmid: 11920532].
45 Rijcken FE, Mourits MJ, Kleibeuker JH, Hollema H, van der Zee AG. Gynecologic screening in hereditary nonpolyposis colorectal cancer. Gynecol Oncol. 2003;91(1):74-80. [pmid: 14529665].
46 Lynch HT, Riley BD, Weissman SM, et al. Hereditary nonpolyposis colorectal carcinoma (HNPCC) and HNPCC-like families: Problems in diagnosis, surveillance, and management. Cancer. 2004;100(1):53-64. [pmid: 14692024].
47 Zhou XP, Hoang JM, Li YJ, et al. Determination of the replication error phenotype in human tumors without the requirement for matching normal DNA by analysis of mononucleotide repeat microsatellites. Genes Chromosomes Cancer. 1998;21(2):101-107. [pmid: 9491320].
48 Balk EM, Bonis PA, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287(22):2973-2982. [pmid: 12052127].
49 Little J, Bradley L, Bray MS, et al. Reporting, appraising, and integrating data on genotype prevalence and gene-disease associations. Am J Epidemiol. 2002;156(4):300-310. [pmid: 12181099].
50 Whiting P, Rutjes AW, Reitsma JB, Bossuyt PM, Kleijnen J. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960]. [pmcid: 305345].
51 Jackson N. The Cochrane Collaboration Handbook for systematic reviews of health promotion and public health interventions. Cochrane. 2006. 2-1-2006.
52 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188. [pmid: 3802833].
53 Raudenbusch SW. Random effects models. In: Cooper H, Hedges LV, editors. The handbook of research synthesis. New York: Russel Sage Foundation, 1994: 301–323.
54 Mulherin SA, Miller WC. Spectrum bias or spectrum effect? Subgroup variation in diagnostic test evaluation. Ann Intern Med. 2002;137(7):598-602. [pmid: 12353947].
55 Syngal S, Fox EA, Li C, et al. Interpretation of genetic test results for hereditary nonpolyposis colorectal cancer: implications for clinical predisposition testing. JAMA. 1999;282(3):247-253. [pmid: 10422993].
56 Muller W, Burgart LJ, Krause-Paulus R, et al. The reliability of immunohistochemistry as a prescreening method for the diagnosis of hereditary nonpolyposis colorectal cancer (HNPCC)—results of an international collaborative study. Fam Cancer. 2001;1(2):87-92. [pmid: 14574003].
57 Aitken J, Bain C, Ward M, Siskind V, MacLennan R. How accurate is self-reported family history of colorectal cancer?. Am J Epidemiol. 1995;141(9):863-871. [pmid: 7717363].
58 Mitchell RJ, Brewster D, Campbell H, et al. Accuracy of reporting of family history of colorectal cancer. Gut. 2004;53(2):291-295. [pmid: 14724166]. [pmcid: 1774933].
59 Murff HJ, Spigel DR, Syngal S. Does this patient have a family history of cancer? An evidence-based analysis of the accuracy of family cancer history. JAMA. 2004;292(12):1480-1489. [pmid: 15383520].
60 Ziogas A, nton-Culver H. Validation of family history data in cancer family registries. Am J Prev Med. 2003;24(2):190-198. [pmid: 12568826].
61 Casey G, Lindor NM, Papadopoulos N, et al. Conversion analysis for mutation detection in MLH1 and MSH2 in patients with colorectal cancer. JAMA. 2005;293(7):799-809. [pmid: 15713769].
62 Kurzawski G, Safranow K, Suchy J, et al. Mutation analysis of MLH1 and MSH2 genes performed by denaturing high-performance liquid chromatography. J Biochem Biophys Methods. 2002;51(1):89-100. [pmid: 11879922].
63 Aaltonen LA, Salovaara R, Kristo P, et al. Incidence of hereditary nonpolyposis colorectal cancer and the feasibility of molecular screening for the disease. N Engl J Med. 1998;338(21):1481-1487. [pmid: 9593786].
64 Calistri D, Presciuttini S, Buonsanti G, et al. Microsatellite instability in colorectal-cancer patients with suspected genetic predisposition. Int J Cancer. 2000;89(1):87-91. [pmid: 10719736].
65 Christensen M, Katballe N, Wikman F, et al. Antibody-based screening for hereditary nonpolyposis colorectal carcinoma compared with microsatellite analysis and sequencing. Cancer. 2002;95(11):2422-2430. [pmid: 12436451].
66 Curia MC, Palmirotta R, Aceto G, et al. Unbalanced germ-line expression of hMLH1 and hMSH2 alleles in hereditary nonpolyposis colorectal cancer. Cancer Res. 1999;59(15):3570-3575. [pmid: 10446963].
67 de Abajo SA, de la HM, Tosar A, et al. Low prevalence of germline hMSH6 mutations in colorectal cancer families from Spain. World J Gastroenterol. 2005;11(37):5770-5776. [pmid: 16270383].
68 de Leon MP, Pedroni M, Benatti P, et al. Hereditary colorectal cancer in the general population: from cancer registration to molecular diagnosis. Gut. 1999;45(1):32-38. [pmid: 10369701]. [pmcid: 1727564].
69 Debniak T, Kurzawski G, Gorski B, et al. Value of pedigree/clinical data, immunohistochemistry and microsatellite instability analyses in reducing the cost of determining hMLH1 and hMSH2 gene mutations in patients with colorectal cancer. Eur J Cancer. 2000;36(1):49-54. [pmid: 10741294].
70 Dieumegard B, Grandjouan S, Sabourin JC, et al. Extensive molecular screening for hereditary non-polyposis colorectal cancer. Br J Cancer. 2000;82(4):871-880. [pmid: 10732761].
71 Katballe N, Christensen M, Wikman FP, Orntoft TF, Laurberg S. Frequency of hereditary non-polyposis colorectal cancer in Danish colorectal cancer patients. Gut. 2002;50(1):43-51. [pmid: 11772966]. [pmcid: 1773070].
72 Lamberti C, Kruse R, Ruelfs C, et al. Microsatellite instability-a useful diagnostic tool to select patients at high risk for hereditary non-polyposis colorectal cancer: a study in different groups of patients with colorectal cancer. Gut. 1999;44(6):839-843. [pmid: 10323887]. [pmcid: 1727554].
73 Liu SR, Zhao B, Wang ZJ, Wan YL, Huang YT. Clinical features and mismatch repair gene mutation screening in Chinese patients with hereditary nonpolyposis colorectal carcinoma. World J Gastroenterol. 2004;10(18):2647-2651. [pmid: 15309712].
74 Luce MC, Marra G, Chauhan DP, et al. In vitro transcription/translation assay for the screening of hMLH1 and hMSH2 mutations in familial colon cancer. Gastroenterology. 1995;109(4):1368-1374. [pmid: 7557107].
75 Moslein G, Tester DJ, Lindor NM, et al. Microsatellite instability and mutation analysis of hMSH2 and hMLH1 in patients with sporadic, familial and hereditary colorectal cancer. Hum Mol Genet. 1996;5(9):1245-1252. [pmid: 8872463].
76 Park JG, Vasen HF, Park KJ, et al. Suspected hereditary nonpolyposis colorectal cancer: International Collaborative Group on Hereditary Non-Polyposis Colorectal Cancer (ICG-HNPCC) criteria and results of genetic diagnosis. Dis Colon Rectum. 1999;42(6):710-715. [pmid: 10378593].
77 Rossi BM, Lopes A, Oliveira FF, et al. hMLH1 and hMSH2 gene mutation in Brazilian families with suspected hereditary nonpolyposis colorectal cancer. Ann Surg Oncol. 2002;9(6):555-561. [pmid: 12095971].
78 Stormorken AT, Muller W, Lemkemeyer B, et al. Prediction of the outcome of genetic testing in HNPCC kindreds using the revised Amsterdam criteria and immunohistochemistry. Fam Cancer. 2001;1(34):169-173. [pmid: 14574174].
79 Syngal S, Fox EA, Eng C, Kolodner RD, Garber JE. Sensitivity and specificity of clinical criteria for hereditary non-polyposis colorectal cancer associated mutations in MSH2 and MLH1. J Med Genet. 2000;37(9):641-645. [pmid: 10978352]. [pmcid: 1734690].
80 Wahlberg SS, Schmeits J, Thomas G, et al. Evaluation of microsatellite instability and immunohistochemistry for the prediction of germ-line MSH2 and MLH1 mutations in hereditary nonpolyposis colon cancer families. Cancer Res. 2002;62(12):3485-3492. [pmid: 12067992].
81 Wang Q, Lasset C, Desseigne F, et al. Prevalence of germline mutations of hMLH1, hMSH2, hPMS1, hPMS2, and hMSH6 genes in 75 French kindreds with nonpolyposis colorectal cancer. Hum Genet. 1999;105(12):79-85. [pmid: 10480359].
82 Yuan Y, Huang YQ, Cai SR, et al. Genetic characterization of Chinese hereditary non-polyposis colorectal cancer by DHPLC and multiplex PCR. Jpn J Clin Oncol. 2004;34(11):660-666. [pmid: 15613555].
83 Colombino M, Cossu A, Budroni M, et al. Identification of predictive factors for the occurrence of predisposing MLH1 and MSH2 germline mutations among Sardinian patients with colorectal carcinoma. Eur J Cancer. 2005;41(7):1058-1064. [pmid: 15862756].
84 Lee SC, Guo JY, Lim R, et al. Clinical and molecular characteristics of hereditary non-polyposis colorectal cancer families in Southeast Asia. Clin Genet. 2005;68(2):137-145. [pmid: 15996210].
85 Salovaara R, Loukola A, Kristo P, et al. Population-based molecular detection of hereditary nonpolyposis colorectal cancer. J Clin Oncol. 2000;18(11):2193-2200. [pmid: 10829038].
86 Wolf B, Gruber S, Henglmueller S, et al. Efficiency of the revised Bethesda guidelines (2003) for the detection of mutations in mismatch repair genes in Austrian HNPCC patients. Int J Cancer 2005.
87 Zhu M, Li J, Zhang X, et al. Large genomic aberrations in MSH2 and MLH1 genes are frequent in Chinese colorectal cancer. Cancer Genet Cytogenet. 2005;160(1):61-67. [pmid: 15949572].
88 Peltomaki P, Vasen H. Mutations associated with HNPCC predisposition — Update of ICG-HNPCC/INSiGHT mutation database. Dis Markers. 2004;20(45):269-276. [pmid: 15528792].
89 van der Klift H, Wijnen J, Wagner A, et al. Molecular characterization of the spectrum of genomic deletions in the mismatch repair genes MSH2, MLH1, MSH6, and PMS2 responsible for hereditary nonpolyposis colorectal cancer (HNPCC). Genes Chromosomes Cancer. 2005;44(2):123-138. [pmid: 15942939].
90 Lynch HT, Coronel SM, Okimoto R, et al. A founder mutation of the MSH2 gene and hereditary nonpolyposis colorectal cancer in the United States. JAMA. 2004;291(6):718-724. [pmid: 14871915].
91 Lynch HT, de la CA, Hampel H, et al. American founder mutation for Lynch syndrome. Prevalence estimates and implications. Cancer. 2006;106(2):448-452. [pmid: 16353207].
92 Balmana J, Stockwell DH, Steyerberg EW, et al. Prediction of MLH1 and MSH2 mutations in Lynch syndrome. JAMA. 2006;296(12):1469-1478. [pmid: 17003395].
93 Wagner A, Barrows A, Wijnen JT, et al. Molecular analysis of hereditary nonpolyposis colorectal cancer in the United States: high mutation detection rate among clinically selected families and characterization of an American founder genomic deletion of the MSH2 gene. Am J Hum Genet. 2003;72(5):1088-1100. [pmid: 12658575]. [pmcid: 1180263].
94 Liu B, Parsons R, Papadopoulos N, et al. Analysis of mismatch repair genes in hereditary non-polyposis colorectal cancer patients. Nat Med. 1996;2(2):169-174. [pmid: 8574961].
95 Peel DJ, Ziogas A, Fox EA, et al. Characterization of hereditary nonpolyposis colorectal cancer families from a population-based series of cases. J Natl Cancer Inst. 2000;92(18):1517-1522. [pmid: 10995807].
96 Nakahara M, Yokozaki H, Yasui W, Dohi K, Tahara E. Identification of concurrent germ-line mutations in hMSH2 and/or hMLH1 in Japanese hereditary nonpolyposis colorectal cancer kindreds. Cancer Epidemiol Biomarkers Prev. 1997;6(12):1057-1064. [pmid: 9419403].
97 Pistorius SR, Kruppa C, Haas S, et al. Clinical consequences of molecular diagnosis in families with mismatch repair gene germline mutations. Int J Colorectal Dis. 2000;15(56):255-263. [pmid: 11151427].
98 Terdiman JP, Gum JR Jr, Conrad PG, et al. Efficient detection of hereditary nonpolyposis colorectal cancer gene carriers by screening for tumor microsatellite instability before germline genetic testing. Gastroenterology. 2001;120(1):21-30. [pmid: 11208710].
99 Yuan Y, Han HJ, Zheng S, Park JG. Germline mutations of hMLH1 and hMSH2 genes in patients with suspected hereditary nonpolyposis colorectal cancer and sporadic early-onset colorectal cancer. Dis Colon Rectum. 1998;41(4):434-440. [pmid: 9559627].
100 Durno C, Aronson M, Bapat B, Cohen Z, Gallinger S. Family history and molecular features of children, adolescents, and young adults with colorectal carcinoma. Gut. 2005;54(8):1146-1150. [pmid: 15845562]. [pmcid: 1774876].
101 Farrington SM, Lin-Goerke J, Ling J, et al. Systematic analysis of hMSH2 and hMLH1 in young colon cancer patients and controls. Am J Hum Genet. 1998;63(3):749-759. [pmid: 9718327]. [pmcid: 1377385].
102 Southey MC, Jenkins MA, Mead L, et al. Use of molecular tumor characteristics to prioritize mismatch repair gene testing in early-onset colorectal cancer. J Clin Oncol. 2005;23(27):6524-6532. [pmid: 16116158].
103 Wijnen JT, Vasen HF, Khan PM, et al. Clinical findings with implications for genetic testing in families with clustering of colorectal cancer. N Engl J Med. 1998;339(8):511-518. [pmid: 9709044].
104 Gritz ER, Peterson SK, Vernon SW, et al. Psychological impact of genetic testing for hereditary nonpolyposis colorectal cancer. J Clin Oncol. 2005;23(9):1902-1910. [pmid: 15774782].
105 Murakami Y, Okamura H, Sugano K, et al. Psychologic distress after disclosure of genetic test results regarding hereditary nonpolyposis colorectal carcinoma. Cancer. 2004;101(2):395-403. [pmid: 15241839].
106 Porteous M, Dunckley M, Appleton S, et al. Is it acceptable to approach colorectal cancer patients at diagnosis to discuss genetic testing? A pilot study. Br J Cancer. 2003;89(8):1400-1402. [pmid: 14562005].
107 Keller M, Jost R, Haunstetter CM, et al. Comprehensive genetic counseling for families at risk for HNPCC: impact on distress and perceptions. Genet Test. 2002;6(4):291-302. [pmid: 12537653].
108 Fujita S, Moriya Y, Sugihara K, Akasu T, Ushio K. Prognosis of hereditary nonpolyposis colorectal cancer (HNPCC) and the role of Japanese criteria for HNPCC. Jpn J Clin Oncol. 1996;26(5):351-355. [pmid: 8895676].
109 Tomoda H, Baba H, Oshiro T. Clinical manifestations in patients with hereditary nonpolyposis colorectal cancer. J Surg Oncol. 1996;61(4):262-266. [pmid: 8627995].
110 Van Dalen R, Church J, McGannon E, et al. Patterns of surgery in patients belonging to amsterdam-positive families. Dis Colon Rectum. 2003;46(5):617-620. [pmid: 12792437].
111 Kruhoffer M, Jensen JL, Laiho P, et al. Gene expression signatures for colorectal cancer microsatellite status and HNPCC. Br J Cancer. 2005;92(12):2240-2248. [pmid: 15956967].
112 Benatti P, Roncucci L, Ganazzi D, et al. Clinical and biologic heterogeneity of hereditary nonpolyposis colorectal cancer. Int J Cancer. 2001;95(5):323-328. [pmid: 11494233].
113 Boks DE, Trujillo AP, Voogd AC, et al. Survival analysis of endometrial carcinoma associated with hereditary nonpolyposis colorectal cancer. Int J Cancer. 2002;102(2):198-200. [pmid: 12385019].
114 Perrin J, Gouvernet J, Parriaux D, et al. MSH2 and MLH1 immunodetection and the prognosis of colon cancer. Int J Oncol. 2001;19(5):891-895. [pmid: 11604984].
115 Bertario L, Russo A, Sala P, et al. Survival of patients with hereditary colorectal cancer: comparison of HNPCC and colorectal cancer in FAP patients with sporadic colorectal cancer. Int J Cancer. 1999;80(2):183-187. [pmid: 9935197].
116 Aarnio M, Salovaara R, Aaltonen LA, Mecklin JP, Jarvinen HJ. Features of gastric cancer in hereditary non-polyposis colorectal cancer syndrome. Int J Cancer. 1997;74(5):551-555. [pmid: 9355980].
117 Gryfe R, Kim H, Hsieh ET, et al. Tumor microsatellite instability and clinical outcome in young patients with colorectal cancer. N Engl J Med. 2000;342(2):69-77. [pmid: 10631274].
118 Halling KC, French AJ, McDonnell SK, et al. Microsatellite instability and 8p allelic imbalance in stage B2 and C colorectal cancers. J Natl Cancer Inst. 1999;91(15):1295-1303. [pmid: 10433618].
119 Elsaleh H, Joseph D, Grieu F, et al. Association of tumour site and sex with survival benefit from adjuvant chemotherapy in colorectal cancer. Lancet. 2000;355(9217):1745-1750. [pmid: 10832824].
120 Popat S, Hubner R, Houlston RS. Systematic review of microsatellite instability and colorectal cancer prognosis. J Clin Oncol. 2005;23(3):609-618. [pmid: 15659508].
121 Benson AB III, Schrag D, Somerfield MR, et al. American Society of Clinical Oncology recommendations on adjuvant chemotherapy for stage II colon cancer. J Clin Oncol. 2004;22(16):3408-3419. [pmid: 15199089].
122 Bermejo JL, Eng C, Hemminki K. Cancer characteristics in Swedish families fulfilling criteria for hereditary nonpolyposis colorectal cancer. Gastroenterology. 2005;129(6):1889-1899. [pmid: 16344057].
123 Cederquist K, Golovleva I, Emanuelsson M, Stenling R, Gronberg H. A population based cohort study of patients with multiple colon and endometrial cancer: correlation of microsatellite instability (MSI) status, age at diagnosis and cancer risk. Int J Cancer. 2001;91(4):486-491. [pmid: 11251970].
124 Brown SR, Finan PJ, Bishop DT. Are relatives of patients with multiple HNPCC spectrum tumours at increased risk of cancer?. Gut. 1998;43(5):664-668. [pmid: 9824348]. [pmcid: 1727311].
125 Bradshaw N, Holloway S, Penman I, Dunlop MG, Porteous ME. Colonoscopy surveillance of individuals at risk of familial colorectal cancer. Gut. 2003;52(12):1748-1751. [pmid: 14633955]. [pmcid: 1773898].
126 Dunlop MG, Farrington SM, Carothers AD, et al. Cancer risk associated with germline DNA mismatch repair gene mutations. Hum Mol Genet. 1997;6(1):105-110. [pmid: 9002677].
127 Plaschke J, Engel C, Kruger S, et al. Lower incidence of colorectal cancer and later age of disease onset in 27 families with pathogenic MSH6 germline mutations compared with families with MLH1 or MSH2 mutations: the German Hereditary Nonpolyposis Colorectal Cancer Consortium. J Clin Oncol. 2004;22(22):4486-4494. [pmid: 15483016].
128 Lindgren G, Liljegren A, Jaramillo E, Rubio C, Lindblom A. Adenoma prevalence and cancer risk in familial non-polyposis colorectal cancer. Gut. 2002;50(2):228-234. [pmid: 11788565]. [pmcid: 1773092].
129 Vasen HF, Stormorken A, Menko FH, et al. MSH2 mutation carriers are at higher risk of cancer than MLH1 mutation carriers: a study of hereditary nonpolyposis colorectal cancer families. J Clin Oncol. 2001;19(20):4074-4080. [pmid: 11600610].
130 Scott RJ, McPhillips M, Meldrum CJ, et al. Hereditary nonpolyposis colorectal cancer in 95 families: differences and similarities between mutation-positive and mutation-negative kindreds. Am J Hum Genet. 2001;68(1):118-127. [pmid: 11112663]. [pmcid: 1234904].
131 Lin KM, Shashidharan M, Thorson AG, et al. Cumulative incidence of colorectal and extracolonic cancers in MLH1 and MSH2 mutation carriers of hereditary nonpolyposis colorectal cancer. J Gastrointest Surg. 1998;2(1):67-71. [pmid: 9841970].
132 Aarnio M, Sankila R, Pukkala E, et al. Cancer risk in mutation carriers of DNA-mismatch-repair genes. Int J Cancer. 1999;81(2):214-218. [pmid: 10188721].
133 Brain K, Sivell S, Bennert K, et al. An exploratory comparison of genetic counselling protocols for HNPCC predictive testing. Clin Genet. 2005;68(3):255-261. [pmid: 16098015].
134 Arver B, Haegermark A, Platten U, Lindblom A, Brandberg Y. Evaluation of psychosocial effects of pre-symptomatic testing for breast/ovarian and colon cancer pre-disposing genes: a 12-month follow-up. Fam Cancer. 2004;3(2):109-116. [pmid: 15340261].
135 Aktan-Collan K, Haukkala A, Kaariainen H. Life and health insurance behaviour of individuals having undergone a predictive genetic testing programme for hereditary non-polyposis colorectal cancer. Community Genet. 2001;4(4):219-224. [pmid: 12751485].
136 Aktan-Collan K, Haukkala A, Mecklin JP, Uutela A, Kaariainen H. Psychological consequences of predictive genetic testing for hereditary non-polyposis colorectal cancer (HNPCC): a prospective follow-up study. Int J Cancer. 2001;93(4):608-611. [pmid: 11477567].
137 Aktan-Collan K, Mecklin JP, Jarvinen H, et al. Predictive genetic testing for hereditary non-polyposis colorectal cancer: uptake and long-term satisfaction. Int J Cancer. 2000;89(1):44-50. [pmid: 10719730].
138 Aktan-Collan K, Mecklin JP, de la CA, et al. Evaluation of a counselling protocol for predictive genetic testing for hereditary non-polyposis colorectal cancer. J Med Genet. 2000;37(2):108-113. [pmid: 10662810]. [pmcid: 1734517].
139 Claes E, Denayer L, Evers-Kiebooms G, Boogaerts A, Legius E. Predictive testing for hereditary non-polyposis colorectal cancer: motivation, illness representations and short-term psychological impact. Patient Educ Couns. 2004;55(2):265-274. [pmid: 15530764].
140 Claes E, Denayer L, Evers-Kiebooms G, et al. Predictive testing for hereditary nonpolyposis colorectal cancer: subjective perception regarding colorectal and endometrial cancer, distress, and health-related behavior at one year post-test. Genet Test. 2005;9(1):54-65. [pmid: 15857188].
141 Lynch HT, Lemon SJ, Karr B, et al. Etiology, natural history, management and molecular genetics of hereditary nonpolyposis colorectal cancer (Lynch syndromes): genetic counseling implications. Cancer Epidemiol Biomarkers Prev. 1997;6(12):987-991. [pmid: 9419392].
142 Meiser B, Collins V, Warren R, et al. Psychological impact of genetic testing for hereditary non-polyposis colorectal cancer. Clin Genet. 2004;66(6):502-511. [pmid: 15521977].
143 Mesters I, Ausems M, Eichhorn S, Vasen H. Informing one's family about genetic testing for hereditary non-polyposis colorectal cancer (HNPCC): a retrospective exploratory study. Fam Cancer. 2005;4(2):163-167. [pmid: 15951968].
144 Peterson SK, Watts BG, Koehly LM, et al. How families communicate about HNPCC genetic testing: findings from a qualitative study. Am J Med Genet C Semin Med Genet. 2003;119(1):78-86. [pmid: 12704641].
145 Berth H, Balck F, Dinkel A. Attitudes toward genetic testing in patients at risk for HNPCC/FAP and the German population. Genet Test. 2002;6(4):273-280. [pmid: 12537651].
146 Brodersen NH, Sutton S, Goff S, Hodgson SV, Thomas HJ. Anticipated reactions to genetic testing for hereditary non-polyposis colorectal cancer susceptibility. Clin Genet. 2004;66(5):437-444. [pmid: 15479189].
147 Codori AM, Petersen GM, Miglioretti DL, et al. Attitudes toward colon cancer gene testing: factors predicting test uptake. Cancer Epidemiol Biomarkers Prev. 1999;8(4 Pt 2):345-351. [pmid: 10207639].
148 Hadley DW, Jenkins J, Dimond E, et al. Genetic counseling and testing in families with hereditary nonpolyposis colorectal cancer. Arch Intern Med. 2003;163(5):573-582. [pmid: 12622604].
149 Keller M, Jost R, Kadmon M, et al. Acceptance of and attitude toward genetic testing for hereditary nonpolyposis colorectal cancer: a comparison of participants and nonparticipants in genetic counseling. Dis Colon Rectum. 2004;47(2):153-162. [pmid: 15043284].
150 Lerman C, Marshall J, Audrain J, Gomez-Caminero A. Genetic testing for colon cancer susceptibility: Anticipated reactions of patients and challenges to providers. Int J Cancer. 1996;69(1):58-61. [pmid: 8600064].
151 Gaff CL, Collins V, Symes T, Halliday J. Facilitating family communication about predictive genetic testing: probands' perceptions. J Genet Couns. 2005;14(2):133-140. [pmid: 15959644].
152 Brain K, Soldan J, Sampson J, Gray J. Genetic counselling protocols for hereditary non-polyposis colorectal cancer: a survey of UK regional genetics centres. Clin Genet. 2003;63(3):198-204. [pmid: 12694229].
153 Norum J, Tranebjaerg L. Health, life and disability insurance and hereditary risk for breast or colorectal cancer. Acta Oncol. 2000;39(2):189-193. [pmid: 10859009].
154 Collins V, Meiser B, Gaff C, St John DJ, Halliday J. Screening and preventive behaviors one year after predictive genetic testing for hereditary nonpolyposis colorectal carcinoma. Cancer. 2005;104(2):273-281. [pmid: 15948171].
155 Hadley DW, Jenkins JF, Dimond E, et al. Colon cancer screening practices after genetic counseling and testing for hereditary nonpolyposis colorectal cancer. J Clin Oncol. 2004;22(1):39-44. [pmid: 14701766].
156 Green SE, Chapman PD, Burn J, Bishop DT, Varma JS. Clinical impact of colonoscopic screening in first-degree relatives of patients with hereditary non-polyposis colorectal cancer. Br J Surg. 1995;82(10):1338-1340. [pmid: 7489157].
157 Wagner A, van K, I, Kriege MG, et al. Long term follow-up of HNPCC gene mutation carriers: compliance with screening and satisfaction with counseling and screening procedures. Familial Cancer. 2005;4(4):295-300. [pmid: 16341806].
158 Arrigoni A, Sprujevnik T, Alvisi V, et al. Clinical identification and long-term surveillance of 22 hereditary non-polyposis colon cancer Italian families. Eur J Gastroenterol Hepatol. 2005;17(2):213-219. [pmid: 15674100].
159 Liljegren A, Lindgren G, Brandberg Y, et al. Individuals with an increased risk of colorectal cancer: perceived benefits and psychological aspects of surveillance by means of regular colonoscopies. J Clin Oncol. 2004;22(9):1736-1742. [pmid: 15117997].
160 Jarvinen HJ, Mecklin JP, Sistonen P. Screening reduces colorectal cancer rate in families with hereditary nonpolyposis colorectal cancer. Gastroenterology. 1995;108(5):1405-1411. [pmid: 7729632].
161 Vasen HF, Taal BG, Nagengast FM, et al. Hereditary nonpolyposis colorectal cancer: results of long-term surveillance in 50 families. Eur J Cancer. 1995;31A(78):1145-1148. [pmid: 7577010].
162 Renkonen-Sinisalo L, Aarnio M, Mecklin JP, Jarvinen HJ. Surveillance improves survival of colorectal cancer in patients with hereditary nonpolyposis colorectal cancer. Cancer Detect Prev. 2000;24(2):137-142. [pmid: 10917133].
163 Schmeler KM, Lynch HT, Chen LM, et al. Prophylactic surgery to reduce the risk of gynecologic cancers in the Lynch syndrome.[see comment]. New England Journal of Medicine. 2006;354(3):261-269. [pmid: 16421367].
164 Cats A, Kleibeuker JH, van der MR, et al. Randomized, double-blinded, placebo-controlled intervention study with supplemental calcium in families with hereditary nonpolyposis colorectal cancer. J Natl Cancer Inst. 1995;87(8):598-603. [pmid: 7752258].
165 Halbert CH, Lynch H, Lynch J, et al. Colon cancer screening practices following genetic testing for hereditary nonpolyposis colon cancer (HNPCC) mutations. Arch Intern Med. 2004;164(17):1881-1887. [pmid: 15451763].
166 Bleiker EM, Menko FH, Taal BG, et al. Screening behavior of individuals at high risk for colorectal cancer. Gastroenterology. 2005;128(2):280-287. [pmid: 15685539].
167 Adams J, White M, Barker G, Mathers J, Burn J. Are there socio-economic inequalities in age of resection of colorectal cancer in people with HNPCC?. Fam Cancer. 2003;2(34):169-173. [pmid: 14707528].
168 Lindor NM, Smalley R, Barker M, et al. Ascending the learning curve - MSI testing experience of a six-laboratory consortium. Cancer Biomark. 2006;2(12):5-9. [pmid: 17192055].