# Executive Summary

## Introduction

Individuals with a familial predisposition to cancer pose an increasing challenge for healthcare systems hoping to provide state-of-the-art care. Optimal strategies for recognizing them, performing (and interpreting) genetic testing, and preventing cancers in at-risk family members have not been well established when considering overall benefits, harms, and costs. The challenges involved will likely become increasingly complicated with advances in understanding of the molecular genetics underlying cancer risk. In this report, we attempt to clarify many of these issues for one form of hereditary cancer, Hereditary Nonpolyposis Colorectal Cancer (HNPCC). HNPCC is associated with a substantially increased risk for several forms of malignancy but particularly colorectal and endometrial cancer.

HNPCC has been defined clinically and genetically. As a genetic disease, it is inherited as an autosomal dominant disorder (with variable penetrance) caused by mutations in DNA mismatch repair (MMR) genes. As a clinical disorder, it can be defined as a clustering of related cancers across generations in a kindred. The disorder has also been referred to as the “Lynch syndrome” in recognition of Henry Lynch, who in 1966 described familial aggregation of colorectal cancer with gastric and endometrial cancer in two large kindreds (although it was first reported by the eminent pathologist Aldred Warthin in 1913).

These definitions are not entirely distinct since the disorder is typically recognized in patients or kindreds with clinical expression of the disease who have an associated genotype. However, the ability to perform predictive genetic testing in individuals with cancer and asymptomatic family members makes it imperative to fully understand its implications. There remain many uncertainties regarding how HNPCC should be identified in patients presenting with associated malignancies, and the full spectrum of implications related to screening and management options for the patient and their at-risk family members. Does, for example, the identification of MMR genotypes in family members of patients with HNPCC-related cancers improve their outcomes compared with management approaches that do not involve predictive genetic testing? What is the likelihood that a family member with a MMR mutation is destined to develop HNPCC-related cancers, and does screening for these cancers improve outcomes?

There were three main objectives of this report: (1) to assess the sensitivity, specificity and reliability of laboratory and genetic tests commonly used in evaluating patients for HNPCC (analytic validity); (2) to summarize the accuracy of commonly used clinical and laboratory characteristics for predicting the presence of HNPCC in patients with colorectal cancer (clinical validity) and to describe the efficiency of various strategies for identifying patients with a mismatch repair mutation; and (3) to describe the benefits and harms related to screening and testing patients with colorectal cancer (CRC) and their family members for HNPCC.

This report is based upon a systematic review of the literature. The Key Questions that it addresses were proposed through the Agency for Healthcare Research and Quality (AHRQ) on behalf of the Centers for Disease Control and Prevention (CDC) Evaluation of Genomic Applications in Practice and Prevention (EGAPP) Project. EGAPP is a three-year model project developed by CDC's Office of Genomics and Disease Prevention to address the increasingly urgent need for timely and objective information that will allow health care providers, consumers, policy makers and payers to distinguish tests that are safe and useful, and to guide their appropriate use in practice.

The Key Questions Addressed Include the Following:

Key Question 1: Does risk assessment and HNPCC mutation testing in patients with newly diagnosed CRC lead to improved outcomes for the patient or family members, or is it useful in medical, personal, or public health decision making? (Over-arching question).

Key Question 2a: Assuming a clinical definition of the Lynch Syndrome, what proportion of patients has a mismatch repair mutation?

2b: Assuming a clinical definition of the Lynch Syndrome, what proportion of patients has MSI?

2c: Assuming a clinical definition of the Lynch Syndrome, what proportion of patients has abnormal protein expression by immunohistochemistry?

2: How accurate are various predictors, assuming a genetic definition of the Lynch Syndrome?

Key Question 3: What are the harms associated with screening high-risk individuals for HNPCC?

Key Question 4: What is known about the analytic (sensitivity, specificity, reproducibility, reliability) and clinical validity of tests that identify HNPCC mutations?

Key Question 5: What are the harms associated with screening for high-risk individuals?

Key Question 6a: What are the management options for CRC patients who are HNPCC positive?

6b: Does the identification of HNPCC mutations lead to improved patient outcomes in terms of early detection, mortality/morbidity or management decisions (e.g., counseling, surveillance, treatment, other decision making) by patients and providers?

Key Question 7: What are the harms associated with subsequent management options after identification of HNPCC mutations in CRC patients?

Key Question 8a: What is the efficacy of pre-test genetic counseling for informing family members of potential risks and benefits of testing?

8b: What is the accuracy of HNPCC testing in family members in predicting the risk of CRC?

8c: Do other factors, such as race/ethnicity, age, gender, or co-morbidities affect the accuracy of the testing?

Key Question 9: What are the harms associated with informing/counseling family members or with subsequent testing for HNPCC mutations?

Key Question 10a: What are the management options for family members of CRC patients who have a positive HNPCC test?

10b1: Does the identification of HNPCC mutations lead to improved outcomes in terms of decision making by patients, family members and providers, or public health policy?

10b2: Does the identification of HNPCC mutations lead to improved outcomes in terms of early detection and mortality/morbidity of patients, family members?

Key Question 11: What are the harms associated with subsequent actions or interventions for family members?

These questions were based upon an analytic framework that begins with a patient with colorectal cancer and examines the full spectrum of implications of identifying HNPCC in the patient and their at-risk family members, and the potential benefits and harms of this process from the perspectives of the patient, provider, family member and the public health.

## Methods

We performed an electronic search of the literature followed by review of abstracts and then full-text review of potentially relevant studies. We also retrieved additional studies based on bibliographies of retrieved articles and suggestions from a technical expert panel. We evaluated all studies critically based upon pre-specified criteria.

We reviewed the full-text of 523 publications. One hundred fifteen papers fulfilled eligibility criteria but 11 were duplicate reports and were therefore excluded (or used to provide supplementary information). Thus, 104 unique studies were included for this review (40 were pertinent to Key Question 2 - clinical validity; 3 were pertinent to Key Question 4 - analytic validity; and 61 to the remaining Key Questions - benefits and harms), while 408 did not meet the inclusion criteria and were rejected.

We reviewed each study for its quality. We assigned an overall quality score (A, B or C) to provide a short hand appraisal of the overall validity of the study but also performed analysis of specific components of study quality that may have influenced the conclusions.

We combined data in studies that used similar methodology and definitions of endpoints in similarly selected CRC populations using meta-analysis to provide a point estimate and 95% confidence interval, mainly for questions pertaining to clinical validity.

We constructed decision trees models to calculate the reported outcomes of various strategies for identifying HNPCC among patients with colorectal cancer. The models were based upon parameters estimated from data presented in this report.

## Results

### Analytic Validity

Key Question 4: What is known about the analytic (sensitivity, specificity, reproducibility, reliability) and clinical validity of tests that identify HNPCC mutations?

The major laboratory tests used in the evaluation of patients suspected of having HNPCC include testing of tumor tissue using immunohistochemistry (IHC), microsatellite instability (MSI) testing, or germline (generally from peripheral blood mononuclear cells) testing for mismatch repair defects. Analytic validity may also apply to the accuracy of the family history.

Family members generally undergo only germline genetic testing (unless they have also developed a relevant cancer), ideally based upon the genotype of the proband. Detection of a pathogenic mutation (i.e., one known to be associated with HNPCC) in a proband permits testing of at-risk family members for the genotype. Family members with the same genotype have HNPCC while HNPCC can be excluded in those who do not. The situation is more complex when the probands do not have a detectable DNA alteration associated with HNPCC or when an alteration with unclear clinical significance is detected.

There was little published information on the analytic validity of laboratory testing in patients or family members suspected of having HNPCC. Thus, the analytic validity of the tests used to evaluate HNPCC is substantially uncertain. However, there was heterogeneity in the type of testing offered by commercial laboratories, and one study demonstrated variability in the accuracy of protein staining by IHC across facilities.

Additional information that could shed light upon analytic validity is available but would require evaluation of non-published data sources. For example, information has been collected through an external proficiency-testing program for MSI conducted by the College of American Pathologists and through internal testing performed by individual laboratories. Committees of experts could also review the strengths and limitations of specific testing techniques based upon clinical experience with these methods in HNPCC and in other genetically based disorders.

### Clinical Validity

Key Questions 2a, 2b and 2c seek to evaluate the prevalence of MMR mutations, suggestive MSI and IHC, respectively, among patients fulfilling the Amsterdam I criteria or the Amsterdam II criteria. We considered several variables in making comparisons across studies such as how populations were selected, the methods used for genetic testing, whether and how mutations were described as being pathogenic, and whether testing for MMR genes other than MLH1 and MSH2 was performed.

Key Question 2a: Assuming a clinical definition of the Lynch Syndrome, what proportion of patients has a mismatch repair mutation?

Most eligible studies evaluated only MLH1 and MSH2 genes; only three studies assessed other MMR genes. Among CRC fulfilling Amsterdam I criteria, the random effects summary prevalence of MLH1 and MSH2 gene mutations was 44% (95% CI: 35, 52; n=19 studies, 464 patients), with evidence for substantial between-study heterogeneity (p<0.01; I^2^=52%). The six studies that performed sequencing among all Amsterdam I patients had a summary prevalence of 51% (95% CI: 35, 66%).

For patients fulfilling the Amsterdam II criteria, the corresponding prevalence values were 39% (95% CI: 30, 49%; 10 studies 279 Amsterdam II patients) and 40% (95% CI: 30, 52%) based upon two studies that performed sequencing on all 87 Amsterdam II patients.

The three studies examining additional genes (MSH6, PMS1 and PMS2) in Amsterdam I patients did not identify any additional MMR mutations. Two additional MSH6 mutations (in addition to five MLH1 and MSH2 mutations) were found among 20 Amsterdam II patients in a single study.

There were limited studies that performed more comprehensive genetic testing for pathogenic MMR genotypes associated with HNPCC or evaluated all the MMR genes that have been associated with HNPCC. For example, only one study performed sequencing in all samples and tested for large genomic mutations/rearrangements for three MMR genes (MLH1, MSH2, MSH6). The study included only 22 Amsterdam I patients; the prevalence of MMR mutation carriers was 64%.

Limited data suggested that approximately one-fourth to one-third of genotypes associated with HNPCC are related to deletions or rearrangements that would be missed through sequencing alone. As a result, the prevalence of mutations in Amsterdam I or II patients assessed from studies that performed sequencing alone are likely to be underestimates. Accounting for this effect, one may derive a prevalence of MMR mutations of approximately 63% to 67% in Amsterdam I patients. For Amsterdam II patients the corresponding prevalence values would be 50% to 53%.

Furthermore, limited data suggest that approximately 10% of MMR genotypes involve MMR genes other than MLH1 and MSH2. Thus, assuming an additional 10% increase in mutations by assessing more genes would result in an overall prevalence of up to 70% to 75% for Amsterdam I patients and 55 to 59% for Amsterdam II patients.

Because of the limited data, these calculations should be considered as being highly imprecise. Furthermore, other considerations, such as how patients are selected and how genotypes are classified as being pathogenic, may affect these estimates.

Key Question 2b: Assuming a clinical definition of the Lynch Syndrome, what proportion of patients has MSI?

Among patients fulfilling the Amsterdam I criteria, 71% (95% CI: 63, 78%; n=11 studies, 159 patients) of tumors were MSI-H. Among patients who fulfilled the Amsterdam II criteria, the corresponding summary prevalence was 68% (95% CI: 58, 76%; n=4 studies, 102 patients).

Key Question 2c: Assuming a clinical definition of the Lynch Syndrome, what proportion of patients has abnormal protein expression by immunohistochemistry?

Among patients fulfilling the Amsterdam I criteria the overall prevalence of tumors with loss of protein expression by IHC was 40% (95% CI: 28, 53%; n= 6 studies, 63 patients) with no evidence for between-study heterogeneity (p=0.75, I^2^=0%).

Only one eligible study provided relevant data for 20 patients fulfilling the Amsterdam II criteria. Eight out of 20 tumors had suggestive IHC for the MLH1, MSH2 or MSH6 genes (40% [95% CI: 9, 64%]).

MSI and IHC testing often depended upon practical and logistical considerations (e.g., patient availability and consent and availability of tumor tissue). Thus, not all patients had all tests and it was unclear whether additional bias may have been introduced in selecting patients for testing.

Key Question 2: How accurate are various predictors assuming a genetic definition of the Lynch Syndrome?

Five studies provided information on eight clinical predictors and on suggestive MSI testing for predicting the presence of MMR mutations among unselected incident CRC. All were limited by verification bias. The table below summarizes the sensitivity and specificity of the predictors most commonly reported (see Executive Summary Table 1).

Table 1 Executive Summary Table. Diagnostic ability of various predictors to detect MMR mutations among unselected incident CRC

Predictor | Unselected CRC probands
| N | Sensitivity [%](95% CI) | Specificity [%](95% CI)
Amsterdam I criteria | 2 | 45 (29, 63) | 99 (74, 100)
Amsterdam II criteria | 2 | 28 (15, 47) | 99 (97, 100)
Modified Amsterdam criteria | 0 | ND | ND
Bethesda guidelines | 1 | 73 (39, 94) | 82 (80, 84)
Revised Bethesda guidelines | 1 | 91 (59, 100) | 77 (75, 79)
Age <50 years | 3 | 31 (18, 47) | 95 (94, 96)
1^st^ degree family history of CRC or EC | 4 | 76 (50, 91) | 87 (86, 89)
Multiple CRC or EC tumors in the same patient | 3 | 38 (25, 54) | 97 (91, 99)
Age <50 years, family history of CRC or EC, or multiple tumors in same patient | 3 | 88 (60, 97) | 77 (74, 81)
Suggestive MSI^a^ | 2 | 100 (88, 100) | 90 (88, 92)
Suggestive IHC | 0 | ND | ND

CRC: colorectal cancer; EC: endometrial cancer; N: Number of studies; ND: no data.

a Estimates are the same for combined MSI-H and MSI-L versus MSS and for MSI-H versus MSS

Decision Tree Modeling of Genetic Testing Strategies. We evaluated nine strategies for identifying patients with CRC with MMR mutations based upon combinations of clinical features, laboratory testing of tumor tissue (i.e., IHC and MSI testing). These can be conceptually organized into four general strategies:

- Group 1: Perform genetic test on everyone
- Group 2: Screen with a set of clinical criteria
- Group 3: Screen tumor tissue with a laboratory test
- Group 4: Screen using two serial tests: a set of clinical criteria first, and then a laboratory test of tumor tissue

Of these, Group 4 strategies selected relatively fewer patients for genetic testing (one out of twenty-five or fewer) and missed at most in approximately 27% of patients with HNPCC. Mismatch repair mutation testing would be performed in less than 6% of CRC patients using these strategies. In contrast, for strategies in groups 1 to 3, more than 13% and up to 100% of newly diagnosed CRC patients would be genetically tested, and approximately 5% to 16% of patients with HNPCC would be missed. Similar results were obtained for both the low (0.90%) and the higher (2.75%) estimate for the prevalence of mutation carriers among incident unselected CRC (see Executive Summary Table 2).

Table 2 Executive Summary Table. Expected number of MMR, MSI or IHC tests and expected MMR testing results with the nine strategies, assuming a population of 100,000 incident cases of CRC

Strategy | Received tests | | | Number of MMR tests that were | | | Unidentified MMR mutation carriers
| MMR | MSI | IHC | Positive | True positive | Inconclusive
Low prevalence estimate for MMR mutation carriers (0.90%)
MMR-All | 100,000 | 0 | 0 | 1,351 | 855 | 252 | 45
BethR-All | 23,612 | 0 | 0 | 892 | 778 | 61 | 122
3Clinical-All | 23,585 | 0 | 0 | 866 | 752 | 61 | 148
MSI-All | 13,738 | 100,000 | 0 | 877 | 812 | 37 | 88
IHC-All | 13,702 | 0 | 100,000 | 843 | 778 | 37 | 122
BethR-MSI | 3,741 | 23,612 | 0 | 754 | 739 | 12 | 161
3Clinical-MSI | 3,716 | 23,585 | 0 | 730 | 715 | 11 | 185
BethR-IHC | 1,828 | 0 | 23,612 | 659 | 654 | 6 | 246
3Clinical-IHC | 3,684 | 0 | 23,585 | 700 | 685 | 11 | 215
Higher prevalence estimate for MMR mutation carriers (2.75%)
MMR-All | 100,000 | 0 | 0 | 3,098 | 2,612 | 257 | 138
BethR-All | 24,870 | 0 | 0 | 2,489 | 2,377 | 69 | 373
3Clinical-All | 24,787 | 0 | 0 | 2,410 | 2,299 | 69 | 451
MSI-All | 15,255 | 100,000 | 0 | 2,545 | 2,481 | 46 | 269
IHC-All | 15,145 | 0 | 100,000 | 2,440 | 2,377 | 45 | 373
BethR-MSI | 5,285 | 24,870 | 0 | 2,273 | 2,258 | 20 | 492
3Clinical-MSI | 5,206 | 24,787 | 0 | 2,198 | 2,184 | 20 | 566
BethR-IHC | 3,220 | 0 | 24,870 | 2,002 | 1,997 | 14 | 753
3Clinical-IHC | 5,110 | 0 | 24,787 | 2,106 | 2,092 | 20 | 658

In the hypothetical population, for the low prevalence estimate 900/100,000 patients are assumed to carry MMR mutations; for the high prevalence estimate 2750 people are assumed to carry MMR mutations. Strategies are presented with respect to the group (1 to 4) to which they belong. MMR-All: test all for mismatch repair mutations; BethR-All: test all using the revised Bethesda criteria; 3 Clinical-all: Perform MMR testing only among those fulfilling at least one of the three simple clinical criteria (age <50y at diagnosis, family history of CRC or endometrial cancer, or multiple tumors, synchronous or metachronous, in the same patient); MSI-All: Perform MSI testing on all patients, followed by MMR testing only among those with suggestive MSI test; IHC-all: Perform immunohistochemistry (IHC) testing on all patients followed by MMR testing only among those with suggestive IHC test; BethR-MSI: Perform MSI testing on patients fulfilling the revised Bethesda guidelines, perform MMR only among those with suggestive MSI test;3 Clinical-MSI: Perform MSI testing on patients fulfilling at least one of the three simple clinical criteria (age <50y at diagnosis, family history of CRC or endometrial cancer or multiple tumors, synchronous or metachronous, in the same patient); perform MMR only among those with suggestive MSI test; BethR-IHC: Perform IHC testing on patients fulfilling the revised Bethesda guidelines; perform MMR only among those with suggestive IHC test; 3 Clinical-IHC: Perform IHC testing on patients fulfilling at least one of the three simple clinical criteria (age <50y at diagnosis, family history of CRC or endometrial cancer or multiple tumors, synchronous or metachronous, in the same patient; perform MMR only among those with suggestive IHC test.

The overall (strategy-level) sensitivity and specificity are shown in Executive Summary Table 3. The overall specificity was high in all strategies. Group 4 strategies had the lowest overall sensitivity (ranging between 73% and 82%). Overall sensitivity and specificity estimates were similar for both the low (0.90%) and the higher (2.75%) prevalence estimates.

Table 3 Executive Summary Table. Overall sensitivity and specificity for each of the nine strategies

Strategy | Sensitivity of strategy (%) | Specificity of strategy (%)
MMR-All | 95.0 | 99.3
BethR-All | 86.5 | 99.8
3Clinical-All | 83.6 | 99.8
MSI-All | 90.3 | 99.9
IHC-All | 86.5 | 99.9
BethR-MSI | 82.1 | 100.0
3Clinical-MSI | 79.4 | 100.0
BethR-IHC | 72.6 | 100.0
3Clinical-IHC | 76.1 | 100.0

Strategies are presented with respect to the group (1 to 4) to which they belong. In the above estimates the sensitivity and the specificity of the whole strategy was calculated. Inconclusive MMR tests were assumed to be false negative (for the calculation of overall sensitivity for each strategy) or false positive (for the calculation of overall specificity for each strategy).

Thus, of the nine clinical strategies, the presence of at least one of three clinical predictors: (i) age less than 50 years old at diagnosis, or ii) a history of colorectal or endometrial cancer in a first degree family member, or iii) the presence of multiple, synchronous or metachronous colorectal or endometrial cancers in the proband, combined with testing of tumor tissue for either IHC or MSI, identified a similar number of patients with colorectal cancer who had mismatch repair mutations associated with HNPCC (and failed to identify a similar number) compared with other, more complex approaches. There were relatively more studies demonstrating test characteristics of MSI testing compared with IHC and thus greater precision in the estimates of sensitivity and specificity of MSI testing.

### Benefits and Harms

Key Question 1: Does risk assessment and HNPCC mutation testing in patients with newly diagnosed CRC lead to improved outcomes for the patient or family members, or is it useful in medical, personal, or public health decision making? (Over-arching question)

No study directly addressed Key Question 1.

Key Question 3: What are the harms associated with screening high-risk individuals for HNPCC?

Studies were considered eligible for Key Question 3 if they reported harms of a risk assessment process (e.g., Amsterdam, Bethesda and/or MSI, IHC) used to identify CRC patients at increased risk for HNPCC.

No study described harms of the risk assessment process in CRC patients at increased risk for HNPCC.

Key Question 5: What are the harms associated with screening for high-risk individuals?

Studies were considered eligible for Key Question 5 if they reported the harms associated with testing CRC patients for MMR mutations. Common harms that are thought to be associated with genetic testing are labeling, discrimination in health coverage, and emotional distress.

Three quantitative, comparative studies of quality A and B, and one qualitative study of B quality reported harms associated with MMR mutation testing in CRC patients. One 1-year prospective study (Grade A) compared the psychological impact of MMR mutation testing between mutation carriers and non-carriers. Subjects in this study were CRC probands or relatives from HNPCC families with a prior diagnosis of any cancer (excluding non-melanoma skin cancer). Anxiety, depression, and quality of life measures did not change over time, and there were no differences in these measures between mutation carriers and non-carriers. Distress levels were significantly decreased 2 weeks and 6 months after revealing the genetic testing results but were not significantly different from the baseline at 1-year follow-up. There was no difference in the distress levels between mutation carriers and non-carriers.

Another 1-month prospective study (Grade B) found that three of the 27 probands (11%) had minor depression at 1 month after revealing the genetic testing results, but the prevalence of minor depression was not significantly different compared to the prevalence at baseline or between mutation carriers and non-carriers. Of the six probands who received a positive result, two (33%) felt severe guilt regarding their children.

One prospective study (Grade B) reported changes in the psychological outcomes of CRC patients from self-completed questionnaires pre- and 4–6 weeks post-genetic counseling. There was no genetic testing performed in this study. There was a trend toward greater anticipated ability to cope with a positive gene test after counseling, as reflected by a decrease in anxiety and cancer-specific distress.

The qualitative study of 111 newly diagnosed CRC patients reported a high acceptance and understanding about information on HNPCC. Nineteen percent of participants rated their current level of worry caused by the genetics information at or above the midpoint of 4 on a 1 (not at all) to 7 (all the time) scale.

Key Question 6a: What are the management options for CRC patients who are HNPCC positive?

6b: Does the identification of HNPCC mutations lead to improved patient outcomes in terms of early detection, mortality/morbidity or management decisions (e.g., counseling, surveillance, treatment, other decision making) by patients and providers?

There are three aspects to Key Question 6: 1) Are management options for patients with CRC with a MMR mutation different from those without a MMR mutation? 2) Does the knowledge of MMR mutation status change management decisions by patients and providers? 3) Does changing management options for MMR positive patients with CRC improve outcomes (e.g., prognosis and survival) compared to standard approaches for patients with CRC?

We encountered a variety of surgical and medical management options in patients with CRC who were MMR positive but there were no comparative studies.

Indirect evidence from one study suggested that identification of HNPCC mutations was associated with better prognosis of CRC. However, there were no data on whether management options for CRC differed based on MMR mutation status.

Indirect evidence from one study showed no difference in survival of patients with endometrial cancer, comparing those who were mutation positive to those who were mutation negative.

In five studies with indirect evidence, there was no evidence in favor or against differences in survival, when comparing CRC patients who fulfilled different clinical criteria for HNPCC or screened positive for HNPCC by suggestive laboratory testing with those who did not.

Key Question 7: What are the harms associated with subsequent management options after identification of HNPCC mutations in CRC patients?

No study described harms associated with subsequent management options after identification of HNPCC mutations in patients with CRC or other forms of HNPCC-related cancers.

One study (involving two centers) described the types of colorectal surgery performed on CRC patients who were part of an Amsterdam criteria-positive family, and compared rates of metachronous cancers that followed each type of index operation. The overall rate of second surgeries for metachronous cancer were 23% in patients who underwent right colectomy, 17% in patients who underwent left/sigmoid colectomy or proctosigmoidectomy, 0% in patients who underwent total/subtotal colectomy, and 44% in patients who underwent segmental colectomy. The two centers had significantly different second resection rates for metachronous cancer.

One study described the survival rate of 45 patients with gastric cancer from HNPCC families with MMR mutations. Many of these patients had already had treatments for other HNPCC-related cancers, including CRC. The 5-year survival was higher in patients in whom radical surgery was performed (48%) than in patients in whom radical palliative surgery or explorative laparotomy alone was performed (15%).

Key Question 8b: What is the accuracy of HNPCC testing in family members in predicting the risk of CRC?

8c: Do other factors, such as race/ethnicity, age, gender, or co-morbidities affect the accuracy of the testing?

Only two studies of B quality reported the risk of CRC in family members of probands with positive MMR mutations (the proposed framework). The lifetime risk of CRC was 68.7% for men and 52.2% for women with MMR mutations in one study, and it was 74% and 30% respectively in the other study. Men had higher lifetime risk of CRC than women in both studies.

In a study that reported the risk of CRC in family members of probands with HNPCC based on clinical criteria, the cumulative risk of CRC by age 75 years old was 57% and 41% in families that fulfilled the Amsterdam I and II criteria, respectively. The cumulative risk of CRC by age 75 years old was 42% and 23% for men and women, respectively, from families that fulfilled Bethesda criteria. In another study, family members of CRC probands who were younger than 50 years old at cancer diagnosis had a higher risk of CRC, compared to family members of CRC probands who were 50 years old and older. The risk of CRC was increased three-fold, comparing first-degree relatives of CRC probands who developed a second primary in the HNPCC spectrum with the single primary group in a third report.

In a study that reported the risk of CRC in kindreds with HNPCC based on genetic criteria, the cumulative risk of CRC by age 70 yr was 82% in MLH1/MSH2 mutation carriers. The cumulative incidence of CRC was 100% in men and 54% in women. There was overall a higher risk of CRC in men, but the sex difference was not consistent among HNPCC kindreds with different MMR mutations.

Key Question 9: What are the harms associated with informing/counseling family members or with subsequent testing for HNPCC mutations?

Key Question 8a: What is the efficacy of pre-test genetic counseling for informing family members of potential risks and benefits of testing?

Studies were considered eligible for Key Question 8a if they summarized the efficacy of pre-test genetic counseling immediately after counseling and before performing genetic testing. Studies addressing Key Question 9 were considered together with those addressing Key Question 8a because there was substantial overlap in the studies addressing these questions. The studies addressed the long-term efficacy of pre-test genetic counseling or harms associated with screening high-risk individuals (such as by using clinical criteria, MSI, or IHC), genetic testing, and informing/counseling family members or with subsequent testing for HNPCC mutations.

Four studies addressed the efficacy of pre-test genetic counseling immediately after counseling and before performing MMR genetic testing. Of these, three were of B quality and one was of C quality.

Eight comparative and four qualitative studies addressed the harms associated with genetic testing for HNPCC mutation or with informing/counseling family members or with subsequent testing for HNPCC mutations. Of these, one study was of A quality, six of B quality, and five of C quality.

Overall, pre-test genetic counseling had good efficacy in improving knowledge about HNPCC, and resulted in high likelihood of proceeding with genetic testing, satisfaction in the decision to undergo genetic testing, and decreasing depression and distress levels among family members of HNPCC probands or among asymptomatic individuals from HNPCC families. Family members of HNPCC who received positive MMR mutation test results had higher psychological distress levels and anxiety compared to those who received negative test results, but this difference generally disappeared with time. However, all of these psychological measures were within the normal ranges for the general populations. There were no differences in quality of life, comparing mutation carriers to non-carriers or the general population.

Key Question 10a: What are the management options for family members of CRC patients who have a positive HNPCC test?

b1: Does the identification of HNPCC mutations lead to improved outcomes in terms of decision making by patients, family members and providers, or public health policy?

b2: Does the identification of HNPCC mutations lead to improved outcomes in terms of early detection and mortality/morbidity of patients, family members?

We included studies evaluating all forms of cancer related to HNPCC since family members of CRC probands are potentially at risk for all such cancers.

Six studies examined the impact of mutation testing on the decision to undergo specific management recommendations among family members of CRC patients or asymptomatic individuals from HNPCC families. Of these, four were of B quality and two were of C quality. No study directly examined the impact of HNPCC mutation testing on public health policy or decision making by insurance providers.

Two studies (in three publications) of B and C quality indirectly addressed outcomes of early detection and mortality/morbidity in relation to the identification of MMR mutations in family members of CRC probands or asymptomatic individuals from HNPCC families. These studies were limited by potential selection bias, and/or unclear effects from treatments or subsequent interventions.

Identification of HNPCC mutations was associated with improved outcomes in terms of decision making to undergo screening for cancers in family members of HNPCC. HNPCC family members who took subsequent actions or interventions had a lower risk of developing HNPCC-related cancers and lower mortality rates, compared to those who did not take actions. Most data pertained to screening for CRC with colonoscopy while there was less information about screening for other forms of HNPCC-related cancer.

Key Question 11: What are the harms associated with subsequent actions or interventions for family members?

We included studies that reported any outcome relating to subsequent management options or interventions in HNPCC family members.

Nine studies reported outcomes related to subsequent actions or interventions among family members. Of these, six were of B quality and three were of C quality. Four of these nine studies reported harms or adverse events associated with subsequent actions or interventions for family members. In addition, one study of C quality examined the psychological impacts associated with colonoscopies. Some of these studies did not have a control group of subjects who declined to undergo surveillance and most results did not adjust for potential confounders such as age, personal history of cancer, and educational levels.

Less than 0.5 percent of family members experienced harms associated with screening or surveillance examination or surgical procedures in the studies we evaluated. However, complication rates associated with these interventions in the non-HNPCC setting are probably applicable. There was some negative psychological impact associated with colonoscopies.

## Implications for Future Research

Our report identified several areas for future research; we considered the following to be particularly important priorities:

- There is very little information regarding the analytic validity of tests used in the diagnosis of HNPCC. Studies specifically addressing sensitivity, specificity and reliability of all of the laboratory and genetic testing methods in HNPCC are needed. Such studies should focus on contemporary testing methods and compare them against well-defined reference standards in tissue samples representative of the spectrum of genotypes associated with HNPCC. Unpublished information regarding analytic validity is also available; it may be feasible to obtain information from commercial or private laboratories performing such testing. It may also be possible to obtain data from the College of American Pathologists regarding their MSI proficiency program once experience has accumulated. Experience with genetic testing methods in other conditions is likely to be relevant to HNPCC; a review of such information could be conducted by groups of experts on genetic testing techniques.
- Additional studies are needed to clarify the validity of specific clinical and laboratory predictors of HNPCC in patients with CRC who are representative of the general population of patients with CRC.
- Future studies should consider all forms of genetically based CRC cancer predisposition to fully understand the effectiveness of various diagnostic strategies. Such studies should consider all known genetic causes of cancer predisposition and the accuracy of clinical and laboratory testing in identifying these disorders in individuals who are representative of the general population.
- Additional studies are needed to establish the availability of genetic testing centers that can provide adequate counseling and whether there are barriers to access them. Such studies may involve electronic, mail, or telephone surveys.
- More studies are needed to understand what forms of surveillance should be offered to MMR mutation carriers for HNPCC-related cancers other than CRC. Well-designed controlled trials comparing various surveillance (or other management) strategies could be helpful.
- More studies are needed to clarify the risk of cancer in family members of probands with an HNPCC-related cancer who are found to carry MMR mutations. Such studies would ideally be prospective, fully account for interventions (such as cancer screening procedures) in those at-risk, and have a well-defined control population of individuals at average risk for cancer.
- Standards for reporting studies of genetically based diseases (including those addressing all aspects of the ACCE model) should be developed. A consensus development process with publication of a guideline(s) could be helpful.