# Acknowledgments

We would like to acknowledge the Centers for Disease Control and Prevention for its funding of the evidence review project. We also acknowledge with appreciation the following members of the Technical Expert Panel for their advice and consultation to the Evidence-based Practice Center during preparation of this report:

- Linda Bradley, Ph.D.
- Evaluation of Genomic Applications in Practice and Prevention (EGAPP)
- Office of Genomics and Disease Prevention
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Robert H. Fletcher, M.D., M.Sc.
- University of North Carolina
- Chapel Hill, North Carolina

- James Haddow, M.D.
- Women & Infants Hospital
- Providence, Rhode Island

- Celia Kaye, M.D., Ph.D.
- University of Colorado School of Medicine Denver, Colorado
- National Newborn Screening and Genetics Resource Center
- University of Texas Health Science Center San Antonio, Texas

- Carolyn Sue Richards, Ph.D., F.A.C.M.G.
- Molecular Diagnostic Center
- Oregon Health & Science University
- Portland, Oregon