# Discussion

Our report was based upon an analytic framework that begins with a patient with CRC and explores the spectrum of implications of screening, testing, and management of the patient and their family members considering the perspectives of the patient, provider, family member and the public health. The Key Questions we addressed reflected the main considerations along this pathway. We have explored a large and varied literature and have found a wide range of quality of the evidence across these areas.

## Analytic Validity

A previous review sponsored by the CDC and EGAPP found that 13 commercial laboratories in the United States offered some form of laboratory testing for HNPCC. (The report is available at http://www.cdc.gov/genomics/gtesting/file/print/FBR/CC_AnalyticValidity.pdf, accessed on August 5th, 2006). The report noted that there were no data from which to assess the analytic sensitivity, specificity, or reliability of genetic tests used to diagnose HNPCC. We also summarized commercial laboratories performing HNPCC-related tests that had been included on a federally sponsored website (www.genetests.org). This likely represents only a partial list, but highlights the variability in the testing available at the participating centers.

The published literature regarding the analytic validity of laboratory testing in HNPCC is extremely limited. Most of the studies we reviewed were only indirectly related to analytic validity and had major methodologic limitations, particularly in use and definitions of reference standards. However, there was some evidence that there may be variability across testing facilities at least for immunohistochemistry (IHC).^56^ Furthemore, a study published after our literature review found a “learning curve” in laboratories performing MSI testing.^168^ Thus, analytic validity is not merely a theoretical concern but may have important clinical impact in the care of probands with HNPCC-related cancer or their families.

A better understanding of analytic validity could be achieved by incorporating non-literature based methods. This might include contact of commercial laboratories performing such testing. In addition, an external proficiency-testing program for MSI was introduced in 2006 (by the College of American Pathologists, information accessible at http://www.cap.org/apps/cap.portal) but results have not been published. Finally, some of the laboratory tests used in evaluation of HNPCC are also used for other disorders. A literature review based upon a search for these methods would not be practical. However, a committee of experts involved in these laboratory procedures could help evaluate their strengths and limitations in detecting the spectrum of genotypes/phenotypes associated with HNPCC.

## Clinical Validity

We summarized the literature describing the relationships among clinical predictors of HNPCC using a clinical or genetic definition of the disorder, depending upon the parameter that we were estimating. Our analysis underscored the difficulty in comparing studies with one another because of important differences in study characteristics such as inclusion criteria, the quality and extent of laboratory testing performed, and the degree to which the diagnosis was verified among participants. Despite these difficulties, we have clarified the accuracy of the clinical predictors and critically evaluated study characteristics that may have a bearing upon them.

We used the estimates of test accuracy to develop a decision-tree model to understand how these predictors can be used to identify MMR mutations among unselected patients with CRC. We performed sensitivity testing across the range of estimates for key parameters. The point estimates (and ranges) tested were derived from our systematic review of the data and thus confidently demonstrate the range of possibilities based upon the best available evidence.

We found that a set of three simple criteria i.e., 1) age less than 50 years old at diagnosis 2) or a history of colorectal or endometrial cancer in a first degree family member, 3) or the presence of multiple, synchronous or metachronous colorectal or endometrial cancers) performed as well as the more complex criteria (such as the Bethesda guidelines) when combined with MSI or IHC testing of tumor tissue. However, our analysis did not consider costs or utilities and thus a more formal cost-effectiveness analysis would be required to more fully understand the implications of the various strategies.

Our model was based upon parameters obtained from the published literature. As a result, it may not fully account for practical considerations that are encountered in the care of patients with CRC and family members with suspected HNPCC. For example, it may not be possible to obtain tumor tissue to perform laboratory testing. In addition, there may not be uniform access to expert laboratory and pathology facilities or qualified genetic counselors. Economic and other barriers may prevent access to care and surveillance in some settings. Obtaining a family history, even if abbreviated, may not always be feasible. As noted in Chapter 1 and 3, the patients' report of the family history may not be accurate, particularly for cancers other than colorectal that are potentially related to HNPCC.^30^ Issues of uncertain paternity may also be relevant in some families while some families may be too small (or have insufficient contact among family members) to obtain a clinically meaningful family history.

Furthermore, testing for HNPCC in patients with CRC represents only one of the diagnostic considerations when evaluating patients for a genetically susceptibility to cancer. To fully understand the implications, diagnostic strategies for other forms of hereditary cancer (such as MUTYH-associated polyposis and attenuated familial adenomatous polyposis) also need to be considered. For example, it is possible that certain combination of clinical history and laboratory testing of tumor tissue may be superior to the strategy proposed above when attempting to optimize the yield in uncovering all recognizable forms of genetically-based CRC predisposition.

We identified many gaps in the literature. For example, there were relatively more studies demonstrating test characteristics of MSI testing compared with IHC and thus greater precision in the estimates of sensitivity and specificity of MSI testing. There were insufficient data to understand confidently whether MSI testing had better sensitivity and specificity compared with IHC and even fewer studies that addressed benefits of using both approaches concurrently. An advantage of IHC compared with MSI testing is that it is easier to perform and less expensive, both features offering important benefits from a public health perspective. Nevertheless, more studies are needed to clarify whether IHC should be preferentially adopted based upon these considerations.

The majority of studies provided data on patients with CRC who were implicitly or explicitly selected based upon heightened suspicion for HNPCC while there were few studies providing estimates on characteristics of these tests in an unselected population-based sample of patients with CRC. More studies on such patients are needed.

## Benefits and Harms

We identified and critically evaluated studies that considered the range of outcomes (harms and benefits) in probands with HNPCC-related cancers and their family members from the perspectives of the patient, their family members, providers and the public health. Where there was limited evidence, we expanded the scope of the Key Questions to include indirect evidence, and variable definitions of HNPCC (e.g., clinical or genetic) to provide as comprehensive an appraisal of the knowledge base as possible. The major conclusions and gaps in the literature are summarized in the Executive Summary, Chapter 3, and (more briefly) below.

We found only limited data on harms associated with testing for MMR mutations in probands with CRC but the available data do not suggest severe psychological impact in most patients. In addition, pre-test genetic counseling had good efficacy in improving knowledge about HNPCC and resulted in a high likelihood of proceeding with genetic testing, satisfaction in the decision to undergo genetic testing and decreasing depression and distress levels among family members of HNPCC probands and among asymptomatic individuals form HNPCC families. Although there was little information regarding how pre-test counseling should optimally be performed, the consistent benefits observed across studies underscore the effectiveness of current programs. Testing of family members also had the potential to exclude the presence of HNPCC and thereby excuse family members from the need for intensive cancer surveillance and the psychosocial concerns related to a cancer predisposition.

There was limited direct evidence regarding whether the identification of MMR mutations led to improved outcomes for the proband in terms of early detection, mortality/morbidity or management decisions by patients or providers. However, identification of HNPCC mutations was associated with an increase in the likelihood that family members of probands with CRC would undergo cancer-screening procedures. Survival was increased among asymptomatic HNPCC family members who received colonoscopy screening, regardless of their mutation status. Family members who underwent cancer-screening procedures had a lower risk of developing HNPCC-related cancers and lower mortality rates than those who did not take actions. The literature most strongly supported surveillance for CRC while there were only a few studies that focused on prevention of other HNPCC-related tumors. However, all of the relevant studies suggesting these benefits had important limitations.

There are a multitude of ethical, social,and medical issues that require clarification. There was very little information regarding surveillance approaches in patients who were considered at risk for HNPCC, but had a negative or equivocal genetic test result. We found very few moderate or high quality studies from which to confidently understand the clinical expression (penetrance) of HNPCC among family members of CRC probands found to have MMR mutations through predictive genetic testing programs. There was also limited information regarding the relationship of specific genotypes to phenotypes.

## Summary

- There is very little published information related to the analytic validity of laboratory testing in HNPCC. However, the available data suggest there may be important variability among testing facilities. Additional unpublished information about analytic validity is available through an external proficiency-testing program for MSI conducted by the College of American Pathologists, and through internal testing performed by individual laboratories. In addition, the analytic validity of the specific testing methods used for other genetic disorders may be applicable to HNPCC.
- Among CRC fulfilling Amsterdam I criteria, approximately 44% (95% CI: 35, 52%) had a MMR (MLH1 or MSH2 in most studies) gene mutation when considering all studies together. The prevalence was 51% (95% CI: 35, 66%) among studies performing relatively comprehensive genetic testing. However, the true prevalence of MMR mutations among Amsterdam I patients may be different (possibly higher) than these estimates for several reasons:
  1 Testing for MMR genes other than MLH1 and MSH2 (particularly MSH6) may increase the proportion of patients with MMR by around 10% (this is an uncertain estimate).
  2 Genomic rearrangements and large deletions are missed when only sequencing and gene screening is performed. Limited evidence suggests that approximately one-fourth to one-third of the identified MMR mutations are large genomic deletions/rearrangements.
  3 The prevalence estimates are influenced by the certainty that identified genotypes are classified as being pathogenic.
  4 The strategy used for selecting patients with CRC can have a substantial impact on the prevalence estimates. Very few studies focused on unselected patients with CRC. Most identified cases from cancer registries or used other selection strategies that may have increased the proportion of patients with MMR mutation included in the study. This report examined various features of studies evaluating these estimates (such as the selection criteria, specific type of laboratory and genetic testing, sample size and methodologic quality), but did not identify consistent associations among these features and the prevalence estimates.
  Accounting for MMR genes other than MLH1 and MSH2 and for the routine use of methods to detect large genomic deletions/rearrangements, one may calculate that approximately 70% to 75% for Amsterdam I patients are MMR mutation carriers.
- The same considerations apply to other clinical criteria such as the Amsterdam II criteria or the Bethesda Guidelines (original and revised). Among CRC patients who fulfilled the Amsterdam II criteria, 39% (95% CI: 30, 49%) had a MLH1 or MSH2 gene mutation when considering all studies together. The prevalence was 40% (95% CI: 30, 52%) when considering two studies that performed gene sequencing in all patients. Accounting for MMR genes other than MLH1 and MSH2 and for the routine use of methods to detect large genomic deletions/rearrangements, one may calculate that approximately 55% to 59% for Amsterdam II patients are MMR mutation carriers.
- 71% (95% CI 63, 78%) of tumors from patients who fulfilled the Amsterdam I criteria were MSI-H. The corresponding prevalence for Amsterdam II was 68% (95% CI: 58, 76%). However, these estimates may be influenced by selection bias (both in selecting patients for study and in the availability of tumor tissue for testing). We examined several other study-related features but did not observe consistent associations with the prevalence estimates.
- Approximately 40% of colorectal cancers (95% CI: 28, 53%) from patients who fulfill the Amsterdam I criteria demonstrate loss of protein expression for MLH1 or MSH2 by IHC. Testing for loss of expression of MSH6 may increase the proportion by about 6% but the data were limited. The potential biases described above for the prevalence of MMR mutations may also apply to these estimates.
- The sensitivity and specificity of clinical criteria for predicting the presence of MMR mutations is described in Chapter 3. A decision model based upon these estimates characterizes the yield of various strategies in identifying MMR mutations among unselected patients with CRC. An abbreviated family history plus tumor tissue testing for MSI or IHC appeared to identify a similar number of patients with MMR mutations as strategies involving a more complex clinical history.
- No studies described harms of the risk assessment process (e.g., using the Amsterdam criteria, Bethesda guidelines, MSI or IHC testing) in identifying CRC patients at increased risk for CRC.
- There was limited data on harms associated with testing for MMR mutations in probands with CRC. However, the available data do not suggest severe psychological impact in most patients.
- There was limited direct evidence regarding whether the identification of MMR mutations led to improved outcomes for the proband in terms of early detection, mortality/morbidity or management decisions by patients or providers.
- No study described harms associated with the subsequent management options after identification of MMR mutations in patients with CRC or other forms of HNPCC-related cancers.
- Several studies described the accuracy of HNPCC testing in predicting the risk of CRC in family members of probands with HNPCC. However, in most, the diagnosis of HNPCC was not based upon genetic testing. There was limited evidence regarding variables associated with penetrance in family members.
- Pre-test genetic counseling had good efficacy in improving knowledge about HNPCC and resulted in a high likelihood of proceeding with genetic testing, satisfaction in the decision to undergo genetic testing and decreasing depression and distress levels among family members of HNPCC probands or among asymptomatic individuals form HNPCC families.
- Identification of HNPCC mutations was associated with an increase in the likelihood that family members of probands with HNPCC would undergo cancer-screening procedures. However, such patients were self-selected based upon their willingness to undergo predictive genetic testing and thus, this observation may not be applicable to all family members. Survival was increased among asymptomatic HNPCC family members who received colonoscopy screening, regardless of their mutation status.
- There was limited direct evidence related to harms of the cancer-screening procedures in family members of probands with HNPCC. Complication rates associated with these procedures in other settings are probably similar.
- HNPCC family members who underwent cancer-screening procedures had a lower risk of developing HNPCC-related cancers and lower mortality rates than those who did not take actions. However, all of the relevant studies suggesting these benefits had important limitations.

## Implications for Future Research

Our report identified several areas for future research; we considered the following to be particularly important priorities:

- There is very little information regarding the analytic validity of tests used in the diagnosis of HNPCC. Studies specifically addressing sensitivity, specificity, and reliability of all of the laboratory and genetic testing methods in HNPCC are needed. Such studies should focus on contemporary testing methods and compare them against well-defined reference standards in tissue samples representative of the spectrum of genotypes associated with HNPCC. Unpublished information regarding analytic validity is also available; it may be feasible to obtain information from commercial or private laboratories performing such testing. It may also be possible to obtain data from the College of American Pathologists regarding their MSI proficiency program once experience has accumulated. Experience with genetic testing methods in other conditions is likely to be relevant to HNPCC; a review of such information could be conducted by groups of experts on genetic testing techniques.
- Additional studies are needed to clarify the validity of specific clinical and laboratory predictors of HNPCC in patients with CRC who are representative of the general population of patients with CRC.
- Future studies should consider all forms of genetically based CRC cancer predisposition to fully understand the effectiveness of various diagnostic strategies. Such studies should consider all known genetic causes of cancer predisposition and the accuracy of clinical and laboratory testing in identifying these disorders in individuals who are representative of the general population.
- Additional studies are needed to establish the availability of genetic testing centers that can provide adequate counseling and whether there are barriers to access them. Such studies may involve electronic, mail, or telephone surveys.
- More studies are needed to understand what forms of surveillance should be offered to MMR mutation carriers for HNPCC-related cancers other than CRC. Well-designed controlled trials comparing various surveillance (or other management) strategies could be helpful.
- More studies are needed to clarify the risk of cancer in family members of probands with an HNPCC-related cancer who are found to carry MMR mutations. Such studies would ideally be prospective, fully account for interventions (such as cancer screening procedures) in those at-risk, and have a well-defined control population of individuals at average risk for cancer.
- Standards for reporting studies of genetically based diseases (including those addressing all aspects of the ACCE model) should be developed. A consensus development process with publication of a guideline(s) could be helpful.