# Methods

## Key Questions Addressed in This Report

The following Key Questions are addressed in this evidence report:

Key Question 1: Does risk assessment and HNPCC mutation testing in patients with newly diagnosed CRC lead to improved outcomes for the patient or family members, or is it useful in medical, personal, or public health decision making? (Over-arching question).

Key Question 2a: Assuming a clinical definition of the Lynch Syndrome, what proportion of patients has a mismatch repair mutation?

2b: Assuming a clinical definition of the Lynch Syndrome, what proportion of patients has MSI?

2c: Assuming a clinical definition of the Lynch Syndrome, what proportion of patients has abnormal protein expression by immunohistochemistry?

2: How accurate are various predictors assuming a genetic definition of the Lynch Syndrome?

Key Question 3: What are the harms associated with screening high-risk individuals for HNPCC?

Key Question 4: What is known about the analytic (sensitivity, specificity, reproducibility, reliability) and clinical validity of tests that identify HNPCC mutations?

Key Question 5: What are the harms associated with screening for high-risk individuals

Key Question 6a: What are the management options for CRC patients who are HNPCC positive?

6b: Does the identification of HNPCC mutations lead to improved patient outcomes in terms of early detection, mortality/morbidity or management decisions (e.g., counseling, surveillance, treatment, other decision making) by patients and providers?

Key Question 7: What are the harms associated with subsequent management options after identification of HNPCC mutations in CRC patients?

Key Question 8a: What is the efficacy of pre-test genetic counseling for informing family members of potential risks and benefits of testing?

8b: What is the accuracy of HNPCC testing in family members in predicting the risk of CRC?

8c: Do other factors, such as race/ethnicity, age, gender, or co-morbidities affect the accuracy of the testing?

Key Question 9: What are the harms associated with informing/counseling family members or with subsequent testing for HNPCC mutations?

Key Question 10a: What are the management options for family members of CRC patients who have a positive HNPCC test?

10b1: Does the identification of HNPCC mutations lead to improved outcomes in terms of decision-making by patients, family members and providers, or public health policy?

10b2: Does the identification of HNPCC mutations lead to improved outcomes in terms of early detection and mortality/morbidity of patients, family members?

Key Question 11: What are the harms associated with subsequent actions or interventions for family members?

These questions were formulated by EGAPP based upon an analytic model that begins with a patient with CRC and proceeds to genetic testing of family members. They broadly reflected the conceptual framework proposed by the ACCE Project from the Office of Genomics and Disease Prevention at the Centers for Disease Control and Prevention (CDC). The aim of the project is to develop a model system for assembling, analyzing, disseminating and updating existing data on the safety and effectiveness of DNA-based genetic tests and testing algorithms (See http://www.cdc.gov/genomics/gtesting/ACCE.htm for details). ACCE takes its name from its four components of evaluation—analytic validity, clinical validity, clinical utility and associated ethical, legal and social implications. It is intended to provide a model process for evaluating data on emerging genetic tests. The process includes collecting, evaluating, interpreting, and reporting data about DNA (and related) testing for disorders with a genetic component in a format that allows policy makers to have access to up-to-date and reliable information for decision making. The CDC Office of Genomics and Disease Prevention has previously published a mini review on HNPCC based upon the ACCE framework, which underscored the need for a more comprehensive review (see http://www.cdc.gov/genomics/gtesting/ACCE/fbr.htm).

The Key Questions were refined in several teleconferences with members of EGAPP and the Technical Expert Panel (TEP), and following review of draft reports.

The Key Questions and subset questions were divided conceptually into three general domains: clinical validity; analytic validity; and benefits and harms of screening, genetic testing and various management strategies from the patient, family member, provider, and public health perspectives. (Table 6) These domains were based upon overlapping concepts implied by the Key Questions and reflect the core components of the ACCE model. Thus, Key Questions were grouped according to the domain, and studies that addressed one of the three domains were often relevant to more than one Key Question, but generally not to more than one domain.

Table 6 Summary of key questions

Domain | Key questions addressed
Analytic validity | 4
Clinical validity | 2, 2a, 2b, 2c
Benefits and harms (including clinical utility and associated ethical, legal and social implications in the ACCE model) | 1, 3, 4, 5, 6a, 6b, 7, 8a, 8b, 8c, 9, 10a, 10b1, 10b2, 11

Table 7 Interpretation of overall quality grading of individual studies

Grade | Explanation for quality scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Table 8 Quality criteria used to characterize studies of clinical validity

Item | Criteria | Yes | No | Un- clear
| General quality criteria
1 | Were unselected patients with CRC included (i.e., were representative of patients seen in clinical practice not selected based upon a suggestive family history or other criteria that may cause selection bias)?
2 | Inclusion criteria clear?
3 | Did the whole sample or a random selection of the sample (i.e., total population of patients with CRC) receive verification using gene sequencing?
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing (i.e., was there blinding)?
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e., was there blinding)?
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g., badly stained tissues etc)?
7 | Were withdrawals from the study explained?
8 | Did the authors report AND analyze results for deleterious MMR mutants?
| Additional relevant quality items
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g., either a full description or relevant references)?
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)?
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated?
12 | Was there a clear description of which mismatch repair mutations were being tested for?
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing.... i.e., avoid verification bias)?
14 | Were quality control methods described for the molecular and genetic tests?
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)?
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e., this helps minimize the effect of random errors.)

Table 9 Quality criteria used to characterize studies of analytic validity

| Study quality | Yes | No | Unc
1 | Was the description of how MSI or IHC and other genetic techniques described in sufficient detail that others could replicate it (e.g., either a full description or relevant references)?
2 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)?
3 | Was MSI, IHC, other genetic testing performed at a similar time interval between specimen collection and processing for all subjects evaluated?
4 | Was there a clear description of which mismatch repair mutations were being tested for?
5 | Were quality control methods described for the molecular and genetic tests?
6 | Did the authors attempt to address the reproducibility of results (reliability of tests)?
7 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e., this helps minimize the effect of random errors).
8 | Was microdissection (technique for removing only tumor tissue from gross specimen) performed?
9 | Did the study specify whether the biological tissues were from patients known to have HNPCC clinically?
10 | Did the study include a control group in which biological material was obtained from patients known not to have HNPCC clinically

Table 10 Quality criteria for studies on benefits and harms

Domain/question | Place an “X” in one | | | | | Overall rating
Selection bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation bias | | | | | | A | B | C
(RCTs only, for quasi- experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e., intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e., intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

We undertook the following steps in conducting this review:

- Performed an electronic search of the literature followed by review of relevant abstracts and then full-text review of potentially relevant studies.
- Retrieved additional studies from bibliographies of retrieved citations and suggestions of the TEP.
- Included or excluded studies based upon prespecified criteria.
- Identified duplicate reports of the same patients by comparing authors and study centers. Data were included only once, except when duplicate studies reported complementary information (e.g., data at one month and then one year).
- Developed data extraction forms for each domain (i.e., three data extraction forms) and tested them until we achieved consensus on the meaning of the data elements in each extraction form.
- Evaluated each study critically according to quality criteria described below.
- Verified all data with at least two extractors.
- Summarized data in tables that addressed specific Key Questions (or groups of Key Questions) that corresponded to the three domains described above. Because only a few studies addressed analytic validity, we described them in the text of the report rather than in tables.
- Reviewed drafts of the summary tables with members of the TEP.
- Pooled data where studies used similar methodology and definition of endpoints using meta-analysis to provide a point estimate and 95% confidence interval, mainly for questions pertaining to clinical validity. We performed multiple sensitivity analyses to explore possible explanations when studies demonstrated statistically significant heterogeneity.
- Constructed models depicting various strategies for identifying HNPCC among patients with colorectal cancer using decision trees. The models were based upon parameters estimated from data presented in this report.
- Prepared a draft report, which underwent peer review and addressed each comment in a revised final report.

## Literature Search Strategy

We conducted a literature search of MEDLINE^®^ using PubMed on January 10, 2006. We used MEDLINE^®^ subject headings and text words to capture relevant English language publications of human studies. Additional sources of potentially relevant studies included technical experts and hand searching of bibliographic references of reviews. An automatic updated search results from PubMed was received on April 1, 2006 after which additional studies were included only if the investigators or TEP considered them to provide substantive new information that might influence the conclusions (see Appendix A *).

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/hnpcctp.htm

We reviewed all abstracts for their relevance to the Key Questions and retrieved the full-text article of potentially relevant citations. We reviewed bibliographies of studies included in the report (as well as previous review articles or meta-analyses, which were not included) to identify additional citations, all of which were retrieved for review. We identified duplicate reports of the same patients by comparing authors and study centers. Duplicate reports were excluded unless they provided complementary information (such as outcomes at different time points) in which case they were considered together.

## Inclusion/Exclusion Criteria and Data Extraction

We applied prespecified inclusion and exclusion criteria in considering each study. The criteria corresponded to the three domains described above.

### Studies Related to Analytic Validity

We required the following for studies of analytic validity:

- The study evaluated biological material from patients with colorectal cancer considered to be at risk for HNPCC. This criterion was selected to choose studies evaluating laboratory techniques that were directly applicable to the spectrum of genotypes associated with HNPCC. We did not consider it feasible to conduct a systematic review on the individual laboratories tests used for other conditions.
- Reported any of the following (these criteria were selected to choose studies evaluating the most common tests performed in HNPCC):
  1 Proportion of tumors that were MSI-H with National Cancer Institute (NCI) panel of markers (i.e., BAT-25, BAT-26 D2S123, DS346 and D17S250) versus other markers
  2 Sensitivity or specificity of MSI-H using NCI markers compared with a reference standard that the study claimed was better
  3 Sensitivity or specificity of IHC compared with an immunohistochemical standard that study claimed was better
  4 Sensitivity or specificity of a genetic technique compared with a reference standard (or combination of standards)
  5 Reliability of MSI, IHC or genetic methods across laboratories or within a laboratory.
- Data were extractable into 2×2 tables.

We excluded studies that included the index test in the reference standard. For example, some studies attempted to calculate sensitivity of a specific NCI MSI marker by comparing it with a reference standard that included the marker plus additional markers. Such an approach produces an invalid estimate of sensitivity since the calculation includes the index test (i.e., the specific NCI marker) in the numerator and the denominator.

### Studies Related to Clinical Validity

We required all three of the following criteria to be met for studies of clinical validity with extractable data:

- Enrolled patients with colorectal cancer
- Compared an index test to genetic testing ([underlined: at least] one of the following: suggestive family history, MSI, or IHC)
- Sought mutations using DNA sequencing (or other similar genetic approaches) for a minimum of MLH1 and MSH2.

HNPCC has been defined clinically and genetically as described in Chapter 1. We used both approaches depending upon which Key Questions were being addressed. In all cases, the definitions used are described explicitly in the tables and figures.

Key Questions 2a–2c focus on the prevalence of MMR mutations, suggestive MSI or ICH among patients with a clinical definition of HNPCC. We defined Lynch Syndrome I and Lynch Syndrome II using the Amsterdam I and II criteria, respectively. Studies that reported this proportion or provided sufficient data for it to be calculated were eligible.

We required that studies evaluated all available patients who fulfilled the Amsterdam criteria or a representative (random) sample thereof. We excluded studies that did not evaluate all patients because they selected a non-random patient sample (e.g., patients who fulfilled the Amsterdam criteria who were also younger than a certain age).

Key Question 2 pertains to the predictive accuracy of clinical or laboratory features for determining the presence of mismatch repair mutations. We assessed the performance of different clinical and laboratory predictors (preliminary tests) to identify carriers of MMR gene mutations. We considered all studies that provided relevant data. When the primary study reported proportions rather than actual counts, we reconstructed the 2×2 tables using the information conveyed by the proportions and their 95% confidence intervals.

We analyzed the following predictors:

Laboratory predictors:

1 MSI high versus MSI stable.
2 MSI high and low versus MSI stable.
3 Suggestive IHC versus non suggestive IHC.

Clinical predictors specified a priori:

1 Amsterdam I criteria fulfilled versus not fulfilled.
2 Amsterdam II criteria fulfilled versus not fulfilled.
3 Modified Amsterdam criteria fulfilled versus not fulfilled.
4 Bethesda guidelines fulfilled versus not fulfilled.
5 Revised Bethesda guidelines fulfilled versus not fulfilled.
6 Young age of onset (<50 years) versus later age of onset
7 Presence of CRC or HNPCC related cancer in first degree family versus sporadic CRC cases.
8 Presence of CRC or HNPCC related cancer in family (any definition) versus sporadic CRC cases (irrespectively of how they were selected).

Clinical predictors specified a posteriori:

9 Presence of multiple tumors in a CRC proband versus probands without multiple tumors.
10 Presence of young age of onset (<50 years) or suggestive family history of cancer or multiple tumors in a CRC proband (i.e., predictors #6 or #7 or #8) versus absence of all three characteristics.

We focused only on patients with CRC who received at least some form of genetic testing to minimize the effects of verification bias. Verification bias occurs when patients with a negative test result are not evaluated with the reference test.^47^ We generally did not accept screening with MSI or IHC as a substitute for genetic testing. A single exception pertained to studies assessing clinical predictors among newly diagnosed, unselected, non-referral CRC, because this was of particular clinical importance and there were few studies available for analysis. For such studies we accepted the authors' assumption that patients who were not tested for mutations based on MSI and IHC test results were indeed mutation negative.

### Studies Related to Benefits and Harms

For studies related to benefits and harms, we accepted studies of virtually any design and using any definition of HNPCC that reported any outcomes or other findings pertinent to patients or families with HNPCC, or provided insights into these issues from a public health perspective. We did not confine our inclusion criteria to studies of patients with colorectal cancer even though this report focuses on patients with colorectal cancer. Benefits and harms of genetic testing, counseling and other management approaches are pertinent to the full spectrum of tumors associated with HNPCC. For example, a woman with colorectal cancer who is found to have HNPCC is at risk for other forms of HNPCC-related cancer (such as endometrial cancer). Thus, the benefits and harms related to genetic testing may not only be relevant to clinical issues related to colorectal cancer management (and prevention of metachronous cancers) but also management (and prevention) of other HNPCC-related cancer in the patient or her family members. We expanded the scope of all pertinent Key Questions to provide as comprehensive a view on these issues as possible.

Although we attempted to be as comprehensive as possible in including studies related to benefits and harms, we occasionally encountered studies that did not report any outcomes or other findings that appeared to be relevant to the Key Questions and thus excluded them. As noted above, the reasons that specific studies were excluded are summarized in the Appendix D *. List of Excluded Studies.

## Evaluation of Study Quality

We evaluated the quality of each study based upon multiple quality features. Evaluation of study quality is a complex process since there is no established method that can comprehensively describe all features that are pertinent to the validity of a study. The included studies varied in the rigor with which they were designed, conducted, analyzed, and reported. Deficiencies in any of these areas can lead to biased reporting and interpretation of results.

Furthermore, the quality of a study and its applicability are not always related; a study that is considered to be of relatively low quality may be more applicable to a specific question (i.e., answers it directly) than a study of higher quality. In addition, assessment of quality is based upon information reported and not necessarily how the study was conducted since there may be omissions or editorial constraints in the published manuscript.

We hoped to critically assess the quality of each study and to present studies based upon their applicability to each Key Question. Thus, we attempted to feature studies that answered Key Questions most directly and reported a composite quality score (A, B or C, described below) to allow comparison among studies. We based the composite quality score upon an overall assessment of the degree to which individual elements describing study quality were fulfilled and the implications of those that were not. There was an element of judgment for the final scoring of each study but we attempted to be as consistent as possible.

The composite quality scores are helpful for giving a shorthand, qualitative appraisal of the overall study quality, but they do not necessarily reflect particular deficiencies or strengths that might be important for fully understanding the results of the study or interpreting the body of knowledge. Thus, strengths and weaknesses of individual studies might be important when considering their validity and relevance for specific Key Questions. We attempted to highlight study features that we considered to be most relevant while making comments as to specific deficiencies to allow readers to have a view on this that was transparent and succinct. The components of the individual quality scores for each study are available in Appendix C *. In addition, important features of each study are summarized in the tables included in the body of the text following each Key Question to allow for easy comparison among them.

We used the composite quality score formally for sensitivity analysis, mainly for studies of clinical validity to determine whether study quality correlated with test characteristics. For example, we determined whether sensitivity and specificity were better for high compared with low quality studies.

The quality criteria selected for this report (summarized below) were based upon discussions with the TEP and quality elements that have been proposed to be relevant for the specific types of studies that we included. All investigators discussed details of the meaning of each quality element to help assure that they were applied uniformly. Investigators discussed the quality of individual studies whenever there were questions related to the overall score that the study should receive until consensus was achieved.

The Tufts-NEMC EPC has used similar systems for several other evidence reports. However, it must be acknowledged that the reliability and validity of quality scoring systems used for systematic reviews, including the one used for this report, have not been extensively evaluated.^48^

We used the following approach for grading studies related to clinical validity. These criteria were adapted, in part from the Centers for Disease Control and Prevention and the QUADAS tool for assessing diagnostic test accuracy.^49,^ ^50^

We used the following quality criteria for studies related to analytic validity. These criteria were adapted from those proposed by the Centers for Disease Control and Prevention.^49^

We used the following quality criteria for studies related to benefits and harms. These criteria were adapted from the Cochrane Collaboration Handbook for Systematic Reviews of Health Promotion and Public Health Interventions for Evaluation of Studies Related to Public health.^51^

## Data Synthesis, Analysis, and Reporting

### Questions Related to Analytic Validity

As will be discussed in Chapter 3, we encountered only a few studies of analytic validity, and thus these are described in the text rather than in tables. There were insufficient data for a pooled analysis.

### Questions Related to Clinical Validity

Studies relevant to each Key Question were grouped together, organized according to their applicability to the specific Key Question and their overall quality score. In some cases, Key Questions that had substantive overlap in the type of findings reported were grouped together to provide a comprehensive yet succinct overview of the literature.

Questions related to clinical validity: For questions related to clinical validity, sensitivity and specificity were based upon the definitions summarized in Chapter 1. We presented studies by categorizing them for important features (such as use of similar definitions and selection criteria) so that similarities and differences would be as transparent as possible.

Prevalence of MMR Mutations, MSI or Suggestive IHC Among Patients Fulfilling Amsterdam I and II Criteria. For each study we estimated the proportion (and exact binomial 95% confidence interval) of Amsterdam I and II patients with MMR mutations, MSI or suggestive IHC. We estimated the corresponding summary prevalence values with random effects meta-analyses.^52,^ ^53^ For the quantitative syntheses, proportions from each study were logit transformed to stabilize variances, and then back-transformed to their natural scale. Analyses using the more drastic Tuckey-Freeman arcsin transform yielded largely similar estimates, and thus are not reported.

Diagnostic Ability of Predictors (Preliminary Tests) To Identify MMR Mutation Carriers. As mentioned above, the preliminary tests that identify MMR mutation carriers are either sets of clinical criteria, or laboratory tests (namely MSI and IHC). Different considerations are applicable to the analysis of clinical and laboratory predictors across a selection of studies.

Considerations on study populations for clinical predictors (preliminary tests). In HNPCC the clinical preliminary tests are highly susceptible to spectrum effects across populations that have been selected with eligibility criteria of a clinical nature. Although the detailed analysis of this statement is cumbersome, it can be intuitively evaluated through an illustrative example. Assume that the preliminary test of interest is the clinical criterion of “age less than 50 years at diagnosis of CRC”. It is expected that the sensitivity and specificity of this criterion will be different among unselected people with CRC compared to CRC patients who were less than 55 years at diagnosis. The second population has already been “pre-selected” based on a clinical criterion (less than 55 years at CRC diagnosis) that is quite similar to the evaluated “preliminary test” (less than 50 years at CRC diagnosis). This pre-selection alters the composition of the population with respect to the clinical predictor in a systematic and non-random way, both among MMR mutation carriers and among non-carriers. The net effect is a change in the apparent sensitivity and specificity across populations with increasing prevalence of MMR mutation carriers (spectrum effects).

Because of the aforementioned consideration we decided a priori not to synthesize the sensitivity and specificity of clinical predictors across populations that had been defined using different clinical eligibility criteria. Identifying such homogeneous populations is challenging, especially given the incomplete descriptions of the studied populations in many of the assessed studies.

Thus we decided to focus on populations fulfilling sets of criteria that are most frequently used for HNPCC, are well known, and presumably assessed identically by different research teams. In order of increasing prevalence of MMR mutation carriers these homogeneous populations were: unselected, incident CRC, patients selected by the Bethesda guidelines and revised Bethesda guidelines, modified Amsterdam criteria, and Amsterdam II and I criteria. We also created separate estimates for the sensitivity and specificity for patients who were pre-selected based on suggestive MSI and/or IHC results.

Considerations on study populations for laboratory predictors (preliminary tests). The above consideration may not be as important for laboratory predictors (e.g., IHC) because there is no strong reason to assume that pre-selection with a clinical eligibility criterion (e.g., “age less than 55 at CRC diagnosis”, as above) in a study would be correlated with IHC results both in MMR carriers and in those who are not MMR mutation carriers. However, it is possible that some laboratory predictor tests (e.g., MSI analysis) may be vulnerable to spectrum effects.^54^ Thus, for laboratory predictors, we did not require the strict similarity of populations across studies as above, and considered all studies together.

Separate analyses of sensitivity and specificity. For each study we estimated the sensitivity and specificity (and exact binomial 95% confidence intervals thereof) for the clinical and laboratory predictors (preliminary tests) of interest. As described before, we derived summary sensitivity and specificity estimates with random effects syntheses using logit-transformations of proportions for the meta-analyses. As a general rule, this approach tends to underestimate the diagnostic performance, because it ignores the correlation between the sensitivity and the corresponding specificity from the same study. However, it provides a pooled estimate (and 95% confidence interval) of sensitivity and specificity that can be useful for providing overall appraisal of test performance.

Summary receiver operating characteristic curve analyses. For laboratory predictors only, we summarize test performance graphically using summary receiver operating characteristic curve (SROC) analyses. SROC curve analysis can be used to graphically describe the tradeoff between sensitivity and specificity across studies. The sensitivity and specificity of each study are represented in the graph, thereby depicting the operating characteristics of a group of studies.

The tradeoff between sensitivity and specificity generally reflects the threshold for calling a test positive or negative. Such a tradeoff can be understood easily when considering a single study that assessed various cutoff values of a diagnostic test. By contrast, the threshold implied in an SROC curve analysis is not always apparent. Different estimates of sensitivity and specificity across studies may be due to several considerations such as variations in how the tests were implemented (e.g., differences in the number of microsatellite markers used) or in interpretation of results. With regard to the latter, the same specimen (e.g., a tumor stained for IHC) may be interpreted differently when the interpreter believes the test is being used for screening versus confirmation of a high-risk patient. Thus, by grouping studies according to specific study features, SROC analysis can be used to help explain differences in test characteristics across studies that seemingly used the same diagnostic test. However, it does not necessarily define an explicit threshold effect.

The area under a receiver operating curve has been used to describe the overall diagnostic ability of a test; the greater the area, the better the test. However, calculating the area under a SROC curve requires extrapolation outside the range of the sensitivity and specificity values of the analyzed studies and thus may not produce a valid appraisal of the test's accuracy. As a result, we did not attempt to calculate the area under the SROC curve.

Subgroup and Sensitivity Analyses. We defined a priori factors that might explain heterogeneity of pooled estimates. These included:

Overall quality. We compared results from high and low quality studies (as defined by the A, B or C classification described above).

Study size. For the questions relating to the proportion of patients with the Lynch Syndrome with mutations or abnormal MSI or IHC results, we used a cutoff of 20 patients (≥20 versus <20) to distinguish larger and smaller studies. Although this was a largely arbitrary cutoff, a single misclassification in smaller studies would result in more than a 5% misclassification rate, which we considered clinically important. Similarly, we used a cutoff of at least 40 people in the 2 by 2 table for studies that were used to assess sensitivity and specificity.

Characteristics of how genetic testing was performed. Studies were categorized in groups according to the comprehensiveness of the genetic testing strategy they used. As least comprehensive, we classified studies that used only gene screening methods to detect MMR mutations, and did not perform sequencing on any sample; performed sequencing on samples with suggestive gene screening analyses; or performed sequencing on all available samples. As most comprehensive we considered studies that performed sequencing and analyses for large genomic deletions/rearrangements in all samples. The application of more advanced techniques such as conversion analysis or mono allelic mutation analysis (MAMA) was only sporadic or in the context of demonstrating their feasibility in only a few samples, and thus did not comprise a separate category. Examples of genetic screening strategies are single-stranded conformation polymorphism (SSCP), conformation sensitive gel electrophoresis (CSGE), denaturing gradient gel electrophoresis (DGGE), and denaturing high-pressure liquid chromatography (DHPLC). Examples of methods to detect large genomic deletions are: southern blotting and multiplex ligation-dependent probe amplification (MLPA). These methods are described in more detail on Chapter 3 in the section on Analytic Validity.

Whether and how the study defined pathogenic mutations. We determined if and how studies defined mutations as being pathogenic (i.e., known to be associated with HNPCC versus a variant of unknown significance). It is possible that the same mutations might have been defined as pathogenic in one study and non pathogenic in another.^55^ Furthermore, not all definitions are equally valid and the methods used to define pathogenicity may not have been conducted with equal rigor. For example evidence from functional studies (i.e., in which the function of the mutated gene was assessed) may provide strong support that the mutation is pathogenic, whereas absence of the mutation in a small sample of healthy controls is not as strong.

Characteristics of MSI testing. We assessed whether studies that used the panel of markers recommended by the NCI and whether they performed microdissection. Microdissection helps assure that the sample analyzed was from malignant tissue and did not contain DNA from surrounding, healthy colonic tissue. Microdissection is not pertinent to germline MMR mutation testing or IHC. Germline mutations are typically assessed in blood samples (non-malignant tissue). For IHC, a pathologist studies a tissue section to evaluate MMR protein expression in regions of malignancy (microdissection it typically not needed).

The sample selection process. We attempted to identify studies that had a biased sample selection process. Studies with transparent sample selection process clearly stated that they selected their samples among all available patients using a set of eligibility criteria. Studies with non-transparent sample selection process did not report that they applied the same criteria to all available patients. For example, they may have used a convenience sample of cases from various sources.

Despite our efforts, we caution that studies that applied seemingly transparent eligibility criteria may still have a highly biased selection process. For example, studies from a referral center may have recruited patients with a relatively higher prevalence of familial cancer compared with studies that recruited consecutive patients with colorectal cancer in the community.

Whether the study used consecutive, unselected patients with CRC. We identified studies that used consecutive CRC (including retrospective studies that assessed all unselected patients that were diagnosed during a specific time period) that were otherwise nonselective or representative of the general population. Populations evaluated in studies from specialized centers or studies that imposed clinical or other criteria to select their populations were not considered to be representative of the general population.

Decision Tree Model Methods. We performed analyses using decision trees to model the expected outcomes with different testing strategies from the payers'/third party perspective. The outcomes were the number of incident CRC with positive diagnosis for HNPCC, and the number of tests (MMR, MSI, or IHC) needed to detect them. We also assessed how many patients found to be mutation carriers with each strategy would be truly positive.

The decision trees pertain to a cross-section in time. We used a hypothetical population of 100,000 incident cases of CRC. This number is in the order of incident cases expected annually in the US (approximately 150,000, given an annual incidence of 50/100,000 and a population of 300 million) and is a number convenient for calculations.

We assessed nine different strategies, which were most commonly represented in the studies summarized in this review. The strategies used clinical criteria, MSI, IHC or a combination of clinical criteria with MSI or IHC to select patients for MMR mutation testing. The probabilities that were used in the decision trees were derived from the eligible studies. See Chapter 3 for a complete description of the modeled strategies and the probabilities that were used.

### Questions Related to Benefits and Harms

For studies related to benefits and harms, we grouped studies according to their relevance to the Key Questions, presenting comparative trials and higher quality studies first followed by qualitative and other types of descriptive studies. Statistical comparisons made within each study are presented; we did not attempt to recalculate these comparisons; however, specific comments about study methods are included in footnotes.

The majority of studies related to benefits and harms were qualitative. Among the comparative trials, there were insufficient studies of similar design to allow for meta-analysis.

We present major findings that were considered to be clinically important or addressed (directly or indirectly) the Key Questions and subset questions. We described together studies that used similar endpoints (e.g., quality of life instruments or depression scales) and interventions (e.g., surveillance colonoscopy) whenever possible.

### Evidence and Summary Tables

Evidence tables offer a detailed description of the studies that addressed each of the Key Questions. Each study appears once regardless of how many interventions or outcomes were reported. We did not attempt to construct evidence tables for all the extracted studies but all data extracted for each study are included in data extraction forms that are available in Appendix C *.

Summary tables succinctly report summary measures of the main study features and outcomes evaluated. They are designed to facilitate comparisons and synthesis across studies. Individual studies may appear more than once if the data they contain are relevant to more than one Key Question. The summary tables are featured in sections corresponding to each Key Question in Chapter 3.