# Appendix G. One-Way Sensitivity Analyses for the Decision Trees

The three variables with the most important influence for each strategy are depicted in the corresponding figures.

Number of tests

Figure G-1 shows the one-way sensitivity analyses on the expected number of MMR genetic tests with each treatment strategy. Among the three variables that exerted the most influence on the expected number of MMR genetic tests were the diagnostic characteristics (mainly the specificities) of the clinical criteria, IHC or MSI, and the prevalence of MMR mutations. For strategies using serial screening with clinical criteria and MSI or IHC, the diagnostic characteristics of both tests (mainly their specificities) were among the three more influential variables.

Figure G-1. One-way sensitivity analysis for the number of MMR genetic tests expected from each strategy among a hypothetical population of 100,000 incident CRC

Shown are the effects of one-way sensitivity analyses on the number of MMR tests performed in each strategy. The horizontal bars illustrate the different values that the outcome takes when a variable is varied from its lower to its higher plausible value in the sensitivity analyses. Only the three variables that had the greatest influence on each strategy are depicted (variable names are explained in Table 15 and in the text). Since all other variables had an even smaller influence, they are not depicted at all. The first strategy (MMR-All) is not shown. The first strategy assumes that all patients receive MMR testing; thus the number of expected MMR tests is always 100% of the population.

Figure G-2 shows the variation in the expected number of MSI and IHC tests for the strategies that are affected by the sensitivity analyses. The remaining strategies either do not use MSI or IHC at all (MMR-All, BethR-All, 3Clinical-All) or use one test in all patients and the other test in none (MSI-All and IHC-All).

Figure G-2. One-way sensitivity analysis for the number of MSI or IHC genetic tests expected from each strategy among a hypothetical population of 100,000 incident cases of CRC

The bars for the first two strategies (BethR-MSI and 3Clinical-MSI) refer to the expected number of MSI tests. The expected number of IHC tests is zero since IHC is not used in these strategies. Similarly, the bars for the last two strategies (BethR-IHC and 3Clinical-IHC) refer to the expected number of IHC tests. The expected number of MSI tests is zero since MSI is not used in the latter strategies. Layout similar to Figure 27.

Number of people with positive test

The most important influence on the number of people with positive or true positive MMR was prevalence of MMR mutation carriers in the population. Diagnostic characteristics of the various tests also have a role. Figure G-3 and Figure G-4 illustrate the pertinent one-way sensitivity analyses.

Figure G-3. One-way sensitivity analysis for the number of positive MMR tests expected from each strategy among a hypothetical population of 100,000 incident cases of CRC

The layout is similar to Figure 27.

Figure G-4. One-way sensitivity analysis for the number of true positive MMR tests expected from each strategy among a hypothetical population of 100,000 incident cases of CRC

The first strategy (MMR-All) is affected only by two variables in the sensitivity analyses. The layout is similar to Figure 27.