# Appendix F. Summary Tables on Clinical Validity

Table F-1. Prevalence of mismatch repair gene mutations among colorectal cancer probands who fulfill Amsterdam I criteria.

Table F-2. Prevalence of MLH1 and MSH2 mutations among colorectal cancer probands who fulfill Amsterdam II criteria.

Table F-3. Prevalence of microsatellite instability among colorectal cancer probands who fulfill Amsterdam I criteria.

Table F-4. Prevalence of microsatellite instability among colorectal cancer probands who fulfill Amsterdam II criteria.

Table F-5. Prevalence of negative immunostaining for MLH1 or MSH2 among colorectal cancer probands who fulfill Amsterdam I criteria.

Table F-6. Ability of Amsterdam I criteria to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands.

Table F-7. Ability of Amsterdam I criteria to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands.

Table F-8. Ability of Amsterdam I criteria to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands fulfilling the Bethesda guidelines.

Table F-9. Ability of Amsterdam I criteria to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands fulfilling Amsterdam II criteria.

Table F-10. Ability of Amsterdam II criteria to identify MLH1 and MSH2 mutation carriers among selected colorectal cancer probands.

Table F-11. Ability of Amsterdam II criteria to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands..

Table F-12. Ability of Amsterdam II criteria to identify MLH1 and MSH2 mutation carriers among selected colorectal cancer probands fulfilling the Revised Bethesda criteria.

Table F-13. Ability of Amsterdam II criteria to identify MLH1 and MSH2 mutation carriers among selected colorectal cancer probands fulfilling the Bethesda guidelines.

Table F-14. Ability of modified Amsterdam criteria to identify MLH1 and MSH2 mutation carriers among selected colorectal cancer probands.

Table F-15. Ability of Bethesda guidelines to identify MLH1 and MSH2 mutation carriers.

Table F-16. Ability of Bethesda guidelines to identify MLH1 and MSH2 mutation carriers among unselected patients with colorectal cancer.

Table F-17. Ability of revised Bethesda guidelines to identify MLH1 and MSH2 mutation carriers among unselected patients with colorectal cancer.

Table F-18. Ability of Ability of young age at diagnosis (early disease onset) to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands.

Table F-19. Ability of Ability of young age at diagnosis (early disease onset) to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands.

Table F-20. Ability of familial history of malignancy to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands.

Table F-21. Ability of familial history of malignancy to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands.

Table F-22. Ability of presence of multiple tumors to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands.

Table F-23. Ability of presence of combined family history of colorectal cancer, young age at onset or presence of multiple tumors to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands.

Table F-24. Ability of microsatellite instability to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands.

Table F-25. Ability of microsatellite instability to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands.

Table F-26. Ability of microsatellite instability to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands fulfilling the revised Bethesda criteria.

Table F-27. Ability of microsatellite instability to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands fulfilling the Amsterdam I criteria.

Table F-28. Ability of immunohistochemistry to identify MLH1 and MSH2 mutation carriers among selected colorectal cancer probands.

Table F-29. Ability of immunohistochemistry to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands fulfilling Amsterdam I criteria.

Appendix F contains summary Tables (Appendices F-1 to F-29). Appendices F-1 to F-5 summarize the prevalence on mismatch repair (MMR) gene mutations, microsatellite instability or negative immunohistochemistry among patients fulfilling Amsterdam I or II criteria. Appendices F-6 to F-29 summarize the diagnostic ability of clinical and laboratory predictors to detect MMR gene mutations among different populations. Table 14 of the evidence report provides a roadmap to the different summary tables. For convenience, the information included in Table 14 of the Evidence Report is repeated after the following table of contents. Note that usually only MLH1 and MSH2 were assessed. Whenever additional genes were assessed (MSH6 or PMS2), they are clearly noted in the Tables and footnotes.

Table F-1 Prevalence of mismatch repair gene mutations among colorectal cancer probands who fulfill Amsterdam I criteria

Study, year (Ref ID); | A. Comments on sampling | N_Am1_/N_total_ | MLH1 and MSH2 mutations | | Quality
Country | B. Genetic testing strategy | | Positive/ Analyzed | Proportion [%](95% CI)
Single-/multi-center | C. Definition of deleterious mutations
De Abajo 2005; | A. Selection among referrals to a specialized center | 56/132 | 32/56 | 57 (42, 70) | B
Spain | B. PCR → DGGE → sequencing (MSH6 assessed in MLH1/MSH2 negative cases, included in the counts)
Single-center | A. Predicted non-conservative transcription alteration; literature; comparison with healthy controls
Syngal 2000 (1672) & | C. Selection among referrals to a specialized center | 28/70 | 11/28 | 39 (22, 59) | B
Wahlberg, 2002 (1158); | D. PCR, sequencing
US | E. Predicted non-conservative transcription alteration; literature
Single-center
Wang, 1999 (1939); | A. Sampled among referrals to a genetic consultation center | 22/70 | 14/22 | 64 (41, 83) | B
France | B. ØRT-PCR → IVSP; ♦ PCR → HD; in vivo hML1 expression
Single-center | C. Predicted transcription alteration; literature
Curia, 1999 (1959); | A. Sampled from pathology registries, unclear selection criteria | 15/30 | 1/15 | 7 (0, 32) | B
Italy | B. ♦RT-PCR → SSCP → Sequencing of abnormal patterns
Single-center | C. Predicted non-conservative transcription alteration; literature; comparison with non-cancer controls
Luce, 1995 (2703); | A. Selection among referrals to a specialized center^a^ | 12/19^a^ | 6/12 | 50 (21, 79) | B
US | B. ♦PCR → IVTT → Sequencing of abnormal peptides
Single-center | C. Unclear
Katballe, 2002 (1310) & | A. Selection from a population of 1514 incident CRC | 11/45 | 5/11 | 45 (17, 77) | B
Christensen, 2002 (1038); | B. ♦PCR → SSCP & HD →Sequencing of abnormal patterns
Denmark | C. Predicted non-conservative transcription alteration; literature
Single-center
Dieumegard, 2000 (1791); | A. Sample assembled with unclear selection process | 10/34 | 6/10 | 60 (26, 88) | B
France | B. ♦PCR → SSCP → Sequencing of abnormal patterns
Multi-center | C. Predicted non-conservative transcription alteration; literature
Aaltonen, 1998 (2282); | A. Selection of all incident unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | 4/509 | 4/4 | 100 (40, 100) | B
Finland | B. ♦PCR → DGGE (for some samples) → Sequencing; PCR → Sequencing (for all other samples); Ø and PCR for founder mutations (all samples)
Multi-center | C. Literature; and comparison with healthy controls
Rossi, 2002 (1146); | A. Selected from consecutive CRC referrals | 4/25 | 1/4 | 25 (0, 81) | B
Brazil | B. PCR → Sequencing
Single-center | C. Unclear
Park, 1999 (2007); | A. Study sample assembled from the ICG-HNPCC database | 154/277 | 77/154^b^ | 50 (42, 58) | C
7 countries | B. ♦PCR → SSCP; and Ø southern blotting (no details)
Multi-center (8 centers) | C. Unclear^b^
Lamberti, 1999 (2036); | A. Study sample assembled with unclear selection process | 57/160 | 15/57 | 26 (16,40) | C
Italy | B. ♦PCR → SSCP, and RT-PCR → PTA
Single-center | C. Literature
de Leon, 1999 (2012); | A. Sample selected from CRC patient registries | 18/36 | 3/18 | 17 (4, 41) | C
Italy | B. ♦PCR → SSCP → Sequencing of abnormal patterns
Single-center | C. Unclear
Liu, 2004 (445); | A. Study sample assembled with unclear selection process | 15/28 | 5/15 | 33 (12,62) | C
China | B. ♦PCR → DHPLC → Sequencing of abnormal patterns
Single center | C. Unclear
Moslein 1996 (2545); | A. Sample assembled from various databases; only cases stated to have had CRC are analyzed^c^ | 14/46 | 6/14^c^ | 43 (18,71) | C
US & Germany | B. PCR → Sequencing
Multi-center | C. Predicted non-conservative transcription alteration; literature
Callistri, 2000 (1797); | A. Study sample assembled with unclear selection process | 13/45 | 7/13 | 54 (25,81) | C
Italy | B. ♦PCR → SSCP
Multi-center | C. Unclear
Colombino, 2005 (1058); | A. Selection from consecutive CRC cases enrolled over 3 years^a^ | 13/362^a^ | 10/13 | 77(46,95) | C
Italy | B. ♦PCR → DHPLC→Sequencing of abnormal patterns
Single-Center | C. Compared mutations to 103 people without cancer
Stormorken, 2001 (721) | A. First 56 families in the Norwegian Radium hospital registry | 12/56 | 3/12 | 25 (5,57) | C
Norway | B. Not described (was already done) (MSH6 was assessed also, included in the counts)
Single-center | C. Not described
Debniak, 2000 (1784); | A. Sampled from consecutive CRC, selection process not transparent | 3/168 | 1/3 | 33 (0,91) | C
Poland | B. PCR → Sequencing
Single-center(?) | C. Unclear
Yuan, 2004 (303); | A. Sampled with unclear selection process; all fulfill Chinese HNPCC criteria^d^ | 3/14 | 1/3 | 33 (0,91) | C
China | B. ♦PCR → DHPLC → Sequencing of abnormal products
Single-center | C. Predicted non-conservative transcription alteration; literature; comparison with non-cancer controls

Studies are ordered by quality and then by decreasing number of patients fulfilling Amsterdam I criteria. Demographic data (on age and gender distributions) were not available for probands fulfilling Amsterdam I criteria. Primary studies did not describe how many of the MMR mutations were MLH1 or MSH2 for the subset of CRC fulfilling Amsterdam I criteria.

CI: confidence interval; CRC: colorectal cancer; DHPLC: denaturating high performance liquid chromatography; HD: heteroduplex formation; IVSP: in vitro synthesized protein assay; IVTT: in vitro transcription-translation; N_Am1_: number fulfilling Amsterdam I criteria; N_total_: total number of studied CRC; PCR: polymerase chain reaction; PTA: protein truncation assay; RT-PCR: reverse transcriptase PCR; SSCP: Single-stranded conformation polymorphism

Conversion analysis was not used in any study.

♦: Gene screening as been used

Ø: Analysis for large deletions has been used

a Unclear if all probands come from unrelated families.

b This study probed for hPSM1 or hPSM2 mutations in some but not all patients; none was found

c Although the paper states that 20 patients fulfilled Amsterdam 1 criteria, only 14 were described to have had CRC in the pertinent data table. The other had other cancers.

d The Chinese HNPCC criteria ≥2 relatives with histologically proven CRC (≥2 must be first degree relatives) and one of the following: multiple colorectal tumors, one CRC diagnosed at age younger than 50 years, or development of extracolonic HNPCC-related cancer in family members.

Table F-2 Prevalence of MLH1 and MSH2 mutations among colorectal cancer probands who fulfill Amsterdam II criteria

Study, year (Ref ID); | A. Comments on sampling | N_Am2_/N_total_ | MLH1 and MSH2 mutations | | Quality
Country | B. Genetic testing strategy | | Positive/A nalyzed | Proportion [%] (95% CI)
Single-/multi-center | C. Definition of deleterious mutations
De Abajo 2005; | A. Selection among referrals to a specialized center | 67/132 | 36/67 | 54 (41, 66) | B
Spain | B. PCR → DGGE → sequencing (MSH6 assessed in MLH1/MSH2 negative cases)
Single-center | C. Predicted non-conservative transcription alteration; literature; comparison with healthy controls
Katballe, 2002 (1310) & | A. Selection from a population of 1514 incident CRC | 18/45 | 8/18 | 44 (22, 69) | B
Christensen, 2002 (1038); | B. ♦PCR → SSCP & HD → Sequencing of abnormal patterns
Denmark | C. Predicted transcription alteration; literature
Single-center
Wolf, 2005 (23) | A. Retrospective cohort of referral cancer patients fulfilling the modified Bethesda criteria | 35/81 | 13/35 | 37 (21, 55) | B
Austria | B. PCR → Sequencing
Single-center | C. Predicted transcription alteration; literature; comparison with healthy controls
Syngal 2000 (1672) & | A. Selection among referrals to specialized center | 34/70 | 14/34 | 41 (25, 59) | B
Wahlberg, 2002 (1158); | B. PCR → Sequencing
US | C. Predicted transcription alteration; literature
Single-center
Zhu, 2005 (138) | A. Study sample assembled with unclear selection process | 21/78 | 4/21 | 19 (5, 42) | B
China | B. Ø MLPA → Sequencing of detected aberrations
Single-center | C. Unclear
Lee, 2005 (105) | A. Sample selected from referrals to a tertiary center | 5/46 | 3/5 | 60 (15, 95) | B
Singapore | B. PCR → Sequencing
Single-center | C. Predicted transcription alteration; literature
Salovaara, 2000 (1740) | A. Selection of all new unrelated CRC from 9 hospitals between 03/1996 and 06/1998 | 5/535 | 4/5 | 80 (28, 99) | B
Finland | B. PCR → Sequencing Ø PCR for founder mutations in MLH1 gene
Multi-center | C. Literature; comparison with non-cancer controls
Rossi, 2002 (1146) | A. Selected from consecutive CRC referrals | 5/25 | 2/5 | 40 (5, 85) | B
Brazil | B. ♦PCR, → Sequencing
Single-center | C. Unclear
Lamberti, 1999 (2036); | A. Study sample assembled with unclear selection process | 69/160 | 17/69 | 25 (15, 36) | C
Italy | B. ♦PCR → SSCP; and RT-PCR, PTA
Single-center | C. Literature
Stormorken, 2001 (721) | A. First 56 families in the Norwegian Radium hospital registry | 20/56 | 7/20^a^ | 35 (15, 59) | C
Norway | B. Not described (was already done) (MSH6 was assessed also)
Single-center | C. Not described

Studies are ordered by quality and then by decreasing number of patients fulfilling Amsterdam II criteria. Demographic data (on age and gender distributions) were not available for probands fulfilling Amsterdam II criteria. Primary studies did not describe how many of the MMR mutations were MLH1 or MSH2 for the subset of CRC fulfilling Amsterdam II criteria.

Conversion analysis was not used in any study.

♦: Gene screening as been used

Ø: Analysis for large deletions has been used

CI: confidence interval; CRC: colorectal cancer; HD: heteroduplex formation; MLPA: Multiple ligation-dependent probe amplification; NAm2: number fulfilling Amsterdam II criteria; Ntotal: total number of studied CRC; PCR: polymerase chain reaction; PTA: protein truncation assay; RT-PCR: reverse transcriptase PCR; SSCP: Single-stranded conformation polymorphism

a 2/7 mutations shown are MSH6

Table F-3 Prevalence of microsatellite instability among colorectal cancer probands who fulfill Amsterdam I criteria

Study, year (Ref ID); | A. Comments on sampling | N_Am1_/ N_total_ | Tumor microsatellite instability | | | | Micro-dissection | NCI 5 marker set | Quality
Country | B. Definition of MSI-H | | MSI-H/Analyzed | MSI-H [%](95% CI) | MSI-H&L/Analyzed | MSI-H&L [%](95% CI)
Single-/multi-center
Wahlberg, 2002 (1158) & Syngal 2000 (1672); | A. Selection among referrals to specialized center | 28/70 | 15/19 | 79 (54, 94) | 18/19 | 95 (74, 100) | √ | √ | B
US | B. ≥2 out of 5 dinucleotide repeats (NCI set)
Multi-center
Curia, 1999 (1959); | A. Sampled from pathology registries, unclear selection criteria | 15/30 | 12/15 | 80 (52, 96) | ND | ND | √ | X | B
Italy | B. Screened with 3 markers and if none was unstable up to a total of 7. MSI-H defined as ≥2 markers
Single-center
Katballe, 2002 (1310) & Christensen, 2002 (1038); | A. Selected from a population of 1514 incident CRC | 11/45 | 7/10 | 70 (34, 93) | 7/10 | 70 (34, 93) | √ | X | B
Denmark | B. ≥2 out of 5 dinucleotide repeats
Single-center
Dieumegard, 2000 (1791); | A. Sample assembled with unclear selection process | 10/34 | 9/10 | 90 (55, 100) | 9/10 | 90 (55, 100) | X | X | B
France | B. ≥10% of up to 23 markers (But all were ≥30%)
Multi-center
Aaltonen, 1998 (2282); | A. Selection of all new unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | 4/509 | 4/4 | 100 (40, 100) | 4/4 | 100 (40, 100) | X | X | B
Finland | B. ≥30% of 16 markers for tumor analyzed with fluorescence methods or ≥2 out of 7 (≈30%) markers analyzed with radioactive technique
Multi-center
Lamberti, 1999 (2036); | A. Study sample assembled with unclear selection process | 57/160 | 35/49 | 71 (57, 83) | 37/49 | 76 (61, 87) | X | X | C
Italy | B. ≥40% out of up to 10 mono- di- and tetranucleotide repeats
Single-center
de Leon, 1999 (2012); | A. Sample selected from CRC patient registries | 18/36 | 11/18 | 61 (36, 83) | ND | ND | √ | X | C
Italy | B. ≥2 out of ≥5 markers
Single-center
Callistri, 2000 (1797); | A. Study sample assembled with unclear selection process | 13/45 | 11/13 | 85 (55, 98) | 11/13 | 85 (55, 98) | √ | √ | C
Italy | B. ≥2 out of 13 microsatellite markers
Multi-center
Peel, 1999 (1660); | A. Referral HNPCC cases, other than the 1134 CRC probands assessed for other purposes | 11/11 | 4/9 | 44 (14, 79) | 4/9 | 44 (14, 79) | √ | X | C
US | B. Unclear; at least 5 markers were used
Multi-center
Moslein, 1996 (2545); | A. Sample assembled from various databases; we present only cases stated to have CRC^a^ | 14/46^a^ | 5/9 | 56 (21, 86) | ND | ND | X | X | C
US & Germany | B. ≥30% of 9 to 34 markers analyzed (unclear which exactly)
Multi-center
Debniak, 2000 (1784); | A. Sampled from consecutive CRC, selection not transparent | 3/168 | 2/3 | 67 (9, 99) | ND | ND | X | X | C
Poland | B. ≥2 out of 5 dinucleotide repeats (panel I), or ≥3 out of 10 dinucleotide repeats (panel II, used if only 1 positive in panel I)
Single-center(?)

Studies are ordered by overall quality and then by decreasing number of patients fulfilling the Amsterdam I criteria. Demographic data (on age and gender distributions) were not available for probands fulfilling Amsterdam I criteria.

CI: confidence interval; CRC: colorectal cancer; MSI-H/H&L: microsatellite instability high/combined high and low; ND: Not described; N_Am1_: number fulfilling Amsterdam I criteria;

N_total_: total number of studied CRC; NCI: National cancer institute

X: Was not used/not stated

√: Was used

a Although the paper states that 20 patients fulfilled Amsterdam I criteria, only 14 were described to have a CRC in the pertinent data table. The other had other cancers. Only the 14 with CRC are analyzed.

Table F-4 Prevalence of microsatellite instability among colorectal cancer probands who fulfill Amsterdam II criteria

Study, year (Ref ID); | A. Comments on sampling | N_Am2_/ N_total_ | Tumor microsatellite instability | | | | Micro-dissection | NCI 5 marker set | Quality
Country | B. Definition of microsatellite instability | | MSI-H/ Analyzed | MSI-H [%] (95% CI) | MSI-H&L/ Analyzed | MSI-H&L [%](95% CI)
Single-/multi-center
Wolf, 2005 (23) | A. Retrospective cohort of referral cancer patients fulfilling the modified Bethesda criteria | 35/81 | 16/24 | 67 (45, 84) | ND | ND | √ | X | B
Austria | B ≥30% out of up to 10 markers
Single-center
Katballe, 2002 (1310) & Christensen, 2002 (1038); | A. Selected from a population of 1514 incident CRC | 17/45 | 10/16 | 63 (35, 85) | 11/16 | 69 (41, 89) | √ | X | B
Denmark | B. ≥2 out of 5 dinucleotide repeats
Single-center
Salovaara, 2000 (1740) | A. Selection of all new unrelated CRC patients from 9 hospitals between 03/1996 and 06/1998 | 5/535 | 4/5 | 80 (28, 99) | NA | NA | X | X | B
Finland | B. Single marker (BAT26) analyzed in all samples
Multi-center
Lamberti, 1999 (2036); | A. Study sample assembled with unclear selection process | 69/160 | 39/57 | 68 (55, 80) | 41/57 | 72 (58, 83) | X | X | C
Italy | B. ≥40% out of up to 10 mono- di- and tetranucleotide repeats
Single-center

Studies are ordered by quality and then by diminishing number of patients fulfilling the Amsterdam II criteria. Demographic data (on age and gender distributions) were not available for probands fulfilling Amsterdam II criteria.

CI: confidence interval; CRC: colorectal cancer; MSI-H/H&L: microsatellite instability high/combined high and low; NA: Not applicable; ND: Not described; N_Am2_: number fulfilling Amsterdam II criteria; N_total_: total number of studied CRC; NCI: National cancer institute

X: Was not used/not stated

√: Was used

Table F-5 Prevalence of negative immunostaining for MLH1 or MSH2 among colorectal cancer probands who fulfill Amsterdam I criteria

Study, year (Ref ID); | A. Comments on sampling | N_Am1_/N_total_ | MLH1 and MSH2 immunostaining | | Quality
Country | B. Antibodies used for immunostaining | | Negative/Analyzed | Proportion [%] (95% CI)
Single-/multi-center
Curia, 1999 (1959) | A. Sampled from pathology registries, but selection process is not transparent | 15/30 | 7/15 | 47 (21, 73) | B
Italy | B. Anti-MSH2: FE11 (Oncogene Research Products); anti-MLH1: clone 14 (Oncogene Research Products)
Single-center
Wahlberg, 2002 (1158) & Syngal 2000 (1672);^a^ | A. Selection among referrals to specialized center | 28/70 | 5/14 | 36 (13, 65) | B
US | B. Anti-MSH2: FE11 (Oncogene Research Products); anti- MLH1: G168–728 (PharMingen)
Single-center
Katballe, 2002 (1310) & Christensen, 2002 (1038);^b^ | A. Selection from a population of 1514 incident CRC | 11/42 | 4/11 | 36 (11, 69) | B
Denmark | B. Anti-MSH2: Ab-1, Ab-2 (Oncogene Research Products); anti-MLH1: G168-15 (PharMingen)
Single-center
Dieumegard, 2000 (1791) | A. Sample assembled without a transparent selection process | 10/34 | 4/8 | 50 (16, 84) | B
France | B. Anti-MSH2: FE11 (Oncogene Research Products); anti- MLH1: Ab-1 (Oncogene Research Products)
Multi-center
Stormorken, 2001 (721) | A. First 56 families in the Norwegian Radium hospital registry | 12/56 | 3/12 | 25 (5, 57) | C
Norway | B. Anti-MSH2: FE11 (Calbiochem); anti-MLH1: G168-15 (Pharmingen); anti-MSH6: Clone 44 (transduction laboratories)^c^
Single-center
Debniak, 2000 (1784); | A. Sampled from consecutive CRC, but selection process is not transparent | 3/168 | 2/3 | 67 (9, 99) | C
Poland | B. Not stated
Single-center(?)

Studies are ordered by overall quality and then by decreasing number of patients fulfilling Amsterdam I criteria. Demographic data (on age and gender distributions) were not available for probands fulfilling Amsterdam I criteria. None of these studies assessed any other mismatch repair genes apart from MLH1 and MSH2.

CI: confidence interval; CRC: colorectal cancer; N_Am1_: number fulfilling Amsterdam I criteria; N_total_: total number of studied CRC

a Data from the Wahlberg et al. 2002 paper; comments on sampling from the Syngal et al. 2000 paper.

b Data from the Christensen et al. 2002 paper; comments on sampling from the Katballe et al. 2002 paper.

c 2 MSH6 MMR mutations were also picked up by the anti-MSH2 IHC exam.

Table F-6 Ability of Amsterdam I criteria to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands

Study, year (Ref ID); | A. Study sample characteristics | A. Genetic testing | N_Am1/_ N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Am1 (+) | Am1 (-) | Am1 (+) | Am1 (-) | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%) | C. Definition of deleterious mutations
Genetic testing irrespectively of tumor microsatellite instability status
Aaltonen, 1998 (2282) | A. Selection of all new unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | A. Ø All CRC: PCR for founder mutations 1 & 2 in MLH1 ♦ CRC with MSI: (some) PCR → DGGE → Sequencing (Remaining) PCR → Sequencing | 4/509 | 4 | 6 | 0 | 499 | 67 (22, 96) | 100 (99, 100) | B
Finland | B. Yes: patients without MSI were screened only for MLH1 founder mutations | B. 9/1
Multi-center | C. ND, ND | C. Literature; comparison with healthy controls
De Abajo 2005; | A. Selection among referrals to a specialized center | A. PCR → DGGE → sequencing (MSH6 assessed in MLH1/MSH2 negative cases) | 56/132 | 33 | 11 | 23 | 65 | 75 (60, 87) | 74 (63, 83) | B
Spain | B. No | B. 24/17 (and 3 MSH6)
Single-center | C. ND; ND | C. Predicted non-conservative transcription alteration; literature; comparison with healthy controls
Syngal, 2000 (1672) & Wahlberg, 2002 (1158); | A. Selection among referrals to specialized center | A. PCR→sequencing | 28/70 | 11 | 7 | 17 | 35 | 61 (36, 83) | 67 (53, 80) | B
US | B. No | B. 18 (MLH1 and MSH2)
Single-center | C. ND; ND | C. Predicted transcription alteration; literature
Wang, 1999 (1939); | A. Sampled among referrals to a genetic consultation center: Familial CRC with Am1 or up to 2 Am1 criteria missing, or aggregation of HNPCC-related tumors, or sporadic CRC aged <50 y at diagnosis | A. ØRT-PCR→ IVSP; ♦ PCR→HD→sequencing; in vivo MLH1 protein expression | 22/70 | 14 | 12 | 8 | 41 | 50 (31, 69) | 84 (70, 93) | B
France | B. No | B. 19/7
Single-center | C. ND; ND | C. Predicted transcription alteration; literature
Katballe, 2002 (1310) & Christensen, 2002 (1038); | A. Familial CRC selected from a population of 1514 newly diagnosed CRC: patients fulfilling Am2 (in extended families and relaxing the age criterion to <55y) and familial CRC with early age of onset | A. ♦ PCR→SSCP & HD→ Sequencing of abnormal patterns | 11/45 | 5 | 5 | 6 | 25 | 50 (19, 81) | 81 (63, 93) | B
Denmark | B. No | B. 4/6
Single-center | C. ND; ND | C. Predicted transcription alteration; literature
Curia, 1999 (1959) | A. Sampled from pathology registries, unclear selection criteria: HNPCC related cancers^a^ | A. ♦RT-PCR→ SSCP→ Sequencing of abnormal products | 15/30^a^ | 1 | 2 | 16 | 11 | 33 (0, 91) | 41 (22, 61) | B
Italy | B. No | B. 2/1
Single-center | C. <50y, ND | C. Predicted non-conservative transcription alteration; literature; comparison with non-cancer controls
Rossi, 2002 (1146) | A. Selected from consecutive CRC referrals: Am2 or familial CRC (including HNPCC-related cancer in family), or sporadic CRC aged <50y or with multiple tumors | A. PCR→ sequencing | 5/25 | 1 | 9 | 3 | 12 | 10 (0, 45) | 80 (52, 96) | B
Brazil | B. No | B. 4/6
Single-center | C. 46 (all sample); 60 (all sample) | C. Unclear
Luce, 1995 (2703); | A. Selection among referrals to specialized center, familial CRC: In 1^st^ degree family ≥2 CRC or endometrial cancer; or ≥1 CRC aged <50y at diagnosis ^b^ | A. ♦RT-PCR→ IVTT → sequencing of abnormal peptides; PCR → IVTT → sequencing of abnormal peptides | 12/19^b^ | 6 | 0 | 6 | 7 | 100 (54, 100) | 54 (25, 81) | B
US | B. No | B. 4/2
Single-center | C. ND; ND | C. Unclear
Colombino, 2005 (181); | A. Consecutive CRC cases enrolled over 3 years in a tertiary center ^b^ | A. ♦PCR→ DHPLC→ Sequencing of abnormal patterns | 13/362^b^ | 10 | 11 | 3 | 338 | 48 (26, 70) | 99 (97, 100) | C
Italy | B. Yes: Patients without family history of cancer were screened only for the mutations identified in the familial cases | B. 11/10
Single-center | C. 62; 49 | C. Compared to 103 people without cancer
Park, 1999 (2007); | A. Study sample assembled from the ICG-HNPCC database of families: Am1; and familial CRC not fulfilling the Am1 criteria | D. ♦ PCR → SSCP; and Ø Southern blotting (no details) | 154/277 | 77^c^ | 24^c^ | 77 | 99 | 76 (67, 84) | 56 (49, 64) | C
7 countries | B. No | E. 101 (MLH1 and hMLH2)
Multi-center (8 centers) | C. ND; ND | F. Unclear
Lamberti, 1999 (2036); | A. Study sample assembled with unclear selection process; includes Am1, Am2, other familial CRC and CRC <50y at diagnosis or multiple tumors^d^ | A. ♦ PCR → SSCP, and RT-PCR → PTA | 69/160^d^ | 15 | 2 | 42 | 10 | 88 (64, 99) | 19 (10, 33) | C
Italy | B. No | B. 11/6
Single-center | C. 44 for Am1, 37 for Am2; ND | C. Literature
de Leon, 1999 (2012) | A. Selected from CRC patient registries: Am1 or familial CRC (2 generations with CRC or HNPCC-tumor, ≥1 CRC aged <50y at diagnosis and ≥50% of siblings with CRC) | A. ♦PCR→SSCP→ Sequencing of aberrant products | 18/36 | 3 | 0 | 15 | 18 | 100 (29, 100) | 55 (36, 72) | C
Italy | B. No | B. 1/2
Single-center | C. ND, ND | C. Unclear
Liu, 2004 (445); | A. Study sample assembled with unclear selection process; all fulfill the Japanese HNPCC criteria^e^ | A. ♦PCR→DHPLC→Sequencing of abnormal products | 15/28 | 5 | 2 | 10 | 11 | 71 (29, 96) | 52 (30, 74) | C
China | B. No | B. 5/7
Single center | C. 46; 55 | C. Unclear
Moslein 1996 (2545) | A. Sample assembled from various databases; includes familial and sporadic cases^f^ | A. PCR→sequencing | 14/46^f^ | 6 | 6 | 8 | 17 | 50 (21, 79) | 68 (46, 85) | C
US & Germany | B. No | B. 7/6
Multi-center | C. 51, ND | C. Predicted non-conservative transcription alteration; literature
Callistri, 2000 (1797); | A. Study sample assembled with unclear selection process: Familial CRC fulfilling Am1 criteria or missing up to 2/3 Am1 criteria, or a CRC among 1^st^ degree family or CRC diagnosis at age <50y, or multiple tumors in the same patient | A. ♦PCR→ SSCP | 13/40^g^ | 7 | 1 | 6 | 5 | 88 (47, 100) | 45 (17, 77) | C
Italy | B. No | B. 4/4
Multi-center | C. ND; 56 (all sample) | C. Unclear
Yuan, 2004 (303) | A. Sampled with unclear selection process; all fulfill Chinese HNPCC criteria^h^ | A. ♦PCR→DHPLC→ Sequencing of abnormal products Ø Multiplex PCR for large deletions | 3/14 | 2 | 1 | 1 | 10 | 67 (9, 99) | 91 (59, 100) | C
China | B. No | B. 2/1
Single-center | C. ND, ND | C. Predicted non-conservative transcription alteration; literature; comparison with non-cancer controls
Genetic testing only among patients with suggestive MSI or ICH.
Casey, 2005 | A. Referrals to the Colon Cancer Family Registry | A. CRC with MSI/IHC: PCR → Sequencing; (also for MSH6) Conversion analysis | 63/89 | Practically among patients with IHC or MSI | | | | | | B
US | B. Yes: 85/89 were pre-selected based on suggestive MSI or IHC | B. 42 in total (1 had an MSH6 mutation) | | 49 | 14 | 15 | 10 | 78 (66, 87) | 40 (21, 61)
Multi-center | C. Aprox 50; ND | C. Predicted non-conservative transcription alteration; literature; mRNA expression for missence mutations and additional data for splice site mutations
Raedle, 2001 (1363) | A. Consecutive referrals to a tertiary center. | A. CRC with MSI: PCR→ Sequencing | 12/125 | Among patients with MSI-H tumors: | | | | | | B
Germany | B. Yes: patients without MSI were not tested for mutation | B. 8/4 (1 had mutation in both genes) | | 6 | 5 | 0 | 11 | 55 (23, 83) | 100 (72, 100)
Multi-center | C. 52, 55 | C. Predicted transcript alteration; literature
Nakahara, 1997 (2354) | A. Sample assembled from hospital registries^b^ | A. CRC with MSI: ♦PCR→ SSCP → Sequencing of abnormal patterns | ≥5/32^b^ | Among patients with MSI-H tumors: | | | | | | C
Japan | B. Yes: patients without MSI were not tested for mutations | B. 5/6 (4 CRC had mutations in both genes) | | 4 | 3 | 1 | 3 | 57 (18, 90) | 75 (19, 99)
Single-center | C. 59, 41 | C. Unclear

Studies are ordered by quality and then by decreasing number of patients available for the calculation of sensitivity and specificity (2 by 2 tables).

Am1/2: Amsterdam I criteria/II; CRC: colorectal cancer; DGGE: Denaturing gradient gel electrophoresis; DHPLC: denaturating high performance liquid chromatography; HD: heteroduplex formation; IVSP: in vitro synthesized protein assay; IVTT: in vitro transcription-translation; MSI(-H): microsatellite instability (high); ND: Not described; N_Am1_:Number fulfilling Amsterdam I criteria; N_total_: total number of studied CRC; PCR: polymerase chain reaction; PTA: protein truncation assay; RT-PCR: reverse transcriptase PCR; SSCP: Single-stranded conformation polymorphism

♦: Gene screening method

Ø: Detection of large genomic deletions

a 4 were not CRC and are excluded from the calculations

b Not strictly clear if all CRC probands come from unrelated families.

c 0/27 and 0/24 had PMS1 or PMS2 mutations; Not all patients were tested for these other MMR genes.

d 69/160 included cases fulfilled Amsterdam II criteria and these are analyzed here. The remaining cases were 45 CRC aged <50 y at diagnosis and relatives with HNPCC related cancers and 46 CRC aged <50 y at diagnosis or CRC with multiple tumors (no age cutoff). However, these received genetic testing inconsistently and are not included in this analysis

st The Japanese HNPCC criteria: ≥3 CRC among 1 degree family; or ≥2 CRC among 1 degree family and one of the following: aged <50y at diagnosis, right colon involvement, synchronous or metachronous multiple CRC, or extracolonic malignancy.

f Interestingly, despite the fact that the study included 46 cancer patients (characterized as CRC), in an analytic description not all were described with CRC. Only cases that were described with CRC were included in this analysis.

g Data from 19 (out of the 45 total studied patients) CRC who missed at most 2 out of 3 Amsterdam criteria (and had available information) are analyzed here, because MMR gene mutations were tested inconsistently among other patient subgroups.

h The Chinese HNPCC criteria: 2 or more relatives with histologically proven CRC (at least 2 first degree relatives) and one of the following: multiple colorectal tumors, one CRC diagnosed at age younger than 50y, or development of extracolonic HNPCC-related cancer in family members.

Table F-7 Ability of Amsterdam I criteria to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands

Study, year (Ref ID); | A. Study sample characteristics | A. Genetic testing | N_Am1_/N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Am1 (+) | Am1 (-) | Am1 (+) | Am1 (-) | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%) | C. Definition of deleterious mutations
Aaltonen, 1998 (2282) | A. Selection of all new unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | A. Ø All CRC: PCR for founder mutations 1 & 2 in MLH1 ♦ CRC with MSI: (some) PCR→ DGGE → Sequencing (Remaining) PCR→ Sequencing | 4/509 | 4 | 6 | 0 | 499 | 67 (22, 96) | 100 (99, 100) | B
Finland | B. Yes: patients without MSI were screened only for MLH1 founder mutations | B. 9/1
Multi-center | C. ND, ND | C. Literature; comparison with healthy controls
Colombino, 2005 (1058); | A. Consecutive CRC cases enrolled over 3 years in a tertiary center^a^ | A. ♦ PCR→ DHPLC→ Sequencing of abnormal patterns | 13/362^a^ | 10 | 11 | 3 | 338 | 48 (26, 70) | 99 (97, 100) | C
Italy | B. Yes: Patients without family history of cancer were screened only for the mutations identified in the familial cases | B. 11/10
Single-center | C. 62; 49 | C. Compared to 103 people without cancer

Studies are ordered by quality. None of the studies in this table assessed genes other than MLH1 and hMLH2. None of the studies used conversion analysis among their genetic testing strategies.

Am1/2: Amsterdam I criteria/II; CRC: colorectal cancer; DGGE: Denaturing gradient gel electrophoresis; DHPLC: denaturating high performance liquid chromatography; ND: Not described; N_Am1_:Number fulfilling Amsterdam I criteria; N_total_: total number of studied CRC; PCR: polymerase chain reaction

♦: Gene screening method

Ø: Detection of large genomic deletions

a Not clear if all CRC probands come from unrelated families.

Table F-8 Ability of Amsterdam I criteria to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands fulfilling the Bethesda guidelines

Study, year (Ref ID); | A. Study sample characteristics | A. Genetic testing | N_Am1_/N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Am1 (+) | Am1 (-) | Am1 (+) | Am1 (-) | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%) | C. Definition of deleterious mutations
De Abajo 2005; | A. Selection among referrals to a specialized center | A. PCR → DGGE → sequencing (MSH6 assessed in MLH1/MSH2 negative cases) | 56/132 | 33 | 11 | 23 | 37 | 75 (60, 87) | 62 (48, 74) | B
Spain | B. No | B. 24/17 (and 3 MSH6)
Single-center | C. ND; ND | C. Predicted non-conservative transcription alteration; literature; comparison with healthy controls
Syngal, 2000 (1672) & Wahlberg, 2002 (1158); | A. Selection among referrals to specialized center | A. PCR→sequencing | 56/70 | 11 | 6 | 17 | 22 | 65 (38, 86) | 56 (40, 72) | B
US | B. No | B. 18 (MLH1 and MSH2)
Single-center | C. ND; ND | C. Predicted transcription alteration; literature

The tabulated study did not assess genes other than MLH1 and MSH2. Genetic testing did not include gene screening, analysis for large genomic deletions or conversion analysis.

Am1: Amsterdam I criteria; ND: Not described; N_Am1_:Number fulfilling Amsterdam I criteria; N_total_: total number of studied CRC; PCR: polymerase chain reaction

Table F-9 Ability of Amsterdam I criteria to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands fulfilling Amsterdam II criteria

Study, year (Ref ID); | A. Study sample characteristics | A. Genetic testing | N_Am1_/N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Am1 (+) | Am1 (-) | Am1 (+) | Am1 (-) | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%) | C. Definition of deleterious mutations
De Abajo 2005; | A. Selection among referrals to a specialized center | A. PCR → DGGE → sequencing (MSH6 assessed in MLH1/MSH2 negative cases) | 56/132 | 33 | 6 | 23 | 5 | 85 (69, 94) | 18 (6, 37) | B
Spain | B. No | B. 24/17 (and 3 MSH6)
Single-center | C. ND; ND | C. Predicted non-conservative transcription alteration; literature; comparison with healthy controls
Syngal, 2000 (1672) & Wahlberg, 2002 (1158); | A. Selection among referrals to specialized center | A. PCR→sequencing | 34/70 | 11 | 3 | 17 | 3 | 79 (49, 95) | 15 (3, 38) | B
US | B. No | B. 18 (MLH1 and MSH2)
Single-center | C. ND; ND | C. Predicted transcription alteration; literature
Katballe, 2002 (1310) & Christensen, 2002 (1038); | A. Familial CRC selected from a population of 1514 newly diagnosed CRC: patients fulfilling Am2 (in extended families and relaxing the age criterion to <55y) and familial CRC with early age of onset | A. ♦ PCR→SSCP & HD→ Sequencing of abnormal patterns | 23/45 | 5 | 3 | 6 | 9 | 63 (25, 92) | 60 (32, 84) | B
Denmark | B. No | B. 4/6
Single-center | C. ND; ND | C. Predicted transcription alteration; literature
Rossi, 2002 (1146) | A. Selected from consecutive CRC referrals: Am2 or familial CRC(including HNPCC-relatedcancer in family), or sporadic CRC aged <50y or with multipletumors | A. PCR→ sequencing | 5/25 | 1 | 1 | 3 | 0 | 50 (1, 99) | 0 (0, 71) | B
Brazil | B. No | B. 4/6
Single-center | C. ND; ND | C. Unclear
Lamberti, 1999 (2036); | A. Study sample assembled with unclear selection process; includes Am1, Am2, other familial CRC and CRC <50y at diagnosis or multiple tumors^a^ | A. ♦ PCR → SSCP, and RT-PCR → PTA | 69/ 160^a^ | 15 | 2 | 42 | 10 | 88 (64, 99) | 19 (10, 33) | C
Italy | B. No | B. 11/6
Single-center | C. 44 for Am1, 37 for Am2; ND | C. Literature

Studies are ordered by quality and then by decreasing number of patients available for the calculation of sensitivity and specificity (2 by 2 tables). None of the studies used deletion analysis to detect large genomic deletions or conversion analysis to detect mismatch repair gene mutations. Most studies did not provide data on demographics (age and gender distribution) for the subgroup of patients fulfilling the Amsterdam II criteria.

Am1/2: Amsterdam I criteria/II; CRC: colorectal cancer; HD: heteroduplex formation; ND: Not described; N_Am1_:Number fulfilling Amsterdam I criteria; N_total_: total number of studied CRC; PCR: polymerase chain reaction; PTA: protein truncation assay; RT-PCR: reverse transcriptase PCR; SSCP: Single-stranded conformation polymorphism

♦: Gene screening method

a 69/160 included cases fulfilled Amsterdam II criteria and these are analyzed here. The remaining cases were 45 CRC aged <50 y at diagnosis and relatives with HNPCC related cancers and 46 CRC aged <50 y at diagnosis or CRC with multiple tumors (no age cutoff). However, these received genetic testing inconsistently and are not included in this analysis

Table F-10 Ability of Amsterdam II criteria to identify MLH1 and MSH2 mutation carriers among selected colorectal cancer probands

Study, year (Ref ID); | A. Study sample characteristics | A. Genetic testing | N_Am2_/N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Am2 (+) | Am2 (-) | Am2 (+) | Am2 (-) | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%) | C. Definition of deleterious mutations
Genetic testing irrespectively of MSI or IHC test results
Salovaara, 2000 (1740) | A. Selection of all new unrelated CRC from 9 hospitals between 03/1996 and 06/1998 | A. PCR → Sequencing Ø PCR for founder mutations in MLH1 gene | 5/535 | 4 | 14 | 1 | 516 | 22 (6, 48) | 100 (99, 100) | B
Finland | B. Yes: patients without MSI were screened only for MLH1 founder mutations | B. 17/1
Multi-center | C. 67, ND | C. Literature; comparison with non-cancer controls
De Abajo 2005; | A. Selection among referrals to a specialized center | A. PCR → DGGE → sequencing (MSH6 assessed in MLH1/MSH2 negative cases) | 67/132 | 39 | 5 | 28 | 60 | 89 (75, 96) | 68 (57, 78) | B
Spain | B. No | B. 24/17 (and 3 MSH6)
Single-center | C. ND; ND | C. Predicted non-conservative transcription alteration; literature; comparison with healthy controls
Wolf, 2005 (123) | A. Retrospective cohort of cancer patients fulfilling the modified Bethesda criteria | A. PCR → Sequencing | 35/81 | 13 | 6 | 22 | 40 | 68 (43, 87) | 65 (51, 76) | B
Austria | B. No | B. 12/7
Single-center | C. ND, 48 | C. Predicted transcription alteration; literature; comparison with healthy controls
Zhu, 2005 (138) | A. Study sample assembled with unclear selection process: Familial CRC and sporadic CRC | A. Ø MLPA → Sequencing of detected aberrations | 21/78 | 4 | 5 | 17 | 52 | 44 (14, 79) | 75 (64, 85) | B
China | B. No | B. 4/5
Single-center | C. ND, ND | C. Unclear
Syngal, 2000 (1672) & Wahlberg, 2002 (1158); | A. Selection among referrals to specialized center | A. PCR → Sequencing | 34/70 | 14 | 4 | 20 | 32 | 78 (52, 74) | 64, (49, 77) | B
US | B. No | B. 18 (MLH1 and MSH2)
Single-center | C. ND; ND | C. Predicted transcription alteration; literature
Katballe, 2002 (1310) & Christensen, 2002 (1038); | A. Familial CRC selected from a population of 1514 newly diagnosed CRC: patients fulfilling Amsterdam II criteria (in extended families and relaxing the age criterion to <55y) and familial CRC with early age of onset | A. ♦PCR → SSCP & HD → Sequencing of abnormal patterns | 18/45 | 8 | 2 | 10 | 21 | 80 (44, 97) | 68 (49, 83) | B
Denmark | B. No | B. 4/6
Single-center | C. ND; ND | C. Predicted transcription alteration; literature
Rossi, 2002 (1146); | A. Selected from consecutive CRC referrals: Am2 or familial CRC (including HNPCC-related cancer in family), or sporadic CRC aged <50y or with multiple tumors | A. PCR → Sequencing | 5/25 | 2 | 8 | 3 | 12 | 20 (3, 56) | 80 (52, 96) | B
Brazil | B. No | B. 4/6
Single-center | C. 46; 60 | C. Unclear
Lee, 2005 (105); | A. Selection among referrals to tertiary center: Amsterdam criteria, familial disease, onset <40y or multiple tumors | A. PCR → Sequencing | 5/46^a^ | 3 | 4 | 2 | 37 | 43 (10, 82) | 95 (83, 99) | C
Singapore | B. No | B. 6/1
Single-center | C. 39 (median), 65 | C. Predicted transcript alteration; literature
Genetic testing only in patients selected after MSI and/or ICH
Pinol, 2005 (52) | A. Selection of newly diagnosed CRC from 25 centers. | A. CRC selected by MSI/IHC: PCR → Sequencing Ø also MLPA | 22/1222 | Assuming no mutations in the absence of MSI-H tumors or tumors with negative immunostaining: | | | | | | B
Spain | B. Yes: patients without MSI or with negative immunostaining were not sequenced | B. 4/7 | | 4 | 7 | 18 | 1197 | 36 (11, 69) | 99 (98, 99)
Multi-center | C. 70, 60 | C. Predicted transcript alteration; literature and databases
Raedle, 2001 (1363); | A. Consecutive referrals to a tertiary center. | A. CRC with MSI: PCR→ Sequencing | 20/125 | Among patients with MSI-H tumors: | | | | | | B
Germany | B. Yes: patients without MSI were not tested for mutations | B. 8/4 (1 had mutation in both genes) | | 8 | 3 | 2 | 9 | 73 (39, 94) | 82 (48, 98)
Multi-center | C. 52, 55 | C. Predicted transcript alteration; literature
Terdiman, 2001 | A. Retrospective cohort of patients who had ≥2 CRC in 1^st^ degree family, or age <50 years at CRC diagnosis or multiple tumors in the same patient | A. CRC with MSI: ♦PCR→ DGGE → Sequencing of abnormal products | 19/114 | Among patients with MSI-H tumors: | | | | | | B
US | B. Yes: Only patients with MSI-H were tested for mutations | B. 11/10 | | 15 | 6 | 4 | 7 | 71 (47, 89) | 64 (31, 89)
Single-center | C. ND, ND | C. Unclear
Pistorius, 2000 (1590); | A. Selection among referrals to tertiary center: Bethesda guidelines met | A. CRC with MSI: PCR → Sequencing | 19/72 | Among patients with MSI-H tumors: | | | | | | B
Germany & Czech Republic | B. Yes: patients without MSI were not genetically tested | B. 6/8 (1 MSH6 mutation also found) | | 12 | 3 | 5 | 18 | 80 (52, 96) | 78 (56, 93)
Multi-center | C. ND, ND | C. Predicted transcript alteration; literature

Only Pistorious et al. assessed genes other than MLH1 and MSH2, namely the MSH6 gene.

Am2: Amsterdam II criteria; CRC: colorectal cancer; DGGE: Denaturating gradient gel electrophoresis; HD: heteroduplex formation; MLPA: Multiple ligation-dependent probe amplification; MSI(-H): microsatellite instability (high); ND: Not described; N_Am2_:Number fulfilling Amsterdam II criteria; N_total_: total number of studied CRC; PCR: polymerase chain reaction; SSCP: Single-stranded conformation polymorphism

Conversion analysis was not used in any study.

♦: Gene screening has been used

Ø: Analysis for large deletions has been used

a Contains two malignant tumors that are not CRC, which could not be separated (>95% are CRC)

Table F-11 Ability of Amsterdam II criteria to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands

Study, year (Ref ID); | A. Study sample characteristics | A. Genetic testing | N_Am2_/N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Am2 (+) | Am2 (-) | Am2 (+) | Am2 (-) | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%) | C. Definition of deleterious mutations
Genetic testing irrespectively of MSI or IHC test results
Salovaara, 2000 (1740) | A. Selection of all new unrelated CRC from 9 hospitals between 03/1996 and 06/1998 | A. PCR → Sequencing Ø PCR for founder mutations in MLH1 gene | 5/535 | 4 | 14 | 1 | 516 | 22 (6, 48) | 100 (99, 100) | B
Finland | B. Yes: patients without MSI were screened only for MLH1 founder mutations | B. 17/1
Multi-center | C. 67, ND | C. Literature; comparison with non-cancer controls
Genetic testing only in patients selected after MSI and/or ICH
Pinol, 2005 (52) | A. Selection of newly diagnosed CRC from 25 centers. | A. CRC selected by MSI/IHC: PCR → Sequencing Ø also MLPA | 22/1222 | Assuming no mutations in the absence of MSI-H tumors or tumors with negative immunostaining: | | | | | | B
Spain | B. Yes: patients without MSI or with negative immunostaining were not sequenced | B. 4/7 | | 4 | 7 | 18 | 1197 | 36 (11, 69) | 99 (98, 99)
Multi-center | C. 70, 60 | C. Predicted transcript alteration; literature and databases

As mentioned in the methods, especially for unselected CRC populations we accepted that patients with MSI negative tumors would be negative for mutations.

Am2: Amsterdam II criteria; CRC: colorectal cancer; MLPA: Multiple ligation-dependent probe amplification; MSI(-H): microsatellite instability (high); ND: Not described;

N_Am2_:Number fulfilling Amsterdam II criteria; N_total_: total number of studied CRC; PCR: polymerase chain reaction

Conversion analysis or gene screening were not used in these two studies.

Ø: Analysis for large deletions has been used

Table F-12 Ability of Amsterdam II criteria to identify MLH1 and MSH2 mutation carriers among selected colorectal cancer probands fulfilling the Revised Bethesda criteria

Study, year (Ref ID); | A. Study sample characteristics | A. Genetic testing | N_Am2_/N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Am2 (+) | Am2 (-) | Am2 (+) | Am2 (-) | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%) | C. Definition of deleterious mutations
Wolf, 2005 (123) | A. Retrospective cohort of cancer patients fulfilling the modified Bethesda criteria | A. PCR → Sequencing | 35/81 | 13 | 6 | 22 | 40 | 68 (43, 87) | 65 (51, 76) | B
Austria | B. No | B. 12/7
Single-center | C. ND, 48 | C. Predicted transcription alteration; literature; comparison with healthy controls

Am2: Amsterdam II criteria; CRC: colorectal cancer; ND: Not described; N_Am2_:Number fulfilling Amsterdam II criteria; N_total_: total number of studied CRC; PCR: polymerase chain reaction

Conversion analysis, gene screening or deletion analysis methods were not used.

Table F-13 Ability of Amsterdam II criteria to identify MLH1 and MSH2 mutation carriers among selected colorectal cancer probands fulfilling the Bethesda guidelines

Study, year (Ref ID); | A. Study sample characteristics | A. Genetic testing | N_Am2_/N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Am2 (+) | Am2 (-) | Am2 (+) | Am2 (-) | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%) | C. Definition of deleterious mutations
Genetic testing irrespectively of MSI test results
De Abajo 2005; | A. Selection among referrals to a specialized center | A. PCR → DGGE → sequencing (MSH6 assessed in MLH1/MSH2 negative cases) | 67/132 | 39 | 5 | 28 | 37 | 89 (75, 96) | 57 (44, 69) | B
Spain | B. No | B. 24/17 (and 3 MSH6)
Single-center | C. ND; ND | C. Predicted non-conservative transcription alteration; literature; comparison with healthy controls
Syngal, 2000 (1672) & Wahlberg, 2002 (1158); | A. Selection among referrals to specialized center | A. PCR → Sequencing | 34/70 | 14 | 4 | 20 | 32 | 78 (52, 74) | 64, (49, 77) | B
US | B. No | B. 18 (MLH1 and MSH2)
Single-center | C. ND; ND | C. Predicted transcription alteration; literature
Genetic testing only in patients selected after MSI
Pistorius, 2000 (1590); | A. Selection among referrals to tertiary center: Bethesda guidelines met | A. CRC with MSI: PCR → Sequencing | 19/72 | Among patients with MSI-H tumors: | | | | | | B
Germany & Czech Republic | B. Yes: patients without MSI were not genetically tested | B. 6/8 (1 MSH6 mutation also found) | | 12 | 3 | 5 | 18 | 80 (52, 96) | 78 (56, 93)
Multi-center | C. ND, ND | C. Predicted transcript alteration; literature

Only Pistorious et al. assessed genes other than MLH1 and MSH2, namely the MSH6 gene

Am2: Amsterdam II criteria; CRC: colorectal cancer; MSI(-H): microsatellite instability (high); ND: Not described; N_Am2_:Number fulfilling Amsterdam II criteria; N_total_: total number of studied CRC; PCR: polymerase chain reaction

Conversion analysis, deletion analysis or gene screening were not used in these two studies.

Table F-14 Ability of modified Amsterdam criteria to identify MLH1 and MSH2 mutation carriers among selected colorectal cancer probands

Study, year (Ref ID); | A. Comments on sample characteristics | A. Genetic testing | N_AmMod_/N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Am Mod (+) | Am Mod (-) | Am Mod (+) | Am Mod (-) | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%) | C. Definition of of deleterious mutations
Wolf, 2005 (123) | A. Selection from a retrospective cohort of cancer patients fulfilling the modified Bethesda criteria ^a^ | A. PCR→ A Sequencing | 52/81 | 16 | 3 | 36 | 26 | 82 (60, 97) | 42 (30, 55) | B
Austria | B. No | B. 12/7
Single-center | C. ND, 48 | D. Predicted transcription alteration; literature; comparison with healthy controls
Syngal, 2000 (1672) & Wahlberg, 2002 (1158); | A. Selection among referrals to specialized center | A. PCR → Sequencing | 39/70 | 13 | 5 | 26 | 26 | 72 (47, 90) | 50 (36, 64) | B
US | B. No | B. 18 (MLH1 and MSH2)
Single-center | C. ND; ND | C. Predicted transcription alteration; literature

AmMod: modified Amsterdam criteria; CRC: colorectal cancer; ND: Not described; N_AmMod_:Number fulfilling Amsterdam criteria; N_total_: total number of studied CRC; PCR: Polymerase chain reaction.

None of the studies used deletion analysis, conversion analysis or gene screening methods to detect mutations. No other genes apart from MLH1 and MSH2 were assessed.

a May include some patients without CRC.

Table F-15 Ability of Bethesda guidelines to identify MLH1 and MSH2 mutation carriers

Study, year (Ref ID); | A. Comments on sampling characteristics | A. Genetic testing | N_Beth_/N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Beth (+) | Beth (-) | Beth (+) | Beth (-) | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%) | C. Definition of deleterious mutations
Genetic Testing irrespectively of MSI/IHC results
De Abajo 2005; | A. Selection among referrals to a specialized center | A. PCR → DGGE → sequencing (MSH6 assessed in MLH1/MSH2 negative cases) | 67/132 | 44 | 0 | 60 | 28 | 100 (92, 100) | 32 (22, 43) | B
Spain | B. No | B. 24/17 (and 3 MSH6)
Single-center | C. ND; ND | C. Predicted non-conservative transcription alteration; literature; comparison with healthy controls
Wolf, 2005 (123) | A. Retrospective cohort of cancer patients fulfilling the modified Bethesda criteria | A. PCR → Sequencing | 72/81 | 19 | 0 | 53 | 9 | 100 (82, 100) | 15 (7, 26) | B
Austria | B. No | B. 12/7
Single-center | C. ND, 48 | C. Predicted transcription alteration; literature; comparison with healthy controls
Syngal, 2000 (1672) & Wahlberg, 2002 1158); | A. Selection among referrals to specialized center | A. PCR → Sequencing | 56/70 | 17 | 1 | 39 | 13 | 94 (73, 100) | 25 (14, 39) | B
US | B. No | B. 18 (MLH1 and MSH2)
Single-center | C. ND; ND | C. Predicted transcription alteration; literature
Genetic testing only in patients selected after MSI and/or ICH
Pinol, 2005 (52) | A. Selection of newly diagnosed CRC from 25 centers. | A. CRC selected by MSI/IHC: PCR → Sequencing Ø also MLPA | 224/1222 | Assuming no mutations in the absence of MSI-H tumors or tumors with negative immunostaining: | | | | | | B
Spain | B. Yes: patients without MSI or with negative immunostaining were not sequenced | B. 4/7 | | 8 | 3 | 216 | 995 | 73 (39, 94) | 82 (80, 84)
Multi-center | C. 70, 60 | C. Predicted transcript alteration; literature and databases
Raedle, 2001 (1363) | A. Consecutive referrals to a tertiary center. | A. CRC with MSI: PCR →Sequencing | 58/125 | Among patients with MSI-H tumors: | | | | | | B
Germany | B. Yes: patients without MSI were not tested for mutations | B. 8/4 (1 had mutation in both genes) | | 11 | 0 | 6 | 5 | 100 (72, 100) | 45 (17, 77)
Multi-center | C. 52, 55 | C. Predicted transcript alteration; literature

Beth: Bethesda guidelines; CRC: colorectal cancer; IHC: immunohistochemistry; MLPA: Multiple ligation-dependent probe amplification; MSI: microsatellite instability; ND: Not described; N_total_: total number of studied CRC; PCR: Polymerase chain reaction

Ø: Deletion analysis (detection of large genomic deletions) was used

No study used gene screening methods or conversion analysis. All studies assessed only MLH1 and MSH2 genes.

Table F-16 Ability of Bethesda guidelines to identify MLH1 and MSH2 mutation carriers among unselected patients with colorectal cancer

Study, year (Ref ID); | A. Comments on sampling characteristics | A. Genetic testing | N_Beth_/ N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Beth (+) | Beth (-) | Beth (+) | Beth (-) | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%) | C. Definition of deleterious mutations
Pinol, 2005 (52) | A. Selection of newly diagnosed CRC from 25 centers. | A. CRC selected by MSI/IHC: PCR → Sequencing Ø also MLPA | 224/1222 | Assuming no mutations in the absence of MSI-H tumors or tumors with negative immunostaining: | | | | | | B
Spain | B. Yes: patients without MSI or with negative immunostaining were not sequenced | B. 4/7 | | 8 | 3 | 216 | 995 | 73 (39, 94) | 82 (80, 84)
Multi-center | C. 70, 60 | C. Predicted transcript alteration; literature and databases

Beth: Bethesda guidelines; CRC: colorectal cancer; IHC: immunohistochemistry; MLPA: Multiple ligation-dependent probe amplification; MSI: microsatellite instability; ND: Not described; N_total_: total number of studied CRC; PCR: Polymerase chain reaction

Ø: Deletion analysis (detection of large genomic deletions) was used

Pinol et al. did not use gene screening methods or conversion analysis. They assessed only the MLH1 and MSH2 genes.

Table F-17 Ability of revised Bethesda guidelines to identify MLH1 and MSH2 mutation carriers among unselected patients with colorectal cancer

Study, year (Ref ID); | A. Comments on sampling characteristics | A. Genetic testing | N_Beth_/N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | B. MLH1/MSH2 | | Beth Rev (+) | Beth Rev (-) | Beth Rev (+) | Beth Rev (-) | Sensitivity [%] | Specificity [%]
Single /multi-center | C. Mean age (y); Males (%) | C. Definition of deleterious mutations
Pinol, 2005 (52) | A. Selection of newly diagnosed CRC from 25 centers. | A. CRC selected by MSI/IHC: PCR → Sequencing Ø also MLPA | 287/1222 | Assuming no mutations in the absence of MSI-H tumors or tumors with negative immunostaining: | | | | | | B
Spain | B. Yes: patients without MSI or with negative immunostaining were not sequenced | B. 4/7 | | 10 | 1 | 277 | 934 | 91 (59, 100) | 77 (75, 79)
Multi-center | C. 70, 60 | C. Predicted transcript alteration; literature and databases

Beth Rev: Revised Bethesda guidelines; CRC: colorectal cancer; IHC: immunohistochemistry; MLPA: Multiple ligation-dependent probe amplification; MSI: microsatellite instability; ND: Not described; N_total_: total number of studied CRC; PCR: Polymerase chain reaction

Ø: Deletion analysis (detection of large genomic deletions) was used

Pinol et al. did not use gene screening methods or conversion analysis. They assessed only the MLH1 and MSH2 genes.

Table F-18 Ability of Ability of young age at diagnosis (early disease onset) to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands

Study, year (Ref ID); | A. Definition of early onset | A. Genetic testing | N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Study sample characteristics | B. MLH1/MSH2 | | Early onset | No early onset | Early onset | No early onset | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Verification bias | C. Definition of deleterious mutations
| D. Mean age (y); Males (%)
Genetic testing irrespectively of tumor microsatellite instability status
Salovaara, 2000 (1740) | A. <50 y | A. PCR → Sequencing Ø PCR for founder mutations in MLH1 gene | 535 | 5 | 13 | 40 | 477 | 28 (10, 53) | 92 (90, 94) | B
Finland | B. Selection of all new unrelated CRC from 9 hospitals between 03/1996 and 06/1998 | B. 17/1
Multi-center | C. Yes: patients without MSI were screened only for MLH1 founder mutations | C. Literature; comparison with non-cancer controls
| D. 67, ND
Aaltonen, 1998 (2282) | A. <50 y | A. Ø All CRC: PCR for founder mutations 1 & 2 in MLH1 ♦ CRC with MSI: (some) PCR → DGGE → Sequencing(Remaining) PCR → Sequencing | 509 | 4 | 6 | 12 | 487 | 67 (22, 96) | 98 (96, 99) | B
Finland | B. Selection of all new unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | B. 9/1
Multi-center | C. Yes: patients without MSI were screened only for MLH1 founder mutations | C. Literature; comparison with healthy controls
| D. ND, ND
Colombino, 2005 (1058); | A. <45 y | A. ♦ PCR→ DHPLC→ Sequencing of abnormal patterns | 362^a^ | 6 | 10 | 5 | 82 | 38 (15, 65) | 94 (87, 98) | C
Italy | B. Consecutive CRC cases enrolled over 3 years in a tertiary center^b^ | B. 11/10
Single-center | C. Yes: Patients without family history of cancer were screened only for the mutations identified in the familial cases | C. Compared to 103 people without cancer
| D. 62; 49
Genetic testing only in patients selected after MSI and/or ICH
Pinol, 2005 (52) | A. <50 y | A. CRC selected by MSI/IHC: PCR → Sequencing also MLPA Ø also MLPA | 1222 | Assuming no mutations in the absence of MSI-H tumors or tumors with negative immunostaining: | | | | | | B
Spain | B. Selection of newly diagnosed CRC from 25 centers. | B. 4/7 | | 3 | 8 | 55 | 1156 | 27 (6, 61) | 95 (94, 97)
Multi-center | C. Yes: patients without MSI or with negative immunostaining were not sequenced | C. Predicted transcript alteration; literature and databases
| D. 70, 60
Samowitz 2001, (34); | A. <55y | A. CRC selected by MSI:^b^PCR → Sequencing Ø Also PCR for founder mutations in the MLH1 gene | 1066 | Assuming no mutations in the absence of MSI-H tumors: | | | | | | B
US | B. Selection among incident CRC | B. 5/3^c^ | | 4 | 3 | 154 | 863 | 57 (18,90) | 85 (83,87)
Multicenter | C. Yes: patients without suggestive MSI results were not sequenced | C. Predicted transcript alteration; literature
| D. ND, ND

Studies are ordered by quality and then by decreasing number of patients available for the calculation of sensitivity and specificity (2 by 2 tables). None of the studies used conversion analysis to detect mismatch repair gene mutations.

Am1/2: Amsterdam I criteria/II; CRC: colorectal cancer; DGGE: Denaturing gradient gel electrophoresis; DHPLC: denaturating high performance liquid chromatography; MLPA: Multiple ligation-dependent probe amplification; MSI: microsatellite instability; ND: Not described; N_total_: total number of studied CRC; PCR: polymerase chain reaction

♦: Gene screening method

Ø: Detection of large genomic deletions

a Not clear if all CRC probands belong to unrelated families; only data on 103 familial cases are analyzed here, since the pertinent information was lacking for sporadic cases.

b 130 out of 171 of people with tumors with MSI instability could be genetically tested.

c One patient had mutations both in the MLH1 and in the MSH2 gene

Table F-19 Ability of Ability of young age at diagnosis (early disease onset) to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands

Study, year (Ref ID); | A. Definition of early onset | A. Genetic testing | N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Study sample characteristics | B. MLH1/MSH2 | | Early onset | No early onset | Early onset | No early onset | Sensitivity [%] | Specificity [%]
Single-/multi- center | C. Verification bias | C. Definition of deleterious mutations
| D. Mean age (y); Males (%)
Genetic testing irrespectively of tumor microsatellite instability status
Salovaara, 2000 (1740) | A. <50 y | A. PCR → Sequencing Ø PCR for founder mutations in MLH1 gene | 535 | 5 | 13 | 40 | 477 | 28 (10, 53) | 92 (90, 94) | B
Finland | B. Selection of all new unrelated CRC from 9 hospitals between 03/1996 and 06/1998 | B. 17/1
Multi-center | C. Yes: patients without MSI were screened only for MLH1 founder mutations | C. Literature; comparison with non-cancer controls
| D. 67, ND
Aaltonen, 1998 (2282) | A. <50 y | A. Ø All CRC: PCR for founder mutations 1 & 2 in MLH1 ♦CRC with MSI: (some) PCR → DGGE → Sequencing (Remaining) PCR → Sequencing | 509 | 4 | 6 | 12 | 487 | 67 (22, 96) | 98 (96, 99) | B
Finland | B. Selection of all new unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | B. 9/1
Multi-center | C. Yes: patients without MSI were screened only for MLH1 founder mutations | C. Literature; comparison with healthy controls
| D. ND, ND
Genetic testing only in patients selected after MSI and/or ICH
Pinol, 2005 (52) | A. <50 y | A. CRC selected by MSI/IHC: PCR → Sequencing Ø also MLPA | 1222 | Assuming no mutations in the absence of MSI-H tumors or tumors with negative immunostaining: | | | | | | B
Spain | B. Selection of newly diagnosed CRC from 25 centers | B. 4/7 | | 3 | 8 | 55 | 1156 | 27 (6, 61) | 95 (94, 97)
Multi-center | C. Yes: patients without MSI or with negative immunostaining were not sequenced | C. Predicted transcript alteration; literature and databases
| D. 70, 60
Samowitz 2001, (34); | A. <55y | A. CRC selected by MSI:^b^PCR → Sequencing Ø Also PCR for founder mutations in the MLH1 gene | 1066 | Assuming no mutations in the absence of MSI-H tumors: | | | | | | B
US | B. Selection among incident CRC | B. 5/3^c^ | | 4 | 3 | 154 | 863 | 57 (18, 90) | 85 (83, 87)
Multicenter | C. Yes: patients without suggestive MSI results were not sequenced | C. Predicted transcript alteration; literature
| D. ND, ND

Studies are ordered by quality and then by decreasing number of patients available for the calculation of sensitivity and specificity (2 by 2 tables). None of the studies used conversion analysis to detect mismatch repair gene mutations.

Am1/2: Amsterdam I criteria/II; CRC: colorectal cancer; DGGE: Denaturing gradient gel electrophoresis; DHPLC: denaturating high performance liquid chromatography; MLPA: Multiple ligation-dependent probe amplification; MSI: microsatellite instability; ND: Not described; N_total_: total number of studied CRC; PCR: polymerase chain reaction

♦: Gene screening method

Ø: Detection of large genomic deletions

Table F-20 Ability of familial history of malignancy to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands

Study, year (Ref ID) | A. Definition of familial history of cancer | A. Genetic testing | N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Definition of sporadic cancer | B. MLH1/MSH2 | | Familial Cancer Hx | Sporadic Cance | Familial Cancer Hx | Sporadic Cancer | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Comments on sample characteristics | C. Definition of deleterious mutations
| D. Verification bias
| E. Mean age (y); Males (%)
Genetic testing irrespectively of tumor microsatellite instability status
Salovaara, 2000 (1740); | A. 1st degree relative with CRC or endometrial cancer | A. PCR → Sequencing Ø PCR for founder mutations in MLH1 gene | 535 | 15 | 3 | 62 | 455 | 83 (59, 96) | 88 (85, 91) | B
Finland | B. All other CRC | B. 17/1
Multi-center | C. Selection of all new unrelated CRC from 9 hospitals between 03/1996 and 06/1998 | C. Literature; comparison with non-cancer controls
| D. Yes: patients without MSI were screened only for MLH1 founder mutations
| E. 67, ND
Aaltonen, 1998 (2282); | A. 1st degree relative with CRC or endometrial cancer | A. Ø All CRC: PCR for founder mutations 1 & 2 in MLH1 ♦ CRC with MSI: (some) PCR → DGGE → Sequencing (Remaining) PCR → Sequencing | 509 | 9 | 1 | 71 | 428 | 90 (55, 100) | 86 (82, 89) | B
Finland | B. All other CRC | B. 9/1
Multi-center | C. Selection of all new unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | C. Literature; comparison with healthy controls
| D. Yes: patients without MSI were screened only for MLH1 founder mutations
| E. ND, ND
Zhu, 2005 (138); | A. CRC with cancer in family | A. Ø MLPA → Sequencing of detected aberrations | 78 | 7 | 2 | 38 | 31 | 78 (40, 97) | 45 (33, 57) | B
China | B. Apparently sporadic CRC consisting of two subgroups (<50y or ≥50y at diagnosis) | B. 4/5
Single center | C. Study subgroups assembled without a clear selection process | C. Unclear
| D. No
| E. ND, ND
Wang, 1999 (1939); | A. CRC from families fulfilling Am1 criteria, or from families with 1 or 2 Amsterdam criteria missing, or families with aggregation of HNPCCC-related tumors | A. Ø RT-PCR→ IVSP; ♦ PCR→HD→Sequencing; in vivo MLH1 protein expression | 75 | 26 | 0 | 37 | 12 | 100 (87, 100) | 24 (13, 39) | B
France | B. CRC with no family Hx aged <50y at diagnosis | B. 19/7
Single-center | C. Sample assembled from referrals to a genetic consultation center | C. Predicted transcription alteration; literature
| D. No
| E. ND, ND
Yuan 1998 (2229); | A. CRC fulfilling the Korean HNPCC criteria | A. ♦ PCR→ SSCP → Sequencing of abnormal Products | 76 | 7 | 1 | 24 | 44 | 88 (47, 100) | 65 (52, 76) | C
Korea | B. CRC without family Hx of colorectal cancer aged <40y at diagnosis | B. 2/1
Single-center | C. Sample assembled with unclear selection process | C. Predicted non-conservative transcription alteration; literature; comparison with non-cancer controls
| D. No
| E. Familial: 50, 65; sporadic: 39, 49
Moslein 1996 (2545); | A. CRC fulfilling Am1; and CRC with “familial Hx of CRC” | A. PCR→sequencing | 46^a^ | 11 | 1 | 18 | 6 | 92 (62, 100) | 25 (10, 47) | C
US & Germany | B. CRC without a family Hx of CRC | B. 7/6
Multi-center | C. Sample assembled with unclear selection process | C. Predicted non-conservative transcription alteration; literature
| D. No
| E. 51, ND
Lee, 2005 (105) | A. CRC fulfilling Amsterdam II criteria; with 3 CRC in 1^st^ degree family; and with 2 CRC in 1^st^ or 2^nd^ degree family | A. PCR → Sequencing | 46^b^ | 6 | 1 | 21 | 17 | 86 (42, 100) | 45 (29, 62) | C
Singapore | B. CRC with no familial Hx and age <40y or with multiple HNPCC-related cancers | B. 6/1
Single-center | C. Sample selected from referrals to a tertiary center | C. Predicted transcript alteration; literature
| D. No
| E. 39 (median); 65
Genetic testing only in patients selected after MSI and/or ICH
Pinol, 2005 (52); | A. 1st degree relative with CRC of endometrial cancer | A. CRC selected by MSI/IHC: PCR → Sequencing Ø also MLPA | 1222 | Assuming no mutations in the absence of MSI-H tumors or tumors with negative immunostaining | | | | | | B
Spain | B. All other CRC | B. 4/7 | | 6 | 5 | 151 | 1060 | 55 (23, 83) | 88 (86, 89)
Multi-center | C. Selection of newly diagnosed CRC from 25 centers. | C. Predicted transcript alteration; literature and databases
| D. Yes: patients without MSI or with negative immunostaining were not sequenced
| E. 70, 60
Samowitz 2001, (34); | A. Family history of CRC | A. CRC selected by MSI:^c^PCR → Sequencing Ø Also PCR for founder mutations in the MLH1 Gene | 1066 | Assuming no mutations in the absence of MSI-H tumors: | | | | | | B
US | B. All other patients | B. 5/3^d^ | | 4 | 3 | 147 | 870 | 57 (18, 90) | 86 (83, 88)
Multicenter | C. Selection among incident CRC | C. Predicted transcript alteration; literature
| D. Yes: patients without suggestive MSI results were not sequenced
| E. ND, ND

Studies are ordered by quality and then by decreasing number of patients available for the calculation of sensitivity and specificity (2 by 2 tables). None of the studies used conversion analysis to detect mismatch repair gene mutations.

Am1: Amsterdam I criteria; CRC: colorectal cancer; DGGE: Denaturing gradient gel electrophoresis; HD: heteroduplex formation; Hx: History; IHC: immunohistochemistry; IVSP: in vitro synthesized protein assay; MSI: microsatellite instability; ND: Not described; N_total_: total number of studied CRC; PCR: polymerase chain reaction; SSCP: Single-stranded conformation polymorphism

♦: Gene screening method

Ø: Detection of large genomic deletions

a Interestingly, only 26/46 patients were described to have had CRC in an analytic petioent-level description, and only these are analyzed

b Contains 2 HNPCC-related non-CRC tumors that could not be separated (>95% of tumors in these data are CRC)

c 130 out of 171 of people with tumors with MSI instability could be genetically tested.

d One patient had mutations both in the MLH1 and in the MSH2 gene

Table F-21 Ability of familial history of malignancy to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands

Study, year (Ref ID); | A. Definition of familial history of cancer | A. Genetic testing | N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Definition of sporadic cancer | B. MLH1/MSH2 | | FamilialCancer Hx | Sporadic Cancer | Familial Cancer Hx | Sporadic Cancer | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Comments on sample characteristics | C. Definition of deleterious mutations
| D. Verification bias
| E. Mean age (y); Males (%)
Genetic testing irrespectively of tumor microsatellite instability status
Salovaara, 2000 (1740); | A. 1st degree relative with CRC or endometrial cancer | A. PCR → Sequencing Ø PCR for founder mutations in MLH1 gene | 535 | 15 | 3 | 62 | 455 | 83 (59, 96) | 88 (85, 91) | B
Finland | B. All other CRC | B. 17/1
Multi-center | C. Selection of all new unrelated CRC from 9 hospitals between 03/1996 and 06/1998 | C. Literature; comparison with non-cancer controls
| D. Yes: patients without MSI were screened only for MLH1 founder mutations
| E. 67, ND
Aaltonen, 1998 (2282); | A. 1st degree relative with CRC or endometrial cancer | A. Ø All CRC: PCR for founder mutations 1 & 2 in MLH1 ♦CRC with MSI: (some) PCR → DGGE → Sequencing (Remaining) PCR → Sequencing | 509 | 9 | 1 | 71 | 428 | 90 (55, 100) | 86 (82, 89) | B
Finland | B. All other CRC | B. 9/1
Multi-center | C. Selection of all new unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | C. Literature; comparison with healthy controls
| D. Yes: patients without MSI were screened only for MLH1 founder mutations
| E. ND, ND
Genetic testing only in patients selected after MSI and/or ICH
Pinol, 2005 (52); | A. 1st degree relative with CRC of endometrial cancer | A. CRC selected by MSI/IHC: PCR → Sequencing Ø also MLPA | 1222 | Assuming no mutations in the absence of MSI-H tumors or tumors with negative immunostaining: | | | | | | B
Spain | B. All other CRC | B. 4/7 | | 6 | 5 | 151 | 1060 | 55 (23, 83) | 88 (86, 89)
Multi-center | C. Selection of newly diagnosed CRC from 25 centers. | C. Predicted transcript alteration; literature and databases
| D. Yes: patients without MSI or with negative immunostaining were not sequenced
| E. 70, 60
Samowitz 2001, (34); | A. Family history of CRC | A. CRC selected by MSI:^a^PCR → Sequencing Ø Also PCR for founder mutations in the MLH1 gene | 1066 | Assuming no mutations in the absence of MSI-H tumors: | | | | | | B
US | B. All other patients | B. 5/3^b^ | | 4 | 3 | 147 | 870 | 57 (18,90) | 86 (83,88)
Multicenter | C. Selection among incident CRC | C. Predicted transcript alteration; literature
| D. Yes: patients without suggestive MSI results were not sequenced
| E. ND, ND

Studies are ordered by quality and then by decreasing number of patients available for the calculation of sensitivity and specificity (2 by 2 tables). None of the studies used conversion analysis to detect mismatch repair gene mutations.

Am1: Amsterdam I criteria; CRC: colorectal cancer; DGGE: Denaturing gradient gel electrophoresis; Hx: History; IHC: immunohistochemistry; MSI: microsatellite instability; ND: Not described; N_total_: total number of studied CRC; PCR: polymerase chain reaction

♦: Gene screening method

Ø: Detection of large genomic deletions

a 130 out of 171 of people with tumors with MSI instability could be genetically tested.

b One patient had mutations both in the MLH1 and in the MSH2 gene

Table F-22 Ability of presence of multiple tumors to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands

Study, year (Ref ID); | A. Definition of multiple tumors | A. Genetic testing | N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B.Comments on sample characteristics | B. MLH1/MSH2 | | Multiple tumors | No multiple tumors | Multiple tumors | No multiple tumors | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Verification bias | C. Definition of deleterious mutations
| D. Mean age (y); Males (%)
Genetic testing irrespectively of tumor microsatellite instability status
Salovaara, 2000 (1740); | A. Synchronous or metachronous endometrial cancer or CRC | A. PCR → Sequencing Ø PCR for founder mutations in MLH1 gene | 535 | 7 | 11 | 5 | 512 | 64 (31, 89) | 99 (98, 100) | B
Finland | B. Selection of all new unrelated CRC from 9 hospitals between 03/1996 and 06/1998 | B. 17/1
Multi-center | C. Yes: patients without MSI were screened only for MLH1 founder mutations | C. Literature; comparison with non-cancer controls
| D. 67, ND
Aaltonen, 1998 (2282); | A. Synchronous or metachronous endometrial cancer or CRC | A. Ø All CRC: PCR for founder mutations 1 & 2 in MLH1 ♦ CRC with MSI: (some) PCR → DGGE → Sequencing (Remaining) PCR → Sequencing | 509 | 4 | 6 | 12 | 487 | 40 (12,74) | 98 (96,99) | B
Finland | B. Selection of all new unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | B. 9/1
Multi-center | C. Yes: patients without MSI were screened only for MLH1 founder mutations | C. Literature; comparison with healthy controls
| D. ND, ND
Genetic testing only in patients selected after MSI and/or ICH
Pinol, 2005 (52); | A. Synchronous or metachronous endometrial cancer or CRC | A. CRC selected by MSI/IHC: PCR → Sequencing Ø also MLPA | 1222 | Assuming no mutations in the absence of MSI-H tumors or tumors with negative immunostaining: | | | | | | B
Spain | B. Selection of newly diagnosed CRC from 25 centers | B. 4/7 | | 4 | 7 | 90 | 1121 | 36 (11, 69) | 93 (91, 94)
Multi-center | C. Yes: patients without MSI or with negative immunostaining were not sequenced | C. Predicted transcript alteration; literature and databases
| D. 70, 60

Studies are ordered by quality and then by decreasing number of patients available for the calculation of sensitivity and specificity (2 by 2 tables). None of the studies used conversion analysis to detect mismatch repair gene mutations.

CRC: colorectal cancer; DGGE: Denaturing gradient gel electrophoresis; Hx: History; IHC: immunohistochemistry; MSI: microsatellite instability; ND: Not described; N_total_: total number of studied CRC; PCR: polymerase chain reaction

♦:Gene screening method

Ø:Detection of large genomic deletions

Table F-23 Ability of presence of combined family history of colorectal cancer, young age at onset or presence of multiple tumors to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands

Study, year (Ref ID); | A. Definition of combined criteria | A. Genetic testing | N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Comments on sample characteristics | B. MLH1/MSH2 | | Combined criteria | Other | Combined criteria | Other | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Verification bias | C. Definition of deleterious mutations
| D. Mean age (y); Males (%)
Genetic testing irrespectively of tumor microsatellite instability status
Salovaara, 2000 (1740); | A. Age <50 or CRC or endometrial cancer in 1^st^ degree family or personal history of CRC or endometrial cancer | A. PCR → Sequencing Ø PCR for founder mutations in MLH1 gene | 535 | 17 | 1 | 100 | 417 | 94 (73, 100) | 81 (77, 84) | B
Finland | B. Selection of all new unrelated CRC from 9 hospitals between 03/1996 and 06/1998 | B. 17/1
Multi-center | C. Yes: patients without MSI were screened only for MLH1 founder mutations | C. Literature; comparison with non-cancer controls
| D. 67, ND
Aaltonen, 1998 (2282); | A. Age <50 or CRC or endometrial cancer in 1^st^ degree family or personal history of CRC or endometrial cancer | A. Ø All CRC: PCR for founder mutations 1 & 2 in MLH1 ♦ CRC with MSI: (some) PCR → DGGE → Sequencing (Remaining) PCR → Sequencing | 509 | 10 | 0 | 112 | 387 | 100 (69, 100) | 78 (74, 81) | B
Finland | B. Selection of all new unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | B. 9/1
Multi-center | C. Yes: patients without MSI were screened only for MLH1 founder mutations | C. Literature; comparison with healthy controls
| D. ND, ND
Genetic testing only in patients selected after MSI and/or ICH
Pinol, 2005 (52); | A. Age <50 or CRC or endometrial cancer in 1^st^ degree family or personal history of CRC or endometrial cancer | A. CRC selected by MSI/IHC: PCR → Sequencing Ø also MLPA | 1222 | Assuming no mutations in the absence of MSI-H tumors or tumors with negative immunostaining: | | | | | | B
Spain | B. Selection of newly diagnosed CRC from 25 centers. | B. 4/7 | | 8 | 3 | 306 | 905 | 73 (39, 94) | 75 (72, 77)
Multi-center | C. Yes: patients without MSI or with negative immunostaining were not sequenced | C. Predicted transcript alteration; literature and databases
| D. 70, 60

Studies are ordered by quality and then by decreasing number of patients available for the calculation of sensitivity and specificity (2 by 2 tables). None of the studies used conversion analysis to detect mismatch repair gene mutations.

CRC: colorectal cancer; DGGE: Denaturing gradient gel electrophoresis; Hx: History; IHC: immunohistochemistry; MSI: microsatellite instability; ND: Not described; N_total_: total number of studied CRC; PCR: polymerase chain reaction

♦:Gene screening method

Ø:Detection of large genomic deletions

Table F-24 Ability of microsatellite instability to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands

Study, year (Ref ID); | A. Comments on sample characteristics | N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Micro-dissection | NCI 5 marker set | Quality
Country | B. Verification bias | | MSI | MSS | MSI | MSS | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%)
| D. Definition of MSI
Barnetson, 2006 (NA) | A. Selection of all incident CRC aged <55 y at diagnosis between 02/1999 and 07/2003 | 870^a^ | 20 | 10 | 24 | 298 | 67 (47, 83) | 93 (89, 95) | √ | √ | A
Scotland | B. No
Multi-center | C. 48; 53
| D. ≥2 out of ≥5 markers (MSI-H)
| ≥1 out of ≥5 markers (MSI-H&L) | | 28 | 2 | 50 | 272 | 93 (78, 99) | 84 (80, 88)
Salovaara, 2000 (1740) | A. Selection of all new unrelated CRC from 9 hospitals between 03/1996 and 06/1998 | 535 | 18 | 0 | 48 | 469 | 100 (81, 100) | 91 (88, 93) | X | X | B
Finland | B. Yes: patients without MSI were screened only for MLH1 founder mutations
Multi-center | C. 67, ND
| D. MSI based on BAT26 only
Aaltonen, 1998 (2282) | A. Selection of all new unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | 509 | 10 | 0 | 53 | 446 | 100 (69, 100) | 89 (86, 92) | X | X | B
Finland | B. Yes: patients without MSI were screened only for MLH1 founder mutations
Multi-center | C. ND, ND
| D. ≥30% of 16 markers for tumor analyzed with fluorescence methods or ≥2 out of 7 (≈30%) markers analyzed with radioactive technique (MSI-H)
Southey, 2005 (66); | A. Randomly selected from a prospective cohort of all CRC with age of onset <45 y; only patients who received genetic testing are presented^b^ | 105 | 13^b^ | 5^b^ | 4 | 36 | 72 (47, 90) | 90 (76, 97) | √ | √ | B
Australia | B. No
Single-center | C. <45y; ND
| D. >5 out of 10 markers (MSI-H)
| >1 out of 10 markers (MSIH&L) | | 17^b^ | 1^b^ | 16 | 60 | 94 (73, 100) | 79 (68, 87)
Wolf, 2005 (123); | A. Selection from a retrospective cohort of cancer patients fulfilling the modified Bethesda criteria | 81 | 13 | 0 | 9 | 33 | 100 (75, 100) | 79 (63, 90) | √ | X | B
Austria | B. No
Single-center | C. ND, 48
| D. ≥30% out of up to 10 markers (MSI-H)
Syngal, 2000 (1672) & Wahlberg, 2002 (1158); | A. Selection among referrals to specialized center^c^ | 70^c^ | 14 | 0 | 14 | 20 | 100 (77, 100) | 59 (41, 75) | √ | √ | B
US | B. No
Single-center | C. ND; ND
| D. ≥2 out of ≥5 markers (MSI-H)
Farrington, 1998 (2205); | A. Retrospective cohort of CRC aged <30 y at diagnosis who were still alive (since 1970) | 50 | 12 | 2 | 7 | 19 | 86 (57, 98) | 73 (52, 88) | √ | √ | B
Scotland | B. No
Single-center | C. <30y, ND
| D. ≥2 out of 7 markers (MSI-H)
Katballe, 2002 (1310) & Christensen, 2002 (1038); | A. Familial CRC selected from a population of 1514 newly diagnosed CRC: patients fulfilling Amsterdam II criteria (in extended families and relaxing the age criterion to <55y) and familial CRC with early age of onset | 45 | 10 | 0 | 3 | 20 | 100 (69, 100) | 87 (66, 97) | √ | X | B
Denmark | B. No
Single-center | C. ND; ND
| D. ≥2 out of ≥5 markers (MSI-H)
| ≥1 out of ≥5 markers (MSI-H&L) | | 10 | 0 | 5 | 20 | 100 (69, 100) | 80 (59, 93)
Dieumegard, 2000 (1791); | A. Sample assembled with unclear selection process: we present analyses only among familial CRC who were at most 1 criterion short of fulfilling Am1 (n=17); study also included 17 apparently sporadic CRC aged <50y at diagnosis. | 34^d^ | 9 | 0 | 6 | 9 | 100 (66, 100) | 60 (32, 84) | X | X | B
France | B. Yes: not all sporadic CRC underwent MMR mutation testing (these are not included in this analysis)
Multi-center | C. Oldest at diagnosis was 56, ND
| D. ≥10% of up to 23 markers (But all were ≥30%) (MSI-H)
| ≥10% of up to 23 markers (MSI-H&L) | | 9 | 0 | 6 | 9 | 100 (66, 100) | 60 (32, 84)
Curia, 1999 (1959); | A. Sampled from pathology registries, unclear selection criteria: HNPCC related cancers^e^ | 30^e^ | 1 | 0 | 15 | 3 | 100 (0, 100) | 17 (4, 41) | √ | X | B
Italy | B. No
Single-center | C. <50y, ND
| D. ≥2 markers out of 3 markers or up to a total of 7 markers (MSI-H)
Debniak,, 2000 (1784); | A. Sampled from consecutive CRC, selection process not transparent. All patient with available data are included. | 168 | 5 | 1 | 8 | 54 | 83 (36, 100) | 87 (76, 94) | √ | √ | C
Poland | B. Yes: Only 43/143 apparently sporadic CRC were tested, but it is unclear how they were selected
Single-center(?) | C. ND, ND
| D. ≥2 out of ≥5 markers or ≥3 out of ≥10 markers (MSI-H)
Lee, 2005 (105); | A. Selection among referrals to tertiary center: Amsterdam criteria, familial disease, onset <40y or multiple tumors | 46^f^ | 4 | 1 | 7 | 21 | 80 (28, 99) | 75 (55, 89) | √ | √ | C
Singapore | B. No
Single-center | C. 39 (median); 65
| D. ≥2 out of ≥5 markers (MSI-H)
| ≥1 out of ≥5 markers (MSI-H&L) | | 4 | 1 | 9 | 21 | 80 (28, 99) | 70 (51, 85)
Moslein 1996 (2545) | A. Sample assembled from various databases; we present analyses only among familial cases (39/46), and only those described to have CRC. Study also included 7 sporadic CRC.^g^ | 46^g^ | 5 | 4 | 4 | 8 | 56 (21, 86) | 67 (35, 90) | X | X | C
US & Germany | B. No
Multi-center | C. 51, ND
| D. ≥30% of 9 to 34 markers analyzed (unclear which exactly) (MSI-H)
Callistri, 2000 (1797); | A. Study sample assembled with unclear selection process: Familial CRC fulfilling Am1 criteria or missing up to 2/3 Am1 criteria, or a CRC among 1^st^ degree family or CRC diagnosis at age <50y, or multiple tumors in the same patient | 40^h^ | 7 | 0 | 5 | 4 | 100 (59, 100) | 44 (14, 79) | √ | √ | C
Italy | B. No
Multi-center | C. ND; 56 (all sample)
| D. ≥2 out of ≥5 markers (MSI-H)
Durno, 2005 (195); | A. Retrospective cohort of CRC aged <24 y at diagnosis who were still alive (since 1960) | 16 | 5 | 0 | 3 | 1 | 100 (48, 100) | 25 (0, 81) | √ | √ | C
Canada | C. <24y, 38
Multi-center | B. No
| D. ≥2 out of ≥5 markers, or (MSI-H) ≥40% out of up to 10 markers (MSI-H)
Peel, 1999 (1660); | A. Referral HNPCC cases, other than the 1134 CRC probands who were also included but were not assessed with laboratory tests | 11 | 3 | 0 | 1 | 5 | 100 (29, 100) | 83 (36, 100) | √ | X | C
US | B. No
Multi-center | C. ND; ND
| D. Unclear; at least 5 markers were used (MSIH?)

Note that studies that assessed genetic mutations only in patients with MSI cannot be used to construct 2 by 2 tables for the ability of MSI testing to detect MMR mutations. Thus such studies are not included in this table. Not included in the table are data from Lamberti 1999, where only the contrast of MSI-H versus combined MSI-L and MSI-S was extractable.

CRC: colorectal cancer; MSI(-H/-L): microsatellite instability (-high/-low); MSS: microsatellite-stable (no instability); NA: Not applicable; ND: Not described; N_total_: total number of studied CRC

a Overall, 359 patients had available tumor tissue of good quality. Study assessed for mutations in the MSH6 gene also.

b This study assessed MSH6 and hPSM2 also. The mutation counts include pathogenic mutations in these genes also.

c Data from the Wahlberg et al. publication

d Only 7/17 apparently sporadic CRC were genetically tested (unclear how they were selected).

e Four were not CRC and were excluded from the calculations; numbers among patients with available tumors; only pathogenic mutations are shown.

f Included are 2 malignant tumors other than CRC that could not be separated.

g Interestingly, despite the fact that all were characterized as CRC, in an analytic description not all were described with CRC. Only familial cases that were described with CRC are included.

h Data out of 20 CRC (of 45 total studied patients) who missed at most 2 out of 3 Amsterdam I criteria are analyzed here, because MMR gene mutations were tested inconsistently among the remaining patients.

Table F-25 Ability of microsatellite instability to identify MLH1 and MSH2 mutation carriers among unselected colorectal cancer probands

Study, year (Ref ID); | A. Comments on sample characteristics | N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Micro-dissection | NCI 5 marker set | Quality
Country | B. Verification bias | | MSI-H | MSS | MSI-H | MSS | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%)
| D. Definition of MSI
Salovaara, 2000 (1740) | A. Selection of all new unrelated CRC from 9 hospitals between 0.3/1996 and 06/1998 | 535 | 18 | 0 | 48 | 469 | 100 (81, 100) | 91 (88, 93) | X | X | B
Finland | B. Yes: patients without MSI were screened only for MLH1 founder mutations
Multi-center | C. 67, ND
| D. MSI based on BAT26 only
Aaltonen, 1998 (2282) | A. Selection of all new unrelated CRC from 9 hospitals between 05/1994 and 04/1996 | 509 | 10 | 0 | 53 | 446 | 100 (69, 100) | 89 (86, 92) | X | X | B
Finland | B. Yes: patients without MSI were screened only for MLH1 founder mutations
Multi-center | C. ND, ND
| D. ≥30% of 16 markers for tumor analyzed with fluorescence methods or ≥ 2 out of 7 (≈30%) markers analyzed with radioactive technique (MSI-H)

Note that studies that assessed genetic mutations only in patients with MSI cannot be used to construct 2 by 2 tables for the ability of MSI testing to detect MMR mutations. Thus such studies are not included in this table.

CRC: colorectal cancer; MSI(-H): microsatellite instability (-high); MSS: microsatellite-stable (no instability); ND: Not described; N_total_: total number of studied CRC

Table F-26 Ability of microsatellite instability to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands fulfilling the revised Bethesda criteria

Study, year (Ref ID); | A. Comments on sample characteristics | N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Micro-dissection | NCI 5 marker set | Quality
Country | B. Verification bias | | MSI | MSS | MSI | MSS | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%)
| D. Definition of MSI
Wolf, 2005 (123); | A. Selection from a retrospective cohort of cancer patients fulfilling the modified Bethesda criteria | 81 | 13 | 0 | 9 | 33 | 100 (75, 100) | 79 (63, 90) | √ | X | B
Austria | B. No
Single-center | C. ND, 48
| D. ≥30% out of up to 10 markers (MSI-H)

Note that studies that assessed genetic mutations only in patients with MSI cannot be used to construct 2 by 2 tables for the ability of MSI testing to detect MMR mutations. Thus such studies are not included in this table.

CRC: colorectal cancer; MSI(-H/-L): microsatellite instability (-high/-low); MSS: microsatellite-stable (no instability); NA: Not applicable; ND: Not described; N_total_: total number of studied CRC

Table F-27 Ability of microsatellite instability to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands fulfilling the Amsterdam I criteria

Study, year (Ref ID); | A. Comments on sample characteristics | N_Am1_/ N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Micro-dissection | NCI 5 marker set | Quality
Country | B. Verification bias | | MSI | MSS | MSI | MSS | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Definition of MSI
Moslein 1996 (2545) | A. Sample assembled from various databases; we present analyses only among familial cases (39/46), and only those described to have CRC. Study also included 7 sporadic CRC. | 14/46 | 5 | 0 | 0 | 4 | 100 (48, 100) | 100 (40, 100) | X | X | C
US & Germany | B. No
Multi-center | C. ≥30% of 9 to 34 markers analyzed (unclear which exactly) (MSI-H)
Dieumegard, 2000 (1791); | A. Sample assembled with unclear election process: we present analyses only mong familial CRC who were at most 1 riterion short of fulfilling Am1 (n=17); study also included 17 apparently sporadic CRC aged <50y at diagnosis. | 10/34 | 6 | 0 | 3 | 1 | 100 (54, 100) | 25 (0, 81) | X | X | B
France | B. Yes: not all sporadic CRC underwent MMR mutation testing (these are not included in this analysis)
Multi-center | C. ≥10% of up to 23 markers (But all were ≥30%) (MSI-H)
| ≥10% of up to 23 markers (MSI-H&L) | | 6 | 0 | 3 | 1 | 100 (54, 100) | 25 (0, 81)
Peel, 1999 (1660); | A. Referral HNPCC cases, other than the 1134 CRC probands who were also included but were not assessed with laboratory tests | 11/11 | 3 | 0 | 1 | 5 | 100 (29, 100) | 83 (36, 100) | √ | X | C
US | B. No
Multi-center | C. Unclear; at least 5 markers were used (MSI-H?)

Demographics (data on age and gender distributions) were not available among people with fulfilling the Amsterdam I criteria. Note that studies that assessed genetic mutations only in patients with MSI cannot be used to construct 2 by 2 tables for the ability of MSI testing to detect MMR mutations. Thus such studies are not included in this table.

CRC: colorectal cancer; MSI(-H/-L): microsatellite instability (-high/-low); MSS: microasatellite-stable (no instability); NA: Not applicable; ND: Not described; N_Am1_: total number of people fulfilling Amsterdam I criteria in the study population; N_total_: total number of studied CRC

Table F-28 Ability of immunohistochemistry to identify MLH1 and MSH2 mutation carriers among selected colorectal cancer probands

Study, year (Ref ID); | A. Comments on sampling | N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | | No staining | Staining | No staining | Staining | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%)
| D. Antibodies used
Genetic testing irrespectively of tumor microsatellite instability status
Barnetson, 2006 (NA) | A. Selection of all incident CRC aged <55 y ate diagnosis between 02/1999 and 07/2003 | 870^a^ | 24 | 3 | 39 | 285 | 89 (71, 98) | 88 (84, 91) | A
Scotland | B. No
Multicenter | C. 48; 53
| D. Anti-MSH2: (Oncogene Research Products); anti-MLH1: (PharMingen); anti-MSH6: (Transduction laboratories);
Southey, 2005 (66) | A. Randomly selected from a prospective cohort of all CRC with age of onset <45y; only patients who received genetic testing are presented^b^ | 105^b^ | 18^b^ | 0^b^ | 8^b^ | 33^b^ | 100 (81, 100) | 80 (65, 91) | B
Australia | B. No
Single-center | C. <45y; ND
| D. Anti-MSH2: FE-11 (Oncogene Research Products); anti-MLH1: G168–728 (PharMingen); anti-MSH6: clone 44 (BD transduction laboratories); anti-PMS2: clone A16-4 (PharMingen)
Syngal, 2000 (1672) & Wahlberg, 2002 (1158); | A. Selection among referrals to pecialized center ^c^ | 70^c^ | 6 | 5 | 3 | 22 | 55 (23, 83) | 88 (69, 97) | B
US | B. No
Single-center | C. ND; ND
| D. Anti-MSH2: FE11 (Oncogene Research Products); anti-MLH1: G168–728 (PharMingen)
Katballe, 2002 (1310) & Christensen, 2002 (1038); | A. Selected from a population of 1514 incident CRC | 42^d^ | 9 | 4 | 3 | 15 | 69 (39, 91) | 83 (59, 96) | B
Denmark | B. No
Single-center | C. ND; ND
| D. Anti-MSH2: Ab-1, Ab-2 (Oncogene Research Products); anti-MLH1: G168-15 (PharMingen)
Curia, 1999 (1959) | A. Sampled from pathology registries, unclear selection criteria: HNPCC related cancers^e^ | 30^e^ | 1 | 0 | 13 | 10 | 100 (0, 100) | 57 (34, 77) | B
Italy | B. No
Single-center | C. <50y, ND
| D. Anti-MSH2: FE11 (Oncogene Research Products); anti-MLH1: clone 14 (Oncogene Research Products)
Dieumegard, 2000 (1791) | A. Sample assembled with unclear selection process: familial CRC missing at most 1 Am1 criterion and sporadic CRC aged <50y at diagnosis | 34 | 4 | 3 | 5 | 9 | 57 (18, 90) | 64 (35, 87) | B
France | B. Yes: only 7 sporadic CRC underwent genetic testing
Multicenter | C. Oldest age at diagnosis 56, ND
| D. Anti-MSH2: FE-11 (Oncogene Research Products); anti-MLH1: Ab-1 (Oncogene Research Products)
Debniak,, 2000 (1784); | E. Sampled from consecutive CRC, selection process not transparent. All patient with available data are included. | 168 | 2 | 9 | 0 | 56 | 18 (2, 51) | 100 (94, 100) | C
Poland | F. Yes: Only 43/143 apparently sporadic CRC were tested, but it is unclear how they were selected
Single-center(?) | G. ND, ND
| H. Unclear
Durno, 2005 (195) | E. Retrospective cohort of CRC aged<24 y at diagnosis who were still alive (since 1970) | 16 | 3 | 1 | 1 | 3 | 75 (19, 99) | 75 (19, 99) | C
Canada | F. No
Multi-center | G. <24y; 38
| H. Anti-MSH2: FE-11 (Oncogene Research Products); anti-MLH1: G168–728 (PharMingen
Genetic testing among patients with MSI-H tumors
Terdiman, 2001 (1572) | A. Retrospective cohort of CRC probands with ≥2 CRC in first degree family, age <50y at diagnosis or multiple tumors in the same patient | 114 | 16 | 1 | 29 | 4 | 94 (71, 100) | 13 (4, 30) | B
US | B. Yes: only patients with MSI-H were assessed
Single-center | C. ND, ND
| D. Unclear

No (nuclear immuno-) staining is the abnormal response. The number of patients in the 2 by 2 tables is the number of patients with available data and is typically smaller than the total number of patients included in the study.

CRC: colorectal cancer; ND: Not described; N_total_: total number of studied CRC

a Overall 359 patients had available tumor tissue of good quality.

b This study assessed PMS2 and MSH6 also. The mutation and IHC testing include pathogenic mutations in these genes also.

c Data from the publication by Wahlberg et al.

d Data from the publication by Christensen et al.

e 4 were not CRC and are excluded from the calculations; Only 24 specimens had available IHC data.

Table F-29 Ability of immunohistochemistry to identify MLH1 and MSH2 mutation carriers among colorectal cancer probands fulfilling Amsterdam I criteria

Study, year (Ref ID); | A. Comments on sampling | N_Am1_/N_total_ | Mutation | | No mutation | | Diagnostic performance (95% confidence interval) | | Quality
Country | B. Verification bias | | No staining | Staining | No staining | Staining | Sensitivity [%] | Specificity [%]
Single-/multi-center | C. Mean age (y); Males (%)
| D. Antibodies used
Katballe, 2002 (1310) & Christensen, 2002 (1038); | A. Selected from a population of 1514 incident CRC | 11/42^a^ | 2 | 2 | 0 | 5 | 50 (7, 93) | 100 (48, 100) | B
Denmark | B. No
Single-center | C. ND; ND
| D. Anti-MSH2: Ab-1, Ab-2 (Oncogene Research Products); anti-MLH1: G168-15 (PharMingen)
Dieumegard, 2000 (1791) | A. Sample assembled with unclear selection process: familial CRC missing at most 1 Am1 criterion and sporadic CRC aged <50y at diagnosis | 10/34 | 2 | 2 | 2 | 2 | 50 (7, 93) | 50 (7, 93) | B
France | B. Yes: only 7 sporadic CRC underwent genetic testing
Multicenter | C. Oldest age at diagnosis 56, ND
| D. Anti-MSH2: FE-11 (Oncogene Research Products); anti-MLH1: Ab-1 (Oncogene Research Products)

No (nuclear immuno-) staining is the abnormal response. The number of patients in the 2 by 2 tables is the number of patients with available data and is typically smaller than the total number of patients included in the study.

CRC: colorectal cancer;; N_Am1_: number fulfilling Amsterdam I criteria; ND: Not described; N_total_: total number of studied CRC

a Data from the publication by Christensen et al.