# Appendix E. Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this Report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report by the peer reviewers.

- Linda Bradley, Ph.D.*
- Evaluation of Genomic Applications in Practice and Prevention (EGAPP)
- Office of Genomics and Disease Prevention
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Ralph J. Coates, Ph.D.
- National Center for Chronic Disease Prevention and Health Promotion
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Albert de la Chapelle, M.D., Ph.D.
- Human Cancer Genetics Program
- Comprehensive Cancer Center
- Ohio State University

- Robert H. Fletcher, M.D., M.Sc.*
- University of North Carolina
- Chapel Hill, North Carolina

- Heather Hampel, M.S., C.G.C.
- Department of Internal Medicine
- James Cancer Hospital & Solove Research Institute
- Columbus, Ohio

- James Haddow, M.D.*
- Women and Infants Hospital
- Providence, Rhode Island

- Celia Kaye, M.D., Ph.D.*
- University of Colorado School of Medicine
- Denver, Colorado
- National Newborn Screening and Genetics Resource Center
- University of Texas Health Science Center
- San Antonio, Texas

- Michael P. Pignone, M.D., M.P.H.
- Department of Medicine
- University of North Carolina
- Chapel Hill, North Carolina

- Philip Prorok, Ph.D.
- National Cancer Institute
- Rockville, Maryland

- Carolyn Sue Richards, Ph.D., F.A.C.M.G.*
- Molecular Diagnostic Center
- Oregon Health & Science University
- Portland, Oregon

- Yvette Seger, Ph.D.
- Office of Biotechnology Activities
- Office of the Director
- National Institutes of Health

* Also served on the Technical Expert Panel, which advised the Evidence-based Practice Center.