# Appendix D. List of Excluded Studies

## References

Aaltonen LA, Peltomaki P, Leach FS, Sistonen P, Pylkkanen L, Mecklin JP, et al. Clues to the pathogenesis of familial colorectal cancer.[comment]. Science. May 7. 1993;260(5109):812-6. Linkage analysis. [pmid: 8484121].
Aarnio M, Sankila R, Pukkala E, Salovaara R, Aaltonen LA, de la CA, et al. Cancer risk in mutation carriers of DNA-mismatch-repair genes. Int J Cancer. Apr 12. 1999;81(2):214-8. Not population of interest. [pmid: 10188721].
Abdel-Rahman WM, Ollikainen M, Kariola R, Jarvinen HJ, Mecklin JP, Nystrom-Lahti M, et al. Comprehensive characterization of HNPCC-related colorectal cancers reveals striking molecular features in families with no germline mismatch repair gene mutations. Oncogene. Feb 24. 2005;24(9):1542-51. Didn't report any of 5 options. [pmid: 15674332].
Ainsworth PJ, Koscinski D, Fraser BP, Stuart JA. Family cancer histories predictive of a high risk of hereditary non-polyposis colorectal cancer associate significantly with a genomic rearrangement in hMSH2 or hMLH1. Clin Genet. Sep. 2004;66(3):183-8. Not population of interest. [pmid: 15324316].
Akrami SM, Dunlop MG, Farrington SM, Frayling IM, MacDonald F, Harvey JF, et al. Screening for exonic copy number mutations at MSH2 and MLH1 by MAPH. Fam Cancer. 2005;4(2):145-9. Didn't report any of 5 options. [pmid: 15951966].
Alexander J, Watanabe T, Wu TT, Rashid A, Li S, Hamilton SR. Histopathological identification of colon cancer with microsatellite instability. Am J Pathol. 2001;158(2):527-35. Genetic testing not compared with an index test. [pmid: 11159189]. [pmcid: 1850324].
Andrew SE, Whiteside D, Buzin C, Greenberg C, Spriggs E. An intronic polymorphism of the hMLH1 gene contributes toward incomplete genetic testing for HNPCC. Genet Test. 2002;6(4):319-22. Didn't report any of 5 options. [pmid: 12537657].
Anonymous. American Gastroenterological Association medical position statement: hereditary colorectal cancer and genetic testing. Gastroenterology 2001 Jul;121(1):195–7. Reference
Anonymous. MSH6 mutations and risk of uterine cancer. Cancer Biol Ther 2004 Jun;3(6):491. News article, not study
Anonymous. Practice parameters for the identification and testing of patients at risk for dominantly inherited colorectal cancer. Dis Colon Rectum 2001 Oct;44(10):1403. Guideline
Anonymous. Statement of the American Society of Clinical Oncology: genetic testing for cancer susceptibility, Adopted on February 20, 1996. J Clin Oncol 1996;14(5):1730–6. Not relevant
Apessos A, Mihalatos M, Danielidis I, Kallimanis G, Agnantis NJ, Triantafillidis JK, et al. hMSH2 is the most commonly mutated MMR gene in a cohort of Greek HNPCC patients. Br J Cancer. Jan 31. 2005;92(2):396-404. Not population of interest. [pmid: 15655560].
Arnold CN, Goel A, Compton C, Marcus V, Niedzwiecki D, Dowell JM, et al. Evaluation of microsatellite instability, hMLH1 expression and hMLH1 promoter hypermethylation in defining the MSI phenotype of colorectal cancer. Cancer Biol Ther. Jan. 2004;3(1):73-8. Not population of interest. [pmid: 14726676].
Ashktorab H, Smoot DT, Carethers JM, Rahmanian M, Kittles R, Vosganian G, et al. High incidence of microsatellite instability in colorectal cancer from African Americans. Clin Cancer Res. Mar. 2003;9(3):1112-7. Genetic testing not compared with index test. [pmid: 12631615].
Ashktorab H, Smoot DT, Farzanmehr H, Fidelia-Lambert M, Momen B, Hylind L, et al. Clinicopathological features and microsatellite instability (MSI) in colorectal cancers from African Americans. Int J Cancer. Oct 10. 2005;116(6):914-9. Genetic testing not compared with an index test; hMLH1 and hMSH2 sequencing not performed. [pmid: 15856472].
Bacher JW, Flanagan LA, Smalley RL, Nassif NA, Burgart LJ, Halberg RB, et al. Development of a fluorescent multiplex assay for detection of MSI-High tumors. Dis Markers. 2004;20(45):237-50. Biological material not evaluated. [pmid: 15528789].
Bai YQ, Akiyama Y, Nagasaki H, Lu SL, Arai T, Morisaki T, et al. Predominant germ-line mutation of the hMSH2 gene in Japanese hereditary non-polyposis colorectal cancer kindreds. Int J Cancer. Aug 12. 1999;82(4):512-5. Not population of interest. [pmid: 10404063].
Bandipalliam P. Syndrome of early onset colon cancers, hematologic malignancies & features of neurofibromatosis in HNPCC families with homozygous mismatch repair gene mutations. Familial Cancer. 2005;4(4):323-33. Case series. [pmid: 16341812].
Banno K, Susumu N, Hirao T, Yanokura M, Hirasawa A, Aoki D, et al. Identification of germline MSH2 gene mutations in endometrial cancer not fulfilling the new clinical criteria for hereditary nonpolyposis colorectal cancer. Cancer Genet Cytogenet. Oct 1. 2003;146(1):58-65. Not population of interest. [pmid: 14499697].
Banno K, Susumu N, Hirao T, Yanokura M, Hirasawa A, Aoki D, et al. Two Japanese kindreds occurring endometrial cancer meeting new clinical criteria for hereditary non-polyposis colorectal cancer (HNPCC), Amsterdam Criteria II. J Obstet Gynaecol Res. Aug. 2004;30(4):287-92. Not population of interest. [pmid: 15238104].
Banno K, Susumu N, Yanokura M, Hirao T, Iwata T, Hirasawa A, et al. Association of HNPCC and endometrial cancers. Int J Clin Oncol. Aug. 2004;9(4):262-9. Not population of interest. [pmid: 15375702].
Bapat BV, Madlensky L, Temple LK, Hiruki T, Redston M, Baron DL, et al. Family history characteristics, tumor microsatellite instability and germline MSH2 and MLH1 mutations in hereditary colorectal cancer. Hum Genet. Feb. 1999;104(2):167-76. Not population of interest. [pmid: 10190329].
Bartosova Z, Fridrichova I, Bujalkova M, Wolf B, Ilencikova D, Krizan P, et al. Novel MLH1 and MSH2 germline mutations in the first HNPCC families identified in Slovakia. Hum Mutat. Apr. 2003;21(4):449. Not population of interest. [pmid: 12655568].
Batra S, Valdimarsdottir H, McGovern M, Itzkowitz S, Brown K. Awareness of genetic testing for colorectal cancer predisposition among specialists in gastroenterology. Am J Gastroenterol. Mar. 2002;97(3):729-33. Not population of interest. [pmid: 11922570].
Baudhuin LM, Burgart LJ, Leontovich O, Thibodeau SN. Use of microsatellite instability and immunohistochemistry testing for the identification of individuals at risk for lynch syndrome. Fam Cancer. 2005;4(3):255-65. Not primary study. [pmid: 16136387].
Baudhuin LM, Ferber MJ, Winters JL, Steenblock KJ, Swanson RL, French AJ, et al. Characterization of hMLH1 and hMSH2 gene dosage alterations in Lynch syndrome patients. Gastroenterology. Sep. 2005;129(3):846-54. Didn't report any of 5 options. [pmid: 16143124].
Baudhuin LM, Mai M, French AJ, Kruckeberg KE, Swanson RL, Winters JL, et al. Analysis of hMLH1 and hMSH2 gene dosage alterations in hereditary nonpolyposis colorectal cancer patients by novel methods. J Mol Diagn. May. 2005;7(2):226-35. Didn't report any of 5 options. [pmid: 15858146]. [pmcid: 1867519].
Baudi F, Fersini G, Lavecchia A, Terracciano R, Leone F, Quaresima B, et al. A novel missense germline mutation in exon 2 of the hMSH2 gene in a HNPCC family from Southern Italy. Cancer Lett. Jun 8. 2005;223(2):285-91. Not population of interest. [pmid: 15896463].
Beck NE, Tomlinson IP, Homfray T, Frayling I, Hodgson SV, Harocopos C, et al. Use of SSCP analysis to identify germline mutations in HNPCC families fulfilling the Amsterdam criteria. Hum Genet. Feb. 1997;99(2):219-24. Didn't report any of 5 options. [pmid: 9048925].
Beck NE, Tomlinson IP, Homfray T, Hodgson SV, Harocopos CJ, Bodmer WF. Genetic testing is important in families with a history suggestive of hereditary non-polyposis colorectal cancer even if the Amsterdam criteria are not fulfilled. Br J Surg. Feb. 1997;84(2):233-7. Not population of interest. [pmid: 9052445].
Beck NE, Tomlinson IP, Homfray TF, Frayling IM, Hodgson SV, Bodmer WF. Frequency of germline hereditary non-polyposis colorectal cancer gene mutations in patients with multiple or early onset colorectal adenomas. Gut. Aug. 1997;41(2):235-8. Did not meet inclusion criteria for population. [pmid: 9301504]. [pmcid: 1891471].
Benatti P, Roncucci L, Ganazzi D, Percesepe A, Di Gregorio C, Pedroni M, et al. Clinical and biologic heterogeneity of hereditary nonpolyposis colorectal cancer. Int J Cancer. Sep 20. 2001;95(5):323-8. Duplicate publication. [pmid: 11494233].
Benatti P, Sassatelli R, Roncucci L, Pedroni M, Fante R, Di Gregorio C, et al. Tumour spectrum in hereditary non-polyposis colorectal cancer (HNPCC) and in families with “suspected HNPCC”. A population-based study in northern Italy. Colorectal Cancer Study Group. Int J Cancer. May 28. 1993;54(3):371-7. Genetic testing not compared with an index test; hMLH1 and hMSH2 sequencing not performed. [pmid: 8509211].
Berends MJ, Hollema H, Wu Y, van der ST, Mensink RG, ten Hoor KA, et al. MLH1 and MSH2 protein expression as a pre-screening marker in hereditary and non-hereditary endometrial hyperplasia and cancer. Int J Cancer. May 1. 2001;92(3):398-403. Not population of interest. [pmid: 11291077].
Berends MJ, Wu Y, Sijmons RH, Mensink RG, van der ST, Hordijk-Hos JM, et al. Molecular and clinical characteristics of MSH6 variants: an analysis of 25 index carriers of a germline variant. Am J Hum Genet. Jan. 2002;70(1):26-37. Not population of interest. [pmid: 11709755]. [pmcid: 384896].
Berends MJ, Wu Y, Sijmons RH, van der ST, Ek WB, Ligtenberg MJ, et al. Toward new strategies to select young endometrial cancer patients for mismatch repair gene mutation analysis. J Clin Oncol. Dec 1. 2003;21(23):4364-70. Not population of interest. [pmid: 14645426].
Bisgaard ML, Jager AC, Myrhoj T, Bernstein I, Nielsen FC. Hereditary non-polyposis colorectal cancer (HNPCC): phenotype-genotype correlation between patients with and without identified mutation. Hum Mutat. Jul. 2002;20(1):20-7. Not population of interest. [pmid: 12112654].
Bocker T, Diermann J, Friedl W, Gebert J, Holinski-Feder E, Karner-Hanusch J, et al. Microsatellite instability analysis: a multicenter study for reliability and quality control. Cancer Res. Nov 1. 1997;57(21):4739-43. Genetic test not compared to index test. [pmid: 9354434].
Boland CR, Fishel R. Lynch syndrome: form, function, proteins, and basketball. Gastroenterology. 2005;129(2):751-5. Not relevant. [pmid: 16083730].
Boland CR, Thibodeau SN, Hamilton SR, Sidransky D, Eshleman JR, Burt RW, et al. A National Cancer Institute Workshop on Microsatellite Instability for cancer detection and familial predisposition: development of international criteria for the determination of microsatellite instability in colorectal cancer. Cancer Res. Nov 15. 1998;58(22):5248-57. Review. [pmid: 9823339].
Broaddus RR, Lynch PM, Lu KH, Luthra R, Michelson SJ. Unusual tumors associated with the hereditary nonpolyposis colorectal cancer syndrome. Mod Pathol. Aug. 2004;17(8):981-9. Case report. [pmid: 15143336].
Brown GJ, St John DJ, Macrae FA, Aittomaki K. Cancer risk in young women at risk of hereditary nonpolyposis colorectal cancer: implications for gynecologic surveillance. Gynecol Oncol. 2001;80(3):346-9. Not relevant. [pmid: 11263929].
Buerstedde JM, Alday P, Torhorst J, Weber W, Muller H, Scott R. Detection of new mutations in six out of 10 Swiss HNPCC families by genomic sequencing of the hMSH2 and hMLH1 genes. J Med Genet. Nov. 1995;32(11):909-12. Not population of interest. [pmid: 8592341]. [pmcid: 1051749].
Burgart LJ. Testing for defective DNA mismatch repair in colorectal carcinoma: a practical guide. Arch Pathol Lab Med. Nov. 2005;129(11):1385-9. Not relevant. [pmid: 16253016].
Burke W, Petersen G, Lynch P, Botkin J, Daly M, Garber J, et al. Recommendations for follow-up care of individuals with an inherited predisposition to cancer. I. Hereditary nonpolyposis colon cancer. Cancer Genetics Studies Consortium. Jama. 1997;277(11):915-9. Not primary study. [pmid: 9062331].
Cai Q, Sun MH, Lu HF, Zhang TM, Mo SJ, Xu Y, et al. Clinicopathological and molecular genetic analysis of 4 typical Chinese HNPCC families. World J Gastroenterol. Dec. 2001;7(6):805-10. Case series. [pmid: 11854906].
Cai SJ, Xu Y, Cai GX, Lian P, Guan ZQ, Mo SJ, et al. Clinical characteristics and diagnosis of patients with hereditary nonpolyposis colorectal cancer. World J Gastroenterol. Feb. 2003;9(2):284-7. Not relevant. [pmid: 12532449].
Caldes T, Godino J, de la HM, Garcia C, Garcia C, Perez SP, Eng C, et al. Prevalence of germline mutations of MLH1 and MSH2 in hereditary nonpolyposis colorectal cancer families from Spain. Int J Cancer. Apr 10. 2002;98(5):774-9. Not population of interest. [pmid: 11920650].
Cameron BH, Fitzgerald GW, Cox J. Hereditary site-specific colon cancer in a Canadian kindred. CMAJ. Jan 1. 1989;140(1):41-5. Case series, no relevant data. [pmid: 2909271]. [pmcid: 1268532].
Carethers JM, Smith EJ, Behling CA, Nguyen L, Tajima A, Doctolero RT, et al. Use of 5-fluorouracil and survival in patients with microsatellite-unstable colorectal cancer.[see comment]. Gastroenterology. Feb. 2004;126(2):394-401. Not relevant. [pmid: 14762775].
Chai SM, Zeps N, Shearwood AM, Grieu F, Charles A, Harvey J, et al. Screening for defective DNA mismatch repair in stage II and III colorectal cancer patients. Clin Gastroenterol Hepatol. Nov. 2004;2(11):1017-25. hMLH1 and hMSH2 sequencing not performed. [pmid: 15551255].
Chan TL, Yuen ST, Chung LP, Ho JW, Kwan KY, Chan AS, et al. Frequent microsatellite instability and mismatch repair gene mutations in young Chinese patients with colorectal cancer. J Natl Cancer Inst. Jul 21. 1999;91(14):1221-6. No data. [pmid: 10413423].
Chapusot C, Martin L, Mungra N, Rageot D, Bouvier AM, Bonithon KC, et al. Sporadic colorectal cancers with defective mismatch repair display a number of specific morphological characteristics: relationship between the expression of hMLH1 and hMSH2 proteins and clinicopathological features of 273 adenocarcinomas. Histopathology. Jul. 2003;43(1):40-7. Genetic testing not compared with an index test; hMLH1 and hMSH2 sequencing not performed. [pmid: 12823711].
Chapusot C, Martin L, Puig PL, Ponnelle T, Cheynel N, Bouvier AM, et al. What is the best way to assess microsatellite instability status in colorectal cancer? Study on a population base of 462 colorectal cancers. Am J Surg Pathol. Dec. 2004;28(12):1553-9. Genetic test not compared to index test. [pmid: 15577673].
Chaves P, Cruz C, Lage P, Claro I, Cravo M, Leitao CN, et al. Immunohistochemical detection of mismatch repair gene proteins as a useful tool for the identification of colorectal carcinoma with the mutator phenotype. J Pathol. Aug. 2000;191(4):355-60. Genetic testing not compared with index test. [pmid: 10918209].
Chen S, Watson P, Parmigiani G. Accuracy of MSI testing in predicting germline mutations of MSH2 and MLH1: a case study in Bayesian meta-analysis of diagnostic tests without a gold standard. Biostatistics. Jul. 2005;6(3):450-64. Meta-analysis. [pmid: 15831578]. [pmcid: 2274000].
Chung DC, Rustgi AK. The hereditary nonpolyposis colorectal cancer syndrome: genetics and clinical implications. Ann Intern Med. 2003;138(7):560-70. Not primary study. [pmid: 12667026].
Church J, Simmang C. Practice parameters for the treatment of patients with dominantly inherited colorectal cancer (familial adenomatous polyposis and hereditary nonpolyposis colorectal cancer). Dis Colon Rectum. Aug. 2003;46(8):1001-12. Guideline. [pmid: 12907889].
Church J. Hereditary colon cancers can be tiny: a cautionary case report of the results of colonoscopic surveillance. Am J Gastroenterol. Nov. 1998;93(11):2289-90. Case report. [pmid: 9820419].
Claro I, Cravo M, Gloria L, Gaspar C, Albuquerque C, Lage P, et al. Colonic cancer in a 34-yr-old woman: should it prompt microsatellite instability studies and mismatch repair gene testing?. Am J Gastroenterol. Oct. 1998;93(10):1991-2. Case report. [pmid: 9772075].
Coggins RP, Cawkwell L, Bell SM, Crockford GP, Quirke P, Finan PJ, et al. Association between family history and mismatch repair in colorectal cancer. Gut. May. 2005;54(5):636-42. Did not meet inclusion criteria. [pmid: 15831908]. [pmcid: 1774492].
Cravo M, Lage P, Albuquerque C, Chaves P, Claro I, Gomes T, et al. BAT-26 identifies sporadic colorectal cancers with mutator phenotype: a correlative study with clinico-pathological features and mutations in mismatch repair genes. J Pathol. Jul. 1999;188(3):252-7. Data not extractable. [pmid: 10419591].
Crijnen TE, Janssen-Heijnen ML, Gelderblom H, Morreau J, Nooij MA, Kenter GG, et al. Survival of patients with ovarian cancer due to a mismatch repair defect. Familial Cancer. 2005;4(4):301-5. Not relevant. [pmid: 16341807].
De Felice C, Parrini S, Chitano G, Gentile M, Dipaola L, Latini G. Fordyce granules and hereditary non-polyposis colorectal cancer syndrome. Gut. Sep. 2005;54(9):1279-82. Not population of interest. [pmid: 15879014]. [pmcid: 1774669].
de Jong AE, van Puijenbroek M, Hendriks Y, Tops C, Wijnen J, Ausems MG, et al. Microsatellite instability, immunohistochemistry, and additional PMS2 staining in suspected hereditary nonpolyposis colorectal cancer. Clin Cancer Res. Feb 1. 2004;10(3):972-80. hMLH1 and hMSH2 sequencing not performed. [pmid: 14871975].
de la CA. Testing tumors for microsatellite instability. Eur J Hum Genet. May. 1999;7(4):407-8. Review. [pmid: 10352929].
Dietmaier W, Hofstadter F. Detection of microsatellite instability by real time PCR and hybridization probe melting point analysis. Lab Invest. Oct. 2001;81(10):1453-6. Not relevant. [pmid: 11598157].
Dietmaier W, Wallinger S, Bocker T, Kullmann F, Fishel R, Ruschoff J. Diagnostic microsatellite instability: definition and correlation with mismatch repair protein expression. Cancer Res. Nov 1. 1997;57(21):4749-56. Incomplete data. [pmid: 9354436].
Domingo E, Laiho P, Ollikainen M, Pinto M, Wang L, French AJ, et al. BRAF screening as a low-cost effective strategy for simplifying HNPCC genetic testing. J Med Genet. Sep. 2004;41(9):664-8. hMLH1 and hMSH2 sequencing not performed. [pmid: 15342696]. [pmcid: 1735885].
Domingo E, Niessen RC, Oliveira C, Alhopuro P, Moutinho C, Espin E, et al. BRAF-V600E is not involved in the colorectal tumorigenesis of HNPCC in patients with functional MLH1 and MSH2 genes. Oncogene. Jun 2. 2005;24(24):3995-8. Not relevant, select patients. [pmid: 15782118].
Douglas JA, Gruber SB, Meister KA, Bonner J, Watson P, Krush AJ, et al. History and molecular genetics of Lynch syndrome in family G: a century later. Jama. 2005;294(17):2195-202. Case report. [pmid: 16264161].
Dovrat S, Figer A, Fidder HH, Neophytou P, Fireman Z, Geva R, et al. Mutational analysis of hMsh6 in Israeli HNPCC and HNPCC-like families. Familial Cancer. 2005;4(4):291-4. Genetic testing not compared with index test. [pmid: 16341805].
Drobinskaya I, Gabbert HE, Moeslein G, Mueller W. A new method for optimizing multiplex DNA microsatellite analysis in low quality archival specimens. Anticancer Res. Sep. 2005;25(5):3251-8. Genetic test not compared to index test. [pmid: 16101135].
Dunlop MG, Farrington SM, Carothers AD, Wyllie AH, Sharp L, Burn J, et al. Cancer risk associated with germline DNA mismatch repair gene mutations. Hum Mol Genet. 1997;6(1):105-10. Not relevant. [pmid: 9002677].
Dunlop MG, Farrington SM, Nicholl I, Aaltonen L, Petersen G, Porteous M, et al. Population carrier frequency of hMSH2 and hMLH1 mutations. Br J Cancer. Dec. 2000;83(12):1643-5. Not population of interest. [pmid: 11104559].
Eisen GM, Weinberg DS. Narrative review: screening for colorectal cancer in patients with a first-degree relative with colonic neoplasia. Ann Intern Med. 2005;143(3):190-8. Review. [pmid: 16061917].
Elsaleh H, Joseph D, Grieu F, Zeps N, Spry N, Iacopetta B. Association of tumour site and sex with survival benefit from adjuvant chemotherapy in colorectal cancer. Lancet. 2000;355(9217):1745-50. Not population of interest. [pmid: 10832824].
Engel C, Forberg J, Holinski-Feder E, Pagenstecher C, Plaschke J, Kloor M, et al. Novel strategy for optimal sequential application of clinical criteria, immunohistochemistry and microsatellite analysis in the diagnosis of hereditary nonpolyposis colorectal cancer. Int J Cancer. Jan 1. 2006;118(1):115-22. Not outcomes of interest. [pmid: 16003745].
Ensenauer RE, Michels VV, Reinke SS. Genetic testing: practical, ethical, and counseling considerations. Mayo Clin Proc. Jan. 2005;80(1):63-73. Not relevant. [pmid: 15667031].
Ericson K, Nilbert M, Bladstrom A, Anderson H, Olsson H, Planck M. Familial risk of tumors associated with hereditary non-polyposis colorectal cancer: a Swedish population-based study. Scand J Gastroenterol. Dec. 2004;39(12):1259-65. Not relevant. [pmid: 15743004].
Evans DG, Walsh S, Jeacock J, Robinson C, Hadfield L, Davies DR, et al. Incidence of hereditary non-polyposis colorectal cancer in a population-based study of 1137 consecutive cases of colorectal cancer. Br J Surg. Sep. 1997;84(9):1281-5. Genetic testing not compared with index test. [pmid: 9313714].
Fallik D, Borrini F, Boige V, Viguier J, Jacob S, Miquel C, et al. Microsatellite instability is a predictive factor of the tumor response to irinotecan in patients with advanced colorectal cancer. Cancer Res. Sep 15. 2003;63(18):5738-44. Not population of interest. [pmid: 14522894].
Faragher IG, Whitehead RH. Rapid diagnostic test for hereditary nonpolyposis colon cancer kindred using polymerase chain reaction. Dis Colon Rectum. Jul. 1998;41(7):938-40. Not relevant. [pmid: 9678385].
Fidalgo P, Almeida MR, West S, Gaspar C, Maia L, Wijnen J, et al. Detection of mutations in mismatch repair genes in Portuguese families with hereditary non-polyposis colorectal cancer (HNPCC) by a multi-method approach. Eur J Hum Genet. Jan. 2000;8(1):49-53. Unknown if patients had CRC. [pmid: 10713887].
Frazier ML, Sinicrope FA, Amos CI, Cleary KR, Lynch PM, Levin B, et al. Loci for efficient detection of microsatellite instability in hereditary non-polyposis colorectal cancer. Oncol Rep. May. 1999;6(3):497-505. Didn't report any of 5 options. [pmid: 10203581].
Froggatt NJ, Brassett C, Koch DJ, Evans DG, Hodgson SV, Ponder BA, et al. Mutation screening of MSH2 and MLH1 mRNA in hereditary non-polyposis colon cancer syndrome. J Med Genet. Sep. 1996;33(9):726-30. Data not extractable. [pmid: 8880570]. [pmcid: 1050724].
Furlan D, Tibiletti MG, Taborelli M, Albarello L, Cornaggia M, Capella C. The value of microsatellite instability in the detection of HNPCC families and of sporadic colorectal cancers with special biological features: an investigation on a series of 100 consecutive cases. Ann Oncol. Aug. 1998;9(8):901-6. No genetic testing. [pmid: 9789614].
Furukawa T, Konishi F, Shitoh K, Kojima M, Nagai H, Tsukamoto T. Evaluation of screening strategy for detecting hereditary nonpolyposis colorectal carcinoma. Cancer. Feb 15. 2002;94(4):911-20. Data not extractable. [pmid: 11920458].
Gaglia P, Atkin WS, Whitelaw S, Talbot IC, Williams CB, Northover JM, et al. Variables associated with the risk of colorectal adenomas in asymptomatic patients with a family history of colorectal cancer. Gut. Mar. 1995;36(3):385-90. Not population of interest. [pmid: 7698698]. [pmcid: 1382451].
Geirdal AO, Reichelt JG, Dahl AA, Heimdal K, Maehle L, Stormorken A, et al. Psychological distress in women at risk of hereditary breast/ovarian or HNPCC cancers in the absence of demonstrated mutations. Fam Cancer. 2005;4(2):121-6. Results of FBOC and HNPCC combined in analyses. [pmid: 15951962].
Genuardi M, Anti M, Capozzi E, Leonardi F, Fornasarig M, Novella E, et al. MLH1 and MSH2 constitutional mutations in colorectal cancer families not meeting the standard criteria for hereditary nonpolyposis colorectal cancer. Int J Cancer. Mar 16. 1998;75(6):835-9. Data not extractable. [pmid: 9506527].
Giardiello FM, Brensinger JD, Petersen GM. AGA technical review on hereditary colorectal cancer and genetic testing. Gastroenterology. 2001;121(1):198-213. Review. [pmid: 11438509].
Gill S, Lindor NM, Burgart LJ, Smalley R, Leontovich O, French AJ, et al. Isolated loss of PMS2 expression in colorectal cancers: frequency, patient age, and familial aggregation. Clin Cancer Res. Sep 15. 2005;11(18):6466-71. Genetic testing not compared with index test, hMLH1 and hMSH2 sequencing not performed. [pmid: 16166421].
Giraldo A, Gomez A, Salguero G, Garcia H, Aristizabal F, Gutierrez O, et al. MLH1 and MSH2 mutations in Colombian families with hereditary nonpolyposis colorectal cancer (Lynch syndrome)—description of four novel mutations. Familial Cancer. 2005;4(4):285-90. Not population of interest. [pmid: 16341804].
Gologan A, Krasinskas A, Hunt J, Thull DL, Farkas L, Sepulveda AR. Performance of the revised Bethesda guidelines for identification of colorectal carcinomas with a high level of microsatellite instability. Arch Pathol Lab Med. Nov. 2005;129(11):1390-7. Genetic testing not compared with index test, hMLH1 and hMSH2 sequencing not performed. [pmid: 16253017].
Grover S, Stoffel EM, Bussone L, Tschoegl E, Syngal S. Physician assessment of family cancer history and referral for genetic evaluation in colorectal cancer patients. Clin Gastroenterol Hepatol. 2004;2(9):813-9. Not relevant. [pmid: 15354282].
Gryfe R, Kim H, Hsieh ET, Aronson MD, Holowaty EJ, Bull SB, et al. Tumor microsatellite instability and clinical outcome in young patients with colorectal cancer. N Engl J Med. 2000;342(2):69-77. Not population of interest, hMLH1 and hMSH2 sequencing not performed. [pmid: 10631274].
Hall NR, Finan PJ, Ward B, Turner G, Bishop DT. Genetic susceptibility to colorectal cancer in patients under 45 years of age. Br J Surg. Oct. 1994;81(10):1485-9. Genetic testing not compared with index test, hMLH1 and hMSH2 sequencing not performed. [pmid: 7820480].
Halling KC, French AJ, McDonnell SK, Burgart LJ, Schaid DJ, Peterson BJ, et al. Microsatellite instability and 8p allelic imbalance in stage B2 and C colorectal cancers. J Natl Cancer Inst. 1999;91(15):1295-303. Not relevant. [pmid: 10433618].
Halvarsson B, Lindblom A, Johansson L, Lagerstedt K, Nilbert M. Loss of mismatch repair protein immunostaining in colorectal adenomas from patients with hereditary nonpolyposis colorectal cancer. Mod Pathol. Aug. 2005;18(8):1095-101. Not outcomes of interest. [pmid: 15731775].
Halvarsson B, Lindblom A, Rambech E, Lagerstedt K, Nilbert M. Microsatellite instability analysis and/or immunostaining for the diagnosis of hereditary nonpolyposis colorectal cancer?. Virchows Arch. Feb. 2004;444(2):135-41. ND on germline mutations. [pmid: 14652751].
Hamilton SR, Liu B, Parsons RE, Papadopoulos N, Jen J, Powell SM, et al. The molecular basis of Turcot's syndrome. N Engl J Med. Mar 30. 1995;332(13):839-47. Not population of interest. [pmid: 7661930].
Hampel H, Frankel WL, Martin E, Arnold M, Khanduja K, Kuebler P, et al. Screening for the Lynch syndrome (hereditary nonpolyposis colorectal cancer). N Engl J Med. 2005;352(18):1851-60. Not outcomes of interest. [pmid: 15872200].
Hatch SB, Lightfoot HM Jr, Garwacki CP, Moore DT, Calvo BF, Woosley JT, et al. Microsatellite instability testing in colorectal carcinoma: choice of markers affects sensitivity of detection of mismatch repair-deficient tumors. Clin Cancer Res. Mar 15. 2005;11(6):2180-7. Genetic test not compared to index test. [pmid: 15788665].
Hegde M, Blazo M, Chong B, Prior T, Richards C. Assay validation for identification of hereditary nonpolyposis colon cancer-causing mutations in mismatch repair genes MLH1, MSH2, and MSH6. J Mol Diagn. Oct. 2005;7(4):525-34. Didn't report any of 5 options. [pmid: 16237223]. [pmcid: 1888496].
Heinimann K, Scott RJ, Buerstedde JM, Weber W, Siebold K, Attenhofer M, et al. Influence of selection criteria on mutation detection in patients with hereditary nonpolyposis colorectal cancer. Cancer. Jun 15. 1999;85(12):2512-8. Not population of interest. [pmid: 10375096].
Hendriks YM, Jagmohan-Changur S, van der Klift HM, Morreau H, van PM, Tops C, et al. Heterozygous Mutations in PMS2 Cause Hereditary Nonpolyposis Colorectal Carcinoma (Lynch Syndrome). Gastroenterology. Feb. 2006;130(2):312-22. [pmid: 16472587].
Hitchins M, Williams R, Cheong K, Halani N, Lin VA, Packham D, et al. MLH1 germline epimutations as a factor in hereditary nonpolyposis colorectal cancer. Gastroenterology. Nov. 2005;129(5):1392-9. Genetic testing not compared with index test. [pmid: 16285940].
Ho JW, Yuen ST, Chung LP, Kwan KY, Chan TL, Leung SY, et al. Distinct clinical features associated with microsatellite instability in colorectal cancers of young patients. Int J Cancer. Jul 20. 2000;89(4):356-60. No data. [pmid: 10956410].
Hodgson SV, Harocopos C, Gaglia P. Screening results in a family cancer clinic: five years experience. Anticancer Res. Nov. 1993;13(6B):2581-5. [pmid: 8135498].
Huang D, Chen C, Sun W, Strom CM, Bender RA. High-throughput gene sequencing assay development for hereditary nonpolyposis colon cancer. Clin Colorectal Cancer. Nov. 2004;4(4):275-9. Unknown population. [pmid: 15555211].
Hurlstone DP, Karajeh M, Cross SS, McAlindon ME, Brown S, Hunter MD, et al. The role of high-magnification-chromoscopic colonoscopy in hereditary nonpolyposis colorectal cancer screening: a prospective “back-to-back” endoscopic study. Am J Gastroenterol. Oct. 2005;100(10):2167-73. Compares 2 methods of conducting colonsocopy in HNPCC patients on adenoma detection. [pmid: 16181364].
Hutter P, Couturier A, Membrez V, Joris F, Sappino AP, Chappuis PO. Excess of hMLH1 germline mutations in Swiss families with hereditary non-polyposis colorectal cancer. Int J Cancer. Dec 9. 1998;78(6):680-4. Not population of interest. [pmid: 9833759].
Iino H, Simms L, Young J, Arnold J, Winship IM, Webb SI, et al. DNA microsatellite instability and mismatch repair protein loss in adenomas presenting in hereditary non-polyposis colorectal cancer. Gut. Jul. 2000;47(1):37-42. Adenoma data. [pmid: 10861262]. [pmcid: 1727981].
Ikenaga M, Tomita N, Sekimoto M, Ohue M, Yamamoto H, Miyake Y, et al. Use of microsatellite analysis in young patients with colorectal cancer to identify those with hereditary nonpolyposis colorectal cancer. J Surg Oncol. Mar. 2002;79(3):157-65. hMLH1 and hMSH2 sequencing not performed; genetic testing not compared to index test. [pmid: 11870666].
Jass JR, Barker M, Fraser L, Walsh MD, Whitehall VL, Gabrielli B, et al. APC mutation and tumour budding in colorectal cancer. J Clin Pathol. Jan. 2003;56(1):69-73. No clinical endpoints. [pmid: 12499439]. [pmcid: 1769852].
Jass JR, Cottier DS, Jeevaratnam P, Pokos V, Holdaway KM, Bowden ML, et al. Diagnostic use of microsatellite instability in hereditary non-polyposis colorectal cancer. Lancet. 1995;346(8984):1200-1. Abstract. [pmid: 7475662].
Jemal A, Murray T, Ward E, Samuels A, Tiwari RC, Ghafoor A, et al. Cancer statistics, 2005. CA Cancer J Clin. 2005;55(1):10-30. Not relevant. [pmid: 15661684].
Jernvall P, Makinen MJ, Karttunen TJ, Makela J, Vihko P. Microsatellite instability: impact on cancer progression in proximal and distal colorectal cancers. Eur J Cancer. Feb. 1999;35(2):197-201. HNPCC not defined. [pmid: 10448259].
Jo WS, Bandipalliam P, Shannon KM, Niendorf KB, Chan-Smutko G, Hur C, et al. Correlation of Polyp Number and Family History of Colon Cancer With Germline MYH Mutations. Clin Gastroenterol Hepatol. 2005;3(10):1022-8. Not relevant. [pmid: 16234049].
Johns LE, Houlston RS. A systematic review and meta-analysis of familial colorectal cancer risk. Am J Gastroenterol. 2001;96(10):2992-3003. Review. [pmid: 11693338].
Johnson KA, Rosenblum-Vos L, Petersen GM, Brensinger JD, Giardiello FM, Griffin CA. Response to genetic counseling and testing for the APC I1307K mutation. Am J Med Genet. Mar 20. 2000;91(3):207-11. Not population of interest. [pmid: 10756345].
Johnson PM, Gallinger S, McLeod RS. Surveillance colonoscopy in individuals at risk for hereditary nonpolyposis colorectal cancer: an evidence-based review. Diseases of the Colon & Rectum. Jan. 2006;49(1):80-93. Review. [pmid: 16284887].
Jong A. Shift in mortality in Lynch syndrome families due to surveillance. In press 2006.
Jordan J, Evans G, Evers-Kiebooms G, Julian-Reynier C, Kash K, Watson M. Congress report of the seventh international meeting on psychosocial aspects of genetic testing for hereditary breast and/or ovarian cancer (HBOC) and hereditary non-polyposis colorectal cancer (HNPCC). Psychooncology. Nov. 2002;11(6):536-9. Meeting proceedings. [pmid: 12476435].
Jourdan F, Sebbagh N, Comperat E, Mourra N, Flahault A, Olschwang S, et al. Tissue microarray technology: validation in colorectal carcinoma and analysis of p53, hMLH1, and hMSH2 immunohistochemical expression. Virchows Arch. Aug. 2003;443(2):115-21. Genetic test not compared to index test. [pmid: 12802583].
Jover R, Paya A, Alenda C, Poveda MJ, Peiro G, Aranda FI, et al. Defective mismatch-repair colorectal cancer: clinicopathologic characteristics and usefulness of immunohistochemical analysis for diagnosis. Am J Clin Pathol. Sep. 2004;122(3):389-94. Genetic testing not compared with an index test. [pmid: 15362369].
Kakar S, Aksoy S, Burgart LJ, Smyrk TC. Mucinous carcinoma of the colon: correlation of loss of mismatch repair enzymes with clinicopathologic features and survival. Mod Pathol. Jun. 2004;17(6):696-700. Not population of interest. [pmid: 15017435].
Kanazawa T, Watanabe T, Kazama S, Tada T, Koketsu S, Nagawa H. Poorly differentiated adenocarcinoma and mucinous carcinoma of the colon and rectum show higher rates of loss of heterozygosity and loss of E-cadherin expression due to methylation of promoter region. Int J Cancer. Nov 20. 2002;102(3):225-9. Not relevant. [pmid: 12397640].
Kee F, Collins BJ, Patterson CC. Prognosis in familial non-polyposis colorectal cancer. Gut. May. 1991;32(5):513-6. HNPCC not defined. [pmid: 2040474]. [pmcid: 1378928].
Khurana V, Stollman N, Rogers AI. Colorectal cancer: predicting prognosis for patients and probands using immunohistochemistry. Am J Gastroenterol. Oct. 2000;95(10):2981-2. Not population of interest. [pmid: 11051382].
Kievit W, de Bruin JH, Adang EM, Ligtenberg MJ, Nagengast FM, van Krieken JH, et al. Current clinical selection strategies for identification of hereditary non-polyposis colorectal cancer families are inadequate: a meta-analysis. Clin Genet. Apr. 2004;65(4):308-16. Meta-analysis. [pmid: 15025724].
Kievit W, de Bruin JH, Adang EM, Severens JL, Kleibeuker JH, Sijmons RH, et al. Cost effectiveness of a new strategy to identify HNPCC patients. Gut. Jan. 2005;54(1):97-102. Not relevant. [pmid: 15591512]. [pmcid: 1774368].
Kim H, Piao Z, Kim JW, Choi JS, Kim NK, Lee JM, et al. Expression of hMSH2 and hMLH1 in colorectal carcinomas with microsatellite instability. Pathol Res Pract. 1998;194(1):3-9. hMLH1 and hMSH2 sequencing not performed. [pmid: 9542742].
Kim WH, Lee HW, Park SH, Kim YI, Chi JG. Microsatellite instability in young patients with colorectal cancer. Pathol Int. Aug. 1998;48(8):586-94. hMLH1 and hMSH2 sequencing not performed. [pmid: 9736405].
Kim YH, Song SY, Kwon YD, Kim DS, Chun HK, Rhee JC. Microsatellite instable double primary cancers of the colorectum and stomach exhibit less favorable outcome. World J Gastroenterol. Jul 14. 2005;11(26):3998-4002. Not population of interest. [pmid: 15996022].
Kinoshita M, Nakamura J, Kusaka H, Hadama T, Bago K, Kitajima M, et al. Automated and simultaneous identification of microsatellite instability by fluorescence-based polymerase chain reaction (PCR) in four loci. Clin Chim Acta. Jan. 1999;279(12):15-23. Not relevant. [pmid: 10064114].
Klaus K, Herfarth F, Ogunbiyi OA, Moley JF, Kodner IJ, Wells SA Jr, et al. Four new mutations in the DNA mismatch repair gene MLH1 in colorectal cancers with microsatellite instability. Mutations in brief no. 157. Online. Hum Mutat. 1998;12(1):73. hMLH1 and hMSH2 sequencing not performed. [pmid: 10627141].
Koehly LM, Peterson SK, Watts BG, Kempf KK, Vernon SW, Gritz ER. A social network analysis of communication about hereditary nonpolyposis colorectal cancer genetic testing and family functioning. Cancer Epidemiol Biomarkers Prev. Apr. 2003;12(4):304-13. Not direct data from screening. [pmid: 12692104].
Kohonen-Corish M, Ross VL, Doe WF, Kool DA, Edkins E, Faragher I, et al. RNA-based mutation screening in hereditary nonpolyposis colorectal cancer. Am J Hum Genet. Oct. 1996;59(4):818-24. Not relevant. [pmid: 8808596]. [pmcid: 1914793].
Koike J, Yamada K, Takano S, Kikuchi Y, Hemmi H, Koi M, et al. Undectable expression of hMLH1 protein in sporadic colorectal cancer with replication error phenotype. Dis Colon Rectum. Oct. 1997;40(10 Suppl):S23-S28. Not relevant. [pmid: 9378008].
Kolble K, Ullrich OM, Pidde H, Barthel B, Diermann J, Rudolph B, et al. Microsatellite alterations in serum DNA of patients with colorectal cancer. Lab Invest. Sep. 1999;79(9):1145-50. Not relevant. [pmid: 10496533].
Komesaroff PA, Greenberg P, Piterman L. Genetic testing: a round table conversation. Part I. Intern Med J. Jan. 2004;34(12):61-5. Not study. [pmid: 14748916].
Kondo E, Suzuki H, Horii A, Fukushige S. A yeast two-hybrid assay provides a simple way to evaluate the vast majority of hMLH1 germ-line mutations. Cancer Res. Jun 15. 2003;63(12):3302-8. Not relevant. [pmid: 12810663].
Koshiji M, Yonekura Y, Saito T, Yoshioka K. Microsatellite analysis of fecal DNA for colorectal cancer detection. J Surg Oncol. May. 2002;80(1):34-40. hMLH1 and hMSH2 sequencing not performed. [pmid: 11967905].
Kotake K, Koyama Y, Nasu J, Fukutomi T, Yamaguchi N. Relation of family history of cancer and environmental factors to the risk of colorectal cancer: a case-control study. Jpn J Clin Oncol. Oct. 1995;25(5):195-202. Not relevant. [pmid: 7474407].
Kouraklis G, Misiakos EP. Hereditary nonpolyposis colorectal cancer (Lynch syndrome): criteria for identification and management. Dig Dis Sci. Feb. 2005;50(2):336-44. Review. [pmid: 15745097].
Krajinovic M, Richer C, Labuda D, Sinnett D. Detection of a mutator phenotype in cancer cells by inter-Alu polymerase chain reaction. Cancer Res. Jun 15. 1996;56(12):2733-7. Not relevant. [pmid: 8665504].
Kruschewski M, Noske A, Haier J, Runkel N, Anagnostopoulos Y, Buhr HJ. Is reduced expression of mismatch repair genes MLH1 and MSH2 in patients with sporadic colorectal cancer related to their prognosis?. Clin Exp Metastasis. 2002;19(1):71-7. Not population of interest. [pmid: 11918085].
Lagarde AE, Stern HS. Genetic pre-disposition to colorectal cancer: Initiation of a prospective study in Eastern Ontario. Int J Cancer. Feb 20. 1996;69(1):68-70. No data. [pmid: 8600067].
Lage PA, Albuquerque C, Sousa RG, Cravo ML, Salazar M, Francisco I, et al. Association of colonic and endometrial carcinomas in Portuguese families with hereditary nonpolyposis colorectal carcinoma significantly increases the probability of detecting a pathogenic mutation in mismatch repair genes, primarily the MSH2 gene. Cancer. Jul 1. 2004;101(1):172-7. Family level reporting/not per proband. [pmid: 15222003].
Laiho P, Launonen V, Lahermo P, Esteller M, Guo M, Herman JG, et al. Low-level microsatellite instability in most colorectal carcinomas. Cancer Res. Feb 15. 2002;62(4):1166-70. hMLH1 and hMSH2 sequencing not performed. [pmid: 11861399].
Lanza G, Gafa R, Maestri I, Santini A, Matteuzzi M, Cavazzini L. Immunohistochemical pattern of MLH1/MSH2 expression is related to clinical and pathological features in colorectal adenocarcinomas with microsatellite instability. Mod Pathol. Jul. 2002;15(7):741-9. hMLH1 and hMSH2 sequencing not performed. [pmid: 12118112].
Leach FS, Polyak K, Burrell M, Johnson KA, Hill D, Dunlop MG, et al. Expression of the human mismatch repair gene hMSH2 in normal and neoplastic tissues. Cancer Res. Jan 15. 1996;56(2):235-40. Not relevant. [pmid: 8542572].
Lecomte T, Cellier C, Meatchi T, Barbier JP, Cugnenc PH, Jian R, et al. Chromoendoscopic Colonoscopy for Detecting Preneoplastic Lesions in Hereditary Nonpolyposis Colorectal Cancer Syndrome. Clin Gastroenterol Hepatol. 2005;3(9):897-902. Not relevant. [pmid: 16234028].
Lee JS, Petrelli NJ, Rodriguez-Bigas MA. Rectal cancer in hereditary nonpolyposis colorectal cancer. Am J Surg. Mar. 2001;181(3):207-10. No outcomes of interest. [pmid: 11376572].
Lerman C, Hughes C, Trock BJ, Myers RE, Main D, Bonney A, et al. Genetic testing in families with hereditary nonpolyposis colon cancer. Jama. May 5. 1999;281(17):1618-22. Not relevant. [pmid: 10235155].
Leung WK, To KF, Man EP, Chan MW, Bai AH, Hui AJ, et al. Quantitative detection of promoter hypermethylation in multiple genes in the serum of patients with colorectal cancer. Am J Gastroenterol. Oct. 2005;100(10):2274-9. Not relevant. [pmid: 16181380].
Li FP. Translational research on hereditary colon, breast, and ovarian cancers. J Natl Cancer Inst Monogr 1995;(17):1–4. Review
Liljegren A, Olsson L, Lindblom A. MSI test to distinguish between HNPCC and other predisposing syndromes — of value in tailored surveillance. Dis Markers. 2004;20(45):259-67. Review. [pmid: 15528791].
Liljestrom B, Aktan-Collan K, Isomaa B, Sarelin L, Uutela A, Groop L, et al. Genetic testing for maturity onset diabetes of the young: uptake, attitudes and comparison with hereditary non-polyposis colorectal cancer. Diabetologia. Feb. 2005;48(2):242-50. Diabetes focus & compared predictive testing to HNPCC. [pmid: 15660263].
Lin KM, Shashidharan M, Thorson AG, Ternent CA, Blatchford GJ, Christensen MA, et al. Cumulative incidence of colorectal and extracolonic cancers in MLH1 and MSH2 mutation carriers of hereditary nonpolyposis colorectal cancer. J Gastrointest Surg. Jan. 1998;2(1):67-71. Not relevant. [pmid: 9841970].
Lin X, Choi JH, Lynch P, Xi L, Wu E, Frazier ML. Reduction in hMSH2 mRNA levels by premature translation termination: implications for mutation screening in hereditary nonpolyposis colorectal cancer. Dig Dis Sci. Mar. 1999;44(3):553-9. Not relevant. [pmid: 10080150].
Lindor NM, Burgart LJ, Leontovich O, Goldberg RM, Cunningham JM, Sargent DJ, et al. Immunohistochemistry versus microsatellite instability testing in phenotyping colorectal tumors. J Clin Oncol. 2002;20(4):1043-8. Genetic testing not compared with an index test. [pmid: 11844828].
Lindor NM, Burgart LJ, Leontovich O, Goldberg RM, Cunningham JM, Sargent DJ, et al. Immunohistochemistry versus microsatellite instability testing in phenotyping colorectal tumors. J Clin Oncol. Feb 15. 2002;20(4):1043-8. Not relevant. [pmid: 11844828].
Lindor NM, Greene MH. The concise handbook of family cancer syndromes. Mayo Familial Cancer Program. J Natl Cancer Inst. 1998;90(14):1039-71. Not relevant. [pmid: 9672254].
Lindor NM, Rabe K, Petersen GM, Haile R, Casey G, Baron J, et al. Lower cancer incidence in Amsterdam-I criteria families without mismatch repair deficiency: familial colorectal cancer type X. Jama. 2005;293(16):1979-85. Not population of interest, hMLH1 and hMSH2 sequencing not performed. [pmid: 15855431].
Lipton LR, Johnson V, Cummings C, Fisher S, Risby P, Eftekhar Sadat AT, et al. Refining the Amsterdam Criteria and Bethesda Guidelines: testing algorithms for the prediction of mismatch repair mutation status in the familial cancer clinic. J Clin Oncol. Dec 15. 2004;22(24):4934-43. Data not extractable. [pmid: 15611508].
Liu B, Farrington SM, Petersen GM, Hamilton SR, Parsons R, Papadopoulos N, et al. Genetic instability occurs in the majority of young patients with colorectal cancer. Nat Med. Apr. 1995;1(4):348-52. Not population of interest. [pmid: 7585065].
Liu B, Parsons R, Papadopoulos N, Nicolaides NC, Lynch HT, Watson P, et al. Analysis of mismatch repair genes in hereditary non-polyposis colorectal cancer patients. Nat Med. Feb. 1996;2(2):169-74. Not population of interest. [pmid: 8574961].
Liu B, Parsons RE, Hamilton SR, Petersen GM, Lynch HT, Watson P, et al. hMSH2 mutations in hereditary nonpolyposis colorectal cancer kindreds. Cancer Res. Sep 1. 1994;54(17):4590-4. hMLH1 and hMSH2 sequencing not performed. [pmid: 8062247].
Liu HX, Zhou XL, Liu T, Werelius B, Lindmark G, Dahl N, et al. The role of hMLH3 in familial colorectal cancer. Cancer Res. Apr 15. 2003;63(8):1894-9. Not relevant. [pmid: 12702580].
Liu T, Tannergard P, Hackman P, Rubio C, Kressner U, Lindmark G, et al. Missense mutations in hMLH1 associated with colorectal cancer. Hum Genet. Nov. 1999;105(5):437-41. Not relevant. [pmid: 10598809].
Liu T, Wahlberg S, Burek E, Lindblom P, Rubio C, Lindblom A. Microsatellite instability as a predictor of a mutation in a DNA mismatch repair gene in familial colorectal cancer. Genes Chromosomes Cancer. Jan. 2000;27(1):17-25. Data not extractable. [pmid: 10564582].
Liu T, Wahlberg S, Rubio C, Holmberg E, Gronberg H, Lindblom A. DGGE screening of mutations in mismatch repair genes (hMSH2 and hMLH1) in 34 Swedish families with colorectal cancer. Clin Genet. Feb. 1998;53(2):131-5. Data not extractable. [pmid: 9611074].
Liu WH, Kaur M, Wang G, Zhu P, Zhang Y, Makrigiorgos GM. Inverse PCR-based RFLP scanning identifies low-level mutation signatures in colon cells and tumors. Cancer Res. Apr 1. 2004;64(7):2544-51. Not relevant. [pmid: 15059910].
Llor X, Pons E, Xicola RM, Castells A, Alenda C, Pinol V, et al. Differential features of colorectal cancers fulfilling Amsterdam criteria without involvement of the mutator pathway. Clin Cancer Res. 2005;11(20):7304-10. Genetic testing not compared with an index test; data not extractable. [pmid: 16243801].
Lorenzo BJ, Buchner FL, Hemminki K. Familial risk of endometrial cancer after exclusion of families that fulfilled Amsterdam, Japanese or Bethesda criteria for HNPCC. Ann Oncol. Apr. 2004;15(4):598-604. Not relevant. [pmid: 15033666].
Losi L, Di Gregorio C, Pedroni M, Ponti G, Roncucci L, Scarselli A, et al. Molecular genetic alterations and clinical features in early-onset colorectal carcinomas and their role for the recognition of hereditary cancer syndromes. Am J Gastroenterol. Oct. 2005;100(10):2280-7. Not all tested. [pmid: 16181381].
Losi L, Fante R, Di Gregorio C, Aisoni ML, Lanza G, Maestri I, et al. Biologic characterization of hereditary non-polyposis colorectal cancer. Nuclear ploidy, AgNOR count, microvessel distribution, oncogene expression, and grade-related parameters. Am J Clin Pathol. Mar. 1995;103(3):265-70. Not relevant. [pmid: 7532909].
Loukola A, de la CA, Aaltonen LA. Strategies for screening for hereditary non-polyposis colorectal cancer. J Med Genet. Nov. 1999;36(11):819-22. Data not extractable. [pmid: 10544224]. [pmcid: 1734266].
Loukola A, Eklin K, Laiho P, Salovaara R, Kristo P, Jarvinen H, et al. Microsatellite marker analysis in screening for hereditary nonpolyposis colorectal cancer (HNPCC). Cancer Res. Jun 1. 2001;61(11):4545-9. Data not extractable. [pmid: 11389088].
Loukola A, Salovaara R, Kristo P, Moisio AL, Kaariainen H, Ahtola H, et al. Microsatellite instability in adenomas as a marker for hereditary nonpolyposis colorectal cancer. Am J Pathol. Dec. 1999;155(6):1849-53. Not population of interest; hMLH1 and hMSH2 sequencing not performed. [pmid: 10595914]. [pmcid: 1866944].
Lu HK, Broaddus RR. Gynecologic Cancers in Lynch Syndrome/HNPCC. Fam Cancer. 2005;4(3):249-54. Review. [pmid: 16136386].
Lu KH, Dinh M, Kohlmann W, Watson P, Green J, Syngal S, et al. Gynecologic cancer as a “sentinel cancer” for women with hereditary nonpolyposis colorectal cancer syndrome. Obstet Gynecol. Mar. 2005;105(3):569-74. Not relevant. [pmid: 15738026].
Lu KH, Dinh M, Kohlmann W, Watson P, Green J, Syngal S, et al. Gynecologic cancer as a “sentinel cancer” for women with hereditary nonpolyposis colorectal cancer syndrome. Obstet Gynecol. 2005;105(3):569-74. Not relevant. [pmid: 15738026].
Lucci-Cordisco E, Rovella V, Carrara S, Percesepe A, Pedroni M, Bellacosa A, et al. Mutations of the ‘minor’ mismatch repair gene MSH6 in typical and atypical hereditary nonpolyposis colorectal cancer. Fam Cancer. 2001;1(2):93-9. hMLH1 and hMSH2 sequencing not performed. [pmid: 14574004].
Lucci-Cordisco E, Zollino M, Baglioni S, Mancuso I, Lecce R, Gurrieri F, et al. A novel microdeletion syndrome with loss of the MSH2 locus and hereditary non-polyposis colorectal cancer. Clin Genet. Feb. 2005;67(2):178-82. Case report. [pmid: 15679831].
Luce MC, Binnie CG, Cayouette MC, Kam-Morgan LN. Identification of DNA mismatch repair gene mutations in hereditary nonpolyposis colon cancer patients. Int J Cancer. Feb 20. 1996;69(1):50-2. Review. [pmid: 8600061].
Luo DC, Cai Q, Sun MH, Ni YZ, Ni SC, Chen ZJ, et al. Clinicopathological and molecular genetic analysis of HNPCC in China. World J Gastroenterol. Mar 21. 2005;11(11):1673-9. Not population of interest. [pmid: 15786548].
Lynch HT, Casey MJ, Lynch J, White TE, Godwin AK. Genetics and ovarian carcinoma. Semin Oncol. Jun. 1998;25(3):265-80. Review. [pmid: 9633840].
Lynch HT, Coronel SM, Okimoto R, Hampel H, Sweet K, Lynch JF, et al. A founder mutation of the MSH2 gene and hereditary nonpolyposis colorectal cancer in the United States. Jama. Feb 11. 2004;291(6):718-24. Not population of interest; hMLH1 and hMSH2 sequencing not performed. [pmid: 14871915].
Lynch HT, Kimberling W, Albano WA, Lynch JF, Biscone K, Schuelke GS, et al. Hereditary nonpolyposis colorectal cancer (Lynch syndromes I and II). I. Clinical description of resource. Cancer. Aug 15. 1985;56(4):934-8. Case report. [pmid: 4016685].
Lynch HT, Riley BD, Weissman SM, Coronel SM, Kinarsky Y, Lynch JF, et al. Hereditary nonpolyposis colorectal carcinoma (HNPCC) and HNPCC-like families: Problems in diagnosis, surveillance, and management. Cancer. 2004;100(1):53-64. Case series. [pmid: 14692024].
Lynch HT, Schuelke GS, Kimberling WJ, Albano WA, Lynch JF, Biscone KA, et al. Hereditary nonpolyposis colorectal cancer (Lynch syndromes I and II). II. Biomarker studies. Cancer. Aug 15. 1985;56(4):939-51. Not relevant. [pmid: 4016686].
Lynch HT, Shaw MW, Magnuson CW, Larsen AL, Krush AJ. Hereditary factors in cancer. Study of two large midwestern kindreds. Arch Intern Med. 1966;117(2):206-12. Case series. [pmid: 5901552].
Lynch J, Lynch HT. Genetic counseling and HNPCC. Anticancer Res. Jul. 1994;14(4B):1651-6. Review. [pmid: 7979202].
Machin P, Catasus L, Pons C, Munoz J, Conde-Zurita JM, Balmana J, et al. Microsatellite instability and immunostaining for MSH-2 and MLH-1 in cutaneous and internal tumors from patients with the Muir-Torre syndrome. J Cutan Pathol. Aug. 2002;29(7):415-20. Not population of interest. [pmid: 12139636].
Maekawa M, Sugano K, Kashiwabara H, Ushiama M, Fujita S, Yoshimori M, et al. DNA methylation analysis using bisulfite treatment and PCR-single-strand conformation polymorphism in colorectal cancer showing microsatellite instability. Biochem Biophys Res Commun. Sep 7. 1999;262(3):671-6. Biological material not evaluated. [pmid: 10471384].
Maekawa M, Sugano K, Ushiama M, Fukayama N, Nomoto K, Kashiwabara H, et al. Heterogeneity of DNA methylation status analyzed by bisulfite-PCR-SSCP and correlation with clinico-pathological characteristics in colorectal cancer. Clin Chem Lab Med. Feb. 2001;39(2):121-8. Genetic testing not compared with index test, hMLH1 and hMSH2 sequencing not performed. [pmid: 11341745].
Maier S, Dahlstroem C, Haefliger C, Plum A, Piepenbrock C. Identifying DNA methylation biomarkers of cancer drug response. Am J Pharmacogenomics. 2005;5(4):223-32. Review. [pmid: 16078859].
Maillet P, Chappuis PO, Vaudan G, Dobbie Z, Muller H, Hutter P, et al. A polymorphism in the ATM gene modulates the penetrance of hereditary non-polyposis colorectal cancer. Int J Cancer. Dec 15. 2000;88(6):928-31. Not population of interest. [pmid: 11093816].
Maliaka YK, Chudina AP, Belev NF, Alday P, Bochkov NP, Buerstedde JM. CpG dinucleotides in the hMSH2 and hMLH1 genes are hotspots for HNPCC mutations. Hum Genet. Feb. 1996;97(2):251-5. Genetic testing not compared with index test. [pmid: 8566964].
Manavis J, Gilham P, Davies R, Ruszkiewicz A. The immunohistochemical detection of mismatch repair gene proteins (MLH1, MSH2, MSH6, and PMS2): practical aspects in antigen retrieval and biotin blocking protocols. Appl Immunohistochem Mol Morphol. Mar. 2003;11(1):73-7. Biological material not evaluated. [pmid: 12610360].
Mangold E, Pagenstecher C, Friedl W, Fischer HP, Merkelbach-Bruse S, Ohlendorf M, et al. Tumours from MSH2 mutation carriers show loss of MSH2 expression but many tumours from MLH1 mutation carriers exhibit weak positive MLH1 staining. J Pathol. Dec. 2005;207(4):385-95. Didn't report any of 5 options. [pmid: 16216036].
Mangold E, Pagenstecher C, Friedl W, Mathiak M, Buettner R, Engel C, et al. Spectrum and frequencies of mutations in MSH2 and MLH1 identified in 1,721 German families suspected of hereditary nonpolyposis colorectal cancer. Int J Cancer. Sep 20. 2005;116(5):692-702. Not population of interest. [pmid: 15849733].
Marcus VA, Madlensky L, Gryfe R, Kim H, So K, Millar A, et al. Immunohistochemistry for hMLH1 and hMSH2: a practical test for DNA mismatch repair-deficient tumors. Am J Surg Pathol. Oct. 1999;23(10):1248-55. Not population of interest. [pmid: 10524526].
Maruyama A, Miyamoto S, Saito T, Kondo H, Baba H, Tsukamoto N. Clinicopathologic and familial characteristics of endometrial carcinoma with multiple primary carcinomas in relation to the loss of protein expression of MSH2 and MLH1. Cancer. Jun 1. 2001;91(11):2056-64. Not population of interest. [pmid: 11391585].
Maruyama A, Saito T, Hachitanda Y, Tsukamoto N. Cancer history and loss of MSH2 and MLH1 protein expression in patients with endometrial hyperplasia. Int J Gynecol Cancer. May. 2003;13(3):352-60. Not population of interest. [pmid: 12801268].
Mathiak M, Rutten A, Mangold E, Fischer HP, Ruzicka T, Friedl W, et al. Loss of DNA mismatch repair proteins in skin tumors from patients with Muir-Torre syndrome and MSH2 or MLH1 germline mutations: establishment of immunohistochemical analysis as a screening test. Am J Surg Pathol. Mar. 2002;26(3):338-43. Not population of interest. [pmid: 11859205].
Matloff ET, Shappell H, Brierley K, Bernhardt BA, McKinnon W, Peshkin BN. What would you do? Specialists' perspectives on cancer genetic testing, prophylactic surgery, and insurance discrimination. J Clin Oncol. Jun. 2000;18(12):2484-92. Not relevant-survey of genetic counselor's attitudes & prophylactic surgery. [pmid: 10856109].
Matsubara N, Yoshitaka T, Matsuno T, Ikeda M, Isozaki H, Tanaka N, et al. Multiple tumors and a novel E2F-4 mutation. A case report. Digestion. 2000;62(23):213-6. Case report. [pmid: 11025371].
Mauillon JL, Michel P, Limacher JM, Latouche JB, Dechelotte P, Charbonnier F, et al. Identification of novel germline hMLH1 mutations including a 22 kb Alu-mediated deletion in patients with familial colorectal cancer. Cancer Res. Dec 15. 1996;56(24):5728-33. hMLH1 and hMSH2 sequencing not performed. [pmid: 8971183].
Mayer F, Gillis AJ, Dinjens W, Oosterhuis JW, Bokemeyer C, Looijenga LH. Microsatellite instability of germ cell tumors is associated with resistance to systemic treatment. Cancer Res. May 15. 2002;62(10):2758-60. Not population of interest. [pmid: 12019150].
McAllister M. Personal theories of inheritance, coping strategies, risk perception and engagement in hereditary non-polyposis colon cancer families offered genetic testing. Clin Genet. Sep. 2003;64(3):179-89. Not relevant - methods paper. [pmid: 12919131].
McDaniel SH. The psychotherapy of genetics. Fam Process. Mar. 2005;44(1):25-44. Not relevant - background material. [pmid: 15807076].
McGrath SB, Bounpheng M, Torres L, Calavetta M, Scott CB, Suh Y, et al. High-speed, multicolor fluorescent two-dimensional gene scanning. Genomics. Nov. 2001;78(12):83-90. Biological material not evaluated. [pmid: 11707076].
McGregor DK, Wu TT, Rashid A, Luthra R, Hamilton SR. Reduced expression of cytokeratin 20 in colorectal carcinomas with high levels of microsatellite instability. Am J Surg Pathol. Jun. 2004;28(6):712-8. Didn't report any of 5 options. [pmid: 15166663].
Mecklin JP, Jarvinen HJ, Aukee S, Elomaa I, Karjalainen K. Screening for colorectal carcinoma in cancer family syndrome kindreds. Scand J Gastroenterol. May. 1987;22(4):449-53. Not relevant. [pmid: 3602925].
Mecklin JP, Jarvinen HJ. Tumor spectrum in cancer family syndrome (hereditary nonpolyposis colorectal cancer). Cancer. 1991;68(5):1109-12. Not relevant. [pmid: 1913482].
Mecklin JP. Frequency of hereditary colorectal carcinoma. Gastroenterology. 1987;93(5):1021-5. Not relevant. [pmid: 2820826].
Meiser B. Psychological impact of genetic testing for cancer susceptibility: an update of the literature. Psycho-Oncology. Dec. 2005;14(12):1060-74. Review. [pmid: 15937976].
Menigatti M, Di Gregorio C, Borghi F, Sala E, Scarselli A, Pedroni M, et al. Methylation pattern of different regions of the MLH1 promoter and silencing of gene expression in hereditary and sporadic colorectal cancer. Genes Chromosomes Cancer. Aug. 2001;31(4):357-61. Not relevant. [pmid: 11433526].
Michalopoulos NV, Saetta AA, Lazaris AC, Gigelou F, Koilakou S, Patsouris E. Microsatellite instability in sporadic and inherited colon adenocarcinomas from Greek patients: correlation with several clinicopathological characteristics. Acta Gastroenterol Belg. Jul. 2005;68(3):294-301. hMLH1 and hMSH2 sequencing not performed. [pmid: 16268414].
Millar AL, Pal T, Madlensky L, Sherman C, Temple L, Mitri A, et al. Mismatch repair gene defects contribute to the genetic basis of double primary cancers of the colorectum and endometrium. Hum Mol Genet. May. 1999;8(5):823-9. Data not extractable. [pmid: 10196371].
Miller M. Colorectal cancer: tackling the genetic aspects of the disease. J Natl Cancer Inst. Jul 15. 1998;90(14):1034-5. Not primary study. [pmid: 9672252].
Mitchell RJ, Farrington SM, Dunlop MG, Campbell H. Mismatch repair genes hMLH1 and hMSH2 and colorectal cancer: a HuGE review. Am J Epidemiol. Nov 15. 2002;156(10):885-902. Review. [pmid: 12419761].
Miyaki M, Iijima T, Yamaguchi T, Shirahama S, Ito T, Yasuno M, et al. Novel germline hMSH2 genomic deletion and somatic hMSH2 mutations in a hereditary nonpolyposis colorectal cancer family. Mutat Res. Apr 14. 2004;548(12):19-25. Not population of interest; hMLH1 and hMSH2 sequencing not performed. [pmid: 15063132].
Miyaki M, Konishi M, Muraoka M, Kikuchi-Yanoshita R, Tanaka K, Iwama T, et al. Germ line mutations of hMSH2 and hMLH1 genes in Japanese families with hereditary nonpolyposis colorectal cancer (HNPCC): usefulness of DNA analysis for screening and diagnosis of HNPCC patients. J Mol Med. Oct. 1995;73(10):515-20. Not population of interest. [pmid: 8581513].
Mori Y, Yin J, Sato F, Sterian A, Simms LA, Selaru FM, et al. Identification of genes uniquely involved in frequent microsatellite instability colon carcinogenesis by expression profiling combined with epigenetic scanning. Cancer Res. Apr 1. 2004;64(7):2434-8. Biological material not evaluated. [pmid: 15059896].
Moriyama H, Sasamoto H, Kambara T, Matsubara N, Ikeda M, Baba S, et al. E2F-4 mutation in hereditary non-polyposis colorectal cancer. J Exp Clin Cancer Res. Jun. 2002;21(2):185-9. hMLH1 and hMSH2 sequencing not performed. [pmid: 12148576].
Moslein G, Pistorius S, Saeger HD, Schackert HK. Preventive surgery for colon cancer in familial adenomatous polyposis and hereditary nonpolyposis colorectal cancer syndrome. Langenbecks Arch Surg. Mar. 2003;388(1):9-16. Review. [pmid: 12690475].
Moslein G. Clinical implications of molecular diagnosis in hereditary nonpolyposis colorectal cancer. Recent Results Cancer Res. 2003;162:73-8. Not primary study. [pmid: 12790322].
Muller A, Edmonston TB, Dietmaier W, Buttner R, Fishel R, Ruschoff J. MSI-testing in hereditary non-polyposis colorectal carcinoma (HNPCC). Dis Markers. 2004;20(45):225-36. Review. [pmid: 15528788].
Muller A, Giuffre G, Edmonston TB, Mathiak M, Roggendorf B, Heinmoller E, et al. Challenges and pitfalls in HNPCC screening by microsatellite analysis and immunohistochemistry. J Mol Diagn. Nov. 2004;6(4):308-15. Case report. [pmid: 15507669]. [pmcid: 1867493].
Muller A, Schackert HK, Lange B, Ruschoff J, Fuzesi L, Willert J, et al. A novel MSH2 germline mutation in homozygous state in two brothers with colorectal cancers diagnosed at the age of 11 and 12 years. American Journal of Medical Genetics. Feb 1. 2006;Part(3):195-9. Case report.
Muller-Koch Y, Kopp R, Lohse P, Baretton G, Stoetzer A, Aust D, et al. Sixteen rare sequence variants of the hMLH1 and hMSH2 genes found in a cohort of 254 suspected HNPCC (hereditary non-polyposis colorectal cancer) patients: mutations or polymorphisms?. Eur J Med Res. Nov 20. 2001;6(11):473-82. Genetic testing not compared with index test, hMLH1 and hMSH2 sequencing not performed. [pmid: 11726306].
Murff HJ, Spigel DR, Syngal S. Does this patient have a family history of cancer? An evidence-based analysis of the accuracy of family cancer history. Jama. 2004;292(12):1480-9. Not relevant. [pmid: 15383520].
Muta H, Noguchi M, Perucho M, Ushio K, Sugihara K, Ochiai A, et al. Clinical implications of microsatellite instability in colorectal cancers. Cancer. Jan 15. 1996;77(2):265-70. Genetic testing not compared with index test. [pmid: 8625233].
Nakagawa H, Hampel H, de la CA. Identification and characterization of genomic rearrangements of MSH2 and MLH1 in Lynch syndrome (HNPCC) by novel techniques. Hum Mutat. Sep. 2003;22(3):258. Biological material not evaluated. [pmid: 12938096].
Nakagawa H, Lockman JC, Frankel WL, Hampel H, Steenblock K, Burgart LJ, et al. Mismatch repair gene PMS2: disease-causing germline mutations are frequent in patients whose tumors stain negative for PMS2 protein, but paralogous genes obscure mutation detection and interpretation. Cancer Res. Jul 15. 2004;64(14):4721-7. Not relevant. [pmid: 15256438].
Nash GM, Gimbel M, Shia J, Culliford AT, Nathanson DR, Ndubuisi M, et al. Automated, multiplex assay for high-frequency microsatellite instability in colorectal cancer. J Clin Oncol. Aug 15. 2003;21(16):3105-12. Not relevant. [pmid: 12915601].
Nilbert M, Planck M, Fernebro E, Borg A, Johnson A. Microsatellite instability is rare in rectal carcinomas and signifies hereditary cancer. Eur J Cancer. Jun. 1999;35(6):942-5. Data not extractable. [pmid: 10533476].
Nomura S, Sugano K, Kashiwabara H, Taniguchi T, Fukayama N, Fujita S, et al. Enhanced detection of deleterious and other germline mutations of hMSH2 and hMLH1 in Japanese hereditary nonpolyposis colorectal cancer kindreds. Biochem Biophys Res Commun. Apr 29. 2000;271(1):120-9. Not relevant. [pmid: 10777691].
Nystrom-Lahti M, Kristo P, Nicolaides NC, Chang SY, Aaltonen LA, Moisio AL, et al. Founding mutations and Alu-mediated recombination in hereditary colon cancer. Nat Med. Nov. 1995;1(11):1203-6. Data not extractable. [pmid: 7584997].
Nystrom-Lahti M, Wu Y, Moisio AL, Hofstra RM, Osinga J, Mecklin JP, et al. DNA mismatch repair gene mutations in 55 kindreds with verified or putative hereditary non-polyposis colorectal cancer. Hum Mol Genet. Jun. 1996;5(6):763-9. Not population of interest. [pmid: 8776590].
Oliveira C, Westra JL, Arango D, Ollikainen M, Domingo E, Ferreira A, et al. Distinct patterns of KRAS mutations in colorectal carcinomas according to germline mismatch repair defects and hMLH1 methylation status. Hum Mol Genet. Oct 1. 2004;13(19):2303-11. Not population of interest. [pmid: 15294875].
Ollikainen M, Abdel-Rahman WM, Moisio AL, Lindroos A, Kariola R, Jarvela I, et al. Molecular analysis of familial endometrial carcinoma: a manifestation of hereditary nonpolyposis colorectal cancer or a separate syndrome?. J Clin Oncol. Jul 20. 2005;23(21):4609-16. Not population of interest. [pmid: 15837969].
Otway R, Tetlow N, Hornby J, Kohonen-Corish M. Evaluation of enzymatic mutation detectiontrade mark in hereditary nonpolyposis colorectal cancer. Hum Mutat. 2000;16(1):61-7. Not relevant. [pmid: 10874307].
Palmer CG, Hadley DW. Evaluating the impact of genetic counseling and testing with signal detection methods. J Genet Couns. Feb. 2005;14(1):17-27. Not relevant - methods paper. [pmid: 15789153].
Palmirotta R, Matera S, Curia MC, Aceto G, el Zhobi B, Verginelli F, et al. Correlations between phenotype and microsatellite instability in HNPCC: implications for genetic testing. Fam Cancer. 2004;3(2):117-21. Genetic testing not compared with index test. [pmid: 15340262].
Palmirotta R, Veri MC, Curia MC, Aceto G, D'Amico F, Esposito DL, et al. Transcripts with splicings of exons 15 and 16 of the hMLH1 gene in normal lymphocytes: implications in RNA-based mutation screening of hereditary non-polyposis colorectal cancer. Eur J Cancer. May. 1998;34(6):927-30. Not relevant. [pmid: 9797709].
Pan KF, Liu W, Lu YY, Zhang L, Li ZP, Lu WL, et al. High throughput detection of microsatellite instability by denaturing high-performance liquid chromatography. Hum Mutat. Nov. 2003;22(5):388-94. Not relevant. [pmid: 14517950].
Paraf F, Gilquin M, Longy M, Gilbert B, Gorry P, Petit B, et al. MLH1 and MSH2 protein immunohistochemistry is useful for detection of hereditary non-polyposis colorectal cancer in young patients. Histopathology. Sep. 2001;39(3):250-8. Not relevant. [pmid: 11532035].
Parc YR, Halling KC, Burgart LJ, McDonnell SK, Schaid DJ, Thibodeau SN, et al. Microsatellite instability and hMLH1/hMSH2 expression in young endometrial carcinoma patients: associations with family history and histopathology. Int J Cancer. Apr 1. 2000;86(1):60-6. Not population of interest. [pmid: 10728595].
Park JG, Park YJ, Wijnen JT, Vasen HF. Gene-environment interaction in hereditary nonpolyposis colorectal cancer with implications for diagnosis and genetic testing. Int J Cancer. Aug 12. 1999;82(4):516-9. hMLH1 and hMSH2 sequencing not performed. [pmid: 10404064].
Park JG, Vasen HF, Park YJ, Park KJ, Peltomaki P, de Leon MP, et al. Suspected HNPCC and Amsterdam criteria II: evaluation of mutation detection rate, an international collaborative study. Int J Colorectal Dis. Mar. 2002;17(2):109-14. Not population of interest. [pmid: 12014418].
Patten SJ, Wallace AJ, Elles R. Benchmark for evaluating the quality of DNA sequencing: proposal from an International External Quality Assessment Scheme. Clinical Chemistry. 2006;52(4):728-736. Biological material not evaluated. [pmid: 16455867].
Peltomaki P, Vasen H. Mutations associated with HNPCC predisposition — Update of ICG-HNPCC/INSiGHT mutation database. Dis Markers. 2004;20(45):269-76. Review. [pmid: 15528792].
Peltomaki P, Vasen HF. Mutations predisposing to hereditary nonpolyposis colorectal cancer: database and results of a collaborative study. The International Collaborative Group on Hereditary Nonpolyposis Colorectal Cancer. Gastroenterology. Oct. 1997;113(4):1146-58. Genetic testing not compared with index test. [pmid: 9322509].
Pensotti V, Radice P, Presciuttini S, Calistri D, Gazzoli I, Grimalt PA, et al. Mean age of tumor onset in hereditary nonpolyposis colorectal cancer (HNPCC) families correlates with the presence of mutations in DNA mismatch repair genes. Genes Chromosomes Cancer. Jul. 1997;19(3):135-42. Genetic testing not compared with index test. [pmid: 9218993].
Pentz RD, Peterson SK, Watts B, Vernon SW, Lynch PM, Koehly LM, et al. Hereditary Nonpolyposis Colorectal Cancer Family Members' Perceptions about the Duty to Inform and Health Professionals' Role in Disseminating Genetic Information. Genet Test. 2005;9(3):261-8. Not relevant. [pmid: 16225406].
Percesepe A, Borghi F, Menigatti M, Losi L, Foroni M, Di Gregorio C, et al. Molecular screening for hereditary nonpolyposis colorectal cancer: a prospective, population-based study. J Clin Oncol. Oct 1. 2001;19(19):3944-50. hMLH1 and hMSH2 sequencing not performed. [pmid: 11579115].
Percesepe A, Kristo P, Aaltonen LA, Ponz dL, de la CA, Peltomaki P. Mismatch repair genes and mononucleotide tracts as mutation targets in colorectal tumors with different degrees of microsatellite instability. Oncogene. Jul 16. 1998;17(2):157-63. Data not extractable. [pmid: 9674699].
Peterlongo P, Nafa K, Lerman GS, Glogowski E, Shia J, Ye TZ, et al. MSH6 germline mutations are rare in colorectal cancer families. Int J Cancer. Nov 20. 2003;107(4):571-9. hMLH1 and hMSH2 sequencing not performed, Data not extractable. [pmid: 14520694].
Pistorius SR, Nagel M, Kruger S, Plaschke J, Kruppa C, Wehrmann U, et al. Combined molecular and clinical approach for decision making for surgery in HNPCC patients: a report on three cases in two families. Int J Colorectal Dis. Nov. 2001;16(6):402-7. Case report. [pmid: 11760904].
Planck M, Koul A, Fernebro E, Borg A, Kristoffersson U, Olsson H, et al. hMLH1, hMSH2 and hMSH6 mutations in hereditary non-polyposis colorectal cancer families from southern Sweden. Int J Cancer. Oct 8. 1999;83(2):197-202. Data not extractable. [pmid: 10471527].
Planck M, Rambech E, Moslein G, Muller W, Olsson H, Nilbert M. High frequency of microsatellite instability and loss of mismatch-repair protein expression in patients with double primary tumors of the endometrium and colorectum. Cancer. May 1. 2002;94(9):2502-10. Data not extractable. [pmid: 12015776].
Plaschke J, Kruger S, Jeske B, Theissig F, Kreuz FR, Pistorius S, et al. Loss of MSH3 protein expression is frequent in MLH1-deficient colorectal cancer and is associated with disease progression. Cancer Res. Feb 1. 2004;64(3):864-70. Genetic testing not compared with index test. [pmid: 14871813].
Plaschke J, Kruger S, Pistorius S, Theissig F, Saeger HD, Schackert HK. Involvement of hMSH6 in the development of hereditary and sporadic colorectal cancer revealed by immunostaining is based on germline mutations, but rarely on somatic inactivation. Int J Cancer. Feb 10. 2002;97(5):643-8. Genetic testing not compared with index test. [pmid: 11807791].
Plaschke J, Kruppa C, Tischler R, Bocker T, Pistorius S, Dralle H, et al. Sequence analysis of the mismatch repair gene hMSH6 in the germline of patients with familial and sporadic colorectal cancer. Int J Cancer. Mar 1. 2000;85(5):606-13. hMLH1 and hMSH2 sequencing not performed. [pmid: 10699937].
Plaschke J, Ruschoff J, Schackert HK. Genomic rearrangements of hMSH6 contribute to the genetic predisposition in suspected hereditary non-polyposis colorectal cancer syndrome. J Med Genet. Aug. 2003;40(8):597-600. hMLH1 and hMSH2 sequencing not performed. [pmid: 12920072]. [pmcid: 1735570].
Plevova P, Krepelova A, Papezova M, Sedlakova E, Curik R, Foretova L, et al. Immunohistochemical detection of the hMLH1 and hMSH2 proteins in hereditary non-polyposis colon cancer and sporadic colon cancer. Neoplasma. 2004;51(4):275-84. Not population of interest. [pmid: 15254659].
Ponz dL, Benatti P, Borghi F, Pedroni M, Scarselli A, Di Gregorio C, et al. Aetiology of colorectal cancer and relevance of monogenic inheritance. Gut. Jan. 2004;53(1):115-22. Patients reported in Ponz 1999, data not extractable. [pmid: 14684585]. [pmcid: 1773932].
Ponz dL, Benatti P, Percesepe A, Rossi G, Viel A, Santarosa M, et al. Clinical and molecular diagnosis of hereditary non-polyposis colorectal cancer: problems and pitfalls in an extended pedigree. Ital J Gastroenterol Hepatol. Aug. 1999;31(6):476-80. Genetic testing not compared with index test. [pmid: 10575566].
Popat S, Hubner R, Houlston RS. Systematic review of microsatellite instability and colorectal cancer prognosis. J Clin Oncol. 2005;23(3):609-18. Review. [pmid: 15659508].
Potocnik U, Glavac D, Golouh R, Ravnik-Glavac M. Causes of microsatellite instability in colorectal tumors: implications for hereditary non-polyposis colorectal cancer screening. Cancer Genet Cytogenet. Apr 15. 2001;126(2):85-96. Data not extractable. [pmid: 11376800].
Pucciarelli S, Agostini M, Viel A, Bertorelle R, Russo V, Toppan P, et al. Early-age-at-onset colorectal cancer and microsatellite instability as markers of hereditary nonpolyposis colorectal cancer. Dis Colon Rectum. Mar. 2003;46(3):305-12. Data not extractable. [pmid: 12626904].
Quaresima B, Grandinetti C, Baudi F, Tassone P, Barbieri V, Conforti S, et al. Hereditary nonpolyposis coloretal cancer: identification of novel germline mutations in two kindreds not fulfulling the Amsterdam criteria. Mutations in brief no. 203. Online. Hum Mutat. 1998;12(6):433. Meeting abstract.
Raedle J, Brieger A, Trojan J, Hardt T, Herrmann G, Zeuzem S. Evaluation of rapid microsatellite analysis of paraffin-embedded specimens in screening for hereditary nonpolyposis colorectal cancer. Mod Pathol. May. 1999;12(5):485-91. Not relevant. [pmid: 10349986].
Raedle J, Schaffner M, Esser N, Sahm S, Trojan J, Kriener S, et al. Frequency of the Amsterdam criteria in a regional German cohort of patients with colorectal cancer. Z Gastroenterol. Aug. 2002;40(8):561-8. Patients reported in Raedle 2001. [pmid: 12297979].
Raevaara TE, Korhonen MK, Lohi H, Hampel H, Lynch E, Lonnqvist KE, et al. Functional significance and clinical phenotype of nontruncating mismatch repair variants of MLH1. Gastroenterology. 2005;129(2):537-49. Not population of interest, genetic testing not compared with an index test. [pmid: 16083711].
Rajkumar T, Soumittra N, Pandey D, Nancy KN, Mahajan V, Majhi U. Mutation analysis of hMSH2 and hMLH1 in colorectal cancer patients in India. Genet Test. 2004;8(2):157-62. Data not extractable. [pmid: 15345113].
Ramsey SD, Burke W, Clarke L. An economic viewpoint on alternative strategies for identifying persons with hereditary nonpolyposis colorectal cancer. Genet Med. Sep. 2003;5(5):353-63. Not relevant. [pmid: 14501830].
Ramsey SD, Clarke L, Etzioni R, Higashi M, Berry K, Urban N. Cost-effectiveness of microsatellite instability screening as a method for detecting hereditary nonpolyposis colorectal cancer. Ann Intern Med. 2001;135(8 Pt 1):577-88. Not relevant. [pmid: 11601929].
Ramsey SD, Clarke L, Etzioni R, Higashi M, Berry K, Urban N. Cost-effectiveness of microsatellite instability screening as a method for detecting hereditary nonpolyposis colorectal cancer. Ann Intern Med. Oct 16. 2001;135(8 Pt 1):577-88. Not relevant - Cost-effectiveness study. [pmid: 11601929].
Ravnik-Glavac M, Potocnik U, Glavac D. Incidence of germline hMLH1 and hMSH2 mutations (HNPCC patients) among newly diagnosed colorectal cancers in a Slovenian population. Journal of Medical Genetics. Jul. 2000;37(7):533-6. Genetic testing not compared with index test. [pmid: 10970186]. [pmcid: 1734642].
Renkonen E, Zhang Y, Lohi H, Salovaara R, Abdel-Rahman WM, Nilbert M, et al. Altered expression of MLH1, MSH2, and MSH6 in predisposition to hereditary nonpolyposis colorectal cancer. J Clin Oncol. 2003;21(19):3629-37. Not population of interest, genetic testing not compared with an index test. [pmid: 14512394].
Reyes CM, Allen BA, Terdiman JP, Wilson LS. Comparison of selection strategies for genetic testing of patients with hereditary nonpolyposis colorectal carcinoma: effectiveness and cost-effectiveness. Cancer. Nov 1. 2002;95(9):1848-56. Comparison of selection. [pmid: 12404277].
Ribic CM, Sargent DJ, Moore MJ, Thibodeau SN, French AJ, Goldberg RM, et al. Tumor microsatellite-instability status as a predictor of benefit from fluorouracil-based adjuvant chemotherapy for colon cancer.[see comment]. New England Journal of Medicine. Jul 17. 2003;349(3):247-57. Population not well defined. [pmid: 12867608].
Riegler G, Savastano A, Selvaggi F, Ciociano R, Martino R, Riccio G, et al. Prevalence of HNPCC in a series of consecutive patients on the first endoscopic diagnosis of colorectal cancer: a multicenter study. The Italian Collaborative Group. Endoscopy. Jun. 1999;31(5):337-41. Not relevant. [pmid: 10433040].
Rigau V, Sebbagh N, Olschwang S, Paraf F, Mourra N, Parc Y, et al. Microsatellite instability in colorectal carcinoma. The comparison of immunohistochemistry and molecular biology suggests a role for hMSH6 [correction of hMLH6] immunostaining. Arch Pathol Lab Med. Jun. 2003;127(6):694-700. hMLH1 and hMSH2 sequencing not performed. [pmid: 12741892].
Rijcken FE, Mourits MJ, Kleibeuker JH, Hollema H, van der Zee AG. Gynecologic screening in hereditary nonpolyposis colorectal cancer. Gynecol Oncol. 2003;91(1):74-80. Not relevant. [pmid: 14529665].
Ripa RS, Katballe N, Wikman FP, Jager AC, Bernstein I, Orntoft T, et al. Presymptomatic diagnosis using a deletion of a single codon in families with hereditary non-polyposis colorectal cancer. Mutat Res. Feb 15. 2005;570(1):89-96. Genetic testing not compared with index test. [pmid: 15680406].
Rodriguez-Bigas MA, Boland CR, Hamilton SR, Henson DE, Jass JR, Khan PM, et al. A National Cancer Institute Workshop on Hereditary Nonpolyposis Colorectal Cancer Syndrome: meeting highlights and Bethesda guidelines. J Natl Cancer Inst. 1997;89(23):1758-62. Meeting paper. [pmid: 9392616].
Rubin SC, Blackwood MA, Bandera C, Behbakht K, Benjamin I, Rebbeck TR, et al. BRCA1, BRCA2, and hereditary nonpolyposis colorectal cancer gene mutations in an unselected ovarian cancer population: relationship to family history and implications for genetic testing. Am J Obstet Gynecol. Apr. 1998;178(4):670-7. Not population of interest. [pmid: 9579428].
Ruszkiewicz A, Bennett G, Moore J, Manavis J, Rudzki B, Shen L, et al. Correlation of mismatch repair genes immunohistochemistry and microsatellite instability status in HNPCC-associated tumours. Pathology. Dec. 2002;34(6):541-7. Genetic testing not compared with index test. [pmid: 12555992].
Salahshor S, Kressner U, Fischer H, Lindmark G, Glimelius B, Pahlman L, et al. Microsatellite instability in sporadic colorectal cancer is not an independent prognostic factor. Br J Cancer. Sep. 1999;81(2):190-3. Not population of interest. [pmid: 10496341].
Salvesen HB, MacDonald N, Ryan A, Iversen OE, Jacobs IJ, Akslen LA, et al. Methylation of hMLH1 in a population-based series of endometrial carcinomas. Clin Cancer Res. Sep. 2000;6(9):3607-13. Not relevant. [pmid: 10999752].
Sarroca C, Valle AD, Fresco R, Renkonen E, Peltomaki P, Lynch H. Frequency of hereditary non-polyposis colorectal cancer among Uruguayan patients with colorectal cancer. Clin Genet. Jul. 2005;68(1):80-7. Data not extractable. [pmid: 15952990].
Sasaki S, Tokino T, Miyatsu T, Muto T, Nakamura Y. Mutational analysis of the hMLH1 gene using an automated two-dimensional DNA typing system. Hum Mutat. 1997;9(2):164-71. Not relevant. [pmid: 9067757].
Scapoli C, Ponz De Leon M, Sassatelli R, Benatti P, Roncucci L, Collins A, et al. Genetic epidemiology of hereditary non-polyposis colorectal cancer syndromes in Modena, Italy: results of a complex segregation analysis. Ann Hum Genet. 1994;58(Pt 3):275-95. Not relevant. [pmid: 7872650].
Scartozzi M, Bianchi F, Rosati S, Galizia E, Antolini A, Loretelli C, et al. Mutations of hMLH1 and hMSH2 in patients with suspected hereditary nonpolyposis colorectal cancer: correlation with microsatellite instability and abnormalities of mismatch repair protein expression. J Clin Oncol. Mar 1. 2002;20(5):1203-8. Not population of interest. [pmid: 11870161].
Schiemann U, Muller-Koch Y, Gross M, Daum J, Lohse P, Baretton G, et al. Extended microsatellite analysis in microsatellite stable, MSH2 and MLH1 mutation-negative HNPCC patients: genetic reclassification and correlation with clinical features. Digestion. 2004;69(3):166-76. Data not extractable. [pmid: 15118395].
Schiemann U, Muller-Koch Y, Gross M, Glas J, Baretton G, Muders M, et al. Detection of occult high graded microsatellite instabilities in MMR gene mutation negative HNPCC tumors by addition of complementary marker analysis. Eur J Med Res. Jan 28. 2005;10(1):23-8. Population not well defined. [pmid: 15737950].
Schlegel J, Bocker T, Zirngibl H, Hofstadter F, Ruschoff J. Detection of microsatellite instability in human colorectal carcinomas using a non-radioactive PCR-based screening technique. Virchows Arch. 1995;426(3):223-7. Not relevant. [pmid: 7773500].
Schulmann K, Brasch FE, Kunstmann E, Engel C, Pagenstecher C, Vogelsang H, et al. HNPCC-associated small bowel cancer: clinical and molecular characteristics. Gastroenterology. 2005;128(3):590-9. Not outcomes of interest. [pmid: 15765394].
Schweizer P, Moisio AL, Kuismanen SA, Truninger K, Vierumaki R, Salovaara R, et al. Lack of MSH2 and MSH6 characterizes endometrial but not colon carcinomas in hereditary nonpolyposis colorectal cancer. Cancer Res. Apr 1. 2001;61(7):2813-5. Mixed population. [pmid: 11306449].
Shia J, Ellis NA, Paty PB, Nash GM, Qin J, Offit K, et al. Value of histopathology in predicting microsatellite instability in hereditary nonpolyposis colorectal cancer and sporadic colorectal cancer. Am J Surg Pathol. Nov. 2003;27(11):1407-17. Not relevant. [pmid: 14576473].
Shin YK, Heo SC, Shin JH, Hong SH, Ku JL, Yoo BC, et al. Germline mutations in MLH1, MSH2 and MSH6 in Korean hereditary non-polyposis colorectal cancer families. Hum Mutat. Oct. 2004;24(4):351. Unclear whether genetic testing compared with index test. [pmid: 15365995].
Singer G, Kallinowski T, Hartmann A, Dietmaier W, Wild PJ, Schraml P, et al. Different types of microsatellite instability in ovarian carcinoma. Int J Cancer. Nov 20. 2004;112(4):643-6. Not population of interest, genetic test not compared to index test. [pmid: 15382045].
Sinicrope FA, Lemoine M, Xi L, Lynch PM, Cleary KR, Shen Y, et al. Reduced expression of cyclooxygenase 2 proteins in hereditary nonpolyposis colorectal cancers relative to sporadic cancers. Gastroenterology. Aug. 1999;117(2):350-8. Not relevant. [pmid: 10419916].
Smyth EF, Sharma A, Sivarajasingham N, Hartley J, Monson JR, Cawkwell L. Prognostic implications of hMLH1 and p53 immunohistochemical status in right-sided colon cancer. Dis Colon Rectum. Dec. 2004;47(12):2086-91. Genetic testing not compared with index test. [pmid: 15657659].
Soliman PT, Broaddus RR, Schmeler KM, Daniels MS, Gonzalez D, Slomovitz BM, et al. Women with synchronous primary cancers of the endometrium and ovary: do they have Lynch syndrome?. Journal of Clinical Oncology. Dec 20. 2005;23(36):9344-50. Not population of interest. [pmid: 16361634].
Solomon CH, Pho LN, Burt RW. Current status of genetic testing for colorectal cancer susceptibility. Oncology (Williston Park). Feb. 2002;16(2):161-71. Review. [pmid: 11866134].
Stanley AJ, Gaff CL, Aittomaki AK, Fabre LC, Macrae FA, St John J. Value of predictive genetic testing in management of hereditary non-polyposis colorectal cancer (HNPCC). Med J Aust. Apr 3. 2000;172(7):313-6. Case report. [pmid: 10844916].
Stone JG, Robertson D, Houlston RS. Immunohistochemistry for MSH2 and MHL1: a method for identifying mismatch repair deficient colorectal cancer. J Clin Pathol. Jun. 2001;54(6):484-7. Data not extractable. [pmid: 11376026]. [pmcid: 1731447].
Stone JG, Tomlinson IP, Houlston RS. Optimising methods for determining RER status in colorectal cancers. Cancer Lett. Feb 28. 2000;149(12):15-20. Didn't report any of 5 options. [pmid: 10737703].
Stormorken AT, Bowitz-Lothe IM, Noren T, Kure E, Aase S, Wijnen J, et al. Immunohistochemistry identifies carriers of mismatch repair gene defects causing hereditary nonpolyposis colorectal cancer. J Clin Oncol. Jul 20. 2005;23(21):4705-12. Data not extractable. [pmid: 16034045].
Stormorken AT, Hoff G, Norstein J, Bowitz-Lothe IM, Hanslien E, Grindedal E, et al. Estimated prevalence of hereditary cancers and the need for surveillance in a Norwegian county, Telemark. Scandinavian Journal of Gastroenterology. Jan. 2006;41(1):71-9. Not population of interest. [pmid: 16373279].
Sutter C, Dallenbach-Hellweg G, Schmidt D, Baehring J, Bielau S, von Knebel DM, et al. Molecular analysis of endometrial hyperplasia in HNPCC-suspicious patients may predict progression to endometrial carcinoma. Int J Gynecol Pathol. Jan. 2004;23(1):18-25. Not population of interest. [pmid: 14668545].
Sutter C, Gebert J, Bischoff P, Herfarth C, von Knebel DM. Molecular screening of potential HNPCC patients using a multiplex microsatellite PCR system. Mol Cell Probes. Apr. 1999;13(2):157-65. Didn't report any of 5 options. [pmid: 10208807].
Syngal S, Weeks JC, Schrag D, Garber JE, Kuntz KM. Benefits of colonoscopic surveillance and prophylactic colectomy in patients with hereditary nonpolyposis colorectal cancer mutations. Ann Intern Med. 1998;129(10):787-96. Not relevant. [pmid: 9841584].
Talseth BA, Meldrum C, Suchy J, Kurzawski G, Lubinski J, Scott RJ. Age of diagnosis of colorectal cancer in HNPCC patients is more complex than that predicted by R72P polymorphism in TP53. International Journal of Cancer. May 15. 2006;118(10):2479-84. Genetic testing not compared with index test.
Tannergard P, Lipford JR, Kolodner R, Frodin JE, Nordenskjold M, Lindblom A. Mutation screening in the hMLH1 gene in Swedish hereditary nonpolyposis colon cancer families. Cancer Res. Dec 15. 1995;55(24):6092-6. Supplemental to Wahlberg 1997. [pmid: 8521398].
Terdiman JP. It is time to get serious about diagnosing Lynch syndrome (hereditary nonpolyposis colorectal cancer with defective DNA mismatch repair) in the general population. Gastroenterology. 2005;129(2):741-4. Editorial. [pmid: 16083727].
Tiller K, Meiser B, Gould L, Tucker K, Dudding T, Franklin J, et al. Knowledge of risk management strategies, and information and risk management preferences of women at increased risk for ovarian cancer. Psychooncology. Apr. 2005;14(4):249-61. Not relevant. [pmid: 15386771].
Tokudome S, Yokoyama Y, Kamiya T, Seno K, Okuyama H, Kuriki K, et al. Rationale and study design of dietary intervention in patients polypectomized for tumors of the colorectum. Jpn J Clin Oncol. Dec. 2002;32(12):550-3. Not relevant. [pmid: 12578906].
Trimbath JD, Petersen GM, Erdman SH, Ferre M, Luce MC, Giardiello FM. Cafe-au-lait spots and early onset colorectal neoplasia: a variant of HNPCC?. Fam Cancer. 2001;1(2):101-5. Not relevant. [pmid: 14574005].
Trojan J, Raedle J, Herrmann G, Brieger A, Zeuzem S. Detection of microsatellite instability from archival, hematoxylin-eosin-stained colorectal cancer specimen. Arch Pathol Lab Med. Feb. 2002;126(2):202-4. Case report. [pmid: 11825119].
Truninger K, Menigatti M, Luz J, Russell A, Haider R, Gebbers JO, et al. Immunohistochemical analysis reveals high frequency of PMS2 defects in colorectal cancer. Gastroenterology. May. 2005;128(5):1160-71. Not population of interest. [pmid: 15887099].
Umar A, Boland CR, Terdiman JP, Syngal S, De La Chapelle A, Ruschoff J, et al. Revised Bethesda Guidelines for hereditary nonpolyposis colorectal cancer (Lynch syndrome) and microsatellite instability. J Natl Cancer Inst. 2004;96(4):261-8. Not relevant. [pmid: 14970275].
Uy GB, Kaw LL, Punzalan CK, Querol RI, Koustova EV, Bowyer MW, et al. Clinical and molecular biologic characteristics of early-onset versus late-onset colorectal carcinoma in Filipinos. World J Surg. Feb. 2004;28(2):117-23. hMLH1 and hMSH2 sequencing not performed. [pmid: 14708047].
van der KH, Wijnen J, Wagner A, Verkuilen P, Tops C, Otway R, et al. Molecular characterization of the spectrum of genomic deletions in the mismatch repair genes MSH2, MLH1, MSH6, and PMS2 responsible for hereditary nonpolyposis colorectal cancer (HNPCC). Genes Chromosomes Cancer. Oct. 2005;44(2):123-38. Biological material not evaluated, didn't report any of 5 options. [pmid: 15942939].
Vasen HF, Hartog Jager FC, Menko FH, Nagengast FM. Screening for hereditary non-polyposis colorectal cancer: a study of 22 kindreds in The Netherlands. Am J Med. Mar. 1989;86(3):278-81. Reports only adenoma data. [pmid: 2919609].
Vasen HF, Mecklin JP, Khan PM, Lynch HT. The International Collaborative Group on Hereditary Non-Polyposis Colorectal Cancer (ICG-HNPCC). Dis Colon Rectum. May. 1991;34(5):424-5. Not relevant. [pmid: 2022152].
Vasen HF, Mecklin JP, Khan PM, Lynch HT. The International Collaborative Group on HNPCC. Anticancer Res. Jul. 1994;14(4B):1661-4. Review. [pmid: 7979204].
Vasen HF, Mecklin JP, Watson P, Utsunomiya J, Bertario L, Lynch P, et al. Surveillance in hereditary nonpolyposis colorectal cancer: an international cooperative study of 165 families. The International Collaborative Group on HNPCC. Dis Colon Rectum. Jan. 1993;36(1):1-4. Not relevant.
Vasen HF, Offerhaus GJ, Hartog Jager FC, Menko FH, Nagengast FM, Griffioen G, et al. The tumour spectrum in hereditary non-polyposis colorectal cancer: a study of 24 kindreds in the Netherlands. Int J Cancer. Jul 15. 1990;46(1):31-4. No benefit and harms data. [pmid: 2365499].
Vasen HF, Taal BG, Griffioen G, Nagengast FM, Cats A, Menko FH, et al. Clinical heterogeneity of familial colorectal cancer and its influence on screening protocols. Gut. Sep. 1994;35(9):1262-6. Not outcomes of interest. [pmid: 7959234]. [pmcid: 1375704].
Vasen HF, Watson P, Mecklin JP, Lynch HT. New clinical criteria for hereditary nonpolyposis colorectal cancer (HNPCC, Lynch syndrome) proposed by the International Collaborative group on HNPCC. Gastroenterology. 1999;116(6):1453-6. Not primary study. [pmid: 10348829].
Vasen HF, Wijnen JT, Menko FH, Kleibeuker JH, Taal BG, Griffioen G, et al. Cancer risk in families with hereditary nonpolyposis colorectal cancer diagnosed by mutation analysis. Gastroenterology. 1996;110(4):1020-7. Not relevant. [pmid: 8612988].
Velayos FS, Allen BA, Conrad PG, Gum J Jr, Kakar S, Chung DC, et al. Low rate of microsatellite instability in young patients with adenomas: reassessing the Bethesda guidelines. Am J Gastroenterol. May. 2005;100(5):1143-9. Not population of interest. [pmid: 15842591].
Velayos FS, Lee SH, Qiu H, Dykes S, Yiu R, Terdiman JP, et al. The mechanism of microsatellite instability is different in synchronous and metachronous colorectal cancer. J Gastrointest Surg. Mar. 2005;9(3):329-35. Genetic testing not compared with index test. [pmid: 15749592].
Verma L, Kane MF, Brassett C, Schmeits J, Evans DG, Kolodner RD, et al. Mononucleotide microsatellite instability and germline MSH6 mutation analysis in early onset colorectal cancer. J Med Genet. Sep. 1999;36(9):678-82. hMLH1 and hMSH2 sequencing not performed; genetic testing not compared to index test. [pmid: 10507723]. [pmcid: 1734424].
Vernon SW, Gritz ER, Peterson SK, Amos CI, Perz CA, Baile WF, et al. Correlates of psychologic distress in colorectal cancer patients undergoing genetic testing for hereditary colon cancer. Health Psychol. Jan. 1997;16(1):73-86. Not relevant. [pmid: 9028817].
Vernon SW, Gritz ER, Peterson SK, Perz CA, Marani S, Amos CI, et al. Intention to learn results of genetic testing for hereditary colon cancer. Cancer Epidemiol Biomarkers Prev. Apr. 1999;8(4 Pt 2):353-60. Not relevant. [pmid: 10207640].
Viel A, Genuardi M, Capozzi E, Leonardi F, Bellacosa A, Paravatou-Petsotas M, et al. Characterization of MSH2 and MLH1 mutations in Italian families with hereditary nonpolyposis colorectal cancer. Genes Chromosomes Cancer. Jan. 1997;18(1):8-18. Family level data reported, unsure all pts were CRC. [pmid: 8993976].
Viel A, Novella E, Genuardi M, Capozzi E, Fornasarig M, Pedroni M, et al. Lack of PMS2 gene-truncating mutations in patients with hereditary colorectal cancer. Int J Oncol. Sep. 1998;13(3):565-9. Not outcomes of interest. [pmid: 9683794].
Viel A, Petronzelli F, Della PL, Lucci-Cordisco E, Fornasarig M, Pucciarelli S, et al. Different molecular mechanisms underlie genomic deletions in the MLH1 Gene. Hum Mutat. Nov. 2002;20(5):368-74. Didn't report any of 5 options. [pmid: 12402334].
Vilkki S, Launonen V, Karhu A, Sistonen P, Vastrik I, Aaltonen LA. Screening for microsatellite instability target genes in colorectal cancers. J Med Genet. Nov. 2002;39(11):785-9. Genetic testing not compared with index test. [pmid: 12414815]. [pmcid: 1735006].
Wagner A, Barrows A, Wijnen JT, van der KH, Franken PF, Verkuijlen P, et al. Molecular analysis of hereditary nonpolyposis colorectal cancer in the United States: high mutation detection rate among clinically selected families and characterization of an American founder genomic deletion of the MSH2 gene. Am J Hum Genet. May. 2003;72(5):1088-100. Not population of interest. [pmid: 12658575]. [pmcid: 1180263].
Wagner A, van der KH, Franken P, Wijnen J, Breukel C, Bezrookove V, et al. A 10-Mb paracentric inversion of chromosome arm 2p inactivates MSH2 and is responsible for hereditary nonpolyposis colorectal cancer in a North-American kindred. Genes Chromosomes Cancer. Sep. 2002;35(1):49-57. Didn't report any of 5 options. [pmid: 12203789].
Wahlberg S, Liu T, Lindblom P, Lindblom A. Various mutation screening techniques in the DNA mismatch repair genes hMSH2 and hMLH1. Genet Test. 1999;3(3):259-64. Not population of interest. [pmid: 10495924].
Wahlberg SS, Nystrom-Lahti M, Kane MF, Kolodner RD, Peltomaki P, Lindblom A. Low frequency of hMSH2 mutations in Swedish HNPCC families. International Journal of Cancer. Feb 20. 1997;74(1):134-7. Family level data reported, unsure all pts were CRC.
Wang L, Baudhuin LM, Boardman LA, Steenblock KJ, Petersen GM, Halling KC, et al. MYH mutations in patients with attenuated and classic polyposis and with young-onset colorectal cancer without polyps. Gastroenterology. Jul. 2004;127(1):9-16. Genetic testing not compared with index test, hMLH1 and hMSH2 sequencing not performed. [pmid: 15236166].
Wang Y, Friedl W, Lamberti C, Jungck M, Mathiak M, Pagenstecher C, et al. Hereditary nonpolyposis colorectal cancer: frequent occurrence of large genomic deletions in MSH2 and MLH1 genes. Int J Cancer. Feb 20. 2003;103(5):636-41. Not population of interest, data not extractable. [pmid: 12494471].
Wang Y, Friedl W, Lamberti C, Nothen MM, Kruse R, Propping P. A novel missense mutation in the DNA mismatch repair gene hMLH1 present among East Asians but not among Europeans. Hum Hered. Mar. 1998;48(2):87-91. Genetic testing not compared with index test. [pmid: 9526167].
Wang Y, Friedl W, Lamberti C, Ruelfs C, Kruse R, Propping P. Hereditary nonpolyposis colorectal cancer: causative role of a germline missense mutation in the hMLH1 gene confirmed by the independent occurrence of the same somatic mutation in tumour tissue. Hum Genet. Sep. 1997;100(34):362-4. Not population of interest; genetic testing not compared with index test. [pmid: 9272156].
Wang Y, Friedl W, Sengteller M, Jungck M, Filges I, Propping P, et al. A modified multiplex PCR assay for detection of large deletions in MSH2 and MLH1. Hum Mutat. Mar. 2002;19(3):279-86. Didn't report any of 5 options. [pmid: 11857745].
Ward R, Meldrum C, Williams R, Mokany E, Scott R, Turner J, et al. Impact of microsatellite testing and mismatch repair protein expression on the clinical interpretation of genetic testing in hereditary non-polyposis colorectal cancer. J Cancer Res Clin Oncol. Aug. 2002;128(8):403-11. Not population of interest. [pmid: 12200596].
Ward RL, Turner J, Williams R, Pekarsky B, Packham D, Velickovic M, et al. Routine testing for mismatch repair deficiency in sporadic colorectal cancer is justified. J Pathol. 2005;207(4):377-84. Genetic testing not compared with an index test; hMLH1 and hMSH2 sequencing not performed. [pmid: 16175654].
Watson P, Lynch HT. Extracolonic cancer in hereditary nonpolyposis colorectal cancer. Cancer. 1993;71(3):677-85. Not relevant. [pmid: 8431847].
Weber TK, Chin HM, Rodriguez-Bigas M, Keitz B, Gilligan R, O'Malley L, et al. Novel hMLH1 and hMSH2 germline mutations in African Americans with colorectal cancer. Jama. Jun 23. 1999;281(24):2316-20. Genetic testing not compared with index test. [pmid: 10386556].
Weber TK, Conlon W, Petrelli NJ, Rodriguez-Bigas M, Keitz B, Pazik J, et al. Genomic DNA-based hMSH2 and hMLH1 mutation screening in 32 Eastern United States hereditary nonpolyposis colorectal cancer pedigrees. Cancer Res. Sep 1. 1997;57(17):3798-803. Not population of interest. [pmid: 9288790].
Weber TK, Conroy J, Keitz B, Rodriguez-Bigas M, Petrelli NJ, Stoler DL, et al. Genome-wide allelotyping indicates increased loss of heterozygosity on 9p and 14q in early age of onset colorectal cancer. Cytogenet Cell Genet. 1999;86(2):142-7. Genetic testing not compared with index test. [pmid: 10545706].
Wei SC, Shun CT, Tsai-Wu JJ, Wu CH, Sheu JC, Wang CY, et al. Microsatellite instability and hMLH1 and hMSH2 gene expression in Taiwanese hereditary nonpolyposis colorectal cancer. J Formos Med Assoc. May. 2004;103(5):331-6. Not population of interest. [pmid: 15216397].
Wei SC, Yu CY, Tsai-Wu JJ, Su YN, Sheu JC, Wu CH, et al. Low mutation rate of hMSH2 and hMLH1 in Taiwanese hereditary non-polyposis colorectal cancer. Clin Genet. Sep. 2003;64(3):243-51. Not population of interest. [pmid: 12919140].
Whelan AJ, Babb S, Mutch DG, Rader J, Herzog TJ, Todd C, et al. MSI in endometrial carcinoma: absence of MLH1 promoter methylation is associated with increased familial risk for cancers. Int J Cancer. Jun 10. 2002;99(5):697-704. Not population of interest. [pmid: 12115503].
Whitehall VL, Wynter CV, Walsh MD, Simms LA, Purdie D, Pandeya N, et al. Morphological and molecular heterogeneity within nonmicrosatellite instability-high colorectal cancer. Cancer Res. Nov 1. 2002;62(21):6011-4. Genetic testing not compared with index test, hMLH1 and hMSH2 sequencing not performed. [pmid: 12414620].
Whiteside D, McLeod R, Graham G, Steckley JL, Booth K, Somerville MJ, et al. A homozygous germ-line mutation in the human MSH2 gene predisposes to hematological malignancy and multiple cafe-au-lait spots. Cancer Res. Jan 15. 2002;62(2):359-62. Not population of interest. [pmid: 11809679].
Wijnen J, Khan PM, Vasen H, van der KH, Mulder A, Leeuwen-Cornelisse I, et al. Hereditary nonpolyposis colorectal cancer families not complying with the Amsterdam criteria show extremely low frequency of mismatch-repair-gene mutations. Am J Hum Genet. Aug. 1997;61(2):329-35. Not population of interest. [pmid: 9311737]. [pmcid: 1715907].
Wijnen JT, Vasen HF, Khan PM, Zwinderman AH, van der KH, Mulder A, et al. Clinical findings with implications for genetic testing in families with clustering of colorectal cancer. N Engl J Med. Aug 20. 1998;339(8):511-8. Family level data reported, no primary data. [pmid: 9709044].
Wikman FP, Katballe N, Christensen M, Laurberg S, Orntoft TF. Efficient mutation detection in mismatch repair genes using a combination of single-strand conformational polymorphism and heteroduplex analysis at a controlled temperature. Genet Test. 2000;4(1):15-21. Didn't report any of 5 options. [pmid: 10794356].
Winawer S, Fletcher R, Rex D, Bond J, Burt R, Ferrucci J, et al. Colorectal cancer screening and surveillance: clinical guidelines and rationale-Update based on new evidence. Gastroenterology. 2003;124(2):544-60. Not primary study. [pmid: 12557158].
Woerner SM, Gebert J, Yuan YP, Sutter C, Ridder R, Bork P, et al. Systematic identification of genes with coding microsatellites mutated in DNA mismatch repair-deficient cancer cells. Int J Cancer. Jul 1. 2001;93(1):12-9. Not outcomes of interest. [pmid: 11391615].
Woerner SM, Kloor M, Mueller A, Rueschoff J, Friedrichs N, Buettner R, et al. Microsatellite instability of selective target genes in HNPCC-associated colon adenomas. Oncogene. Apr 7. 2005;24(15):2525-35. Not population of interest. [pmid: 15735733].
Wu Y, Berends MJ, Mensink RG, Kempinga C, Sijmons RH, Der Zee AG, et al. Association of hereditary nonpolyposis colorectal cancer-related tumors displaying low microsatellite instability with MSH6 germline mutations. Am J Hum Genet. Nov. 1999;65(5):1291-8. Not population of interest. [pmid: 10521294]. [pmcid: 1288281].
Wu Y, Berends MJ, Post JG, Mensink RG, Verlind E, van der ST, et al. Germline mutations of EXO1 gene in patients with hereditary nonpolyposis colorectal cancer (HNPCC) and atypical HNPCC forms. Gastroenterology. Jun. 2001;120(7):1580-7. Not outcomes of interest. [pmid: 11375940].
Wu Y, Berends MJ, Sijmons RH, Mensink RG, Verlind E, Kooi KA, et al. A role for MLH3 in hereditary nonpolyposis colorectal cancer. Nat Genet. Oct. 2001;29(2):137-8. Not population of interest. [pmid: 11586295].
Wullenweber HP, Sutter C, Autschbach F, Willeke F, Kienle P, Benner A, et al. Evaluation of Bethesda guidelines in relation to microsatellite instability. Dis Colon Rectum. 2001;44(9):1281-9. No data. [pmid: 11584201].
Xu DQ, Mattox W. Identification of a splicing enhancer in MLH1 using COMPARE, a new assay for determination of relative RNA splicing efficiencies. Human Molecular Genetics. Jan 15. 2006;15(2):329-36. Not relevant. [pmid: 16357104]. [pmcid: 1400605].
Yagi OK, Akiyama Y, Nomizu T, Iwama T, Endo M, Yuasa Y. Proapoptotic gene BAX is frequently mutated in hereditary nonpolyposis colorectal cancers but not in adenomas. Gastroenterology. Feb. 1998;114(2):268-74. Not outcomes of interest. [pmid: 9453486].
Yamamoto H, Min Y, Itoh F, Imsumran A, Horiuchi S, Yoshida M, et al. Differential involvement of the hypermethylator phenotype in hereditary and sporadic colorectal cancers with high-frequency microsatellite instability. Genes Chromosomes Cancer. Mar. 2002;33(3):322-5. Not outcomes of interest. [pmid: 11807990].
Yamamoto H, Sawai H, Weber TK, Rodriguez-Bigas MA, Perucho M. Somatic frameshift mutations in DNA mismatch repair and proapoptosis genes in hereditary nonpolyposis colorectal cancer. Cancer Res. Mar 1. 1998;58(5):997-1003. hMLH1 and hMSH2 sequencing not performed. [pmid: 9500462].
Yamashita K, Arimura Y, Kurokawa S, Itoh F, Endo T, Hirata K, et al. Microsatellite instability in patients with multiple primary cancers of the gastrointestinal tract. Gut. Jun. 2000;46(6):790-4. Not population of interest. [pmid: 10807889]. [pmcid: 1756432].
Young J, Simms LA, Biden KG, Wynter C, Whitehall V, Karamatic R, et al. Features of colorectal cancers with high-level microsatellite instability occurring in familial and sporadic settings: parallel pathways of tumorigenesis. Am J Pathol. Dec. 2001;159(6):2107-16. Genetic testing not compared with an index test. [pmid: 11733361]. [pmcid: 1850604].
Yuen ST, Chan TL, Ho JW, Chan AS, Chung LP, Lam PW, et al. Germline, somatic and epigenetic events underlying mismatch repair deficiency in colorectal and HNPCC-related cancers. Oncogene. Oct 24. 2002;21(49):7585-92. No data. [pmid: 12386821].
Zhao B, Wang ZJ, Xu YF, Wan YL, Li P, Huang YT. Report of 16 kindreds and one kindred with hMLH1 germline mutation. World J Gastroenterol. Apr. 2002;8(2):263-6. Not relevant. [pmid: 11925604].
Zhou XL, Eriksson U, Werelius B, Kressner U, Sun XF, Lindblom A. Definition of candidate low risk APC alleles in a Swedish population. Int J Cancer. Jul 1. 2004;110(4):550-7. Not population of interest, different question. [pmid: 15122587].
Zhou XP, Kuismanen S, Nystrom-Lahti M, Peltomaki P, Eng C. Distinct PTEN mutational spectra in hereditary non-polyposis colon cancer syndrome-related endometrial carcinomas compared to sporadic microsatellite unstable tumors. Hum Mol Genet. Feb 15. 2002;11(4):445-50. Not outcomes of interest. [pmid: 11854177].
Zhou XP, Loukola A, Salovaara R, Nystrom-Lahti M, Peltomaki P, de la CA, et al. PTEN mutational spectra, expression levels, and subcellular localization in microsatellite stable and unstable colorectal cancers. Am J Pathol. Aug. 2002;161(2):439-47. Not outcomes of interest. [pmid: 12163369]. [pmcid: 1850747].