# Appendix C. Evidence Tables

Study: Aaltonen 1998

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
509 consecutive patients with CRC from 9 hospitals in Finland between May 1994 and April 1996 ie does not overlap with Salovaara | MSI wad done in all patients (Battery of MSI was not common to all), founder mutation 1 in MLH1 was looked for in all patients; MLH1 and MLH2 sequencing was done in MSI positive and founder mutations negative patients | Founder mutation 1 in MLH1 and other mutations in MLH1 and MLH1 | | Y | N | ? | Am 1 | | Literature and previous analyses on the founder mutation and comparison wit with non-cancer controls
mean age 67 | | (NB Salovaara tested founder mutation 2 also) | ≥5 MSI markers used? | | x | | Am R
| | | MSI-H defined by ≥ 2 markers? | | x | | Beth 1
| | | Microdissection? | | | x | Beth R
| | | Gene screening? | x | | | MSI-H
| | | Deletion analysis? | | | x | MSI-L | X
| | | Conversion analysis? | | | x | IHC
| | | Genetic testing varied between first 198 and subsequent 311 pts. MSI testing differed between pts, all however received the BAT26 test and correlation was OK. | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other | x
| | | | | | | MSI

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | | | | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
509 mean age ? males ? | 10 MMR/509 patients with CRC 9 MLH1 and 1 MSH2 NOT COUNTING THE NON-PATHOGENIC MUTATIONS | 4/509 (0.8%) Am I | Other miniSATs | | | | Large scale molecular screening for HNPCC can be done by 2- stage procedure: screening for founders mutations, then MSI, then sequencing for those with + MSI | no | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | Combined 4/4 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | X
| | | | | + | - | To select who to screen for MSI, use Age <50, family Hx of EC or CRC or multiple tumor in same pt. | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)? | | X
| | | BAT | + | 58 | 6 | | | | | Other (specify) | | | Am 1 +
| | | 26 | - | 5 | 440 | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | Combined 0/4 | Am R +
| | | | | | | | | | | Amsterdam R | X | | Beth 1 +
| | | | | | | | | | | Other (specify) | | | Beth R +
| | | | | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | NA | Age <50
| | | | | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR
Consecutive CRCs | Am 1 + | | + | 4 | 0
| Am R + | | - | 6 | 499
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| Combined Am1&R | X

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Consecutive CRCs | Am 1 + | | + | 10 | 53
| Am R + | | - | 0 | 446
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI, Other Sats | X

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Consecutive CRCs | Am 1 + | | + | 10 | 54
| Am R + | | - | 0 | 443
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI, BAT26 | X

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | X
7 | Were withdrawals from the study explained? | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Aarnio, 1997 RefID 2366 Multicenter, Finland
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Focused on same patients as Aarnio 1995 Ref ID 2666 but reported different outcomes. | Suspected HNPCC by Amsterdam I, some families with known mutation. | | | History of gastric cancer and member of an HNPCC family. | Examined 24 gastric cancer specimens for histology and H. pylori staining. Performed IHC for P53 expression and MSI on 20 cases. Also assessed survival in a total of 45 patients. | 45 patients with gastric cancer (24 men, 21 women) mean age 56 (range 31–85). Metachronous other cancer occurred in 23 (51%). Total number of tumors 90. | ND | Gastric cancer was an HNPCC-associated tumor on average in 11% of affected family members. Predominant tumor type was intestinal. Existence of this tumor in patients younger than 60 suggests HNPCC in the background. Relative rarity in HNPCC families makes cost-effectiveness of endoscopic screening questionable. | C
Focused on 51 families with HNPCC affected by gastric cancer. Of 92 families registered in HNPC registry, a mutated MLH1 gene segregated in 45 and a mutated MSH2 in 2 while four met Amsterdam I criteria. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | There was variation in the occurrence of gastric cancer in families with different MLH1 or MSH2 genes but difference was not statistically significant. 19/24 were intestinal type; 6 (32%) were poorly differentiated, four others (17%) classified as diffuse or mucinous. | | | Significance of survival data is unclear since there was no information on staging or how patients were selected for treatment. Incomplete verification of tissues samples, and tissue samples were assessed only in a subset of patients. Unclear how many patients of eligible population agreed to participate. Unclear how survival/death was ascertained.
In these 51 families, there were 570 family members affected by cancer of whom 62 (10.9%) had gastric cancer and formed the basis for the study. | Yes | No | Uncl | | | 7/15 samples (47%)with suitable tissue were MSI-H
| X | | | | | H. pylori positive in 3/15.
| | | | | | Overall 5-year survival 15%; 48% in patients in whom radical surgery was performed.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 x | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | X | NA
| | No
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Analysis | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | Yes | No | X
| | | ND
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | X | Provider | Client | Institution
| | Organization/group
Indicate the unit of analysis | Community | X | Provider | Client | Institution
| | Organization/group
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | X
| | | Can't tell
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | X | ND | NA
| | No
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | X | No | Can't Tell
| Yes

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Adams, J 2003, RefID 653 Multicenter UK
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Secondary analysis of data recorded for a study on polyp prevention (a database) on chemopreventive effects of aspirin. Study had included 600 patients with HNPCC; of these 154 were available for analysis and full data were available on 134. Of these 134, 49 had a personal history of CRC. | Amsterdam II criteria | | | Inclusion criteria included age >25 and, in those with a previous diagnosis of CRC, at least five years since resection. | Primary outcome was relationship between TDS and age of resection of first colorectal cancer. | There was a statistically non-significant correlation between the TDS and the age of first resection indicating that individuals in less deprived areas tended to have their colorectal cancer resected at an earlier age than those living in more deprived areas. | Most dropouts from missing data due to wrong postal codes | More affluent individuals from HNPCC families tended to undergo surgical resection for CRC earlier than less affluent individuals. This relationship bordered on statistical significance and probably represents socio-economic variations in access to treatment. | C
Socioeconomic status assessed using the Town-Deprivation Score (TDS) of the current enumeration district of residence. This score is based upon relative material deprivation based upon census data. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | | | | Poorly defined populations, interventions, documentation of cancers, no correlation with ages of family members who may have resided in affluent areas. Reasons for resection not stated.
| Yes | No | Uncl
| | X

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C(weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | X
| | | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | X
| | | | | NA
Allocation Bias | | | | | | A | B | C (weak)
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | X | NA
| | No
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | X
| | No
Blinding | | | | | | A | B | C (weak)
| | | | | | (strong) | (moderate)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | X | <60 | ND | NA
| | 60–79
Analysis | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | Yes | X | ND
| | No
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | X
| | | Can't tell
Intervention Integrity | | | | | | A | B | C (weak)
| | | | | | (strong) | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | X | NA
| | | ND
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | X | No | Can't Tell
| Yes

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Aktan-Collan 2000 Ref ID 1798, same patients as Atkan-Collan 2000-2001, Ref ID 866, 1419 and 1835 but studied different outcomes
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Counseling offered to members of 36 families in which a genetic mutation had been identified. Questionnaires filled out before, counseling and then 1 month and 1 year afterward. | Mutation identified in families | | | As per study description | Surveys | 334/381 accepted genetic testing of whom 30% were mutation-positive. Acceptors differ from decliners in more often having a spouse or partner, being employed and having higher education. On multivariate analysis, the only significant factor for accepting genetic testing was employment status. | ND | The possibility of early detection and treatment of colorectal tumors makes predictive testing for HNPCC beneficial. The test was welcomed by the majority of individuals at risk for HNPCC, and few reported having regretted the decision to make it. Thus, we suggest that all members of families with HNPCC should be actively informed about the predictive test by their physician. | B
Of 446, 90% consented to participate, 381 (85%) returned a baseline questionnaire. Education/counseling attended by 347 of whom 333 (96%; 75% of total population) opted for predictive testing. Of these, 271 filled out all three questionnaires. These form the basis of the study group. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | At 1-month, there was no difference in satisfaction in decision to undergo testing in mutation positive and negative subjects.
| Yes | No | Uncl | | | At one-year, subjects who had not inherited a mutation were slightly more satisfied.
| | X | | | | Most common reasons cited against undergoing testing were: being old already and having no children (23%), would not trust result (15%), timing found unsuitable because of pregnancy 1 (8%), no reason given (54%)

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | X | <60 | ND | NA
| | 60–79
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | X | No | Can't tell
| Yes
If there were differences between groups for important confounders, were they adequately managed in the analysis? | X | No | NA
| Yes
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | X | <60 | ND | NA
| | 60–79
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | X
| | | | | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't Tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Atkan-Collan, 2000 RefID 1835
Multicenter Finland, Same patients as Atkan-Collan 2001, Ref ID 866 and 1419 but different outcomes
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
446 family members from 36 HNPCC families with known mutations at 50% risk offered counseling and genetic testing. Families contacted by letter. | Families known to have a genetic mutation. | | | See study description. | Surveys | Mean age 43 (range 19–77, SD 13) | As per study description' | A protocol that includes one-comprehensive pretest counseling session and a test disclosure session, supplemented with option of professional psychological support, seems to be sufficient for both the educational and supportive needs of counselees. Only a minority expressed a need for post-test follow-up sessions. | B
Along with counseling and testing, all sent questionnaires before counseling, 1 month, and 1 year after testing. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | At one month 88% indicated counseling was easily comprehended. 10% wanted minor changes, most commonly asking for more written material. Those with a university education suggested changes more than those without
Of 446 eligible, 401 (90%) agreed to participate and 381 (85%) returned a baseline questionnaire. Educational counseling attended by 347, of whom 333 (96%, 75% of whole group) opted for predictive genetic testing. | Yes | No | Uncl | | | At one year, pretest counseling considered very useful by 49%, fairly useful by 40% and slightly useful by 10%. Women and those with a lower level of education were significantly more likely to consider counseling useful.
Study focused on 271 subjects (61% of whole group) who had been tested and returned all questionnaires. | | X | | | | At post-test follow-ups, 89 and 95%, respectively, considered a single post-test session sufficient.
| | | | | | 53% indicated that they might have used professional psychological support along with counseling if it had been provided. The support might have been used by women with children more than by others.
| | | | | | Mutation positive subjects more often reported the greatest need for support soon after hearing the results.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 x | 9 x | 8a x | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | X | <60 | ND | NA
| | 60–79
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | X | No | Can't tell
| Yes
If there were differences between groups for important confounders, were they adequately managed in the analysis? | X | No | NA
| Yes
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | X | <60 | ND | NA
| | 60–79
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | X
| | | | | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't Tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Aktan-Collan 2001, Ref ID 1419, Multicenter Finland. Same patients as Aktan-Collan 2001 Ref ID 866 but studied different outcomes
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Counseling offered to members of 36 families in which a genetic mutation had been identified. Questionnaires filled out before, counseling and then 1 month and 1 year afterward. | Mutation in participating families | | | See study description and Aktan-Collan 2001 | Surveys | Data analyzed according to mutation positive or negative. Fear of cancer, fear of dying soon and satisfaction were life were all modestly (but significantly) different between those who turned out to be mutation positive and negative even after adjusting for age. | As per study description | Counseling and testing relieve fear of cancer; no harmful emotional impact was detectable at 1-year follow-up. These findings should be studied after a longer interval. | B
Of 446, 90% consented to participate, 381 (85%) returned a baseline questionnaire. Education/counseling attended by 347 of whom 333 (96%; 75% of total population) opted for predictive testing. Of these, 271 filled out all three questionnaires. These form the basis of the study group. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Mutation positive subjects who had just received their results had significantly higher scores than mutation-negative subjects.
| Yes | No | Unclr | | | After 1 year, the fear of cancer had decreased from baseline in both groups. Mutation-positive subjects were slightly, although significantly, more afraid of cancer at every measurement.
| | X

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | X | <60 | ND | NA
| | 60–79
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | X | No | Can't tell
| Yes
If there were differences between groups for important confounders, were they adequately managed in the analysis? | X | No | NA
| Yes
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | X | <60 | ND | NA
| | 60–79
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | X
| | | | | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Aktan-Collan 2001, Ref ID 866 Multicenter Finland
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Described insurance behavior of 271 patients who had undergone predictive genetic testing for HNPCC. | Mutation identified in family. | | | See study description. | Surveys | Mutation-positive subjects reported that they already had a life insurance before entering study more often than mutation-negative subjects (36 versus 28%) but results were not statistically significant. | See study description | Mutation-positive subjects did not differ from others in purchase of life or health insurance policies. However, the mutation-positive individuals reported that they possessed health insurance policies before entering the study more often than their counterparts. | B
446 family members from 36 HNPCC families with known mutations at 50% risk offered counseling and genetic testing. Families contacted by letter. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | The difference in possessing a health insurance plan before genetic counseling between mutation-positive and negative individuals was significant (21 versus 11%). | | | Incomplete reporting of data on denials, extent to which insurers requested information about genetic testing. Validity of surveys unclear.
Along with counseling and testing, all sent questionnaires before counseling, 1 month, and 1 year after testing. | Yes | No | Uncl | | | 3% indicated that they had purchased a life insurance policy and 2% correspondingly a health insurance policy before they were tested.
Of 446 eligible, 401 (90%) agreed to participate and 381 (85%) returned a baseline questionnaire. Educational counseling attended by 347, of whom 333 (96%, 75% of whole group) opted for predictive genetic testing. | | X
Study focused on 271 subjects (61% of whole group) who had been tested and returned all questionnaires.

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | X | <60 | ND | NA
| | 60–79
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | X | No | Can't tell
| Yes
If there were differences between groups for important confounders, were they adequately managed in the analysis? | X | No | NA
| Yes
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | X | <60 | ND | NA
| | 60–79
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | X
| | | | | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't Tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Arrigoni, A 2005, Ref ID 276 Multicenter, Italy
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Individuals form families fulfilling Amsterdam I criteria advised to take place in a surveillance program as follows (all tests repeated every two years) | Amsterdam criteria I | | | As per study description | Surveillance procedures as outlined in study description | 22 families identified with a total of 331 at-risk living relatives of whom 40 had already developed CRC. | As per outcomes. | Our study confirms the importance of collecting a careful family history for each patient with CRC. Data on a relatively short followup seem to support the efficacy of repeat colonoscopies in reducing CRC rate in at-risk members of HNPCC. Studies with longer followup are needed. | C
Colonoscopy starting at age 25 | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | 199 accepted surveillance while 132 refused. Patients who accepted or refused did not differ significantly for by sex or age. | | | Data do not support their conclusions. Possibility of lead-time bias in earlier stage detection. Data not analyzed using survival analysis.
GYN exam, and transvaginal US starting at age 30 | Yes | No | Uncl | | | Six individuals accepting surveillance were found to have CRC (3%). Overall incidence of CRC was 7/199 in patients undergoing surveillance and 5/132 in those not (p=NS). However, CRC detected in those undergoing surveillance was significantly less advanced.
Urinary ultrasonography and urine analysis starting at age 30 | | X | | | | Seven at-risk individuals were found to have extracolonic cancer during surveillance. Extracolonic cancers were detected in six of 132 who refused.
Endoscopy starting at age 30
Thyroid ultrasonography starting at age 35
Breast mammography starting at age 35

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 x | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | 80–100 | X | <60 | ND | NA
| | 60–79
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | X
| | | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | X | NA
| | No
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | X | ND | NA
| | No
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | Yes | X | ND
| | No
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | X
| | | | | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | X | NA
| | | ND
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Arver B 2004 Ref ID 433 Multicenter Sweden
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
1000 families underwent “oncogenetic counseling” between 1995 and 1995. In those where an autosomal dominant breast/ovarian or colon cancer gene mutation was suspected, genetic screening of BrcA1 and BRCA2 or MLH1 and MSH2 offered. A total of 295 BRCA1 and BRCA2 and 57 MLH1 and MSH2 offered. | Women at risk for a genetic syndrome as defined in study description. HNPCC defined genetically. | | | Healthy females belonging to a family with a known mutation in BRCA1, BRCA2, MLH1 and MSH2 desiring genetic testing, age>18 and Swedish speaking. Men were excluded except if they had a personal history of cancer. | Surveys conducted before testing and then 1 week, 2, 6 and 12 months after results were given. | Al but one woman agreed to genetic testing. The one exception worried about consequences of insurance and employment in the future. | 1 because of worries about insurance and employment, 1 non Swedish-speaking, 1 did not receive surveys | Predictive testing for hereditary breast/ovarian or colon cancer gene mutations will not confer impaired mental health in motivated individuals who receive thorough pre- and post-test information and support and for whom preventive surveillance is offered. | B
114 healthy men and women from 73 of the 80 families with an identified mutation opted for genetic testing. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | Hospital anxiety and depression scale | Mean age in 87 women was 38.1 in mutation carriers and 41 in non-mutation carriers. | | | Did not describe details of surveillance and relationship with survey results.
Study sample consisted of 90 healthy women. | Yes | No | Uncl | | Swedish SF-36 | A statistically significant decrease in anxiety mean scores over time was observed in total sample irrespective of tested gene or carrier status. Anxiety scores were similar to a normative Swedish population. | | | Mixed population of HNPCC and BRC.
| | X | | | | Women tested for breast cancer predisposing genes showed an average lower levels of depression measured over time than women tested for colon cancer genes but difference was not statistically significant.
| | | | | | QOL subscores did not change significantly during observation. Women tested for colon cancer genes showed increased vitality scores over time. However, carriers of colon cancer genes had a decrease in vitality scores two to six months after the result of disclosure, followed by increased levels while levels in non-carriers were more stable. The difference between carriers and non-carriers over time was statistically significant. No differences were found between study group and Swedish normative data on any of the five QOL parameters.
| | | | | | 83% thought decision to undergo genetic counseling was “easy”. All but one woman would have redone the testing again.

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | 80–100 | X | <60 | ND | NA
| | 60–79
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | X | No
| Yes
Were data collection tools shown or are they known to be reliable? | X | No
| Yes
Withdrawals and Dropouts | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | X | 60–79 | <60 | ND | NA
| 80–100
Analysis | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | X
| | | Can't tell
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | X
| | | | | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Benatti, 2001 RefID 1411 Italy, multicenter
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | | | | | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
HNPCC families from the data of a population-based CRC registry were identified in 1984. All incident CRC cases diagnosed in the period 1984-1997 were collected and then stratified according to the presence of 6 clinical features. When a patient had 2 or more of these features, an extended genealogic pedigree was traced and then analyzed for the presence of diagnostic criteria for HNPCC. | 1) fulfillment of AM-II for HNPCC diagnosis, (2) MSI testing in at least 1 case of CRC or endometrial cancer in the family, or (3) availability of hMLH1 and hMSH2 mutation analysis results. | | | (1) fulfillment of AM-II for HNPCC diagnosis, (2) MSI testing in at least 1 case of CRC or endometrial cancer in the family and (3) availability of hMLH1 and hMSH2 mutation analysis results. | Observation only | Baseline clinical features of the 3 groups examined: | | | | | Retrospective cohort analyses. No dropouts described. | Authors' conclusions: “Our results support the hypothesis that the biomolecular heterogeneity of HNPCC is reflected in heterogeneous clinical features and confirm the value of MSI analysis as a surrogate marker for MMR gene mutations. The clinical similarities between group A and group B patients indicate the MSI testing could be useful to better define clinical HNPCC families, identifying groups with different risks of carrying genetic defects.” | C
Once identified, families were considered eligible for the study if they met the inclusion criteria. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | | Group A: MMR+ | Group B: MSI&MMR- | Group C: MSS&MMR- | P value | Due to significant differences in many factors between the 3 groups at baseline, followup results from univariate analyses (such as analyses for cancer occurrence and log-rank analyses) are not useful.
29 families met the inclusion criteria: 10 carried MMR gene mutations (group A), 10 were characterized by MSI phenotype but not by MMR gene mutation (group B), and 9 did not show mutations or MSI (group C). | Yes | No | Uncl | | | No. of family | 10 | 10 | 9 | | Only results from Cox regression multivariate analyses (variables in the model: groups, sex, age ≤50 vs. >50, Stage, and site) might have some implications for the benefit-and-harm question.
Time of followup was calculated from the date of HNPCC diagnosis in the index case to 12/31/1999. Mean duration was 8.2, 6.7, and 9.4 years for group A, B, and C, respectively. | x | | | | | Subjects (M/F) | 361 (188/173) | 241 (129/112) | 355 (169/186) | ns | Our interpretation of the Cox survival analyses results: After controlling for sex, age, cancer stage, and site of CRC tumor, hazard ratio of dying is significantly higher for Group C (MSS and MMR negative) patients (HR=2.51 95%CI 1.32– 4.79), when compared to the Group A (presence of MMR gene mutations) patients. There was no statistical difference in the hazard ratio of dying between group A and group B patients after controlling for sex, age, cancer stage, and site of CRC tumors.
| | | | | | Tumor spectrum | 66 (58.9) | 38 (78.0) | 47 (66.2) | <0.005
| | | | | | - Colon (% of total)
| | | | | | - Extracolonic HNPCC-related sites | 29 (25.9) | 6 (12.0) | 5 (7.0)
| | | | | | Mean age at diagnosis (years) | | | | <0.05
| | | | | | - Colon | 47.6 | 49.0 | 63.4 | <0.05
| | | | | | - HNPCC-related sites | 48.4 | 61.0 | 65.6 | ns
| | | | | | - Extra-HNPCC sites | 52.5 | 53.2 | 57.6
| | | | | | MSI-H tumors | 25/25 (100%) | 23/25 (92%) | 2/26 (7.7%)
| | | | | | I. Cancer occurrence in the follow-up of the 3 groups: In the follow-up, among HNPCC-related neoplasms, endometrial cancer was more frequent for gastric carcinoma in groups A and B, whereas in group C the stomach was the only extracolonic organ involved. Patients developing CRC in the follow-up were significantly younger (p=0.001) in groups A and B than in group C.
| | | | | | II. CRC-specific Survival: The log-rank test revealed a significantly better prognosis for patients from families with a germline MMR gene mutation or MSI (p=0.0001).
| | | | | | Furthermore, the presence of MMR gene mutations or MSI, together with stage, appeared as an independent prognostic factor by Cox regression multivariate analysis.

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B x | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
| | x
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | X NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C x
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
| x
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
| | x
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
| x
Blinding | | | | | | A | B | C x
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
| | | x
Data Collection methods | | | | | | A x | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes x | No
Were data collection tools shown or are they known to be reliable? | Yes x | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
| | | | x
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Bermejo 2005 UI 16344057 Sweden Multicenter
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
The families of the Swedish Family-Cancer Database with at least 4 generations (N=566,877) were classified according to Amsterdam or Bethesda criteria. Survival methods were used to assess the risk of cancer in the classified families, the prognosis of cancer patients, and the risk of subsequent malignancies after CRCs and after CRCs/endometrial carcinomas. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | Families with at least 4 generations were included. If a founder parent of the family was missing or if they had married several times, the family was excluded. Overlap between families was possible, eg, individuals in the 4^th^ generation could belong to 4 different families. The ages of the parents were unlimited, but the maximum age in the second generation was 70 years. | | N=566,877 families | | “Most malignancies in the classified families reflect typical features of HNPCC. The data presented should help to define surveillance strategies for members of families that fulfill the criteria for HNPCC testing.” | B
| Yes | No | Uncl | | | 21 fulfilled Am I; 42 fulfilled Am II; 5095 fulfilled Beth (0.9%)
| | x | | | | 1 By age 75 yr, the cumulative risk of CRC in Am I families was 57.1% (95% CI, 46–68.8%); the cumulative risk of CRC in Am II families was 41.2% (95%CI, 33.3–50.1%); 2 The cumulative risk of CRC in Beth families was 41.7% (95%CI, 39.4–44.1%) in men, and 23.3% (95%CI, 22.2–24.4%) in women.; 3 The cumulative risk of endometrial cancer in Am II by age 75 yr was 45.4% (95%CI, 34.1–58.5%), and it was 8.7% (95%CI, 8–9.5%) in Beth.; 4 For ovarian cancer, the cumulative risk by age 75 yr in Beth was 4.7% (95%CI, 4.2–5.3%); for gastric cancer, it was 2.3% (95%CI, 2–2.7%).; 5 Families that fulfilled the Beth criteria showed increase risk of cancer in the colorectum, endometrium, small bowel, ovary, stomach, bile ducts, renal pelvis, and ureter; members of Beth criteria families were at decreased risks of lung and cervical cancers.; 6 The prognosis of cancer in the ureter, renal pelvis, stomach, ovary, and colorectum, but not in the endometrium, was better in Beth criteria than in nonclassified families.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Bertario 1999, Ref ID 2106 Multicenter, Italy
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
2340 CRC patients consisting of 3 groups (144 HNPCC, 161 FAP, 2035 sporadic). Comparative survival estimated. | Amsterdam criteria | | | As per study description | Cumulative probability of five-year survival. | No substantial survival advantage for patients with HNPCC and FAP versus sporadic group after adjustment for age, gender, stage and tumor location. | ND | No substantial survival advantage for HNPCC and FAP compared with sporadic group after adjustment for age, gender, stage, and tumor location. HR for HNPCC was 1.01 (95% CI 0.72–1.39) compared with sporadic. | B
FAP=familial adenomatous polyposis | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | For HNPCC and FAP patients, the follow-up procedures and adjuvant-treatment protocols were the same as for patients with sporadic colorectal carcinoma. Taking into consideration the increased risk of extracolonic manifestations, hereditary-colorectal cancer patients were also subjected to periodical instrumental examinations tailored to the different spectrum of the disease. | | | | Short followup. No details on reliability of survival data. Study may have been underpowered.
| Yes | No | Uncl
| | X

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | X | No | Can't tell
| Yes
If there were differences between groups for important confounders, were they adequately managed in the analysis? | X | No | NA
| Yes
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Analysis | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | Yes | X | ND
| | No
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | X | Provider | Client | Institution
| | Organization/group
Indicate the unit of analysis | Community | X | Provider | Client | Institution
| | Organization/group
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | X | NA
| | | ND
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Berth 2002 Ref ID 985 Germany single center
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Survey sent to 2076 persons of the general population and 36 patients at high risk for HNPCC or FAP. | ND | | | As per study description | Survey regarding attitudes about genetic testing. | "overall, both the general population and at-risk persons hold a favorable attitude toward genetic testing. | ND | Attitudes of persons at risk for HNPCC and FAP similar to general population. | C
FAP=familial adenomatous polyposis | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | | | | Validity of survey instruments unclear, no details provided about response rates, differences among responders and nonresponders, definition of at-risk individuals or any other details about at-risk individuals.
| Yes | No | Uncl
| | X

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed | Yes | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | X
| | | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | X | NA
| | | ND
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | X | No | Can't tell
| Yes

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Bleiker, EM 2005, Ref ID 268 Multicenter, Netherlands
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comment | Study Conclusions | Quality score* (comments)
178 patients at high risk for CRC (27 Amsterdam I criteria 43 familial CRC occurrence). All had received counseling from a geneticist and were advised to have periodic colonoscopy. | As per study description. Selected patients who fulfilled Amsterdam were tested for mutations. 21% had been treated for CRC and/or endometrial cancer in the past. | | | As per study description | Objective and self-reported compliance | 149/178 returned a completed questionnaire. Respondents significantly older than nonrespondents. Average f/u 5.8 years | ND | Although few high-risk individuals abstain from screening entirely, approximately 1 in 4 deviates significantly from the recommended frequency of screening. Increased compliance may be achieved by reducing the discomfort and embarrassment associated with the procedure and the use of reminder letters. | B
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | 61% of study sample fulfilled Amsterdam I | | | No details on whether noncompliers had poor access/economic barriers to screening.
| Yes | No | Uncl | | | Objective compliance data available for 132/149. Of these 95 (72%) were found to be compliant with screening advise. | | | Survey instruments novel and have not been validated.
| | X | | | | Of 37 (28%) noncompliant, 20 had postponed screening for at least 1 year, 13 were screened only once and 4 never underwent screening.
| | | | | | Compliers were significantly younger than noncompliers and there was a nonsignificant trend to increased level of education, mutation status and type of colon screening.
| | | | | | No difference between perceived colon cancer risk.
| | | | | | Noncompliers significantly more likely to perceive barriers to screening.
| | | | | | Noncompliers rated screening as being more embarrassing.
| | | | | | On multivariate analysis only the perceived number of barriers to screening was associated significantly with noncompliance (OR 1.2, 95% CI 1.1–1.3).
| | | | | | Of self-reported data, noncompliance was associated with embarrassment with screening procedure and sigmoidoscopy rather than colonoscopy.
| | | | | | Compliers were significantly more likely to have remembered receiving a reminder letter.

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | X | 60–79 | <60 | ND | NA
| 80–100
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | X | No | NA
| Yes
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | X | 60–79 | <60 | ND | NA
| 80–100
Analysis | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | X | Client | Institution
| | | Provider
Indicate the unit of analysis | Community | Organization/group | X | Client | Institution
| | | Provider
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
What % of participants received the allocated intervention or exposure of interest? | X | 60–79 | <60 | ND | NA
| 80–100
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | X | Can't tell
| | No

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Boks, DE 2002, Ref ID 1059 Multicenter, Netherlands
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
66 patients with endometrial cancer from 46 families in an HNPCC registry | Had an HNPCC mutation OR met revised Amsterdam criteria 38/50 patients included in final analysis had a mutation (19 MLH1, 16 MSH2 and 3 MSH6) | | | Cancer diagnosis verified by medical record or pathology report. | Survival compared with an age and stagematched control group (2 controls per case) of patients with endometrial cancer from a population registry who lacked other malignancies. | No significant difference in distribution of tumor histologic types between cases and control. | 16 patients excluded from survival analysis because stage of cancer could not be verified or because a matched control | The outcomes in survival for endometrial cancer in the general population and women from families with HNPCC do not differ significantly. | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Survival rates for cases and controls were not significantly different. Cumulative 5-years survival 88 versus 82% for HNPCC versus sporadic. | | | Treatment not described.
| Yes | No | Uncl | | | No difference in survival was observed between patients in the study group with a mutation identified and those without an mutation.
| X | | | | | No significant difference in survival for age or stage matching.

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | X | No | Can't tell
| Yes
If there were differences between groups for important confounders, were they adequately managed in the analysis? | X | No | NA
| Yes
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Were data collection tools shown or are they known to be valid? | X | No
| Yes
Were data collection tools shown or are they known to be reliable? | X | No
| Yes
Withdrawals and Dropouts | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | X | <60 | ND | NA
| | 60–79
Analysis | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | Yes | X | ND
| | No
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | X | Provider | Client | Institution
| | Organization/group
Indicate the unit of analysis | Community | X | Provider | Client | Institution
| | Organization/group
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | X | Can't tell
| | No
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | X
| | | | | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | X
| | | | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Bradshaw 2003, Ref ID 692 Single center UK
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
A two year cohort study described results of colonoscopy surveillance in a total of asymptomatic patients with a family history of CRC at a young age but who do not fulfill the Amsterdam criteria and those who fulfill the Amsterdam criteria. | Amsterdam I Criteria | | | Asymptomatic individuals attending an appointment for CRC risk assessment with a genetic counselor between 2000 and 2002. | Individuals with a family history fulfilling the Amsterdam criteria 1 (high risk, table 1) were recommended to undergo colonoscopy every two years from the age of 30 years. Moderate risk cases were offered colonoscopy at the age of 35 years, or five years before the youngest age of diagnosis of CRC in the family if this resulted in colonoscopy at a younger age and, if this colonoscopy was normal, a second at the age of 55 years. | No cases of CRC were detected. | 448 attended genetic service for risk assessment. 53 with a high risk family history and 123 at moderate risk had a colonoscopy. Colonoscopy was complete to the cecum in 92%. See Figure 1 in original paper for detailed accounting of dropouts. | These findings indicate that the prevalence of significant neoplasia in groups defined by family history is low, particularly in younger age groups. These prospective data call into question the value of colonoscopy before the age of 50 in moderate risk individuals. | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | Risk definitions: Low risk - Anyone not fulfilling medium or high risk criteria. | | 4 patients (8%) in high-risk group had adenomas. | | | Low completion rate of colonoscopy suggests examinations were not performed optimally (possible variation in endoscopists' experience). Analyses were post-hoc. Study likely to be underpowered. Short followup. No comment as to whether endoscopists were aware of the family history.
| Yes | No | Uncl | Moderate risk - with family history of CRC but not fulfill Amsterdam criteria | | In moderate group, overall five individuals had an adenoma (2%).
| | X | | High risk - with a family history fulfilling the Amsterdam criteria 1 | | Proportion of patients younger than 50 found to have an adenoma was significantly greater in the high risk group than those in the moderate risk group (p=0.05).
| | | | Fifty three individuals with a high risk family history and 123 individuals assessed at moderate risk were eligible for and had colonoscopic evaluation.
| | | | Excluded patients with FAP.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | X
| | | | | | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | X
| | | | | | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | X | 60–79 | <60 | ND | NA
| 80–100
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | X
| | | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | | X
| | | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | X | 60–79 | <60 | ND | NA
| 0–100
Analysis | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | Yes | X | ND
| | No
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | X | 60–79 | <60 | ND | NA
| 80–100
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | X | NA
| | | ND
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | X | Can't tell
| | No

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Brain, K, 2003, Ref ID 895 Single center UK
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Survey obtained from 16 regional genetic centers involved in predictive testing for HNPCC. Purpose was to gain evidence regarding core elements of the pre-test counseling protocol for HNPCC. | ND | | | Center performs genetic testing for HNPCC. | Questionnaire involving core features of protocol for predictive testing. | Average number of pre-test counseling sessions was 2 (range 1–3) with an average of 4 weeks between sessions. | 16/20 centers participated. One declined because of few patients counseled. No other details provided. | “The present findings suggest that although some UK centers are favorable towards shortening pretest counseling for HNPCC, there is some uncertainty regarding the key elements of genetic counseling. There is currently little empirical evidence regarding which components of pretest counseling are effective in promoting good psychological outcomes. Controlled trials are needed.” | B
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Minimum number of sessions was 1 (range 1–2). | | | Very little detail provide about characteristics of centers/patient populations educational level etc. that might have bearing on the need for specific counseling protocols.
| Yes | No | Uncl | | | Counselors included clinical geneticists and genetic nurse and gastroenterologists.
| | X | | | | Some included home visits, psychiatric consultation, explicit circumstances in which a client would be excluded or postponed from testing. Four centers reported that they were considered shortening the counseling protocol.
| | | | | | Centers described a total of 144 topics as being core topics of prêt-test counseling.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | X | 8b,8c | 1,6b,9,10,11
| | | | 8a
Public health or policy | 2,3 | 5 | 9 | X | 8b,8c | 1,6,a,6b,7,10
| | | | 8a

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | X
| | | | | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | X
| | | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | X | ND | NA
| | No
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | X | 60–79 | <60 | ND | NA
| 80–100
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | Yes | No | X
| | | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | X | Provider | Client | Institution
| | Organization/group
Indicate the unit of analysis | Community | X | Provider | Client | Institution
| | Organization/group
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
What % of participants received the allocated intervention or exposure of interest? | X | 60–79 | <60 | ND | NA
| 80–100
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | X | Can't tell
| | No

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Brain, K 2005, Ref ID 74 Single center UK
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Randomized controlled trial involving 26 high-risk individuals for HNPCC who were randomly assigned to extended or shortened genetic counseling. | Mutation | | | Unaffected individuals from families with a known HNPCC mutation. | Extended (two sessions of education and reflection held one month apart) or shortened (a single educational session) of genetic counseling. | At baseline, counseling preferences were significantly more likely to be for information than for support (Z=- 298, p=0.003). | 51 family members of proband invited, 34 agreed to participate, consent form returned by 31 of whom four subsequently declined and one withdrew for “practical” reasons. | This exploratory study indicates that shortening genetic counseling may be an appropriate means of supporting decisions already made by individuals about HNPCC testing. However, participants would benefit from preparatory information to help them reflect on issues not previously considered, which can then be explored more fully as part of a tailored counseling approach. | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | Questionnaires administered prior to and immediately after counseling (two “in house” measures and “validated measures” of systemic decision-making, satisfaction and psychological distress Also qualitative interviews. | Participants were very positive in their evaluations of genetic counseling, reporting high levels of satisfaction with the information and support received in both groups (p=0.13). | | | No details regarding baseline familiarity, education level and other potentially relevant characteristics across study groups to assure randomization was successful.
| Yes | No | Uncl | | | There were high levels of decision satisfaction regardless of study group (p=0.40).
| | X | | | | Levels of psychological distress were not significantly different (p=0.98).
| | | | | | The effect of counseling protocol on knowledge was not significant.
| | | | | | Analysis of counseling sessions indicated that counselor's reflective questions occurred equally in both protocols.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | X | 8b,8c | 1,6b,9,10,11
| | | | 8a
Public health or policy | 2,3 | 5 | 9 | X | 8b,8c | 1,6,a,6b,7,10
| | | | 8a

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | X | ND | NA
| | | <60
Allocation Bias | | | | | | A | B | X
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Is the method of random allocation stated? | Yes | X
| | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | X
| | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | X
| | | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | X | ND | NA
| | | <60
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | Yes | X | ND
| | No
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | X | ND | NA
| | | <60
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | X | NA
| | | ND
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Brodersen, N 2004, Ref 385 Multicenter UK
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Cross sectional study to examine anticipated reactions to genetic testing for HNPCC in 437 asymptomatic people with a family history of colorectal cancer | Amsterdam 1 criteria/mutations | | | Registered with St. Mark's family cancer clinic as being at increased risk for CRC because of a family history. | Questionnaires (non-validated) regarding anticipated emotional response and intended actions upon receiving test results. | A number of significant differences between men and women in anticipated emotional response. More women anticipated feeling fairly or extremely worried if they did not have the test (36 versus 23 percent, p =0.009) or if the test was positive (64 versus 40 percent, p =0.008). | 743 questionnaires sent out, 516 returned (71%), 79 who had cancer excluded. | The emotional effects of receiving a test result are unlikely to be much more severe than the effects of choosing not to have a genetic test, and in some cases not having a genetic test is likely to result in a poorer emotional adjustment. Women anticipate more extreme emotional reactions than men. | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | All receiving regular colonoscopy screening. | | More women anticipated that they would feel fairly or extremely regretful if the test showed that they were at high risk (30 versus 20 percent, p =0.03). | | | Access, educational levels, familiarity with CRC screening or HNPCC not described.
| Yes | No | Uncl | No FAP in family. | | More women thought that they would feel fairly or extremely angry if the test showed that they were at high risk (33 versus 13$, p <0.001).
| | X | | No personal history of cancer. | | There was only one significant difference between men and women in anticipated reaction following genetic testing: if at low risk more women then men would try to adopt a healthier lifestyle (p=0.007.
| | | | | | When asked if they would have more screening if found to be at high risk, 416/432 (96%) said that they probably (23%) or definitely (74%) would.

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
| X
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
| X
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
| | | X
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
| | X
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
| | X
Were data collection tools shown or are they known to be reliable? | Yes | No
| | X
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
| X
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation | Yes | Partially | No
| | | X
Is there a statistically significant difference between groups? | Yes | No | ND
| X
Are the statistical methods appropriate? | Yes | No | ND
| X
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study: Christensen, M 2002

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Multicenter, Denmark | MSH2 and MLH1 genes sequenced in 31 patients. | hMLH1 and hMSH2 | | Y | N | ? | Am 1 | | ND
42 patients with colorectal cancer selected based upon clinical and family history meeting either Amsterdam I criteria (n=11) or a suggestive family history. | MSI obtained in 35 patients | | ≥5 MSI markers used? | X | | | Am R
| IHC performed in 40 patients. Compared sensitivity/specificity of these tests against sequencing as the reference standard. | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1
| | | Microdissection? | | | X | Beth R
| | | Gene screening? | X | | | MSI-H | X
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC | X
| | | | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
42 enrolled, all analyzed as above, sex not described, age not described | MMR detected in 13/42 patients [Note that only 31 pts got gene sequencing!] | 11/42 Amsterdam I | There was concordance between sequencing and the combined MS/IHC approach for 94% (16/17) tumors. | IHC should be used in combination with MSI analysis to prescreen suspected HNPCC patients for selection for sequencing. | ND | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 4/11 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
| 8 hMSH2 5 hMLH1 (one patient had both) | 11/25 tested had MSI-H | Concordance among the three methods was found for 74% (17/23) tumors | | | Authors did not explain how patients were selected for sequencing or index tests. Had incomplete verification in cohort. | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | 9/29 tested had lack of staining on IHC | | | | | | Other (specify) | | | Am 1 + | X
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | 8/11 | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | 4/11 | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify) | X
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients who fulfilled Amsterdam I or were otherwise considered at increased risk for HNPCC | Am 1 + | | + | (A) 11 | (B) 6
| Am R + | | - | (C) 1 | (D) 16
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients who fulfilled Amsterdam I or were otherwise considered at increased risk for HNPCC | Am 1 + | | + | (A) Only one patient has MSI-L so not extracted | (B)
| Am R + | | - | (C) | (D)
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L* | X
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients who fulfilled Amsterdam I or were otherwise considered at increased risk for HNPCC | Am 1 + | | + | (A) 9 | (B) 3
| Am R + | | - | (C) 4 | (D) 15
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | X
| Other (specify)**

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | X
7 | Were withdrawals from the study explained? | | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Claes, E 2004, Ref ID337 Single center, Belgium
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Describe motivation, recall of cancer risks and illness representations of 40 individuals who had a predictive test for HNPCC. | Mutation | | | Self-referred unaffected persons who had a predictive test for HNPCC. | Surveys pretest and one-month post-test | Motivation for predictive testing: Most common motivations cited were early detection of CRC (95%), early detection of endometrial cancer (93%), knowledge of children's risk (70%), reduction of uncertainty (38%). | 40/48 included | “Our results in the first applicants of predictive genetic testing for HNPCC who came forward on their own initiative within our clinic-based genetic testing program illustrate that predictive genetic testing did not induce major short-term psychological problems and/or reluctance to adopt health-related behavior in the future when it is offered in the context of a multidisciplinary approach.” | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Recall and perception of risk: 36/40 correctly recalled the 50% risk of being a mutation carrier | 1 patient who had difficulty concentrating | | Small sample, highly-selected (since self-referred). Followup short. Some data collected by telephone and others by written instrument; unclear if mode of administering affected the results.
| Yes | No | Uncl | | | Awareness of cancer risk: The majority provided an “accurate” estimation of the lifetime risk of developing CRC. | 1 patient did not fill in survey
| | X | | | | Distress (STAI-Trait scale): Differences between carriers and non-carriers regarding mean pre- and post-test IES scores for colorectal cancer and State-anxiety were not statistically significant. Although there was a decrease of distress over time in the total group, the decrease was only significant for State-anxiety and avoidance for colorectal cancer. The difference between pre- and post-test scores in the subgroup of carriers was not statistically significant while the decrease in the group of non-carriers was statistically significant for State-anxiety (Wilcoxon signed ranks test, P < 0.01) | 2 patients who were >70
| | | | | | Early detection behavior: 26/40 had at least one colonoscopy before predictive testing. All carriers had the intention of having colonoscopies on a regular basis. All female carriers had intention of having yearly examinations of the endometrium. The majority of noncarriers either did not have the intention to have a colonoscopy or only when indicated. | 4 did not fill out survey at 1 month

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | X | 60–79 | <60 | ND | NA
| 80–100
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | X | 60–79 | <60 | ND | NA
| 80–100
Analysis | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | X | 60–79 | <60 | ND | NA
| 80–100
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | X | ND | NA
| | No
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Claes, E 2005 Ref ID 185. Note same patients as Claes, E 2004, Ref ID337 Single center, Belgium
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Evaluated illness representations, distress, and health-related behavior one-year after disclosure of predictive genetic tests results for HNPCC in 36 carriers and 36 noncarriers. | Mutations | | | Predictive testing offered to unaffected persons from families in which a DNA MMR mutation had been identified. | Surveys before and one-year after predictive testing. | General distress: Mean scores within normal ranges or lower than population means. Carriers and noncarriers did not differ significantly before testing but carriers had significantly higher scores than noncarriers on cancer-specific distress scores for CRC and endometrial cancer. | One excluded because of difficulty concentrating others because age >70. | “Our study did not reveal major psychological problems, measured by psychometric measurements, as a consequence of predictive testing when offered in the context of a multidisciplinary counseling context. However, interview data indicated some individually different problems specifically related to the predictive test (e.g. worry, difficulties in relation to other relatives burden of regular follow-up). The presented data are promising regarding the impact on health-related behavior.” | B
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | Excluded age >70 | | Impact of genetic testing result: about ½ of carriers (19/36) and less than 20% of noncarriers (6/36) reported at least one disadvantage of knowing the predictive test result. The main reported disadvantages for carriers were “burden of regular medical examinations” (22%) and the psychological burden (20%). The main disadvantage for noncarriers was that they experienced difficulties due to their favorable test results toward carrier relatives (e.g. survivor guilt). | 72/79 participated. | | Highly-selected (since self-referred). Some data collected by telephone and others by written instrument and not clear if mode of administering affected the results.
| Yes | No | Uncl | | | All but one carrier and all but 2 noncarriers reported at least one advantage. The two advantages most cited by carriers were “instrumental advantage” (89%) and certainty/reduction of uncertainty (33%). For noncarriers, the two most cited advantages were “reassurance” (50%) and the fact that the children were not at risk anymore (39%).
| | X | | | | Health-related behavior within the year after the predictive test: 11 carriers (31%) never had a colonoscopy prior to genetic testing. Within the year after disclosure, 27 carriers had a colonoscopy. The three who did not were <25. Thus, compliance with recommendation was 100%.
| | | | | | 22 noncarriers (61%) had at last one colonoscopy prior to genetic testing. None had a colonoscopy within the year after testing.

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | X | 60–79 | <60 | ND | NA
| 80–100
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | X | 60–79 | <60 | ND | NA
| 80–100
Analysis | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | X | 60–79 | <60 | ND | NA
| 80–100
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | X | ND | NA
| | No
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Codori, A 1999, Ref ID 2053 Single center, USA
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Evaluated uptake of genetic testing for HNPCC among 1^st^-degree relatives of CRC by comparing 77 test acceptors and 181 decliners. | Amsterdam criteria I or mutation in family. | | | >18, no personal history of CRC, at least one 1^st^-degree relative with CRC. | Invitation to undergo genetic counseling | Significant predictors of acceptance on multivariate analysis were: perceived ability to cope with a positive gene test result, risk perception, frequency of thoughts about CRC (not at all or rarely versus sometimes or more) and CRC screening history. | ND | “Our study showed that people who believe they will get CRC, think about getting it, believe that they can cope with the “bad news,” and already engage in cancer prevention behaviors are more likely to be tested.” | B
505 1^st^-degree relatives of CRC from 118 kindreds invited to participate. Final sample included 77 acceptors and 181 decliners (see intervention for definitions). | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | Flow: 505 invited; 233 interested 264 not interested and 8 undeliverable. Of the 233 Interested, 104 completed phase I (8/104 withdrew, 19/104 entered phase 2 awaiting blood draw and 77/104 entered phase II and had blood draw). Of the 264 not interested 247 were called for interview (the remaining have not been interviewed yet); 181/147 completed the interview. | Acceptors = accepted counseling and testing | Coping: ≥90% confident OR 4.0 (95% CI 1.53–10.3, p=0.005) | | | Validity of survey instruments and telephone interviews were not established.
| Yes | No | Uncl | | Decliners = declined counseling and testing | CRC screening: never had a colonoscopy (OR 0.45, 95% CI 0.21–0.93, p=0.030)
| | X | | | Decliners had telephone interview, acceptors filled out a questionnaire | Cancer thoughts: Rarely/never versus sometimes, often, a lot: OR 0.44 95% CI 0.17–1.13, p =0.088)

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | X | ND | NA
| | | <60
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | X | No | Can't tell
| Yes
If there were differences between groups for important confounders, were they adequately managed in the analysis? | X | No | NA
| Yes
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | X
| | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | X | ND | NA
| | | <60
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | X | ND | NA
| | | <60
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | X | NA
| | | ND
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Collins, V 2005, Ref ID 140 Multicenter, Australia
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
134 invited to participate, 114 returned the baseline questionnaire, 98/114 returned a follow-up questionnaire | Mutation. | | | Individuals undergoing predictive genetic testing at 1 of 5 familial cancer clinics in Australia between1998-2002. Individuals were eligible who had never had CRC or any of the cancers associated with HNPCC. They were excluded if they had limited literacy in English. | Surveys | Of 114 participants, 32 identified as MMR carriers and 82 as noncarriers. | ND | The majority of individuals reported appropriate screening behaviors after predictive testing for HNPCC. The small group of noncarriers who had screening after genetic testing might benefit from additional counseling. | B
Evaluate screening and preventive behaviors following predictive testing for HNPCC. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | At baseline, 3/12 <25 and 74/101 ≥25 reported a colonoscopy. On multivariate analysis, perceived risk of developing bowel carcinoma was the only variable significantly associated with having a colonoscopy (OR 103, 95% CI 1.00–1.05, p=.03) | | | 12 month data subject to Hawthorne Effect. Self-report without attempt at verification of procedures. Issues of access to screening procedures not addressed.
Annual colonoscopy beginning at age 25 or 5 years earlier than youngest affected family members recommended in those at risk for HNPCC. Those not carrying the mutation are advised to follow population screening guidelines. | Yes | No | Uncl | | | At 12-month follow-up, 71% of carriers reported having a colonoscopy in the 12 months since receiving their genetic results. Among noncarriers, 8 (12%) also reported a colonoscopy.
Endometrial screening “can be considered” from age 30–35 or even 25 generally with annual transvaginal ultrasound and endometrial sampling in premenopausal women and annual transvaginal ultrasound and CA 125 testing for postmenopausal women. Prophylactic oophorectomy and TAH also considered for known mutation carriers ages 30 to 35 or when childbearing is complete. | | X | | | | A significantly higher proportion of those who reported a colonoscopy were mutation carriers or women. This group also had higher levels of perceived risk. However, only carriers status was statistically significant in a multivariate model (OR 20, 95% CI 5.8–68, p<.0001).
| | | | | | At baseline 19/63 women (30%) reported ever having a transvaginal ultrasound and 4/58 (7%) an endometrial sampling. At 12 months, 47% (8 of 17)of carriers reported having a transvaginal ultrasound and 53% (9 of 17) endometrial sampling. 39 noncarriers reported either a transvaginal ultrasound (10%) or endometrial sampling (5%).
| | | | | | At baseline, no one reported having a prophylactic colectomy; at 12 months, one indicated intention to do so.

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | X | 60–79 | <60 | ND | NA
| 80–100
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | X | 60–79 | <60 | ND | NA
| 80–100
Analysis | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | X | 60–79 | <60 | ND | NA
| 80–100
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Study: Colombino 2005

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have at least one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Multicenter, Italy 362 patients proven to be of Sardinian origin with histologically proven CRC. | Family history assessed. Patients classified as sporadic if no CRC in 1^st^ and 2^nd^-degree relatives, low familial recurrence if one additional family member, familial if at least three family members. HNPCC diagnosed based on Amsterdam criteria. Patients with familiar CRC underwent gene sequencing Sporadic were screened for mutations identified in “familial” | hMLH1 and hMSH2 | | Y | N | ? | Am 1 | X | Compared mutations to 103 unrelated normal individuals
All are consecutive, unselected CRC patients | | | ≥5 MSI markers used? | | | | Am R | | There were 8 different mutations and half of them were missense.
| | | MSI-H defined by ≥ 2 markers? | | | | Beth 1 | | No separate data given, unfortunately
| | | Microdissection? | | | | Beth R
| | | Gene screening? | X | | | MSI-H
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | | | | | Age <50 | X
| | | | | | | Suggestive family history | X
| | | | | | | Specify As in inclusion criteria
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
179/362 men=49% Median age at dx 60 (27–87) | Of 48 patients tested, 14 had a germline MMR: 12 on MSH2, 2 in MLH1 | 103/362 “familial” 55/162 two cases 48/362 had at least three family members 13/362 fulfilled Amsterdam | ND | Strongly reaffirms several previous predictors (earlier diagnosis age, presence in family of three or more CRC) for occurrence of MLH1 and MSH2 mutations | ND | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 10/13 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
| | | | | | Incomplete verification and reporting. | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | ND | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify) | X
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with one additional family member with CRC vs sporadic | Am 1 + | | + | (A) 16 | (B) 87
| Am R + | | - | (C) No data (5) | (D) No data (254)
| Beth 1 + | | | In parentheses, because the “sporadic” were screened only for the mutations found in the “familial”
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| Among 103 with >=2 CRC in family

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Two cases in family | Am 1 + | | + | (A) 2 | ((B) 53
| Am R + | | - | (C) No data | (D) No data
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
3 cases in family | Am 1 + | | + | (A) 14 | (B) 35
| Am R + | | - | (C) No data | (D) No data
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
| Am 1 + | X | + | (A) 10 | (B) 3
| Am R + | | - | (C) | (D)
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Age <= 45 | Am 1 + | | + | (A) 6 | (B) 55
| Am R + | | - | (C) No data | (D) No data
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | | X
7 | Were withdrawals from the study explained? | | | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | | | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Curia 1999

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | x
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | x
Was a minimum of hMLH1 and hMSH2 sequencing performed? | x

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
30 unrelated HNPCC patients from the files of the University of Florence; 17 has Amsterdam criteria | SSCP and sequencing were done in all patients; IHC were done in 24 patients; MSI were done in 22 patients | HMLh1 and hMSH2 | | Y | N | ? | Am 1 | | Based on the literature, predicted alteration and contrast with controls
26 have CRC and 15 are Am1 among them | We caution that the MSI and IHC data are completely convenience-based | | ≥5 MSI markers used? | | X* | | Am R
| | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1
| | | Microdissection? | X | | | Beth R
| | | Gene screening? | X | | | MSI-H
| | | Deletion analysis? | | X | | MSI-L
| | | Conversion analysis? | | X | | IHC
| | | They screened with 3 and if none was unstable up to a total of 7. | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsattelite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
30 unrelated patients, but only 26 have CRC | 7 hMLH1 and 5 MSH2 (3 pathogenic, 4 uncertain, 5 polymorphisms) in 30 unrelated patients | 15/26 eligible were AM1 | Notably, the lack of hMLH1 or hMSH2 immunostaining and microsatellite instability were observed in tumors from patients in whom a pathogenic mutation could not be identified by SSCP screening of the coding sequence. | Constitutional alterations in hMLH1 and hMSH2 transcript expression may represent genetic markers for HNPCC carrier status also in cases in which mutational analysis did not detect a definite pathogenic variant. | | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | x | 1/15 Am1 Eligible has pathogenic mutation | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | x
| Pathogenic: 3 (2mlh1, 1 msh2) | Unclear if 2 or 1 they refer to “Am criteria” | | | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | 23/26 were <50 y | | | | | | Other (specify) | | | Am 1 +
| | 12/26 were <40y | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | 12/15 were MSI-H (Am1) | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | 7/15 had IHC (Am1) | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Unrelated patients with HNPCC | Am 1 + | X | + | 1 | 16
| Am R + | | - | 2 | 11
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Unrelated patients with HNPCC with available specimens | Am 1 + | | + | 1 | 13
| Am R + | | - | 0 | 10
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | X
| Other (specify)**
| MSI only

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Unrelated patients with HNPCC with available specimens | Am 1 + | | + | 1 | 18
| Am R + | | - | 0 | 3
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI unstable | X

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | | X
2 | Inclusion criteria clear? | | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | x
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | x
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | | x
7 | Were withdrawals from the study explained? | x
8 | Did the authors report AND analyze results for deleterious MMR mutants | x
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | x
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | x
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | x
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | | | x
14 | Were quality control methods described for the molecular and genetic tests? | | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | | x
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: De Abajo 2005

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Referrals to the clinic for familial cancer at the San Carlos University Hospital in Madrid. | All tested for MLH1 and MSH2 and the ones who were negative were tested for MSH6 too. | MLH1 | | Y | N | ? | Am 1 | X | Predicted alteration; comparison with 100 controls; literature and databases
All index cases were CRC | | MSH2 | ≥5 MSI markers used? | X | | | Am R | X
| | MSH6 (among negative for the above) | MSI-H defined by ≥ 2 markers? | X | | | Beth 1 | X
| | | Microdissection? | X | | | Beth R
| | | Gene screening? | X | | | MSI-H
| | | Deletion analysis? | | X | | MSI-L
| | | Conversion analysis? | | X | | IHC
| | | The NCI/Bethesda marker ser was used | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
132 nd on age and sex dropouts NA (only 19 not MSI-typed ) | 24 mlh1 | 56/132 AM1 | NA | MSH6 disease causing mutations are very infrequent in Spanish CRC referral cases | ND | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | AM1 → 32/56 (MLH1 and MSH2) and 1/56 MSH6 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | X
| 17 msh2 | 67/132 AM2 | | | | | | Amsterdam R | | AM2 → 36/67 (MLH1 and MSH2) and 3/56 MSH6 | If yes, which clinical criteria (check all that apply)?
| 3 msh6 | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | Am1 → 42/55 analyzed were MSI-H | Am R +
| | | | | | | | Amsterdam R | | Am2 → 44/62 analyzed were MSI-H | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Referrals to the clinic for familial cancer at the San Carlos University Hospital in Madrid. | Am 1 + | X | + | 33 | 23
All index cases were CRC | Am R + | | - | 11 | 65
MSH6 is included | Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Referrals to the clinic for familial cancer at the San Carlos University Hospital in Madrid. | Am 1 + | | + | 39 | 28
All index cases were CRC | Am R + | X | - | 5 | 60
MSH6 is included | Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Referrals to the clinic for familial cancer at the San Carlos University Hospital in Madrid. | Am 1 + | | + | 44 | 60
All index cases were CRC | Am R + | | - | 0 | 28
MSH6 is included | Beth 1 + | X
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Among AM2 patients MSH6 is included | Am 1 + | X | + | 33 | 23
| Am R + | | - | 6 | 5
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Among Beth patients MSH6 is included | Am 1 + | | + | 39 | 28
| Am R + | X | - | 5 | 37
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Among Beth patients MSH6 is included | Am 1 + | X | + | 33 | 23
| Am R + | | - | 11 | 37
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | X
7 | Were withdrawals from the study explained? | | | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Debniak 2000

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
168 consecutive patients with CRC in whom FAP was excluded. | IHC performed in all patients | MLH1, MSH2 | | Y | N | ? | Am 1 | | ND
GROUP B: 25were SHNPCC based on age <=40, familial HNPCC-related Ca or synchronous or Metachronous Ca 143 were the rest, apparently sporadic: GROUP A: 43/143 Patients apparently sporadic, ie a) late-onset (>40) no family history of HNPCC-related tumors and no syn-or metachornous cancer presumably sporadic Poland Center | MSI examined in all | | ≥5 MSI markers used? | X | | | Am R
| Sequencing performed in all from group B and those from group A that showed abnormal IHC or MSI | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1
| | | Microdissection? | | | X | Beth R
| | | Gene screening? | | | X | MSI-H | X
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC | X
| | | | | | | Age <50
| | | | | | | Suggestive family history | X
| | | | | | | Specify Absence of sporadic criteria
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsattelite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
168 but only 68 analyzed, age ND, dropouts ND | 6 mutations detected of the 68 included | Group A: normal protein expression in 42/43 | Among 9 patients with MSI 2 were “probably abnormal” for protein staining. | Performing pedigree analysis/clinical data (for exlusion of late-onset sporadic CRC) in conjunction with IHC was lowest cost but missed 1/6 mutations. Additional preselection by IHC and MSI was required to detect all mutations. | ND | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 1/3 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X | X
| 4 MLH1 | 1 patient probably negative staining MSI present in 4/43 tumors | | | | Not clear how “sporadic” subgroups was chosen | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| 2 MSH2 | Group B: Normal protein expression 18/25 tumors | | | | | | Other (specify) | | | Am 1 +
| | Staining definitively negative MLH1 3 cases, MSH2 in two while in 2 patients, MLH1 was probably absent | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | 2/3 | Am R +
| | MSI was present in 9/25 cancers | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | 2/3 | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify) Absence of criteria that suggested sporadic disease above: Also performed testing on a sample ? random of low-risk population | x

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Selected patients considered to Have sporadic colorectal cancer Because of absence of clinical Features suggestive of HNPCC PLUS a group of patients considered To be at high risk for HNPCC | Am 1 + | | + | (A) 5 | (B) 20
| Am R + | | - | (C) 0 | (D) 43
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| Suggestive family History as above | X

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with clinical history Suggestive of Lynch syndrome | Am 1 + | | + | (A) 5 | (B) 4
| Am R + | | - | (C) 1 | (D) 15
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with clinical history Suggestive of Lynch syndrome | Am 1 + | | + | (A) 1 | (B) 1
| Am R + | | - | (C) 5 | (D) 18
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | X
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with clinical history Suggestive of Lynch syndrome | Am 1 + | | + | (A) 5 | (B) 2
| Am R + | | - | (C) 1 | (D) 17
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| IHC OR MSI | X

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients without a clinical history Suggestive of Lynch syndrome | Am 1 + | | + | (A) 0 | (B) 1
| Am R + | | - | (C) 0 | (D) 42
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50 | X
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients without a clinical history Suggestive of Lynch syndrome | Am 1 + | | + | (A) 0 | (B) 5
| Am R + | | - | (C) 0 | (D) 38
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| IHC OR MSI | X

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | X
7 | Were withdrawals from the study explained? | | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Dieumegard 2000

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Multicenter, France | All patients tested for MSI. Patients with MSI-H and nine MSS cases underwent germline testing for MMR. IHC was performed in all but 4 patients. | hMLH1 and hMSH2 | | Y | N | ? | Am 1 | X | Reported results as “non-ambiguous:(frame-shift or splice site) and missense”
34 patients with CRC who represented one of three groups: 1) Amsterdam I criteria 2) Incomplete Amsterdam (missing at least one criteria but strong family history) 3) Age <50 and absence of HNPCC-related cancer sin family | | | ≥ 5 MSI markers used? (20 markers) | X | | | Am R
| | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1
| | | Microdissection? | | | X | Beth R
| | | Gene screening? | X | | | MSI-H | X
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC | X
| | | | | | | Age <50
| | | | | | | Suggestive family history | X
| | | | | | | Specify See inclusion criteria
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
34: 10 group 1, 7 group 2 and 17 group 3, sex not described Age at cancer diagnosis group 1 26–55 (range), group 2 37–56, group 3 17–50 | 6 patients with MMR in group 1, 3 in group 2 and none in group 3. In total, 9 MMRs detected 6 inMLH1 and 3 in MSH2 | 15/34 MSI-H Lack of protein expression observed in 10 tumors (of 30 who had complete testing) | Lack of protein expression in 10 tumors all being MSI-H. All sporadic MSS tested had normal staining. | Simple tests such as MS study combined with hMSH2 and hMLH1 protein immunostaining performed on tumor tissues may provide valuable information to distinguish between familial and probably hereditary, and sporadic CRC cases | ND | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 6/10 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased?
| | | | | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 + | X
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | 9/10 | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | X | 4/8 (not all tested) | Age <50 | X
| | | | | | | | Amsterdam R | | | Suggestive family history (specify) Amsterdam I except missing 1 criteria | X
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients fulfilling Am 1 | Am 1 + | | + | (A) 6 | (B) 3
| Am R + | | - | (C) 0 | (D) 1
| Beth 1 +
| Beth R +
| MSI-H*+L | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients fulfilling Am 1 | Am 1 + | | + | (A) 2 | (B) 2
| Am R + | | - | (C) 2 | (D) 2
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | X
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients fulfilling Am 1 minus 1 criteria | Am 1 + | | + | (A) 3 | (B) 3
| Am R + | | - | (C 0 | (D) 1
| Beth 1 +
| Beth R +
| MSI-H*+L | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients fulfilling Am 1 minus 1 criteria | Am 1 + | | + | (A) 2 | (B) 3
| Am R + | | - | (C) 1 | (D) 0
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | X
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients age <50 and no family History of HNPCC cancers | Am 1 + | | + | (A) 0 | (B) 0
| Am R + | | - | (C) 0 | (D) 7
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients age <50 and no family History of HNPCC cancers | Am 1 + | | + | (A) 0 | (B) 0
| Am R + | | - | (C) 0 | (D) 7
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | X
| Other (specify)**

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | X
7 | Were withdrawals from the study explained? | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e.avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Dove-Edwin, 2002 UK, The Netherlands Multicenter
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
UK family clinic: 184 women from HNPCC (67) or HNPCC-like families (117) had annual or biennial endometrial carcinoma surveillance by ultrasound. Amsterdam Criteria had not yet been established so modification included no cancer cases under 50 years, or cases of endometrial carcinoma | Amsterdam Criteria | | | See study description | Annual or biennial endometrial transvaginal ultrasound scan, if unavailable transabdominal pelvic scans recommended | 522 scans carried out with ration of 0.63 for years scanned/years of risk. No cases of endometrial carcinoma detected by ultrasound but one case each of endometrial carcinoma from each group. Both women had hMLH1 mutation | 292 women offered screening - data on 269 (171 from HNPCC families, 98 from HNPCC-like families). Limited data on dropouts - 8 died from unrelated causes | “Endometrial carcinoma surveillance in hereditary colorectal carcinoma may not offer obvious clinical benefits.” | B
The Netherlands registry: 108 women from 38 HNPCC families had transvaginal ultrasound scan annual or biennial. 25 families were AC positive, 3 ACII positive, 10 families suggestive of HNPCC and HNPCC mutations present | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | Netherlands registry: Women were advised to have a transvaginal ultrasound scan annually or biennially from age 30–35 years.
| Yes | No | Uncl
| | X

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study: Durno C 2005

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Multicenter, Canada | Tumors analyzed for MSI, IHC and blood for MMR | hMLH1 and hMSH2 and PMS2 (select patient not described who) | | Y | N | ? | Am 1 | X | ND
Patients with CRC at ≤ age 24 (selected from a total of 1382 patients in a cancer registry. | | | ≥5 MSI markers used? | X | | | Am R | X
| | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1
| | | Microdissection? | X | | | Beth R
| | | Gene screening? | X | | | MSI-H | X
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC | X
| | | | | | | Age <50
| | | | | | | Suggestive family history | X
| | | | | | | Specify Age ≤ 24
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
N=16, all analyzed, 6/16 = 38% male | MMR 6 of 12 tested; 2 with MLH1, 3 with MSH2 and 1 with PMS2 | 8/16 fulfilled revised Amsterdam criteria | ND | Patients with early onset CRC often have an inherited predisposition to the disease. Tumors with MSI-H and germline MMR mutations are sufficiently common in this population that they should be considered even though family histories may not satisfy the stringent Amsterdam criteria for HNPCC. | 7/16 patients developed a second cancer during followup (mean 1.8 years). Majority (75 %), were in the GI tract. | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 3/5 Amsterdam 1 (not all patients were tested) | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased?
| | MSI-H 11/16 | | | | Partial verification: IHC/MSI/MMR were tested only in a subset of patients and authors did not explain why. Extent of gene testing seemed to vary but authors did not explain why. | | Amsterdam R | X | 3/6 Amsterdam 2 (not all patients were tested) | If yes, which clinical criteria (check all that apply)?
| | IHC abnormal in 2 of 8 tested | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | 4/6 (not all tested) | Am R +
| | | | | | | | Amsterdam R | X | 4/6 Am2 (ie the Am1) | Beth 1 +
| | | | | | | | Other (specify) | | no other Am R were tested | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | X | 1/5 Amsterdam I | Age <50
| | | | | | | | Amsterdam R | X | 1/5 Am2 (ie the Am1) | Suggestive family history (specify) | X
| | | | | | | | Other (specify) | | no other Am R were tested | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
CRC ≤ age 24 | Am 1 + | | + | (A) 5 | (B) 3
| Am R + | | - | (C) 0 | (D) 1
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
CRC ≤ age 24 | Am 1 + | | + | (A) 3 | (B) 1
| Am R + | | - | (C) 1 | (D) 3
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | X
| Other (specify)**

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding) | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | X
7 | Were withdrawals from the study explained? | | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing….i.e. avoid verification bias)?
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Farrington, SM 1998

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
50 unrelated patients with CRC at age <30 identified retrospectively from cancer registrations since 1970 compared with 26 age matched volunteers without cancer. | Detailed family history obtained from cases, paraffin-embedded archival tumor material obtained along with matched normal tissue from 42 patients. Tumor and normal tissue analyzed for MSI. Genomic sequencing done on all patients and controls using peripheral blood. | hMSH2 and hMLH1 | | Y | N | ? | Am 1 | X | “[mutations] not considered pathogenic unless either there was a nonconservative amino acid change or the variant arose at a conserved sequence around a splice site”
Edinburgh, Scotland, Single center | | | ≥5 MSI markers used? | X | | | Am R
| | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1
| | | Microdissection? “Only areas with >90% tumor tissue used” | X | | | Beth R
| | | Gene screening? “genomic sequencing and IVSP analysis” | X | | | MSI-H
| | | Deletion analysis? | X | | | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history | X
| | | | | | | Specify 4 categories: 0= no family hx; 1= relative with non-CRC; 2 = relative with CRC but not Amsterdam,; 3 =Amsterdam

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g., of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
50 patients enrolled of whom 42 samples could be assessed for MSI | 14 mutations identified from 50 patients (7 hMLH1, 7 hMSH2) | MSI-H 19/50 | As below | IVSP complemented genomic sequencing by detection of mutations not identified by genomic analysis….An appreciable proportion of young colon cancer probands carry a germ-line mutation in a DNA mismatch-repair gene | Sensitivity of genomic sequencing 80% and IVSP 64%; IVSP and genomic sequencing complementary. | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 3/6 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
| | | | | | Population selected from a registry thus would have selected for survivors. If survival influenced by mutation status, assessment of prevalence of mutations may be biased. However, authors found no such association. | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | 5/5 (one did not have tissue for MSI) | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify) CRC <30 | X
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with CRC <30 | Am 1 + | | + | (A) 12 | (B) 7
| Am R + | | - | (C) 2 | (D) 19
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with CRC <30 | Am 1 + | | + | (A) 4 | (B) 10
| Am R + | | - | (C) 3 | (D) 8
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| Family history 1 vs family history 0 as noted above

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with CRC < 30 | Am 1 + | | + | (A) 7 | (B) 3
| Am R + | | - | (C) 3 | (D) 8
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| Family history 2 vs family history 0 as noted above

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with CRC < 30 | Am 1 + | | + | (A) 3 | (B) 3
| Am R + | | - | (C) 3 | (D) 8
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| Family history 3 vs family history 0 as noted above (i.e. Amsterdam 1 positive)

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | | X
7 | Were withdrawals from the study explained? | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing….i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Fujita, 1996 (RefID 2533) UI 8895676 Japan Single center
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
3356 patients with CRC underwent surgery and follow up between 1968 and 1993. They were classified into 4 categories: | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | Subjects who died within 30 days of surgery were excluded from calculation | | 5-year survival rate: | Not all patient with CRCs were accounted for? | “Prognosis of HNPCC is better than that of sporadic CRC, and Japanese A criteria can be used to select putative HNPCC patients from among those with sporadic CRC.” | B-
Amsterdam 14 | Yes | No | Uncl | | | Amsterdam 92.3%
Japanese A 31 | x | | | | | Japanese A 81.2%
Japanese B 100 | | | | | | Japanese B 66.5%
Sporadic 1604 | | | | | | Sporadic 60%
Kaplan-Meier was performed | | | | | | The first 2 groups were better than the latter 2 groups (P<0.05).

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
| X
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
| | | | X
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can'tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Graff 2005; Ref ID 125 Single center Australia
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Investigated experiences of 12 individuals with HNPCC in a semi structured telephone interview. All patients had been asked to inform family members. | Pathogenic mutation causing HNPCC | | | Pathogenic mutation, English speaking, excluded those with inconclusive test results. All had received genetic counseling. All had an HNPCC-related cancer. | Semi-structured telephone interview. | 12 subjects (4 men and 3 women) Respondents older than nonrespondents (55 versus 49), had more cancer diagnoses per individual and were more likely to be female (no statistical comparisons made). | 19 invited, 2 declined and five failed to respond | Respondents informed their immediate family about the availability of genetic testing but more distant relatives were not directly informed. Men expressed a need for guidance or support in communicating to relatives more than women. Letters and booklets were thought to enhance the quality of information. | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | All had told some (mainly immediate family) at-risk family members about predictive testing. | | | Very small sample size. No information about experience of probands (e.g., with screening or cancer treatment), which might have influenced their attitude. No validation of what relatives were actually told.
| Yes | No | Uncl | | | Family reactions ranged form interest to disinterest.
| X | | | | | Men expressed a need for guidance and support in communicating to relatives more than women.
| | | | | | Letters and booklets were thought to enhance the quality of information but further aids were unlikely to increase the number of relatives made aware of predictive testing by the probands.

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | 80–100 | X | <60 | ND | NA
| | 60–79
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | | X | Can't tell
| Yes | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | X | 60–79 | <60 | ND | X
| 80–100 | | | | NA
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | Yes | No | X
| | | ND
Are the statistical methods appropriate? | Yes | No | X
| | | ND
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | X | 60–79 | <60 | ND | NA
| 80–100
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Green S 1995, Ref ID 2706 Single center UK.
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Data on all screening colonoscopies performed in 61 HNPCC family members from start of a screening program in 1990-1994 analyzed. | Amsterdam I criteria | | | Member of family fulfilling Amsterdam I criteria and undergoing a colonoscopy. | Analysis of colonoscopy results. | 2 patients (3 %) had a malignant neoplasm (one Dukes B and the other dukes C) at ages 66 and 41, respectively. Another patient presented with an obstructing sigmoid carcinoma. Seven patients had adenomas (mean age 45.3, range 26–63). | ND | These findings support the hypothesis that adenomas do not occur in large numbers in HNPCC families but, because of the high malignant conversion rate, biennial colonoscopy with removal of polyps is recommended. | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | | | | Retrospective, uncontrolled, small sample size, unclear if data collection methods were valid.
| Yes | No | Uncl
| | X

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | X
| | | | | | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | X
| | | | | | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | X
| | | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Analysis | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | Yes | X | ND
| | No
Are the statistical methods appropriate? | Yes | No | X
| | | ND
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | X
| | | Can't tell
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | X
| | | | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Gritz E 2005, Ref ID 227 Single center US. Note, same patients as Vernon, SW: participation in colorectal cancer screening: a review. J Natl Cancer Inst 1997; 89:1406.
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
155 affected and unaffected persons with HNCC completed psychological tests before genetic testing and at 2 weeks, 6 and 12 months afterward. | Amsterdam or suggestive family history followed by mutation testing. (Not clear if original or revised Amsterdam). | | | ≥18 Probands: fulfilled Amsterdam or suggestive family history: Family of mutation positive probands at 25 to 50% risk of carrying a mutation. “Affected” included any index patients or relatives with a prior diagnosis of any cancer excluding non-melanoma skin cancer; unaffected included relatives with no personal history of cancer. | Short form of the Social support Questionnaire (SSQ). Center for Epidemiologic Studies Depression scale (CES-D) State anxiety subscale of the State-Trait Anxiety inventory (STAI-S). Ferrans and Powers Quality of Life Index (QQLI) Cancer worries scale Perceived risk of colorectal cancer | Affected participants: | 126 affected participated (79 families) but 15 (12%) did not receive their results. 178 unaffected relatives of mutation-positive index patients invited; 68 (38%) refused and 24 (13%) completed the questionnaire only. Of 86 unaffected who completed the questionnaire and gave blood samples for testing, 4 (5%) did not receive their results. Individuals who declined their genetic test results did not differ from those who received results on demographic or distress variables. | Although HNPCC genetic testing does not result in long-term adverse psychological outcomes, unaffected mutation carriers may experience increased distress during the immediate postdisclosure time period. Furthermore, those with higher levels of baseline mood disturbance lower quality of life, and lower social support may be at risk for both short and long-term increased distress. | A
Among 89 affected participants, 33 were HNPCC predisposing mutation carriers. Among unaffected participants, 19 were HNPCC mutation carriers and 47 were noncarriers who received definitive negative test results. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Nonwhites had significantly higher mean scores on the CES-D, STAI-S and RIES over time on all measures compared with whites; | | | Would have benefited if form more detail regarding effect of actual screening behaviors and issues related to access and psychological distress.
| Yes | No | Uncl | | | Those with lower educational levels had significantly higher scores than those who had higher educational levels.
| | X | | | | Carriers had significantly higher mean RIES scores at 2 weeks and 6 months postdisclosure compared with affected participants and uninformative results.
| | | | | | Scores decreased significantly form 2 weeks to 12 months postdisclosure except for those with uninformative results, which did not changed.
| | | | | | Unaffected participants:
| | | | | | Race or ethnicity were significantly associated with mean CES-D and STAI-S scores over time with nonwhites having significantly higher means scores compared with whites and those with lower educational levels having significantly higher scores compared with those who had higher educational levels. Nonwhites also had significantly higher mean RIES scores compared with whites.
| | | | | | Carriers had significantly higher mean RIES scores compared with noncarriers at the 2 week and 6 month postdisclosure time points. Post hoc comparisons showed a significant reduction in mean RIES scores for both unaffected carriers and noncarriers form 2 weeks to 6 months post disclosure.
| | | | | | Effect of baseline distress on postdisclosure outcomes:
| | | | | | Cluster analysis identified two well-defined subgroups for affected and unaffected participants using the mean baseline scores on the CES-D, STAIS-S, QLI, and SSQ scales: a high, and low-distress cluster. The proportion comprising the high-and lowdistress groups was the same among affected and unaffected participants (30.3%).
| | | | | | The high-distress groups had significantly higher scores (regardless of mutation status) at two weeks, 6 and 12 months postdisclosure. Cancer worries and perceived risk scores were not affected by distress, and changes in these scores were primarily related to mutation status.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | X | X | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | X | X | 8b,8c | 1,6b,9,10,11
| | | 9 | 8a
Public health or policy | 2,3 | 5 | X | X | 8b,8c | 1,6,a,6b,7,10
| | | 9 | 8a

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | X | <60 | ND | NA
| | 60–79
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | X
| | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Were data collection tools shown or are they known to be valid? | X | No
| Yes
Were data collection tools shown or are they known to be reliable? | X | No
| Yes
Withdrawals and Dropouts | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | X | <60 | ND | NA
| | 60–79
Analysis | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | X | <60 | ND | NA
| | 60–79
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Hadley, DW 2003, Ref ID 946 Multicenter, US (one author from Ireland but patients US). Same patients as Hadley Ref ID 657)
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Elucidate factors affecting decisions regarding genetic testing in individuals form families with newly identified HNPCC. | Mutations | | | Members of families with newly identified HNPCC with any of the following features: HNPCC-associated cancer demonstrating MSI or a family history suggestive of HNPCC and 1^st^ degree relatives at 50% risk of inheriting the mutation. | Individuals contacted by telephone, filled out baseline questionnaire, received genetic education, contacted by telephone 6 and 12 months later. | 104/165 (63%) eligible patients (including index cases and 1^st^ degree relatives agreed to participate. This included 54 probands (of whom 87% agreed to participate) and 111 family members of whom 51% agreed to participate. | ND | Genetic counseling and testing offers the potential to focus cancer screening resources in individuals truly at increased risk, thereby reducing mortality and morbidity. Fears of discrimination and concerns about psychological and psychosocial issues may present barriers to the use of current cancer prevention strategies, including genetic counseling and testing. | B
165 adult men and women from 15 families identified with HNPCC mutations invited to participate; 104 agreed to participate. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | Had to agree to fill out questionnaires, undergo counseling and participate in telephone interviews 6 and 12 months later. | | Awareness of genetic testing: those at higher household income levels were more aware of genetic testing for cancer (p=0.001) and colon cancer (p=0.009) than those at lower household income levels. There was no significant association between participants' awareness and age, sex, personal cancer history or number of 1sdegree relatives. | | | Surveys used had not been validated. Selection bias is likely to have influenced the results since almost one-half of family members declined to participate. Authors did not explore differences in those who declined from those who agreed. Access to resources not described. Perceptions about screening procedures, ability to prevent cancer not fully explored. Conclusions are not fully supported by data presented since mortality and morbidity were not a focus of the study.
| Yes | No | Uncl | | | Perceived risk of being a carrier: Participant's feelings about their chances of getting colon cancer were significantly associated with their beliefs about the likelihood that they carry a mutation (p<0.001)
| | X | | | | Intentions toward genetic testing: The intention to pursue genetic testing was found to have a positive association with participants beliefs that cancer may be explained by family heredity (p=0.006). Concern about the psychosocial effect of genetic testing on the family demonstrated a negative association with their intention to pursue testing (p=0.001). Participant's concerns about their ability to handle the emotional aspects of genetic test results demonstrated a negative association with their intentions to pursue testing (p<0.001). No association between age, sex or cancer status in regard to their intentions toward genetic testing.
| | | | | | Reasons for pursuing genetic tests: 50% of respondents believe that the most important reason for undergoing genetic testing was to learn about their children's risk. Second most important reason (17%) was to guide cancer screening; third (13%) as to confirm their belief that they carry a mutation. With respect to the importance of genetic testing for reproductive decision making, a statistically significant difference was detected between those younger than the median age of 43 or older (p=0.002).
| | | | | | Reasons for not pursuing testing: Worry about losing health insurance (39%), concerns about how it might affect the family (27%), concerns about handling the results emotionally (10%). A statistically significant difference was detected between those younger than the median age of 43 compared with those older with respect to concerns about handling the emotional aspects of genetic testing (p=0.006).
| | | | | | Testing decisions: 44/54 (81%) of eligible probands eventually chose to undergo genetic testing for HNPCC. 56/111 eligible first-degree relatives chose to pursue genetic testing (intention-to-treat analysis).
| | | | | | Of those agreeing to participate in the study, 44/47 (94%) probands agreed to undergo genetic testing and 56/57 (98%) of family members agreed.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | X | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
| | | | X
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10
| | | | X

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | X | ND | NA
| | | <60
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | X | No | NA
| Yes
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | X | ND | NA
| | | <60
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | X | ND | NA
| | | <60
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Hadley, DW 2004, Ref ID 657 (same patients as Hadley Ref ID 946) Multicenter, United States
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Assess impact of genetic counseling and mutation testing on endoscopic screening procedures and adherence to recommended endoscopic screening guidelines in 56 at-risk individuals from families known to carry an HNPCC mutation. | Deleterious mutation | | | ≥18, no personal history of cancer, 50% risk of carrying their families previously identified deleterious HNPCC mutation who chose to undergo genetic testing and who completed questionnaires at baseline, 6 and 12 months. | Genetic counseling and surveys as described in Hadley 2003. | 30/56 patients had at least one colonoscopy before genetic counseling and testing. | ND. | Genetic counseling and testing for HNPCC significantly influences the use of colonic endoscopy and adherence to recommendations for colon cancer screening. | B
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | Excluded those simultaneously participating in clinical trials involving colonoscopy | | 12/56 had at least one colonoscopy within 12 months after testing. Mutation-positive individuals were more likely to undergo colonoscopy. Among mutation-negative individuals, use of colonoscopy and flexible sigmoidoscopy decreased significantly between pre and post testing. Among mutation-positive individuals, a nonsignificant increase in use was noted. On logistic regression, colonoscopy was significantly more likely in mutationpositive individuals (OR 61, 95% CI 5.8–652, p=0.006), and increasing age (OR 1.1, 95% CI 1.008–1.2, p=.03). Employment, income, sex or colonoscopy status before testing did not predict use. | | | Small sample size. Not clear if authors fully adjusted for eligibility for followup procedures in the year following counseling. Compliance was assessed by selfreport rather than by verifying whether patients had procedures. No exploration about access or other barriers to colonoscopy.
| Yes | No | Uncl | | | 11/56 were classified as nonadherent with colonoscopy recommendations 12 months after testing. Mutation positive (OR 7.5, 95% CI 1.3–42.2, p=0.02) and unemployed individuals (OR 8.6, 95% CI 1.3–56.6, p=0.025) were significantly less likely to adhere to guidelines for endoscopic screening. Age, sex, income, or pre-testing colonoscopy status were not associated with adherence.
| | X

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | X | X | 8a | 8b,8c | X
| | 5 | 9 | | | 1,6b,9,10,11
Public health or policy | 2,3 | X | X | 8a | 8b,8c | X
| | 5 | 9 | | | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | X | No | NA
| Yes
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | X | 60–79 | <60 | ND | NA
| 80–100
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Halbert, CH 2004, Ref ID 405 Multicenter, United States
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Evaluate whether genetic testing for HNPCC mutations and receipt of positive test results have an effect on the use of colonoscopy. Identify factors associated with adherence to identify potential barriers to patient compliance. | Mutations. | | | 25% risk of having HNPCC identified in family. | All eligible invited by mail to participate; those who agreed were interviewed by telephone. They were then invited to participate in a information/education session. Subjects requesting genetic testing were notified by letter when mutation results became available. Following disclosure, they were contacted by telephone to reassess screening behaviors at 1, 6 and 12 months. | 134/222 participated but after exclusions, 98 were available for analysis. Men and subjects who were younger were significantly more likely to be lost to follow-up or not participate. | Excluded 25/14 due to a prior history of colectomy or colon cancer and 2/134 who developed colon cancer during the study, and 9/134 who received genetic test results during follow-up. | Genetic testing may motivate increased colonoscopic screening among HNPCC mutation carriers. Increased efforts may be needed to assess patients' family histories of colon cancer and provide appropriate referrals for genetic counseling and testing to target colonoscopic screening to high-risk individuals. | B
222 eligible, 98 in final sample. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | Excluded individuals with colon cancer or a history of colectomy. | | Colonoscopy use before genetic counseling was not significantly different between test result groups. During the 12 months following genetic testing, 73% (16/22) of mutation carriers and 16% (8/49) noncarriers and 22% (6/27) decliners reported having a colonoscopy (p<.001). Mutation carriers were significantly more likely than noncarriers and decliners to have a colonoscopy. No clinical or sociodemographic factors were significantly associated with colonoscopy use during the 12 months followinggenetic counseling. | | | All colonoscopy data based upon selfreport. High dropout rate. Issues related to access and perceptions of colonoscopy not assessed fully.
| Yes | No | Uncl
| | X

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | X | X | 8a | 8b,8c | X
| | 5 | 9 | | | 1,6b,9,10,11
Public health or policy | 2,3 | X | X | 8a | 8b,8c | X
| | 5 | 9 | | | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | X | ND | NA
| | | <60
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | X | No | NA
| Yes
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | X | ND | NA
| | | <60
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | X | Can't tell
| | No
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | X | ND | NA
| | | <60
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Hampel 2005, Ref ID 29
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
70 HNPCC families including 88 probands and 373 mutation-positive family members evaluated for risk of CRC and endometrial cancer. | Mutations and clinical criteria, mostly Amsterdam I or II. | | | Excluded if mutation unknown diagnosis or data incomplete | Cohort 1, 45 HNPCC families in which a mutation for MLH1 had been detected. Probands had presented with CRC. | Mean age of diagnosis of CRC 55.1 (95% CI 52.6–57.6)) for men and 60.3 (95% CI 58.0–62.6) for women; approximately 10–15 years older than previous estimates of age at onset for CRC among HNPCC patients. | ND | A markedly later age of onset of CRC at 61 year than previously reported (approximately 44 years) is suggested, resulting mainly from a more rigorous method of analysis in which all gene-positive individuals (both affected and unaffected with cancer) are considered. Lifetime cancer risk may be lower for CRC and endometrial cancer than presently assumed. If confirmed, these data suggest a need to alter counseling practices, and to consider HNPCC in older individuals than before. | B
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | Cohort 2, family members from 25 HNPCC families in whom a mutation for MLH1 or MSH2 had been detected. The probands had been diagnosed with CRC. | Lifetime risk of CRC was 68.7% for men and 52.2% for women. | | | Description of followup, surveillance procedures and dropouts incomplete making it unclear whether the relatively advanced age of diagnosis of cancer in family members may have been due to detection of precursor lesions.
| Yes | No | Uncl | | | Mean age of onset for endometrial cancer in women was 58.6 (95% CI 56.9–60.3). Lifetime risk of endometrial cancer was approximately 54%
| | X | | | | Mean age of ovarian cancer was 54.1 (95% CI 53.5–54.7). Women had a 13.5% lifetime risk for ovarian cancer.
| | | | | | Among probands, average age at diagnosis of CRC in men was 44.8 (95% CI 41.6–48.0) and for women was 47.0 (95% CI 43.0–51.0)
| | | | | | Among probands, average age of diagnosis of endometrial cancer was 53.1 (95% CI 50.5–55.7)

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | X | 1,6a,6b,7,10
| | | | | 8c
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | X | 1,6b,9,10,11
| | | | | 8b,8c
Public health or policy | 2,3 | 5 | 9 | 8a | X | 1,6a,6b,7,10
| | | | | 8b,8c

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | X
| | | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | Yes | No | X
| | | ND
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | X
| | | | | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | X
| | | | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Jarvinen, H 2000, Ref ID 5 Multicenter, Finland. Same patients (and includes) Jarvinen HJ. Gastroenterology 1995; 108:1405 Ref ID 2746
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Incidence of CRC and survival compared in 2 cohorts of at-risk members of 22 families with HNPCC. Colonic screening at 3-year intervals arranged for 133 subjects while 119 had no screening. | Amsterdam I criteria or other suggestive family history (some mutation positive). | | | Asymptomatic member of an HNPCC family at 50% risk of. Other inclusion/exclusion criteria as per Jarvinen 1995; 108:1405 as follows: | Initial colonoscopy or double contrast barium enema and sigmoidoscopy and then repeated examinations at 3-year intervals. The proportion of colonoscopy was 56% on the second round and 83% on the third round and 100% on the fourth round. | Cancer morbidity data, survival and causes of death checked at the Finnish Cancer Registry and the Population Registry of Finland. | 252 asymptomatic individuals belonging to 22 HNPCC families and being at 50% risk. Of those invited to participate, 78 eligible declined and 40 could not be traced; these patients constituted the control group. | Colonoscopic screening at 3-eyar intervals more than halves the risk of CRC, prevents CRC deaths, and decreases overall mortality by about 65% in HNPCC families. | B
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Significantly more patients developed CRC in control group (19 (16%) versus 8 (6%), p=0.014; RR CRC 0.377 (95% CI 0.171–0.829). | | | Nonrandomized design; not clear if those who declined screening has same baseline risk. However, the treatment effect was very large. Validity of cancer/mortality database not clear.
| Yes | No | Uncl | | | Among mutation-positive subjects, the frequency of CRC was 18% (8 of 44) in the study group and 41% (19 of 46) in the control group, p=0.02; RR 0.440 (95% CI 0.215–0.900).
| | X | | | | Mortality was greater in study group (9 of 119 (8%) versus 0/133 in study group (p<0.001).Overall there we re 10 deaths (8%) in the study group compared with 26 deaths (22%) in the control group during a 15-year period (p<0.001). Relative risk of deaths for the screened group was 0.344 (95% CI 0.173–0.683) overlap and 0.348 (95% CI 0.122–0.999) for mutation positive subjects.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | X
| | | | | | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | X
| | | | | | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | X
| | | | | | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Are individuals selected to participate likely to be representative of target population? | X | Somewhat likely | Not likely
| Very likely
What % of selected individuals agreed to participate? | X | 60–79 | <60 | ND | NA
| 80–100
Allocation Bias | | | | | | A | X | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is the method of random allocation stated? | X | No
| Yes
If the method of random allocation is stated, is it appropriate? | Yes | X
| | No
Was the method of random allocation reported as concealed? | Yes | X
| | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | X
| | | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | X | 60–79 | <60 | ND | NA
| 80–100
Analysis | | | | | | X | B | C
| | | | | | A | (moderate) | (weak)
| | | | | | (strong)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | X | 60–79 | <60 | ND | NA
| 80–100
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | X | ND | NA
| | No
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Study: Katballe Gut 2002

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Consecutive Danish patients with CRC in 4 counties (11/1995 to 10/1998) Inclusion criteria: Amsterdam criteria I or II or on extended pedigree; Amsterdam criteria with HNPCC related cancers; Amsterdam criteria except youngest was 50–55yrs; pts ≤ 40 with at least one CRC among family members; Proband and one first degree relative with CRC before 55 yrs | Prospective population study; if a family met criteria for suspected HNPCC, screening for hMSH2 or hMLH1 were done and tumor were analyzed for MSI; HNPCC defined as Amsterdam I or II; or suspected HNPCC based on history plus pathogenic hMLH1 or hMSH2 mutation. | MLH1 and MSH2 | | Y | N | ? | Am 1 | | Based on previous reports by them and other authors; in a case based on the fact that splice mutations are usually pathogenic.
| | | ≥ 5 MSI markers used? | X | | | Am R
| | | MSI-H defined by ≥ 2 markers? | X (>=2 bands, but OK) | | | Beth 1
| | | Microdissection? | X | | | Beth R
| | | Gene screening? | X | | | MSI-H
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | | | | | Age <50 | X
| | | | | | | Suggestive family history | X
| | | | | | | Specify
| | | | | | | Other

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positiveAM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
1514 with 1° CRC (median age 71 yrs) 1328 eligible, 1200 in study, excluded pts who died shortly after dx, psychological problems, ethical reasons, did not complete questionnaires | 10 pts were found with MMR among the 41 HNPCC who were sequenced → or among the 1200 CRC who were included. | 11/1200 (0.9%, 0.5–1.6%) fulfilled Amsterdam I | The sensitivity of MSI is only 61% in terms of detecting families that satisfied the Amsterdam criteria I or II. | “The sensitivity of MSI is only 61% in terms of detecting families that satisfied the Amsterdam criteria I or II → MSI is not as appropriate to identify the families with suspected HNPCC.” “The majority of mutation carriers present with a strong family Hx of HNPCC-related Cancers.” | No | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 5/11 Am1 people; (4/10 independent, ie without familial clustering) | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
| | 18/1200 (1.5%, 95% CI 0.8–2.25%) fulfilled Amsterdam II | | | | | | Amsterdam R | X | 8/18 Am2 (including AM1) people; (6/16 independent) | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 + | X
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | Am1 →7/10 analyzable had MSI-H | Am R + | X
| | | | | | | | Amsterdam R | X | Am1 →0/10 analyzable had MSI-L | Beth 1 +
| | | | | | | | Other (specify) | | Am2 →10/16 analyzable has MSI-H | Beth R +
| | | | | | | | | | Am2 →1/16 analyzable has MSI-L | Age <50 | X
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | | Suggestive family history (specify) | X
| | | | | | | | Amsterdam R | | | Other (specify)
| | | | | | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
All 45 Patients with CRC and S-HNPCC as defined above (actually 41, because 4 were not analyzed) | Am 1 + | X | + | 5 | 6
| Am R + | | - | 5 | 25
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
All 45 Patients with CRC and S-HNPCC as defined above (actually 41, because 4 were not analyzed) | Am 1 + | | + | 8 | 10
| Am R + | X | - | 2 | 21
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
MSI-H+MSI-L vs MSI-S among all people analyzable out of the 45 | Am 1 + | | + | 10 | 5
| Am R + | | - | 0 | 20
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L* | X
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
MSI-H vs MSI-S among all people analyzable out of the 45 | Am 1 + | | + | 10 | 3
| Am R + | | - | 0 | 20
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
| Am 1 + | | + | 11 | 7
| Am R + | X | - | 4 | 18
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Un clr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | X
7 | Were withdrawals from the study explained? | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or thosewho did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Keller, 2002 Ref ID 984 Germany Single center
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Longitudinal study, data reported come from self-completed questionnaires preand post-counseling (4–6 weeks after counseling) | | | | >18 year olds, patients with HNPCCrelated cancer or unaffected individuals from families at risk for HNPCC; referred by physician or self-referred | Standardized protocol of interdisciplinary team counseling by geneticists, pathologists, molecular biologists, surgeons, and psycho-oncologists; comprised of genetic, clinical, and psychosocial counseling | Distress and worries related to HNPCC declined after counseling. | | “Counselees demonstrated less stress and perceived cancer threat as well as enhanced beliefs regarding personal control over cancer, suggesting an overall beneficial impact of comprehensive counseling. Further research is needed to identify those individuals most at risk for increased fear and worry related to HNPCC so that they may be most appropriately counseled.” | B
94 individuals received counseling between 7/2000 and 8/2001 73/82 completed a post-counseling questionnaire; 8 of those did not have a precounseling questionnaire; Final sample size: 65, 31 patients and 34 unaffected individuals | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | An increase was found in personal belief in control of cancer risk.
| Yes | No | Uncl | | | A trend was observed toward greater anticipated ability to cope with a positive gene test after counseling.
| | X | | | | Changes after counseling were generally more pronounced for persons at risk, as compared to patients with cancer. 1/3 of the sample reported enhanced communication specific to hereditary disease within the family after counseling.
| | | | | | A substantial minority, however, experienced increased worry and physical symptoms after counseling.

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Keller, 2004 RefID 585 Germany Single center
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Of 140 eligible patients and their families, 36 families participated in the information session, 25 participants were patients, and 11 were spouses or relatives of patients who had died or were too ill to attend. Participation rate 26%. Questionnaire completed by spouses or relatives were not included in the analysis. Of the 104 nonparticipating patients addressed by mail, 61 responded (59%), 12 died, 48 returned a completed questionnaire. Sample here consisted of 73 patients: 25 participants and 48 nonparticipants | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | >18 year olds, had surgery for CRCassociated or HNPCC-associated cancer between 1994 and 1998, met Amsterdam or Bethesda or FH suggestive of HNPCC | Eligible patients received a letter announcing the discovery of HNPCC mutations and the availability of free genetic counseling and testing. Patients and their families were invited to partcipate in comprehensive information session on HNPCC. Participation in an information session was followed by answering a questionnaire. | “Among participants, 60% reported being very worry because of familial cancer; among non-participants 35% reported being very worry because of familial cancer (P<0.05). 28% of participants reported impairment of daily life because of these worries compared to 19% of nonparticipants (difference not significant). Similarly, perceived distress of spouse and family from patient's point of view was higher in participants than in nonparticipants (difference not significant). Regardless of whether patients participated in the information session, most were in favor of genetic testing. Twice as many nonparticipants (25%) as participants (13%) were undecided about whether to accept genetic testing. All participants definitely expressed the wish to know whether a mutation is present in the family, compared to 81% of nonparticipants.” | No actual genetic testing was done. | “Expressed intention and attitude toward genetic testing do not reliably predict actual uptake of counseling or testing. Thorough interdisciplinary counseling should be provided to every patient with clinical criteria suggestive of HNPCC. The considerable distress related to the hereditary disorder should be adequately addressed, as should be communication issues.” | C
| Yes | No | Uncl | FAP were excluded

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Kruhoffer, 2005, RefID 129 Country: Denmark and Finland Center: 15
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Colorectal cancer tissue from a total of 151 patients was collected from 15 different clinics in Denmark and Finland. A sample set consisting of 101 stages II and III cancers (34 MSI-H; 67 MSI-L and MSS) were used. MSI classification data were correlated to the overall survival of the patients for stage II (in 36 patients) and III (in 65 patients) tumors separately. | Among the 101 stages II and III cancer patients, 19 had sporadic MSI tumors, 15 had hereditary MSI tumors, and 67 had MSS tumors. | | | A sample set consisting of 101 stages II and III cancers (34 MSI-H; 67 MSI-L and MSS) was included in the analyses for the relation between microsatellite status, cancer stage, and patient survival. | 65 patients with Stage III tumors receiving adjuvant chemotherapy | Kaplan-Meier survival analyses were performed for stage II and III tumors separately. Note that MSS in this study includes MSI-L. | No “dropouts” due to retrospective design. | “Our findings are in accordance with other recent publications, the MSI classification (or MSI-H) clearly proved to be a strong predictor of survival in stage II disease, and there is a relation between MSI classification and a good prognosis in stage II patients.” | C
| MSI tumors with HNPCC origin were classified by a maximum likelihood MSI classifier with a “leave-one-out” cross validation scheme basically as described (Dyrskjot et al, 2003). All HNPCC cases included in this study carry MLH1 or MSH2 mutations identified by sequencing. | | | | | The overall survival was highly significantly related to the classification in 36 Stage II patients, as 10 out of 11 patients that died within 5 years belonged to the MSS group (p=0.0014). | | | Retrospective design and likely to have selection bias
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Among 65 patients with Stage III tumors receiving adjuvant chemotherapy, 16 were classified as MSI tumors and 49 as MSS tumors. As 6 MSI and 30 MSS patients died within 5 years of follow-up, there was no significant difference in overall survival between these group (p=0.55)
| Yes | No | Uncl
| | x

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
| | | | | | | | x
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND x | NA
Allocation Bias(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction for Analytic Validity

Study: (Author, year, UI) Kurzawki, G, 2002, Ref ID 1253

Inclusion criteria (all must be yes)

| Yes | No
Did study evaluate biological material from patients considered to be at risk for HNPCC? | X
Did the study report ANY of the following? (check which one below)
5) Proportion MSI-H with NIH markers versus other markers
6) Sensitivity or specificity of MSI-H using NIH markers compared with a reference standard that the study claims is better
7) Sensitivity or specificity of IHC compared with an immunohistochemical standard that study claims is better
8) Sensitivity or specificity of a genetic technique compared with a reference standard (or combination of standards) | X
Are data (proportions or 2 X 2 tables) extractable? | X

Exclusion criteria (exclude if yes)

| Yes | No
Did the study include the index test in the reference standard? | | X

Describe source of biological materials (and whether patients were known to have an HNPCC phenotype) | Summarize how materials were processed and analyzed
46 unrelated patients with CRC: nine families fulfilled Amsterdam II and in 37 there was a strong suspicion of HNPCC. In 19, MLH1 or MSH2 mutations or polymorphisms had been identified by DNA sequencing | Genomic DNA analyzed using DHPLC and sequencing

MSI Proportion (add additional 2 X 2 tables where relevant)

Proportion MSI-H using NIH markers (≥2 markers) | Proportion MSI-H using other markers

MSI with a reference standard

| | MSI-H using another reference standard | Describe
| | Positive | Negative
MSI-H using NIH markers | MSI-H (≥2 markers)
| MSI-S or MSI-L

IHC with a reference standard

| | IHC using another immunohistochemical reference standard | Describe
| | Positive | Negative
IHC | Positive
Describe | Negative

Genetic technique with a reference standard

| | Reference standard genetic technique | Describe Sequencing
| | Positive | Negative
Index genetic technique | Positive | 42 | NR
Describe: | Negative | 42
DHPLC

| Study Quality | Yes | No | Unc
1 | Was the description of how MSI or IHC and other genetic techniques described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
2 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | | | X
3 | Was MSI, IHC, other genetic testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
4 | Was there a clear description of which mismatch repair mutations were being tested for? | X
5 | Were quality control methods described for the molecular and genetic tests? | X
6 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | | X
7 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | X
8 | Was microdissection performed?
9 | Did the study specify whether the biological tissues were from patients known to have HNPCC clinically? | X
10 | Did the study include a control group in which biological material was obtained from patients known not to have HNPCC clinically | | X
11 | Overall rating (A B C) | C

Study: Lamberti 1999

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply | | How were deleterious, missense/variants mutations defined (ND if not described)
I do not know from which population these index pts come from (!) | Blood sample ant tumor tissues from all index pts (when possible); All Gr1 and Gr2 pts were screened for mutations irrespectively of MSI status; Gr3 and GR4 screened only if MSI was positive | hMLH1 and hMSH2 | | Y | N | ? | Am1 | X | With references to other papers; other are not.
160 index pts who were GR1 Am1 (57); GR2 (Loose criteria with relatives with extracolonic HNPCC malignancies →) Am2NOT Am1 (12); GR3 CRC aged <50 AND with relatives with nonCRC HNPCC related cancer (n=45); GR4 Apparently sporadic CRC <50y OR sporadic CRC with synchronous or metachronous CRC tumor (no age limit; n=46) | | | ≥5 MSI markers used? | X | | | Am R
German Study, | | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1
| | | | (By >40% of loci being unstable)
| | | Microdissection? | | | X | Beth R
| | | Gene screening? | X | | | MSI-H
| | | Deletion analysis? | | X | | MSI-L
| | | Conversion analysis? | | X | | IHC
| | | D2S123, D2S136, D3S1298, D3S1611, D5S346, D6S470, D18S35, D18S37, BAT25, HBAP1 | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
Overall N=160 index pts; Am1 N=57; Am2 N=69 (57 + 12); % male unknown; dropouts not described [[57 Am I mean age at dx of CRC = 44 (11.8); 12 non-Am I mean age at dx of CRC = 37 (10.8)]] | 17 with MMR/69 patients with CRC and Am2; 11 MLH1; 6 MSH2 | [Of the enrolled population, which is not described.] 57/160 are Am1 and 69/160 essentially AM2 | ND | A positive MSI is an efficient indicator of a germline mutation in the mismatch repair genes MSH2 and MLH1, both in patients meeting the clinical criteria for HNPCC and pts with sporadic CRC. It is a matter of debate whether the age cutoff should be used at all for the MSI test. Pts with CRC <50 y should be examined anyhow, even if F Hx is negative. | No | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | Am1: 15/57 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | X (But, again, the population is not really defined)
| | | | | | | | Amsterdam R | X | Am2 (INCLUDING AM1): 17/69 | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | MSI-H: Am1: 35/49 | Am R +
| | | | | | | | Amsterdam R | X | MSI-H Am2: 39/57 | Beth 1 +
| | | | | | | | Other (specify) | | [Not all tumors assessed for MSI] | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Among people with Am2, | Am 1 + | X | + | 15 | 42
| Am R + | | - | 2 | 10
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Contrast BETWEEN MSI-H vs MSI-S & MSI-? | Am 1 + | | + | 15 | 24
AMONG PEOPLE with AMI2 In total 52 that could be assessed This is the only contrast you can extract with certainty; | Am R + | | - | 2 | 16
You cannot compare against MSI-S only, because of the way the data are reported | Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | | X
2 | Inclusion criteria clear? | | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | | X
7 | Were withdrawals from the study explained? | | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Lee, 2005

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply | | How were deleterious, missense/variants mutations defined (ND if not described)
Inclusion: CRC with Am I or Am II family history; or CRC ≤ 40; or CRC with 1^st^ degree relative with CRC or HNPCC-like cancer (cancer of endometrium, small bowel, biliary tract, pancreas, stomach, ureter, ovary, renal pelvis or glioblast); or proband ≥ 2 primary cancers classical of HNPCC (CRC or HNPCC-like cancer) | Blood sample for genotyping and paraffin-embedded colon cancer tissue blocks for MSI testing | MLH1 and MSH2 | | Y | N | ? | Am1 | | Deleterious mutation: truncated protein (nonsense or frameshift mutations) or if previously reported in HNPCC kindreds
Exclusion: familial adenomatous polyposis | | | ≥5 MSI markers used? | X | | | Am R | x
Singapore | | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1
Single center | | | Microdissection? | X | | | Beth R
| | | Gene screening? | | | X | MSI-H | x
| | | Deletion analysis? | | X | | MSI-L
| | | Conversion analysis? | | X | | IHC
| | | | | | | Age <50 | x
| | | | | | | Suggestive family history | x
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Result

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described)
N=46 | 7/46 WITH DELETERIOUS MUTATIONS | 5/46 Am2 23/46 >=2 first degree relatives 5 multiple tumors 13 apparently sporadic aged <40 | ND | Singapore patients may have the same key characteristics for HNPCC as those described widely in the western families. | ND | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | 3/5 AM2
Median 39 yr (18–82) | | | | | | But 96% are CRC | | Amsterdam R | X
30 (65%) men | | | | | | | | Other (specify)
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | ND
| | | | | | | | Amsterdam R
| | | | | | | | Other (specify)
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND
| | | | | | | | Amsterdam R
| | | | | | | | Other (specify)

| MMR+ | MMR-
Am2 | 3 | 2
3 1^st^ degree family members CRC | 2 | 7
2 1^st^ or 2^nd^ degree family members CRC | 1 | 13
CRC with Multiple cancers (not adenomas) | 1 | 4
Sporadic aged <40 | 0 | 13

| MMR+ | MMR-
MSI-H | 4 | 7
MSI-L | 0 | 2
MSI-S | 1 | 21

| Yes | No
Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | X
If yes, which clinical criteria (check all that apply)?
Am 1 +
Am R +
Beth 1 +
Beth R +
Age <50
Suggestive family history (specify)
Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
| Am 1 + | | + | (A) | (B)
| Am R + | | - | (C) | (D)
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | | X
7 | Were withdrawals from the study explained? | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Lerman, 1996 RefID 2617, US Single Center
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
24 consecutive index colon cancer patients (who did not fulfill the Amsterdam criteria) identified 61 first degree relatives for the study (index patient consent rate = 83%). Of these first degree relatives, 44 (72%) completed the interview, 2 (2%) declined, 16 (26%) could not be reached. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | Person who had a prior diagnosis of cancer were excluded. | 15-minute telephone interview | “Anticipated reactions to positive and negative results of a genetic test: Over ½ of respondents indicated that they would become depressed or very anxious if they tested positive. Most subjects reported that they would react by changing their health habits, including diet and screening behaviors. In response to negative test result, about 1/3 of respondents anticipated they would feel guilty and ½ would still worry because the test might be wrong. About ½ of respondents expected that they would decrease their use of screening tests and make fewer attempts to reduce dietary fat if they tested negative.” | Pilot study, no actual genetic tests were done. | “These preliminary results underscore the importance of educating patients about the potential risks, benefits, and limitations of genetic testing, with particular emphasis on the possibility of adverse psychological effects and implications for health insurance. The potential for false reassurance following a negative test result should be addressed by emphasizing the residual risks of cancer among non-carriers of predisposing mutations.” | C
This was a pilot study in preparation for a prospective study of genetic testing for HNPCC-associated mutations. | Yes | No | Uncl
| | x

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Liljegren 2004, Ref ID 541 SAME PATIENTS AS Lindgren G. Gut 2002; 50:228–234. Single center Sweden
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Evaluated psychological aspects of colorectal cancer screening in 240 individuals at high risk for CRC. | Patients categorized into: 1) mutation positive; 2) suggestive family history but not fulfill Amsterdam I; 3) two close relatives affected by CRC. | | | Subjects from Cancer Family Clinic at Karolinska Hospital form 1990-1999 who fell into three categories described. | Colonoscopies were performed every 2–3 years in patients enrolled over a 10-year period between 1990 and 1999. In 1999 all eligible patients were asked to fill out a questionnaire about experiences with colonoscopy and to complete the Hospital Anxiety and Depression Scale (HAD), Medical Outcomes Study Short-Form 36 (SF-36). | Perceived benefit of colonoscopy was rated an 8/10 on a visual analogue scale where 0 = no benefit and 10=great benefit. | 304 included of whom 23 later proven to be mutation negative and were excluded. 16 excluded because address could not be found. 265 sent questionnaire of 91% returned usable data. | A majority of the study sample understood why they were under surveillance and regular colonoscopies were well-tolerated. The wide range of risk perception as well as low-risk perception in mutation positive subjects is acceptable as long as these individuals adhere to surveillance programs and do not demonstrate increased levels of anxiety or depression. | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Risk perception: Among 28 mutation-positive subjects 17 (61%) reported their personal risk as being 40% or less and 36% perceived a 1 to 20% lifetime risk of CRC. In risk groups 2 and 3 (129 and 83 individuals), approximately 50% either under-or over-estimated their personal lifetime risk of colorectal. Cancer. | | | Data do not fully support authors' conclusions. Small sample size of mutation-positive patients. No control group of patients who declined to undergo surveillance so there may have been selection bias for patients with relatively favorable psychological profiles. Unclear if any of these patients had a personal history of cancer. Results not adjusted for potential covariates such as age, personal history of cancer, educational level.
| Yes | No | Uncl | | | HAD scores we within the normative data range.
| | X | | | | SF-36 scores were significantly lower on mental health (p=.013) and vitality (p=0.16) compared with the reference population. Women and significantly lower scores on vitality (p=0.48) while men had lower scores on mental health (p=0.47).
| | | | | | 88% of subjects gave a correct answer to the questions “Why have you been offered regular colonoscopies”.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCCrelated cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | X | X | 8b,8c | 1,6b,9,10,11
| | | 9 | 8a
Public health or policy | 2,3 | 5 | X | X | 8b,8c | 1,6,a,6b,7,10
| | | 9 | 8a

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | 80–100 | X | <60 | ND | NA
| | 60–79
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | X | X
| | | | | | (strong) | B | C
| | | | | | | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Were data collection tools shown or are they known to be valid? | X | No
| Yes
Were data collection tools shown or are they known to be reliable? | X | No
| Yes
Withdrawals and Dropouts | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | X | <60 | ND | NA
| | 60–79
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | X | <60 | ND | NA
| | 60–79
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Lindgren, G 2002, Ref ID 1300 SAME PATIENTS AS Lilegren A 2004, Ref ID 541 Single Center, Sweden
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Evaluate outcomes in 304 patients at increased risk for CRC including HNPCC who were undergoing surveillance colonoscopy. | Patients categorized into: 1) mutation positive; 2) suggestive family history but not fulfill Amsterdam I; 3) two close relatives affected by CRC | | | Subjects from Cancer Family Clinic at Karolinska Hospital form 1990-1999 who fell into three categories described. | Screening colonoscopy approximately every two years except those with an adenoma in whom it was repeated every year. | 304 subjects underwent 765 colonoscopies | ND | There was clear overrepresentation of adenomas in all three family types compared with the reference population. In HNPCC, we found earlier onset of adenomas and faster progression to cancer. | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | Adenoma prevalence for normal population estimated from three autopsy studies. | 10 colorectal cancers found in 9 individuals before recruitment into the surveillance program. | | | Non-uniform protocol, endoscopists were unblended and thus may have been more vigilant for adenomas in these high risk patients. It is likely that clustering effects were occurring among patients that were not accounted for in the analysis. The control group was based upon autopsy studies rather than adenoma detection rates based upon colonoscopy.
| Yes | No | Uncl | | | 4 had CRC at first colonoscopy and two developed Metachronous cancers during surveillance.
| | X | | | | RR of adenoma before age 54 compared with general population 2.6 (p=0.001)
| | | | | | RR for tested gene carriers in HNPCC families 4.5.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCCrelated cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | X 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | X 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | X
| | | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Analysis | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | Yes | X | ND
| | No
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X | Client
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | X | NA
| | | ND
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Study: Liu 2004 Ref ID 445

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
28 independent Chinese families: 15 fulfill Am1 criteria; 13 not Am1 but fulfill Japanese Clinical Diagnosis Criteria for HNPCC. | DHPLC analysis was performed | HMSH2 and hMLH1 | | Y | N | ? | Am 1 | x | ND
| | | ≥5 MSI markers used? | | x | | Am R
| | | MSI-H defined by ≥ 2 markers? | | x | | Beth 1
| | | Microdissection? | | x | | Beth R
| | | Gene screening? | x | | | MSI-H
| | | Deletion analysis? | | x | | IHC
| | | Conversion analysis? | | x | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
28 probands from 28 families are described onwards. They all meet the Japanese HNPCC criteria; they are assumed to be with CRC - not clearly stated though. Overall, 128 pts among all family members has CRC. Among these 128: 45.9 yrs mean age onset of CRC, 55% male | 7 patients with MMR/28 patients with CRC; 2 with hMSH2 and 5 with hMLH1 | 15/28 probands from AM1 families | ND | “Three novel germline mutations were found, the germline G204X nonsense mutation in the 3rd exon of hMSH2 is the first MMR gene mutation found in Chinese Mongolian people.” | | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 5/15 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | x
| | | | | | | | Amsterdam R | | 7/28 Japanese HNPCC criteria | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | CheckONE | Index test | Number withMMR+ | Number withMMR-
Japanese Criteria for HNPCC; Sample seems to be a convenience Sample; unknown selection. | Am 1+ | x | + | 5 | 10
| Am R + | | - | 2 | 11
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Un clr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | | x
2 | Inclusion criteria clear? | | x
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | x
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | x
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | x
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | x
7 | Were withdrawals from the study explained? | | | x
8 | Did the authors report AND analyze results for deleterious MMR mutants | | | x
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | | x
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | x
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | x
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | | | x
14 | Were quality control methods described for the molecular and genetic tests? | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | x
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Luce, 1995

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | x
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | x
Was a minimum of hMLH1 and hMSH2 sequencing performed? | x

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Consecutive cases of CRC referred to a tertiary hospital. Patients reporting 2 or more cases of colorectal or endometrial cancer in first-degree relatives or only 1 affected first-degree relative younger than 50 years old were interviewed, and detailed pedigrees were obtained. | Genetic testing was done in all enrolled patients with CRC | hMLH1 & hMSH2 | | Y | N | ? | Am 1 | x | ND
Country: US | | | ≥5 MSI markers used? | | | | Am R
Center: Single | | | MSI-H defined by ≥ 2 markers? | | | | Beth 1
| | | Microdissection? | | | | Beth R
| | | Gene screening? | | | | MSI-H
| | | Deletion analysis? | | | | IHC
| | | Conversion analysis? | | | | Age <50
| | | None of these testing was done | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda GuidelinesMSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with RC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
N=19 cases/families Mean age=40.3 %male=ND Dropouts=0 | 6 cases/families with MMR / 19 cases/families with CRC 4 MLH1 2 MSH2 | 19 cases/families with CRC, 63% positive AM | ND | | ND | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | x | 6/12 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | x
| | | | | | Small sample size | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | ND | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
See definition above; Essentially they are not Am1 Selected Familial CRCs (proband and 1 or 2 1^st^ degree) | Am 1+ | x | + | (A) 6 | (B) 6
| Am R + | | - | (C) 0 | (D) 7
| Beth 1 +
| Beth R
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis)

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Un clr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | x
2 | Inclusion criteria clear? | x
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | x
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding) | N/A
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | x
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | x
7 | Were withdrawals from the study explained? | N/A
8 | Did the authors report AND analyze results for deleterious MMR mutants | | | x
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | N/A
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | x
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | N/A
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | x
14 | Were quality control methods described for the molecular and genetic tests? | | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | N/A
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Lynch, HT 1996, Ref ID 2661 Single center USA.
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Evaluated reaction of 51 members of Navaho Indian CRC patients who received MLH1 genetic testing underwent genetic counseling | Mutation | | | As per study description | Family reservation visited three times with interceding genetic testing and counseling | Many family members believed the family's fate was influenced by factors such as fear, a taboo, or a curse. | ND | DNA-based genetic counseling requires compassion and empathy coupled with intensive pre-education regarding potential penalties and advantages that might emanate from this knowledge. Special care must be given to patients' culture. | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Four family members denied their heightened cancer genetic risk. | | | No formal instrument used to assess subjects' reactions. Important covariates such as educational level and personal history of cancer not described.
| Yes | No | Uncl | | | Several who had not undergone gene testing wanted their children testing.
| | X

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | X | 8b,8c | 1,6b,9,10,11
| | | | 8a
Public health or policy | 2,3 | 5 | 9 | X | 8b,8c | 1,6,a,6b,7,10
| | | | 8a

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | X
| | | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | X
| | | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | X
| | | | NA
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest) | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Analysis | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | Yes | No | X
| | | ND
Are the statistical methods appropriate? | Yes | No | X
| | | ND
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | X
| | | Can't tell
Intervention Integrity | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Lynch 1997 (RefID 2355) US; also see Lynch 1996 for similar information Single Center
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
High-risk members from 4 extended HNPCC families that were selected from Creighton's HNPCC resource, which comprised about 100 HNPCC extended kindreds | Did all patients have a personal history of an HNPCC-related cancer? Check oneYes No Uncl | | | Of the 89 members did not enroll in the study, 67% did not respond to the invitation, 22% had their counseling postponed, and 10% refused, citing fear of knowing, fear of insurance discrimination, surviving guilt and disinterest. | Genetic counseling | 1 When mutation positive, 20% exhibited sadness, particularly because of concern of the potential risk of transmission of the deleterious mutation to their children. Others were concerned about their personal cancer destiny, particularly the possibility of an unfavorable prognosis that could lead to their early death and may put their children in jeopardy of not having a biological parent to care for them.; 2 Following a positive test result, 67% were considering prophylactic colectomy.; 3 Following a positive test result, 87% were considering prophylactic total abdominal hysterectomy and bilateral salpingo-oophorectomy.; 4 18/130 were concerned with sharing information with their insurance company. | | “DNA testing should be restricted to wellverified candidate families and accompanied by genetic counseling...patients exhibited a wide range of emotional responses when told of their genetic testing status...Whether... the test results, has a long-term effect on behavior, quality of life, or on cancer morbidity and mortality remains to be seen....” | C
Emotional responses to receiving genetic test results in 130 individuals from 4 extended families with HNPCC. | Yes | No | Uncl
36% had positive test | | X
64% had negative test

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Meiser 2004 Australia Multicenter
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Psychological impact of predictive genetic testing in 114 individuals (32 carriers and 82 non-carriers) were assessed after disclosure of carrier status. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | Only individuals in whose families a known HNPCC mutation had already been identified, who chose to receive a predictive genetic testing result and had never had CRC or any of HNPCC-related cancers were included in the study. | Self-answered questionnaires pre-test, post-test at 2 wk, 4 mo and 12 mo after carrier status disclosure | 1 Compared to baseline, carriers showed a significant increase in mean scores for intrusive and avoidant thoughts about CRC and a significant decrease in mean depression scores 2 wk and 4 mo post notification of results.; 2 Carriers had significantly higher intrusive and avoidant thoughts 2 wk and 12 mo post-notification compared to non-carriers.; 3 Compared to baseline, non-carriers showed a significant decrease in mean scores for intrusive and avoidant thoughts, and mean depression scores at all follow up time points. | | Predictive genetic testing for HNPCC leads to psychological benefits amongst non-carriers, and no adverse psychological outcomes were observed amongst carriers. | B
| Yes | No | Uncl

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Mesters 2005 Netherlands Single
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
30 persons from the database of the Netherlands Foundation for the Detection of Hereditary Tumors (the article did not explicitly state who these subjects were but 37% had confirmed carrier status) were interviewed at home. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | 1 Disclosure was stimulated if people felt morally obliged to do so or when they anticipated regret if something happened because it is preventable. Presence of external cues (eg, professionals) appeared important for disclosure as well; 2 Disrupted and tense family relations were reasons not to disclose, as well as young age of the message recipients and negative experience at their first attempt to disclose.; 3 Disclosure was restricted to the nuclear family. A personal approach was preferred.; 4 Participant disclosed only the presence of the hereditary defect and the possibility of testing. It was mostly considered the recipients' responsibility and own choice to obtain further information.; 5 Limitations of this study include that findings might be affected by recall bias since the interviews focused on prior experiences about HNPCC disclosure. | | See paper concerning practice implications | C
| Yes | No | Uncl
| | | X

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study: Moslein, 1996

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X*
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

* although not all study patients had CRC but data on those patients with CRC are extractable

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Patients having sporadic, familial colorectal carcinoma, and HNPCC meeting the Amsterdam criteria | The DNA sequence of hMSH2 and hMLH1 was evaluated in all patients | HMSH2 and hMLH1 | | Y | N | ? | Am 1 | x | Based on predicted transcript alteration
Convenience samples | | | ≥5 MSI markers used? | X | | | Am R
Country: Germany | | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1
Center: multi | | | Microdissection? | | | X | MSI-H | X
| | | Gene screening? | | X | | MSI-L
| | | Deletion analysis? | | | X | IHC
| | | Conversion analysis? | | | X | Age <50
| | | | | | | Suggestive family history | x
| | | | | | | “Familial CRC”
| | | | | | | Other

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
N=36 | 13 patients with MMR/ 36 patients with CRC 7 MLH1 4 MSH2; 1 MLH1&MSH2 | NA | 5/9 patients who met Amsterdam criteria (HNPCC) had positive MSI | “In this study, MSI was present in 100% (10/10) tumors (whether from familial or HNPCC cases) in which mutations in either hMLH1 or HMSH2 were subsequently found. These results suggest that MSI may be a very sensitive method for distinguishing a subset of HNPCC colon cancers (i.e., those resulting from defective mismatch repair) from sporadic colon cancers.” | ND | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | x | 6/14 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | x
Mean age=51 | | | 8/12 patients who had familial CRC had positive MSI | | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
%Male=ND | | | | | | | | Other (specify) | | | Am 1 + | x
Dropouts=0 | | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | x | 5/9 positive MSI (≥ 2 markers showing instability) Note: 5 (14–9) patients who met Amsterdam criteria did not have tissue available for MSI testing | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (Familial CRC) | x
| | | | | | | | Other (specify) | | | Other (MSI+) | x

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with CRC who met Amsterdam criteria (n=14) | Am 1 + | | + | (A) 5 | (B) 0
Note: 5 patients did not have tissue for MSI testing, so that they are not in the 2×2 table | Am R + | | - | (C) 0 | (D) 4
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with sporadic CRC (n=7) | Am 1 + | | + | (A) 1 | (B) 6
Note: 5 patients did not have tissue for MSI testing, so that they are not in the 2×2 table | Am R + | | - | (C) 0 | (D) 0
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with familial CRC (n=15) | Am 1 + | | + | (A) 4 | (B) 4
Note: 3 patients did not have tissue for MSI testing, so that they are not in the 2×2 table | Am R + | | - | (C) 0 | (D) 4
| Beth 1 +
| Beth R +
| MSI-H* | x
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Un clr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | x
2 | Inclusion criteria clear? | | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | x
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | x
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | x
7 | Were withdrawals from the study explained? | | x
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at asimilar time interval between specimen collection and processing for all subjects evaluated? | | | x
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | | x
14 | Were quality control methods described for the molecular and genetic tests? | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | x
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction for Analytic Validity

Study: (Author, year, UI) Muller 2001, Ref ID 731

Inclusion criteria (all must be yes)

| Yes | No
Did study evaluate biological material from patients considered to be at risk for HNPCC? | X
Did the study report ANY of the following? (check which one below) | X
9) Proportion MSI-H with NIH markers versus other markers
10) Sensitivity or specificity of MSI-H using NIH markers compared with a reference standard that the study claims is better
11) Sensitivity or specificity of IHC compared with an immunohistochemical standard that study claims is better
12) Sensitivity or specificity of a genetic technique compared with a reference standard (or combination of standards)
5) Reliability of MSI/IHC/genetic method across laboratories or within a laboratory | X
Are data (proportions or 2 X 2 tables) extractable? | X

* NIH markers are BAT-25, BAT-26 D2S123, DS346 and D17S250

Exclusion criteria (exclude if yes)

| Yes | No
Did the study include the index test in the reference standard? | | X

Describe source of biological materials (and whether patients were known to have an HNPCC phenotype) | Summarize how materials were processed and analyzed
20 colorectal cancers from different institutions including those known to be MSI-H or have DNA mismatch repair mutations of hMLH1 (n=6) or hMSH2 (n=11) or negative controls (n=3) | A set of two unstained slides from each case were sent to participating medical centers with capability of performing immunoperoxidase assays for hMLH1 and hMSH2

MSI Proportion (add additional 2 X 2 tables where relevant)

Proportion MSI-H using NIH markers (≥2 markers) | Proportion MSI-H using other markers

MSI with a reference standard

| | MSI-H using another reference standard | Describe
| | Positive | Negative
MSI-H using NIH markers | MSI-H (≥2 markers)
| MSI-S or MSI-L

IHC with a reference standard

| | IHC using another immunohistochemical reference standard | Describe
| | Positive | Negative
IHC | Positive
Describe | Negative

Genetic technique with a reference standard

| | Reference standard genetic technique | Describe
| | Positive | Negative
Index genetic technique | Positive
Describe | Negative

Intra or inter-hospital reliability data | Describe
| Of 18 participating centers 2 were excluded: one because slides were damaged in transit and the other because of insufficient staining.
| Sensitivity for detecting loss of hMSH2 2 expression ranged from 84 to 100%; 10 centers identified all six. 5/6 false positive results were in the same case suggesting that staining or interpretation were not random.
| 14/16 laboratories showed 100% specificity (one laboratory had 93% specificity due to staining failure on one slide and one lab demonstrated 45% specificity due to weak or absent staining in most cases.
| Re-review of returned hMSH2 slides shoed lack of internal positive control staining in at least 2 of the 6 hMSH2-negative cases from 8 of 16 centers. The other 8 centers had 100% sensitivity and 93–100% specificity on re-review. The slides that lacked internal positive control staining were largely accounted for by two cases suggesting the possibility of fixation or processing variation.
| Variation of staining quality and interpretation was much greater for hMLH1 than for hMSH2. individual centers reported 0 to 100% sensitivity and 40 to 100% specificity.
| Re-review of the returned slides resulted in sensitivities of 0–90%. 12 centers experienced difficulty with lack of internal positive control or high background.
| Overall, four laboratories performed relatively well with both hMLH1 and hMSH2 staining protocols. The key element common to these and distinguishing them from the rest was a heated antigen retrieval step. Steam treatment in the presence of EDTA provided the best results although steam and citrate buffer also provided acceptable results.

| Study Quality | Yes | No | Unc
1 | Was the description of how MSI or IHC and other genetic techniques described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
2 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
3 | Was MSI, IHC, other genetic testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | X
4 | Was there a clear description of which mismatch repair mutations were being tested for? | X
5 | Were quality control methods described for the molecular and genetic tests? | | X
6 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | X
7 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | X
8 | Was microdissection performed? | | | X
9 | Did the study specify whether the biological tissues were from patients known to have HNPCC clinically? | X
10 | Did the study include a control group in which biological material was obtained from patients known not to have HNPCC clinically | X
11 | Overall rating (A B C) | B

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Murakami 2004 Japan Single
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
47 participants who had genetic testings.42 completed 1-month psychologic follow up | 6/27 probands had positive genetic test | | | Probands or unaffected relatives whose family members had been identified as carrying the hMSH2/hMLH1 mutation before or during this psychologic study procedure, and age ≥ 20 yrs. | Structured Clinical Interview based on DSMIIIR or DSMIV | 3/27 probands had minor depression at 1 month (1 had minor depression at baseline). | See Figure 1 in original paper. | Disclosure of genetic test results for HNPCC may not cause significant psychologic distress in Japanese probands or relatives, but healthcare providers should not neglect to assess these individuals for psychologic responses, such as minor depression or posttraumatic stress symptoms. | B
| 21/27 probands received uninformative test result | | | | | 2/42 had posttraumatic stress symptoms at 1 month (both had positive test results).
| 5/15 relatives received positive test | | | | | 5/42 had feelings of guilt.
| 10/15 received negative test | | | | | The only predictor of psychologic distress found was the presence of a major or minor depression (OR 19.41; 95%CI, 1.42–264.95).
| Did all patients have a personal history of an HNPCC-related cancer? Check one
| Yes | No | Uncl
| | X

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study: Nakahara, 1997

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Patients who met the Japanese registry's clinical diagnostic criteria for HNPCC proposed at the 34^th^ Annual Meeting of the JSCCR | MSI was performed in all 32 patients with (multiple) colonic and/or extracolonic cancers. PCR-SSCP analysis of hMSK2 and hMLH1 mutations was performed in DNA samples from 11 MSI phenotype cases (of the 18 MSI+ cases). | hMSK2 and hMLH1 | | Y | N | ? | Am 1 | x | ND
Country: Japan | | | ≥5 MSI markers used? | x | | | Am R
Center: Single | | | MSI-H defined by ≥ 2 markers? | x | | | Beth 1
| | | Microdissection? | | | X | Beth R
| | | Gene screening? | X | | | MSI-H
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | Not the NCI marker set. | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other | x
| | | | | | | MSI phenotype, defined as “MSI+ in cancer lesions at most of the microsatellite loci examined.”

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
N=32 | 7 patients with MMR / 11 patients with CRC and MSI phenotype 1 MLH1, 2 MSH2; 4 MLH1&MSH2 | 32 patients with CRC, 22% positive AM, 56% positive MSI | 5 (28%) of the 18 MSI+ patients fulfilled the Amsterdam criteria | “The ‘Japanese criteria’ have the advantage of being able to detect more HNPCC kindreds from borderline HNPCC kindreds, compared to the Amsterdam criteria. We propose that a microsatellite assay is necessary to detect more “true-HNPCC kindreds” from borderline HNPCC kindreds, and molecular findings of MSI phenotype should be added to the criteria for HNPCC.” | ND | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | ND | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | x
Mean age=59.3 | | | 2 (14%) of the 14 MSI- patients fulfilled the Amsterdam criteria | | | Two of the 11 patients analyzed were from the same family. Small sample size. Highly selected sample. | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
%Male=41 | | | | | | | | Other (specify) | | | Am 1 +
Exclusions=66%, MSI- (n=14) or non-MSI phenotype cases (n=7) | | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | 5/7 MSI high | Am R +
For the 11 patients with CRC and MSI phenotype: Mean Age: 45 Male: 45% | | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (Japanese registry's clinical diagnostic criteria for HNPCC) | x

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with CRC who fulfilled the Japanese registry's clinical diagnostic criteria for HNPCC and had MSI phenotype (MSI+ in cancer lesions at most of the microsatellite loci examined) | Am 1 + | x | + | (A) 4 | (B) 1
NOTE THAT WE DO NOT KNOW HOW MANY OF THE MSI-L&S WERE AM1 SO WE CANNOT ESTIMATE THE SAME TABLE ASSUMING THAT ALL MSI-S&L ARE NEGATIVE FOR MUTATIONS | Am R + | | - | (C) 3 | (D) 3
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Un clr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | x
2 | Inclusion criteria clear? | x
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | x
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | x
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | x
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | x
7 | Were withdrawals from the study explained? | x
8 | Did the authors report AND analyze results for deleterious MMR mutants | | x
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | x
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | x
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | x
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | x
14 | Were quality control methods described for the molecular and genetic tests? | | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | x
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Norum 2000 Norway Single Center
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
11 health insurers in Norway were mailed a questionnaire to evaluate two hypothetical individuals' requests for insurance; one has HNPCC mutation, the other has BRCA1/BRCA2 | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | 9/11 insurers responded. | | In Norway: “According to the survey, individuals with hereditary risk for breast or CRC may experience insurance discrimination simply based on family history of cancer. Genetic testing results are generally not included in determination of health insurance. Therefore, based on the present state, Norwegians should have no need for hesitation in undergoing genetic testing out of fear of insurance discrimination.” | C
| Yes | No | Uncl | | | 2 companies reported results on personal indemnity insurance.
| | | | | | There were no restrictions for individuals with a genetic risk of breast CA when seeking life insurance or disability pension. One company raised premium on the one with genetic risk of CRC.
| | | | | | Another company offered standard or higher rate of premium on personal indemnity insurance in the person with genetic risk of CRC.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study: Park, 1999, 2002, & 2007

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
123 pts (123 families) with Suspected-HNPCC which were not Am1; from 8/58 centers (7 countries) of ICG-HNPCC. | All 123 S-HNPCC received genetic testing. All 154 excluded Am1 have received genetic testing (Discussion) | HMLH1 (n=123) | | Y | N | ? | Am 1 | | ND
Criteria: | All detected mutations were verified by sequencing | HMSH2 (n=122) | ≥5 MSI markers used? | | | X | Am R
Cat1: (vertical CRC transmission OR 2 CRC siblings in family) AND (multiple CR tumors including adenoma OR >=1 CRC before 50y OR extracolonic cancer endometrium/urinary tract/small intestine/stomach/hepatobiliary/ovary) | | HPMS1 (n=27) | MSI-H defined by ≥ 2 markers? | | | X | Beth 1
Cat2 (Sporadic): 1 CRC patient AND (onset<40y OR endometrial, Urinary tract, or small intestine cancer in patient or a sibling <50y OR 2 siblings with other integral colonic cancers, one aged <50y ) | | HPMS2 (n=24) | Microdissection? | | | X | Beth R
They compare them against 154 Am1 families which have received genetic testing | | | Gene screening? | X | | | MSI-H
| | | Deletion analysis? | X | | | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history | X
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
N=123 S-HNPCC; ND on %M; dropouts not pertinent | 24 with MMR/123 with CRC; 16 with hMLH1 / 123; 8 with hMSH2 /122 | N=123 S-HNPCC-NOT-AM1 and n=154 AM1 pts | NA | Criteria I detected a mutation rate of 28% which is sufficiently high to recommend genetic testing in such families; useful in clinical setting; should be offered genetic testing. Criteria II have been ineffective as a means of identifying individuals with mutations; should not be offered genetic testing. | NO | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 19/67 for Cat1; 5/56 for Cat2 → 24/123 S-HNPCC 77/154 for Am1 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
| | | | | | In the definitions of Criteria II, authors added the <40y age factor post hoc; 50/56 crit2 pts are because of the age factor -only 3/50 had mutations (see Discussion). | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | X | | Am 1 + | X
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (see the description of the population) | X
| | | | | | | | Other (specify) | | | Other (Discussion: 50 centers didn't test because the PIs are clinicians; testing is expensive; as of that paper, it was unclear whether non Am1 pts need testing) | X

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Defined above. | Am 1 + | X | + | 77 | 77
Am1 vs Cat1 & Cat2 S-HNPCC | Am R + | | - | 24 | 99
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Un clr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | X
7 | Were withdrawals from the study explained? | | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | | | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | | | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | | | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Peel, 2000

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Referral HNPCC case families (Amsterdam criteria) | MSI were performed in 10 families; MSH2 and MLH1 were done in 11 families | MSH2 and MLH1 | | Y | N | ? | Am 1 | X | 2 MLH1 Were truncating and expected to be pathogenic; 1 MLH1 was a nonsense mutation; 2 MSH2 were predicted to cause missense changes and likely to disrupt MSH2 function
These were from the ICG HNPCC group database (but they give MSI-HL vs MSI which is not covered in the other papers) | | | ≥5 MSI markers used? | X | | | Am R
| | | MSI-H defined by ≥ 2 markers? | | | X | Beth 1
| | | Microdissection? | X | | | Beth R
| | | Gene screening? | X | | | MSI-H
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
11 families | 5 families/11 families have MMR 3 MSH2 and 2 MLH1; 2 mutations were previously identified; 3 were novel mutations | 5/556 had Am1 (.9%; 0.3 to 2.1%) | NO comments | “The prevalence of HNPCC in the general population is most likely closer to 1% rather than 5% Previously reported characteristics of HNPCC like proximal tumor location may not always hold true in a population-based sample.” | No | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 5/11 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
| | | | | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 + | X?
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | 4/9 MSI H or Low | Am R + | X?
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
| Am 1 + | | + | 3 | 1
| Am R + | | - | 0 | 5
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L* | X
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only | X

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Un clr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | | X
2 | Inclusion criteria clear? | | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | X
7 | Were withdrawals from the study explained? | | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Perrin, 2001, RefID 1361 Country: France Center: single
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
A retrospective series of 225 patients diagnosed with sporadic CRC. 208 tumors were tested for IHC, and correlations with survival were performed by log-rank test and Cox model. | ND | | | A retrospective series of 225 patients diagnosed between 1990 and 1998 with sporadic colorectal cancers underwent surgery. There were 121 men and 104 women. 46% were >65 years old. | ND | 27 of 208 (13%) of the tumors tested showed abnormal MSH2 and/or MLH1 expression. | 17/225 (7.5%), no IHC testing | Abnormal IHC measurement of MLH1 and /or MSH2 protein were frequently tumors of proximal colon; in this subpopulation or proximal tumors, MSH2 and/or MLH1 negativity was associated with a longer disease-free survival. | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | For the whole population, there was no association of MSH2 and/or MLH1 status (by IHC) with either overall or disease-free survival. | | | Retrospective series of sporadic CRC cases No information on treatments.
| Yes | No | Uncl | | | 56/225 tumors were located in the proximal colon. 15/56 (31%) tumors were negative for either protein or both. Negativity of MLH1, and “MSH2 and/or MLH1” were correlated with a localization in the proximal colon (p=0.02 and p<0.01, respectively). Negativity of MSH2 was close to being significantly associated to this localization (p=0.07); the absence of significance may be due to a low number of cases (n=10).
| | | x | | | For the subpopulation of proximal tumors, MSH2 and/or MLH1 negativity was associated with a longer disease-free survival.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
| | x
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND x | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Peterson 2003 (RefID 833) US Single Center
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
39 members of 5 families, representing 30 separate households were interviewed by telephone. Each family included a proband with HNPCC mutation who had genetic counseling and testing through clinical research protocol, each family included at least 5 members estimated to be at 50% risk of carrying a mutation (regardless if they have had actual genetic testing) | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | 1 The identification of a cancer-predisposing gene mutation was new information that confirmed their beliefs, and families were not shocked or surprised by the news. This information was not viewed as a medical crisis.; 2 No one reported that the news of the mutation was intentionally withheld from any family members. They willingly shared this information with other relatives, including those who did not participate in the study.; 3 Compared with mutation carriers, those who tested negative for a mutation and those who did not test perceived those topics as less personally relevant and were less involved in discussing the mutation and the need for genetic testing. Spouse's reactions were similar.; 4 Probands assumed that each adult who was told about the mutation would be responsible for telling his or her children; however, probands did not follow up with these adults to find out if news about the mutation had been actually conveyed to those children. Participants (other than probands) viewed themselves as primarily responsible for notifying their nuclear family and encouraging them to seek counseling or testing. | | “Family members who were persuaded to seek those services by the proband were more likely to have counseling and testing and were more likely to seek those services sooner. Genetic counseling should attempt to identify the existing communication norms within families and ways that family members can take an active role in encouraging others to learn about their cancer risk and options for testing. Interventions may also need to target beyond the immediate family and to unaffected family members who may be central to the communication process (eg, spouses of mutation carriers).” | C
| Yes | No | Uncl
| | x

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Pinol, 2005

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Newly diagnosed CRC; Spain, multi-center | MSI and IHC performed in all patients with CRC; testing centralized in 2 centers; pts with MSI and/or IHC of MSH2 or MLH1 underwent germline genetic testing for MSH2 and MLH1 by probe amplification and sequencing | MSH2 and MLH1 | | Y | N | ? | Am 1 | | Predicted transcript alteration; literature and databases
Excluded FAP, IBD, patient or family refusal to participate | | | ≥5 MSI markers used? | | X* | | Am R
| | | MSI-H defined by ≥ 2 markers? | | | | Beth 1 | X
| | | Microdissection? | | X | | Beth R | X
| | | Gene screening? | | X | | MSI-H
| | | Deletion analysis? | X | | | MSI-L
| | | Conversion analysis? | | | X | IHC | X
| | | Pre screen with BAT26 and if non-conclusive the remaining battery of the 5 marker set | | | | Age <50 | X
| | | | | | | Suggestive family history | X
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI)Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
1222/1872 eligible | 11 among the 91 tumor samples that were genotyped (MSI OR IHC abnormalities) | 24% Beth revised | See tables for various data | MSI testing and IHC testing are equivalent in terms of cost-effectiveness to screening for the MMR. | Unclear | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | 4/22 = 18% (but 4 MSI-S and IHC(+) were not genetically tested) | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | X, on MSI or IHC results
| [To clarify: 91 were MSI OR IHC abnormal; 73 were abnormal in MSI AND IHC; 10 ONLY in MSI and 8 ONLY in IHC] | 18% Beth original | | | | | | Amsterdam R | | AMONG THE GENETICALLY TESTED | If yes, which clinical criteria (check all that apply)?
| | 1.8% (22)Am2 | | | | | | Other (specify) | | 4/18 = 22% | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | ND | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
| Am 1 + | | + | (A) | (B)
| Am R + | | - | (C) | (D)
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | X
7 | Were withdrawals from the study explained? | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Pistorius, 2000

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
106 pts with Fam Hx or early Hx of Cancer were referred 72 patients met Bethesda, but not all of them CRC. | MSI was performed; sequencing was done in patients with MSIH | hMLH1 and hMSH2 and hmsh6 | | Y | N | ? | Am 1 | X | Based on predicted alteration, literature
Patients from Germany and Czech Republic | IHC only in those with mutations (negative stain in all) | | ≥5 MSI markers used? | X | | | Am R | x
(multicenter?) | | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1 | x
| | | Microdissection? | | | x | Beth R
| | | Gene screening? | x | | | MSI-H
| | | Deletion analysis? | | | x | MSI-L
| | | Conversion analysis? | | | x | IHC
| | | The NCI marker set was used | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
72 index patients fulfilled Bethesda; Not all 72 CRC | 15 patients with MMR in 38 MSI-H patients, 6 MLH1 8 MSH2 1 MSH6 | 72/106=68% had Beth | | Family history and MSI-H are both strong indicators of germline mutations in MSH2, MLH1 and MSH6 genes. Identification of mutation status allows clear-cut decisions on whether or not inclusion in surveillance programs is indicated. | Of the 15 families with mutations, 60 patients and family members were analyzed, 26 were affected and 8 were asymptomatic. They were included in the HNPCC surveillance program, where as 26 noncarriers were excluded from this program. But 3 of 26 noncarriers presented with colon CA at age 35, testicular CA at age 30, and 2 colon polyps at age 58, respectively. | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | x | 12/17 (Amsterdam and MSI-H) | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
19 Am2 and they are all CRC | Among 19 Am2, 17 were MSI-H and 12/17 had mutations | Among Beth: 50/72 Beth1–3 19/72 Am1 | | | | | | Amsterdam R | X | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | 38/72 | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 + | x
| | | | | | | | Bethesda | x | | Beth R + | X
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with CRC who fulfilled Bethesda and had MSI-H | Am 1 + | | + | 12 | 5
| Am R + | x | - | 3 | 18
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | x
2 | Inclusion criteria clear? | x
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | x
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | x
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | x
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | | x
7 | Were withdrawals from the study explained? | | x
8 | Did the authors report AND analyze results for deleterious MMR mutants | x
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | x
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | x
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | x
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | x
14 | Were quality control methods described for the molecular and genetic tests? | | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | | x
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Plaschke 2004, Ref ID 382, Multicenter Germany
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Clinical and molecular data on families with an established mutation in MSH6 were compared with families with MLH1 and MSH2 mutations | Fulfillment of Amsterdam 1 or 2 plus Bethesda plus absence of MSH6 expression by protein staining plus normal expression of MLH1 and MSH2 by protein staining | | | 1) Patients had developed tumors that were either low or high MSI | Observation only (not clear if patients underwent any screening) | Among 396 enrolled members of families with pathogenic MSH6 mutations, 115/29%) were affected by malignant disease. This rate was lower than for families with MLH1 or MSH2 mutations (37.5%). | ND | “Later age of disease onset and lower incidence of colorectal cancer may contribute to lower proportion of identified MSH6 mutations in families suspected of HNPCC. However, in approximately half of these families, at least one patient developed colorectal or endometrial cancer in the fourth decade of life. Therefore, a surveillance program as stringent as that for families with MLH1 or MSH2 mutations is recommended.” | C
| Patients selected from a registry based upon Amsterdam I and II criteria without age restriction and Bethesda guidelines | | | 2) MLH1 and MSH2 were expressed in the tumor cells | | Colorectal cancer was statistically less frequent among all tumors (42.4 versus 66 percent). Such a difference was not observed for any other HNPCC tumors. | | | Potential for selection bias.
| A total of 706 families had been registered. Available tumors were analyzed for MLH1 and MSH 2 protein expression and selected patients in whom these proteins were expressed underwent additional testing for MSH6 expression. | | | Tumor samples from selected patients were studied for MSH6 expression with IHC and by sequencing. | | Median age of onset of colorectal cancer in putative mutation carriers was 10- years higher than for MLH1 and MSH2 (54 versus 44 percent). | | | Extent to which a mutation was confirmed genetically in MLH1 and MSH2 families unclear.
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Median age of onset of any tumor was 8 years higher for MSH6 (51 versus 43). | | | Any interventions, screening was not described.
| Yes | No | Uncl | | | Cumulative risk by age to develop CRC or any tumor was statistically lower for MSH6 mutation carriers compared with MLH1 and MSH2. | | | How tumors were verified/ascertained was not described.
| | | X

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | X
| | | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | X | Can't tell
| | No
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Analysis | | | | | | A) | B | X
| | | | | | (strong | (moderate) | C
| | | | | | | | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | X | Provider | Client | Institution
| | Organization/group
Indicate the unit of analysis | Community | X | Provider | Client | Institution
| | Organization/group
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | X
| | | | | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | X | NA
| | | ND
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | X | No | Can't tell
| Yes

Study: Ponz de Leon 1999

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
1899 colorectal malignancies and 1831 patients registered of whom a family history could be obtained in 1721 | Patients and families classified into five categories to a more or less likely genetic basis: 1) HNPCC (Amsterdam 1) 2) suspected HNPCC (2 generations with CRC or other HNPCC tumor plus at least one before 50 plus 50% or more of siblings affected by cancer), 3) juvenile cases 4) A specific cancer aggregation; 5) Sporadic cases. | hMLH1 and hMSH2 | | Y | N | ? | Am 1 | X | ND
Cancer registry in Modena, Italy and surrounding communities | MSI and mutation analysis performed in 18 families with HNPCC and 18 with suspected HNPCC | | ≥5 MSI markers used? | X | | | Am R
| | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1
| | | Microdissection? | X | | | Beth R
| | | Gene screening? | X | | | MSI-H | X
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history | X
| | | | | | | Specify Family history categories 1–5 as in column 2
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
18 in HNPCC and 18 suspected | 3 mutations detected of 36 patients analyzed 2 hMSH2 1 MLH1 | Of 1721 in whom a family history could be obtained, 47 individuals fulfilled Am-1 and 84 suspected HNPCC | ND | Incidence of mutations using a population-based approach lower than previously reported and limited to families with full-blown HNPCC. | ND | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 3/18 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
| | | | | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 + | X
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | 11/18 | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify) “Suspected HNPCC as above” | X

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Amsterdam criteria 1 positive | Am 1 + | | + | (A) DATA CANNOT BE EXRACTED | (B)
| Am R + | | - | (C) | (D)
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | | X
7 | Were withdrawals from the study explained? | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | | | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Porteous, 2003, RefID 736, UK, Single
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
A total of 160 patients who were approached for the Colorectal Cancer Genetic Susceptibility (COGS) study between February 1999 and July 2000, were eligible to participate in the patient feedback study. Of the 160 questionnaires given to patients, 111 (69%) were returned completed. Only one of the 111 patients who completed the questionnaire had declined to participate in the COGS study. | Newly diagnosed CRC patients under the age of 55 years are offered genetic testing for 3 mutations in MMR genes (i.e. MLH1, MSH2, MSH6) | | | Patients who were approached for the Colorectal Cancer Genetic Susceptibility (COGS) study between February 1999 and July 2000, were eligible to participate in the patient feedback study. | N/A | “Of the 111 participants, 61 (55%) were male and 50 (45%) were female ranging in age from 31 to 55 years (mean=48.6, s.d.=5.5). The risk of HNPCC for their relatives was low for 60% of participants (n=65), moderate for 39% (n=42) and high for 2% (n=2). The majority were married or living with a partner (n=90, 83%), and had been educated up to age 16 years only (n=56, 60%). In all, 81% (n=89) had at least one child. After receiving the information sheet about the COGS study, but prior to discussing participation with a member of staff, 91% (n=101) reported that they had decided to take the genetic test, one individual (1%) had decided not to take the test and nine (8%) were undecided. | | “The majority of participants found it highly acceptable to have information about HNPCC brought to their attention at a time when they were coping with a new diagnosis of colorectal cancer, despite a lack of prior awareness that the disease could run in families. The vast majority had decided to accept the offer of a genetic test and reported high levels of subjective understanding concerning genetic testing. | B
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Most participants (n=97, 87%) reported some degree of difficulty coming to terms with the diagnosis of cancer, with 15% (n=17) overall reporting that it had been very difficult. Similarly, the majority of participants (n=89, 80%) indicated that it had been difficult to cope physically with their illness and treatment, with eight participants (7%) overall reporting that it had been very difficult. A total of 45% of participants (n=48) rated their current worry about their cancer and its treatment at or above the midpoint of 4 on a 1 (not at all) to 7 (all the time) scale. | | The results suggest that although receiving information about HNPCC did not cause most participants undue worry, a minority of participants rated this worry at the top end of the scale. This was despite the fact that most had been informed that their relatives were at low risk of HNPCC. Likewise, these participants tended to have rated worry about their cancer and its treatment at the top end of the scale.” | Results from this survey can only apply to those newly diagnosed CRC patients who decided to accept mutation testing.
| Yes | No | Uncl | | | In total, 19% of participants (n=21) rated their current level of worry caused by the genetics information at or above the midpoint of 4 on a 1 (not at all) to 7 (all the time) scale. Of these 21 participants, 80% (n=16) had rated their current worry about their cancer and its treatment at or above the midpoint, 57% (n=12) and 43% (n=9) had been informed that their relatives were at low or moderate risk of HNPCC, respectively.”
| x

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 x | 5 x | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study: Raedle 2001

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Single center, Germany | Family history obtained from all, MSI performed on all MLH1 promoter methylation analysis performed on all MSI Genomic sequencing performed in all patients with MSI | MLH1 and MSH2 | | Y | N | ? | Am 1 | X | Reported as “pathogenic” based upon previous reports but details not described.
125 consecutive, unrelated patients with CRC | | | ≥5 MSI markers used? | X | | | Am R | X
| | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1 | X
| | | Microdissection? | X | | | Beth R
| | | Gene screening? | | X | | MSI-H
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history | X
| | | | | | | Specify Analyzed each component of Bethesda 1
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
125 no dropouts 56 women 69 men Mean age 52 +/- 14.4 (range 22–95) | 11 had pathogenic mutation in MLH1 (4) MSH2 (8) or both (1) NB. Doesn't add up to 11, because they double count the common. | 58/125 fulfilled at least one of seven Bethesda criteria (31 met one, 12 met 2, 8 met 3 and 7 met 4). Criteria B4 mostly commonly satisfied (i.e. CRC or endometrial cancer diagnosed age <45) | ND | “Bethesda guideline useful for selecting patients for MSI. MLH1 and MSH2 should be recommended in all patients with CRC and MSI who fulfill at least one Bethesda criteria. MLH1 promoter methylation may accompany rather than initiate carcinogenesis in patients with CRC who have mismatch repair gene defects.” | ND | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | ND | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | X
| | MSI 22/125 | | Authors present diagram suggesting that patients with CRC who fulfill AM II should undergo genetic testing for MLH1 and MSH2. Those who do not should be asked Bethesda. If positive, MSI testing should be done and genetic testing done if MSI positive. | | | | Amsterdam R | X | [CANNOT ANSWER THIS QUESTION, BECAUSE WE HAVE MMR AMONG MSI-H] | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | Based on the proportions and the CIs reported in the paper: | Am R +
| | | | | | | | Amsterdam R | | Sens of Am1 is 6/22 | Beth 1 +
| | | | | | | | Other (specify) | | Sens of Am-R is 10/22 | Beth R +
| | | | | | | | | | Spec of Am1 is 97/103 | Age <50
| | | | | | | | | | Spec of Am-R is 93/103 | Suggestive family history (specify)
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Other (specify)
| | | | | | | | Amsterdam R
| | | | | | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Nonselected patients with CRC who were MSI-H | Am 1 + | X | + | (A) 6 | (B) 0
| Am R + | | - | (C) 5 | (D) 11
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Nonselected patients with CRC who were MSI-H | Am 1 + | | + | (A) 8 | (B) 2
| Am R + | X | - | (C) 3 | (D) 9
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Nonselected patients with CRC who were MSI-H | Am 1 + | | + | (A) 11 | (B) 6
| Am R + | | - | (C) 0 | (D) 5
| Beth 1 + | X
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Nonselected patients with CRC who were MSI-H | Am 1 + | | + | (A) 9 | (B) 6
| Am R + | | - | (C) 2 | (D) 5
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| BG, items 1–3

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Nonselected patients with CRC who were MSI-H | Am 1 + | | + | (A) 2 | (B) 2
| Am R + | | - | (C) 10 | (D) 8
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| BG, item #2

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Nonselected patients with CRC who were MSI-H | Am 1 + | | + | (A) 8 | (B) 1
| Am R + | | - | (C) 4 | (D) 9
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| BG, item #3

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Nonselected patients with CRC who were MSI-H | Am 1 + | | + | (A) 8 | (B) 3
| Am R + | | - | (C) 4 | (D) 7
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| Individuals with CRC or endometrial Cancer <45

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Nonselected patients with CRC who were MSI-H | Am 1 + | | + | (A) 1 | (B) 0
| Am R + | | - | (C) 11 | (D) 10
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| Individuals with right-sided CRC with an undifferentiated pattern (solid, Cribriform, defined as poorly differentiated or undifferentiated Carcinoma composed of irregular, solid sheets of Large eosinophilic cells and containing small gland-like Spaces).

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Nonselected patients with CRC who were MSI-H | Am 1 + | | + | (A) 3 | (B) 0
| Am R + | | - | (C) 9 | (D) 10
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| Individuals with signet-ring cell type CRC diagnosed At age <45

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Nonselected patients with CRC who were MSI-H | Am 1 + | | + | (A) 0 | (B) 0
| Am R + | | - | (C) 12 | (D) 10
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| Individuals with adenomas Dx <40

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Uncl
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | | X
7 | Were withdrawals from the study explained? | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Renkonen-Sinisalo, 2000, RefID 1701 Finland, Single
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
The patients came from 57 different families (49 families with a known mutation, 8 families that met the Amsterdam criteria). There were 137 CRC patients. They were divided into 2 groups, depending on how CRC had been diagnosed. 35 cases of CRC in 33 patients had been diagnosed via the surveillance program. Of these, 13 patients in whom CRC had been detected during very first surveillance examination (age range, 28–59 years). Among the others, 20 patients had been aware of their inherited susceptibility to cancer and had undergone thorough colonic examination at least once. | Known mutation or Amsterdam criteria | | | All new CRC cases occurring in known HNPCC families in Finland from 1983 to the end of 1997. | Surveillance program involving use of colonoscopy or double-contrast barium enema and signoidoscopy | No significant difference in age or gender distribution between the 2 groups of patients. | Retrospective analysis; some data was missing | “Colonoscopic surveillance is beneficial in at-risk members of the HNPCC families. Even if CRC cannot be prevented by polypectomies, tumors found during surveillance usually are detected at least so early that expectation of survival is excellent and significantly better than if there had been no surveillance.” | B
115 carcinomas had been found in 104 patients merely because of symptoms. These patients had undergone colonic examination and mostly not been aware of their susceptibility to cancer nor had they taken part in any surveillance program. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | The stage distribution of the 34 tumors in the surveillance group was significantly more favorable then that of the 114 tumors in the nonsurveillance group.
| Yes | No | Uncl | | | In the nonsurveillance group, CRC was considered disseminated or nonoperable in 19 cases (17%).
| x | | | | | Synchronous CRC occurred in 2 patients in the surveillance group and in 10 in the nonsurveillance group. During this 15- year period, metachronous CRC was observed in 2 and 11 patients in the surveillance and nonsurveillance group, respectively.
| | | | | | Five of 33 patients (15%) in the surveillance group had died, compare to 40 of 104 patents (38%) in the nonsurveillance group. CRC resulted in 2 deaths in the surveillance group and 33 deaths in the nonsurveillance group.
| | | | | | The cumulative CRC-specific survival was 93% in the surveillance group, significantly higher than the 68% in the nonsurveillance group (p<0.02) 10 years after surgery. Similar results were shown for patients' overall survival.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10 x
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11 x
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Rijcken, 2003 The Netherlands Single center
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Females from HNPCC families identified by physicians and national registry. Annual screening performed and results treated accordingly. Women encouraged to report symptoms | MMR gene mutation or Amsterdam criteria II | | | MMR gene mutation or Amsterdam criteria II, 30–35 years | Annual screening consisting of gynecological exam, transvaginal ultrasound (TVU), serum levels of CA125 (normal ≤35 kU/L). Endometrial sampling as indicated | 179 TVU performed over 197 patient years, Endometrial sampling for 11 from 17 TVU results, 4 from clinical symptoms | None | “No asymptomatic malignant lesions detected but asymptomatic premalignant lesions detected and treated appropriately. Annual gynecologic screening with TVA as triage for endometrial sampling remains justified for women motivated for it but also that recognition and reporting of clinical symptoms by the women is of utmost importance.” | B
Women included in the program had a known MMR gene mutation and/or belonged to a family fulfilling the Amsterdam criteria II | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | 14/17 endometrial samplings showed no severe pathology, 3 premalignant lesions detected resulting in 1 hysterectomy for premenopausal woman and 2 hysteroscopy and curettage procedures with normal histology for 1 pre- and 1 postmenopausal women. | | | Data gather retrospectively
41 enrolled and followed for 5 year (median, 5 months to 11 years) | Yes | No | Uncl | | | Another postmenopausal woman reporting symptoms was diagnosed with interval endometrial cancer outside regular screening program resulting in hysterectomy and bilateral salpingo-oophorectomy
At enrollment: | | X | | | | 115 serum CA125 levels ranged from 1–24 kU/L with median of 7 kU/L
85% premenopausal | | | | | | No ovarian cancers detected by screening or outside of annual screening
Genetic status known for following:
8 MLH1
2 MSH2
1 MSH6

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
| x | | | | | x
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study: Rossi, 2002

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | x
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | x
Was a minimum of hMLH1 and hMSH2 sequencing performed? | x

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
25 different Brazilian families with suspected hereditary CRC were consecutively enrolled from 1/1995 to 7/1999 | All patients underwent gene sequencing. | HMSH2 and hMLH1 | | Y | N | ? | Am 1 | x | ND
Country: Brazil | Note: MSI was not considered as a standard preliminary test in this study | | ≥5 MSI markers used? | | | | Am R | x
Center: Single | | | MSI-H defined by ≥ 2 markers? | | | | Beth 1
- Am2 criteria, or; - A relative (degree?) with CRC or HNPCC-related cancer, or; - Proband aged <50y with or without affected relatives, or Multiple neoplasms in a proband | | | Microdissection? | | | | Beth R
| | | Gene screening? | | x | | MSI-H
| | | Deletion analysis? | | x | | MSI-L
| | | Conversion analysis? | | x | | IHC
| | | No MSI | | | | Age <50 | X
| | | | | | | Suggestive family history | X
| | | | | | | Familial CRC without fulfilling Amsterdam criteria
| | | | | | | Other

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
N=25 | 10 patients with MMR / 25 patients with CRC 8 MLH1 2 MSH2 | 25 patients with CRC, 20% positive AM-I, 4% AM-II, 28% familial CRC w/o fulfilling AM, 44% probands <50 years | ND | “In addition to the Amsterdam criteria I and II, the physician in Brazil should also consider HNPCC when a patient is young and has CRC or when a patient has CRC and a family history of HNPCC, even if it is nontypical, with specific attention being given to gastric tumors.” | ND | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | x | 1/4 (4 have Am1) | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | x
Mean age=46.16 | | | | | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
Dropout=0 | | | | | | | | Other (specify) | | | Am 1 + | x
Probands 60% males | | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | 2/5 (5 have Am2= 4with Am1 and 1 with Am2) | Am R + | x
| | | | | | | | Amsterdam R | x | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | ND | Age < 50 | x
| | | | | | | | Amsterdam R | | | Suggestive family history (Familial CRC without fulfilling Amsterdam criteria) | x
| | | | | | | | Other (specify) | | | Other (specify)
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND
| | | | | | | | Amsterdam R
| | | | | | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check | Index test | Number with MMR+ | Number with MMR-
| | ONE
Patients with CRC who had suspected hereditary CRC (fulfilled AM-1 or AM-II, Familial CRC without fulfilling Amsterdam criteria, probands presented at an early age (<50years) or a proband presented with multiple CRCs) | Am 1 + | | + | (A) 2 | (B) 3
| Am R + | X | - | (C) 8 | (D) 12
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check | Index test | Number with MMR+ | Number with MMR-
| | ONE
Of the 5 pts with Am2, 4 had Am1! So among those with AM2 | Am 1 + | X | + | (A) 1 | (B) 3
NB very small table | Am R + | | - | (C) 1 | (D) 0
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Un clr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | x
2 | Inclusion criteria clear? | x
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | x
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | N/a
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | x
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | x
7 | Were withdrawals from the study explained? | | | N/a
8 | Did the authors report AND analyze results for deleterious MMR mutants | | | x
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | | | N/a
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | x
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | x
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | x
14 | Were quality control methods described for the molecular and genetic tests? | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | x
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Salovaara, 2000

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
535 consecutive patients with CRC from 9 hospitals in Finland | MSI wad done in all patients, founder mutations 1 & 2 in MLH1 were looked for in all patients; MLH1 and MLH2 sequencing was done in MSI positive and founder mutations negative patients | Founder mutations 1 and 2 in MLH1 and other mutations in MLH1 and MLH1 | | Y | N | ? | Am 1 | x | Literature and previous analyses on the founder mutations, and comparison with noncancer controls
mean age 67 | | | ≥5 MSI markers used? | | x | | Am R | x
| | | MSI-H defined by ≥ 2 markers? | | x | | Beth 1
| | | Microdissection? | | | x | Beth R
| | | Gene screening? | | x
| | | Deletion analysis? | | | x | MSI-H
| | | Conversion analysis? | | | x | MSI-L
| | | | | | | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other | x
| | | | | | | MSI

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
535 | 18 MMR/535 patients with CRC 17 MLH1 and 1 MSH2 | 3/535 (0.6%) Am I | | Large scale molecular screening for HNPCC can be done by a 2-stage procedure: screening for founders mutations, then MSI, then sequencing for those with + MSI. | | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | Combined 5/535 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased?
mean age 67 | | 2/535 (0.4%) Am R | | The authors also proposed that a strategy that screened for MSI based on age<50, familial disease or multiple tumor, would identify most tumors. | | | | Amsterdam R | X | | If yes, which clinical criteria (check all that apply)? | | X
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | Combined 4/5 | Am R +
| | | | | | | | Amsterdam R | X | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check | Index test | Number with MMR+ | Number with MMR-
| | ONE
Consecutive CRCs | Am 1 + | | + | 4 | 1
| Am R + | | - | 14 | 516
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| Combined Am1&R | X

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check | Index test | Number with MMR+ | Number with MMR-
| | ONE
Consecutive CRCs | Am 1 + | | + | 18 | 48
| Am R + | | - | 0 | 469
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI | X

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Un clr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | X
7 | Were withdrawals from the study explained? | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Samowitz, 2001

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Population based sample from the Keiser Permanente Medical care program of Northern California or a 8 county area in Utah. | 1917 people were contacted, but complete questionnaire data and MSI screening in 1066; | MLH1 & MSH2 | | Y | N | ? | Am 1 | | Based on the predicted change in the gene and on the HNPCC mutations database.
Eligible were incident CRC cases aged between 30 and 79 who were mentally competent | Then the 130/171 MSI-H who could be sequenced/had good quality DNA in paraffin blocks → MMR mutations | | ≥5 MSI markers used? | X | | | Am R
| | | MSI-H defined by ≥ 2 markers? | | X** | | Beth 1
| | | Microdissection? | | X | | Beth R
| | | Gene screening? | | X
| | | Deletion analysis? | X only for Finnish mutation | | | MSI-H
| | | Conversion analysis? | | X | | MSI-L
| | | 3 measures of instability 1: BAT 26; 2: TGFbetaRII 126–128; 3: 10 tetranucleotide repair markers used previously (ref); Measures 1 and 3 are reported to be are highly correlated with the 5 2nucleotide marker set. | | | | IHC
| | | ** with >=one measure of instability. | | | | Age <50
| | | | | | | Suggestive family history | X
| | | | | | | CRC in Fam
| | | | | | | Other | X
| | | | | | | Endom Ca in Fam Age <55

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
1917 people were contacted, but complete questionnaire data and MSI screening in 1066; | Among the 130 MSHI-H 7 MMR mutations (5 ML1; 3 MSH2 - one person had both mutations) | Of 130 MSI-H: | ND | The clinical criteria notwithstanding, MSI testing is important on its own. Ought to be done in all CRC. Incorporation of MSI testing in clinical practice might lessen the need for clinical criteria. | ND | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | ND | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
Then the 130/171 MSI-H who could be sequenced/had good quality DNA in paraffin blocks → MMR mutations | | 18% (23/129)with CRC in family | | The estimated prevalence of HNPCC in the CRC population (0.86%) might be an underestimate. | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)? | | X
| | 5% (6/129) with endometrial ca in family | | | | | | Other (specify) | | | Am 1 +
| | 16% (21/130) aged<55y | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | ND | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify) MSI-H | X

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check | Index test | Number with MMR+ | Number with MMR-
| | ONE
Among 130 CRC with MSI-H | Am 1 + | | + | 4 | 17
| Am R + | | - | 3 | 107
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| Age <55y

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check | Index test | Number with MMR+ | Number with MMR-
| | ONE
Among 130 CRC with MSI-H | Am 1 + | | + | 4 | 19
| Am R + | | - | 3 | 103
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)** | X
| Familial CRC

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Un clr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | NA
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | X
7 | Were withdrawals from the study explained? | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | NA
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Schmeler, K, 2006, US, Multicenter
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score
315 women with HNPCC identified. Those who had undergone prophylactic TAH (14) compared with those who had undergone prophylactic TAH/BSO (47) compared with age-matched, mutation positive women who had not undergone either procedure (n=210 for endometrial cancer and n=223 for ovarian cancer) | Documented MLH1, MSH2 or MSH6 germline mutation. | | | Women with genetic variants of unknown functional significance excluded. | TAH versus TAHBSO versus observation | 0/61 who had undergone a hysterectomy developed endometrial cancer compared with 69/210 controls (p<0.001) | Patients selected from a registry, and thus presumably all had a family history of HNPCC. ? selection bias for groups with increased penetrance? | Findings support consideration of prophylacticTAH/BSO in women with Lynch syndrome after the age of 35, or once childbearing has been completed. (Median age of diagnosis of endometrial cancer was 46, ovarian cancer 42). | B
| Did all patients have a personal history of an HNPCC-related cancer Check one: | | | | | 0/47 women who had undergone oophorectomy developed ovarian cancer compared with 12/223 controls (p=0.09) | Did not describe how patients were assigned to surgery or no surgery ? selection bias. Did not describe what type of screening was performed on women who did not undergo the procedures.
| Yes | No | Uncl | | | Surgical complications in 1/61 women who underwent prophylactic surgery (ureteral injury, ureterovaginal and ureteroeneteric and then rectovaginal fistula)) | Other risk factors for gynecologic malignancy (eg, BMI) not assessed. Effects on survival or death not assessed. Quality of life not assessed
| | | X

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Scott, 2001 RefID 1607 Australia, single
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score
Index patients from 95 families with HNPCC. Each pedigree was classified as either Amsterdam-criteria positive or Bethesda-criteria positive. Genetic analysis was performed on a fresh blood specimen from the youngest living affected proband in each family. Disease verification in affected individuals was based on either examination of pathology reports or death certificates. | Amsterdam-criteria positive or Bethesdacriteria positive | | | ND | ND | Of the 95 families, 12 harbored a genetic change in the hMSH2 gene, 22 harbored a change in the hMLH1gene, and 61 were found not to harbor any change in either gene. When mutation status based on the Amsterdam criteria was compared with that based on the Bethesda criteria, differences between the two groups were observed. As expected, 60% (20/33) of Amsterdam-criteria families were mutation positive, compared with 20% of Bethesda-criteria families (12/32). | ND | “In conclusion, use of the Bethesda criteria for the selection of families for gene analysis results in a reduced probability of mutation detection. Nevertheless, families or patients that can be identified on the basis of these criteria should be offered genetic testing for genes associated with HNPCC, since this will result in an increased rate of identification of gene-mutation carriers. To improve the probability of mutation detection if the Bethesda criteria are adopted, we would suggest that mutation analysis be performed in conjunction with DNA microsatellite testing and, possibly, immunohistochemical staining for DNAmismatch- repair proteins. Subdivision of the mutation-positive and mutation-negative groups makes it possible to tease out subtle differences between the various populations, such as similar ages at onset of disease in the mutation-negative and hMLH1 mutation-positive groups and disease-spectrum differences within each mutation-positive group. Better knowledge of the disease spectrum associated with mutation status will aid in the management of these families. Better classification of the mutationnegative group will aid in identification of additional genes associated with this disorder.” | B
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | There appeared to be no relationship, between the sites of mutations, that could be used to establish a genotype-phenotype correlation, for either hMLH1 or hMSH2. Within each of the two groups, a comparison between the age at onset of CRC, the spectrum of extracolonic disease, and how this related to the mutation-negative group was made. | | | Not sure how representable of the sample population. Familial clustering was considered in analyses
| Yes | No | Uncl | | | Cancer Occurrence
| x | | | | | The overall percentage of tumors observed—in the total population, in the mutation-negative group, and in the hMSH2 mutation-positive and hMLH1 mutation-positive groups—is shown in table 3 of the paper. Briefly, the 9.86% of the total population had CRC and 1.37% had endometrial or ovarian carcinoma. Other types of malignancy were less prevalent.
| | | | | | The relative standardized incidence rates (SIRs), including 95% confidence intervals (95% CIs), for all cancers identified in each group are shown in table 4 of the paper. Among all patients the SIR for CRC was 159.5 (139 – 182.9). This was of the same order among MLH1 and MSH2 carriers (196.8 [143–270.7] and 134.2 [99.1–181.8], respectively), as well as in the mutation negative part of the population (158.6 [132.8 – 189.4]). Data on other malignancies were more sparse, but the estimated SIRs were of similar order across all subgroups (see Table 4 of the paper).
| | | | | | II. CRC
| | | | | | The age distributions of the hMSH2 mutation-positive group and the hMLH1 mutation-positive group were essentially identical, but there was an about 5-year shift in the distribution seen in the mutation-negative group. The average age at diagnosis in hMSH2 mutation-positive families was 45.77 years, and that in hMLH1 mutation-positive families was 47.16 years.
| | | | | | When the authors adjusted for familial clustering there was no statistical difference between the two groups. The average age at diagnosis in the mutation-negative group was 52.7 years. The average age at diagnosis was significantly different from that in the hMSH2 mutation-positive group but was not statistically different from that in the hMLH1 mutation-positive group.
| | | | | | III. Extracolonic cancers:
| | | | | | The frequencies of the following cancer types were found not to differ between the hMSH2 mutation-positive group, the hMLH1 mutation-positive group, and mutation-negative group: lymphoproliferative disease, renal/renal tract cancers, endometrial/ovarian cancers, and stomach cancer. The authors of the paper note that all these malignancies were overrepresented in all three groups, compared with the expected frequency in the general population.

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy ofcounseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A (strong) | B (moderate) | C (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely x | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND x | NA
Allocation Bias | | | | | | A (strong) | B (moderate) | C (weak)
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A (strong) | B (moderate) | C (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A (strong) | B (moderate) | C (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A (strong) | B (moderate) | C (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A (strong) | B (moderate) | C (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND x | NA
Analysis | | | | | | A (strong) | B (moderate) | C (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A (strong) | B (moderate) | C (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study: Shia, 2005

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | x
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | x
Was a minimum of hMLH1 and hMSH2 sequencing performed? | x

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy(brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
A group of 112 colorectal adenocarcinomas (n=83) or adenomas (n=29) obtained from 110 patients treated at the cancer center was assembled. These cases had a family history that fulfilled one of the following criteria: 1) Amsterdam criteria I or II, 2) a set of relaxed AC that we referred to as “HNPCC-like”, and 3) Bethesda criteria Country: US Center: single | All patients started with MSI testing, followed by mutation analysis | MLH1 and MSH2 | | Y | N | ? | Am 1 | | “Mutations were determined to be disease-causing based on sequencing results, segregation analysis, and published data and mutation databases.”
| | | ≥5 MSI markers used? | x | | | Am R
| | | MSI-H defined by ≥ 2 markers? | | x | | Beth 1
| | | Microdissection? | | | | Beth R
| | | Gene screening? | x | | | MSI-H
| | | Deletion analysis? | | | | MSI-L
| | | Conversion analysis? | | | | IHC
| | | *MSI markers were scored for the appearance of novel locus-specific bands in the tumor but not in the DNA from normal tissue. A tumor was scored “MSI present” when the proportion of successfully typed loci exhibiting instability was ≥0.3. | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene) (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
110 patients derived from 84 kindreds., 48/110 males, 50.5 (range 23–78) years old | 49 patients with MMR / 92 patients with CRC analyzed. 13 MLH1, 31 MSH2, 5 MSH6 | 83 colorectal carcinomas, 51% AM I or II, 39% HNPCC-like patients, and 11% Beth | Abnormal IHC was detected in 31 of 41 tumors that exhibited MSI, whereas all 63 tumors that did not exhibit MSI showed presence of expression of all three proteins. | Even though the authors found that IHC could not replace MSI testing, the authors recommended the use of IHC as a first line screening method to identify patients for mutation analysis because of the simplicity and ready availability. | ND | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutatioem | Amsterdam 1 | | ND | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
Total number of tumors assessed was 112, including 83 primary colorectal adenocarcinomas and 29 colorectal adenomas | 36 patients (from 32 families) with disease-causing MMR / 92 patients with CRC analyzed. 9 MLH1, 23 MSH2, 4 MSH6 | 29 colorectal adenomas, 45% AM I or II, 55% HNPCC-like patients | | | | Family clustering not accounted for; primarily tumor analyses; dropouts were not described; a “convenience sample” study | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| 13 patients with variants of uncertain clinical significant MMR / 92 patients with CRC analyzed. 4 MLH1, 8 MSH2, 1 MSH6 | | | | | | | Other (specify) | | | Am 1 + | X
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | X | 31/48 tumors MSI present | Am R + | X
| | | | | | | | Amsterdam R | X | | Beth 1 + | X
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | 4/43 tumors MSI present | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (“HNPCC-like”, defined as 3 or more colorectal cancers among the first- and second-degree relatives) | X
| | | | | | | | Other (HNPCC-like) | X | | Other (specify)
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | X | 29/55 tumors
| | | | | | | | Amsterdam R | X
| | | | | | | | Other (specify)
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | 4/44 tumors
| | | | | | | | Amsterdam R
| | | | | | | | Other (HNPCC-like) | X

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population(e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Colorectal adenomas (n=17) and carcinomas (n=64), fulfilled one of the inclusion criteria: 1) Amsterdam criteria I or II, 2) a set of relaxed AC that we referred to as “HNPCC-like”, and 3) Bethesda criteria | Am 1 + | | + | (A) 29 | (B) 9
| Am R + | | - | (C) 4 | (D) 39
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | X
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Colorectal adenomas (n=12) and carcinomas (n=61), fulfilled one of the inclusion criteria: 1) Amsterdam criteria I or II, 2) a set of relaxed AC that we referred to as “HNPCC-like”, and 3) Bethesda criteria | Am 1 + | | + | (A) 30 | (B) 1
| Am R + | | - | (C) 7 | (D) 35
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (MSI present)** | x

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias)
2 | Inclusion criteria clear?
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing?
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding).
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding)
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)?
7 | Were withdrawals from the study explained?
8 | Did the authors report AND analyze results for deleterious MMR mutants
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)?
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)?
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated?
12 | Was there a clear description of which mismatch repair mutations were being tested for?
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)?
14 | Were quality control methods described for the molecular and genetic tests?
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)?
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors).

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: (Southey, 2005, RefID 3071)

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Men and women from Victorian Colorectal Cancer Family Study who were younger than age 45 years when diagnosed with a histologically confirmed, first primary adenocarcinoma of the colon or rectum from July 1, 1992 to September 30, 1996. A random selection of 222 patients were asked to participate. Country: Australia Single center | Patients answered a risk factor questionnaire, received IHC and MSI screening. Germline MMR mutation testing was conducted for all patients with one or more of the following characteristics: a family history that fulfilled the Amsterdam Criteria for hereditary nonpolyposis colorectal cancer (HNPCC); having a tumor that was high MSI, low MSI, or that lacked expression of at least one MMR protein; and presence in a random sample of 23 patients selected from those who had tumors that were MS stable and did not lack expression of any MMR protein. | hMLH1, hMSH2, hMSH6, and hPMS2 | | Y | N | ? | Am 1 | | Variants were defined to be deleterious if they could be predicted to produce (or were known to produce) a shortened or truncated protein product, or were missense mutations that have been reported previously to be deleterious.
| | | ≥5 MSI markers used? | x | | | Am R | x
| | | MSI-H defined by ≥ 2 markers? | x | | | Beth 1
| | | Microdissection? | x | | | Beth R
| | | Gene screening? | x | | | MSI-H | x
| | | Deletion analysis? | X* | | | MSI-L
| | | Conversion analysis? | | | X | IHC | x
| | | * Only in 10 people with IHC abnormality and no MMR mutation detected | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) (Report what study found such as correlation coefficients or other measures of correlation | Study conclusion(What did the authors conclude about the testing strategy or other major findings). | | | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
N=131, ND, ND Attrition due to death (12.6%), refusal (doctor, 10.4%; patient, 12.6%), or because the patient moved and was not located (5.4%) resulted in 131 consenting to participate (59.0% of those eligible). The median time between diagnosis and interview was 9 months. Invasive tumor samples of primary colorectal adenocarcinoma were obtained from hospitals and private pathology laboratories for 118 patients (90%). An assessment of MSI was not successful for 13 (12%) tumor samples because of technical reasons related to tumor DNA quality, which left 105 tumors tested. | 18 patients with deleterious MMR / 105 patients with CRC 9 hMLH1 4 hMSH2 4 hMSH6 1 hPMS2 | 105 patients with CRC, 11% AM II, 17% MSI-H, 15%MSIL, 19% IHC abnormal | ND | “Because we did not conduct germline MMR testing on all patients who had tumors that were MS stable and IHC normal, we could not calculate sensitivity and specificity directly. The formula used to estimate the sensitivity and specificity were in Appendix.” See Table 2 original paper for detailed results. | | | ND | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | 9/12 [NOT FOR THE PREVALENCE QUESTION, THESE ARE ALL AGED <45] | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | x
| | | | | Sensitivity (95%CI) | Specificity (95%CI) | | | | Amsterdam R | X | | If yes, which clinical criteria (check all that apply)?
| | | | Loss of MMR protein | 1.00 | 0.91 | | | | Other (specify) | | | Am 1 +
| | | | Expression | (0.82–1.00) | (0.83–0.96) | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | 7/9 MSI-H; 2/9 MSI-L [ NOT FOR THE PREVALENCE QUESTION, THESE ARE ALL AGED <45] | Am R +
| | | | High or low MSI | 0.94 | 0.80 | | | | Amsterdam R | x | | Beth 1 +
| | | | | (0.73 –1.00) | (0.71–0.88) | | | | Other (specify) | | | Beth R +
| | | | Any family history | 0.67 | 0.63 | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | 9/9 [NOT FOR THE PREVALENCE QUESTION, THESE ARE ALL AGED <45] | Age <50
| | | | | (0.41–0.87) | (0.52–0.73) | | | | Amsterdam R | x | | Suggestive family history (specify)
| | | | Conclusion: “Tumor IHC analysis of four MMR proteins and MSI testing provide a highly sensitive strategy for identifying MMR gene mutation-carrying, early-onset colorectal cancer patients, half of whom would have been missed using Amsterdam Criteria alone. Tumor-based approaches for triaging early-onset colorectal cancer patients for MMR gene mutation testing, irrespective of family history, appear to be an efficient screening strategy for HNPCC.” | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with CRC (assuming all MSI-S and IHC(-) are MMR(-)) | Am 1 + | | + | (A) 9 | (B) 3
WILL NOT USE THIS IN THE SUMMARY TABLES (AM2 WHO ARE <45y) | Am R + (<45y) | x | - | (C) 9 | (D) 84
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis)

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with CRC who got tested for MMR (All Am2, signal in MSI or IHC and 23 randomly selected out of the sporadics) All <45y | Am 1 + | | + | (A) 13 | (B) 5
| Am R + | | - | (C) 5 | (D) 36
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with CRC (All Am2, signal in MSI or IHC and 23 randomly selected out of the sporadics) all <45y | Am 1 + | | + | (A) 4 | (B) 12
*Note the 18 patients with MSI-H were not included in this analysis | Am R + | | - | (C) 1 | (D) 24
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L* | x
| Age <50
| IHC (no staining)
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients with CRC | Am 1 + | | + | (A) 18 | (B) 8
*“of the 79 patients with tumors that expressed all proteins, no mutations were detected in the 33 who were tested” | Am R + | | - | (C) 0 | (D) 33/79*
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | X
| Other (specify)**

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | X
2 | Inclusion criteria clear? | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | X
7 | Were withdrawals from the study explained? | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing….i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Stormorken 2002Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Index patients from the first 56 families registered at the Norwegian Radium hospital | The patients with the mutations have been described in the Wijnen logistic regression model. | Mlh1 (1) | | Y | N | ? | Am 1 | X | ND
| | Msh2 (4) | ≥5 MSI markers used? | | NA | | Am R | X
| | Msh6 (2) | MSI-H defined by ≥ 2 markers? | | NA | | Beth 1
| | | Microdissection? | | NA | | Beth R
| | | Gene screening? | | | X | MSI-H
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings) | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
56 index cases not only with CRC, but we focus on 20 AM2 and 12 AM1 who had CRC | 3/12 AM1 | 12/56 AM1 | NA | Should use IHC as a screening | | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | 3/12 AM1 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased?
| 7/20 AM2 | 20/56 AM2 | | | | Unclear description of molecular methods and characterization of pathogenic mutations | | Amsterdam R | | 7/20 AM2 | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | 3/12 AM1 | Am R +
| | | | | | | | Amsterdam R | | 4/20 AM2 | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (specify)

[NOT APLPICABLE FOR THE REST OF THE EXTRACTION FORM BECAUSE WE ARE NOT SURE THAT ALL PARTICIPANTS HAD CRC]

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
| Am 1 + | | + | (A) | (B)
| Am R + | | - | (C) | (D)
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | X
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | X
7 | Were withdrawals from the study explained? | | | X
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing….i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Syngal, 2000 [see also Wahlberg 2002]Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Families were identified by self or health care provider referral and were enrolled on the basis of multiple cases of CRC, early age of CRC diagnosis, or the familial association of CRC with other HNPCC associated tumors | Each pedigree were classified into Amsterdam, Amsterdam Mod, Amsterdam II; each proband had genetic analysis, results entered into a 2X2 analysis with respect to clinical classification | MSH2 or MLH1 | | Y | N | ? | Am 1 | x | Based on predicted major change in the protein or on others' results from the literature.
| | | ≥5 MSI markers used? | | | | Am R | x
| | | MSI-H defined by ≥ 2 markers? | | | | Beth 1 | x
| | | Microdissection? | | | | Beth R
| | | Gene screening? | | X | | MSI-H
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Am Mod | x
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
70 families were enrolled, representing 297 CRCs and 364 other cancer diagnoses | 18 MMR/70 families | 28/70 (40%) Am I | | The most sensitive clinical criteria for identifying pathogenic MSH2 and MLH1 were Bethesda Guidelines. | | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 11/28 Am1 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | X
| | 39/70 (56%) Am M | | | | | | Amsterdam R | | 14/34 AmII | If yes, which clinical criteria (check all that apply)?
| | 34/70 (49%) Am II | | | | | | Other (specify) | | 13/39 Modified Am (this is like Am1, but small families so that 2 1^st^ degree related CRC, 2 generations, <55y OR 2 1^st^ degree CRC and 3^rd^ with early onset of HNPCC related) | Am 1 +
| | 56/70 (80%) Beth | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | 17/56 Beth | Am R +
| | | | | | | | Amsterdam II | X | 14/56 Beth 1to3 | Beth 1 +
| | | | | | | | Other (specify) | | See Wahlberg | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | | Age <50
| | | | | | | | Amsterdam R | | See Wahlberg | Suggestive family history (specify)
| | | | | | | | Am Mod | X | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Families were identified by self or health care provider referral and were enrolled on the basis of multiple cases of CRC, early age of CRC diagnosis, or the familial association of CRC with other HNPCC associated tumors | Am 1 + | X | + | 11 | 17
| Am R + | | - | 7 | 35
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | x
| Other (specify)**
| MSI only

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Families were identified by self or health care provider referral and were enrolled on the basis of multiple cases of CRC, early age of CRC diagnosis, or the familial association of CRC with other HNPCC associated tumors | Am 1 + | | + | 14 | 20
| Am II | X | - | 4 | 32
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | x
| Other (specify)**
| MSI only

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Families were identified by self or health care provider referral and were enrolled on the basis of multiple cases of CRC, early age of CRC diagnosis, or the familial association of CRC with other HNPCC associated tumors | Am Mod | X | + | 13 | 26
| Am R + | | - | 5 | 26
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Families were identified by self or health care provider referral and were enrolled on the basis of multiple cases of CRC, early age of CRC diagnosis, or the familial association of CRC with other HNPCC associated tumors | Am 1 + | | + | 17 | 39
| Am R + | | - | 1 | 13
| Beth 1 + | x
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | x
2 | Inclusion criteria clear? | x
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | x
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | x
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | x
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | | x
7 | Were withdrawals from the study explained? | | | x
8 | Did the authors report AND analyze results for deleterious MMR mutants | | x
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | | x
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | x
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | x
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing….i.e. avoid verification bias)? | x
14 | Were quality control methods described for the molecular and genetic tests? | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | x
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Terdiman, 2001

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Eligible families had to have 2 or more first-degree relatives with CRC at any age, an individual with CRC diagnosed before 50 years of age, or a single individual with synchronous or metachronous CRCs. Probands were selected based on convenience and age at cancer diagnosis. When multiple family members were available for molecular testing, the individual with cancer diagnosed at the youngest age was selected as proband. | Paraffin-embedded tumor samples were obtained from all probands for MSI analysis and MSH2/MLH1 immunostaining → Subjects found to have tumors demonstrating MSI-H (n=47) were invited for germline genetic testing of MSH2 and MLH1 → Gene testing was carried out in 32 of the 47 eligible families. Eight probands refused testing for fear of insurance discrimination. In 7 instances, the proband was deceased (n=4) or could not be recontacted (n=3) | MSH2 and MLH1 | | Y | N | ? | Am 1 | X | Predicted alteration, previous studies, (literature)
Country: US | | | ≥5 MSI markers used? | X | | | Am R
Center: Single | | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1 | X
| | | Microdissection? | | | X | Beth R
| | | Gene screening? | X | | | MSI-H | X
| | | Deletion analysis? | | X | | MSI-L | X
| | | Conversion analysis? | | X | | IHC | X
| | | MSI-H was if 3 or more of the 7 marker loci exhibited band size shifts or if 2 or more loci exhibited hand size shifts when 1 of the involved loci was either BAT26or BAT40 | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
N=114 Mean age=ND %Male=ND Dropouts=5 (4%), no tumor tissue or medical records | 16 patients with deleterious MMR / 32 patients with CRC 7 MLH1 9 MSH2 | 109 patients with CRC, 43% MSI-H, 3% MSI-L, 23% positive AM, 70% positive Beth | 0/40 MSI-L or MSS tumors had positive IHC | “In clinical practice today, detection of germline MSH2 or MLH1 mutations is best approached by a 2-step method in which the tumor of high-risk patients are tested either for MSIH or for the absence of MSH2 or MLH1 protein staining.” | ND | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | ND | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
| 5 patients with MMR of variants of uncertain significance / 32 patients with CRC 4 MLH1 1 MSH2 | | 45/56 MSI-H tumors had positive IHC; 6/38 MSI-H tumor had ambiguous IHC | | | Since study started from MSI testing and gene sequencing only performed in patients with MSIH, the MMR prevalence questions could not be answered. | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | 21/44 (48%) MSI-H patients met Amsterdam criteria | | | | | Other (specify) | | | Am 1 +
| | | 42/44 (95%) MSI-H patients met Bethesda criteria | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | 21/24 (AM2) | Am R +
| | | 3/61 (48%) MSI-L or MSS patients met Amsterdam criteria | | | | | Amsterdam R | X | | Beth 1 +
| | | 30/61 (49%) MSI-L or MSS patients met Bethesda criteria | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify)
| | | | | | | | Other (specify) | | | Other (CRC and MSI-H) | X

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ (deleterious and variants of uncertain significance) | Number with MMR-
Patients with CRC who had MSI-H | Am 1 + | | + | (A) 16 | (B) 29
*6 ambiguous IHC were excluded from this analysis | Am R + | | - | (C) 1 | (D) 4
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining) | X
| Other (specify)**

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ (deleterious and variants of uncertain significance) | Number with MMR-
Patients with CRC who had MSI-H | Am 1 + | | + | (A) 15 | (B) 4
| Am R + | X | - | (C) 6 | (D) 7
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | x
2 | Inclusion criteria clear? | x
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | x
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | x
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding)
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | | x
7 | Were withdrawals from the study explained? | x
8 | Did the authors report AND analyze results for deleterious MMR mutants | | | x
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | x
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | x
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | x
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing….i.e. avoid verification bias)? | x
14 | Were quality control methods described for the molecular and genetic tests? | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | x
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | X for IHC

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Van Dalen 2003, RefID 851 Country: US Center: Multicenter
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
To document the patterns of colorectal surgery performed for cancer-bearing patients who are part of an Amsterdam criteriapositive family, and to compare rates of metachronous cancers that followed each type of index operation. | Amsterdam criteria defined by Vasen et al in 1991 | | | Family kindreds fulfilling the Amsterdam criteria for HNPCC were identified from the David G. Jagelman Inherited Colorectal Cancer registries. All patient for whom surgical and pathology records were available were eligible to be included in the study. The type of surgery and the outcome of subsequent follow-up were abstracted. | Patients were divided into 2 groups: those treated at the Cleveland Clinic Foundation (CCF) and those treated elsewhere. 33 patients had their initial operation at CCR, and 60 had the surgery elsewhere. Primary surgery performed including colectomy and proctosigmoidectomy. 16 (48%) of the 33 patients who had surgery at CCF had a total colectomy vs. 7 (12%) of the 60 patients who had surgery elsewhere (p<0.001) | Incidence of 2^nd^ surgeries for metachronous cancer: only 1 patient who had surgery at CCF had a second operation, this after an initial right colectomy. Thus, 1 (6%) of 17 patients had a segmental resection. 15 (28%) of 53 patients who had surgery elsewhere needed a second resection (p=0.094). | | “There is potentially a high risk of metachronous colorectal cancer if an index cancer in an HNPCC patient defined according to Amsterdam criteria is treated by partial colectomy. However, this risk can be lowered, either by performing a total colectomy at the time of index surgery or possibly by effective postoperative surveillance.” | B
39 HNPCC families with 93 affected patients. The number of patients per family ranged from 1 to 13. There were 127 CRC. Median age at diagnosis of index cancer was 47 (range, 25–81) years. A total of 16 patients (17%) had metachronous cancers, whereas it was 14 (4%) had synchronous cancer. | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | The median follow-up for patients who underwent surgery at CCR was 13 (range 4–49) years, whereas it was 14 (range 1–42) years for those who had surgery elsewhere.
| Yes | No | Uncl
| x

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 x | 5 | | | 8c | 1,6a,6b,7,10 x
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Vasen, 1995, UI7577010 The Netherlands National registry
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
5 year followup (1–20 yr) of surveillance program from registry of families with CRC including colonoscopy or sigmoidoscopy with barium enema every 2–3 years. | Amsterdam criteria | | | See study description | Surveillance/screening | CRCs in index group were at an advanced histopathological stage compared to screened group; 33 (8.5%) subjects with ≥1 adenomas and 11 (2.8%) CRCs; 5 of 11 CRC patients had negative screening exam 11mo - 3.6 yr previously; in addition to 33 patients with adenoma there were adenomas in 26 patients with CRC. | 80% compliance | The screened group had high detection rate CRC, better 5 year survival rate, earlier histopathological stage than the control group. | B
50 families with 238 CRC (control pts), 388 (79%) first-degree relative screened of 493 could be traced from 597 high-risk relatives | Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | Mortality lower in screened versus control group, 9% vs 45%; 5 year survival higher in screened versus control group, 87% vs 63% | | Periodic examination of HNPCC families allow cancer detection at earlier stage than patients not under surveillance.
| Yes | No | Uncl | | | 1 patient with severe complication due to screening exam (cardiac arrest with good response to resuscitation); 1 patient had inappropriate exam (sigmoidoscopy rather than colonoscopy) | | Recommend screening interval of 1–2 years because of aggressive nature of polyps associated with HNPCC
| X

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
| | | | | | | X
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
| X
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
| | X
Allocation Bias | NA | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated | Yes | No
If the method of random allocation is stated, is it appropriate | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
| | | | | | | | X
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
| | | X
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | NA | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
| | | | | | X
Were data collection tools shown or are they known to be valid? | Yes | No
| X
Were data collection tools shown or are they known to be reliable? | Yes | No
| X
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
| | | | | | X
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
| X
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
| | | | | | | | X
Is there a sample size calculation or power calculation | Yes | Partially | No
| | | X
Is there a statistically significant difference between groups? | Yes | No | ND
| | | X
Are the statistical methods appropriate? | Yes | No | ND
| | | X
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
| | | | X
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
| | | | X
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
| | | X
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
| | | | | | X
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
| | | | | X
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
| X
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell
| | | X

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Vasen, HF 2001, Ref ID 1364 Multicenter, Netherlands/Norway
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Survival analysis performed in 138 families with HNPCC. | Amsterdam I or II or high suspicion +/- mutation testing. | | | Family with HNPCC included in Netherlands HNPCC registry or mutation carriers from a Norwegian registry. | Cumulative cancer rates evaluated in three groups: | Pathogenic mutations in 71 Dutch and 8 Norwegian families (34 MLH1 and 40 MSH2 and 5 MSH6). | ND | Pending large prospective studies, the extension of the current surveillance program in MSH2 mutation carriers with the inclusion of the urinary tract should be considered. | C
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | 1) “Putative” carriers (those relatives affected with CRC or endometrial cancer if a mutation had not been excluded | Mean age at diagnosis of CRC higher in carriers of MSH6 compared with MLH1 or MSH2 (50 versus 43 and 44, respectively), statistical significance not reported. | | | No description as to whether the difference may have been observed by clustering of urinary tract cancer in only a subset of families.
| Yes | No | Uncl | | 2) Obligate carriers because of their position in the pedigree in relation to relatives with a mutation | Lifetime risk of developing cancer at any age was significantly higher in MSH2 than MLH1 (p<0.01). Risk of CRC higher in MSH2 than MLH1 (p=0.13). | | | No description of whether all families received the same degree of surveillance; could incident cancers have been missed in the clinical and pathological databases due to slow growth etc.?
| | | X | | 3) Those carrying a mutation | Overall, risk of CRC in male mutation carriers was higher than risk of CRC in female mutation carriers but difference was statistically significant only for MSH2 mutation carriers (p<0.01).
| | | | | | The risk of developing endometrial cancer was higher in MSH2 mutation carriers than MLH1 (p=.057)
| | | | | | MSH2 carriers had significantly higher risk of developing cancer of the urinary tract by age 70 (12%, p<0.05).

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | X | 1,6a,6b,7,10
| | | | | 8c
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | X | 1,6b,9,10,11
| | | | | 8b,8c
Public health or policy | 2,3 | 5 | 9 | 8a | X | 1,6,a,6b,7,10
| | | | | 8b,8c

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Are individuals selected to participate likely to be representative of target population? | Very likely | X | Not likely
| | Somewhat likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | X
| | | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | X
| | | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | X | No
| Yes
Blinding | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | X | NA
| | | ND
Data Collection methods | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Were data collection tools shown or are they known to be valid? | Yes | X
| | No
Were data collection tools shown or are they known to be reliable? | Yes | X
| | No
Withdrawals and Dropouts | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Analysis | | | | | | A | X | C
| | | | | | (strong) | B | (weak)
| | | | | | | (moderate)
Is there a sample size calculation or power calculation? | Yes | Partially | X
| | | No
Is there a statistically significant difference between groups? | X | No | ND
| Yes
Are the statistical methods appropriate? | X | No | ND
| Yes
Indicate the unit of allocation | Community | Organization/group | Provider | X | Institution
| | | | Client
Indicate the unit of analysis | Community | Organization/group | Provider | X | Institution
| | | | Client
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | X
| | | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | X | No | Can't tell
| Yes
Intervention Integrity | | | | | | A | B | X
| | | | | | (strong) | (moderate) | C
| | | | | | | | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | X | NA
| | | | ND
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | X | No | ND | NA
| Yes
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | X
| | | Can't tell

Data Extraction Form For Benefits/Harms

Au, Year, UI, Country Single or Multicenter?
Wagner, 2005, #16341806 The Netherlands Single center
Study description (N enrolled) | How was HNPCC defined? | | | Inclusion/exclusion criteria | Intervention(s) | Outcomes | Dropouts, explanations, other comments | Study Conclusions | Quality score* (comments)
Long-term surveillance & counseling to relatives of HNPCC cases. Mutation carriers referred to local specialist for follow-up and surveillance consisting of colonoscopy every 1–2 years from age 20–25 years and on. Female carriers offered gynecological screening by US and CA125-measurements of blood from age 30–35 years and on. Additional screening for stomach, duodenum or urinary tract as advised. | MMR genetic testing | | | First- and second-degree relatives of patients with HNPCC-related tumor | Surveillance by screening (colonoscopy, gynecologcial screening, or screening of stomach, duodenum or urinary tract), psychological support & counseling program | Long-term satisfaction with screening, counseling procedure Compliance Worry and consequences on daily activities, work, insurance | 21/115 (18%) mutation carriers died or moved away | Colonoscopy satisfaction of health gene carriers: | B
| Did all patients have a personal history of an HNPCC-related cancer? Check one | | | | | | 70 (74%) responded to questionnaires | 88% (37) healthy mutation carrier had colonoscopy screening 1–2 years
| Yes | No | Uncl | | | | 28 (40%) were already diagnosed with HNPCC-related tumor at time of testing | colonoscopy unpleasant 57%
| | X | | | | | 5 has had no screening -burdensome of procedure (1), lack of time (1), plan to go (3) | fearful 32%
| | | | | | | | painful 51%
| | | | | | | | shameful 16%
| | | | | | | | Faith of colonoscopy effectiveness 90%
| | | | | | | | Worry about complications of colonoscopy 14%
| | | | | | | | Preferred another screening method 71%
| | | | | | | | Long-term satisfaction with counseling:
| | | | | | | | 84% approved of how they were informed of HNPCC genetic testing
| | | | | | | | 97% approved information given during counseling
| | | | | | | | 4/10 had life, disability or mortgage insurance problems, none had health insurance or getting job

Place an X in boxes that the study is relevant

Perspective | Benefits/Harms screening (e.g. family history, Amsterdam, Bethesda other) | Benefits/Harms genetic testing | Benefits/Harms counseling/informing | Efficacy of counseling (e.g., ability to accurately convey risks and options, minimize anxiety, inform decisions to take tests) | Accuracy/penetrance testing for HNPCC for HNPCC-related cancers/factors such as race, age sex, comorbidities that may be related to accuracy/penetrance | Benefits/Harms management options individuals with a mutation/Outcomes (e.g. early detection, mortality/morbidity, decision-making by patients, family members and providers, or public health/policy?)
Proband with CRC | 2,3 | 5 | | | 8c | 1,6a,6b,7,10
Family member/other high risk individual | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6b,9,10,11
| x | x | x | x | | x
Public health or policy | 2,3 | 5 | 9 | 8a | 8b,8c | 1,6,a,6b,7,10

* Score Overall Quality of Study as Follows

(A) Most overall quality rating scores are an “A” and the results of the study are considered to provide strong evidence

(B) Most overall quality rating scores are a “B” and the results of the study are considered to provide moderate evidence

(C) Most overall quality rating scores are a “C” and the results of the study are considered to provide weak evidence

Domain/question | Place an “X” in one | | | | | Overall rating
Selection Bias | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Are individuals selected to participate likely to be representative of target population? | Very likely | Somewhat likely | Not likely
What % of selected individuals agreed to participate? | 80–100 | 60–79 | <60 | ND | NA
Allocation Bias | | | | | | A | B | C
(RCTs only, for quasi-experimental, case-control/before/after, no control group or other skip to “Confounders”) | | | | | | (strong) | (moderate) | (weak)
Is the method of random allocation stated? | Yes | No
If the method of random allocation is stated, is it appropriate? | Yes | No
Was the method of random allocation reported as concealed? | Yes | No
Confounders | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Prior to the intervention, were there between group differences for important confounders reported in the paper? | Yes | No | Can't tell
If there were differences between groups for important confounders, were they adequately managed in the analysis? | Yes | No | NA
Were there important confounders NOT reported in the paper (describe above under quality score)? | Yes | No
Blinding | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Was (were) the outcome assessor(s) blinded to the intervention or exposure status of the participants? | Yes | No | ND | NA
Data Collection methods | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Were data collection tools shown or are they known to be valid? | Yes | No
Were data collection tools shown or are they known to be reliable? | Yes | No
Withdrawals and Dropouts | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Indicate the % of participants completing the study. (If the % differs by groups, record the lowest). | 80–100 | 60–79 | <60 | ND | NA
Analysis | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
Is there a sample size calculation or power calculation? | Yes | Partially | No
Is there a statistically significant difference between groups? | Yes | No | ND
Are the statistical methods appropriate? | Yes | No | ND
Indicate the unit of allocation | Community | Organization/group | Provider | Client | Institution
Indicate the unit of analysis | Community | Organization/group | Provider | Client | Institution
If the unit of allocation and analysis differed, was the cluster analysis done? | Yes | No | NA
Is the analysis performed by intervention allocation status (i.e. intention to treat) rather than the actual intervention received? | Yes | No | Can't tell
Intervention Integrity | | | | | | A | B | C
| | | | | | (strong) | (moderate) | (weak)
What % of participants received the allocated intervention or exposure of interest? | 80–100 | 60–79 | <60 | ND | NA
Was the consistency of the intervention measured (i.e. intervention was provided to all participants in the same way)? | Yes | No | ND | NA
Is it likely that subjects received an unintended intervention (contamination or cointervention) that may influence the results? | Yes | No | Can't tell

Study: Wahlberg 2002 also see Syngal 2000 for additional details

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
Families were identified by self or health care provider referral and were enrolled on the basis of multiple cases of CRC, early age of CRC diagnosis, or the familial association of CRC with other HNPCC associated tumors | 48 families with tumors available for MSI analysis, 24 of them also had tumor material of sufficient quality for IHC analysis, gene sequencing done previously in Syngal 2000; they were also resequenced using new sequencers | MSH2 or MLH1 | | Y | N | ? | Am 1 | X | By predicting major Alteration in the protein structure and based on the literature
| | | ≥5 MSI markers used? | X (NCI) | | | Am Mod | X
| | | MSI-H defined by ≥ 2 markers? | X | | | Beth 1 | X
| | | Microdissection? | X | | | Beth R
| | | Gene screening? | | X | | MSI-H
| | | Deletion analysis? | | | X | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
48 families with available tumor tissue for MSI analysis were included (original study by Syngal 2000 enrolled 70 families) | See Syngal 2000 | | | A combination of the Bethesda criteria for HNPCC and an MSI-H phenotype defined the smallest number of cases having all of the germ-line MSH2 and MLH1 mutations that could be detected by DNA sequencing. | | B like Syngal, same study | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | See Syngal 2000 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | | X
| | | | | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | MSI H and MSI-L | Am R +
| | | | | | | | Amsterdam R | | 15/19 Am1 and 3/19 | Beth 1 +
| | | | | | | | Other (specify) | | 18/28 Modif Amsterdam like Syngal and 4/28 | Beth R +
| | | | | | | | | | 24/36 Beth1 and 4/36 | Age <50
| | | | | | | | | | 20/28 Beth 1 to 3 and 4/28 | Suggestive family history (specify)
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | 5/19 Am1 | Other (specify)
| | | | | | | | Amsterdam R | | 7/28 Md Am1 like Syngal
| | | | | | | | Other (specify) | | 8/28 Beth 1 to 3
| | | | | | | | | | 9/36 Beth

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
48 families with CRCs with available tumor tissue for MSI analysis | Am 1 + | X | + | 15 | 4
| Am R + | | - | 13 | 16
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
48 families with CRCs with available tumor tissue for MSI analysis | Am 1 + | | + | 24 | 12
| Am R + | | - | 4 | 8
| Beth 1 + | X
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias)
2 | Inclusion criteria clear?
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing?
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding).
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding)
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)?
7 | Were withdrawals from the study explained?
8 | Did the authors report AND analyze results for deleterious MMR mutants
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)?
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)?
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated?
12 | Was there a clear description of which mismatch repair mutations were being tested for?
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)?
14 | Were quality control methods described for the molecular and genetic tests?
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)?
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors).

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Wang 1999 & 1997

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
75 unrelated families from France, selected from genetic consultations, multicenter 22 Amsterdam 33 not Amsterdam 12 sporadic CRC 8 CRC+extra-colonic tumor | Combined DNA and RNA-based screening for hMLH1, hMSH2, hPMS1, hPMS2, and hMSH6 | hMLH1, hMSH2 | | Y | N | ? | Am 1 | X | They defined them by predicting protein structure loss and based on the literature
| | | ≥5 MSI markers used? | | X | | Am R | | Missense of unknown pathogenicity were excluded from the analysis
| | | MSI-H defined by ≥ 2 markers? | | X | | Beth 1
| | | Microdissection? | | | | Beth R
| | | Gene screening? | X | | | MSI-H
| | | Deletion analysis? | X | | | MSI-L
| | | Conversion analysis? | | | | IHC
| | | | | | | Age <50 | X
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsattelite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion(What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
See above | 26 deleterious mutations were found; 19 MLH1and 7 MSH2 in 55 unrelated families | | | Data confirmed that hPMS1, hPMS2, and HMSH6 germline mutations are rare in familial aggregation of CRCs. | | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 14/22 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
| | | | | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 + | x
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify) | X
| | | | | | | | Other (specify) | | | Other (specify) | X

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number withMMR+ | Number withMMR-
Unrelated kindreds with HNPCC, some fulfilled Amsterdam, some did not | Am 1 + | X | + | 14 | 8
| Am R + | | - | 8 | 25
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | x
2 | Inclusion criteria clear? | | x
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | x
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | x
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | x
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | | x
7 | Were withdrawals from the study explained? | | | x
8 | Did the authors report AND analyze results for deleterious MMR mutants | x
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | | x
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | x
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | x
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | x
14 | Were quality control methods described for the molecular and genetic tests? | | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | | x
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Wolf, 2005

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
81 unrelated patients from Austria who met at least the Beth R guidelines | Pts who met Beth R, Beth 1, Am Mod, or Am II were preselected; DNA sequencing was done in all, and MSI was done in available tumor samples | MLH1 and MSH2 | | Y | N | ? | Am 1 | | Predicted alteration; literature; contrast with healthy controls
Unclear if all are CRCs, | | | ≥5 MSI markers used? | X | | | Am R | X
| | | MSI-H defined by ≥ 2 markers? | | | x | Beth 1 | X
| | | Microdissection? | | | X | Beth R | X
| | | Gene screening? | | x | | MSI-H
| | | Deletion analysis? | | | x | MSI-L
| | | Conversion analysis? | | | x | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other | X
| | | | | | | Am Mod (2004)

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsatellite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
81 pts; 48% M | 19 pts with MMR/81 pts with CRC 12 MLH1 7 MSH2 | Not applicable | Detection of mutation was correlated with Am R and Am Mod (2004) (P=0.011 and P=0.038) | MSI enhanced specificity in screening; recommend the use of Am Mod (2004) to select for patients for primary sequence analysis if MSI is not possible. | | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | 13/35 | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
| | | | | | | | Amsterdam R | X | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | 16/24 | Am R + | X
| | | | | | | | Amsterdam R | X | | Beth 1 + | X
| | | | | | | | Other (specify) | | | Beth R + | X
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | | Suggestive family history (specify)
| | | | | | | | Amsterdam R | | | Other (specify) Am Mod (2004) | X
| | | | | | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients who fulfilled Beth R | Am 1 + | | + | 13 | 22
| Am R + | X | - | 6 | 40
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients who fulfilled Beth R | Am 1 + | | + | 19 | 53
| Am R + | | - | 0 | 9
| Beth 1 + | X
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients who fulfilled Beth R | Am 1 + | | + | 16 | 36
| Am R + | | - | 3 | 26
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| ** Am Mod (2004) | X
| MSI only

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with MMR+ | Number with MMR-
Patients who fulfilled Beth R | Am 1 + | | + | 13 | 9
| Am R + | | - | 0 | 33
| Beth 1 +
| Beth R +
| MSI-H* | X
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | x
2 | Inclusion criteria clear? | x
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | | x
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | | | x
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | x
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | x
7 | Were withdrawals from the study explained? | x
8 | Did the authors report AND analyze results for deleterious MMR mutants | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | x
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | x
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | x
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | x
14 | Were quality control methods described for the molecular and genetic tests? | | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | | x
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Yuan 1998 [included data from Han 1996]

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | x
Was a minimum of hMLH1 and hMSH2 sequencing performed? | x

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
31 families (from Korean Hereditary CRC registry) with suspected HNPCC and 45 patients with sporadic early-onset CRC | One CRC patient from each family had DNA testing except for one family (hyperplastic polyp); sequencing done in patients with altered mobility on SSCP bands only | hMLH1 and hMSH2 | | Y | N | ? | Am 1 | | Predicted change in the transcripts; literature (at least in 1 case)
| | | ≥5 MSI markers used? | | x | | Am R
| | | MSI-H defined by ≥ 2 markers? | | x | | Beth 1
| | | Microdissection? | | | | Beth R
| | | Gene screening? | x | | | MSI-H
| | | Deletion analysis? | | | | MSI-L
| | | Conversion analysis? | | | | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history | X
| | | | | | | Suspect HNPCC
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsattelite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
31 suspected HNPCC; 45 sporadic CRC Dx <40y (table1 range) | 7/31 in suspected HNPCC (5 hMLH1, 2 hMSH2); 1/45 in sporadic CRC (hMSH2) | | | The Korean definition of suspected HNPCC is useful in the diagnosis of HNPCC and for identifying those families suspected of having HNPCC. | | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | | ND | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
suspected HNPCC 50y 65%male | | | | | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
Sporadic CRC diagnosed <40y 39y 49% male | | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | ND | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | ND | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify) Korean criteria HNPCC
| | | | | | | | Other (specify) | | | Other (specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check ONE | Index test | Number with Abnormal PCR-SSCP who had hMLH1 or hMSH2pathogenic mutations | Number with Normal PCR-SSCP(no further DNAsequencing)
| Am 1 + | | + | 7 | 24
| Am R + | | - | 1 | 44
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Korean criteria | X
| MSI only

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Unclr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | X
2 | Inclusion criteria clear? | | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | X
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding). | NA
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | X
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | X
7 | Were withdrawals from the study explained? | NA
8 | Did the authors report AND analyze results for deleterious MMR mutants
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | | X
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | X
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | X
12 | Was there a clear description of which mismatch repair mutations were being tested for? | X
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | X
14 | Were quality control methods described for the molecular and genetic tests? | | X
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | X
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | | | X

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.

Study: Yuan 2004

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | x
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | x
Was a minimum of hMLH1 and hMSH2 sequencing performed? | x

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
14 families that fulfilled the Chinese HNPCC criteria; 3 of them fulfilled Amsterdam | DHPLC was performed, DNA sequencing was performed if DHPLC were abnormal | HMLH1 and hMSH2 | | Y | N | ? | Am 1
| | | ≥5 MSI markers used? | | x | | Am R
| | | MSI-H defined by ≥ 2 markers? | | x | | Beth 1
| | | Microdissection? | | x | | Beth R
| | | Gene screening? | x | | | MSI-H
| | | Deletion analysis? | x | | | MSI-L
| | | Conversion analysis? | | | x | IHC
| | | | | | | Age <50
| | | | | | | Suggestive family history
| | | | | | | Chinese criteria
| | | | | | | Other | x
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsattelite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
14 probands | 12 abnormal DHPLC; all 12 had point mutations in either hMLH1 or hMSH2 3 pathogenic mutations identified (2 mhl1 and 1 msh2) | 3 were Am1 | | Detection of large genomic deletions should be involved in the routine screening of HNPCC families. | | C | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | x | 1/3 were Am1 all other were Chinese criteria | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased?
| | | | | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | NA | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | NA | Age <50
| | | | | | | | Amsterdam R | | | Suggestive family history (specify) Chinese HNPCC
| | | | | | | | Other (specify) | | | Other (specify) Chinese HNPCC criteria

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above) “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check | Index test | Number with Abnormal DHPLC that had pathogenic mutation by sequence analysis | Number with Abnormal DHPLC that had no pathogenic mutation by sequence analysis
| | ONE
Patients who fulfilled Chinese HNPCC criteria | Am 1 + | X | | 2 | 1
| Am R + | | | 2 | 9
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other
| (specify)**
| MSI only

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis).

Study: Zhu, 2005

Inclusion/exclusion criteria for clinical validity (all must be checked “yes” for study to be included)

| Yes | No
Did study enroll patients with CRC? | X
Was genetic testing compared with an index test (must have [underlined: at least] one of the following: suggestive family history, MSI, or IHC)? | X
Was a minimum of hMLH1 and hMSH2 sequencing performed? | X

Characteristics of Design

Population inclusion/exclusion criteria; country, single or multicenter, | Design and analytic strategy (brief description of strategy used for testing patients with CRC) | Which MMR mutations were sought? | Characteristics of laboratory testing (see definitions below) | | | | Predictors analyzed (check all that apply) | | How were deleterious, missense/variants mutations defined (ND if not described)
1. 45 unrelated patients with familial CRC,21 fulfilled Amsterdam | Screen for large deletions and duplications in MSH2 and MLH1 by multiplex ligation-dependent probe amplification (MLPA_ | MSH2 and MLH1 | | Y | N | ? | Am 1 | X | Unclear
2. 20 patients with CRC <50 yr | | | ≥5 MSI markers used? | NA | | | Am R
3. 13 patients with CRC > 50 yr | | | MSI-H defined by ≥ 2 markers? | NA | | | Beth 1
China | | | Microdissection? | NA | | | Beth R
| | | Gene screening? | | X | | MSI-H
| | | Deletion analysis? | X | | | MSI-L
| | | Conversion analysis? | | | X | IHC
| | | | | | | Age <50 | X
| | | | | | | Suggestive family history
| | | | | | | Specify
| | | | | | | Other
| | | | | | | Specify

Am 1= original Amsterdam criteria; Am 2 = revised Amsterdam criteria; Beth 1= original Bethesda Guidelines; Beth 2 = Revised Bethesda Guidelines

MSI-H = Microsattelite instability high; MSI-L = Microsatellite instability low; IHC= immunohistochemistry (staining for mismatch repair proteins); ?=unclear

Results

N enrolled, Mean age, %male dropouts, reasons for dropouts | Proportion with a mismatch repair mutation (describe which MMR gene). (e.g. 23 patients with MMR/1000 patients with CRC 18 MLH1 5 MSH2) | Proportion of overall population positive for each predictor (e.g. of 1000 patients with CRC, 5% positive AM, 10% positive Beth, 12% suggestive family history) | Correlation of predictors to one another (e.g. IHC versus MSI) Report what study found such as correlation coefficients or other measures of correlation | Study conclusion (What did the authors conclude about the testing strategy or other major findings). | Implications to family /other findings or comments from authors relevant to any key question | Quality grade (see checklist below) and add specific comments about study quality/concerns here | | How was Lynch Syndrome defined (check all that apply)? | | Specify numerator and denominator and any comments (ND if not described) | | Yes | No
See above | Genomic aberration was detected in 4/21 patients with Amsterdam | Genomic aberration was detected in 4/21 patients with Amsterdam; 3/24 patients without Amsterdam; 2/20 patients with CRC < 50 yr | | Genomic aberrations, large-fragment deletions and duplications, in MSH2 and MLH1 play a role in the pathogenesis of Chinese CRC patients with a family history. | | B | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had an MMR gene mutation? | Amsterdam 1 | X | 4/21 has genomic aberration | Did the study perform testing only on patients who fulfilled clinical criteria (i.e. when clinical suspicion for HNPCC was increased? | X
| | | | | | | | Amsterdam R | | | If yes, which clinical criteria (check all that apply)?
| | | | | | | | Other (specify) | | | Am 1 + | X
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had MSI (high or low, please specify) | Amsterdam 1 | | | Am R +
| | | | | | | | Amsterdam R | | | Beth 1 +
| | | | | | | | Other (specify) | | | Beth R +
| | | | | | | Among patients with the Lynch syndrome defined clinically (i.e. fulfillment of the Amsterdam criteria) what proportion had abnormal IHC | Amsterdam 1 | | | Age <50 | X
| | | | | | | | Amsterdam R | | | Suggestive family history (specify) | X
| | | | | | | | | | | Other (Specify)

COPY A NEW 2 X 2 TABLE FOR EACH INDEX TEST

What was the population (i.e. from table above)? “ND” if not a restricted population (e.g. Patients with CRC who had a suggestive family history) | Index tests | Check | Index test | Number with | Number with
| | ONE | | MMR+ | MMR?
45 unrelated patients with familial CRC, 21 fulfilled Amsterdam | Am 1 + | X | + | 4 | 17
| Am R + | | - | 3 | 21
| Beth 1 +
| Beth R +
| MSI-H*
| MSI-L*
| Age <50
| IHC (no staining)
| Other (specify)**
| MSI only

* Note comparator to MSI-H or MSI-L is MSI-stable

** Add combinations of tests under “other” category (eg. MSI-H plus positive IHC for MLH1; MSI-H plus negative results on methylation analysis)

Grade | Explanation for Quality Scoring
A | Most or all of the criteria are fulfilled and the conclusions of the study would be very unlikely to be affected by those that are not.
B | Some of the criteria are fulfilled and the conclusions of the study would be unlikely to be affected by those that are not
C | Few or no criteria were fulfilled and the conclusions of the study would be thought likely or very likely to be altered by multiple omissions in the required criteria for an acceptable study

Item | Criteria | Yes | No | Un clr
| General Quality Criteria
1 | Were unselected patients with CRC included? (i.e. were representative of patients seen in clinical practice {not selected based upon a suggestive family history or other criteria that may cause selection bias) | | x
2 | Inclusion criteria clear? | | X
3 | Did the whole sample or a random selection of the sample (i.e. total population of patients with CRC) receive verification using gene sequencing? | x
4 | Were the results of IHC or MSI or other predictors interpreted without knowledge of the results of sequencing? (i.e. was there blinding) | | | x
5 | Were the results of sequencing interpreted without knowledge of the results of the index test results (i.e. was there blinding) | | | x
6 | Did authors describe how uninterpretable or intermediate results were analyzed (e.g. badly stained tissues etc)? | | x
7 | Were withdrawals from the study explained? | | x
8 | Did the authors report AND analyze results for deleterious MMR mutants | | | X
| Analytic Validity
9 | Was the description of how MSI or IHC or other predictors described in sufficient detail that others could replicate it (e.g. either a full description or relevant references)? | x
10 | Did authors describe what specimens were tested (e.g., blood, tumor tissue etc.)? | x
11 | Was MSI, IHC, sequencing or other testing performed at a similar time interval between specimen collection and processing for all subjects evaluated? | | | x
12 | Was there a clear description of which mismatch repair mutations were being tested for? | x
13 | Was there a clear description of percentage of eligible subjects for whom valid genotypic data were obtained across study groups (e.g., the proportion of patients who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI who underwent sequencing....i.e. avoid verification bias)? | x
14 | Were quality control methods described for the molecular and genetic tests? | | | x
15 | Did the authors attempt to address the reproducibility of results (reliability of tests)? | | | x
16 | Did the authors specify that samples from each group of subjects (e.g., those who fulfilled and did not fulfill clinical criteria or those who did or did not have MSI) included in each batch analyzed? (i.e. this helps minimize the effect of random errors). | x

Genetic and molecular testing methods

| Examples of tests
Genetic screening methods | Single-stranded conformation polymorphism (SSCP)
| Conformation sensitive gel electrophoresis (CSGE)
| Denaturing gradient gel electrophoresis (DGGE)
| Denaturing high-pressure liquid chromatography (DHPLC)
Deletion analysis | Southern blotting
| Multiplex Ligation-dependent Probe Amplification (MLPA)
Conversion analysis | Process of converting diploid cells to haploid cells. This is potentially important in HNPCC since the presence of a normal allele can sometimes make it difficult to identify a mutation in the mutant allele
MSI methods | Should have testing for five or more MSI markers. The five markers are “BAT25, BAT26, D2S123, D5S346 AND D17S250”
IHC | All methods ok
Microdissection | Whether or not the tumor tissue used for MSI is microdissected to reduce the amount of DNA contributed by non-tumor cells definitely affects the sensitivity of detecting MSI because the non-tumor cells are microsatellite stable and reduce the unstable peak signals as a percentage of the total signal, not allowing detection of MSI at many loci.