# Appendix A. Search Strategy

“colorectal neoplasms, hereditary nonpolyposis”[MeSH Terms]

hereditary non-polyposis[tw]

(HNPCC[tw]

(MLH1[tw] OR MSH2[tw]OR MSH6[tw]

(hMSH2[tw] OR hMLH1[tw] OR hPMS1[tw]

hPMS2[tw] OR hMSH6[tw] OR hMLH3[tw]

English[Lang] AND “humans”[MeSH Terms]