# Appendixes

Appendix A. Search Strategy

Appendix B. Sample Data Abstraction Forms

Appendix C. Evidence Tables

Appendix D. List of Excluded Studies

Appendix E. Peer Reviewers

Appendix F. Summary Tables on Clinical Validity

Appendix G. One-Way Sensitivity Analyses for the Decision Trees