# Evidence Tables

Evidence Table 1. Key question 1: Natural history of acute otitis media (in alphabetical order by first author)

Author Year | Study Design and Quality | Intervention | Time/Place Inclusion/Exclusion Criteria | Influencing Factors and Sample Size | Outcomes | Findings
Appelman 1991 Claessen 1994 | Randomized double-blind placebo-controlled trial Jadad's quality score ^1^ (0-5): 5 [1,1,1,1,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [0,0,1] | Oral amoxicillin/clavulanate, tid 7 d vs. placebo | Time: 9/86-4/90 Place: Netherlands, primary care setting Inclusion:; 1. Age: 6 mo-<12 yr; 2. Recurrent AOM; 3. Documented AOM within 4 wk-12 mo; Exclusion:; 1. Antibiotic use past 4 wk; 2. Penicillin allergy; 3. Serious concurrent disease requiring antibiotic | Age: 22% <2 yr 78% >2 yr Otitis prone: (prior episodes) 12% >3 28% 2 60% 1 0% 0 N=121 N1=67 drug N2=54 placebo | Treatment failure or irregular course as defined by presence of otalgia or a body temperature of >38°C or both after 3 d | Placebo Group:
  Pain or fever after 3 days:
  Overall: | 10/54 (18%)
  <2 yr | 7/12 (58%)
  >2 yr | 3/42 (7%)
Bollag 1991 | Observational cohort study, one main group and one followup group Number of study design components satisfied ^3^ (0-8): 1 [0,0,1,0,0,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [0,0,1] | Antibiotics vs. observation Antibiotics if had history of purulent meningitis or concurrent focal bacterial infection, irregular course, or parental demand. | Time: 2/86-2/88 and 3/88-2/89 Place: Switzerland, office-based setting Inclusion:; 1. Age: <16 yr (lower limit not specified); 2. AOM; Exclusion: None listed | Age: Mean=4.3 yr Otitis prone: Not addressed N=230 N1=168 main group N2=62 followup group 13 in Group 1 had antibiotics 6 in Group 2 had antibiotics | Hearing deficit at 2 wk, 2 mo, and mastoiditis or meningitis at 2 mo | Main Followup: *only 4 in Group 1 and 1 in Group 2 were followed more than 2 wk.
  Hearing deficit
  2 wk | 4/168 (2%)
  | 1/62 (2%)
  2 mo | 0/168 (0%)
  | 0/62 (0%)
  Mastoiditis/meningitis*
  2 mo | 0/168 (0%)
  | 0/62 (0%)
Burke 1991 | Randomized double-blind placebo controlled trial Jadad's quality score ^1^ (0-5): 4 [1,1,0,1,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [0,0,1] | Amoxycillin 125 mg tid 7 d vs. matching controls Both groups dispensed with 100 ml paracetamol 120 mg/5ml | Time: 10/86-4/87, 10/87-4/88, 10/88-4/89 Place: 48 general practitioners from 17 practices in Southampton, Bristol, and Portsmouth Inclusion:; 1. Age: 3-<10 yr; 2. Acute earache; 3. At least one abnormal eardrum; Exclusion:; 1. Antibiotic tx prior 2 wk; 2. Serious chronic disorder; 3. AOM prior 2 wks; 4. Strong indication of antibiotics (bulging eardrum, perforation, pus, grommets); 5. Penicillin allergy | Age: All >2 yr Otitis prone: (prior episodes) 47% >2 53% 0-2 N1=114 drug N2=118 placebo | Pain at <48 hr 14-21 d Otorrhea at same time points GI symptoms at same time points Clinical signs at 1 wk Limited TM mobility at 1-3 mo Complications 14 d-1 yr Adverse effects at time points as for pain Others | Placebo Group:
  Presence of pain
  Day 0 | 102/118 | (86%)
  Day 2 | 56/117 | (48%)
  Days 5-7 | 29/114 | (25%)
  Presence of fever
  Day 2 | 19/93 | (20%)
  Days 5-7 | 8/70 | (11%)
  Treatment failure at 1 wk
  Total | 32/236 | (14%)
  3-9 yr | 17/118 | (14%)
  3-5 yr | 10/66 | (15%)
  6-9 yr | 7/52 | (13%)
  0-2 prior AOM
  | 6/55 | (11%)
  >2 prior AOM
  | 7/48 | (15%)
  Worse otoscopy day 8
  | 26/110 | (24%)
  Otorrhea day 8
  | 22/118 | (19%)
  Effusion
  1 mo | 41/116 | (35%)
  3 mo | 31/111 | (28%)
  Referred to ENT
  3 mo-1 yr | 9/111 | (8%)
  Mean duration (n=113)
  Pain | 3.34
  Crying | 1.44
  Mean recurrence rate
  per 100 person/yr (n=111): 0.63
Froom 1990 | Prospective observational study based on questionnaires filled out by general practitioners Number of study design components satisfied ^3^ (0-8): 4 [1,0,1,0,0,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Antibiotics vs. no antibiotics | Time: Not specified Place: International network of primary care general practice physicians from nine countries (Australia, Belgium, Canada, Great Britain, Israel, Netherlands, New Zealand, Switzerland, and U.S.) Inclusion:; 1. Age: Not specified; 2. New episode of AOM; 3. Physician enrolled 10 or more patients; Exclusion:; 1. Canadian followup data not available; 2. Referral to another physician at initial visit | Age: 9% 0-12 mo 16% 13-30 mo 74% >30 mo Otitis prone: Not addressed N=419 with no antibiotics N=2,563 with antibiotics | Presence of pain at 2 mo Presence of otorrhea at 2 mo Presence of hearing deficit at 2 mo Assessment of recovery (yes, no, uncertain) including pain, ear draining, hearing problem, others | No antibiotic group (n=419):
  Failed recovery at 2 mo
  Total | 40/4 19 | (9.5%)
  0-12 mo | 5/39 | (12.8%)
  13-30 mo | 7/69 | (10.1%)
  31+ mo | 28/311 | (9.0%)
Halsted 1967, 1968 | Randomized double-blind placebo-controlled trial Jadad's quality score ^1^ (0-5): 5 [1,1,1,1,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Group 1: Ampicillin 100 mg/kg/d, qid 10 days Group 2: Penicillin G 50,000 units/kg/and sulfisoxazole 150 gm/kg/day qid 10 Group 3: Placebo (Study 1: Groups 1 vs. 3; Study 2: Groups 2 vs. 3) | Time: 7/65-3/66 Place: Outpatient department of Cleveland Metropolitan General Hospital Inclusion:; 1. Age: 2-66 mo; 2. AOM; Exclusion:; 1. Antibiotics during prior; 2. wks in study 1, 10 in Study 2.; 3. Any complications requiring antibiotics; 4. Allergic to antibiotics; 5. Ruptured TM (Study 2) | Age: 75% <2 yr 25% >2 yr Otitis prone: Not addressed N1=30 ampicillin N2=32 penicillin N3=27 placebo | Fever at 24 hr and 24-72 hr Recurrence of AOM 14 d-3 mo and up to 1 yr Improvement/failure at 14-72 hr and 14-18 based on symptomatology and appearance of TM | Placebo Group:
  Failure rate
  24-72 hr | 7/27 | (26%)
  Positive culture
  | 6/19 | (32%)
  Negative culture
  | 1/8 | (12%)
  14-18 d | 0/21 | (0%)
  Recurrence rate at 1 yr (estimated)
  | 11/27 | (41%)
Howie 1972 | Randomized placebo-controlled trial Jadad's quality score ^1^ (0-5): 1 [1,0,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Group 1: Placebo Group 2: Triple sulfonamide Group 3: Erythromycin estolate Group 4: Ampicillin Group 5: Erythromycin estolate-triple sulfonamide | Time: 12/68-7/70 Place: Private practice of authors in Alabama Inclusion:; 1. Age: <2.5 yr (lower limit not specified); 2. AOM; Exclusion:; 1. Authors felt parents would not accept diagnostic aspiration; 2. Patient condition required antibiotic | Age: All <2.5 yr Otitis prone: Not addressed N1=116 placebo N2=23 triple sulfonamide N3=25 erythromycin estolate N4=36 ampicillin N5=80 erythromycin estolate-triple sulfonamide | Otorrhea at 2-7 d Presence of exudate while on medication at 2-7 d Bacteriologic findings of exudate when present at 2-7 d | Placebo Group:
  Outcome at 2-7 d
  Febrile | 0/116 | (0%)
  Exudate | 92/116 | (79%) present
Kaleida 1991 | Randomized double-blind controlled trial Jadad's quality score ^1^ (0-5): 2 [1,1,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | For nonsevere AOM: amoxicillin alone vs. placebo For severe AOM: amoxicillin vs. myringotomy vs. amoxicillin combined with myringotomy | Time: 5/81-8/85 Place: Pittsburgh, private and academic setting Inclusion:; 1. Age: 7 mo-12 yr; 2. Non-severe AOM at onset (otalgia score=12 & fever); 3. >15 days after TX of previous AOM; Exclusion:; 1. Recent antibiotic; 2. TM perforation; 3. Asthma; 4. Sinusitis; 5. Other complications or confounding factors | Age: 50% <2 yr 50% > 2 yr Otitis prone: 21% > 3 prior episodes 41% 1-2 prior episodes 38% no prior episode Nonsevere N1=263 amoxicillin N2=273 placebo Severe N3=252 amoxicillin N4=198 amoxicillin and myringotomy N5=86 placebo and myringotomy (>2 yr only) | Short-term:; 1. InitialTXfailure at 24-48 hr; 2. Effusion at 2 wk; 3. Effusion at 6 wk; 4. Recurrence at 2-6 wk; Long-term:; 1. Average % with effusion; 2. % developed ultimate TX failure; 3. Average rate of recurrence of AOM; Ultimate TX failure defined as any of the following conditions:; 1. 180 d of effusions in same ear cumulatively; 2. 4+ episodes of severe OM; 3. Protocol-defined indication for a 4th tympanocentesis or myringotomy within 6 mo, or 5th in 1 yr; 4. Suppurative complication, cholesteatoma, or an allergic reaction to penicillin | For nonsevere AOM Placebo Group:
  Initial TX failure
  <2 yr | 25/254 | (9.8%)
  > 2 yr | 13/238 | (5.5%)
  Effusion at 2 wk
  <2 yr | 143/209 | (68%)
  >2 yr | 112/199 | (56%)
  Effusion at 6wk
  <2 yr | 99/175 | (57%)
  >2 yr | 70/153 | (46%)
  Recurrence at 2-6wk
  <2 yr | 73/232 | (31%)
  >l×d′2 yr | 50/214 | (23%)
  Average% with effusion
  <2 yr | 50% (n=102)
  >2 yr | 39% (n=109)
  % ultimately failed
  <2 yr | 30/82 | (37%)
  >2 yr | 16/88 | (18%)
  Average recurrent rate/yr
  <2 yr | 3.1 (n=102)
  >2 yr | 1.5 (n=109)
Laxdal 1970 | Randomized controlled trial Jadad's quality score ^1^ (0-5): 2 [1,0,0,1,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Ampicillin vs. penicillin vs. symptomatic TX | Time: 1/66-9/68 Place: Saskatchewan, Canada; private practice setting Inclusion:; 1. Age: 15 yr (lower limit not specified); 2. AOM; Exclusion:; 1. Predominantly respiratory symptoms; 2. Allergy a significant factor; 3. Rupture of eardrum | Age: 49% <3 yr 51% >3 yr Otitis prone: Not addressed N=142 total N1=48 placebo N2=45 penicillin N3=49 ampicillin | TX failure and middle-ear inflammation disappearance by 7 d Failure defined as either deterioration or no improvement observed by 7 d | Symptomatic Group:
  Failure rate
  <15 yr | 18/48 | (38%)
  Failure rate by age (no denominator given)
  0-3 yr | 46%
  3-6 yr | 38%
  6-9 yr | 25%
  9-14 yr | 0%
Mygind 1981 | Randomized double-blinded, placebo-controlled trial Jadad's quality score ^1^ (0-5): 3 [1,1,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [0,1,1] | Peroral penicillin V vs. (55 mg/kg/d in 7 d) vs. placebo | Time: 11/77-4/78 Place: Copenhagen, Denmark; house visits by general practitioners Inclusion:; 1. Age: 1-10 yr; 2. AOM; 3. Earache for 1-24 hr; Exclusion:; 1. On other TX; 2. Secretion in external ear; 3. Antibiotic within 1 mo; 4. Suspected chronic OM; 5. Treated for secretory OM within yr; 6. Concurrent disease; 7. Suspected penicillin allergy | Age: Mean=3.9 yr Otitis prone: Not addressed N=149 total N1=72 penicillin N2=77 placebo | Tympanometry at 1 wk, 1 mo, and 3 mo Nasopharynx culture at 7 d, 1 mo Symptom scores for earache, fever, and common cold Otoscopy for redness and retraction at 1 mo, 3 mo | Placebo group: * from nasopharyngeal cultures
  Contralateral OM at 1 wk
  | 6/42 | (14%)
  Parancentesis at 2-3 d
  | 8/65 | (12%)
  Perforated TM (?time)
  | 12/42 | (29%)
  Average days otorrhea
  | 2.7 (n=56)
  Otorrhea>5 d at 1 mo(?)
  | 1/56 | (1.8%)
  Abnormal TM (no Ns)
  1 wk | 77%
  1 mo | 58%
  3 mo | 51%
  Flat curve
  1 wk | 50%
  1 mo | 32%
  3 mo | 24%
  Presence of H Influenzae*
  PreTx | 30% | 23/77
  2-3 d | 32% | 1/65
  1 wk | 33% | 4/42
  1 mo | 34% | 19/56
  Presence of H streptococci*
  PreTx | 14% | 11/77
  2-3 d | 14% | 9/65
  1 wk | 12% | 5/42
  1 mo | 7% | 4/56
  Presence of Pneumococci*
  PreTx | 19% | 15/77
  2-3 d | 22% | 14/65
  1 wk | 19% | 8/42
  1 mo | 4% | 2/56
Ostfeld 1988 | Prospective comparative cohorts Number of study design components satisfied ^3^ (0-8): 2 1,0,1,0,0,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1[1,0,0] | Group 1: Without primary systemic adminstration Group 2: antibiotics | Time: 3/81 - 2/83 Place: Not specified Inclusion:; 1. Infants and children-age limits not specified; 2. AOM; Exclusion:; 1. Otorrhea; 2. External otitis; 3. PE tubes; 4. Lack of effusion on tympanocentesis; 5. Chronic OM | Age: 90% >2 yr 10% >2 yr Otitis prone: Not addressed N=693 total N1=397 N2=296 | Prevalence of acute recurrent episodes, otorrhea, chronic MEE, tympanostomy tube insertion, acute mastoiditis, and otogenic meningitis at 2 yr | No antibiotic group: (No denominators given)
  Recurrent AOM | 33%
  Otorrhea | 14%
  Chronic MEE | 42%
  Tube | 5%
  Mastoiditis | 2%
  Meningitis | 0%
Thalin 1986 | Randomized double-blind trial Jadad's quality score ^1^ (0-5): 4 [1,1,0,1,1] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Penicillin V vs. placebo | Time: 7/84- 6/85 Place: Halstad,Sweden; ENT department or referred by general practitioners Inclusion:; 1. Age: 2-15 yr; 2. Purulent AOM; Exclusion:; 1. Allergic to antibiotics; 2. AOM last 30 d; 3. Chronic diseases; 4. Ventilation tubes; 5. Antibiotics within 30 d; 6. Sensorineural hearing loss; 7. Concomitant infection needing antibiotic treatment | Age: 100% >2 yr Otitis prone: 27% suffered from AOM more than 10 times; 23% no prior AOM episode N=293 subjects, 317 episodes N1=159 penicillin V N2=158 placebo | Parental report card first 10 d: Otomicroscopy on d 3-4, d 8-10, and d 30 and/or tympanogram 2 mo after d 30 if had serous OM at d 30 Failure defined as remaining nonnegligible symptoms (pain, fever, etc.) or insufficient resolution of infectious signs during the medical Tx period of 7 d Relapse defined as recurrence of AOM after the end of medical Tx and before d 30 | Placebo Group: Denominator for failure or relapse is implied in text At d 2 and 3, more children in placebo group with earache and/or discharge than in penicillin group, but at end of therapy no difference.
  Failure d 7
  | 12/158 | (8%)
  Relapse d 30
  | 7/158 | (4%)
  Rash | 1/158 | (1%)
  Serious Complications
  | 0/158 | (0%)
Tilyard 1997 | Retrospective cohort Number of study design components satisfied ^3^ (0-8): 3 [1,0,1,0,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Antibiotic vs. no antibiotic therapy | Time: 7/93-6/94 Place: New Zealand, 20 general practices Inclusion:; 1. Age: <=15 yr (lower limit not specified); 2. Consulting cases for OM; Exclusion: None | Age: 35% <2 yr 65% >2 yr Otitis prone: Not addressed. Episodes of AOM: | Success/failure rate of antibiotic and nonantibiotic therapy for OM at 1 mo | Failure rate (episodes) without antibiotic treatment at 1 mo:
  N=2,367 | total
  <2 | 827
  ? | 799
  ? | 466
  >15 | 275
  <2 yr | 4/29 | (17%)
  2-5 yr | 4/22 | (18%)
  6-15 yr | 0/12 | (0%)
  >15 yr | 0/11 | (0%)
  Total | 8/74 | (11%)
Townsend 1964 | Prospective comparative cohorts study Number of study design components* satisfied ^3^ (0-8): 2[0,0,0,0,0,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 1[0,0,1] | Group 1: Symptomatic Group 2: Symptomatic plus antimicrobial agents Group 3: Symptomatic plus myringotomy Group 4: Symptomatic plus antimicrobial plus myringotomy | Time: 11/60-5/62 Place: Rochester, NY Inclusion:; 1. Age: children, age not specified; 2. OM; 3. Myringitis without OM; Exclusion: None noted | Age: Not specified Otitis prone: Not addressed N=292 total N1=189 N2=86 N3=2 N4=15 | Complications at unspecified time points. "All patients were urged to appear for a followup visit." Complication defined as purulent progression of disease after treatment begun; serous OM | Unspecified endpoint (1 yr?) *Denominators are highly questionable due to attrition.
  Complication rate*:
  Group 1 | 11/189 | (6%)
  Group 2 | 15/86 | (17%)
  Group 3 | 0/2 | (0%)
  Group 4 | 7/15 | (47%)
van Buchem 1981 | Randomized double-blind trial Jadad's quality score ^1^ (0-5): 4 [1,1,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Placebo vs. myringotomy vs. amoxicillin vs. amoxicillin plus myringotomy | Time: 1/79-5/79 and 10/80-3/81; Monday-Thursday, 8a.m.-5p.m. Place: Tilburg, Netherlands; 12 general practitioners Inclusion:; 1. Age: 2-12 yr; 2. AOM; Exclusion:; 1. Antibiotic within 14 d; 2. Chronic OM; 3. Allergic to antibiotic; 4. Disagreement about diagnosis among researchers | Age: All >2 yr Otitis prone: Not addressed N=171 children; (239 ears) N1=40 no TX N2=36 myringotomy N3=47 amoxicillin N4=48 myringotomy + amoxicillin | Physician recording of TM as being normal or diffusely red, bulging, or perforated at 24 hr, 7 d,14 d, and 6 mo. Mother reporting severity of pain at 24 hr, 7 d, 14 d and 6 m Recurrence in 2 wk | Placebo group:
  Presence of pain (pts)
  Pre Tx | 98% | (39/40)
  >24 hr | 28% | (11/40)
  >7 d | 10% | (4/38)
  Abnormal otoscopy (ear)
  Pre Tx | 00% | (58/58)
  >7 d | 49% | (26/54)
  >14 d | 28% | (16/58)
  Discharge (ears)
  >24 hrs | 15% | (9/58)
  >7 d | 5% | (3/58)
  Relapse (ears)
  At 6 mo | 13% | (10/75)
van Buchem 1985 | Prospective cohort study Number of study design components satisfied ^3^ (0-8): 4 [1,0,1,1,1,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Three month cohort suffering from AOM with nose drops and analgesics alone | Time: 2/82-4/82 Place: Tilburg, Netherlands, 45 general practitioners in the area Inclusion:; 1. Age: 2-12 yr; 2. AOM; Exclusion:; 1. Concurrent infection requiring antibiotics | Age: 100% 2-12 yr Otitis prone: Not addressed N=490 | Cured rate percent with severe course, percent with discharge after 14 d, and percent with mastoiditis | No antibiotic group: *2 mastoiditis were observed in a 17-month study. Using extrapolation, a 0.04% rate was estimated (2/4,860)
  Given antibiotics
  | 5.1% | (25/490)
  Severe course
  | 2.7% | (12/490)
  Discharge after 14 days
  | 1.5% | (7/490)
  Mastoiditis*
  | 0.0% | (0/490)

1 Jadad score components: randomization mentioned; double-blind mentioned; dropouts described; randomization appropriate; double-blinding appropriate.

2 AOM definition components: middle ear effusion; rapid onset; acute inflammation.

3 Eight components to evaluate quality of cohort studies: clear definition of cohort; early inception point; clear pathway of patient entry; complete followup achieved; description of dropouts; use objective outcome criteria; "blind" outcome assessment; adjust for extraneous factors.

AOM=acute otitis media; ENT=ear, nose, and throat; GI=gastrointestinal; MEE=middle ear effusion; OM=otitis media; PE=pressure equalization; QID=four times a day; TID=three times a day; TM=tympanic membrane; Tx=treatment

Evidence Table 2. Key Question 3: To treat or not to treat with antibiotics (in alphabetical order by first author)

Author Year | Study Design and Quality | Intervention | Time/Place Inclusion/Exclusion Criteria | Influencing Factors and Sample Size | Outcomes | Findings
Appelman 1991 Claessen 1994 | Randomized double-blind placebo-controlled trial Jadad's quality score ^1^ (0-5): 5 [1,1,1,1,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [0,0,1] | Oral amoxicillin/clavulanate, tid 7 d vs. placebo | Time: 9/86-4/90 Place: Netherlands, primary care setting Inclusion:; 1. Age: 6 mo-<12 yr; 2. Recurrent AOM; 3. Documented AOM within 4 wk-12 mo; Exclusion:; 1. Antibiotic use past 4 wk; 2. Penicillin allergy; 3. Serious concurrent disease requiring antibiotic | Age: 22% <2 yr 78% >=2 yr Otitis prone: 12% >=3 prior episodes 28% 2 prior episodes 60% 1 prior episode 0% no prior episode N=121 N1=67 amoxicillin/clavulanate N2=54 placebo | Treatment failure or irregular course as defined by presence of otalgia or a body temperature of >=38°C or both after 3 d | Pain or fever after 3 d:
  | Antibiotic | Placebo
  Total | 11/67 16% | 10/54 18%
  <2 yr | 4/15 27% | 7/12 58%
  >=2 yr | 7/52 13% | 3/42 7%
  Multivariate logistic regression showed only age (<2 yr vs. >=2 yr) was a relevant prognostic factor for the course of the disease.
Burke 1991 | Randomized double-blind placebo-controlled trial Jadad's quality score ^1^ (0-5): 4 [1,1,0,1,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [0,0,1] | Amoxicillin 125 mg tid 7d vs. matching controls Both groups treated with 100 ml paracetamol 120 mg/5 ml | Time: Oct to Apr of 1986-7, 1987-8, 1988-9 Place: 48 general practitioners from 17 practices in Southampton, Bristol, and Portsmouth Inclusion:; 1. Age: 3-<10 yr; 2. Acute earache; 3. At least one abnormal eardrum; Exclusion:; 1. Antibiotic used prior 2 wks; 2. Serious chronic disorder; 3. OM prior 2 wks; 4. Strong indication of antibiotics (bulging eardrum, perforation or pus, grommets); 5. Penicillin allergy | Age: All > 2 yr Otitis prone: 47% >2 prior episodes 53% 0-2 prior episodes N=232 total N1=114 drug N2=118 placebo | Pain at <48 hr, 3-7 d, 7-14 d, 14-21 d Otorrhea at same time points GI symptoms at same time points Clinical signs at 1 wk Limited TM mobility at 1-3 mo Complications 14 d-1 yr Adverse effects at time points as in for pain Others
  | Amoxicillin | Placebo
  Presence of pain
  Day 0 | 8/102 96% | 02/118 86%
  Day 2 | 53/112 47% | 6/117 48%
  Days 5-7 | 20/111 18% | 29/114 25%
  Presence of fever
  Day 2 | 7/87 8% | 19/93 20%
  Days 5-7 | 3/51 6% | 8/70 11%
  Treatment failure
  1 wk | 2/114 2% | 17/118 14%
  Effusion
  1 mo | 41/112 37% | 41/116 35%
  3 mo | 20/111 18% | 31/111 28%
  Referred to ENT
  3 mo-1 yr | 7/112 6% | 9/111 8%
  Mean duration
  Pain (d) | 2.82 | 3.34
  Crying (d) | 0.50 | 1.44
  Mean recurrence rate
  | 0.69 | 0.63
Halsted1967. 1968 | Randomized double-blind placebo-controlled trial Jadad's quality score ^1^ (0-5): 5 [1,1,1,1,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Group1: Ampicillin 100 mg/kg/d qid 10 d Group2: Penicillin G 50,000 units/kg/d and sulfisoxazole 150 gm/kg/d qid 10 d Group3: Placebo Study 1: Group 1 vs. Group3 Study 2: Group2 vs. Group3 | Time: 7/65-3/66 Place: Outpatient department of Cleveland Metropolitan General Hospital Inclusion:; 1. Age: 2-66 mo; 2. AOM; Exclusion:; 1. Antibiotics during prior 2 wk in Study 1, 10 d in Study 2; 2. Any complications requiring antibiotics; 3. Allergic to antibiotics; 4. Ruptured TM (Study 2) | Age: 75% <2 yr 25% >=2 yr Otitis prone: Not addressed N1=30 ampicillin N2=32 penicillin N3=27 placebo | Fever at 24 hr and 24-72 hr Recurrence of AOM 14 d-3mo and up to 1 yr Improvement/failure at 14-72 hr and 14-18 d based on symptomatology and appearance of the TM
  No improvement rate
  Ampicillin | Pen.S | Placebo
  24-72 hr: all cases
  10/30 | 7/32 | 7/27
  (33%) | (22%) | (26%)
  24-72 hr: Pos. cult. Cases
  3/16 | 4/19 | 6/19
  (19%) | (21%) | (32%)
  24-72 hr: Neg. cult. Cases
  7/14 | 3/13 | 1/8
  (50%) | (23%) | (12%)
  Not resolved d 14-18 All cases
  2/25 | 2/25 | 0/21
  (8%) | (8%) | (0%)
  Recurrence rate at 1 yr (estimated)
  14/32 | 15/30 | 11/27
  (44%) | (50%) | (41%)
Howie 1972 | Randomized placebo-controlled trial Jadad's quality score ^1^ (0-5): 1 [1,0,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Group 1: Placebo Group 2: Triple sulfonamide Group 3: Erythromycin estolate Group 4: Ampicillin Group 5: Erythromycin estolate-triple sulfonamide | Time: 12/68-7/70 Place: Private practice of authors in Alabama Inclusion:; 1. Age: <=2.5 yr (lower limit not specified); 2. AOM; Exclusion:; 1. Authors felt parents would not accept diagnostic aspiration; 2. Patient condition required antibiotic | Age: All <=2.5 yr Otitis prone: Not addressed N=116 placebo N=23 triple sulfonamide N=25 erythromycin estolate N=36 ampicillin N=80 erythromycin estolate-triple sulfonamide | Otorrhea at 2-7 d Presence of exudate while on medication at 2-7 d Bacteriologic findings of exudate when present at 2-7 d | Exudate present at 2-7 d Group 1-Placebo 92/116 (79%) Group 2-Triple sulfonamide 16/23 (70%) Group 3-Erythromycin estolate 19/25 (76%) Group 4-Ampicillin 19/36 (53%) Group 5-Combo 39/80 (49%) Nonsterile/exudate at 2-7d Group 1-Placebo 83/116 (72%) Group 2-Triple sulfonamide 10/23 (43%) Group 3-Erythromycin estolate 11/25 (44%) Group 4-Ampicillin 6/36 (17%) Group 5-Combo 15/80 (19%)
Kaleida 1991 | Randomized double-blind controlled trial Jadad's quality score ^1^ (0-5): 2 [1,1,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | For nonsevere AOM: Amoxicillin alone vs. placebo For severe AOM: Amoxicillin vs. myringotomy vs. amoxicillin combined with myringotomy | Time: 5/81-8/85 Place: Pittsburgh, private and academic setting Inclusion:; 1. Age: 7 mo-12 yr; 2. Non-severe AOM at onset (otalgia score=12 & fever) 3.>15 d after treatment of previous AOM; Exclusion:; 1. Recent antibiotic; 2. TM perforation; 3. Asthma; 4. Sinusitis; 5. Other complications or confounding factors | Age: 50% <2 yr 50% >=2 yr Otitis prone: 21% >=3 prior episodes 41% 1-2 prior episodes 38% no prior episode Nonsevere N1=263 amoxicillin N2=273 placebo Severe N3=252 amoxicillin N4=198 amoxicillin and myringotomy N5=86 placebo and myringotomy (>2 yr only) | Short-term; 1. Initial treatment failure at 24-48 hr; 2. Effusion at 2 wk; 3. Effusion at 6 wk; 4. Recurrence at 2-6 wk; Long-term; 1. Average % with effusion; 2. % developed ultimate treatment failure; 3. average rate of AOM recurrence; Ultimate treatment failure defined as any of the following:; 1. 180 d of effusions in same ear cumulatively; 2. 4+ episodes of severe OM; 3. Protocol-defined indication for a 4th tympanocentesis or myringotomy within 6 mo, or 5th in 1 yr; 4. Suppurative complication, cholesteatoma, or allergic to antibiotic
  For nonsevere AOM:
  | % (N-epi) | % (N-epi)
  | Amoxicillin | Placebo
  Initial treatment failure
  <2 yr | 6.5(277) | 9.8(254)
  >=2 yr | 0.5(211) | 5.5(238)
  Total | 3.9(488) | 7.7(492)
  Effusion at 2 wk
  <2 yr | 52(226) | 68(209)
  >=2 yr | 41(175) | 56(199)
  Total | 47(401) | 62(408)
  Effusion at 6 wk
  <2 yr | 54(179) | 57(175)
  >=2 yr | 36(150) | 46(153)
  Total | 46(329) | 52(328)
  Recurrence at 2-6 wk
  <2 yr | 32(254) | 32(232)
  >=2 yr | 23(194) | 23(214)
  Total | 28(448) | 28(446)
  Average % with effusion
  <2 yr | 41(105) | 50(102)
  >=2 yr | 30(91) | 39(109)
  Total | 36(196) | 44(211)
  % ultimately failed
  <2 yr | 24(89) | 37(82)
  >=2 yr | 16(80) | 18(88)
  Total | 20(169) | 7(170)
  Average recurrent rate/yr
  <2 yr | 3.0(105) | 3.1(102)
  >=2 yr | 1.5(91) | 1.5(109)
  Total | 2.3(196) | 2.3(211)
Laxdal 1970 | Randomized controlled trial Jadad's quality score ^1^ (0-5): 2 [1,0,0,1,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Ampicillin vs. penicillin vs. symptomatic treatment | Time: 1/66-9/68 Place: Saskatchewan, Canada; private practice setting Inclusion:; 1. Age: <15 yr (lower limit not specified); 2. AOM; Exclusion:; 1. Predominantly respiratory symptoms; 2. Allergy a significant factor; 3. Rupture of eardrum | Age: 49% <3 yr 51% >=3 yr Otitis prone: Not addressed N=142 total N1=48 placebo N2=45 penicillin N3=49 ampicillin | Treatment failure and middle ear inflammation disappearance by the 7th day Failure defined as either deterioration or no improvement observed by 7th d
  Failure rate <15 yr
  Pen. | Amp. | Symp. Tx.
  11/45 | 5/49 | 18/48
  24% | 10% | 38%
  Failure rate by age (no denominator given)
  Age | Pen | Amp | Symp.
  0-3 | 32% | 15% | 46%
  3-6 | 30% | 0% | 38%
  6-9 | 0% | 9% | 25%
  9-14 | 0% | 0% | 0%
  9-14 | 0% | 0% | 0%
Mygind 1981 | Randomized double-blind placebo-controlled trial Jadad's quality score ^1^ (0-5): 3 [1,1,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [0,1,1] | Peroral penicillin V (55mg/kg/d in 7 d) vs. placebo | Time: 11/77-4/78 Place: Copenhagen, Denmark, house visits by general practitioners Inclusion:; 1. Age: 1-10 yr; 2. AOM; 3. Earache for 1-24 hr; Exclusion:; 1. On other treatment; 2. Secretion in external ear; 3. Antibiotic within month; 4. Suspected chronic OM; 5. Treated for secretory OM within year; 6. Concurrent disease; 7. Suspected penicillin allergy | Age: Mean=3.9 yr Otitis prone: Not addressed N=149 total N1=72 penicillin N2=77 placebo | Tympanometry at 1wk, 1 mo, and 3 mo Nasopharynx culture at 7d, 1 mo Symptom scores for earache, fever, and common cold Otoscopy for redness and retraction at 1 m, 3 m
  | Placebo | Penicillin V
  Contralateral OM at 1 wk
  | 6/42(14%) | 2/34(6%)
  Parancentesis at 2-3 d
  | 8/65(12%) | 2/62(3%)
  Perforated TM (?time)
  | 2/42(29%) | 7/34(21%)
  Average days otorrhea
  | 2.7(n=56) | 2.5(n=52)
  Otorrhea>5 days at 1 mo(?)
  | 1/56 | 1/52
  Abnormal TM (no N's)
  1 wk | 77% | 83%
  1 mo | 58% | 52%
  3 mo | 51% | 47%
  Flat curve at 1 mo
  1 wk | 50% | 51%
  1 mo | 32% | 32%
  3 mo | 24% | 25%
  Flat curve at 1 mo
  1 wk | 50% | 51%
  1 mo | 32% | 32%
  3 mo | 24% | 25%
  Symptom unresolved by d 2
  | 38% | 21%
  Unsatisfactory course of acute phase at d 7
  | 31% | 14%
  Relapse by 1 wk
  | 13% | 16%
  Recurrence 1-3 mo
  | 27% | 27%
  Presence of H influenzae
  PreTx | 30% 23/77 | 28% 20/72
  2-3 d | 32% 21/65 | 27% 17/62
  1 wk | 33% 14/42 | 32% 11/34
  1 mo | 34% 19/56 | 33% 17/52
  Presence of H streptococci
  PreTx | 14% 11/77 | 17% 12/72
  2-3 d | 14% 9/65 | 2% 1/62
  1 wk | 12% 5/42 | 3% 1/34
  1 mo | 7% 4/56 | 11% 5/52
  Presence of Pneumococci
  PreTx | 19% 15/77 | 12% 9/72
  2-3 d | 22% 14/65 | 5% BR>3/62
  1 wk | 19% 8/42 | 6% 2/34
  1 mo | 4% 2/56 | 8% 4/52
Thalin 1985 | Randomized double-blind trial Jadad's quality score ^1^ (0-5): 4 [1,1,0,1,1] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Penicillin V vs. placebo | Time: 7/84-6/85 Place: Halstad, Sweden ENT department or referred by general practitioners Inclusion:; 1. Age: 2-15 yr; 2. Purulent AOM; Exclusion:; 1. Allergic to antibiotic; 2. AOM last 30 d; 3. Chronic diseases; 4. Ventilation tubes; 5. Antibiotic within 30 d; 6. Sensorineural hearing loss; 7. Concomitant infection needing antibiotic treatment | Age: 100% >=2 yr Otitis prone: 27% suffered from AOM more than 10 times 23% no prior AOM episode N=293 subjects 317 episodes N1=159 penicillin V N2=158 placebo | Parental report card first 10 d: Otomicroscopy on d 3-4, d 8-10, and d 30 and/or tympanogram 2 mo after d 30 if had serous OM at d 30 Failure defined as remaining non-negligible symptoms (pain, fever, etc.) or insufficient resolution of infectious signs during the medical treatment period of 7 d Relapse defined as recurrence of AOM after the end of medical treatment and before d 30 | Denominator for failure or relapse is implied in text At days 2 and 3, more children in placebo group with earache and/or discharge than in penicillin group, but at end of therapy no difference
  Penicillin V | Placebo
  Failure at d 7
  4/159(3%) | 12/158(8%)
  Relapse at d 30
  9/159(6%) | 7/158(4%)
  Rash
  1/159(1%) | 1/158(1%)
  Serious complications
  0/159(0%) | 0/158(0%)
van Buchem 1981 | Randomized double-blind trial Jadad's quality score ^1^ (0-5): 4 [1,1,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Placebo vs. myringotomy vs. amoxicillin vs. amoxicillin plus myringotomy | Time: 1/79-5/79 and 10/80-3/81; Monday-Thursday, 8a.m.-5p.m. Place: Tilburg, Netherlands; 12 general practitioners Inclusion:; 1. Age: 2-12 yr; 2. AOM; Exclusion:; 1. Antibiotic within 14 d; 2. Chronic OM; 3. Allergic to antibiotic; 4. Disagreement about diagnosis among researchers | Age: All >2 yr Otitis prone: Not addressed N=171 children (239 ears) N1=40 no Tx N2=36 myringotomy N3=47 amoxicillin N4=48 amoxicillin plus myringotomy | Physician recording of TM as being normal or diffusely red, bulging, or perforated at 24 hr, 7th d, 14th d, and 6m Mother reporting severity of pain at 24 hr, 7th d, 14th d and 6 mo Recurrence in 2 wk
  Presence of pain pre Tx
  Placebo | 98% (39/40)
  Myringotomy | 100% (36/36)
  Amoxicillin | 94% (44/47)
  Amoxicillin plus
  myringotomy | 94%(45/48)
  Presence of pain at 24 hr
  Placebo | 28% (11/40)
  Myringotomy | 28% (10/36)
  Amoxicillin | 28% (13/47)
  Amoxicillin plus
  myringotomy | 35% (17/48)
  Presence of pain >7th d
  Placebo | 10% (4/38)
  Myringotomy | 11% (4/35)
  Amoxicillin | 7% (3/46)
  Amoxicillin plus
  myringotomy | 10% (5/48)
  Note: only patients in myringotomy group had fever
  Abnormal otoscopy, pre Tx (ear)
  Placebo | 100% (58/58)
  Myringotomy | 100% (50/50)
  Amoxicillin | 100% (64/64)
  Amoxicillin plus
  myringotomy | 100% (66/66)
  Abnormal otoscopy, >7 d
  Placebo | 49% (26/54)
  Myringotomy | 49% (23/47)
  Amoxicillin | 40% (25/63)
  Amoxicillin plus
  myringotomy | 44% (26/57)
  Abnormal otoscopy, >14 d
  Placebo | 28% (16/58)
  Myringotomy | 25% (12/48)
  Amoxicillin | 10% (6/63)
  Amoxicillin plus
  myringotomy | 11% (6/57)
  Discharge >24 hr (ears)
  Placebo | 15% (9/58)
  Myringotomy | 64% (30/47)
  Amoxicillin | 20% (13/63)
  Amoxicillin plus
  myringotomy | 69% (41/59)
  Discharge > 7 d (ears)
  Placebo | 5% (3/58)
  Myringotomy | 18% (9/48)
  Amoxicillin | 8% (5/63)
  Amoxicillin plus
  myringotomy | 7% (4/57)
  Relapse at 6 mo (ears)
  No amoxicillin | 13% (10/75)
  Amoxicillin | 10% (9/92)

1 Jadad score components: randomization mentioned; double-blind mentioned; dropouts described; randomization appropriate; double-blinding appropriate.

2 AOM defininition components: middle ear effusion; rapid onset; acute inflammation

AOM=acute otitis media; ENT=ear, nose, and throat; EPI=episode; GI=gastrointestinal; OM=otitis media; QID=four times a day; TID=three times a day; TM=tympanic membrane; TX=treatment

Evidence Table 3. Key question 4a: Other antibiotic vs. amoxicillin or trimethoprim/sulfamethoxazole (in alphabetical order by first author)

Author Year | Study Design and Quality | Intervention | Time/Place Inclusion/Exclusion Criteria | Influencing Factors and Sample Size | Outcomes | Findings
Barnett 1997 | Randomized single-blind trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Single intramuscular dose of ceftriaxone vs. 10 d oral TMP-SMX | Time: 2/91-4/94 Place: Boston including suburban private practice, neighborhood health center, urban hospital ER and private care clinic Inclusion:; 1. Age: 3 mo-3 yr; 2. AOM; Exclusion:; 1. Antibiotic within 7 d; 2. Anatomic problem; 3. Immunosuppressed; 4. Chronic illness; 5. Allergy; 6. Ever had PE tube; 7. No phone; 8. Non-English, Portuguese, Spanish, French | Age: 3 mo-3 yr Otitis prone: 41% >3 prior episodes N=484 patients N1=241 ceftriaxone N2=243 TMP-SMX | Noncured or cured/improved rate on day 3, day 14, and day 28 (for total only) Noncured or cured/improved rate on d 14 for subgroups of each influencing factor Adverse events reported on day 3 for total cases
  Noncured rate
  | Ceftriaxone | TMP-SMX
  Day 3 | 18/241(8%) | 12/243(4.9%)
  Day 14 | 39/197(20%) | 38/212(18%)
  Day 28 | 28/136(21%) | 31/155(20%)
  Noncured rate on d 14
  White | 41/155(26%) | 37/153(24%)
  Black | 10/46(22%) | 6/46(13%)
  Hisp | 4/21(19%) | 5/32(16%)
  Other | 2/19(11%) | 2/12(17%)
  Male | 31/132(23%) | 30/121(25%)
  Fem | 26/109(24%) | 20/122(16%)
  Past AOM
  Yes | 44/180(24%) | 42/183(23%)
  No | 13/61(21%) | 8/60(13%)
  Otitis prone
  Yes | 19/96(20%) | 22/99(22%)
  No | 38/145(26%) | 28/144(19%)
  Day care
  Yes | 8/52(15%) | 16/56(29%)
  No | 49/189(26%) | 34/187(18%)
  Breastfed
  Yes | 38/148(26%) | 32/152(21%)
  No | 19/93(20%) | 18/91(20%)
  First episode <6 mo
  Yes | 19/83(23%) | 21/81(26%)
  No | 38/158(24%) | 29/162(18%)
  Fever at onset
  Yes | 35/125(28%) | 30/130(23%)
  No | 22/116(19%) | 20/113(18%)
  Ear discharge at onset
  Yes | 4/13(31%) | 2/14(14%)
  No | 53/228(23$) | 48/229(21%)
  Ear pain at onset
  Yes | 40/178(22%) | 32/173(18%)
  No | 17/63(27%) | 18/70(21%)
  Vomiting at onset
  Yes | 14/45(31%) | 9/34(26%)
  No | 43/196(22%) | 41/209(20%)
  Lethargy at onset
  Yes | 23/78(29%) | 17/77(22%)
  No | 34/163(21%) | 33/166(20%)
  Irritability at onset
  Yes | 49/209(23%) | 40/202(20%)
  No | 8/32(25%) | 10/41(24%)
  Adverse events on day 3
  Pain at site
  | 10/225(8%) | ----
  Diarrhea
  | 46/195(24%) | 19/207(9%)
  Rash | 21/206(10%) | 14/201(7%)
  (Diarrhea was significant at P<0.001)
Bass 1967 | Randomized double-blind controlled trial Jadad quality score (0-5): 3 [1,1,0,1,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Gp1: Oxytetracycline Gp2: Procaine penicillin & benzathine penicillin G injection plus sulfisoxazole Gp3: Penicillin V plus sulfisoxazole Gp4: Ampicillin Treatments are for 7 d | Time: 1/66-5/66 Place: Not specified Inclusion:; 1. 2 mo-12 yr; 2. AOM; Exclusion:; 1. AOM of 1 mo duration; 2. Acute viral exanthematous DZ; 3. Symptoms >1 wk; 4. Allergic to antibiotic; 5. Hx chronic or serous OM | 1. Age: 2 mo-12 yr; 2. Otitis prone: Not addressed; N=400 100 per group | Clinical outcomes evaluate on or before 14 d Therapeutic failure defined as no improvement after 48 hr or exacerbation after initial improvement during 14 d of observation, with repeat therapy Untoward reaction defined as serious reaction due to therapy with administration of med discontinued Relapse defined recurrence of OM requiring repeated antimicrobial therapy within 2 wk beyond initial 14 d
  | Gp1 | Gp2 | Gp3 | Gp4
  N | 100 | 100 | 100 | 100
  Therapeutic failure at <14 d
  | 15% | 15% | 14% | 15%
  Severe untoward reactions
  | 3% | 0% | 4% | 1%
  Relapses
  | 11% | 3% | 6% | 5%
  Therapeutic ineffectiveness
  | 28% | 18% | 24% | 21%
  Reactions All type
  | 21% | 5% | 21% | 29%
  Vomit
  | 2% | 2% | 3% | 3%
  Loose stool
  | 18% | 3% | 15% | 21%
  Skin rash
  | 1% | 0% | 3% | 5%
Bass 1973 | Randomized double-blind trial (same as Bass/1967) Jadad quality score ^1^ (0-5): 3 [1,1,0,1,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Gp1: Penicillin V Gp2: Penicillin V plus sulfa Gp3: Erythromycin estolate Gp4: Ampicillin Treatments are for 10 d | Time: 11/68-8/71 Place: U.S. Army Tripler General Hospital, Hawaii, hospital clinic Inclusion: Same as Bass/1967 Exclusion: Same as Bass/1967 | 1. Age: 2 mo-12 yr; 2. Otitis prone: Not addressed.; N=400 100 per group | Same as Bass/1967 except therapeutic failures immediately evaluated by otolaryngologist when possible and tympano-centesis performed if middle ear fluid present
  | Gp1 | Gp2 | Gp3 | Gp4
  N | 100 | 100 | 100 | 100
  Therapeutic Failure at <14 d
  | 11% | 8% | 7% | 9%
  Severe untoward reactions
  | 0% | 6% | 0% | 2%
  Relapses
  | 7% | 3% | 4% | 8%
  Total failure
  | 18% | 17% | 11% | 19%
  Reactions All type
  | 12% | 29% | 6% | 22%
  Vomit
  | 1% | 7% | 2% | 2%
  Diarrhea
  | 11 % | 17% | 3% | 12%
  Skin rash
  | 0% | 3% | 1% | 8%
Berman 1983 | Randomized double-blind comparative trial Jadad quality score ^1^ (0-5): 3 [1,1,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1[1,0,0] | Oral amoxicillin vs. cefaclor | Time: 6/80-3/82 Place: Denver, pediatric outpatient clinics at university and general hospitals Inclusion:; 1. Age: 1-<3 mo; 2. AOM; Exclusion:; 1. Without hx of prior antibiotic use | Age: All <3 mo Otitis prone: Not addressed N=40 patients N1=21 amoxicillin N2=19 cefaclor | Treatment failure defined as persistent ongoing bacterial infection, bulging TM after at least 5 d of therapy Adverse drug effects at 48-72 hr, 5-7 d, 2-3 wk
  | Cefaclor | Amoxicillin
  Treatment failure after 5 d tx
  | 5/19(26%) | 6/21(29%)
  Diarrhea | 2/19(11%) | 3/21(14%)
Blumer 1984 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 3 [1,1,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Cefaclor vs. TMP-SMX | Time: Not specified Place: Cleveland, ambulatory care unit Inclusion:; 1. Age: 3 mo-7 yr; 2. AOM; Exclusion:; 1. Hospitalization; 2. Concurrent antibiotic needed within 48 hr; 3. Allergic to antibiotic | Age: 3 mo-7 yrs Otitis prone: 38% recurrent episode N=100 children N1=50 cefaclor N2=50 TMP-SMX | Treatment success/failure at 2 days, 4 days, and 9-10 days. Recurrence rate at 10 d
  | Cefaclor | TMP-SMX
  Presence of symptom
  48 hr | 3/50(6%) | 6/50(12%)
  96 hr | 0/50(0%) | 0/50(0%)
  Treatment failure/recurred
  10 d | 4/50(8%) | 2/50(4%)
Brodie 1990 | Randomized open trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Cefuroxime axetil vs. amoxicillin 125 mg for < 2 yr 250 mg for 2 +yr | Time: Not specified Place: UK, multicenter general practice Inclusion:; 1. Age: 3 mo-12 yr; 2. AOM in title; OM in text; Exclusion:; 1. Allergic to antibiotic; 2. Serious infection; 3. Previously in study; 4. Antibiotic within 3 d | Age: 36% <2 yr 64% >2 yr Otitis prone: Not addressed N=660 total N1=332 cefuroxime N2=328 amoxicillin | Cured/Improved/failure at 1-4 d, 12-16 d Clinical responses not defined Adverse events
  | Cefuroxime | Amoxicillin
  Failure at 1-4 d
  Total | 15/263(6%) | 16/294(5%)
  3 mo-2 yr | 6/114(5%) | 7/123(6%)
  2-12 yr | 9/149(6%) | 9/171(5%)
  Adverse events 3 mo-12 yr
  Overall | 68/332(20%) | 51/328(16%)
  GI | 35/332(11%) | 14/328(4%)
  Withdrawn due to adverse effects
  | 17/332(5%) | 11/328(3%)
Coles 1993 | Randomized single-blind multicenter trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Clarithromycin bid vs. amoxicillin TID 125 mg for <25 kg; 250 mg for 25 kg+ 5 d therapy | Time: 7/91-1/92 Place: UK 20 clinical sites, setting not specified Inclusion:; 1. Age: 1-12 yr; 2. AOM (title); Exclusion:; 1. Pregnancy; 2. Allergic to antiobioc; 3. Hepatic,renal impairment; 4. Glandular fever; 5. Cronic OM; 6. Antibiotic within 3 d; 7. Topical antibiotic prior to study drug; 8. Long acting antibiotic within 4 wk; 9. On drug metabolized by P450 cytochrome system | Age: 1-12 yr Otits prone: Addressed but statistics not reported N=218 total N1=114 clarithromycin N2=105 amoxicillin | Clinical evaluation at pretreatment, d 1, 6-9, 28-32 Clinical failure defined as exhibited no improvement or worsening of pretreatment clinical signs and symptoms Recurrence on d 28-32 Adverse events
  | Clarithromycin | Amoxicillin
  Ear pain present at 48 hr
  | 24/114(21%) | 27/105(26%)
  Failure at 6-9 d
  | 4/114(4%) | 4/105(4%)
  Recurrence at 28-32 d
  | 6/96(6%) | 5/83(6%)
  Failure at 6-9 d by symptoms
  Otalgia | 4/110(4%) | 2/98(2%)
  Red TM | 6/98(6%) | 7/100(7%)
  Irritab. | 3/90(3%) | 2/85(2%)
  URI | 7/85(8%) | 7/82(9%)
  TM landmarks
  | 13/90(14%) | 11/81(14%)
  Adverse events
  Overall | 4/132(3%) | 8/127(6%)
  Diarrhea | 2/132(2%) | 3/127(2%)
  Vomit | 1/132(1%) | 4/127(3%)
Feigin 1973 | Randomized single-blind trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Clindamycin 15mg/kg/day QID, 10 d vs. ampicillin 75mg/kg/day QID, 10 d | Time:3/70-12/71 Place: St. Louis, outpatient department or ER Inclusion; 1. Ages:3 mo-10 yr; 2. Acute bacterial OM; Exclusion:; 1. Infection at other sites; 2. Antibiotic in past 2 wk; 3. Chronic OM; 4. Allergic to antibiotic | Age: Range: 3 mo-10 yr; Mean: 1.6 yr Otitis prone: Not addressed N=271 total N1=135 clindamycin N2=136 ampicillin | Excellent, good or poor status at 3-4 d and 10 d Poor defined as persistence or worsening of all signs and symptoms at 3 d Organisms isolated
  | Clindamycin | Ampicillin
  Poor response at 3-4 d
  | 10/73(14%) | 8/68(12%)
  Poor response at 3-4 d by major organisms in patients with single isolates
  D.pneu | 2/12(17%) | 1/15(7%)
  H.influ | 5/12(42%) | 2/7(29%)
  S.epid | 2/32(6%) | 2/25(8%)
Feldman 1990 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 5 [1,1,1,1,1] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | TMP/SMX vs. amoxicillin-clavulanate | Time: 1987-1988 Place: Ontario, Canada, walk-in clinics Inclusion:; 1. Age: 1-14 yr; 2. AOM; Exclusion:; 1. Allergic to antibiotic; 2. Recurrent OM (>3 episodes in 6 mo); 3. Hx of otic surgery; 4. Lived >20 km from hospital | Age: 1-14 yr Otitis prone: Not addressed N=202 total N1=101 TMP-SMX N2=101 amoxicillin | Cured/improved/failure rates at 2-4 d, 12-16 d Treatment failure defined as abnormal appearance of the TM along with an acoustic reflectometry reading of 5 units or more.
  | TMP-SMX | Amoxicillin
  Failure at 12-16 days
  | 7/101(7%) | 18/101(18%)
  Adverse effects:
  Diarrhea | 20/101(20%) | 72/101(71%)
  Rash | 4/101(4%) | 0/101(0%)
  D. rash | 1/101(1%) | 14/101(14%)
Foshee 1992 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 4 [1,1,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Loracarbef (30mg/kg/d BID, 7d vs. Amoxicillin 40mg/kg/d, TID, 7d | Time: 10/88-3/90 Place; 7 sites in Finland, 4 sites in Iceland, 1 site in Netherlands, setting not specified Inclusion:; 1. age: 6 mo-12 yr; 2. AOM; Exclusion:; 1. Renal impairment; 2. Allergic to antibiotic; 3. Perforated TM>24 hr; 4. Suspected meningitis; 5. Antibiotic within 3 d; 6. Investigational agents within 28 d | Age: 6 mo-12 yr Otitis prone: Not Addressed N=291 total N1=148 Loracarben N2=143 amoxicillin | Clinical and bacteriologic evaluation and adverse events check at each followup within 72 hr and at 10-16 d after therapy completion Clinical outcomes not defined in this article
  | Loracarbef | Amoxicillin
  Failure at 7-10 d
  | 22/148(15%) | 17/143(12%)
  Failure at 10-16 d by pathogen
  All | 28/148(19%) | 18/143(13%)
  S. pneu | 12/77(16%) | 6/71(8%)
  H. inf | 8/35(23%) | 7/32(22%)
  Morax | 3/17(18%) | 2/18(11%)
  Failed bacteriologic eradication at 7-10 d
  | 31/148(21%) | 4/143(3%)
  Adverse events starting during tx
  1+ | 49/419(12%) | 62/422(15%)
  Ear | 13/419(3%) | 13/422(3%)
  Diar | 8/419(2%) | 13/422(3%)
  Somnolence
  | 8/419(2%) | 9/422(2%)
  Anorexia
  | 7/419(2%) | 7/422(2%)
  Nervous
  | 5/419(1%) | 7/422(2%)
  Vomit | 1/419(0%) | 9/422(2%)
Giebink 1984 | Randomized trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Cefaclor vs. amoxicillin 40mg/kg/d TID for 14 d | Time: not specified Place: Minneapolis, pediatric clinic of a medical center Inclusion: Age: 3 mo-17 yr AOM Exclusion:; 1. Significant underlying disease; 2. Concomitant infection; 3. Other antibiotic TX; 4. Antibiotic TX within 3 d; 5. Allergy | Age: 44% under 2 yr 56% 2-17 yr Otitis prone: 41% hx of >5 episodes 93% hx of >2 episodes N=61 total N1=31 cefaclor N2=30 amoxicillin | Failure to resolve/resolution of signs and symptoms at 3 d and 10-14 d after discontinuing therapy
  | Cefaclor | Amoxicillin
  Failure to resolve signs/symptoms at 3 d posttreatment:
  | 7/31(23%) | 5/30(17%)
  AOM within 7 d of discontinuing study antibiotic:
  Aspirated ear
  | 7/31(23%) | 4/30(13%)
  Nonaspirated ears
  | 4/31(13%) | 4/30(13%)
  AOM/OME within 7 d of discontinuing study antibiotic:
  Aspirated ear
  | 16/31(52%) | 19/30(63%)
  Nonaspirated ears
  | 7/31(23%) | 12/30(40%)
Green 1993 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 4 [1,1,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [0,0,1] | Single-dose intramuscular ceftriaxone vs. Amoxicillin (40mg/kg/d TID for 10 d | Time: 9/90-6/91 Place: California, emergency department at county or university hospital Inclusion:; 1. Age: 5 mo-5 yr; 2. AOM; Exclusion:; 1. Antibiotic in prior 14 d; 2. AOM in last month; 3. Chronic OM; 4. PE tubes; 5. Bleeding dyscrasia; 6. Serious underlying illness; 7. Concurrent infection; 8. Scarred/perforated TM; 9. Allergic to antibiotic; 10. Unable to return for followup | Age: Range: 5 mo-5 yr Mean: .8 yr Otitis prone: 18% 3+ prior episodes; 30% 2+ prior episodes N=233 total N1=117 amoxicillin N2=116 ceftriaxone | Treatment success/failure relapse, and reinfection at 14 and 60 d Unsuccessful defined as no resolution of AOM symptoms or return to ER within 10 d for AOM symptoms; Included both failure or complication
  | Ceftriaxone | amoxicillin
  Unsuccessful at 10 d
  | 11/105(10%) | 10/107(9%)
  Complication at 10 d
  | 5/105(5%) | 7/107(7%)
  Failure at 10 d
  | 6/105(6%) | 3/107(3%)
  Abnormal otoscopic finding
  14 d | 17/48(35%) | 19/56(34%)
  60 d | 8/48(17%) | 12/56(21%)
  Abnormal tympanometric findings
  14 d | 27/47(57%) | 26/55(47%)
  60 d | 18/47(38%) | 24/55(44%)
  Recurrence in 60 d
  | 44/116(38%) | 45/117(38%)
  Reinfection in 31-90 d
  | 12/116(10%) | 21/117(18%)
  Relapse in 11-30 d
  | 19/116(16%) | 13/117(11%)
Halsted 1967, 1968 | Randomized double-blind placebo-controlled trial Jadad quality score ^1^ (0-5): 5 [1,1,1,1,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Gp 1: Ampicillin 100mg/kg/d, QIF 10 d Gp2: Penicillin G 50,000 units/kg/d and sulfisoxazole 150 gm/kg/d, QID 10 d Gp3: Placebo Study 1: Gp 1 vs. Gp 3 Study 2: Gp 2 vs. Gp 3 | Time: 7/65-3/66 Place: Cleveland Metropolitan General Hospital, outpatient department Inclusion:; 1. age: 2-66 mo; 2. AOM; Exclusion:; 1. Antibiotics during prior 2 wk in Study 1, 10 d in Study 2; 2. Any complications requiring antibiotics; 3. Allergic to antibiotics; 4. Ruptured TM (Study 2) | Age: 75% <2 yr 25% >2 yr Otitis prone: Not addressed N=89 total N1=30 ampicillin N2=32 penicillin+sulfisoxazole N3=27 placebo | Fever at 24 hr and 24-72 hr Recurrence of AOM 14 d-3 mo and up to 1 yr Improvement/Failure at 14-72 hr and 14-18 d based on symptomatology and appearance of the TM
  Failure rate
  Amp | Pen+sulf | Placebo
  24-72 hr: all cases
  10/30 (33%) | 7/32 (22%) | 7/27 (26%)
  24-72 hr: positive cult. cases
  3/16 (19%) | 4/19 (21%) | 6/19 (32%)
  24-72 hr: negative cult. cases
  7/14 (50%) | 3/13 (23%) | 1/8 (12%)
  14-18 d: all cases
  2/25 (8%) | 2/25 (8%) | 0/21 (0%)
  Recurrence rate at 1 yr(estimated)
  14/32 (44%) | 15/30 (50%) | 11/27 (41%)
Howie 1985 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 2 [1,1,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Eight combinations of antibiotics, but only two groups were randomized within the same time period Gp 5: TMP-SMX vs. Gp 8 cefaclor | Time: 1970-1980 Place: Huntsville, AL; pediatric clinic Inclusion:; 1. Age: age range not specified; 2. Acute or recurrent OM; Exclusion:; 1. Antibiotic treatment in prior 2 wk; 2. Denial of tympanocentesis | Age: Not addressed Otitis prone: Not addressed N=948 (episodes) N5=124 N8=76 | Clinical evaluation and bacteriologic outcomes at 3-5 d, 14 d, 31 d after first visit Unsatisfactory defined as presence of a bulging eardrum or middle ear drainage on the 14 d visit
  | Cefaclor | TMP-SMX
  Unsatisfactory 14 d
  | 34/76(45%) | 27/83(33%)
Jacobson 1979 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 5 [1,1,1,1,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Cefaclor vs. amoxicillin 40mg/kg/d, TID, 10 d | Time: 5/77-8/78 Place: Utah, outpatient pediatric clinic at university medical center Inclusion: Age: 1-12 yr Exclusion:; 1. Antibiotic in preceding 72 hr; 2. Allergy | Age: Mean=3.9 yr Otitis prone: Not addressed N=28 total N1=13 cefaclor N2=15 amoxicillin | Clinical evaluation: cured, improved, not improved at 3 d, 1 wk. (only 1 wk findings reported)
  | Cefaclor | amoxicillin
  Not cured at 1 wk:
  | 1/13(8%) | 0/15(0%)
  Not improved or cured at 1 wk:
  | 2/13(15%) | 2/15(13%)
  Skin rash at 1 wk:
  | 1/13(8%) | 1/15(7%)
Johnson 1991 | Randomized single-blind trial Jadad quality score ^1^ (0-5): 1 [1,0,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Cefixime vs. amoxicillin | Time: 10/86-6/89 Place: Cleveland, Ohio, pediatric clinic at medical center Inclusion:; 1. Age:8 wk-13 yr; 2. AOM; Exclusion:; 1. Allergic to antibiotic; 2. Serious chronic disease; 3. Immunodeficient; 4. PE/history of PE tubes; 5. Craniofacial defects; 6. Antibiotic within 3 d; 7. Non-English speaking | Age Mean=1.5 yr Otitis prone: 27% >3 prior episodes 73% <3 prior episodes N=126 total N1=62 amoxicillin N2=64 cefixime | Symptomatic improvement at 3-5 d MEE at 10 d MEE at 4-5 wk Recurrence of OM at 4-5 wk Side effects within 10 d of therapy Persistence of bacterial pathogens
  | Cefixime | Amoxicillin
  Failed improvement at 3-5 d
  | 3/30(10%) | 4/34(12%)
  MEE at 10 d
  | 16/21(76%) | 13/24(54%)
  MEE at 4-5 wk
  | 15/20(75%) | 10/20(50%)
  Recurrence at 4-5 wk
  | 3/20(15%) | 3/20(15%)
  Side effects within 10 d
  Rash | 13/59(22%) | 5/51(10%)
  Diarrhea | 20/59(34%) | 15/51(29%)
  Vomit | 5/59(8%) | 3/51(6%)
  Tinnitus | 0/59(0%) | 1/59(0%)
  Persistence of bacterial pathogens
  S. pneu | 4/16(25%) | 1/15(7%)
  H. influ | 0/10(0%) | 5/13(38%)
  M. catarr | 1/7(14%) | 1/8(12%)
Kara 1998 | Randomized controlled trial Jadad quality score ^1^ (0-5): 1 [1,0,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Amoxicillin (40mg/kg/d, TID, 10d) vs. cefuroxime axetil (30mg/kg/d, BID, 10d) vs. Ccftriaxone (50mg/kg/single dose, IM) | Time:9/97-5/97 Place: Turkey, ENT, pediatric and infectious disease clinics Inclusion:; 1. Age: 6 mo-6 yr; 2. AOM; Exclusion:; 1. AOM within 3 mo; 2. Antibiotic within 2 wk; 3. Allergic to antibiotic | Age: 6 mo-6 yr Otitis prone: Not addressed N=75, 25 per group | Clinical evaluation at 3, 10, 30 d after therapy Treatment failure defined as no resolution of symptoms and clinical and tympanometric appearance of the TM
  Cefuro | Ceftri | Amox
  Failure at d 5
  2/25 | 4/25 | 2/25
  (8%) | (16%) | (8%)
  Rash/loose stool
  0/25 | 0/25 | 2/25
  (0%) | (0%) | (8%)
Laxdal 1970 | Randomized controlled trial Jadad quality score ^1^ (0-5): 2 [1,0,0,1,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Ampicillin vs. Penicillin vs. symptomatic treatment | Time: 1/66-9/68; Place: Saskatchewan, Canada private practice Inclusion:; 1. Age: <15 yr (lower limit not specified); 2. AOM; Exclusion:; 1. Predominantly respiratory symptoms; 2. Allergy a significant factor; 3. Rupture of eardrum | Age: 49% <3 yr 51% >3 yr Otitis prone: Not addressed N=142 total N1=48 with placebo N2=45 with penicillin N3=49 with ampicillin | Treatment failure and middle ear inflammation disappearance by the 7^th^ d
  | Pen | Amp | Symp.
  Failure rate <15 yr
  | 11/45 24% | 5/49 10% | 18/48 38%
  Failure rate by age (no denominator given)
  Age | Pen | Amp | Symp.
  0-3 | 32% | 15% | 46%
  3-6 | 30% | 0% | 38%
  6-9 | 0% | 9% | 25%
  9-14 | 0% | 0% | 0%
Leigh 1989 | Randomized open label trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Oral cephalosporin, cefixime vs. amoxicillin | Time: not specified Place: Gosport, (UK?) General practice setting Inclusion:; 1. Age: 6 mo-16 yr; 2. AOM; Exclusion:; 1. Allergic to antibiotic; 2. Antibiotic within 5d; 3. Renal or hepatic dz; 4. Other infection; 5. Diabetes; 6. Chronic OM; 7. Mastoiditis | Age: Mean=4.9 yr Otitis prone: Not addressed N=325 total N1=160 cefixime N2=165 amoxicillin | Clinical evaluation in terms of cured, improved, failed at 10-14 day after initiation of treatment. Clinical failure was classed as no response to therapy judged by physician. Adverse effects at 2-3 d and 10-14 d.
  | Cefixime | Amoxicillin
  Failure at 10-14d
  | 7/150 (5%) | 8/150 (5%)
  Adverse reactions
  Total | 26/150(17%) | 11/150(7%)
  GI symtoms | 21/15014%) | 7/150(5%)
  Diarrh | 19/150(13%) | 5/150(3%)
  Rash | 1/150(1%) | 3/150(2%)
  Vomit | 2/150(1%) | 0/150(0%)
Lenoski 1968 | Randomized non-blinded trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Gp1 Erythromycin ethyl succinate vs. Gp2: Erythromycin ethyl succinate plus triple sulfonamide vs. Gp3: Triple sulfonamide vs. Gp4: Ampicillin | Time: 8/66-8/67 Place: Los Angeles, CA; pediatric emergency clinic Inclusion:; 1. Age: not specified; 2. Acute bacterial otitis; Exclusion:; 1. Chronic OM; 2. Any antibiotic during present illness | Age: 58% <3 yr 42% >3 yr Otitis prone: Not specified N=250 total N1=72 N2=64 N3=63 N4=51 For acute purulent cases: N=76 N1=19 N2=18 N3=18 N4=21 | Clinical outcome: cured/failure at day 14 Failure defined as symptoms worsened or recurred after initial improvement or if TM appearance did not improve or regressed after initial improvement regardless of clinical symptoms.
  Failure at day 14 (for acute purulent cases only)
  | Gp1 | Gp2 | Gp3 | Gp4
  Total | 1/19 (5%) | 6/18 (33%) | 7/18 (39%) | 6/21 (29%)
  <3 yr | 1/7 (14%) | 4/8 (50%) | 2/8 (25%) | 1/7 (14%)
  >3 yr | 0/12 (0%) | 2/10 (20%) | 5/10 (50%) | 5/14 (36%)
  Recurrence after cure
  Total | 4/13 (31%) | 1/9 (11%) | 2/7 (29%) | 1/11 (9%)
Marchant 1984 | Randomized double-blind controlled trial Jadad quality score ^1^ (0-5): 4 [1,1,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Cefaclor vs. TMP-SMZ | Time: not specified Place: Cleveland Ohio, outpatient clinic Inclusion:; 1. Age: 2-24 mo; 2. AOM; 3. Effusion on tympanocentesis; Exclusion:; 1. Allergy to antibiotic; 2. Concurrent illness; 3. Immunodeficient; 4. G-GPD (glucose-6-phosphate dehydro-genase deficiency) | Age: 100% <2 yr Otitis prone: Not addressed N=129 total N1=64 cefaclor N2=65 TMP-SMZ | Clinical evaluations at 3-6 d, 2 wk, 4wk. Symptomatic improvement defined as decreased irritability, as reported by parent or guardian, or absence of fever on 3-6 d visit.
  | Cefaclor | TMP-SMZ
  Lack of improvement at 3-6d
  | 5/35(14%) | 4/34(12%)
  MEE at 2 wk
  | 6/38(16%) | 5/33(15%)
  MEE at 4 wk
  | 10/37(27%) | 10/30(33%)
  Recurrence 1-2wk
  | 6/38(16%) | 1/33(3%)
  Recurrence at 2-4wk
  | 9/37(24%) | 13/30(43%)
  Persistence of pathogen at 3-6 d
  All | 12/40(30%) | 2/37(5%)
  S. pneu | 4/20(80%) | 0/19(0%)
  H. influ | 8/18(44%) | 1/14(7%)
  B. Catarr | 0/8(0%) | 0/9(0%)
McLinn 1979 | Randomized trial Jadad quality score ^1^ (0-5): 1 [1,0,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Cephradine vs. amoxicillin | Time: not specified Place: Pennsylvania private practice Inclusion:; 1. Age:4 mo-14 yr; 2. AOM only in introduction (om was used throughout); Exclusion:; 1. Allergic to antibiotic; 2. Prior antibiotic for present AOM episode | Age: 4 mo-14 yr Otitis prone; Not addressed N=100 total N1=50 cephradine N2=50 amoxicillin | Clinical evaluations at 2, 7, 10 d; Recurrence rate evaluated for 1 yr; Bacteriologic evaluations Excellent defined as initial improvement in <3 d and a cure within 3-4 d in mild, 5-6 d in moderate, and 7-8 d in severe infections.
  | Cephradine | Amoxicillin
  No initial improvement of signs
  | 2/49 (4%) | 0/50(0%)
  Overall outcome at 10 d
  Poor | 3/50(6%) | 3/50(6%)
  Fair | 2/50(4%) | 0/50(0%)
  Good | 13/50(26%) | 17/50(34%)
  Excellent | 32/50(64%) | 30/50(60%)
  Recurrence
  <3 mo | 11/50(22%) | 14/50(28%)
  <6 mo | 12/50(24%) | 21/50(42%)
  <12 mo | 13/50(26%) | 26/50(52%)
McLinn 1980 | Randomized single-blind trial Jadad quality score ^1^ (0-5): 2 [1,0,0,1,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Cefaclor vs. amoxicillin | Time: not specified Place: Pennsylvania, private outpatient Inclusion:; 1. Age: 1 mo-11 yr; 2. OM; Exclusion: None reported | Age: 45% <2 yr 55% >2 yr Otits prone: Not addressed N=130 total N1=64 cefaclor N2=66 amoxicillin | Failure/cured rate at 10-21 d Failure defined as no improvement of signs and symptoms of infection and persistence of pathogen on culture
  | Cefaclor | Amoxicillin
  Failure at 10-21 d
  | 3/64 (5%) | 6/66 (9%)
  Reinfection/relapse 10-21 d
  | 2/64 (3%) | 2/66 (3%)
  Failure at 10-21 d by organism
  S. pneu
  | 1/37 (3%) | 4/37 (11%)
  H. influ
  | 3/20 (15%) | 4/14 (21%)
  Strep group A
  | 1/6 (17%) | 1/5 (20%)
  Staphylococcus aureus
  | 0/3 (0%) | 0/7 (0%)
  Neisseria catarrhalis
  | 0/2 (0%) | 0/6 (0%)
  Total | 5/68 (7%) | 8/69 (12%)
McLinn 1987 | Randomized open label trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Cefixime vs amoxicillin | Time:4/85-9/85 Place:15 sites in U.S. setting not specified Inclusion:; 1. Ages: 6 mo-11 yr; 2. AOM with effusion; Exclusion:; 1. Antibiotic within 72 hr; 2. Allergy; 3. Underlying diseases; 4. Concurrent illness; 5. Underlying ME DZ; 6. Sensorineural hearing loss | Age: 61%<2 yr 39% >2 yr Otitis prone: 62.5% had prior episodes; 37.5% no prior eisodes N=120 total N1=60 cefixime N2=60 amoxicillin | Clinical response at 3-5 d and at 10 d Bacteriologic outcomes Failure defined as no improvement of signs and symptoms of infection and persistence of pathogen on culture
  | Cefixime | Amoxicillin
  Clinical failure at 10 d
  | 1/30 (3%) | 1/34 (3%)
  Relapse at 10 d
  | 1/30 (3%) | 1/34 (3%)
  Bacteriologic persistence
  | 2/32 (6%) | 2/39(5%)
  GI problem (total of 3)
  | 27/60(45%) | 15/60(25%)
  Diarrhea
  | 10/60(17%) | 9/60(15%)
  Stool changes
  | 13/60(22%) | 5/60(8%)
  Nausea/vomiting
  | 7/60(12%) | 1/60(2%)
  Rash | 9/60(15%) | 1/60(2%)
Nassar 1974 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 3 [1,1,0,0,1] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Cephalexin vs. ampicillin | Time: Not specified Place: England, setting not specified Inclusion:; 1. Age: < 12 yr (lower limit not specified); 2. AOM; Exclusion:; 1. Allergic to antibiotic | Age: Mean=4.9 yr Otitis prone: 52% recurrence 48% first episode N=54 total N1=24 cephalexin N2=30 ampicillin | Clinical evaluation at 7-14 d Bacteriologic outcomes Failure defined as no improvement within 14 days so that a change of treatment or surgical intervention was necessary.
  | Cephalexin | Ampicillin
  Failure at 14 d
  | 1/24 (4%) | 1/30 (3%)
Nilson 1969 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 4 [1,1,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Gp 1: Penicillin V Gp 2: Pencicillin V plus sulfonamide Gp 3: Ampicillin | Time:12/66-2/68 Place: Baltimore, MD; outpatient clinic setting Inclusion:; 1. Age: <3 yr (lower limit not specified); 2. AOM requiring antibiotic; Exclusion:; 1. Pneumonia; 2. Underlying debilitating disease; 3. Symptoms>10 d; 4. Vomiting; 5. Perforated TM; 6. Antibiotic within 2 wk | Age: 15% <6 mo 27% 6-12 mo 36% 1-<2 yr 21% 2-3 yr Otitis prone: Not addressed N=306 102 each | Evaluation at 3-4 d, 10-12 d Unsatisfactory defined as marked injection >1/3 TM, marked decrease TM mobility, bubbles, Otorrhea, marked distortion or obliteration of bony landmarks, or any degree of TM distension
  Unsatisfactory outcome at 10-12 d
  | Pen V | Pen V+S | Amp
  Total | 27/96 | 17/93 | 25/101
  | (28%) | (18%) | (25%)
  Unsatisfactory 10-12 d by organism
  Pneum | 8/28 | 5/31 | 4/25
  | (29%) | (16%) | (16%)
  H.influ | 12/18 | 6/21 | 8/28
  | (67%) | (29%) | (29%)
  Other | 1/10 | 1/6 | 5/10
  | (10%) | (17%) | (50%)
  Sterile | 6/40 | 5/35 | 8/38
  | (15%) | (14%) | (21%)
Owen 1993 | Randomized non-blinded Trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Cefixime vs. amoxicillin | Time: 10/87 to 3/88 Place: Texas, pediatric clinic of university medical center Inclusion:; 1. Age: 2 mo-6 yr; 2. AOM; Exclusion:; 1. Antibiotic within 3 d; 2. Allergic to antibiotic; 3. PE tubes; 4. Chronic perforation; 5. Chronic OM; 6. HX of ME surgery; 7. Sensorineural hearing loss; 8. Malabsorption; 9. Severe underlying disease | Age: Mean=1.8 yr Otitis prone: 26% >3 episodes 48% 1-2 episodes 26% no prior episode N=201 children N1=99 cefixime N2=102 amoxicillin | Clinical outcome in terms of cured/improved and failing at 4-6, 10-13, and 31-38 days after start of therapy Clinical failure defined as continued or recurrent symptoms with red or yellow, bulging TM or purulent drainage through a persisting perforation Bacteriologic outcomes at similar times
  | Cefixime | Amoxicillin
  Failure* (on all evaluable subjects)
  4-6 d | 21/90(23%) | 30/92(33%)
  10-13 d | 19/74(26%) | 14/61(23%)
  31-38 d | 13/40(32%) | 12/35(34%)
  Failure* (excl cases with no pathogen at baseline and poor compliance)
  4-6 d | 18/71(25%) | 22/64(34%)
  10-13 d | 15/48(31%) | 10/39(26%)
  31-38 d | 9/23(39%) | 6/22(27%)
  Persistence of pathogen at 4-10 d
  H.infl | 3/34(9%) | 9/35(26%)
  Srep Pneu | 5/26(19%) | 2/31(6%)
  M.catar | 0/10(0%) | 8/21(38%)
  Side Effects
  Total | 31/91(34%) | 32/93(34%)
  Diarrhea | 26/91(29%) | 13/93(14%)
  Rash | 13/91(14%) | 10/93(11%)
  Vomit | 6/91(7%) | 4/93(4%)
  +Lab | 4/91(4%) | 6/93(6%)
  StopMed | 3/91(3%) | 1/93(1%)
  *Failure at 4-6 d based solely on clinical grounds while failure at 10-13 d and 31-38 d included bacteriologic failures.
Ploussard 1984 | Randomized open label trial Jadad quality score ^1^ (0-5): 3 [1,0,0,1,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Oral doses of cefaclor, 40mg/kg/day for 5 d vs. oral doses of amoxicillin, 40mg/kg/day for 10 d | Time: Not specified Place: Not specified Inclusion:; 1. Age: 5 mo-5 yr; 2. AOM; Exclusion:; 1. Allergy; 2. Renal disease; 3. Hepatic disease; 4. Significant underlying disease; 5. Antibiotic within 3 d; 6. Concurrent infection; 7. B strep, group A | Age: 84% <2 yr 16% >2 yr Otitis prone: Not addressed N=60 N1=30 N2=30 | Unsatisfactory clinical outcome defined as no improvement of signs and symptoms, as soon as after d 3 of therapy Recurrence: signs and symptoms returned within 16 d after therapy end
  | Cefaclor | Amoxicillin
  Overall unsatisfactory outcome
  | 0/27(0%) | 4/29(14%)
  Recurrence
  | 2/27(7%) | 0/29(0%)
  Unsatisfactory outcome by pathogen
  S. pneu
  | 0/14(0%) | 0/13(0%)
  H. flu
  | 0/3(0%) | 0/3(0%)
  Sterile culture
  | 0/3(0%) | 0/5(0%)
Principi 1991 | Randomized open label trial Jadad quality score ^1^ (0-5): 2 [1,0,0,1,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Cefixime vs. amoxicillin | Time: Not specified Place: Italy, setting not specified Inclusion:; 1. Age:under 12 yr (lower limit not specified); 2. AOM; Exclusion:; 1. Otorrhea >12 hr | Age: 40% <2 yr 60% >2 yr Otitis prone: 37.5% had prior episodes, 62.5% none N=40 total N1=20 cefixime N2=20 amoxicillin | Cure, improved, persistent effusion, failure, recurrences at 15, 30, 60 and 90 d Failure defined as persistence of signs and symptoms of AOM midtreatment and/or need for discontinuation of treatment because of adverse effects
  | Cefixime | Amoxicillin
  Failure
  15 d | 2/20(10%) | 2/20(10%)
  30-90 d | 0/20(0%) | 0/20(0%)
  Persistent effusion
  30 d | 14/20(70%) | 13/20(65%)
  60 d | 8/20(40%) | 10/20(50%)
  90 d | 5/20(25%) | 7/20(35%)
  Recurrence
  30 d | 1/20(5%) | 0/20(0%)
  60 d | 3/20(15%) | 1/20(5%)
  90 d | 4/20(20%) | 2/20(10%)
  Adverse Reactions
  Vomiting | 1/20(5%) | 0/20(0%)
  Diarrhea | 3/20(15%) | 3/20(15%)
Pukander 1993 | Randomized single-blind trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Clarithromycin vs. amoxicillin | Time: 12/90-3/92 Place: 4 Finnish sites, setting not specified Inclusion:; 1. Age: 1-12 yr; 2. AOM; Exclusion:; 1. Antiobiotic within 7 d; 2. Topical antibiotic drops; 3. Long acting/investigational antibiotic within 4 wk; 4. In prior trials; 5. Allergic to antibiotic; 6. Major systemic disease; 7. Chronic OM; 8. Perforated TM; 9. AOM within 28 d | Age: 1-12yrs Otitis prone: Not addressed N=79 total N1=39 clarithromycin N2=40 amoxicillin | Clinical response within 48 hr and at 10-14 d posttreatment; clinical success rate posttreatment by pretreatment pathogen; adverse events Failure defined as pretreatment signs and symptoms did not improve or worsened and effusion was present in the middle ear.
  | Clarithromycin | Amoxicillin
  Failure within 48 hr
  | 2/27(7%) | 2/20 (10%)
  Failure rate posttreatment by pretreatment pathogen:
  S.pneu | 0/11(0%) | 1/9(11%)
  H.infl | 1/11(9%) | 1/6(17%)
  M.catar | 1/6(17%) | 0/1(0%)
  Adverse Events
  Total | 10/39(26%) | 7/40(18%)
  GI | 6/39(15%) | 6/40(12%)
Rodriguez 1985 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 3 [1,1,1,1,-1] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Erythromycin sulfisoxazole (50mg/kg/d, QID, 10 d) vs. amoxicillin (40mg/kg/d if <20 kg; 250 mg/dose if >20 kg; TID, 10 d) | Time: 2/80-5/82 Place: Washington DC; private practice and hospital outpatient clinics Inclusion:; 1. Age: 2 mo-17 yr; 2. AOM; Exclusion:; 1. Antibiotic within 1 wk; 2. PE tubes | Age: 2 mo-17 yr mean=3.2 yr Otitis prone: Not addressed N=253 total N1=126 erythromycin N2=127 amoxicillin | Clinical evaluation at 4, 10-14, 28 d Failure defined as persistent signs and symptoms of AOM while on initial therapy or at 10-14 d Recurrence defined as recur of signs and symptoms of AOM after considered cured at 10-14 d Persistent OME defined as nonbulging, opaque TM in neutral or retracted position with poor or no mobility
  | Eryth/Sulf | Amox
  Failure at 10-14 d
  | 8/73(11%) | 8/72(11%)
  Failure at 10-14 d by organism
  S. pneu | 0/40(0%) | 4/35(11%)
  H. fllu | 0/24(0%) | 0/31(0%)
  Recurrence at 30 d
  | 9/73(12%) | 12/72(17%)
  Persistent OME
  10-14 d | 35/73(48%) | 27/72(38%)
  28 d | 11/70(16%) | 7/71(10%)
Scholz 1998 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 4 [1,1,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Erthromycin estolate (EE) (40 mg/kg/d, BID, 10 d vs. amoxicillin (50mg/kg/d, BID, 10 d | Time: 5/95-1/96 Place: 19 pediatricians from 19 pediatric practices in Germany Inclusion:; 1. Age: 6 mo-11 yr; 2. AOM; 3. Onset within 4 d before entry; Exclusion:; 1. Chronic otitis media; 2. AOM within 4 wks; 3. PE tubes; 4. Antibiotic within 7 d; 5. Depot antibiotic within 4 wk; 6. Prior enrollment; 7. Allergic to antibiotic; 8. Craniofacial disorder | Age: 14% <2 yr 86% >2 yr Mean=4.3 yr Otitis prone: Not addressed N=302 total 151 each group | Clinical evaluation on d 3-4, d 9-11, and wk 5 Failure defined as worsening or lack of resolution of clinical signs and symptoms; lack of marked improvement of otoscopic findings; new clinical or otoscopic signs or symptoms of AOM; change of antimicrobial med or tympanocentesis deemed necessary; AOM complications >24 hr after initiation of therapy
  | Erythromycin | Amoxicillin
  Failure at 9-11 d
  | 9/141(6%) | 6/139(4%)
  Recurrence
  <14 d | 0/141(0%) | 0/139(0%)
  <21 d | 1/141(1%) | 1/139(1%)
  <31 d | 4/141(3%) | 4/139(3%)
  <41 d | 8/141(6%) | 7/139(5%)
Stechenberg 1976 | Randomized controlled trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Cephalexin vs. ampicillin | Time: 7/73-7/75 Place: St. Louis, outpatient department. or emergency room Inclusion:; 1. Age: 3 mo-11.6 yr; 2. AOM; Exclusion:; 1. Concurrent; 2. Vomiting; 3. Underlying disease; 4. Chronic OM | Age: Mean=1.5 yr Otitis prone: Not addressed N=179 total N1=78 ampicillin N2=101 cephalexin | Clinical evaluation at 3-4 d and at 10-14 d Specific organisms Poor response defined as persistence or worsening of all signs and symptoms at 3 d
  | Cephalexin | Ampicillin
  Poor response
  Total | 20/80 (25%) | 5/60 (8.3%)
  Poor response by organism
  S. aure | 2/13(15%) | 1/4 (25%)
  S. epid | 2/21(10%) | 1/15(7%)
  S. pneu | 3/12(25%) | 0/14(0%)
  H. influ | 4/10(40%) | 0/2(0%)
  Diarrhea
  | 2/80 (2.5%) | 3/60 (5%)
Varsano 1988 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 4 [1,1,1,0,1] Number of components addressed in defining AOM (0-3): 2 [1,0,1] | Single intramuscular dose of ceftriaxone vs. 7-d amoxicillin | Time: Not specified Place: Israel, walk-in clinic of emergency room Inclusion:; 1. Age: 6 mo-8 yr; 2. AOM; Exclusion:; 1. AOM in prior month; 2. Antibiotic within 2 wk; 3. Perforated TM; 4. Cleft lip; 5. Immunodeficient; 6. Allergic to antibiotic | Age: Mean=2 yr Otitis prone: 58% >2 prior episodes 15% <2 prior episodes 27% no prior episodes N=52 total N1=27 ceftriaxone N2=25 amoxicillin | Rate of acute symptom resolution and incidence of recurrence during first month Early failure defined as persistence or recurrence of fever and/or pain, associated with otoscopic signs at first 10 d Late failure defined similarly at 10-30 d
  | Ceftriaxone | Amoxicillin
  Treatment failure at 1 wk
  | 4/22(18%) | 3/22(14%)
  Recurrence at 1 mo
  | 2/18(11%) | 2/15(13%)

1 Jadad score components: randomization mentioned; double-blink mentioned; droupouts described; randomization appropriate; double-blinging appropriate.

2 AOM definition components: middle ear effusion; rapid onset; acute inflammation.

Abbreviations used: AOM -- acute otitis media; BID -- twice a day; DZ -- disease; ENT -- ear, nose, and throat; ER -- emergency room; GI -- gastrointestinal; HX -- history; MEE -- Middle ear; OM -- otitis media OME -- otitis media with effusion; PE -- pressure equalization; QID -- four times a day; TID -- three times a day; TM -- tympanic membrane; TMP-SMX -- trimethoprim-sulfamethoxazole; TX -- treatment; URI -- upper respiratory infection.

Evidence Table 4. Key question 4b. Effectiveness of oral fluoroquinolones

No articles eligible for inclusion as scientific evidence.

Key question 4c. High-dose amoxicillin vs. standard-dose amoxicillin

Author Year | Study Design and Quality | Intervention | Time/Place Inclusion/Exclusion Criteria | Influencing Factors and Sample Size | Outcomes | Findings
Bottenfield 1998 | Randomized controlled trial Jadad quality score ^1^ (0-5): 1[1,0,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Amoxicillin/clavulanate (Augmentin) 90mg/kg/d Bid for 10 d vs. 45mg/kg/d Bid for 10 d | Time: 12/96-2/97 Place: 19 U.S. treatment centers, setting not specified Inclusion:; 1. Age 3 mo - 12 yr; 2. Aom; Exclusion:; 1. Serious underlying disease; 2. Concomitant infections; 3. Renal insufficiency; 4. Allergic to antibiotic; 5. Hx A/C-associated jaundice or hepatic dysfunction; 6. PKU or aspartame hypersensitivity; 7. Bowel function-altering meds within 48 hr | Age: 43%<2 yr 57%>2 yr Otitis prone: Not addressed N=408 N1=201 A/C-90 N2=207 A/C-45 Completed study: N1=177 A/C-90 N2=189 A/C-45 | Clinical response (either success or failure) at end of therapy; Recurrence at 22 to 28 d Adverse experiences during therapy
  | A/C 90 | A/C 45
  Failed at end of therapy
  | 63/201(31%) | 66/207(32%)
  Recurrence at 22-28d
  | 28/177 (16%) | 40/189(21%)
  Adverse experiences (frequent ones)
  Any | 101/201(50%) | 98/207(47%)
  Cough | 24/201(12%) | 14/207(7%)
  Vomit | 13/201(6%) | 16/207(8%)
  D. Rash | 12/201(6%) | 11/207(5%)
  Fever | 11/201(5%) | 8/207(4%)
  URI | 6/201(3%) | 19/207(9%)

1 Jadad score components: randomization mentioned; double-blind mentioned; dropouts described; randomization appropriate; double-blinding appropriate

2 AOM definition components: middle ear effusion; rapid onset; acute inflammation Abbreviations used: A/C -- amoxicillin/clavulanate; AOM -- acute otitis media; BID -- twice a day; HX -- history; PKU -- phenylketonuria; TID -- three times a day; TM -- tympanic membrane; URI -- upper respiratory infection.

Evidence Table 4. Key question 4d: Twice a day high-dose amoxicillin therapy vs. three time a day amoxicillin (continued)

Author, Year | Study Design and Quality | Intervention | Time/Place Inclusion/Exclusion Criteria | Influencing Factors and Sample Size | Outcomes | Findings
1669 Principi 1986 | Randomized trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components ^1^ addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Amoxicilln Bid vs. TID for 10 d | Time: 10/84-2/85 Place: Italy, outpatient ward Inclusion; 1. Age: 6 mo-12 yrs; 2. AOM; Exclusion; 1. Underlying serious illness; 2. Concurrent infection; 3. Allergic to antibiotic; 4. Antibiotics within 2 wk; 5. Draining >12 hr from spontaneously perforated TM | Age: 14% <1 yr 67% 1-5 yr 19% >5 yr Otitis prone: 6% 3+ prior episodes 29% 1-2 prior episodes 65% no prior episode N=110 total N1=55 BID N2=55 TID | Clinical cure or failure at 5, 15, 30, 60, and 90 d Recurrence at 30, 60, and 90 d
  | BID | TID
  15 d outcome-Bilateral disease
  Failure | 5/47(11%) | 4/45(9%)
  B-effuse | 29/47(62%) | 27/45(60%)
  U-effuse | 7/47(15%) | 4/45(9%)
  15 d outcome-Unilateral disease
  Failure | 1/8(12%) | 0/10(0%)
  B-effuse | 0/8(0%) | 3/10(30%)
  U-effuse | 5/8(62%) | 6/10(60%)
  30 d outcome-Bilateral disease
  Recurred | 4/42(10%) | 0/41(0%)
  B-effuse | 26/42(62%) | 26/41(63%)
  U-effuse | 4/42(10%) | 5/41(12%)
  30 d outcome-Unilateral disease
  Recurred | 0/7(0%) | 0/10(0%)
  B-effuse | 0/7(0%) | 6/10(60%)
  U-effuse | 4/7(57%) | 1/10(10%)
  60 d outcome-Bilateral disease
  Recurred | 4/39(10%) | 1/40(2%)
  B-effuse | 22/39(56%) | 22/40(55%)
  U-effuse | 3/39(8%) | 4/40(10%)
  60 d outcome-Unilateral disease
  Recurred | 0/7(0%) | 0/10(0%)
  B-effuse | 1/7(14%) | 4/10(40%)
  U-effuse | 2/7(28%) | 1/10(10%)
  90 d outcome-Bilateral disease
  Recurred | 4/39(10%) | 1/40(2%)
  B-effuse | 12/39(31%) | 13/40(32%)
  U-effuse | 7/39(18%) | 9/40(22%)
  90 d outcome-Unilateral disease
  Recurred | 0/7(0%) | 0/9(0%)
  B-effuse | 0/7(0%) | 3/9(33%)
  U-effuse | 1/7(14%) | 1/9(11%)

1 Jadad score components: randomization mentioned; double-blind mentioned; dropouts described; randomization appropriate; double-blinding appropriate

2 AOM definition components: middle ear effusion; rapid onset; acute inflammation

Abbreviations used: A/C -- amoxicillin/clavulanate; AOM -- acute otitis media; BID -- twice a day; HX -- history; PKU -- phenylketonuria; TID -- three times a day; TM -- tympanic membrane; URI -- upper respiratory infection.

Evidence Table 5. Key Question 4e: Short- Versus Long-Term Antibiotic Therapy (In Alphabetical Order by First Author)

Author Year | Study Design And Quality | Intervention | Time/Place Inclusion/Exclusion Criteria | Influencing Factors and Sample Size | Outcomes | Findings
Adam 1995 | Randomized open trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | 5 d cefpodoxime vs. 10 d Cefaclor | Time: Unspecified Place: Germany, private practice of pediatricians Inclusion:; 1. Age: 3 mo-6 yr; 2. AOM; Exclusion:; 1. Chronic OM; 2. Mastoiditis; 3. Allergic to antibiotic; 4. Renal failure; 5. PKU; 6. Immunodeficient; 7. Antibiotic within 72 hr; 8. Investigational drug within 30 d; 9. Prior in study | Age: Mean=3.5 yr Otitis prone: Not addressed. N=100 total N1=N2=50 | Clinical outcomes at 1-3 d and 3 wk after end of treatment. Failure defined as persistence or worsening of signs and symptoms of infection. Relapse defined as recurrence of signs and symptoms of infection at 3 wk following discontinuation of therapy.
  | 5-d | 10-d
  Failure at 11-13 d
  | 0/50(0%) | 0/50(0%)
  Relapse at 3 wk
  | 6/48(12%) | 4/48(8%)
  Adverse reaction:
  Diarrhea | 5/50(10%) | 4/50(8%)
  Abdominal pain | 0/50(0%) | 2/50(4%)
  Urticaria | 1/50(2%) | 0/50(0%)
  Total | 6/50(12%) | 6/50(12%)
Arguedas 1996 | Randomized open trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Azithromycin (10mg/kg once daily for 3 d) vs. amoxycillin/clavulanate potassium (40mg/kg/d TID, 10 d) | Time: Not specified Place: San Jose, Costa Rica, ambulatory unit of children's hospital Inclusion:; 1. Age: 6 m-12 yr; 2. AOM; Exclusion:; 1. Perforated TM; 2. Prior PE tubes; 3. Allergic to antibiotic; 4. antibiotic within 72 hr; 5. Serious underlying illness; 6. Malabsorption | Age: Mean=4 yr Otitis prone: Not addressed N=100 total N1=51 Azithromycin N2=49 Amoxicillin/clavulanate | Clinical outcome in terms of satisfactory or failure at 10-11 d, 11-13 d, 23-30 d, 23-30 d, 55-60 d Clinical failure defined as inability to clear presenting clinical symptoms or persistent ear drainage by end of therapy Bacteriological failure defined as inability to sterilize middle ear fluid in pts with persistent ear drainage or had repeated tympanocentesis Recurrence defined as relapse or reinfection
  | Azithrmycin | Amoxicillin/clavunate
  Failed on 10-11 d
  | 0/47 (0%) | 2/45 (4%)
  Relapse/reinfected on 28-30 d
  | 0/47 (0%) | 0/45 (0%)
  Persistent middle ear effusion
  11-13 d | 33/40(82%) | 30/38(79%)
  28-30 d | 12/40(30%) | 30/38(79%)
  55-60 d | 6/40(15%) | 8/38(21%)
  Adverse effects 10-14 d
  Nausea | 1/47 (2%) | 7/45(16%)
  Vomit | 4/47 (9%) | 6/45(13%)
  Loose stool | 3/47 (6%) | 14/45(31%)
  Rash | 0/47 (0%) | 3/45(7%)
Arguedas 1997 | Randomized open trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | 3 d azithromycin vs. 10 d clarithromycin | Time: Not specified Place: Costa Rica, pediatric ambulatory unit Inclusion:; 1. Age: 6 mo-12 yr; 2. AOM; Exclusion:; 1. Perforated TM; 2. PE tubes; 3. Allergic to antibiotic; 4. Antibiotic within 72 hr; 5. Serious underlying disease; 6. Malabsorption | Age: Mean=4,2 yr Otitis prone: Not addressed N=97 total N1=50 3-d N2=47 10-d | Clinical evaluations on 3-5, 10-11, 28-32 d Clinical failure defined as inability to clear initial symptoms or persistent ear drainage by end of therapy
  | 3 d | 10 d
  Clinical Failure
  | 0/50(0%) | 2/47(4%)
  Persistent middle ear effusion
  11-13 d | 35/50 (68%) | 33/47(70%)
  28-30 d | 8/50(16%) | 9/47(19%)
  55-60 d | 0/50(0%) | 0/47(0%)
  Adverse events
  Loose stool | 3/50(6%) | 6/47(13%)
  Rash | 0/50(0%) | 1/47(2%)
  Vomit | 1/50(2%) | 2/47(4%)
  Nausea | 1/50(2%) | 2/47(4%)
Aronovitz 1996 | Randomized open label trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | 5 d azithromycin vs. 10 d amoxicillin-clavulanate | Time: Not specified Place: US, academic multi-centers Inclusion:; 1. Age: 2-15 yr; 2. AOM; Exclusion:; 1. OM persisting>4 wk; 2. No symptoms of AOM; 3. Antibiotic within 72 hr; 4. Long acting antibiotic within 6 wk; 5. Concurrent use of antihistamine; 6. Malabsorption; 7. Allergic to antibiotic; 8. Renal, hepatic, cardiovascular disease | Age: All >2 yrs Otitis prone: Not addressed N=92 total N1=49 short-term N2=43 long-term | Clinical evaluations on d 11, d 30 Failure defined as no apparent response to study drug (no resolution of signs and symptoms or presence of middle ear effusion) Relapse defined as new appearance or worsening of signs and symptoms or for whom antibiotics for middle ear infection were prescribed in secondary visits. | *presumed based on clinical grounds and not on culture results.
  | Short-term | Long-term
  Failure
  D 11 | 6/49(12%) | 0/43 (0%)
  D 30 | 8/45(18%) | 7/35(20%)
  Relapse | 2/39(5%) | 8/38(21%)
  Persistence by pathogen* at 11 d
  S. pneu | 4/29(14%) | 0/26(0%)
  H. flu | 2/11(18%) | 0/9(0%)
  M. cat | 0/7(0%) | 0/5(0%)
  S. pyog | 0/2(0%) | 0/5(0%)
  Persistence by pathogen* at 30 d
  S. pneu | 6/28(21%) | 4/22(18%)
  H. flu | 2/10(20%) | 2/8(25%)
  M. cat | 0/5(0%) | 1/2(50%)
  S. pyog | 0/2(0%) | 0/4(0%)
  Adverse events
  Any | 3/85(4%) | 26/84(31%)
  GI | 3/85(4%) | 25/84(30%)
  Rash | 0/85(0%) | 2/84(2%)
Bain 1985 | Randomized open label trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | 2 d vs. 7 d amoxicillin | Time: Winter 1983, 1984 Place: Unknown, 4 private practices, 16 participating general practitioners Inclusion:; 1. Age: 3-10 yr; 2. AOM; Exclusion:; 1. AOM within 1 mo; 2. Antibiotic within 14 d; 3. Allergic to antibiotic; 4. On other medications | Age: All >2 yr Otitis prone: 75% had prior episode of OM N=243 total N1=125 short N2=118 long | Follow-up home visits within 24 hr, at 7-10 d and 3 wk after entry into study. Signs and symptoms were evaluated independently.
  | 2 d | 7 d
  Presence of signs/symptoms Earache
  D 1 | 118/125(94%) | 106/118(90%)
  D 5 | 13/125(10%) | 11/118(9%)
  D 10 | 7/125(6%) | 6/118(5%)
  Earache at night
  D 1 | 84/125(67%) | 76/118(64%)
  D 5 | 3/125(2%) | 4/118(3%)
  D 10 | 3/125(2%) | 3/118(3%)
  Resolution of eardrum signs at 7 d
  Redness | 12/89(13%) | 8/75(11%)
  Red Rim | 26/62(42%) | 21/54(39%)
  Pink Blush | 28/72(39%) | 20/53(38%)
  Bulged TM | 8/85(9%) | 7/67(10%)
  Ls lt reflex | 29/86(34%) | 27/83(33%)
  Discharge | 1/13(8%) | 2/23(9%)
  Recurrence at 1 yr
  | 42/89(47%) | 34/86(40%)
Barnett 1997 | Randomized single-blind trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Single intramuscular dose of ceftriaxone vs. 10 d oral TMP-SMX | Time: 2/91-4/94 Place: Boston including suburban private practice, neighborhood health center, urban hospital ER and private care clinic Inclusion:; 1. Age: 3 mo-3 yr; 2. AOM; Exclusion:; 1. Antibiotic within 7 d; 2. Anatomic problem; 3. Immunosuppressed; 4. Chronic illness; 5. Allergy; 6. Ever had PE tube; 7. No telephone; 8. Non-English, Portugese, Spanish, French | Age: 3 mo-3 yr Otitis prone: 41% >3 prior episodes. N=484 patients N1=241 ceftriaxone N2=243 TMP-SMX | Noncured or cured/improved rate on d 3, d 14 and d 28 (for total only) Noncured or cured/improved rate on d 14 for subgroups of each influencing factor Adverse events reported on d 3 for total cases. | (Diarrhea was significant at P<0.001)
  Noncured rate
  | Ceftriaxone | TMP-SMX
  D 3 | 18/241(8%) | 12/243(4.9%)
  D 14 | 39/197(20%) | 38/212(18%)
  D 28 | 28/136(21%) | 31/155(20%)
  Noncured rate on D 14
  White | 41/155(26%) | 37/153(24%)
  Black | 10/46(22%) | 6/46(13%)
  Hisp | 4/21(19%) | 5/32(16%)
  Other | 2/19(11%) | 2/12(17%)
  Male | 31/132(23%) | 30/121(25%)
  Fem | 26/109(24%) | 20/122(16%)
  Past AOM
  Yes | 44/180(24%) | 42/183(23%)
  No | 13/61(21%) | 8/60(13%)
  Otitis prone
  Yes | 19/96(20%) | 22/99(22%)
  No | 38/145(26%) | 28/144(19%)
  Day-care
  Yes | 8/52(15%) | 16/56(29%)
  No | 49/189(26%) | 34/187(18%)
  Breastfed
  Yes | 38/148(26%) | 32/152(21%)
  No | 19/93(20%) | 18/91(20%)
  First episode<6 mo
  Yes | 19/83(23%) | 21/81(26%)
  No | 38/158(24%) | 29/162(18%)
  Fever at onset
  Yes | 35/125(28%) | 30/130(23%)
  No | 22/116(19%) | 20/113(18%)
  Ear Discharge at onset
  Yes | 4/13(31%) | 2/14(14%)
  No | 53/228(23%) | 48/229(21%)
  Ear Pain at onset
  Yes | 40/178(22%) | 32/173(18%)
  No | 17/63(27%) | 18/70(21%)
  Vomiting at onset
  Yes | 14/45(31%) | 9/34(26%)
  No | 43/196(22%) | 41/209(20%)
  Lethargy at onset
  Yes | 23/78(29%) | 17/77(22%)
  No | 34/163(21%) | 33/166(20%)
  Irritability at onset
  Yes | 49/209(23%) | 40/202(20%)
  No | 8/32(25%) | 10/41(24%)
  Adverse events on d 3
  Pain at site
  | 10/225(8%) | ----
  Diarrhea
  | 46/195(24%) | 19/207(9%)
  Rash | 21/206(10%) | 14/201(7%)
Bauchner 1996 | Randomized open lantibioticel controlled trial Jadad quality score ^1^ (0-5): 2 [1,0,0,1,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Single intramuscular (IM) ceftriaxone vs. 10 d oral amoxicilli-clavulanate | Time: 10/93-5/94 Place: private practices from 15 sites in U.S. Inclusion:; 1. Age: 3 mo-6 yr; 2. AOM; Exclusion:; 1. Aom within 30 d; 2. Antibiotic within 7 d; 3. PE tubes; 4. Allergic to antibiotic; 5. Anatomic abnormality; 6. Recurrent OM; 7. >4 AOM within 1 yr; 8. >3 AOM within 1 yr in patient under 1 yr; 9. No telephone in household | Age: 34% < 1.5 yr 66%>1.5 yr Otitis prone: (prior episode) 11% >2 25% 1 63% none N=648 total N1=327 IM N2=321 oral | Clinical evaluations and parent satisfaction at 3-5 and 14-16 d Physician summarized resolution of signs of AOM with exception of MEE, as improved, not improved, or worse.
  | Single dose IM | 10 d oral
  Unimproved or worse at 14-16 d
  | 50/267(19%) | 28/271(10%)
  Parent unsatisfied at 14-16 d
  | 21/268(8%) | 29/271(11%)
Boulesteix 1995 (French) | Randomized open Trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Cefpodoxime (8mg/kg/d, BID) 5 d vs. cefixime (8mg/kg/d, BID) 8 d | Time: 9/91-3/92 Place: France, 41 general doctors' offices Inclusion:; 1. Age: 6 mo-6 yr; 2. AOM, presumed bacterial; 3. 7-10 kg; Exclusion:; 1. Allergic to antibiotic; 2. Paracentesis required; 3. Cholesteatoma; 4. Antibiotic within 72 hr; 5. Immunodeficient; 6. Serous OM; 7. >3 AOM episodes in 6 mo or >4 in 12 mo; 8. Chronic renal, hepatic, GI problems; 9. Chronic TM perforation >3 mo; 10. PE tubes | Age: Range: 6 mo-6 yr Otitis prone: 100% not otitis prone (otitis prone subjects were excluded in study). N=245 total N1=124 5 d N2=121 8 d | Clinical outcomes on d 8-10 d Otolaryngologic outcomes on d 30-40 d Not satisfactory defined as treatment failure, relapse and recurrences. Clinical failure defined as persistence signs of OM or serous OM requiring increased duration or change in ab therapy or surgical procedure or intercurrent respiratory infection without OM. Unsatisfactory otolaryngologic defined as recurrence of OM after treatment ended or presented with OM or serous OM needing another antibiotic at 30-40 d visit
  | 5 d | 8 d
  Unsatisfactory at 8-10 d
  | 8/124(6%) | 8/121(7%)
  Unsatisfactory at 30-40 d
  | 25/1 19(21%) | 29/115(25%)
  Intercurren at 30-40 d
  | 8/1 19(7%) | 14/115(12%)
  Relapse at d30-40
  | 7/1 19(6%) | 7/115(6%)
  Side effects
  GI | 7/124(6%) | 8/121(7%)
Chamberlain 1994 | Randomized controlled trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Single-dose ceftriaxone vs. 10 d of cefaclor | Time: Not specified Place: Washington DC; pediatric ambulatory and emergency departments Inclusion:; 1. Age: 18 mo-6 yr; 2. AOM; Exclusion:; 1. Immuno compromised; 2. Allergic to antibiotic; 3. Antibiotic within 10 d; 4. Chronic OM; 5. Other infection; 6. Recurrent OM; 7. >4 AOM/yr; 8. PE tubes; 9. Need for admission; 10. Ruptured TM; 11. No telephone | Age: All >1.5 yr Mean=3 yr Otitis prone: (By exclusion criteria) All <4 AOM/yr Mean episode/yr: 1.4 N=79 total N1=48 single dose N2=31 10 d | Clinical evaluations at 2-3, 7-10 d, 3-4 wk for 90 d Failure defined as persistence of ear pain or fever for more than 48 hr Recurrence of ear pain or fever with clinical signs of AOM classified as early if <14 d, late if <15-90 d Persistent effusion defined as type B tympanogram and persistent serous effusion, without recurrent pain or inflammation.
  | 1 dose | 10 d
  Failure within 14 d
  | 0/48(0%) | 0/31(0%)
  Recurrence <14 d
  | 0/48(0%) | 0/31(0%)
  Recurrence at 90 d
  Total | 10/48(21%) | 7/31(23%)
  Persistent effusion within 90 d
  Total | 12/48(25%) | 9/31(29%)
Chaput de Saintonge 1982 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 4 [1,1,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | 3 vs. 10 d amoxicillin | Time: winters of 1979 and 1980 Place: London, 17 general practitioners from 5 health centers Inclusion:; 1. Age: 2-10 yr; 2. Acute painful condition of the middle ear and for which antibiotics given; Exclusion:; 1. Chronic ear disease; 2. >1 AOM in prior yr; 3. No AOM within1 mo; 4. Onset>1 wk; 5. Acute exanthemata; 6. Serious illness; 7. Allergic to antibiotic; 8. No serious prior medical problem | Age: All >2 yr Otitis prone: All not otitis prone (those with >1 AOM in prior yr excluded) N=70 total N1=35 3 d N2=35 10 d | Clinical evaluations on day 3 and d 15 Failure defined as those whose rate of recovery was considered unsatisfactory by the general practitioner and who were consequently prescribed additional antibiotics on an open basis.
  | 3 d | 10 d
  Failure 15 d
  | 5/42(12%) | 3/42(7%)
  Blocked nose
  D 0 | 30/42(71%) | 33/42(78%)
  D 3 | 21/42(50%) | 21/42(50%)
  D 15 | 11/42(27%) | 5/42(13%)
  Cough
  D 0 | 31/42(73%) | 31/42(74%)
  D 3 | 21/42(50%) | 24/42(58%)
  D 15 | 10/42(24%) | 10/42(10%)
  Hearing loss
  D 0 | 10/42(24%) | 7/42(17%)
  D 3 | 3/42(7%) | 7/42(17%)
  D 15 | 3/42(7%) | 2/42(5%)
  Ear pain
  D 0 | 22/42(52%) | 23/42(54%)
  D 3 | 3/42(7%) | 2/42(5%)
  D 15 | 1/42(2%) | 0/42(0%)
  Discharge
  D 0 | 1/42(2%) | 1/42(2%)
  D 3 | 0/42(0%) | 0/42(0%)
  D 15 | 0/42(0%) | 0/42(0%)
  Red drum
  D 0 | 23/42(54%) | 27/42(64%)
  D 3 | 15/42(35%) | 15/42(15%)
  D 15 | 3/42(7%) | 8/42(19%)
  Dullness(loss of light reflex)
  D 0 | 19/42(46%) | 24/42(58%)
  D 3 | 11/42(26%) | 14/42(33%)
  D 15 | 1/42(2%) | 8/42(19%)
  Bulging drum
  D 0 | 11/42(26%) | 12/42(29%)
  D 3 | 3/42(7%) | 1/42(2%)
  D 15 | 0/42(0%) | 0/42(0%)
  (Based on intent to treat analysis)
Cohen 1997 (Same study as 2325) | Randomized open trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Cefpodoxime (8mg/kg/d, bid) 5 d vs. amoxicillin/clavulanate (80mg/kg/d, tid) 8 d | Time: 10/93-3/94 Place: 23 French private practice pediatricians Inclusion:; 1. Age: 4 mo-4.5 yr; 2. AOM; Exclusion:; 1. Antibiotic within 7 d; 2. Allergic to antibiotic; 3. Severe underlying disease; 4. In previous studies; 5. No bacteriologic sample before or after treatment; 6. Spontaneous TM perforation with drainage | Age: 75% <2 yr 25% >2 yr Otitis prone: 25% recurrent AOM 75% nonrecurrent. N=400 total N1=N2=200 | Clinical evaluations at d 4 and 1 mo after end of therapy Failure defined as persistence or increase of classic symptoms or otoscopic findings during course of treatment or at d 4 visit or prescription of new antibiotic or paracentesis or increased duration of treatment
  | 5 d | 8 d
  Persistence of pathogens
  S. pneu | 57/97(59%) | 37/104(36%)
  H. influ | 49/72(68%) | 67/75(89%)
  Failure at d 4 posttreatment
  | 26/186(14%) | 31/184(17%)
  Failure at d 17
  | 31/197(16%) | 35/196(18%)
  Serous om at 1 mo posttreatment
  | 23/140(16%) | 28/137(20%)
  New AOM at 1 mo posttreatment
  | 34/140(24%) | 25/137(18%)
Cohen 1998 | Randomized double-blind Trial Jadad quality score ^1^ (0-5): 5 [1,1,1,1,1] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | 5 d vs. 10 d amoxicillin/clavulanate (80mg/10mg/kg/d, TID) | Time: 11/94-6/96 Place: France, 24 pediatricians, setting not specified Inclusion:; 1. 4 mo-2.5 yr included but no age criterion stated; 2. AOM; Exclusion:; 1. Antibiotic within 7 d; 2. Allergic to antibiotic; 3. Significant underlying disease; 4. PE tubes; 5. Previously in study; 6. Otorrhea; 7. Ruptured TM | Age: All under 2.5 yr Mean=1.1 yr Otitis prone: (prior episode in 6 mo) 9% >3 episode 11% 2 episode 23% 1 episode 57% 0 episode N=382 total N1=194 5 d N2=188 10 d | Clinical outcomes from d 0 to d 12-14 and at d 28-42. Failure defined as fever, otalgia, or irritability worsened or recurred, together with otoscopic signs of AOM; spontaneous otorrhea and/or complication of AOM; underwent tympanocentesis; given antibiotic other than study drug Relapse defined as reappearance of signs and symptoms during treatment or within 4 d of therapy end Recurrence defined as reappearance of signs and symptoms after 4 d of treatment end
  | 5 d | 10 d
  Failure, d 12-14
  | 38/163(23%) | 20/168(12%)
  Relapse/recurrence at d 28-42
  | 20/141(14%) | 28/139(20%)
  Adverse events-all types
  | 88/194(45%) | 80/188(43%)
  Adverse events-(drug related)
  | 60/194(31%) | 55/188(29%)
Daniel 1993 | Randomized open label trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Single dose azithromycin vs. 10 d co-amoxicillin/clavulanate | Time: Not specified Place: European multicenter study, setting not specified Inclusion:; 1. Age: 2-8 yr; 2. AOM; Exclusion; 1. Allergic to antibiotic; 2. GI disorder; 3. Chronic OM; 4. Mononucleosis; 5. Life threatening condition | Age: 1% (only 1 case) <2 yr 99% >2 yr Otitis prone; Not addressed N=159 total N1=105 1 dose N2=54 10 d | Cured, improved, failed at 3-5, 10-12, and 35 d Failure defined as no apparent clinical response Adverse effects
  | Single dose | 10 d
  Failure
  3-5 d | 5/103(5%) | 1/54(2%)
  10-12 d | 6/103(6%) | 0/54(0%)
  Adverse effects
  Total | 8/103(8%) | 2/54(4%)
  GI | 8/103(8%) | 0/54 (0%)
  Rash | 3/103(3%) | 2/54(4%)
Gooch 1996 | Randomized single-blind trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | 5 vs. 10 d cefuroxime vs. 10 d amoxicillin/clavulanate | Time: Not specified Place: 20 centers in U.S, setting not specified Inclusion:; 1. Age: 3 mo-12 yr; 2. AOM; Exclusion:; 1. Ruptured TM; 2. PE tube; 3. Allergic to antibiotic; 4. Malabsorption; 5. Antibiotic within 72 hr; 6. Renal impairment; 7. Craniofacial abnormality; 8. Serious underlying disease; 9. Immunodeficient | Age: Mean=3.5 yr Otitis prone: 84% had prior episode; 84% had episode within 1 yr; 16% no prior episode N=719 total N1=242 5 d N2=235 10 d N3=242 10 d amoxicillin/clavulanate | Clinical evaluations at 3-5 d of treatment, 1-4 d posttreatment; and at 14-18 d posttreatment Failure defined as no apparent response to treatment or worsening after 3 d or more of therapy Recurrence defined as resolution or improvement of clinical signs and symptoms at 1-4 d posttreatment visit, with recurrence of clinical symptoms by the 14-18 d visit
  5 d Cefuroxime | 10 d Cefuroxime | 10 d Amoxicillin
  Clinical Failure
  26/147 (18%) | 32/173 (18%) | 17/177 (10%)
  Recurrence
  20/147 (14%) | 20/173 (12%) | 29/177 (16%)
  Bacteriological Failure
  2/26 (8%) | 3/38 (8%) | 2/38 (5%)
  Adverse events
  Any
  48/242 (20%) | 37/235 (16%) | 89/242 (37%)
  GI
  41/242 (17%) | 29/235 (12%) | 82/242 (34%)
  Diarrhea
  28/242 (12%) | 18/235 (8%) | 73/242 (30%)
  Vomit
  16/242 (7%) | 9/235 (4%) | 9/242 (4%)
Green 1993 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 4 [1,1,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [0,0,1] | Single-dose intramuscular ceftriaxone vs. 10 d amoxicillin | Time: 9/90-6/91 Place: California, emergency department at county or university hospital Inclusion:; 1. Age: 5 mo-5 yr; 2. AOM; Exclusion:; 1. Antibiotic in prior 14 d; 2. AOM in last month; 3. Chronic OM; 4. PE tubes; 5. Bleeding dyscrasia; 6. Serious underlying illness; 7. concurrent infection; 8. Scarred/perforated TM; 9. Allergic to antibiotic; 10. Unable to return for followup | Age: Range: 5 mo-5 yr Mean:1.8 yr Otitis prone: 18% 3+ prior episodes; 30% 2+ prior episodes. N=233 total N1=117 amoxicillin N2=116 ceftriaxone N=233 total N1=117 amoxicillin N2=116 ceftriaxone | Treatment success/failure relapse, and reinfection at 14 and 60 d Unsuccessful defined as no resolution of AOM symptoms or return to ER within 10 d for AOM symptoms. Included both failure or complication
  | Ceftriaxone | Amoxicillin
  Unsuccessful at 10 d
  | 11/105(10%) | 10/107(9%)
  Complication at 10 d
  | 5/105(5%) | 7/107(7%)
  Failure at 10 d
  | 6/105(6%) | 3/107(3%)
  Abnormal otoscopic finding
  14 d | 17/48(35%) | 19/56(34%)
  60 d | 8/48(17%) | 12/56(21%)
  Abnormal tympanometric findings
  14 d | 27/47(57%) | 26/55(47%)
  60 d | 18/47(38%) | 24/55(44%)
  Recurrence in 60 d
  | 44/116(38%) | 45/117(38%)
  Reinfection in 31-90 d
  | 12/116(10%) | 21/117(18%)
  Relapse in 11-30 d
  | 19/116(16%) | 13/117(11%)
Hendrickse 1988 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 5 [1,1,1,1,1] Number of components addressed in defining AOM2 (0-3): 2 [1,0,1] | 5 d vs. 10 d cefaclor followed by 5 d of placebo | Time: Not specified Place: U.S. pediatricians, setting not specified Inclusion:; 1. Age: 1 mo-12 yr; 2. AOM; 3. Wt <30 kg; Exclusion:; 1. Craniofacial abnormality; 2. Allergic to antibiotic; 3. antibiotic within 2 wk; 4. Concurrent infection; 5. Spontaneous perforation of TM>24 hr; 6. Likely not return to followup | Age: 53% <2 yr 47% >2 yr Otitis prone: 20% prone* 80% not prone *3+ episodes in preceding 6 mo or >=4 episodes in preceding 12 mo N=151 patients N1=74 5 d N2=77 10 d | Clinical and bacteriologic evaluations at 5-6, 10, 30, 60 and 90 d Clinical failure defined as inantibioticility to clear fever, pain or drainage by 5 d Bacteriologic failure defined as inability to sterilize the middle ear fluid Relapse defined as infection with the same pathogen within 3 d of discontinuing medication Reinfection defined as infection more than 3 d after completion of treament of first episode
  | 5-d | 10-d
  Failure - TM Intact group
  <=5 d | 4/59(7%) | 2/64(3%)
  6-10 d | 2/55(4%) | 2/62(3%)
  Relapse - TM Intact group
  3 d | 0/53(0%) | 1/60(2%)
  Reinfection - TM intact group
  14-30 d | 4/41(10%) | 6/49(12%)
  31-60 d | 4/35(11%) | 4/45(9%)
  61-90 d | 2/33(6%) | 3/42(7%)
  Persistent MEE - TM intact group
  10-15 d | 37/55(67%) | 48/60(80%)
  30 d | 16/41(39%) | 18/49(37%)
  60 d | 10/35(29%) | 13/45(29%)
  90 d | 7/33(21%) | 10/42(24%)
  Failure - Spontaneous TM perforation group
  <=5 d | 2/15(13%) | 0/13(0%)
  6-10 d | 6/13(46%) | 1/13(8%)
  Relapse - Spontaneous TM perforation group
  3 d | 0/7(0%) | 0/12(0%)
  Reinfection - Spontaneous TM perforation group
  14-30 d | 2/7(29%) | 3/11(27%)
  31-60 d | 0/6(0%) | 2/8(25%)
  61-90 d | 0/5(0%) | 1/7(14%)
  Persistent MEE - Spontaneous TM perforation group
  10-15 d | 3/13(23%) | 7/13(54%)
  30 d | 2/7(29%) | 3/11(27%)
  60 d | 2/6(33%) | 1/8(12%)
  90 d | 1/5(20%) | 1/7(14%)
Hoberman 1997 | Randomized trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Amoxicillin/clavulanate BID × 5 d vs. amoxicillin/clavulanate BID × 10 d vs. amoxicillin/clavulanate TID × 10 d | Time: 1/94-7/94 Place: U.S. and Canada, 4 university-affiliated hospitals and 20 private practices Inclusion:; 1. Age: 2 mo-12 yr; 2. AOM; Exclusion:; 1. Craniofacial abnormality; 2. Serious underlying illness; 3. Concurrent infection; 4. Allergic to antibiotic; 5. PKU; 6. Antibiotic within 1 wk; 7. Previously in study; 8. On medications that alter bowel movement | Age: 39% <2 yr 62% >2 yr Otitis prone: Not addressed. N=868 N1=189 TID 10 d N2=178 BID 10 d N3=197 BID 5 d | Success or failure; presence of MEE at d 12-14 and at 32-38 Clinical failure defined as persistent signs/symptoms after >2 d of therapy and requiring additional ar alternative antimicrobial therapy (included unable to determine cases) Recurrence defined as completely resolved at end of hterapy, but recurred or worsened thereafter and additional antimicrobial therapy needed
  | 5 d BID | 10 d BID | 10 d TID
  Clinical Failure 12-14 d
  | 57/197 (29%) | 4/178 (13%) | 40/189 (21%)
  Recurrence at 32-38 d
  | 16/161 (10%) | 32/149 (22%) | 21/148 (14%)
  Adverse effects (intent-to-treat est.)
  D. rash | 15/293 (5%) | 23/287 (8%) | 30/288 (10%)
  Vomit | 21/293 (7%) | 29/287 (10%) | 31/288 (11%)
  Diarrhea | 18/293 (6%) | 15/287 (5%) | 28/288 (10%)
  For <2 yrs, clinically cured/improved^1^
  12-14 d | 47/76 (62%) | 61/72 (85%) | ------
  32-38 d | 21/55 (38%) | 37/61 (61%) | ------
  For 2-5 yr, clinically cured/improved^3^
  12-14 d | 60/85 (71%) | 64/75 (85%) | ------
  32-38 d | 47/76 (62%) | 38/62 (61%) | ------
Ingvarsson 1982 | Randomized trial Jadad quality score ^1^ (0-5): 1 [1,0,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | 5 d twice normal dose vs. 10 d normal dose of Penicillin V | Time: Period 1: 10/76-12/76; Period 2: 2/77-4/77 Place: Sweden, ENT department of hospital Inclusion:; 1. Age: 6 mo-7 yr; 2. AOM; Exclusion:; 1. Antibiotic within 30 d | Age: 24% <2 yr 76% >2 yr Otitis prone: Not addressed. N=297 patients N1=148 5 d N2=149 10 d | Normal mobility of TM; relapse; failure to respond at 10-12 d and 28-30 d Not healed defined as eardrums showed serous OM or relapses or therapeutic failure. Therapeutic failure defined as insufficient effect of therapy or a new attack of otitis during antibiotic therapy.
  | 5 d Penicillin V | 10 d Penicillin V
  Not healed 28-30 ds
  Total | 31/148(21%) | 35/149(23%)
  <2 yr | 7/28(25%) | 14/43(33%)
  >2 yr | 24/120(20%) | 21/106(20%)
  Serous OM 28-30 d
  | 18/148(12%) | 24/149(16%)
  Relapse 28-30 d
  | 10/148(7%) | 8/149(5%)
  Therapeutic failure
  | 3/148(2%) | 3/149(2%)
  New attack of otitis within 6 mo
  | 40/148(27%) | 39/149(26%)
Jones 1986 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 4 [1,1,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | 3 vs. 7 d cefaclor | Time: winters of 1983-4, 1984-5 Place: Southampton, 14 general practitioners, four health centers Inclusion:; 1. Age: 3-10 yr; 2. A clinical syndrome recognized as OM for which antibiotic treatment was appropriate; Exclusion:; 1. Antibiotic within 2 wk; 2. Allergic to antibiotic | Age: All >2 yr Mean=5.7 yr Otitis prone: 77% had HX of OM 23% none N=96 N1=45 3 d N2=51 7 d | Resolution of ear signs 1 wk and 6 wk posttreatment
  | 3-d | 7-d
  No resolution of ear signs at 1 wk
  Redness | 1/26(3%) | 6/27(22%)
  Bulging | 0/21(0%) | 1/19(5%)
  Indrawn | 3/9(33%) | 2/5(50%)
  Loss reflex | 12/33(36%) | 14/34(41%)
  Pink blush | 1/15(73%) | 7/12(58%)
  Red rim | 5/15(33%) | 11/11(100%)
  Perforation | 1/6(17%) | 0/2(0%)
  Discharge | 0/6(0%) | 3/7(43%)
  Mean(±SD) d
  Earache | 1.80±1.68 | 2.49±1.89
  Nasal
  Discharge | 3.57±2.60 | 3.73±2.46
  Cough | 2.87±2.54 | 3.23±2.83
  Crying | 0.67±1.16 | 0.53±0.83
  Mean (±SD) time analgesia used
  | 1.64±1.97 | 1.50±1.71
Kafetzis 1997 | Randomized comparative trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [0,0,1] | 5 d vs. 10 d course of cefprozil | Time: not specified Place: 26 pediatricians in 10 Greek towns Inclusion:; 1. Age: 2 mo-14.3 yr; 2. AOM; 3. >38 degrees centigrade; Exclusion:; 1. Antibiotic within 2 wk; 2. Complication of OM; 3. Chronic OM; 4. Underlying disease; 5. Perforated TM | Age: Mean=4.1 yr Otitis prone: (prior episodes) 3% >2 episodes 6% 2 episodes 24% 1 episodes 66% 0 episodes N=560 total N1=286 5-d N2=264 10-d | Clinical evaluations at 2-3 d, 7-14 d and 28-32 d Failure defined as persistence or worsening of signs and symptoms of infection Relapse defined as resolution of signs and symptoms of infection followed by reappearance of signs and symptoms of same infection in same ear during the 32-d followup period after end of therapy
  | 5-d | 10-d
  Failure at 28-32 d
  | 12./249(5%) | 5/250(2%)
  Relapse after end of therapy
  | 4/249(2%) | 5/250(2%)
  Adverse reaction at 28-32 d
  Total | 26/249(10%) | 22/250(9%)
  Adverse events at end of Rx
  AbdominalPain
  | 3/249(1%) | 4/250(2%)
  Vomit
  | 6/249(2%) | 6/250(2%)
  Nausea
  | 1/249(0%) | 1/250(0%)
  Diarrhea
  | 11/249(4%) | 8/250(3%)
  Rash
  | 6/249(2%) | 2/250(1%)
  Itch
  | 0/249(0%) | 2/250(1%)
Kara 1998 | Randomized controlled trial Jadad quality score ^1^ (0-5): 1 [1,0,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Amoxicillin (40mg/kg/d, TID, 10 d) vs. cefuroxime axetil (30mg/kg/d, BID, 10 d) vs. ceftriaxone (50mg/kg/single dose, IM) | Time: 9/97-5/97 Place: Turkey, ENT, pediatric and infectious disease clinics Inclusion:; 1. Age: 6 mo-6 yr; 2. AOM; Exclusion:; 1. AOM within 3 mo; 2. Antibiotic within 2 wk; 3. Allergic to antibiotic | Age: 6 mo-6 yr Otitis prone: Not addressed N=75 25 per group | Clinical evaluation at 3, 10, 30 d after therapy Treatment failure defined as no resolution of symptoms and clinical and tympanometric appearance of TM
  Cefurotime | Ceftriaxone | Amoxicillin
  Failure at d 5
  2/25 | 4/25 | 2/25
  (8%) | (16%) | (8%)
  Rash/loose stool
  0/25 | 0/25 | 2/25
  (0%) | (0%) | (8%)
Khurana 1996 | Randomized open label trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Once daily for 5 d azithromycin vs. TID 10 d amoxicillin-clavulanate | Time: not specified Place: Multicenters in U.S., setting not specified Inclusion:; 1. Age: 6 mo-12 yr; 2. AOM; 3. Attend school or day-care >20 hr/wk; 4. >10 lbs; Exclusion:; 1. Chronic OM; 2. Allergic to antibiotic; 3. Antibiotic within 14 d; 4. Long-acting PCN within 4 wks; 5. Investigational drug within 4 wk; 6. Malabsorption; 7. Mononucleosis | Age: Mean=5.6 yr 53%<5 yr 47%>5 yr Otitis prone: (# episodes past 12 mo) 3% >5 episodes 12% 3-5 episodes 38% 1-2 episodes 46% 0 episodes N=526 total N1=263 short-term N2=263 long-term | Clinical evaluations at 3, 14, 30 and 45 d after therapy Failure defined as no significant response before d 3 Relapse defined as complete or partial response at d 3, with subsequent deterioration at or before d 14 Recurrence defined as complet or partial response at d 3, with subsequent deterioration after d 14
  | Short-term | Long-term
  D 45 evaluations
  Failure
  10/233(4%) | 10/211(5%)
  Relapse
  23/233(10%) | 19/211(9%)
  Recur
  59/233(25%) | 45/211(21%)
  Unsatisfactory (total of above)
  92/233(39%) | 74/211(35%)
  Adverse events
  Any
  19/263(7%) | 45/260(17%)
  GI-all
  16/263(6%) | 39/260(15%)
  Diarrhea
  3/263(1%) | 25/260(10%)
  Loose stool
  3/263(1%) | 4/260(2%)
  Vomit
  5/263(2%) | 8/260(3%)
  Nausea
  3/263(1%) | 5/260(2%)
  Abdominal pain
  4/263(1%) | 3/260(1%)
Leigh 1989 | Randomized open label trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Oral cephalosporin, cefixime vs. amoxicillin | Time: Not specified Place: Gosport, (UK?), general practice setting Inclusion:; 1. Age: 6 mo-16 yr; 2. AOM; Exclusion:; 1. Allergic to antibiotic; 2. Antibiotic within 5 d; 3. Renal or hepatic DZ; 4. Other infection; 5. Diabetes; 6. Chronic OM; 7. Mastoiditis | Age: Mean=4.9 yr Otitis prone: Not addressed N=325 total N1=160 cefixime N2=165 amoxicillin | Clinical evaluation in terms of cured, improved, failed at 10-14 d after initiation of treatment Clinical failure was classed as no response to therapy judged by physician Adverse effects at 2-3 d and 10-14 d
  | Cefixime | Amoxicillin
  Failure at 10-14 d
  | 7/150 (5%) | 8/150 (5%)
  Adverse reactions
  Total | 26/150(17%) | 11/150(&%)
  GI sym | 21/150(4%) | 7/150(5%)
  Diarrhea | 19/150(13%) | 5/150(3%)
  Rash | 1/150(1%) | 3/150(2%)
  Vomit | 2/150(1%) | 0/150(0%)
McLinn 1996 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 4 [1,1,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Azithromycin once daily for 5 d vs. amoxicillin-clavulanate TID for 10 d | Time: not specified Place: 12 medical centers in U.S., private practice and academic centers Inclusion:; 1. Age: 1-15 yr; 2. AOM; 3. Intact eardrums; 4. >10kg; Exclusion:; 1. Perforated TM; 2. Chronic OM; 3. No symptoms; 4. Antibiotic within 14 d; 5. Long acting PCN within 6 wk; 6. TX with carbamazepine, ergotamine or digitalis; 7. Malabsorption; 8. Mononucleosis; 9. Renal, hepatic,heart disease; 10. Pregnant | Age: Range: 1-15 yr Otitis prone: Not addressed N=677 N1=341 short-term N2=336 long-term | Clinical evaluations at entry, d 4, 11, 18, and 30 Failure defined as no change or worsening of signs or symptoms from baseline or necessity for further antibiotic therapy or discontinuation of study drug due to side effects Relapse defined as satisfactory clinical response at d 11 with return of signs or symptoms or required additional antibiotic therapy d 15-30
  | Short-term | Long-term
  Failure
  D 11 | 35/280(12%) | 33/273(12%)
  D 30 | 70/264(27%) | 74/257(29%)
  Side effects
  Any | 30/340(9%) | 103/334(31%)
  Skin | 1/340(0%) | 8/334(2%)
  CNS | 4/340(1%) | 4/334(1%)
  GI-all | 27/340(8%) | 96/334(29%)
  Diarrhea
  | 8/340(2%) | 54/334(16%)
  Abdomial pain
  | 7/340(2%) | 15/334(4%)
  Loose stool
  | 6/340(2%) | 14/334(4%)
  Vomit | 5/340(1.5%) | 23/334(7%)
  Nausea | 2/340(1%) | 9/334(3%)
  Clinically significant, possible treatment-related lab test abnormality
  Any | 18/305(6%) | 21/321(7%)
  Liver | 4/305(1%) | 3/321(1%)
  Dec WBC | 4/305(1%) | 2/321(1%)
  Inc WBC | 0/305(0%) | 1/321(0%)
  Dec RBC | 0/305(0%) | 1/321(0%)
  Inc Eos | 2/305(1%) | 2/321(1%)
  Dec Neut | 8/305(3%) | 11/321(3%)
  Dec Gluc | 0/305(0%) | 1/321(0%)
  Dec Hem | 0/305(0%) | 1/321(0%)
Meistrup-Larsen 1983 | Randomized Double-blind controlled trial Jadad quality score ^1^ (0-5): 3 [1,1,0,0,1] Number of components addressed in defining AOM ^2^ (0-3): 2 [0,1,1] | 2 vs. 7 d penicillin therapy | Time: 11/80-5/81 Place: Copenhagen, Denmark, initially general practice home visits Inclusion:; 1. Age: 1-10 yr; 2. AOM; 3. Earache for 1-48 hr; Exclusion:; 1. ASA but no other RX; 2. Antibiotic within 1 mo; 3. AOM within 1 mo; 4. Chronic OM; 5. Secretory OM within 1 yr; 6. Concurrent infection; 7. Allergic to antibiotic | Age: Mean=4.5 yr Otitis prone: Not addressed. N=95 total N1=46 short-term N2=49 long-term | Clinical evaluations at 1-2 d, 3-7 d, and 8-14 d Satisfactory course:; 1. Not crying from pain after d 1; 2. Analgesics unnecessary after d 1; 3. No otitis symptoms after d 2; 4. Otorrhea<6 d; 5. No contralateral otitis during 1^st^ wk
  | Short-term | Long-term
  Unsatisfactory d 14
  | 13/46(28%) | 7/49(14%)
  Contralateral otitis
  D 1-2 | 6/45(13%) | 2/48(4%)
  D 3-7 | 2/45(4%) | 5/48(10%)
  D 8-14 | 1/45(2%) | 1/48(2%)
  Myringotomy
  D 1-2 | 0/45(0%) | 1/48(2%)
  D 3-7 | 0/45(0%) | 1/48(2%)
  D 8-14 | 0/45(0%) | 0/48(2%)
  Spontaneous perforation
  D 1-2 | 6/45(13%) | 0/48(0%)
  D 3-7 | 2/45(4%) | 2/48(4%)
  D 8-14 | 1/45(2%) | 1/48(2%)
  Required amoxicillin after 1^st^ wk
  | 4/45(9%) | 2/48(4%)
  Relapse
  | 5/45(11%) | 3/48(6%)
  Abnormal tympanogram at d 14
  | 9/38(24%) | 9/39(23%)
Pestalozza 1992 | Randomized trial Jadad quality score ^1^ (0-5): 1 [1,0,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [0,0,1] | Once daily for 3 d azithromycin vs. BID 10 d amoxycillin/clavulanic acid | Time: Not specified Place: Italy, d hospital or outpatient Inclusion:; 1. Age: 11 mo-9 yr; 2. AOM; Exclusion:; 1. Sensitive to macrolides or beta-lactams; 2. Antibiotic within 1 mo | Age: Mean=3 yr Otitis prone: Not addressed N=30 total N1=15 short-term N2=15 long-term | Clinical outcome (cured vs. improved vs. failed) on d 3-5, d 12-14 and d 30.
  | Short-term | Long-term
  [no failures in either group at all time points]
  Not cured (improved only)
  3-5 d | 11/15(73%) | 15/15(100%)
  12-14 d | 1/15(7%) | 9/15(60%)
  30 d | 1/15(7%) | 2/15(13%)
Ploussard 1984 | Randomized open label trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | Oral doses of cefaclor, 40mg/kg/d for 5 d vs. Oral doses of amoxicillin, 40mg/kg/d for 10 d | Time: not specified Place: not specified Inclusion:; 1. 5 mo-5 yr; 2. AOM; Exclusion:; 1. Allergy; 2. Renal disease; 3. Hepatic disease; 4. Significant underlying disease; 5. Antibiotic within 3 d; 6. Concurrent infection; 7. B strep, group A | Age: 84% <2 yr 16% >2 yr Otitis prone: Not addressed N=60 N1=30 N2=30 | Unsatisfactory clinical outcome defined as no improvement of signs and symptoms, after d 3 of therapy Recurrence: signs and symptoms returned within 16 d after therapy end
  | Cefaclor | Amoxicillin
  Overall unsatisfactory outcome
  | 0/27 (0%) | 4/29 (14%)
  Recurrence
  | 2/27 (7%) | 0/29 (0%)
  Unsatisfactory outcome by pathogen
  S. pneumoniae
  | 0/14(0%) | 0/13 (0%)
  H.Flu
  | 0/3 (0%) | 0/3 (0%)
  Sterile culture
  | 0/3 (0%) | 0/5 (0%)
Principi 1995 | Randomized open label trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [0,0,1] | Once-daily for 3 d azithromycin vs. tid for 10 d amoxicillin/clavulanic acid | Time: not specified Place: 8 countries: Brazil, Chile, Germany, Italy, Korea, Spain, Turkey and Venezuela; inpatient or outpatient. Inclusion:; 1. Age: 6 mo-12 yr; 2. Acute or recurrent OM; Exclusion:; 1. Terminal illness; 2. Antibiotic within 2 wk; 3. Prior RX with azithromycin; 4. Allergic to antibiotic; 5. Concurrent infection; 6. Concurrent ergotamine, carbamazepine or digitalis | Age: 25% <2 yr 75% >2 yr Otitis prone: 10% recurrent episode 90% acute episode N=413 total N1=215 short-term N2=198 long-term | Cured, improved, failed and relapsed at 10-14 d Failed defined as no change or worsening of pretreatment signs and symptoms Bacteriological responses
  | Short-term | Long-term
  Failed at 10-14 d, AOM subjects
  | 16/203(8%) | 11/182(6%)
  Failed at 10-14 d, Recurrent subjects
  | 0/12 (0%) | 1/16 (6%)
  Failed at 10-14 d all subjects
  Total | 16/215(7%) | 12/198(6%)
  <2 yr | 11/61(18%) | 5/49(10%)
  >=2 yr | 5/154(3%) | 7/149(5%)
  no perf TM | 11/185(6%) | 8/174(5%)
  perf TM | 2/27(7%) | 2/22(9%)
  Not cured (failed+improved) at 10-14 d
  Total | 32/215(15%) | 53/198(27%)
  <2 yr | 15/61(25%) | 19/49(39%)
  >=2 yr | 17/154(11%) | 34/149(23%)
  Persistence of pathogens
  Total | 2/31 (6%) | 1/26 (4%)
  Patients experiencing adverse effects
  Total | 14/243 (6%) | 20/204 (10%)
  <2 yr | 2/64 (3%) | 4/58(7%)
  >=2 yr | 12/179 (7%) | 16/146(11%)
  Adverse effects
  GI | 11/243(5%) | 24/140(10%)
  Diarrhea | 4/243(2%) | 13/240(5%)
  Vomit | 2/243(1%) | 7/240(3%)
  Rash | 1/243(.4%) | 1/240(.4%)
Puczynski 1987 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 3 [1,1,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Single dose of amoxicillin (100mg/kg) followed by 10 d placebo vs. first dose placebo followed by 10 d amoxicillin (4/mg/kg/d, tid) | Time: 5/84-2/85 Place: Chicago; setting not specified Inclusion:; 1. Age : >2 yrs (upper limit not specified); 2. AOM; Exclusion:; 1. Allergic to antibiotic; 2. Antibiotic within 21 d; 3. Perforation of TM; 4. AOM within 1 wk; 5. Chronic OM; 6. Concurrent infection | Age: 100% >2 yr Otitis prone: Not addressed N=17 total N1=10 long-term N2=7 single dose | Clinical assessment at 48-72 hr, 10-14 d Failure defined as no clinical improvement at 48-72 hr and changed antibiotic therapy
  | Single dose | Long-term
  Failures | 3/7(43%) | 0/10(0%)
Rodriguez 1996 | Randomized open label trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Azithromycin (once daily for 3 d) vs. cefaclor (TID for 10 d) | Time: Not specified Place: Guatemala; setting not specified Inclusion:; 1. Age: 6 mo-13 yr; 2. AOM; Exclusion:; 1. Chronic OM; 2. Perforated TM; 3. Terminal illness; 4. Malabsorption; 5. Concurrent infection; 6. Cytochrome p450 medication; 7. Allergic to antibiotic; 8. Antibiotic within 72 hr; 9. Investigational drug within 1 mo | Age: Mean=4 yr Otitis prone: Not addressed. N=259 total N1=125 short-term N2=134 long-term | Clinical response at d 10-14 and at 25-30 (optional). Failure defined as no disappearance or worsening of pretreatment signs and symptoms
  | Short-term | Long-term
  Failure at 10-14 d
  10-14 d | 2/114(2%) | 4/120(3%)
  25-30 d | 1/32(3%) | 5/36(14%)
  Adverse effects at 10-14 d
  Diarrhea | 1/125(1%) | 7/134(5%)
  Nausea | 3/125(2%) | 0/134(0%)
  Abd Pain
  | 1/125(1%) | 0/134(0%)
  Enteritis | 1/125(1%) | 0/134(0%)
  Rash | 0/125(0%) | 1/134(1%)
  Total | 6/125(5%) | 8/134(6%)
Rubenstein 1965 | Randomized open study Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Gp1: Bicillin (=benzathine PCN G plus procaine PCN G plus potassium PCN G) Gp2: Bicillin+pseudoephedrine Gp3: Bicillin+triple sulfonamide Gp4: Bicillin+triple sulfonamide+pseudoephedrine Gp5: Tetracycline Gp6: Tetracycline+ pseudoephedrine | Time: 11/63-4/64 Place: Pediatric outpatient clinic at Mayo, Rochester, MN Inclusion:; 1. Age: <15 yr (lower limit not specified); 2. AOM; Exclusion:; 1. History of drug reaction; 2. Viral exanthem; 3. Chronic OM; 4. Secretory otitis | Age: 48% <2 yr 52% >2 yr Otitis prone: Not addressed. N=462 evaluable N1=79 N2=77 N3=79 N4=70 N5=78 N6=79 | Clinical outcomes at 2 wk exam or contacted by phone or letter Failure defined as signs and symptoms of AOM persisted sufficiently to require a change in antimicrobial regimen within 2 wks after initiation of therapy
  Failure at 2 wk
  Gp1 | Gp2 | Gp3 | Gp4 | Gp5 | Gp6
  4/79 | 5/77 | 1/79 | 3/70 | 10/78 | 6/79
  (5%) | (7%) | (1%) | (4%) | (13%) | (8%)
  Adverse reactions
  Total
  0/79 | 0/77 | 3/79 | 0/70 | 7/78 | 0/79
  (0%) | (0%) | (4%) | (0%) | (9%) | (0%)
  Diarrhea
  0/79 | 0/77 | 1/79 | 0/70 | 5/78 | 0/79
  (0%) | (0%) | (1%) | (0%) | (6%) | (0%)
  Vomiting
  0/79 | 0/77 | 0/79 | 0/70 | 1/78 | 0/79
  (0%) | (0%) | (0%) | (0%) | (1%) | (0%)
  Rash
  0/79 | 0/77 | 2/79 | 0/70 | 1/78 | 0/79
  (0%) | (0%) | (3%) | (0%) | (1%) | (0%)
Schaad 1993 | Randomized trial Jadad quality score ^1^ (0-5): 2 [1,0,1,0,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Azithromycin (single daily dose for 3 d) vs. co-amoxiclav (TID for 10 d) | Time: not specified Place: Switzerland, setting not specified Inclusion:; 1. Age:0.5-10.2 yr; 2. AOM; Exclusion:; 1. Other investigational drug within 4 wk; 2. Antibiotic within 2 wk; 3. Allergic to antibiotic; 4. Malabsorption | Age: 7.5% <2 yr 92.5% >2 yr Otitis prone: Not addressed N=389 total N1=197 azithromycin N2=192 Co-amoxiclav | Clinical response in terms of cured, failed, relapsed at d 12-16 Incidence and severity of side effects
  | Azithromycin | Co-amoxiclav
  Failed at 7-20 d
  .6-10 yr | 6/192 (3%) | 1/189 (0.5%)
  <2 yr | 0/14 (0%) | 0/14 (0%)
  >2 yr | 6/178 (3%) | 1/175 (0.6%)
  Failed or relapse at 7-20 d
  .6-10 yr | 12/192 (6%) | 5/189 (3%)
  <2 yr | 2/14 (14%) | 2/14 (14%)
  Adverse effects, .12-16 d(?)
  Rash | 5/197 (3%) | 7/192 (4%)
  GI | 15/197(8%) | 36/192 (19%)
  General | 6/197(3%) | 1/192 (0.5%)
  Patients | 23/197(12%) | 43/192 (22%)
Simon 1997 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 2 [1,1,0,0,0] Number of components addressed in defining AOM ^2^ (0-3): 1 [1,0,0] | 5 d vs. 10 d Ceftibuten (9mg/kg/d) | Time: Unspecified Place: Kentucky, pediatric private practice Inclusion:; 1. Age: 6 mo-14 yr; 2. AOM; Exclusion:; 1. Allergic to antibiotic | Age: Mean=3.7 yr Otitis prone: Not addressed N=232 total N1=99 5 d N2=133 10 d | Clinical outcomes at d 14 Failure defined as persistent OM at time of evaluation Recurrence defined as complete resolution of symptoms at d 14 but reappearance of OM within the next mo
  | 5 d | 10 d
  Failure, d 14
  | 22/99(22%) | 3/133(2%)
  Recurrence, d 14
  | 14/99(14%) | 11/133(8%)
  Persistence of serous fluid
  | 27/99(27%) | 37/133(28%)
Stickler 1967 | Randomized controlled trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 0 [0,0,0] | Gp1 Penicillin Gp2 Penicillin and antihistamine Gp3 Penicillin and triple sulfonamides Gp4 Penicillin, triple sulfonamidesand antihistamine | Time: unspecified Place: Rochester, MN, pediatric outpatient clinic Inclusion:; 1. Age<15 yr (lower limit not specified); 2. AOM; Exclusion:; 1. History of drug reaction; 2. Concurrent viral exanthem; 3. Chronic OM; 4. History of secretory OM; 5. Febrile child whose crying associated with suffusion of the drum | Age: 45% <2 yr 55% > 2 yr Otitis prone: Not addressed N=514 patients N1=137 N2=122 N3=127 N4=128 | Treatment failure evaluated at 2 wk; Histories recalled for recurrence or complications 2 mo after last subject enrolled Failure defined as signs and symptoms of AOM persisted long enough to require a change in antimicrobial regimen within 2 wk after therapy was initiated
  Gp1 | Gp2 | Gp3 | Gp4
  Treatment failure at 2 wk
  8/137 | 3/122 | 5/127 | 1/128
  6% | 2% | 4% | 0.8%
  Recurrence within 1 mo
  2/137 | 4/122 | 2/127 | 4/128
  1% | 3% | 2% | 3%
  Minimal hearing loss at 2 wk, Age >3 yr
  2/29 | 7/40 | 4/32 | 4/36
  7% | 18% | 12% | 11%
  Marked hearing loss(> 40 db) at 2 wk, age>3 yr
  2/29 | 1/40 | 0/32 | 0/36
  7% | 2% | 0% | 0%
  Mastoiditis or meningitis at 2 wk: none in any group
Varsano 1988 | Randomized double-blind trial Jadad quality score ^1^ (0-5): 4 [1,1,1,0,1] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Single IM dose of ceftriaxone vs. 7 d amoxicillin | Time: Not specified Place: Israel, pediatric emergency walk-in clinic Inclusion:; 1. Age: 6 mo-8 yr; 2. AOM; Exclusion:; 1. AOM in prior mo; 2. Antibiotic within 2 wk; 3. Perforated TM; 4. Cleft lip; 5. Immunodeficient; 6. Allergic to antibiotic | Age: Mean=2 yr Otitis prone: 58% >2 prior episodes 15% <2 prior episodes 27% no prior episodes N=52 total N1=27 ceftriaxone N2=25 amoxicillin | Rate of acute symptom resolution and incidence of recurrence during first month Early failure defined as persistence or recurrence of fever and/or pain, associated with otoscopic signs at first 10 d. Late failure defined similarly at 10-30 d
  | Ceftriaxone | Amoxicillin
  Treatment failure at 1 wk
  | 4/22(18%) | 3/22(14%)
  Recurrence at 1 mo
  | 2/18(11%) | 2/15(13%)
Varsano 1997 | Randomized trial Jadad quality score ^1^ (0-5): 3 [1,0,1,1,0] Number of components addressed in defining AOM ^2^ (0-3): 2 [1,0,1] | Single IM injection of ceftriaxone vs. TID for 10 d of amoxicillin clavulanate | Time: 11/92-4/93 and 11/93-4/94 Place: Israel, pediatric emergency room and primary care clinics Inclusion:; 1. Age: 4 mo-6 yr; 2. AOM; Exclusion:; 1. AOM within 1 mo; 2. Antibiotic within 2 wk; 3. Perforation of TM; 4. PE tubes; 5. Craniofacial abnormality; 6. Immunodeficient; 7. Allergic to antibiotic | Age: Mean=2.7 yr Otitis prone: 13% >3 episodes during preceding 6 mo or >=4 episodes during past 12 mo 87% otherwise N=227 total N1=115 ceftriaxone N2=112 amox/clav | Clinical assessment at 3, 11, 30, 60, and 90 d after initiation of therapy Failure defined as persistence or recurrence of AOM-related symptoms within 11 d of initiation of therapy. Relapse defined as initial resolution of symptoms and their reappearance on d 12-30. Recurrence defined as resolution of symptoms within the first 11 d of onset of treatment and their reappearance on d 31-90.
  | Ceftriaxone Single im | Amox/Clav 10 d
  Failure at 11 d
  5/109(5%) | 5/106(5%)
  Relapses at 12-30 d
  11/104(11%)
  11/101(11%)
  Recurrence at 31-90 d
  11/81(14%) | 25/84(30%)
  Adverse events
  Diarrhea
  3/109(3%) | 17/106(16%)
  Vomit
  1/109(1%)
  12/106(11%)
  Mean otoscopy scores for various time points were compared between the two groups and no significant differences were reported.

1 Jadad score components: randomization mentioned; double-blind mentioned; dropouts described; randomization appropriate; double-blinding appropriate.

2 AOM definition components: middle ear effusion; rapid onset; acute inflammation].

Abbreviations used: AOM=acute otitis media; BID -- twice a day; DZ -- disease; ENT -- ear, nose, and throat; ER -- emergency room; GI -- gastrointestinal; HX -- history; IM -- intramuscular, MEE -- middle ear effusion; OM -- otitis media; PCN -- penicillin; PE -- pressure equalization; PKU -- phenylketonuria; TID -- three times a day; TM -- tympanic membrace; TMP-SMX -- trimethoprim-sulfamethoxazole; RX -- perscription; TX -- treatment; URI -- upper respiratory infection.